# Acknowledgments

We are indebted to the following investigators who provided us additional information or clarification on their clinical trials: Albert P. Aldenkamp; Eduardo Cumbo; Richard M. Dasheiff; Mei Sheng Duh M.D.; Douglas Gillies; Kevin W. Kraushaar; Anthony G. Marson M. D.; Maria Mazurkiewicz-Beldzinska; Mohamad Mikati; K.S. Oldes; Mauri Reunanen; Alan Richens; Victor J. Vadney. We appreciate their willingness to provide us with the information we needed.