# References

1 Chandrasekharan NV, Dai H, Roos KLT, et al. COX-3, a cyclooxygenase-1 variant inhibited by acetaminophen and other analgesic/antipyretic drugs: cloning, structure, and expression.[see comment]. Proc Natl Acad Sci U S A. Oct. 15. 2002;99(21):13926-13931. [pmid: 12242329].
2 Towheed TE, Maxwell L, Anastassiades TP, et al. Impact of musculoskeletal disorders in Canada. Annals of the Royal College of Physicians and Surgeons of Canada. 1998;31(5):229-232.
3 Felson DT, Lawrence RC, Dieppe PA, et al. Osteoarthritis: New insights. Part 1: The disease and its risk factors. Ann Intern Med. 2000;133:635-646. [pmid: 11033593].
4 Oliveria SA, Felson DT, Reed JI, Cirillo PA, Walker AM. Incidence of symptomatic hand, hip, and knee osteoarthritis among patients in a health maintenance organization. Arthritis & Rheumatism. 1995;38:1134-1141. [pmid: 7639811].
5 Felson DT, Zhang Y. An update on the epidemiology of knee and hip osteoarthritis with a view to prevention. Arthritis & Rheumatism. 1998;41(8):1343-1355. [pmid: 9704632].
6 Bandolier. Bandolier extra. Topical analgesics: a review of reviews and a bit of perspective. http://wwwjr2oxacuk/bandolier/Extraforbando/Topextra3pdf. Accessed 16 Dec 2005.
7 Haddox JD, Joranson D, Angarola RT, et al. The use of opioids for the treatment of chronic pain. A consensus statement from the American Academy of Pain Medicine and the American Pain Society. The Clinical Journal of Pain. 1997;13:6-8. [pmid: 9084947].
8 Jovey RD, Ennis J, Garder-Nix J, et al. Use of opioid analgesics for the treatment of chronic noncancer pain--A consensus statement and guidelines from the Canadian Pain Society, 2002. Pain Res Manage. 2003;8(Suppl A):3A-14A.
9 Gotzsche PC. Musculoskeletal disorders. Non-steroidal anti-inflammatory drugs.[update in Clin Evid. 2004 Jun;(11):1551-9; PMID: 15652070][update of Clin Evid. 2002 Dec;(8):1203–11;PMID: 12603936]. Clinical Evidence. Jun. 2003;(9):1292-1300.
10 van Tulder MW, Scholten R, Koes BW, Deyo RA. Non-steroidal anti-inflammatory drugs for low-back pain. Cochrane Database of Systematic Reviews. 2005(3).
11 Tarone RE, Blot WJ, McLaughlin JK. Nonselective nonaspirin nonsteroidal anti-inflammatory drugs and gastrointestinal bleeding: relative and absolute risk estimates from recent epidemiologic studies. Am J Therapeutics. 2004;11:17-25. [pmid: 14704592].
12 Moore R, Phillips C. Cost of NSAID adverse effects to the UK National Health Service. Journal of Medical Economics. 1999;2:45-55.
13 Blower A, Brooks A, Fenn G, Hill A, Pearce M, Morant S. Emergency admissions for upper gastrointestinal disease and their relation to NSAID use. Aliment Pharmacol Ther. 1997;(11):283-291.
14 Bandolier Cox-2 roundup http://wwwjr2oxacuk/bandolier/band75/b75-2html Accessed 16 Dec 2005>
15 Feldman M, McMahon AT. Do cyclooxygenase-2 inhibitors provide benefits similar to those of traditional nonsteroidal anti-inflammatory drugs, with less gastrointestinal toxicity?[erratum appears in Ann Intern Med 2000 Jun 20;132(12):1011]. Annals of Internal Medicine. Jan. 18. 2000;132(2):134-143. [pmid: 10644275].
16 Graham GG, Graham RI, Day RO. Comparative analgesia, cardiovascular and renal effects of celecoxib, rofecoxib and acetaminophen (paracetamol). Curr Pharm Des. 2002;8(12):1063-1075. [pmid: 11945151].
17 Johnson DL, Hisel TM, Phillips BB. Effect of cyclooxygenase-2 inhibitors on blood pressure. Ann Pharmacother. 2003;37:442-446. [pmid: 12639178].
18 Stiller C-O, Hjemdahl P. Endothelial COX-2 inhibition: possible relevance for hypertension and cardiovascular risk?. Journal of Hypertension. 2003;21:1615-1618. [pmid: 12923388].
19 Bombardier C, Laine L, Reicin A, et al. Comparison of upper gastrointestinal toxicity of rofecoxib and naproxen in patients with rheumatoid arthritis. VIGOR Study Group.[see comment]. New England Journal of Medicine. p following 1528, 2000. Nov. 23. 2000;343(21):1520-1528. [pmid: 11087881].
20 FitzGerald GA. Coxibs and cardiovascular disease. New England Journal of Medicine. 2004;351:1709-1711. [pmid: 15470192].
21 Aw T-J, Haas SJ, Liew D, Krum H. Meta-analysis of cyclooxygenase-2 inhibitors and their effects on blood pressure. Arch Intern Med. 2005;165:490-496. [pmid: 15710786].
22 Topol EJ. Failing the public health--rofecoxib, Merck, and the FDA. New England Journal of Medicine. 2004;351:1707-1709. [pmid: 15470193].
23 USFDA. Alert for Healthcare Professionals: Valdecoxib (marketed as Bextra). http://wwwfdagov/cder/drug/InfoSheets/HCP/valdecoxibHCPhtm. Accessed 21 Dec 2005. 2005.
24 Hersh EV, Moore PA, Ross GL. Over-the-counter analgesics and anti-pyretics: a critical assessment. Clinical Therapeutics. 2000;22(5):500-548. [pmid: 10868553].
25 Patrono C. Aspirin as an antiplatelet drug. New England Journal of Medicine. 1994;330(18):1287-1294. [pmid: 8145785].
26 Scheiman JM, Elta GH. Gastroduodenal mucosal damage with salsalate versus aspirin: Results of experimental models and endoscopic studies in humans. Semin Arthritis Rheum. 1990;20(2):121-127. [pmid: 2123561].
27 Crofford LJ. Rational use of analgesic and antiinflammatory drugs. New England Journal of Medicine. 2001;345:1844-1846. [pmid: 11752364].
28 Zhang W, Doherty M, Arden N, et al. EULAR evidence based recommendations for the management of hip osteoarthritis: report of a task force of the EULAR Standing Committee for International Clinical Studies Including Therapeutics (ESCISIT). Ann Rheum Dis. 2005;64:669-681. [pmid: 15471891].
29 Bassleer C, Rovati L, Franchimont P. Stimulation of proteoglycan production by glucosamine sulfate in chondrocytes isolated from human osteoarthritic cartilage in vitro. Osteoarthritis Cartilage. 1998;6:427-434. [pmid: 10343776].
30 Adebowale AO, Cox DS, Liang Z, Eddington ND. Analysis of glucosamine and chondroitin sulfate content in marketed products and the caco-2 permeability of chondroitin sulfate raw materials. Journal of the American Nutraceutical Association. 2000;3(1). Spring issue.
31 Heyneman CA, Lawless-Liday C, Wall GC. Oral versus topical NSAIDs in rheumatic diseases. Drugs. 2000;60(3):555-574. [pmid: 11030467].
32 Mason L, Moore RA, Edwards JE, McQuay HJ, Derry S, Wiffen PJ. Systematic review of efficacy of topical rubefacients containing salicylates for the treatment of acute and chronic pain. BMJ. 2004;(7446):995.
33 Bandolier. Topical analgesics introduction. http://wwwjr2oxacuk/bandolier/booth/painpag/topical/topintrohtml. Accessed 27 Dec 2005.
34 Rains C, Bryson HM. Topical capsaicin. A review of its pharmacological properties and therapeutic potential in post-herpetic neuralgia, diabetic neuropathy and osteoarthritis. Drugs Aging. Oct. 1995;7(4):317-328. [pmid: 8535059].
35 Strand V, Kelman A. Outcome measures in osteoarthritis: randomized controlled trials. Current Rheumatology Reports. 2004;6:20-30. [pmid: 14713399].
36 McConnell S, Kolopack R, Davis AM. The Western Ontario and McMaster Universities Osteoarthritis Index (WOMAC): a review of its utility and measurement properties. Arth Care Res. 2001;45:453-461.
37 Ware JE Jr, Kosinski M, Bayliss MS, McHorney CA, Rogers WH, Raczek A. Comparison of methods for the scoring and statistical analysis of SF-36 health profile and summary measures: summary of results from the Medical Outcomes Study. Medical Care. Apr. 1995;33(4 Suppl):AS264-279. [pmid: 7723455].
38 Pham T, Van Der Heijde D, Lassere M, et al. Outcome variables for osteoarthritis clinical trials: The OMERACT-OARSI set of responder criteria. J Rheumatol. Jul. 2003;30(7):1648-1654. [pmid: 12858473].
39 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. American Journal of Preventive Medicine. Apr. 2001;20(3 Suppl):21-35.
40 Deeks JJ, Dinnes J, D’Amico R, et al. Evaluating non-randomized intervention studies. Health Technol Assess. 2003;7(27):1-192.
41 Towheed TE, Hochberg MC, Shea BJ, Wells G. Analgesia and non-aspirin, non-steroidal anti-inflammatory drugs for osteoarthritis of the hip. Cochrane Database of Systematic Reviews. 2005(3).
42 Watson M, Brookes ST, Faulkner A, Kirwan J. Non-aspirin, non-steroidal anti-inflammatory drugs for treating osteoarthritis of the knee. Cochrane Database of Systematic Reviews. 2005(3).
43 Liang TH, Hsu PN. Double-blind, randomised, comparative trial of etodolac SR versus diclofenac in the treatment of osteoarthritis of the knee. Curr Med Res Opin. 2003;19(4):336-341. [pmid: 12841927].
44 Rogind H, Bliddal H, Klokker D, Jensen F. Comparison of etodolac and piroxicam in patients with osteoarthritis of the hip or knee: A prospective, randomised, double-blind, controlled multicentre study. Clinical Drug Investigation. 1997;13(2):66-75. [pmid: 18370453].
45 Alballa A-AHA-SSA-AAA-SSA Sr. Randomized, double-blind, short-term trial of nabumetone versus diclofenac in osteoarthritis of the knee. Curr Ther Res Clin Exp. 1992;52(4):581-586.
46 Schnitzer TJ, Ballard IM, Constantine G, McDonald P. Double-blind, placebo-controlled comparison of the safety and efficacy of orally administered etodolac and nabumetone in patients with active osteoarthritis of the knee. Clinical Therapeutics. Jul-Aug. 1995;17(4):602-612. [pmid: 8565024].
47 Dequeker J, Hawkey C, Kahan A, et al. Improvement in gastrointestinal tolerability of the selective cyclooxygenase (COX)-2 inhibitor, meloxicam, compared with piroxicam: results of the Safety and Efficacy Large-scale Evaluation of COX-inhibiting Therapies (SELECT) trial in osteoarthritis. Br J Rheumatol. Sep. 1998;37(9):946-951. [pmid: 9783758].
48 Goei The HS, Lund B, Distel MR, Bluhmki E. A double-blind, randomized trial to compare meloxicam 15 mg with diclofenac 100 mg in the treatment of osteoarthritis of the knee. Osteoarthritis Cartilage. Jul. 1997;5(4):283-288. [pmid: 9404473].
49 Hawkey C, Kahan A, Steinbruck K, et al. Gastrointestinal tolerability of meloxicam compared to diclofenac in osteoarthritis patients. International MELISSA Study Group. Meloxicam Large-scale International Study Safety Assessment.[see comment][erratum appears in Br J Rheumatol 1998 Oct;37(10):1142]. Br J Rheumatol. Sep. 1998;37(9):937-945. [pmid: 9783757].
50 Hosie J, Distel M, Bluhmki E. Meloxicam in osteoarthritis: a 6-month, double-blind comparison with diclofenac sodium. Br J Rheumatol. Apr. 1996;35(Suppl 1):39-43. [pmid: 8630635].
51 Hosie J, Distel M, Bluhmki E. Efficacy and tolerability of meloxicam versus piroxicam in patients with osteoarthritis of the hip or knee. A six-month double-blind study. Clinical Drug Investigation. 1997;13(4):175-184.
52 Linden B, Distel M, Bluhmki E. A double-blind study to compare the efficacy and safety of meloxicam 15 mg with piroxicam 20 mg in patients with osteoarthritis of the hip. Br J Rheumatol. Apr. 1996;35(Suppl 1):35-38. [pmid: 8630634].
53 Valat JP, Accardo S, Reginster JY, et al. A comparison of the efficacy and tolerability of meloxicam and diclofenac in the treatment of patients with osteoarthritis of the lumbar spine. Inflamm Res. Mar. 2001;50(Suppl 1):S30-34. [pmid: 11339519].
54 Wojtulewski JA, Schattenkirchner M, Barcelo P, et al. A six-month double-blind trial to compare the efficacy and safety of meloxicam 7.5 mg daily and naproxen 750 mg daily in patients with rheumatoid arthritis. Br J Rheumatol. Apr. 1996;35(Suppl 1):22-28. [pmid: 8630632].
55 Furst D, Hall DB, Roszko J, Leonard JP. Efficacy, safety and dose response of meloxicam up to 22.5 mg in the treatment of rheumatoid arthritis (RA): results of a phase III double-blind, placebo controlled trial. Zeitschrift fur Rheumatologie. 2001;60(Suppl 1):38.
56 Liyanage SP, Tambar PK. Comparative study of salsalate and aspirin in osteoarthrosis of the hip or knee. Curr Med Res Opin. 1978;5(6):450-453. [pmid: 350497].
57 Bensen W, Fiechtner JJ, McMillen JI, et al. Treatment of osteoarthritis with celecoxib, a cyclooxygenase-2 inhibitor: a randomized controlled trial. Mayo Clin Proc. Nov. 1999;74(11):1095-1105. [pmid: 10560596].
58 Goldstein JL, Correa P, Zhao WW, et al. Reduced incidence of gastroduodenal ulcers with celecoxib, a novel cyclooxygenase-2 inhibitor, compared to naproxen in patients with arthritis. The American journal of gastroenterology. Apr. 2001;96(4):1019-1027. [pmid: 11316141].
59 Kivitz AJ, Moskowitz RW, Woods E, et al. Comparative efficacy and safety of celecoxib and naproxen in the treatment of osteoarthritis of the hip. J Int Med Res. Nov-Dec. 2001;29(6):467-479. [pmid: 11803730].
60 Silverstein FE, Faich G, Goldstein JL, et al. Gastrointestinal toxicity with celecoxib vs nonsteroidal anti-inflammatory drugs for osteoarthritis and rheumatoid arthritis: the CLASS study: A randomized controlled trial. Celecoxib Long-term Arthritis Safety Study.[see comment]. JAMA. Sep. 13. 2000;284(10):1247-1255. [pmid: 10979111].
61 Deeks JJ, Smith LA, Bradley MD. Efficacy, tolerability, and upper gastrointestinal safety of celecoxib for treatment of osteoarthritis and rheumatoid arthritis: systematic review of randomised controlled trials.[see comment]. BMJ. Sep. 21. 2002;325(7365):619. [pmid: 12242171].
62 Moore RA, Derry S, Makinson GT, McQuay HJ. Tolerability and adverse events in clinical trials of celecoxib in osteoarthritis and rheumatoid arthritis: systematic review and meta-analysis of information from company clinical trial reports. Arthritis Research & Therapy. 2005;7:R644-R655. [pmid: 15899051].
63 Singh G, et al. Celecoxib versus naproxen and diclofenac in osteoarthritis patients: SUCCESS-I Study. The American Journal of Medicine. 3/06- Public Comment. 2006;119:255-266. [pmid: 16490472].
64 Laine L, Harper S, Simon T. A randomized trial comparing the effect of rofecoxib, a cyclooxygenase 2-specific inhibitor, with that of ibuprofen on the gastroduodenal mucosa of patients with osteoarthritis. Gastroenterology. 1999;117(4):776-783. [pmid: 10500058].
65 Hawkey CJ, Laine L, Simon T. Comparison of the effect of rofecoxib (a cyclooxygenase 2 inhibitor), ibuprofen and placebo on the gastroduodenal mucosa of patients with osteoarthritis: A randomized, double-blind, placebo-controlled trial. Arthritis & Rheumatism. 2000;43(2):370-377. [pmid: 10693877].
66 Saag K, van der Heijde D, Fisher C, et al. Rofecoxib, a new cyclooxygenase 2 inhibitor, shows sustained efficacy, comparable with other nonsteroidal anti-inflammatory drugs: a 6-week and a 1-year trial in patients with osteoarthritis. Osteoarthritis Studies Group. Archives of Family Medicine. Nov–Dec. 2000;9(10):1124-1134. [pmid: 11115219].
67 Day R, Morrison B, Luza A, et al. A randomized trial of the efficacy and tolerability of the COX-2 inhibitor rofecoxib vs ibuprofen in patients with osteoarthritis. Rofecoxib/Ibuprofen Comparator Study Group. Archives of Internal Medicine. Jun. 2000;160(12):1781-1787. [pmid: 10871971].
68 Cannon G, Caldwell J, Holt P. Rofecoxib, a specific inhibitor of cyclooxygenase 2, with clinical efficacy comparable with that of diclofenac sodium: Results of a one-year, randomized, clinical rial in patients with osteoarthritis of the knee and hip. Arthritis & Rheumatism. 2000;43(5):978-987. [pmid: 10817549].
69 Acevedo E, Castaneda O, Ugaz M, et al. Tolerability profiles of rofecoxib (Vioxx) and Arthrotec. A comparison of six weeks treatment in patients with osteoarthritis. Scand J Rheumatol. 2001;30(1):19-24. [pmid: 11252687].
70 Chrubasik S, Kunzel O, Model A. Treatment of low back pain with herbal or synthetic anti-rheumatic: a randomized controlled study. Willow bark extract for low back pain. Br J Rheumatol. 2001;(40):1388-1393. [pmid: 11752510].
71 Truitt K, Sperling R, Ettinger W. A multicenter, randomized, controlled trial to evaluate the safety profile, tolerability and efficacy of rofecoxib in advanced elderly patients with osteoarthritis. Aging Clinical & Experimental Research. 2001;13(2):112-121. [pmid: 11405384].
72 Niccoli L, Bellino S, Cantini F. Renal tolerability of three commonly employed non-steroidal anti-inflammatory drugs in elderly patients with osteoarthritis. Clin Exp Rheumatol. 2002;20(2):201-207. [pmid: 12051399].
73 Myllykangas-Luosujarvi R, Lu H, Chen S. Comparison of low-dose rofecoxib versus 1000 mg naproxen in patients with osteoarthritis. Scand J Rheumatol. 2002;31(6):337-344. [pmid: 12492248].
74 Lisse JR, Perlman M, Johansson G, et al. Gastrointestinal tolerability and effectiveness of rofecoxib versus naproxen in the treatment of osteoarthritis: a randomized, controlled trial.[see comment]. Annals of Internal Medicine. Oct. 7. 2003;139(7):539-546. [pmid: 14530224].
75 Kivitz AJ, Greenwald MW, Cohen SB, et al. Efficacy and safety of rofecoxib 12.5 mg versus nabumetone 1,000 mg in patients with osteoarthritis of the knee: a randomized controlled trial. Journal of the American Geriatrics Society. May. 2004;52(5):666-674. [pmid: 15086644].
76 Geusens PP, Truitt K, Sfikakis P, et al. A placebo and active comparator-controlled trial of rofecoxib for the treatment of rheumatoid arthritis. Scand J Rheumatol. 2002;31(4):230-238. [pmid: 12369656].
77 Garner SE, Fidan DD, Frankish R, Maxwell L. Rofecoxib for osteoarthritis. Cochrane Database of Systematic Reviews. 2005C(1):CD005115.
78 Garner SE, Fidan DD, Frankish RR, et al. Rofecoxib for rheumatoid arthritis.[update of Cochrane Database Syst Rev. 2002;(3):CD003685; PMID: 12137705]. Cochrane Database of Systematic Reviews. 2005b(1):CD003685.
79 Makarowski W, Zhao W, Bevirt T. Efficacy and safety of the COX-2 specific inhibitor valdecoxib in the management of osteo-arthritis of the hip: a randomized, double-blind, placebo-controlled comparison with naproxen. Osteoarthritis Cartilage. 2002(10):290-296.
80 Bensen W, Weaver A, Espinoza L. Efficacy and safety of valdecoxib in treating the signs and symptoms of rheumatoid arthritis: a randomized, controlled comparison with placebo and naproxen. Rheumatology. 2002;41(9):1008-1016. [pmid: 12209034].
81 Kivitz A, Eisen G, Zhao W. Randomized placebo-controlled trial comparing efficacy and safety of valdecoxib with naproxen in patients with osteoarthritis (Comment). Journal of Family Practice. 2002;51(6):530-537. [pmid: 12100776].
82 Sikes DH, Agrawal NM, Zhao WW, Kent JD, Recker DP, Verburg KM. Incidence of gastroduodenal ulcers associated with valdecoxib compared with that of ibuprofen and diclofenac in patients with osteoarthritis. European Journal of Gastroenterology & Hepatology. Oct. 2002;14(10):1101-1111. [pmid: 12362101].
83 Pavelka K, Recker DP, Verburg KM. Valdecoxib is as effective as diclofenac in the management of rheumatoid arthritis with a lower incidence of gastroduodenal ulcers: results of a 26-week trial. Rheumatology. Oct. 2003;42(10):1207-1215. [pmid: 12810937].
84 Whelton A, Fort JG, Puma JA, et al. Cyclooxygenase-2--specific inhibitors and cardiorenal function: a randomized, controlled trial of celecoxib and rofecoxib in older hypertensive osteoarthritis patients.[erratum appears in Am J Ther 2001 May-Jun;8(3):220]. American Journal of Therapeutics. Mar–Apr. 2001;8(2):85-95. [pmid: 11304662].
85 Whelton A, White WB, Bello AE, Puma JA, Fort JG, Investigators S-V. Effects of celecoxib and rofecoxib on blood pressure and edema in patients > or =65 years of age with systemic hypertension and osteoarthritis.[see comment]. American Journal of Cardiology. Nov. 1. 2002;90(9):959-963. [pmid: 12398962].
86 McKenna F, Weaver A, Fiechtner J, Bello A, Fort J. COX-2 specific inhibitors in the management of osteoarthritis of the knee: A placebo-controlled, randomized, double-blind study. JCR: Journal of Clinical Rheumatology. 2001;7(3 SUPPL):151-159.
87 Geba G, Weaver AL, Polis AB, et al. Efficacy of rofecoxib, celecoxib, and acetominophen in osteoarthritis of the knee. Jama. 2002;287(1):64-71. [pmid: 11754710].
88 Bianchi M, Broggini M. A randomised, double-blind, clinical trial comparing the efficacy of nimesulide, celecoxib and rofecoxib in osteoarthritis of the knee. Drugs. 2003;63(1):37-46. [pmid: 14506910].
89 Gibofsky A, Williams GW, McKenna F, Fort JG. Comparing the efficacy of cyclooxygenase 2-specific inhibitors in treating osteoarthritis: appropriate trial design considerations and results of a randomized, placebo-controlled trial.[see comment]. Arthritis & Rheumatism. Nov. 2003;48(11):3102-3111. [pmid: 14613272].
90 Ehrich E, Davies GM, Watson DJ, Bolognese JA, Seidenberg BC, Bellamy N. Minimal perceptible clinical improvement with the Western Ontario and McMaster Universities osteoarthritis index questionnaire and global assessments in patients with osteoarthritis. The Journal of rheumatology. Nov. 2000;27(11):2635-2641. [pmid: 11093446].
91 Laine L, Connors LG, Reicin A, et al. Serious lower gastrointestinal clinical events with nonselective NSAID or coxib use. Gastroenterology. Feb. 2003;124(2):288-292. [pmid: 12557133].
92 Laine L, Bombardier C, Hawkey CJ, et al. Stratifying the risk of NSAID-related upper gastrointestinal clinical events: results of a double-blind outcomes study in patients with rheumatoid arthritis. Gastroenterology. Oct. 2002;123(4):1006-1012. [pmid: 12360461].
93 USFDA. Transcript of the arthritis advisory committee. http://wwwfdagov/ohrms/dockets/ac/01/transcripts/3677t1rtf. Accessed 29 Dec 2005. 2001.
94 Witter J. Celebrex Capsules (Celecoxib) NDA 20-998/S-009 Medical Officer Review. http://www.fda.gov/ohrms/dockets/ac/01/briefing/3677b1_03_med.pdf. Accessed 21 Dec, 2005.
95 Hrachovec JB, Mora M. Reporting of 6-month vs 12-month data in a clinical trial of celecoxib. JAMA. 2001;286(19):2398. [pmid: 11712924].
96 Juni P, Rutjes WS, Dieppe PA. The authors respond. BMJ. 2003;327:141-142.
97 Juni P, Rutjes AWS, Dieppe PA. Are selective COX 2 inhibitors superior to traditional non steroidal anti-inflammatory drugs?. BMJ. 2002;324:1287-1288. [pmid: 12039807].
98 Juni P, Sterchi R, Dieppe P. Systematic review of celecoxib for osteoarthritis and rheumatoid arthritis. Problems compromise review’s validity. BMJ. 2003;326:334. [pmid: 12574052].
99 Scheiman JM. Gastrointestinal outcomes: evidence for risk reduction in patients using coxibs. American Journal of Managed Care. Nov. 2002;8(17 Suppl):S518-528. [pmid: 12458821].
100 Silverstein F, Simon L, Faich G. Reporting of 6-month vs 12-month data in a clinical trial of celecoxib. In reply. JAMA. 2001;286(19):2399-2400.
101 Geis GS. CLASS clarification: reaffirms the medical importance of the analyses and results. BMJ. 2003;327:143-144. [pmid: 12869458].
102 USFDA. Labeling changes for arthritis drug Celebrex. FDA Talk Paper T02-24. 2002. 2005(6 Dec).
103 Curfman GD, Morrissey S, Drazen JM. Expression of concern: Bombardier, et al., “Comparison of upper gastrointestinal toxicity of rofecoxib and naproxen in patients with rheumatoid arthritis,” N Engl J Med 2000;343:1520-8. New England Journal of Medicine. 2005;353(26):2813-2814. [pmid: 16339408].
104 Targum S. Review of cardiovascular safety database - Rofecoxib. FDA Memorandum: Consultation NDA 21-042, S-007. 2001. 2005(21 Dec).
105 White WB, Faich G, Whelton A, et al. Comparison of thromboembolic events in patients treated with celecoxib, a cyclooxygenase-2 specific inhibitor, versus ibuprofen or diclofenac. American Journal of Cardiology. 2002;89:425-430. [pmid: 11835924].
106 Mukherjee D, Nissen S, Topol E. Risk of cardiovascular events associated with selective COX-2 inhibitors. JAMA. 2001;(286):954-959. [pmid: 11509060].
107 Sanmuganathan PS, Ghahramani P, Jackson PR, Wallis EJ, Ramsay LE. Aspirin for primary prevention of coronary heart disease: safety and absolute benefit related to coronary risk derived from meta-analysis of randomised trials. Heart. 2001;85:265-271. [pmid: 11179262].
108 Solomon SD, McMurray JJV, Pfeffer MA, et al. Cardiovascular risk associated with celecoxib in a clinical trial for colorectal adenoma prevention. N Engl J Med. 2005;352:1071-1080. [pmid: 15713944].
109 Solomon SD, Pfeffer MA, McMurray JJV, et al. Effect of celecoxib on cardiovascular events and blood pressure in two trials for the prevention of colorectal adenomas. Circulation. 2006;114:1028-1035. [pmid: 16943394].
110 Arber N, Eagle CJ, Spicak J, et al. Celecoxib for the prevention of colorectal adenomatous polyps. New England Journal of Medicine. 2006;355:885-895. [pmid: 16943401].
111 National Institutes of Health. Use of non-steroidal anti-inflammatory drugs suspended in large Alzheimer’s disease prevention trial. http://wwwnihgov/news/pr/dec2004/od-20htm. Accessed 3 Jan 2006.
112 Pfizer Corp. Celebrex/celecoxib clinical study synopsis. http://www.clinicalstudyresults.org/documents/company-study_76_70.pdfAvailable at. Accessed 17 May, 2006.
113 Wright JM. The double-edged sword of COX-2 selective NSAIDs. CMAJ Canadian Medical Association Journal. 2002;167(10):1131-1137.
114 USFDA. Vioxx gastrointestinal safety. FDA Advisory Committee Briefing Document NDA 21-042, s007. 2001. 2001(8 Feb).
115 Rostom A. Systematic review of the gastrointestinal effects of COX-2 inhibitors 2005:Personal communication, 01 Dec 2005 (slide presentation).
116 Singh G, Goldstein J, Bensen W, et al. Success-1 in Osteoarthritis (OA) Trial: Celecoxib significantly reduces the risk of serious upper GI complications complications compared to NSAIDs while providing similar efficacy in 13,274 randomized patients. EULAR 2001: Prague. 2001.
117 Goldstein JL, Eisen GM, Agrawal N, Stenson WF, Kent JD, Verburg KM. Reduced incidence of upper gastrointestinal ulcer complications with the COX-2 selective inhibitor, valdecoxib. Aliment Pharmacol Ther. Sep. 1. 2004;20(5):527-538. [pmid: 15339324].
118 Langman MJ, Jensen DM, Watson DJ, et al. Adverse upper gastrointestinal effects of rofecoxib compared with NSAIDs.[see comment]. JAMA. Nov. 24. 1999;282(20):1929-1933. [pmid: 10580458].
119 Goldkind L. Medical Officer’s Consult Review, Division of Gastrointestinal and Coagulation Drug Products. http://wwwfdagov/cder/foi/nda/99/021042_52_vioxx_medr_P26pdf. Accessed 30 Dec 2005. 1998.
120 Watson DJ, al E. The upper gastrointestinal safety of rofecoxib vs. NSAIDs: an updated combined analysis. Current Medical Research and Opinion. 3/06 Public Comment. 2004;20:1539-1548. [pmid: 15462687].
121 Goldstein JL. Significant upper gastrointestinal events associated with conventional NSAID versus celecoxib. J Rheumatol Suppl. Oct. 2000;60:25-28. [pmid: 11032099].
122 Konstam MA, Weir MR, Reicin A, et al. Cardiovascular thrombotic events in controlled, clinical trials of rofecoxib.[see comment]. Circulation. Nov. 6. 2001;104(19):2280-2288. [pmid: 11696466].
123 Reicin AS, Shapiro D, Sperling RS, Barr E, Yu Q. Comparison of cardiovascular thrombotic events in patients with osteoarthritis treated with rofecoxib versus nonselective nonsteroidal anti-inflammatory drugs (ibuprofen, diclofenac, and nabumetone).[see comment]. American Journal of Cardiology. Jan. 15. 2002;89(2):204-209. [pmid: 11792343].
124 Juni P, Nartey L, Reichenbach S, Sterchi R, Dieppe PA, Egger M. Risk of cardiovascular events and rofecoxib: cumulative meta-analysis.[see comment]. Lancet. Dec. 4. 2004;364(9450):2021-2029. [pmid: 15582059].
125 Juni P, Reichenbach S, Dieppe PA, Egger M. Discontinuation of Vioxx. Authors’ reply. Lancet. 2005;365:26-27.
126 Kim PS, Reicin AS. Discontinuation of Vioxx. Lancet. 2005;365:23. [pmid: 15639669].
127 Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions 4.2.5 (updated May 2005). Chichester, UK. John Wiley & Sons Ltd. 2005. The Cochrane Library; No. Issue 3.
128 Scolnick E. VIOXX: A Scientific Review.
129 Kearney PM, Baigent C, Godwin J, Halls H, Emberson JR, Patrono C. Do selective cyclo-oxygenase-2 inhibitors and traditional non-steroidal anti-infalmmatory drugs increase the risk of atherothrombosis? Meta-analysis of randomized trials. BMJ. 2006;332:1302-1308. [pmid: 16740558].
130 Reines S, al E. No effect on Alzheimer’s disease in a 1-year, randomized, blinded, controlled study. Neurology. 3/06 Public Comment. 2004;62:66-71. [pmid: 14718699].
131 Thal L, et al. A Randomized, Double-Blind, Study of Rofecoxib in Patients with Mild Cognitive Impairment. Neuropsychopharmacology. 3/06 Public Comment. 2005:30.
132 Bresalier RS, Sandler RS, Quan H, et al. Cardiovascular events associated with rofecoxib in a colorectal adenoma chemoprevention trial. New England Journal of Medicine. 2005;352:1092-1102. [pmid: 15713943].
133 Nissen S. Adverse cardiovacular effects of rofecoxib. New England Journal of Medicine. 2006;355(2):203-204. [pmid: 16801355].
134 White WB, Strand V, Roberts R, Whelton A. Effects of the cyclooxygenase-2 specific inhibitor valdecoxib versus nonsteroidal antiinflammatory agents and placebo on cardiovascular thrombotic events in patients with arthritis. American Journal of Therapeutics. Jul–Aug. 2004;11(4):244-250. [pmid: 15266215].
135 USFDA. Advisory Committee Briefing Document: Celecoxib and Valdecoxib Cardiovascular Safety. http://wwwfdagov/ohrms/dockets/ac/05/briefing/2005-4090B1_03_Pfizer-Celebrex-Bextrapdf. Accessed 21 Dec 2005. 2005.
136 Caldwell B, Aldington S, Weatherall M, Shirtcliffe P, Beasley R. Risk of cardiovascular events and celecoxib: a systematic review and meta-analysis. Journal of the Royal Society of Medicine. 2006;99:132-140. [pmid: 16508052].
137 Schneeweiss S, Avorn J. A review of uses of health care utilization databases for epidemiologic research on therapeutics. Journal of Clinical Epidemiology. 2005;58:323-337. [pmid: 15862718].
138 Hippisley-Cox J, Coupland C, RL. Risk of adverse gastrointestinal outcomes in patients taking cyclo-oxygenase-2 inhibitors or conventional non-steroidal anti-inflammatory drugs: population based nested case-control analysis. BMJ. 2005. [pmid: 16322018].
139 Mamdani M, Rochon PA, Juurlink DN, et al. Observational study of upper gastrointestinal hemorrhage in elderly patients given selective cyclo-oxygenase-2 inhibitors or conventional non-steroidal anti-inflammatory drugs. BMJ. 2002;325:624. [pmid: 12242172].
140 Layton D, Heeley E, Hughes K, Shakir SAW. Comparison of the incidence rates of selected gastrointestinal events reported for patients prescribed rofecoxib and meloxicam in general practice in England using prescription-event monitoring data.[see comment]. Rheumatology. May. 2003;42(5):622-631. [pmid: 12709537].
141 Laporte J-R, Ibanez L, Vidal X, Vendrell L, Leone R. Upper gastrointestinal bleeding associated with the use of NSAIDs: newer versus older agents. Drug Saf. 2004;27(6):411-420. [pmid: 15144234].
142 Kasliwal R, Layton D, Harris S, Wilton L, Shakir SAW. A Comparison of Reported Gastrointestinal and Thromboembolic Events Between Rofecoxib and Celecoxib Using Observational Data. Drug Saf. 2006;28(9):803-816.
143 Levesque LE, Brophy JM, Zhang B. The risk for myocardial infarction with cyclooxygenase-2 inhibitors: a population study of elderly adults.[summary for patients in Ann Intern Med. 2005 Apr 5;142(7):I45; PMID: 15809454]. Annals of Internal Medicine. Apr. 5. 2005;142(7):481-489. [pmid: 15809459].
144 Kimmel SE, Berlin JA, Reilly M, et al. Patients exposed to rofecoxib and celecoxib have different odds of nonfatal myocardial infarction. Ann Intern Med. 2005;142:157-164. [pmid: 15684203].
145 Solomon DH, Schneeweiss S, Glynn RJ, et al. Relationship between selective cyclooxygenase-2 inhibitors and acute myocardial infarction in older adults. Circulation. 2004;109:2068-2073. [pmid: 15096449].
146 Hippisley-Cox J, Coupland C. Risk of myocardial infarction in patients taking cyclo-oxygenase-2 inhibitors or conventional non-steroidal anti-inflammatory drugs: population based nested case-control analysis.[see comment]. BMJ. 2005;330(7504):1366. [pmid: 15947398].
147 Mamdani M, Rochon P, Juurlink DN, et al. Effect of selective cyclooxygenase 2 inhibitors and naproxen on short-term risk of acute myocardial infarction in the elderly. Arch Intern Med. 2003;163:481-486. [pmid: 12588209].
148 Graham DJ. Review of Epidemiologic Studies on Cardiovascular Risk with Selected NSAIDs. http://wwwfdagov/ohrms/dockets/ac/05/slides/2005-4090S2_02_FDA-Graham_files/framehtm. Accessed 5 Jan 2006.
149 Johnsen SP, Larsson H, Tarone RE, et al. Risk of hospitalization for myocardial infarction among users of rofecoxib, celecoxib, and other NSAIDs: a population-based case-control study. Archives of Internal Medicine. May. 9. 2005;165(9):978-984. [pmid: 15883235].
150 Shaya FT, Blume SW, Blanchette CM, Weir MR, Mullins CD. Selective cyclooxygenase-2 inhibition and cardiovascular effects. Arch Intern Med. 2005;165:181-186. [pmid: 15668364].
151 Ray WA, Stein CM, Hall K, Daugherty JR, Griffin MR. Non-steroidal anti-inflammatory drugs and risk of serious coronary heart disease: an observational cohort study.[see comment]. Lancet. Jan. 12. 2002;359(9301):118-123. [pmid: 11809254].
152 Layton D, Heeley E, Hughes K, Shakir SAW. Comparison of the incidence rates of thromboembolic events reported for patients prescribed rofecoxib and meloxicam in general practice in England using prescription-event monitoring (PEM) data. Rheumatology. 2003;42:1342-1353. [pmid: 12832706].
153 Velentgas P, West W, Cannuscio CC, Watson DJ, Walker AM. Cardiovascular risk of selective cycloxygenase-2 inhibitors and other non-aspirin non-steroidal anti-inflammatory medications. Pharmacoepidemiol Drug Saf. 2005. In Press.
154 Harrison-Woolrych M, et al. Incidence of thrombotic cardiovascular events in patients taking celecoxib compared with those taking rofecoxib. Drug Safety 2005; 28: 435–42. Drug Saf. 3/06 Public Comment. 2005;28:435-442. [pmid: 15853444].
155 Andersohn F, Suissa S, Garbe E. Use of First- and Second-Generation Cyclooxygenase-2-Selective Nonsteroidal Antiinflammatory Drugs and Risk of Acute Myocardial Infarction. Circulation. April. 25. 2006;113(16):1950-1957. [pmid: 16618816].
156 Kiyota Y, Schneeweiss S, Glynn RJ, Cannuscio CC, Avorn J, Soloomon DH. Accuracy of Medicare claims-based diagnosis of acute myocardial infarction: estimating positive predictive value on the basis of review of hospital records. Am Heart J. 2004;148:99-104. [pmid: 15215798].
157 Jollis JG, Ancukiewicz M, DeLong ER, Pryor DB, Muhlbaier LH, Mark DB. Discordance of databases designed for claims payment versus clinical information systems. Ann Intern Med. 1993;119:844-850. [pmid: 8018127].
158 Schneeweiss S, Glynn RJ, Tsai EH, Avorn J, Solomon DH. Adjusting for unmeasured confounders in pharmacoepidemiologic claims data using external information. Epidemiology. 2004;16(1):17-24.
159 Solomon DH. Selective cyclooxygenase 2 inhibitors and cardiovascular events. Arthritis & Rheumatism. 2005;52(7):1968-1978. [pmid: 15986365].
160 Graham DJ, Campen D, Hui R, et al. Risk of acute myocardial infarction and sudden cardiac death in patients treated with cyclo-oxygnease 2 selective and non-selective non-steroidal anti-inflammatory drugs: nested case-control study. Lancet. 2005;365:475-481. [pmid: 15705456].
161 Ray WA, Stein C, JR D, Hall K, Arbogast P, MR G. COX-2 selective non-steroidal anti-inflammatory drugs and risk of serious coronary heart disease. Lancet. 2002;360(9339):1071-1073. [pmid: 12383990].
162 Layton D, Hughes K, Harris S, Shakir SAW. Comparison of the incidence rates of selected gastrointestinal events reported for patients prescribed celecoxib and meloxicam in general practice in England using prescription-event monitoring (PEM) data. Rheumatology. Nov. 2003;42(11):1332-1341. [pmid: 12810929].
163 Mamdani M, Juurlink DN, Lee DS, et al. Cyclo-oxygenase-2 inhibitors versus non-selective non-steroidal anti-inflammatory drugs and congestive heart failure outcomes in elderly patients: a population-based cohort study. Lancet. 2004;363:1751-1756. [pmid: 15172772].
164 Eisen GM, Goldstein JL, Hanna DB, Rublee DA. Meta-analysis: upper gastrointestinal tolerability of valdecoxib, a cyclooxygenase-2-specific inhibitor, compared with nonspecific nonsteroidal anti-inflammatory drugs among patients with osteoarthritis and rheumatoid arthritis. Aliment Pharmacol Ther. Mar. 1. 2005;21(5):591-598. [pmid: 15740543].
165 Ott E, Nussmeier NA, Duke PC, et al. Efficacy and safety of the cyclooxygenase 2 inhibitors parecoxib and valdecoxib in patients undergoing coronary artery bypass surgery. J Thorac Cardiovasc Surg. 2003;125:1481-1492. [pmid: 12830070].
166 Nussmaier NA, Whelton AA, Brown MT, et al. Complications of the COX-2 inhibitors parecoxib and valdecoxib after cardiac surgery. N Engl J Med. 2005;352(11):1081-1091. [pmid: 15713945].
167 Furberg CD, Psaty BM, FitzGerald GA. Parecoxib, valdecoxib, and cardiovascular risk. Circulation. 2005;111:249. [pmid: 15655125].
168 Goldkind L. FDA warning letter to Pharmacia Corporation. http://wwwfdagov/cder/foi/appletter/2002/21341slr002ltrpdf. 2002.
169 Mockenhaupt M, Kelly JP, Kaufman D, Stern RS. The risk of Stevens-Johnson syndrome and toxic epidermal necrolysis associated with nonsteroidal antiinflammatory drugs: a multinational perspective. J Rheumatol. 2003;30:2234-2240. [pmid: 14528522].
170 Ramey D, Watson DJ, Yu C, Bolognese J, Curtis S, Reicin A. The incidence of upper gastrointestinal adverse events in clinical trials of etoricoxib vs non-selecting NSAIDS: an updated combined analysis. Curr Med Res Opin. 2005;21(5):715-722. [pmid: 15974563].
171 Hunt RH, Harper S, Watson DJ, et al. The gastrointestinal safety of the COX-2 selective inhibitor etoricoxib assessed by both endoscopy and analysis of upper gastrointestinal events. Am J Gastroenterol. Aug. 2003;98(8):1725-1733. [pmid: 12907325].
172 van der Heijde D, Baraf HSB, Ramos-Remus C, et al. Evaluation of the efficacy of etoricoxib in ankylosing spondylitis: results of a fifty-two-week, randomized, controlled study. Arthritis & Rheumatism. Apr. 2005;52(4):1205-1215. [pmid: 15818702].
173 Aldington S, Shirtcliffe P, Weatherall M, Beasley R. Systematic review and meta-analysis of the risk of major cardiovascular events with etoricoxib therapy. N Z Med J. Oct. 7. 2005;118(1223):U1684. [pmid: 16224508].
174 Curtis SP, Mukhopadhyay S, Ramey DR, Reicin A. Cardiovascular safety summary associated with etoricoxib development program (abstract). Arthritis & Rheumatism. 2005:S616.
175 Schnitzer TJ, Burmester GR, Mysler E, et al. Comparison of lumiracoxib with naproxen and ibuprofen in the Therapeutic Arthritis Research and Gastrointestinal Event Trial (TARGET), reduction in ulcer complications: randomised controlled trial.[see comment]. Lancet. Aug. 21. 2004;364(9435):665-674. [pmid: 15325831].
176 Hawkey CJ, Farkouh M, Gitton X, Ehrsam E, Huels J, Richardson P. Therapeutic arthritis research and gastrointestinal event trial of lumiracoxib - study design and patient demographics. Aliment Pharmacol Ther. Jul. 1. 2004;20(1):51-63. [pmid: 15225171].
177 Farkouh ME, Kirshner H, Harrington RA, et al. Comparison of lumiracoxib with naproxen and ibuprofen in the Therapeutic Arthritis Research and Gastrointestinal Event Trial (TARGET), cardiovascular outcomes: randomised controlled trial. Lancet. Aug. 2004;364(9435):675-684. [pmid: 15325832].
178 Furst D, Kolba KS, Fleischmann R, et al. Dose response and safety study of meloxicam up to 22.5 mg daily in rheumatoid arthritis: a 12 week multicenter, double blind, dose response study versus placebo and diclofenac. The Journal of Rheumatology. Mar. 2002;29(3):436-446. [pmid: 11908554].
179 Degner F, Sigmund R, Zeidler H. Efficacy and tolerability of meloxicam in an observational, controlled cohort study in patients with rheumatic disease. Clinical Therapeutics. 2000;22(4):400-410. [pmid: 10823362].
180 Mann J, Evans T. Gastrointestinal-related complications in a long-term care population taking NSAIDs versus COX-2 inhibitor therapy. Consultant Pharmacist. 2004;19(7):602-612. [pmid: 16553490].
181 Schoenfeld P. Gastrointestinal safety profile of meloxicam: a meta-analysis and systematic review of randomized controlled trials. Am J Med. Dec. 13. 1999;107(6A):48S-54S. [pmid: 10628593].
182 Jick SS. The risk of gastrointestinal bleed, myocardial infarction, and newly diagnosed hypertension in users of meloxicam, diclofenac, naproxen, and piroxicam. Pharmacotherapy. 2000;20(7):741-744. [pmid: 10907963].
183 Richy F, Bruyere O, Ethgen O, et al. Time dependent risk of gastrointestinal complications induced by non-steroidal anti-inflammatory drug use: a consensus statement using a meta-analytic approach. Annals of the Rheumatic Diseases. 2004;63(7):759-766. [pmid: 15194568].
184 Garcia Rodriguez LA, Hernandez-Diaz S. Relative risk of upper gastrointestinal complications among users of acetaminophen and nonsteroidal anti-inflammatory drugs. Epidemiology. 2001;12:570-576. [pmid: 11505178].
185 Garcia Rodriguez LA, Varas-Lorenzo C, Maguire A, Gonzalez-Perez A. Nonsteroidal antiinflammatory drugs and the risk of myocardial infarction in the general population. Circulation. 2004;109:3000-3006. [pmid: 15197149].
186 Singh G, Lanes S, Triadafilopoulos G. Risk of serious upper gastrointestinal and cardiovascular thromboembolic complications with meloxicam. Am J Med. Jul. 15. 2004;117(2):100-106. [pmid: 15234645].
187 Fleischmann RM. Clinical efficacy and safety of nabumetone in rheumatoid arthritis and osteoarthritis. J Rheumatol Suppl. Nov. 1992;36:32-40. [pmid: 1474533].
188 Weideman RA, Kelly KC, Kazi S, et al. Risks of clinically significant upper gastrointestinal events with etodolac and naproxen: a historical cohort analysis. Gastroenterology. 2004;127(5):1322-1328. [pmid: 15521001].
189 Garcia Rodriguez LA, Hernandez-Diaz S, de Abajo FJ. Association between aspirin and upper gastrointestinal complications: systematic review of epidemiologic studies. Br J Clin Pharmacol. 2001;52:563-571. [pmid: 11736865].
190 Henry D, Lim LL, Garcia Rodriguez LA, et al. Variability in risk of gastrointestinal complications with individual non-steroidal anti-inflammatory drugs: results of a collaborative meta-analysis.[see comment]. BMJ. Jun. 22. 1996;312(7046):1563-1566. [pmid: 8664664].
191 Hernandez-Diaz S, Garcia Rodriguez LA. Association between nonsteroidal anti-inflammatory drugs and upper gastrointestinal tract bleeding/perforation. An overview of epidemiologi studies published in the 1990s. Arch Intern Med. 2000;160:2093-2099. [pmid: 10904451].
192 Song F, Altman DG, Glenny AM, Deeks JJ. Validity of indirect comparisons for estimatingn efficacy of competing interventions: empirical evidence from published meta-analyses. BMJ. 2003;326:472. doi:410.410.1136/bmj.1326.7387.1472. [pmid: 12609941].
193 Rahme E, Pilote L, LeLorier J. Association between naproxen use and protection against acute myocardial infarction.[see comment][erratum appears in Arch Intern Med 2002 Sep 9;162(16):1858]. Archives of Internal Medicine. May. 27. 2002;162(10):1111-1115. [pmid: 12020180].
194 Kimmel SE, Berlin JA, Reilly M, et al. The effects of nonselective non-aspirin non-steroidal anti-inflammatory medications on the risk of nonfatal myocardial infarction and their interaction with aspirin. Journal of the American College of Cardiology. 2004;43(6):985-990. [pmid: 15028354].
195 Watson DJ, Rhodes T, Cai B, Guess HA. Lower risk of thromboembolis cardiovascular events with naproxen among patients with rheumatoid arthritis. Arch Intern Med. 2002;162:1105-1110. [pmid: 12020179].
196 Solomon DH, Glynn RJ, Levin R, Avorn J. Nonsteroidal anti-inflammatory drug use and acute myocardial infarction. Arch Intern Med. 2002;162:1099-1104. [pmid: 12020178].
197 Schlienger R, et al. Use of nonsteroidal anti-inflammatory drugs and the risk of first-time acute myocardial infarction. British Journal of Clinical Pharmacology. 3/06 Public Comment. 2002;54:327-332. [pmid: 12236854].
198 USFDA. FDA Public Health Advisory. FDA Announces Important Changes and Additional Warnings for COX-2 Selective and Non-Selective Non-Steroidal Anti-Inflammatory Drugs (NSAIDs). http://wwwfdagov/cder/drug/advisory/COX2htm. Accessed 5 Jan 2006. 2005.
199 Antithrombotic Trialists’ Collaboration. Collaborative meta-analysis of randomised trials of antiplatelet therapy for prevention of death, myocardial infarction, and stroke in high risk patients. BMJ. 2002;324:71-86. [pmid: 11786451].
200 Derry S, Loke YK. Risk of gastointestinal haemorrhage with long term use of aspirin: meta-analysis. BMJ. 2000;321:1183-1187. [pmid: 11073508].
201 Singh G, Terry R, Ramey D, et al. Comparative GI Toxicity of NSAIDs. American College of Rheumatology. 1/6/05. 1997;40(Suppl 9):S115.
202 Serebruany VL, Steinhubl SR, Berger PB, et al. Analysis of risk of bleeding complications after different doses of aspirin in 192,036 patients enrolled in 31 randomized controlled trials. Am J Cardiol. 2005;95:1218-1222. [pmid: 15877994].
203 Ashworth NL, Peloso PM, Muhajarine N, Stang M. A population based historical cohort study of the mortality associated with nabumetone, Arthrotec, diclofenac, and naproxen. J Rheumatol. May. 2004;31(5):951-956. [pmid: 15124256].
204 Johnson AG, Nguyen TV, Day RO. Do nonsteroidal anti-inflammatory drugs affect blood pressure? A meta-analysis. Ann Intern Med. 1994;121:289-300. [pmid: 8037411].
205 Pope JE, Anderson JJ, Felson DT. A meta-analysis of the effects of nonsteroidal anti-inflammatory drugs on blood pressure. Arch Intern Med. 1993;153:477-484. [pmid: 8435027].
206 Gertz BJ, Krupa D, Bolognese JA, Sperling RS, Reicin A. A comparison of adverse renovascular experiences among osteoarthritis patients treated with rofecoxib and comparator non-selective non-steroidal anti-inflammatory agents. Curr Med Res Opin. 2002;18(2):82-91. [pmid: 12017215].
207 Sowers JR, White WB, Pitt B, et al. The effects of cyclooxygenase-2 inhibitors and nonsteroidal anti-inflammatory therapy on 24-hour blood pressure in patients with hypertension, osteoarthritis, and type 2 diabetes mellitus.[see comment][erratum appears in Arch Intern Med. 2005 Mar 14;165(5):551]. Archives of Internal Medicine. Jan. 24. 2005;165(2):161-168. [pmid: 15668361].
208 Sandhu GK, Heyneman CA. Nephrotoxic potential of selective cyclooxygenase-2 inhibitors. Ann Pharmacother. 2004;38(4):700-704. [pmid: 14982980].
209 Whelton A, Maurath CJ, Verburg KM, Geis GS. Renal safety and tolerability of celecoxib, a novel cyclooxygenase-2 inhibitor.[see comment][erratum appears in Am J Ther 2000 Sep;7(5):341]. American Journal of Therapeutics. May. 2000;7(3):159-175. [pmid: 11317165].
210 Solomon DH, Schneeweiss S, Levin R, Avorn J. Relationship between COX-2 specific inhibitors and hypertension. Hypertension. 2004;44:140-145. [pmid: 15226279].
211 Hudson M, Richard H, Pilote L. Differences in outcomes of patients with congestive heart failure prescribed celecoxib, rofecoxib, or non-steroidal anti-inflammatory drugs: population based study. BMJ. 2005;330:1370. [pmid: 15947399].
212 Garcia Rodriguez LA, Hernandez-Diaz S. Nonsteroidal antiinflammatory drugs as a trigger of clinical heart failure. Epidemiology. 2003;14:240-246. [pmid: 12606892].
213 Rostom A, Goldkind L, Laine L. Nonsteroidal anti-inflammatory drugs and hepatic toxicity: a systematic review of randomized controlled trials in arthritis patients. Clin Gastroenterol Hepatol. May. 2005;3(5):489-498. [pmid: 15880319].
214 Rubenstein JH, Laine L. Systematic review: the hepatotoxicity of non-steroidal anti-inflammatory drugs. Aliment Pharm Ther. 2004;20:373-380.
215 Traversa G, Bianchi C, Da Cas R, Abranha I, Menniti-Ippolito F, Venegoni M. Cohort study of hepatotoxicity associated with nimesulide and other non-steroidal anti-inflammatory drugs. BMJ. 2003;327:18-22. [pmid: 12842950].
216 Walker AM. Quantitative studies of the risk of serious hepatic injury in persons using nonsteroidal antiinflammatory drugs. Arthritis & Rheumatism. 1997;40(2):201-208. [pmid: 9041931].
217 Furst D, Blocka K, Cassell S, et al. A controlled study of concurrent therapy with a nonacetylated salicylate and naproxen in rheumatoid arthritis. Arthritis & Rheumatism. Feb. 1987;30(2):146-154. [pmid: 3548732].
218 Kolodny AL. Two double blind trials of diclofenac sodium with aspirin and with naproxen in the treatment of patients with rheumatoid arthritis. The Journal of rheumatology. Aug. 1988;15(8):1205-1211. [pmid: 3054094].
219 Deodhar SD, McLeod MM, Dick WC, Buchanan WW. A short-term comparative trial of salsalate and indomethacin in rheumatoid arthritis. Curr Med Res Opin. 1977;5(2):185-188. [pmid: 340137].
220 Bombardier C, Peloso PM, Goldsmith CH. Salsalate, a nonacetylated salicylate, is as efficacious as diclofenac in patients with rheumatoid arthritis. Salsalate-Diclofenac Study Group. J Rheumatol. Apr. 1995;22(4):617-624. [pmid: 7791151].
221 Montrone F, Caruso I, Cazzola M. Salsalate in the treatment of rheumatoid arthritis: a double-blind clinical and gastroscopic trial versus piroxicam. I. Clinical trial. J Int Med Res. Jul-Aug. 1989;17(4):316-319. [pmid: 2676647].
222 Fries JF, Williams C, Bloch D. The Relative Toxicity of Nonsteroidal Antiinflammatory Drugs. Arthritis & Rheumatism. 1/6/06. 1991;34(11). [pmid: 1953813].
223 Fries JF. Toward an Understanding of NSAID-Related Adverse Events: The Contribution of Longitudinal Data. Scand J Rheuamtol. 1/6/06. 1996;25(Suppl 102):3-8.
224 Fries JF, Ramey DR, Singh G, Morfeld D, Bloch DA, Raynauld JP. A reevaluation of aspirin therapy in rheumatoid arthritis. Archives of Internal Medicine. Nov. 8. 1993;153(21):2465-2471. [pmid: 8215751].
225 Garner S, Fidan D, Frankish R, et al. Celecoxib for rheumatoid arthritis. Cochrane Database of Systematic Reviews. 2005A(3).
226 Watson DJ, Harper SE, Zhao PL, Quan H, Bolognese JA, Simon TJ. Gastrointestinal tolerability of the selective cyclooxygenase-2 (COX-2) inhibitor rofecoxib compared with nonselective COX-1 and COX-2 inhibitors in osteoarthritis. Archives of Internal Medicine. Oct. 23. 2000;160(19):2998-3003. [pmid: 11041909].
227 Edwards JE, McQuay HJ, Moore RA. Efficacy and safety of valdecoxib for treatment of osteoarthritis and rheumatoid arthritis: systematic review of randomised controlled trials. Pain. Oct. 2004;111(3):286-296. [pmid: 15363872].
228 Lee C, Straus WL, Balshaw R, Barlas S, Vogel S, Schnitzer TJ. A comparison of the efficacy and safety of nonsteroidal antiinflammatory agents versus acetaminophen in the treatment of osteoarthritis: a meta-analysis. Arthritis & Rheumatism. Oct. 15. 2004;51(5):746-754. [pmid: 15478167].
229 Towheed TE, Judd MG, Hochberg MC, Wells G. Acetaminophen for osteoarthritis. Cochrane Database of Systematic Reviews. 2005;(3).
230 Wegman A, van der Windt D, van Tulder M, Stalman W, de Vries T. Nonsteroidal antiinflammatory drugs or acetaminophen for osteoarthritis of the hip or knee? A systematic review of evidence and guidelines.[see comment]. J Rheumatol. Feb. 2004;31(2):344-354. [pmid: 14760807].
231 Zhang W, Jones A, Doherty M. Does paracetamol (acetaminophen) reduce the pain of osteoarthritis? A meta-analysis of randomised controlled trials.[see comment]. Annals of the Rheumatic Diseases. Aug. 2004;63(8):901-907. [pmid: 15020311].
232 Boureau F, Schneid H, Zeghari N, Wall R, Bourgeois P. The IPSO study: ibuprofen, paracetamol study in osteoarthritis. A randomised comparative clinical study comparing the efficacy and safety of ibuprofen and paracetamol analgesic treatment of osteoarthritis of the knee or hip. Annals of the Rheumatic Diseases. Sep. 2004;63(9):1028-1034. [pmid: 15308513].
233 Pincus T, Koch G, Lei H, et al. Patient preference for Placebo, Acetaminophen (paracetamol) or Celecoxib Efficacy Studies (PACES): two randomised, double blind, placebo controlled, crossover clinical trials in patients with knee or hip osteoarthritis.[see comment]. Annals of the Rheumatic Diseases. Aug. 2004;63(8):931-939. [pmid: 15082468].
234 Garcia Rodriguez LA, Hernandez-Diaz S. Risk of uncomplicated peptic ulcer among users of aspirin and nonaspirin nonsteroidal antiinflammatory drugs. American Journal of Epidemiology. 2004;159(1):23-31. [pmid: 14693656].
235 Rahme E, Pettitt D, LeLorier J. Determinants and sequelae associated with utilization of acetaminophen versus traditional nonsteroidal antiinflammatory drugs in an elderly population. Arthritis & Rheumatism. 2002;46(11):3046-3054. [pmid: 12428249].
236 Lewis SC, Langman MJS, Laporte J-R, Matthews JNS, Rawlins MD, Wiholm B-E. Dose-response relationships between individual nonaspirin nonsteroidal anti-inflammatory drugs (NANSAIDs) and serious upper gastrointestinal bleeding: a meta-analysis based on individual patient data. British Journal of Clinical Pharmacology. Sep. 2002;54(3):320-326. [pmid: 12236853].
237 Chan AT, Manson JE, Albert CM, et al. Nonsteroidal antiinflammatory drugs, acetaminophen, and the risk of cardiovascular events. Circulation. 2006;113:1578-1587. [pmid: 16534006].
238 McLaughlin JK, Lipworth L, Chow W-H, Blot WJ. Analgesic use and chronic renal failure: a critical review of the epidemiologic literature. Kidney International. 1998;54:679-686. [pmid: 9734593].
239 Fored CM, Ejerblad E, Lindblad P, et al. Acetaminophen, aspirin, and chronic renal failure. New England Journal of Medicine. 2001;345:1801-1808. [pmid: 11752356].
240 Curhan GC, Knight EL, Rosner B, Hankinson SE, Stampfer MJ. Lifetime nonnarcotic analgesic use and decline in renal function in women. Arch Intern Med. 2004;164:1519-1524. [pmid: 15277282].
241 Kurth T, Glynn RJ, Walker AM, et al. Analgesic use and change in kidney function in apparently healthy men. American Journal of Kidney Diseases. 2003;42(2):234-244. [pmid: 12900803].
242 Rexrode KM, Buring JE, Glynn RJ, Stampfer MJ, Youngman LD, Gaziano JM. Analgesic use and renal function in men. JAMA. 2001;286:315-321. [pmid: 11466097].
243 Forman JP, Stampfer MJ, Curhan GC. Non-narcotic analgesic dose and risk of incident hypertension in US women. Hypertension. 2005;46:500-507. [pmid: 16103274].
244 Dedier J, Stampfer MJ, Hankinson SE, Willett WC, Speizer FE, Curhan GC. Nonnarcotic analgesic use and the risk of hypertension in US women. Hypertension. 2002;40:604-608. [pmid: 12411450].
245 Curhan GC, Willett WC, Rosner B, Stampfer MJ. Frequency of analgesic use and risk of hypertension in younger women. Arch Intern Med. 2002;162:2204-2208. [pmid: 12390063].
246 Kurth T, Hennekens CH, Sturmer T, et al. Analgesic use and risk of subsequent hypertension in apparently healthy men. Arch Intern Med. 2005;165:1903-1909. [pmid: 16157836].
247 McAlindon TE. Why are clinical trials of glucosamine no longer uniformly positive?. Rheum Dis Clin N Am. 2003;29:789-801.
248 Towheed TE, Maxwell L, Anastassiades TP, et al. Glucosamine therapy for treating osteoarthritis. Cochrane Database of Systematic Reviews. 2005(3).
249 Lopes Vaz A. Double-blind clinical evaluation of the relative efficacy of ibuprofen and glucosamine sulphate in the management of osteoarthrosis of the knee in out-patients. Curr Med Res Opin. 1982;8(3):145-149. [pmid: 7128187].
250 Rovati L. The clinical profile of glucosamine sulfate as a selective symptom modifying drug in osteoarthritis: current data and prospectives. Osteoarthritis Cartilage. 1997;(5):72.
251 Muller-Fassbender H, Bach GL, Haase W, Rovati LC, Setnikar I. Glucosamine sulfate compared to ibuprofen in osteoarthritis of the knee. Osteoarthritis Cartilage. Mar. 1994;2(1):61-69. [pmid: 11548225].
252 Qiu GX, Gao SN, Giacovelli G, Rovati L, Setnikar I. Efficacy and safety of glucosamine sulfate versus ibuprofen in patients with knee osteoarthritis. Arzneimittelforschung. May. 1998;48(5):469-474. [pmid: 9638313].
253 Nowlan C, Wetmore S. Short report: ibuprofen versus glucosamine sulfate. Treating osteoarthritis pain. Canadian Family Physician Medecin de famille canadien. 2003;49(4):1632. [pmid: 14708929].
254 Thie NM, Prasad NG, Major PW. Evaluation of glucosamine sulfate compared to ibuprofen for the treatment of temporomandibular joint osteoarthritis: a randomized double blind controlled 3 month clinical trial. J Rheumatol. Jun. 2001;28(6):1347-1355. [pmid: 11409130].
255 McAlindon TE, LaValley MP, Gulin JP, Felson DT. Glucosamine and chondroitin for treatment of osteoarthritis. A systematic quality assessment and meta-analysis. JAMA. 2000;283:1469-1475. [pmid: 10732937].
256 Richy F, Bruyere O, Ethgen O, Cucherat M, Henrotin Y, Reginster J-Y. Structural and symptomatic efficacy of glucosamine and chondroitin in knee osteoarthritis: a comprehensive meta-analysis.[see comment]. Archives of Internal Medicine. Jul. 14. 2003;163(13):1514-1522. [pmid: 12860572].
257 Poolsup N, Suthisisang C, Channark P, Kittkiulsuth W. Glucosamine long-term treatment and the progression of knee osteoarthritis: systematic review of randomized controlled trials. Ann Pharmacother. 2005;39:1080-1087. [pmid: 15855241].
258 Leeb BF, Schweitzer H, Montag K, Smolen JS. A metaanalysis of chondroitin sulfate in the treatment of osteoarthritis. J Rheumatol. 2000;27:205-211. [pmid: 10648040].
259 Clegg D, al E. Glucosamine, Chondroitin Sulfate and the Two in Combination for Painful Knee Osteoarthritis. NEJM. 2006;354(8):795-808. [pmid: 16495392].
260 Clegg DO, Reda DJ, Harris CL, Klein MA. The efficacy of glucosamine and chondroitin sulfate in patients with painful knee osteoarthritis (OA): the Glucosamine/chondroitin Arthritis Intervention Trial (GAIT). Paper presented at: American College of Rheumatology Annual Scientific Meeting. November 12-17, 2005. 2005. San Diego, CA.
261 Levesque LE, Brody JM, Zhang B. Time variations in the risk of mycardial infarction among elderly users of COX-2 inhibitors. CMAJ Canadian Medical Association Journal. 2006;174(11). online 1-8.
262 Layton D, Riley J, Wilton LV, Shakir SAW. Safety profile of rofecoxib as used in general practice in England: results of a prescription-event monitoring study. British Journal of Clinical Pharmacology. Feb. 2003;55(2):166-174. [pmid: 12580988].
263 Levin B. Celecoxib in adnoma prevention--the PreSAP trial. Slide presentation at: meeting of the FDA Advisory Committee on COX-2 inhibitors and NSAIDS. February. 16-18. 2005. Gaithersburg, MD. Available at: http://www.fda.gov/ohrms/dockets/ac/05/slides/2005-4090s1_09_FDA-Levin.ppt. 2005.
264 Emery P, Kong SX, Ehrich EW, Watson DJ, Towheed TE. Dose-effect relationships of nonsteroidal anti-inflammatory drugs: a literature review. Clinical Therapeutics. 2002;24(8).
265 Fries JF, Bruce B. Rates of serious gastrointestinal events from low dose use of acetylsalicylic acid, acetaminophen, and ibuprofen in patients with osteoarthritis and rheumatoid arthritis. J Rheumatol. 2003;30:2226-2233. [pmid: 14528521].
266 Lisse J, Espinoza L, Zhao SZ, Dedhiya SD, Osterhaus JT. Functional status and health-related quality of life of elderly osteoarthritic patients treated with celecoxib. The Journals of Gerontology Series A, Biological Sciences and Medical Sciences. Mar. 2001;56(3):M167-175.
267 Detora L, Krupa D, Bolognese J, Sperling R, Ehrich E. Rofecoxib shows consistent efficacy in osteoarthritis clinical trials, regardless of specific patient demographic and disease factors. The Journal of Rheumatology. 2001;28(11):2494-2503. [pmid: 11708424].
268 Izhar M, Alausa T, Folker A, Hung E, Bakris GL. Effects of COX inhibition on blood pressure and kidney function in ACE inhibitor-treated blacks and hispanics. Hypertension. Mar. 2004;43(3):573-577. [pmid: 14744921].
269 Fredy J, Diggins DA, Morrill GB. Blood pressure in Native Americans switched from celecoxib to rofecoxib. Ann Pharmacother. 2005;39:797-802. [pmid: 15797981].
270 Chan F, Hung L, Suen B, Wu J, Lee K, Leung V. Celecoxib versus diclofenac and omeprazole in reducing the risk of recurrent ulcer bleeding in patients with arthritis. N Engl J Med. 2002;347(26):2104-2110. [pmid: 12501222].
271 Lai KC, Lam SK, Chu KM, et al. Celecoxib compared with lansoprazole and naproxen to prevent gastrointestinal ulcer complications. Am J Med. 2005;118:1271-1278. [pmid: 16271912].
272 Norgard B, Pedersen L, Johnsen SP, et al. COX-2-selective inhibitors and the risk of upper gastrointestinal bleeding in high-risk patients with previous gastrointestinal diseases: a population-based case-control study. Aliment Pharmacol Ther. 2004;19:817-825. [pmid: 15043523].
273 Solomon DH, Avorn J, Sturmer T, Glynn RJ, Mogun H, Schneeweiss S. Cardiovascular outcomes in new users of coxibs and nonsteroidal antiinflammatory drugs: high-risk subgroups and time course of risk. Arthritis & Rheumatism. 2006;54(5):1378-1389. [pmid: 16645966].
274 Gislason GH, Jacobsen S, Rasmussen JN, et al. Risk of death or reinfarction associated with the use of selective cyclooxygenase-2 inhibitors and nonselective nonsteroidal antiinflammatory drugs after acute myocardial infarction. Circulation. 2006;113:2906-2913. [pmid: 16785336].
275 Knijff-Dutmer EAJ, Schut GA, van de Laar MAFJ. Concomitant coumarin-NSAID therapy and risk for bleeding. Ann Pharmacother. Jan. 2003;37(1):12-16. [pmid: 12503926].
276 Schorr RI, Ray WA, Daugherty JR, Griffin MR. Concurrent use of nonsteroidal anti-inflammatory drugs and oral anticoagulants places elderly persons at high risk for hemorrhagic peptic ulcer disease. Arch Intern Med. 1993;153:1665-1670. [pmid: 8333804].
277 Battistella M, Mamdami MM, Juurlink DN, Rabeneck L, Laupacis A. Risk of upper gastrointestinal hemorrhage in warfarin users treated with nonselective NSAIDs or COX-2 inhibitors. Arch Intern Med. 2005;165:189-192. [pmid: 15668365].
278 Knijff-Dutmer EAJ, Van der Palen J, Schut G, Van de Laar MAFJ. The influence of cyclo-oxygenase specificity of non-steroidal anti-inflammatory drugs on bleeding complications in concomitant coumarine users. QJM. Jul. 2003;96(7):513-520. [pmid: 12881594].
279 Schaefer MG, Plowman BK, Morreale AP, Egan M. Interaction of rofecoxib and celecoxib with warfarin. American Journal of Health-System Pharmacy. Jul. 1. 2003;60(13):1319-1323. [pmid: 12901032].
280 Merck & Co. Inc. Vioxx(R) product label (approved 26 March 2004). http://www.fda.gov/cder/foi/label/2004/21647_vioxx_lbl.pdfAvailable at. Accessed 17 May, 2006.
281 Larson RJ, Fisher ES. Should aspirin be continued in patients started on warfarin? A systematic review and meta-analysis. J Gen Intern Med. 2004;19:879-886. [pmid: 15242475].
282 Rothberg MB, Celestin C, Fiore LD, Lawler E, Cook JR. Warfarin plus aspirin after myocardial infarction or the acute coronary syndrome: meta-analysis with estimates of risk and benefit. Ann Intern Med. 2005;143:241-250. [pmid: 16103468].
283 Mahe I, Bertrand N, Drouet L, et al. Paracetamol: a haemorrhagic risk factor in patients on warfarin. Br J Clin Pharmacol. 2004;59(3):371-374. [pmid: 15752384].
284 Hylek EM, Heiman H, Skates SJ, Sheehan MA, Singer DE. Acetaminophen and other risk factors for excessive warfarin anticoagulation. JAMA. 1998;279:657-662. [pmid: 9496982].
285 Mahe I, Caulin C, Bergmann J-F. Does paracetamol potentiate the effects of oral anticoagulants. Drug Saf. 2004;27(5):325-333. [pmid: 15061686].
286 Metcalfe S, Dougherty S, McNee W. Celecoxib’s relative gastrointestinal safety is overstated. BMJ. 2003;326:334-335. [pmid: 12575714].
287 Deeks JJ, Smith LA, Bradley MD. Authors’ reply. BMJ. 2003;326:335-336.
288 Laine L, Maller ES, Yu C, Quan H, Simon T. Ulcer formation with low-dose enteric-coated aspirin and the effect of COX-2 selective inhibition: a double-blind trial. Gastroenterology. Aug. 2004;127(2):395-402. [pmid: 15300570].
289 Goldstein JL, Bello AE, Spalding W, Suh S, Fort JG. Cyclooxygenase-2 specific inhibitors and upper gastrointestinal tolerability in patients with osteoarthritis receiving concomitant low dose aspirin: pooled analysis of 2 trials. J Rheumatol. 2005;32:111-117. [pmid: 15630735].
290 MacDonald TM, Wei L. Effect of ibuprofen on cardioprotective effect of aspirin. Lancet. 2003;361:573-574. [pmid: 12598144].
291 Rostom A, Dube C, Wells G, et al. Prevention of NSAID-induced gastroduodenal ulcers. Cochrane Database of Systematic Reviews. 2005(3).
292 Rostom A, Dube C, Jolicoeur E, Boucher M, Joyce J. Gastroduodenal ulcers associated with the use of non-steriodal anti-inflammatory drugs: a systematic review of preventative pharmacological interventions. Canadian Coordinating Office for Health Technology Assessment, Technology Overview no 12. 2004.
293 Hooper L, Brown TJ, Elliott R, Payne K, Roberts C, Symmons D. The effectiveness of five strategies for the prevention of gastrointestinal toxicity induced by non-steroidal anti-inflammatory drugs: systematic review. BMJ. Oct. 23. 2004;329(7472):948. [pmid: 15475342].
294 Agrawal N, Roth S, Graham D, et al. Misoprostol compared with sucralfate in the prevention of nonsteroidal anti-inflammatory drug-induced gastric ulcer. A randomized, controlled trial. Annals of Internal Medicine. Aug. 1991;115(3):195-200. [pmid: 1905501].
295 Agrawal N, Van Kerckhove HE, Erhardt LJ, Geis GS. Misoprostol coadministered with diclofenac for prevention of gastroduodenal ulcers. A one-year study. Digestive Diseases and Sciences. May. 1995;40(5):1125-1131. [pmid: 7729275].
296 Bocanegra T, Weaver AL, Tindall EA, et al. Diclofenac/misoprostol compared with diclofenac in the treatment of osteoarthritis of the knee or hip: a randomized, placebo controlled trial. Arthrotec Osteoarthritis Study Group. The Journal of rheumatology. Aug. 1998;25(8):1602-1611. [pmid: 9712107].
297 Bolten W, Gomes JA, Stead H, Geis GS. The gastroduodenal safety and efficacy of the fixed combination of diclofenac and misoprostol in the treatment of osteoarthritis. Br J Rheumatol. Nov. 1992;31(11):753-758. [pmid: 1450797].
298 Chan F, Sung J, Ching J, et al. Randomized trial of low dose misoprostol and naproxen vs nambumetone to prevent recurrent upper gastrointestinal hemorrhage in users on non-steroidal anti-inflammatory drugs. Aliment Pharm Ther. 2001(15).
299 Chandrasekaran A, Sambandam P, Lal H, et al. Double blind, placebo controlled trial on the cytoprotective effect of misoprostol in subjects with rheumatoid arthritis, osteoarthritits and seronegative sp ondarthropathy on NSAIDs (see comments). Journal of the Association of Physicians of India. 1991(39).
300 Cohen de Lara A, Gompel H. Two comparative studies of Dosmalfate vs Misoprostol in the prevention of NSAID-induced gastric ulcers in rheumatic patients. Drugs Today (Barc). 2000;(36).
301 Delmas P, Lambert R, Capron MH. Misoprostol for preventing gastric erosions induced by nonsteroidal antiinflammatory drugs in patients with rheumatic diseases. Rev Rhum Engl Ed. 1994;61(2):115-120.
302 Dieppe P, Bartlett C, Davey P, Doyal L, Ebrahim S. Balancing benefits and harms: the example of non-steroidal anti-inflammatory drugs. BMJ. 2004;(329):31-34. [pmid: 15231619].
303 Elliott S, Yeomans ND, Buchanan RRC, Smallwood RA. Efficacy of 12 months’ misoprostol as prophylaxis against NSAID- induced gastric ulcers. Scand J Rheumatol. 1994;23(4):171-176. [pmid: 8091141].
304 Geis GS. Overall safety of Arthrotec. Scandinavian journal of rheumatology Supplement. 1992;96:33-36. [pmid: 1439622].
305 Geis GS. Efficacy and upper GI safety of diclofenac/misoprostol, piroxicam and naproxen in patients with osteoarthritis. Drugs. 1993;45(Suppl 1):15. discussion 15-16. [pmid: 7685683].
306 Graham DY, Agrawal NM, Campbell DR, et al. Ulcer prevention in long-term users of nonsteroidal anti-inflammatory drugs: results of a double-blind, randomized, multicenter, active- and placebo-controlled study of misoprostol vs lansoprazole. Archives of Internal Medicine. 2002;162(2):169-175. [pmid: 11802750].
307 Graham D, Agrawal NM, Roth SH. Prevention of NSAID-induced gastric ulcer with misoprostol: multicentre, double-blind, placebo-controlled trial. Lancet. Dec. 1988;2(8623):1277-1280. [pmid: 2904006].
308 Hannequin JR. Efficacy of Arthrotec in the treatment of rheumatoid arthritis. Scandinavian journal of rheumatology Supplement. 1992;96:7-14. [pmid: 1439627].
309 Hawkey CJ, Karrasch J, Szczepanski L, et al. Omeprazole compared with misoprostol for ulers associated with nonsteroidal antiinflammatory drugs. N Engl J Med. 1998(338). [pmid: 9494149].
310 Henriksson K, Uribe A, Sandstedt B, Nord C. Helicobacter pylori infection, ABO blood group and effect of misoprostol on gastroduodenal mucosa in NSAID-treated patients with rheumatoid arthritis. Digestive Diseases & Sciences. 1993;(38).
311 Jensen D, Ho S, Hamamah S, et al. A randomized study of omeprazole compared to misoprostol for prevention of recurrent ulcers and ulcer hemorrhage in high risk patients ingesting aspirin or NSAIDs. Gastroenterology. 2000;118(4 Suppl 2 Pt 1):A892.
312 McKenna F. Diclofenac/misoprostol: the European clinical experience. J Rheumatol Suppl. May. 1998;51:21-30. [pmid: 9596551].
313 Melo Gomes JA, Roth SH, Zeeh J, Bruyn GA, Woods EM, Geis GS. Double-blind comparison of efficacy and gastroduodenal safety of diclofenac/misoprostol, piroxicam, and naproxen in the treatment of osteoarthritis. Annals of the Rheumatic Diseases. Dec. 1993;52(12):881-885. [pmid: 8311540].
314 Raskin J, White R, jackson J, et al. Misoprostol dosage in the prevention of nonsteroidal anti-inflammatory drug-induced gastric and duodenal ulcers: A comparison of three regimens. Ann Intern Med. 1995(123).
315 Roth S, Tindall EA, Jain AK, et al. A controlled study comparing the effects of nabumetone, ibuprofen, and ibuprofen plus misoprostol on the upper gastrointestinal tract mucosa. Archives of Internal Medicine. Nov. 1993;153(22):2565-2571. [pmid: 8239849].
316 Saggioro A, Alvisi V, Blasi A, Dobrilla G, Fioravanti A, Marcolongo R. Misoprostol prevents NSAID-induced gastrodudenal lesions in patients with osteoarthritis and rheumatoid arthrittis (published erratum appears in Ital J Gastroenterol 1991 Jun:23(5):273). Italian Journal of Gastroenterology. 1991(23).
317 Silverstein F, Graham D, Senior J, et al. Misoprostol reduces gastrointestinal complications in patients with rheumatoid arthritis receiving nonsteroidal anti-inflammatory drugs: A randomized, double-blind, placebo-controlled trial. Ann Intern Med. 1995(123).
318 Verdickt W, Moran C, Hantzschel H, Fraga A, Stead H, Geis G. A double-blind comparison of the gastroduodenal safety and efficacy of diclofenac and a fixed dose combination of diclofenac and misoprostol in the treatment of rheumatoid arthritis. Scand J Rheumatol. 1992;21(2):85-91. [pmid: 1570496].
319 Yeomans N, Tulassay Z, Juhasz L, Racz I, Howard J. A comparison of omeprazole with ranitidine for ulcers associated with nonsteroidal anti-inflammatory drugs. N Engl J Med. 1998(338).
320 Raskin J, White R, Jaszewski R, Korsten M, Schubert T, Fort J. Misoprostol and rantidine in the prevention of NSAID-induced ulcers: a prospective, double-blind, multicenter study. Am J Gastroenterol. 1996(91). [pmid: 8607484].
321 Valentini M, Cannizzaro R, Poletti M, et al. Nonsteroidal antinflammatory drugs for cancer pain: comparison between misoprostol and ranitidine in prevention of upper gastrointestinal damage. Journal of Clinical Oncology. 1995(13). [pmid: 7595718].
322 Berkowitz J, Rogenes P, Sharp J, Warner C. Ranitidine protects against gastroduodenal mucosal damage associated with chronic aspirin therapy. Archives of Internal Medicine. 1987(147).
323 Ehsanullah R, Page MC, Tildesley G, Wood JR. Prevention of gastroduodenal damage induced by non-steroidal anti-inflammatory drugs: controlled trial of ranitidine. BMJ (Clinical research ed). Oct. 1988;297(6655):1017-1021. [pmid: 3142593].
324 Taha As, Hudson N, Hawkey CJ, et al. Famotidine for the prevention of gastric and duodenal ulcers caused by nonsteroidal antiinflammatory drugs. The New England Journal of Medicine. May. 1996;334(22):1435-1439. [pmid: 8618582].
325 Hudson N, Taha A, Russell R, Trye P, Cottrell, Mann S. Famotidine for healing and maintenance in nonsteroidal anti-inflammatory drug-associated gastroduodeanl ulceration. Gastroenterology. 1997;112(6):1817-1822. [pmid: 9178671].
326 Levine L, Cloud M, Enas N. Nizatidine prevents peptic ulceration in high-risk patients taking nonsteroidal anti-inflammatory drugs (see comments). 1993;(153).
327 Robinson M, Griffin J, Bowers J. Effect of ranitidine on gastroduodenal mucosal damage induced by non-steroidal anti-inflammatory drug therapy. Dig Dis Sci. 1989(34).
328 Robinson M, Mills R, Euler A. Ranitidine prevents duodenal ulcers associated with non-steroidal anti-inflammatory drug therapy. Aliment Pharm Ther. 1991;5(2):143-150.
329 Swift G, Heneghan M, Williams G, Williams B, O’Sullivan M, Rhodes J. Effect of rantidine on gastroduodenal mucosal damage in patients on long-term non-steriodal anti-inflammatory drugs. Digestion. 1989(44).
330 Van Groenendael J, Markusse H, Dijkmans B, Breedveld F. The effect of ranitidine on NSAID related dyspeptic symptoms with and without peptic ulcer disease of patients with rheumatoid arthritis and osteoarthritis. Clin Rheumatol. 1996(15).
331 Spiegel BMR, Farid M, Dulai GS, Gralnek IM, Kanwal F. Comparing rates of dyspepsia with coxibx vs NSAID+PPI: a meta-analysis. Am J Med. 2006;119:448.e427-e436. [pmid: 16651060].
332 Lin Y, Zhang W, Jones A, Doherty M. Efficacy of topical non-steroidal anti-inflammatory drugs in the treatment of osteoarthritis: meta-analysis of randomised controlled trials. BMJ. 2004;(239).
333 Mason L, Moore RA, Edwards JE, Derry S, McQuay HJ. Topical NSAIDs for chronic musculoskeletal pain: systematic review and meta-analysis. BMC Musculoskelet Disord. 2004;5(28).
334 Dickson DJ. A double-blind evaluation of topical piroxicam gel with oral ibuprofen in osteoarthritis of the knee. Curr Ther Res Clin Exp. 1991;49(2):199-207.
335 Sandelin J, Harilainen A, Crone H, Hamberg P, Forsskahl B, Tamelander G. Local NSAID gel (eltenac) in the treatment of osteoarthritis of the knee. A double blind study comparing eltenac with oral diclofenac and placebo gel. Scand J Rheumatol. 1997;26(4):287-292. [pmid: 9310109].
336 Zacher J, Burger KJ, Farber L, Grave M, Abberger H, Bertsch K. Topical diclofenac versus oral ibuprofen: A double blind, randomized clinical trial to demonstrate efficacy and tolerability in patients with activated osteoarthritis of the finger joints (Heberden and/or Bouchard arthritis). Aktuelle Rheumatologie. 2001;26(1):7-14.
337 Moore RA, Tramer MR, Carroll D, Wiffen PJ, McQuay HJ. Quantitative systematic review of topically applied non-steroidal anti-inflammatory drugs.[see comment][erratum appears in BMJ 1998 Apr 4;316(7137):1059]. BMJ. Jan. 31. 1998;316(7128):333-338. [pmid: 9487165].
338 Tugwell PS, Wells GA, Shainhouse JZ. Equivalence study of a topical diclofenac solution (pennsaid) compared with oral diclofenac in symptomatic treatment of osteoarthritis of the knee: a randomized controlled trial.[see comment]. J Rheumatol. Oct. 2004;31(10):2002-2012. [pmid: 15468367].
339 Balthazar-Letawe D. Voltaren Emulgel en pratique rhumatologique. Essai comparatif avec Indocid gel. [Voltaren Emugel in clinical rheumatology. Comparative trial with Indocid gel]. Acta Belg Med Phys. 1987;10:109-110. [pmid: 2961174].
340 Burgos A, Busquier M, Reino Jea. Double-blind, double-dummy comparative study of local action transcutaneous flurbiprofen versus piketoprofen cream in the treatment of extrarticular rheumatism. Clin Drug Invest. 2001;21:95-102.
341 Waikakul S, Penkitt iP, Soparat K, Boonsanong W. Topical analgesics for knee arthrosis: a parallel study of ketoprofen gel and diclofenac emulgel. Journal of the Medical Association of Thailand = Chotmaihet thangphaet. Sep. 1997;80(9):593-597. [pmid: 9347673].
342 Baer PA, Thomas LM, Shainhouse Z. Treatment of osteoarthritis of the knee with a topical diclofenac solution: a randomised controlled, 6-week trial [ISRCTN53366886]. BMC Musculoskelet Disord. 2005;6:44. [pmid: 16086839].
343 Bookman AAM, Williams KSA, Shainhouse JZ. Effect of a topical diclofenac solution for relieving symptoms of primary osteoarthritis of the knee: a randomized controlled trial. CMAJ: Canadian Medical Association journal = journal de l’Association medicale canadienne. Aug. 2004;171(4):333-338.
344 Roth SH, Shainhouse JZ. Efficacy and safety of a topical diclofenac solution (pennsaid) in the treatment of primary osteoarthritis of the knee: a randomized, double-blind, vehicle-controlled clinical trial.[see comment]. Archives of Internal Medicine. Oct. 11. 2004;164(18):2017-2023. [pmid: 15477437].
345 Trnavsky K, Fischer M, Vogtle-Junkert U, Schreyger F. Efficacy and safety of 5% ibuprofen cream treatment in knee osteoarthritis. Results of a randomized, double-blind, placebo-controlled study. J Rheumatol. Mar. 2004;31(3):565-572. [pmid: 14994406].
346 Cross PL, Ashby D, Harding G, et al. TOIB Study. Are topical or oral ibuprofen equally effective for the treatment of chronic knee pain presenting in primary care: a randomised controlled trial with patient preference study. ISRCTN79353052. BMC Musculoskelet Disord. 2005;6:55. [pmid: 16274477].
347 Towheed TE. Pennsaid therapy for osteoarthritis of the knee: a systematic review and metaanalysis of randomized controlled trials. J Rheumatol. 2006;33:567-573. [pmid: 16511925].
348 Evans JM, McMahon AD, McGilchrist MM, et al. Topical non-steroidal anti-inflammatory drugs and admission to hospital for upper gastrointestinal bleeding and perforation: a record linkage case-control study. BMJ. 1995;311(6996):22-26. [pmid: 7613317].
349 Evans JM, McGregor E, McMahon AD, et al. Non-steroidal anti-inflammatory drugs and hospitalization for acute renal failure. QJM. 1995;(88):551-557. [pmid: 7648241].
350 Mason L, Moore RA, Derry S, Edwards JE, McQuay HJ. Systematic review of topical capsaicin for the treatment of chronic pain. BMJ. 2004;328:991. [pmid: 15033881].
351 Zhang WY, Li Wan Po A. The effectiveness of topically applied capsaicin. A meta-analysis. Eur J Clin Pharmacol. 1994;46(6):517-522. [pmid: 7995318].