# Acknowledgments

We would like to acknowledge with appreciation the members of the Technical Expert Panel for their advice and consultation. In addition, we would also like to acknowledge Eric Johnson, Ph.D., for reviewing this manuscript.

Technical Expert Panel

- Vibeke Strand, M.D.
- Adjunct Clinical Professor
- Division of Immunology, Stanford University
- Portola Valley, CA
- Expertise: Rheumatology

- Kenneth Saag, M.D., M.Sc.
- UAB Center for Education and Research on Therapeutics (CERTs) of Musculoskeletal Disorders
- Birmingham, AL
- Expertise: Rheumatology

- Leslie J. Crofford, M.D.
- UK Hospital, University of Kentucky
- Lexington, KY
- Expertise: Rheumatology

- Michel Boucher, B.Pharm., M.Sc.
- Canadian Coordinating Office for Health Technology Assessment
- Ottawa, Ontario
- Expertise: Pharmacology

- Lara Maxwell
- Coordinator, Cochrane Musculoskeletal Group
- Institute of Population Health
- University of Ottawa
- Ottawa, Ontario
- Expertise: Rheumatology

AHRQ Contacts

- Beth A. Collins Sharp, Ph.D., R.N.
- Director
- Evidence-based Practice Center Program
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- Rockville, MD

- Carmen Kelly, Pharm.D., R.Ph.
- Task Order Officer
- Evidence-based Practice Center Program
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- Rockville, MD