# Addendum

As this report was going to press, two relevant meta-analyses on risks associated with NSAIDs were published. We were unable to fully incorporate these studies into our report, but their results generally appear consistent with our conclusions.

One meta-analysis evaluated risk of renal events (peripheral edema, hypertension, or renal dysfunction) and arrhythmias from 114 randomized trials of COX-2 selective NSAIDs [Zhang J, Ding EL, Song Y. Adverse effects of cyclooxygenase 2 inhibitors on renal and arrhythmia events. Meta-analysis of randomized trials. JAMA. 2006;296:(doi:10.1001/jama.296.13.jrv6001)]. It was rated fair-quality because it did not assess the quality of included studies. It found rofecoxib associated with increased risks of arrhythmia relative to control (placebo, other NSAID, or mixed/other) treatments (RR 2.90, 95% CI 1.07 to 7.88), though the number and rate of events was low (13/10126 or 0.1% in the rofecoxib arms, with 10 of the events ventricular fibrillation, cardiac arrest, or sudden cardiac death). The increase in risk was equivalent to about 1.1 additional arrhythmia events per 1000 patients treated with rofecoxib. Rofecoxib was also associated with an increased risk of peripheral edema (RR 1.43, 95% CI 1.23 to 1.66), hypertension (RR 1.55, 95% CI 1.29 to 1.85) and renal dysfunction (RR 2.31, 95% CI 1.05 to 5.07). For composite renal events (peripheral edema, hypertension, or renal dysfunction), risks were significantly higher with increased dose and increased duration of rofecoxib. Celecoxib was associated with lower risks of renal dysfunction (RR 0.61, 95% CI 0.40 to 0.94) and hypertension (RR 0.83, 95% CI 0.71 to 0.97) than control treatments, though there was no difference for composite renal events (RR 0.97, 95% CI 0.84 to 1.12) or arrhythmia (RR 0.84, 95% CI 0.45 to 1.57). There was no clear association between other COX-2 inhibitors (valdecoxib/parecoxib, etoricoxib, or lumiracoxib) and arrhythmia or renal events, though there was a trend towards increased renal events with valdecoxib/parecoxib (RR 1.24, 95% CI 1.00 to 1.55), and no arrhythmia events were reported in six trials of lumiracoxib.

Several factors complicate interpretation of estimates of arrhythmia risk from this meta-analysis. First, the rate of arrhythmias varied widely between control arms for different COX-2 selective inhibitors. For example, the rate of arrhythmias was fourteen-fold higher in the control arms of the celecoxib trials compared to the control arms of the rofecoxib trials (18/6568 or 0.3% vs. 2/10,126 or 0.01%). In addition, the proportion of specific arrhythmia events varied widely between drugs. For valdecoxib, over half (69/129 or 53%) of the arrhythmia events were atrial fibrillation, compared to 14% (3/22) for celecoxib and 8% (1/13) for rofecoxib. Finally, even though funnel plots and statistical tests did not suggest the presence of publication bias, only a minority of trials reported usable data on arrhythmia events. For example, only 10 of 37 included trials of celecoxib (accounting for about one-third of trial participants) had data that could be used in the analysis of arrhythmia events.

The second meta-analysis evaluated cardiovascular risk (primarily myocardial infarction) associated with NSAIDs from 23 observational studies (mostly of older populations) [McGettigan P, Henry D. Cardiovascular risk and inhibition of cyclooxygenase. A systematic review of the observational studies of selective and nonselective inhibitors of cyclooxygenase 2. JAMA. 2006;296:(doi:10.1001/jama.292.13.jrv60011)]. Its results are largely consistent with our qualitative assessment of cardiovascular risk from the observational literature. This meta-analysis appears to meet criteria for a good-quality systematic review, but its interpretation is complicated by the presence of substantial (p<=0.001), unexplained between-study heterogeneity for the main pooled analyses. It found rofecoxib associated with an increased risk of cardiovascular events at both lower (25 mg/day or less, RR 1.33, 95% CI 1.00 to 1.79) and higher (>25 mg/day, RR 2.19, 95% CI 1.64 to 2.91) doses, with the increased risk observable during the first month of treatment. Of the other NSAIDs, diclofenac (RR 1.40, 95% CI 1.16 to 1.70) was associated with the greatest cardiovascular risk, followed by indomethacin (RR 1.30, 95% CI 1.07 to 1.60) and meloxicam (RR 1.25, 95% CI 1.00 to 1.55). Celecoxib (RR 1.06, 95% CI 0.91 to 1.23), naproxen (RR 0.97, 95% CI 0.87 to 1.07), piroxicam (RR 1.06, 95% CI 0.70 to 1.59), and ibuprofen (RR 1.07, 95% CI 0.97 to 1.18) were not associated with increased risks. Only 3 of the 23 included studies reported adjusting for over-the-counter aspirin or NSAID use; two other studies included patients shortly after myocardial infarction that were all prescribed or presumed to be on aspirin.