# Summary and Discussion

The table below summarizes the strength of evidence and results for each key question. Publication bias is an issue for all of these questions, because we do not know the complete details or results of unpublished trials submitted to the FDA or trials that have been conducted but not published or submitted to the FDA

Table 34

Summary of findings with strength of evidence

Key Question | Level of Evidence | Conclusion
1a. What are the comparative benefits and harms of treating osteoarthritis with oral medications or supplements?
Efficacy: Non-selective NSAID vs. non-selective NSAID | Non-selective NSAID vs. non- selective NSAID: good. Consistent evidence from several good-quality systematic reviews and published trials. Salsalate vs. aspirin. Poor. One short-term trial. Salsalate or aspirin vs. non- aspirin NSAIDs. Poor. | No difference in efficacy between various non- aspirin, non-selective NSAIDs or partially selective NSAIDs (meloxicam, nabumetone, etodolac). No difference between salsalate and aspirin in one short-term trial. There were no trials or eligible observational studies of salsalate or aspirin vs. non-aspirin NSAIDs.
Efficacy: COX-2 selective vs. non-selective NSAID | Good. Consistent evidence from many published trials | No difference.
Efficacy: COX-2 selective vs. COX-2 selective | Good. Consistent evidence from six published trials. | No clinically significant differences at comparable doses.
GI and CV safety: Rofecoxib | Good. One large published trial, multiple meta-analyses and systematic reviews of published and unpublished trials, multiple observational studies. | In a pivotal, long-term trial (VIGOR) of patients with rheumatoid arthritis, rofecoxib 50 mg daily reduced symptomatic ulcers and serious ulcer complications compared with naproxen. After an average of 9 months, rofecoxib use was associated with 1 fewer symptomatic ulcer for every 62 patients treated; one fewer serious GI complication for every 191; and one additional MI for every 333 patients. The overall rate of serious adverse events, however, was higher with rofecoxib than naproxen. Higher-quality systematic reviews and observational studies are generally consistent with these findings (about 3.5 additional myocardial infarctions for every 1000 patients treated for one year). One long- term placebo-controlled polyp prevention trial also found an increased risk of MI.
GI and CV safety: Celecoxib | Fair: Multiple meta-analyses and systematic reviews of mostly short-term published and unpublished trials, multiple observational studies. | In the only published large, long-term study (CLASS), celecoxib was no better than diclofenac or ibuprofen for complicated or symptomatic ulcers at the end of follow-up. In subgroup analyses of patients not on aspirin, celecoxib was superior to ibuprofen but not to diclofenac for ulcer complications. There was no increase in the rate of cardiovascular events for celecoxib in CLASS. The overall rate of serious adverse events was similar with celecoxib compared to ibuprofen and diclofenac. Systematic reviews and other meta-analyses of primarily short-term, unpublished data and lower doses found celecoxib superior to non-selective NSAIDs for ulcer complications. Observational studies are generally consistent with the short-term trials. However, recent meta-analyses found an increased risk of myocardial infarction with celecoxib compared with placebo (about 3.5 myocardial infarction for every 1000 patients treated for one year), with much of the evidence for increased risk coming from two large polyp prevention trials.
GI and CV safety: Valdecoxib | Fair: Fair quality meta-analyses of published and unpublished trials | Compared to non-selective NSAIDs, valdecoxib was associated with one fewer upper GI complication with valdecoxib for every 78 patients treated for 3 to 6 months. There was no association between valdecoxib and myocardial infarction in primarily short- term chronic pain trials. However, two short- term trials in a high-risk post-coronary artery surgery setting found that valdecoxib was associated with an acute two- to three-fold higher risk of cardiovascular events compared with placebo.
GI and CV safety: Etoricoxib | Fair: Several fair quality meta-analyses of published and unpublished trials | GI safety: Etoricoxib was associated with fewer perforations, symptomatic ulcers, and bleeds than diclofenac, ibuprofen, and naproxen (rate/100 patient-years 1.00 vs. 2.47). CV safety: Based on limited data from short- term trials, etoricoxib has a cardiovascular safety profile similar to non-selective NSAIDs, with the possible exception of naproxen.
GI and CV safety: Lumiracoxib | Fair: One large, long-term trial | GI safety: In patients not taking low-dose aspirin, lumiracoxib was associated with a lower risk of ulcer complications compared to naproxen and ibuprofen (1-year incidence 0.25% vs. 1.09%, p<0.0001). CV safety: There were no differences in the risk of serious CV events (rates ranged from 0.11% to 0.38% after 1 year).
GI and CV safety: Partially selective NSAIDs | GI safety: Fair for meloxicam (short-term RCTs, meta- analyses, observational studies); poor for nabumetone and etodolac CV safety: Poor for all; two observational studies for meloxicam | GI safety: Meloxicam and non-selective NSAIDs were generally associated with similar risks of serious GI events; evidence was insufficient to make reliable judgments about GI safety of nabumetone and etodolac CV safety: Very sparse evidence that meloxicam and non-selective NSAIDs were associated with similar risks of serious CV events; no evidence for nabumetone and etodolac
GI and CV safety: Non- selective NSAIDs | Good for GI safety. Consistent evidence from many published trials, systematic reviews, and observational studies Fair for CV safety. No large, long-term controlled trials. Almost all evidence from observational studies | No clear difference in GI safety between non- selective NSAIDs at commonly used doses. Naproxen was associated with a modest cardiovascular protective effect compared to other NSAIDs in a good-quality systematic review of observational studies, but methodological issues could have affected the results. Comparative CV safety of other non-aspirin NSAIDs is not clear. A large systematic review of RCTs addressing this issue has not yet been published.
GI and CV safety: Aspirin | Fair. Many trials and systematic reviews, but almost exclusively in patients receiving aspirin at doses used for cardiovascular prophylaxis. | Aspirin is associated with a lower risk of thromboembolic events and a higher risk of GI bleeds when given in prophylactic doses. There is insufficient evidence to assess safety of aspirin in doses used for pain control compared with non-aspirin NSAIDs.
GI and CV safety: Salsalate | Poor. Flawed observational data | Salsalate was associated with a lower risk of adverse events using broad composite endpoints in older, poor-quality observational studies. In a more recent observational study, salsalate had a similar rate of complications compared with other NSAIDs. Almost no data is available on CV safety.
Mortality | Fair. Individual trials not large enough to detect differences in mortality. One meta-analysis of celecoxib using unpublished information, and one fair-quality observational study of non- selective NSAIDs. | No difference between celecoxib and non- selective NSAIDs, but few deaths occurred. In one cohort study, nabumetone was associated with lower all-cause mortality compared with diclofenac and naproxen, but this finding has not been replicated.
HTN, CHF, edema, and impaired renal function | Fair. Multiple systematic reviews, clinical trials, and observational studies, but analyses limited by inconsistent reporting of results and probable publication bias | All NSAIDs are associated with deleterious effects on blood pressure, edema, and renal function. Indirect evidence and observational data suggests that rofecoxib is associated with a greater risk of hypertension, CHF, and edema compared to celecoxib. Rofecoxib was also associated with more cardiorenal events than celecoxib in three head-to-head trials of high-risk patients, but possible nonequivalent dosing limits interpretation of these results. No clear differences between celecoxib, partially selective, and non- selective NSAIDs.
Hepatotoxicity | Good. Systematic reviews of multiple trials and observational studies | Clinically significant hepatotoxicity was rare. Several NSAIDs associated with high rates of hepatotoxicity have been removed from the market. Among currently marketed NSAIDs, diclofenac was associated with a higher rate of liver-related discontinuations compared with placebo (2.17%).
Tolerability | Good for coxibs and non- selective NSAIDs (consistent results from multiple systematic reviews); fair for partially selective NSAIDs, aspirin, and salsalate (few meta-analyses and short-term trials) | Relative to non-selective NSAIDs, coxibs and partially selective NSAIDs were at least as well tolerated and aspirin was less tolerated; salsalate was less well tolerated than non- selective NSAIDs in 2 of 3 trials, but less toxic in flawed observational studies; no clear differences among coxibs or among non- selective NSAIDs
Acetaminophen | Good overall. Consistent results from multiple systematic reviews for efficacy and GI adverse events. Poor for cardiovascular safety (no evidence on myocardial infarctions) and fair for renal safety (observational studies) | Acetaminophen is modestly inferior to NSAIDs for reducing pain and improving function. Acetaminophen is superior to NSAIDs for GI side effects (clinical trials data) and GI complications (observational studies). Acetaminophen may be associated with modest increases in blood pressure and renal dysfunction (observational studies). Acetaminophen does not appear to be associated with an increased risk of hepatotoxicity at therapeutic doses in patients without underlying liver disease.
Glucosamine and chondroitin | Fair. Inconsistent evidence from clinical trials. The most promising results have been obtained in trials funded by a European manufacturer of pharmaceutical grade glucosamine not approved in the U.S. | A recent large, good-quality NIH-funded trial found that pharmaceutical grade glucosamine hydrochloride and chondroitin sulfate alone or in combination were not superior to placebo among all patients studied. In a small subgroup of patients with at least moderate baseline pain, there appeared to be a modest benefit for pain relief from the combination, but this did not appear to be a preplanned analysis. In older trials, many with some flaws, glucosamine was superior to oral NSAIDs and placebo in trials evaluating pharmaceutical grade glucosamine and funded by its manufacturer. Other trials found no difference between glucosamine and placebo or glucosamine and oral NSAIDs. Chondroitin was superior to placebo in older, flawed trials. Data on the effects of glucosamine on slowing progression of disease are limited to two trials showing beneficial effects on progression of knee joint narrowing. Glucosamine and chondroitin were consistently well tolerated, with no serious adverse events reported in the trials.
1b. How do these benefits and harms change with dosage and duration of treatment, and what is the evidence that alternative dosage strategies, such as intermittent dosing and drug holidays, affect the benefits and harms of oral medication use? | Good for safety (consistent evidence from multiple clinical trials and observational studies), no evidence for alternative dosage strategies. | Risk of GI bleeding increases with higher doses of non-selective NSAIDs. Effects of dose and duration are somewhat inconsistent. Celecoxib was most effective for GI safety at 6 months and not after longer follow-up in the CLASS trials. A trend towards a dose- dependent CV risk of celecoxib was observed in a long-term prevention trial. CV risk of rofecoxib became most apparent after 8 months in VIGOR and after 18 months in the APPROVe prevention trial, but interpretation of earlier risk is imprecise because of small numbers of events. Most, but not all, observational studies suggest a dose- dependent effect of rofecoxib on MI risk.
2. Do the comparative benefits and harms of oral treatments for osteoarthritis vary for certain demographic and clinical subgroups?
Demographic subgroups including age, sex, and race | Good (age, sex) Poor (race) | Most studies included a majority of women. The risks of GI and CV events increase in older patients. The data that selective COX-2 inhibitors are safe and efficacious in different racial groups have been presented to the FDA. In the peer-reviewed literature, there is no evidence that the comparative efficacy of different selective and non-selective NSAIDs varies according to age, gender, or race.
Pre-existing disease including history of previous bleeding due to NSAIDs or peptic ulcer disease; hypertension, edema, ischemic heart disease, and heart failure | Previous bleeding: Good Hypertension, edema: Fair Ischemic Heart Disease: Poor (no comparative studies) Heart failure: Fair | Risk of bleeding is higher in patients with prior bleeding or PUD. Two trials found high rates of recurrent ulcer bleeding in patients randomized either to celecoxib or a non- selective NSAID + PPI. Risk of CV and renal events is higher in patients with cardiac and renal co-morbidities. In a single observational study that examined mortality, rofecoxib and non-selective NSAIDs were associated with higher rates of death and recurrent heart failure than celecoxib.
Concomitant anticoagulant use | Fair overall: Primarily observational studies | Concomitant use of anticoagulants and non- selective NSAIDs increase the risk of GI bleeding three- to six-fold. Reliable conclusions about the safety of selective NSAIDs in the setting of anticoagulation could not be drawn from flawed observational studies, though there are case reports of serious bleeding events (primarily in the elderly). Warfarin plus aspirin (prophylactic doses) increased the risk of bleeding compared with warfarin alone in patients with indications for antithrombotic prophylaxis. Acetaminophen can increase INR levels, but effects on bleeding rates have not been studied.
Concomitant aspirin use | Good for GI safety: Consistent evidence from clinical trials and observational studies Fair for CV safety: Subgroup analyses from few trials, few observational studies | Concomitant use of aspirin appears to attenuate or eliminate the GI benefits of selective NSAIDs. Concomitant low-dose aspirin increased the rate of endoscopic ulcers by about 6% in patients on celecoxib and those on non-selective NSAIDs in one meta-analysis. In one trial, rofecoxib plus low- dose aspirin and ibuprofen were associated with a similar risk of endoscopic ulcers (16–17%); both were significantly higher than placebo (6%) or aspirin alone (7%). Evidence regarding the effects of concomitant aspirin use on CV risk associated with selective or non-selective NSAIDs is limited, though three polyp prevention trials of rofecoxib or celecoxib found that concomitant aspirin use did not attenuate the observed increased risk of CV events.
3. What are the comparative effects of co-prescribing of H2-antagonists, misoprostol, or proton pump inhibitors (PPIs) on the gastrointestinal harms associated with NSAID use? | Good: Consistent evidence from good-quality systematic reviews and numerous clinical trials | Co-prescribing of misoprostol or PPIs with NSAIDs offers some advantages over full- dose H2-antagonists. PPIs are associated with the lowest rates of endoscopically detected duodenal ulcers. Misoprostol and PPIs are associated with similar rates of endoscopically detected gastric ulcers as PPIs. While misoprostol offers the advantage of being the only gastroprotective agent to reduce rates of clinical GI events, it is also associated with an increased risk of GI-related adverse event withdrawals. Full-dose H2 blockers were associated with lower ulcer risk than placebo, but head-to-head trials against PPIs and misoprostol are lacking. Endoscopic duodenal ulcer risk for standard dose H2 blockers was lower than placebo, similar to misoprostol, and higher than omeprazole; standard dosages of H2 blockers and placebo were associated with similar gastric ulcer risk
4. What are the comparative benefits and harms of treating osteoarthritis with oral medications as compared with topical preparations?
Topical NSAIDs: efficacy | Good: Consistent evidence for selected topical NSAIDs from clinical trials | Topical NSAIDs are similar to oral NSAIDs for efficacy. Topical diclofenac is the best studied, though many trials evaluated a formulation using a DMSO carrier that is not available in the U.S. Topical ibuprofen was superior to placebo in several trials.
Topical NSAIDs: safety | Good: Consistent evidence from trials and systematic reviews and observational studies | Topical NSAIDs are associated with increased local adverse events compared with oral NSAIDs. Total adverse events and withdrawal due to adverse events are similar. Topical NSAIDs are superior for GI events, including severe events, and changes in hemoglobin (data from one good-quality trial).
Topical salicylates: (including capsaicin) | Fair: Only placebo-controlled trials, many of which were flawed | Topical salicylates were no better than placebo in higher-quality trials. Topical capsaicin was superior to placebo (NNT 8.1), but associated with increased local adverse events and withdrawals due to adverse events.

## Discussion

This report provides a comprehensive summary of the comparative efficacy and safety of oral nonsteroidal anti-inflammatory drugs (NSAIDs) (selective, non-selective, aspirin, and salsalate), acetaminophen, certain over-the-counter supplements (chondroitin and glucosamine), and topical agents (NSAIDs and rubefacients, including capsaicin) that are commonly used for pain control and improvement of functional status in patients with osteoarthritis. At this time, no drug or supplement is known to modify the course of disease, though initial long-term trials of pharmaceutical grade glucosamine suggest an effect on radiologic evidence for disease progression.

Evidence regarding the benefits of oral NSAIDs from primarily short-term randomized controlled trials is abundant and demonstrates no clear, consistent differences for relieving pain or other osteoarthritis-related symptoms, or for superior tolerability. On the other hand, much of the uncertainty and confusion regarding NSAIDs centers on their comparative safety.

The trade-offs between reduced GI risk and increased CV harms was first clearly observed in VIGOR. In this trial, rofecoxib 50 mg daily significantly reduced symptomatic ulcers (NNT=62) and serious ulcer complications (NNT=191) compared with naproxen in patients with rheumatoid arthritis.19 However, the GI-protective effects were accompanied by a more than four-fold increase in myocardial infarctions, or one additional myocardial infarction for every 333 patients treated with rofecoxib. When considering all “serious” adverse events, moreover, rofecoxib was not associated with any clear benefit compared with naproxen.114

Rofecoxib became the focus of intense scrutiny following publication of VIGOR. Subsequently, multiple observational studies138–141, 143–152 and systematic reviews124, 129 of RCTs have reported findings largely consistent with an increased risk of cardiovascular events with exposure to rofecoxib. Rofecoxib was voluntarily withdrawn from the market in 2004, after a long-term placebo-controlled polyp prevention trial reported increased cardiovascular risk.132 Valdecoxib was likewise voluntarily withdrawn from the market in 2005. Withdrawal was recommended by FDA based on their conclusion that valdecoxib associated with no clear GI benefit,117 an increased risk of serious skin reactions,168 and potential increased risk of CV events.165, 166 As a result, celecoxib is the only selective NSAID currently available in the U.S. The same concerns about the overall safety of rofecoxib have been directed at celecoxib. The evidence regarding the relative GI and CV safety of celecoxib, however, is less clear. In CLASS, the largest published study of GI complications, celecoxib was not significantly different than diclofenac or ibuprofen for either ulcer complications or myocardial infarctions by the end of follow-up.94 Like the VIGOR trial, re-analysis of all serious adverse events in CLASS found no significant advantage for celecoxib.94 On the other hand, systematic reviews and other meta-analyses of primarily short-term and frequently unpublished data found that celecoxib (primarily at lower doses than were used in CLASS) was associated with lower rates of ulcer complications than non-selective NSAIDs.62, 121 These findings, in combination with earlier systematic reviews of primarily short-term trials that found no increased cardiovascular risk with celecoxib, suggested a possible advantage of celecoxib over non-selective NSAIDs.62, 134, 135 More recent meta-analyses (including data from long-term polyp prevention trials) reporting an increased risk of myocardial infarctions with celecoxib (particularly at high doses) relative to placebo, however, raise additional questions about its appropriate use.129, 136

Well-designed, long-term observational studies could provide ‘real-world’ information not available from most RCTs, which are usually designed as short-term efficacy trials that evaluate selected populations and employ rigid dosing regimens (often at high doses) under carefully controlled conditions. Observational studies are generally consistent with the RCTs in that celecoxib is consistently GI protective139, 162 or neutral138 and not associated with higher risks of CV events relative to non-selective NSAIDs.144, 145, 150, 160 Additionally, celecoxib is associated with lower risks of serious GI events than rofecoxib.139, 142 Evidence from observational studies is less clear with regard to how celecoxib compares to rofecoxib in terms of CV risk due to differences in outcome reporting and in the number and type of factors adjusted for in outcome analyses.

An important drawback of the observational studies, however, is that they largely focus on individual adverse events in isolation. More informative analyses of the overall trade-off between risks and benefits would consider net harms from all serious adverse events. Our re-analysis of results from three studies139, 147, 163 reporting myocardial infarctions, heart failure hospitalizations, and gastrointestinal bleeding in an elderly Canadian population receiving multiple prescriptions suggests that in everyday use, celecoxib may confer net advantages in terms of the number of these events compared with rofecoxib and non-selective NSAIDs. However, additional studies on original data are needed to confirm this finding in other settings.

The cardiovascular effects of naproxen and other non-selective NSAIDs have been the subject of considerable debate since the publication of the VIGOR trial. At this time, among NSAIDs with sufficient evidence to assess cardiovascular risk, naproxen appears to offer the most favorable cardiovascular safety profile. In a recent, comprehensive systematic review, naproxen (even at high doses) was moderately superior to COX-2 inhibitors for cardiovascular safety.129 In addition, naproxen was the only NSAID (selective or non-selective) associated with a neutral cardiovascular effect relative to placebo, though these analyses were primarily based on indirect comparisons. The cardiovascular risks of non-naproxen, non-selective NSAIDs were similar to the selective COX-2 inhibitors, though most of the evidence was limited to high-dose ibuprofen and diclofenac. At this time, there is insufficient evidence to reliably judge the relative cardiovascular safety of other non-selective NSAIDs or the partially selective drugs nabumetone, diclofenac, and meloxicam. For GI safety, no clear advantage for any particular partially selective or non-selective NSAIDs has been demonstrated.

Topical NSAIDs may offer the advantages of local analgesic and anti-inflammatory effects without the systemic side effects of oral administration. They would probably be most useful in patients with a limited number of affected joints. Although topical NSAIDs appear comparable to oral NSAIDs for pain relief in several trials, the most convincing evidence comes from a recent trial that evaluated a proprietary formulation of diclofenac with DMSO that has not been FDA-approved.338 Topical NSAIDs appear safer than oral NSAIDs for GI safety, but data on comparative cardiovascular risks are not available. The relative benefits of topical rubefacients compared with topical or oral NSAIDs has not been adequately studied, and other than for capsaicin (which is sometimes classified separately from the rubefacients), there is insufficient evidence to prove that topical rubefacients are superior to placebo for osteoarthritis.

Acetaminophen is often considered an attractive alternative to NSAIDs because of its perceived safety profile. It was associated with GI-protective effects relative to non-selective NSAIDs,229, 231 though at the expense of modestly inferior efficacy.234 More evidence is needed to compare the effects of acetaminophen and NSAIDs on other important adverse events such as cardiovascular safety, renal dysfunction, blood pressure, and heart failure. However, one recent observational study found that heavy use of acetaminophen is associated with increased cardiovascular risks similar to that seen with NSAIDs.237 Aspirin is another alternative that has the advantage of a cardiovascular protective effect. However, nearly all of the evidence on cardiovascular and GI safety of aspirin is from trials using lower, preventative doses rather than higher anti-inflammatory and analgesic doses.

Glucosamine and chondroitin are widely available as over-the-counter supplements. The highly variable content of currently available products, however, remains a significant issue in the U.S. Further, nearly all of the trials demonstrating benefits of glucosamine have been conducted using pharmaceutical grade preparations not currently available in the U.S.248 Compared with the evidence for glucosamine, the evidence for chondroitin appears less promising. While these agents appear to be safe in the short term, high-quality, long-term safety data are sparse. A recent large, NIH-sponsored trial helps clarify the role of these supplements in management of osteoarthritis.259 It found that the combination of pharmaceutical grade glucosamine and chondroitin was modestly superior to placebo only in an analysis of a small subgroup of patients with at least moderate severity of baseline disease. Neither glucosamine nor chondroitin alone was superior to placebo overall or in the subgroup of patients with greater baseline severity. Data on effects of glucosamine on osteoarthritis progression are limited to two trials showing a beneficial effect on knee joint space narrowing over three years using a pharmaceutical grade preparation.

Strategies to reduce the risk of GI complications in patients taking NSAIDs include co-prescription of misoprostol, standard- or double-dose H2 blockers, or PPIs. All of these strategies are effective in reducing the risk of NSAID-associated endoscopic gastric and duodenal ulcers relative to use of non-selective NSAIDs alone. Misoprostol (RR 0.36, 95% CI 0.20 to 0.67) and PPIs (RR 0.09, 95% CI 0.02 to 0.47) also reduced NSAID-associated symptomatic ulcers.293 Further, misoprostol is the only agent proven to decrease risk of clinical GI events, but is associated with an increased risk of withdrawals due to nausea, diarrhea, and/or abdominal pain.317 In high-risk patients (those with a recent bleed), non-selective NSAIDs and the combination of a non-selective NSAID plus a PPI were both associated with similar, high rates of recurrent bleeding.270, 271

In summary, each of the analgesics evaluated in this report was associated with a unique set of risks and benefits. The role of selective and non-selective oral NSAIDs and alternative agents will continue to evolve as additional information emerges. At this time, although the amount and quality of evidence varies, no currently available analgesic reviewed in this report offers a clear overall advantage compared with the others, which is not surprising given the complex trade-offs between the many benefits (pain relief, improved function, improved tolerability, and others) and harms (cardiovascular, renal, GI, and others) involved. In addition, individuals are likely to differ in how they prioritize the importance of the various benefits and harms of treatment. Adequate pain relief at the expense of a small increase in CV risk, for example, could be an acceptable trade-off for many patients. Others may consider even a marginal increase in CV risk unacceptable. Factors that should be considered when weighing the potential effects of an analgesic include age (older age being associated with increased risks for bleeding and cardiovascular events), co-morbid conditions, and concomitant medication use (such as aspirin and anticoagulation). As in other medical decisions, choosing the optimal analgesic for an individual with osteoarthritis should always involve careful consideration and thorough discussion of the relevant trade-offs.