# Introduction

Osteoarthritis, the most common form of arthritis, is associated with substantial disability and reduced quality of life.2 Among U.S. adults aged 30 or older, approximately 6% have symptomatic osteoarthritis of the knee, and 3% have symptomatic osteoarthritis of the hip.3 Osteoarthritis increases with age, with the incidence and prevalence increasing 2- to 10-fold from age 30 to 65, and continues to increase after age 65.^4^ Osteoarthritis accounts for more disability in walking, stair climbing, and other tasks requiring use of the lower extremities than any other disease, particularly in the elderly.5 The total costs for arthritis, including osteoarthritis, may be greater than 2% of the gross domestic product,3 with more than half of these costs related to work loss.5

In addition to non-pharmacologic interventions (such as physical therapy, weight reduction, and exercise), numerous medications and over-the-counter supplements are available to treat pain and potentially improve functional status in patients with osteoarthritis. Each class of medication or supplement is associated with a unique balance of risks and benefits. In addition, efficacy and safety may also vary for individual drugs within a class. Oral medications commonly used to treat osteoarthritis include nonsteroidal anti-inflammatory drugs (NSAIDs) and acetaminophen (Appendix A). Many are available at lower over-the-counter and higher prescription doses. Commonly used supplements sold over-the-counter and not regulated as pharmaceuticals by the FDA include glucosamine and chondroitin. Topical agents frequently used by patients with osteoarthritis are rubefacients (including capsaicin), NSAIDs, and other miscellaneous preparations.6 Opioid medications are also used for patients with chronic pain, especially if it is refractory to other therapies, but are not recommended for first-line treatment for osteoarthritis or other conditions because of risks of addiction, tolerance, diversion, and other adverse events.7, 8

NSAIDs exert analgesic, anti-inflammatory, and anti-pyretic effects by blocking cyclo-oxygenases (COX), enzymes that are needed to produce prostaglandins. Understanding of the pharmacology of NSAIDs continues to evolve, but it is now thought that most NSAIDs block three different COX isoenzymes, known as COX-1, COX-2, and COX-3. COX-2, found in joint and muscle, contributes to pain and inflammation. Because they block COX-2, non-steroidal anti-inflammatory drugs reduce pain compared to placebo in patients with arthritis,9 low back pain,10 minor injuries, and soft tissue rheumatism. Less is known about COX-3, which has been found in the cerebral cortex and cardiac tissue and appears to have effects on centrally-mediated pain.1

NSAIDs are also associated with important adverse effects. NSAIDs cause gastrointestinal (GI) bleeding because they also block the COX-1 enzyme, which protects the lining of the stomach from acid. In the 1990s in the United States, nonaspirin NSAIDs are estimated cause 32,000 hospitalizations and 3,200 deaths annually from GI bleeding.11 A risk analysis12 based on a retrospective case-control survey of emergency admissions for upper GI disease in two United Kingdom general hospitals provided useful estimates of the frequency of serious GI complications from NSAIDs.13 In people taking NSAIDs, the 1-year risk of serious GI bleeding ranges from 1 in 2,100 in adults under age 45 to 1 in 110 for adults over age 75, and the risk of death ranges from 1 in 12,353 to 1 in 647 (Table 1). In addition to age, prednisone use, disability level, and previous NSAID-induced GI symptoms are risk factors for GI bleeding.

Table 1

One year risk of GI bleeding due to NSAID

Age range (years) | Chance of GI bleed due to NSAID | Chance of dying from GI bleed due to NSAID
| Risk in any one year is 1 in:
16–45 | 2100 | 12,353
45–64 | 646 | 3800
65–74 | 570 | 3353
≥ 75 | 110 | 647

Data are from Blower,13 recalculated in Moore12 and in Bandolier14

NSAIDs differ in their selectivity for COX-2—how much they affect COX-2 relative to COX-1. Theoretically, an NSAID that blocks COX-2 but not COX-1 might reduce pain and inflammation in joints but leave the stomach lining alone. Appendix B15 summarizes the NSAIDs and their selectivity based on assay studies (done in the laboratory instead of in living patients). The table gives an idea of how widely NSAIDs vary in their selectivity, but should be interpreted with caution. Different assay methods give different results, and assay method may not reliably predict what will happen when the drug is given to patients. Clinical studies, rather than these assay studies, are the best way to determine whether patients actually benefit from using more selective NSAIDs.

In addition to their propensity to cause GI bleeding, NSAIDs are also associated with adverse effects on blood pressure, renal function, and fluid retention. Mechanisms may involve attenuation of prostaglandin-mediated vasodilation, promotion of sodium and water retention, increased vascular resistance, and increased renal endothelin-1 synthesis.16–18

An association between selective COX-2 inhibitors and increased rates of myocardial infarction was first observed in the large, pivotal Vioxx Gastrointestinal Outcomes Research (VIGOR) trial comparing high-dose rofecoxib (50 mg) to naproxen 1000 mg.19 Reasons for the increase in thromboembolic cardiovascular event risk are complex and not completely understood, but may be related in part to suppression of endothelial-derived prostaglandin I2 formation by selective COX-2 inhibition, in the setting of unaffected platelet production of pro-thrombotic COX-1 mediated thromboxane A2.^20^ Blood pressure elevations associated with COX-2 inhibitors may also play a role in increasing cardiovascular risk.21 On September 30, 2004, rofecoxib was withdrawn from the market after a long-term polyp prevention trial found an increased risk of myocardial infarction compared with placebo.22 On December 9, 2004, the US Food and Drug Administration issued a black-box warning for valdecoxib for life-threatening skin reactions and increased cardiovascular risk. This drug was subsequently also withdrawn voluntarily by the manufacturer.23

Aspirin, or acetylsalicylic acid, has long been known to have analgesic, anti-pyretic, and anti-inflammatory effects.24 It is thought to be the most consumed medicinal drug in the world. Like the non-aspirin NSAIDs, aspirin’s effects are due to blockade of cyclo-oxygenases. However, an important distinction between aspirin and non-aspirin NSAIDs is that aspirin also induces irreversible functional defects in platelets (although non-aspirin NSAIDs also have effects on platelet aggregation, they are short-lived). Because of these antiplatelet effects, low-dose aspirin is also used prophylactically to reduce the risk of thrombotic events.25 However, even at doses of 325 mg daily or lower, the potential cardiovascular benefits must be balanced against dose-dependent risk of aspirin-induced adverse GI events. Salsalate, a nonacetylated salicylate, is a prodrug of salicylic acid, the active metabolite of aspirin. However, salsalate is considered a relatively weak inhibitor of cyclo-oxygenases.26

Acetaminophen (also known as paracetamol) is an anti-pyretic and analgesic medication that is not thought to have significant anti-inflammatory properties. Although its mechanism of inducing analgesia is still not completely understood, it is thought to work in part by indirectly decreasing production of prostaglandins through inhibitory effects involving COX-2.^16, 27^ Acetaminophen is frequently recommended as a first line agent for osteoarthritis and other pain conditions because of its perceived favorable safety profile—particularly with regard to ulcer risk.28

Chondroitin sulfate and glucosamine sulfate are natural compounds found in cartilage. Both are marketed to patients who have osteoarthritis. The precise mechanisms of action are unknown, but may involve promoting maintenance and repair of cartilage. Glucosamine, for example, has been shown to increase proteoglycan synthesis.29 In the European Union countries, glucosamine is available as a prescription drug manufactured by the Rotta Pharmaceutical Company. In the U.S., by contrast, glucosamine and chondroitin are considered dietary supplements and are not regulated as pharmaceuticals. Adequate standardization of glucosamine and chondroitin preparations is a significant concern. It has been shown that the actual content often varies substantially from what is stated on the label.30 Such inconsistencies may have implications on estimates of efficacy and safety for different commercial preparations.

Topical administration of NSAIDs could theoretically result in local analgesic and anti-inflammatory effects by direct absorption through the skin, with reduced systemic adverse events compared with oral administration.31 Experimental studies indicate that topical administration is associated with substantially higher concentrations of NSAIDs in soft tissue (particularly meniscus and cartilage) and lower peak plasma concentrations compared with oral administration.6 For a topical NSAID to be effective, it has to reach the inflamed tissue in sufficient concentrations to produce analgesic and anti-inflammatory activity. The solubility of specific NSAIDs varies considerably, and is also affected by the carrier or formulation used.31 Superior in vivo permeability characteristics, however, may not predict clinical effectiveness.

In contrast to topical NSAIDs, whose mechanism of action involves inhibition of cyclo-oxygenase, topical rubefacients are thought to relieve pain through counter irritation.6, 32 Although the mechanism of action of topical preparations containing salicylate esters is unclear, they are now usually classified as rubefacients rather than topical NSAIDs because they may not work via inhibition of cyclo-oxygenase.6, 33 Capsaicin, which is also often classified as a rubefacient, is derived from the hot chili pepper (Capsicum species). It is applied topically and thought to work by stimulating the release of substance P and other neuropeptides from sensory nerve endings.34 Although this release can initially lead to burning and pain, analgesia occurs after repeated and continued application, as substance P becomes depleted. Although a wide variety of other rubefacients are available, only topical salicylates and capsaicin were included in this review.

The purpose of this report was to assess the comparative efficacy and safety of non-opioid oral medications (selective and non-selective non-aspirin NSAIDs, aspirin, salsalate, and acetaminophen), over-the-counter supplements (chondroitin and glucosamine), and topical agents (NSAIDs and rubefacients, including capsaicin) for osteoarthritis.

## Scope and Key Questions

1. What are the comparative benefits and harms of treating osteoarthritis with oral medications or supplements? How do these benefits and harms change with dosage and duration of treatment, and what is the evidence that alternative dosage strategies, such as intermittent dosing and drug holidays, affect the benefits and harms of oral medication use? (Note: This question addresses the therapeutic benefits of long-term use for the condition osteoarthritis. However, the question does address all harms associated with NSAID use, including use for other labeled indications such as the treatment of rheumatoid arthritis.)

Oral NSAIDs include:

- aspirin; - celecoxib; - choline magnesium trisalicylate; - diclofenac; - diflunisal; - etodolac; - etoricoxib^*^; - fenoprofen; - flurbiprofen; - ibuprofen; - indomethacin; - ketoprofen; - ketoprofen ER; - ketorolac; - lumiracoxib^*^; - meclofenamate sodium; - mefenamic acid; - meloxicam; - nabumetone; - naproxen; - oxaprozin; - piroxicam; - rofecoxib^*^; - salsalate; - sulindac; - tenoxicam^*^; - tiaprofenic acid^*^; - tolmetin; - valdecoxib^*^

* These drugs are currently not approved (etoricoxib, lumiracoxib, tenoxicam, tiaprofenic acid) for use in the United States by the FDA or have been withdrawn from the market (rofecoxib and valdecoxib)

Other oral agents include acetaminophen, chondroitin, and glucosamine. See Appendix A for a detailed listing of pharmacokinetics, indications, and recommended dosing information for all included drugs. Appendix C shows low, medium and high doses for the more commonly used NSAIDs.

For this report, we defined the terms “selective NSAID” or “COX-2 selective NSAID” as drugs in the “coxib” class (e.g. celecoxib, rofecoxib, and valdecoxib). We grouped etodolac, nabumetone, and meloxicam into a separate category that we referred to as “partially selective NSAIDs,” to explore how in vitro differences in COX-2 selectivity might translate into clinical differences in safety. The salicylic acid derivatives aspirin and salsalate were also considered a separate subgroup. We defined “non-aspirin, non-selective NSAIDs” or simply “non-selective NSAIDs” as all other NSAIDs. We included evidence on the efficacy and safety of the COX-2 inhibitor rofecoxib, even though it is no longer available in the U.S., because it was the first drug to be associated with cardiovascular risks and therefore provides important historical context and illustrates important issues to consider when evaluating the risks and benefits of selective and non-selective NSAIDs. For other COX-2 inhibitors not approved by the FDA for use in the U.S. (lumiracoxib and etoricoxib) or withdrawn from the market (valdecoxib), we focused only on evidence regarding long-term, serious GI and CV adverse events, which is likely to be the most important factor driving future decisions regarding their use.

“Benefits” include relief of pain and osteoarthritic symptoms and improved functional status. The main outcome measures for this review were pain, functional status, and discontinuations due to lack of efficacy. Frequently used outcome measures include visual and categorical pain scales:35

Visual analogue scale (VAS): Using VAS, patients indicate their level of pain, function, or other outcome by marking a scale labeled with numbers (such as 0 to 100) or descriptions (such as “none” to “worst pain I’ve ever had”). An advantage of VAS is that they provide a continuous range of values for relative severity. A disadvantage is that the meaning of a pain score for any individual patient depends on the patient’s subjective experience of pain. This poses a challenge in objectively comparing different patients’ scores, or even different scores from the same patient.

Categorical pain scales consist of several pain category options from which a patient must choose (e.g., no pain, mild, moderate, or severe). A disadvantage of categorical scales is that patients must chose among categories that may not accurately describe their pain. A variety of disease-specific and non-specific scales are used to assess these outcomes in patients with osteoarthritis. Commonly used categorical pain scales include:

- The Western Ontario and McMaster Universities Osteoarthritis Index (WOMAC), a 24-item, disease-specific questionnaire used to assess the functional status of patients with osteoarthritis of the knee and hip. A lower score indicates better function.36
- The Medical Outcomes Short Form-36 (SF-36) health survey, a commonly used general instrument for measuring health-related quality of life across different diseases.37
- Patient Global Assessment of Disease Status and Investigator Global Assessment of Disease Status. The patient or investigator answers questions about the overall response to treatment, functional status, and pain response, using a VAS or categorical scale.
- American College of Rheumatology (ACR) criteria measure disease activity and response to treatment. ACR 20, ACR 50, or ACR 70 reflect either an improvement to the 20%, 50%, or 70% level in the parameters outlined.

Another method for measuring outcomes is classifying patients dichotomously as “responders” or “non-responders.” Responders are often defined as patients with at least a 50% improvement in pain or function. The Outcomes Measures in Arthritis Clinical Trials-Osteoarthritis Research Society International (OMERACT-OARSI) criteria, for example, were developed through a consensus process and classifies patients as responders if they meet specific pre-defined criteria (>=50% improvement in pain or function that was >=20 mm on a 100 mm VAS, or a >=20% improvement in at least two of pain, function, or patient global assessment that was >=10 mm on a 100 mm VAS).38

“Harms” include tolerability (not having to stop the drug due to adverse effects); cardiovascular, hepato-, renal, and gastrointestinal toxicity; and increased risk for hospitalizations, drug interactions, and death. For gastrointestinal toxicity, we focused on serious complications associated with NSAIDs including perforation, bleeding ulcer, and gastric outlet obstruction, though we also evaluated other gastrointestinal side effects (such as nausea, dyspepsia, and gastrointestinal tolerability. We only considered rates of endoscopic ulcers when data on clinical ulcer complications were incomplete or not available.

2. Are there clinically important differences in the harms and benefits of oral treatments for osteoarthritis for certain demographic and clinical subgroups?

- Demographic subgroups include age, sex, and race.
- Co-existing diseases include hypertension, edema, ischemic heart disease, heart failure, PUD, and history of previous bleeding due to NSAIDS.
- Concomitant medication use includes anticoagulants and aspirin.

3. What is the evidence that the gastrointestinal harms of NSAID use are reduced by co-prescribing of H2-antagonists, misoprostol, or proton pump inhibitors?

4. What are the benefits and safety of treating osteoarthritis with oral medications as compared with topical preparations?

Topical preparations include:

- Capsaicin
- Diclofenac
- Ibuprofen
- Ketoprofen
- other NSAIDs
- salicylates