# Evidence Tables

Evidence Table 1. 01 [1]

Trials of NSAIDs vs NSAIDs

| | | | | | | | | | | Internal Validity | | | | | | | | | | External Validity
Author year | Subjects | Comparison | Number of subjects^*^ | Duration (weeks) | Aspirin permitted? | Efficacy measures | Withdrawals^**^ | | | Other outcomes | Randomizati on adequate? | Allocation concealment adequate? | Groups similar at baseline? | Eligibility criteria specified? | Outcome assessors masked? | Care provider masked? | Patient masked? | Reporting of attrition, crossovers, adherence, and contamination | Loss to follow-up: differential/high | Intention-to-treat (ITT) analysis | Post-randomization exclusions | Quality Rating | Number screened/eligible/enrolled | Exclusion criteria | Run-in/Washout | Class naïve patients only | Control group standard of care | Funding
| | Meloxicam (mg) | NSAID (mg) | | | | | Meloxicam | NSAID
Dequeker (SELECT) † | OA hip, knee, hand, or spine | 7.5 | piroxicam 20 | 8656 | 4 | unclear | pain, PGA, withdrawals | [underlined: 1.7%] | [underlined: 1.6%] | No difference | method NR | NR | yes | no | unclear, reported as double-blind | unclear, reported as double-blind | yes | no/no/no/no | no | no | yes (n=630) | fair | NR/NR/9286 | NR | NR/NR | no | NA | Boehringer Ingelheim
Furst | RA | 7.5, 15, 22.5 | diclofenac 150 | 894 | 12 | no | PGA, pain, painful/tender joints, physical functioning | [underlined: 25.7% (7.5 mg);] [underlined: 24.5% (15 mg);] [underlined: 20.9% (22.5 mg)] | [underlined: 14.4%] | No differences | method NR | NR | yes | yes | unclear, reported as double-blind | unclear, reported as double-blind | unclear, reported as double-blind | no/no/no/no | no | no | NR | fair | NR/NR/894 | NR | NR/12hrs (acetaminophen) | no | yes | Boehringer Ingelheim
Goei The | OA knee | 7.5 | diclofenac 100 | 258 | 6 | yes | pain during active movement, PGA, acetaminophen use | [underlined: 3.9%] | [underlined: 2.3%] | No difference, trend favored meloxicam
Hawkey (MELISSA) | OA hip, knee, hand, or spine | 7.5 | diclofenac 100 | 9323 | 4 | unclear | pain, PGA, withdrawals | 1.7% | 1.0% | No difference, trend slightly favored meloxicam | method NR | NR | yes | yes | unclear, reported as double-blind | unclear, reported as double-blind | unclear, reported as double-blind | no/no/no/no | no | unclear, only mean values reported | NR | fair | NR/NR/10,051 | Active peptic ulcer; hypersensitivity to analgesics, antipyretics or NSAIDs; asthma; nasal polyps; angioneurotic oedema or urticaria following NSAID administration; concomitant anticoagulants; litium, methotrextate, other NSAIDs or analgesic agents; significant impairment of renal function; severe liver injury; hemotological disorder; pregnant or breastfeeding; any disease which could interfere with the evaluation of efficacy or tolerabilityl corticosteroid treatment within 2 mos of study; prior replacement of, trauma to, or infection of evaluated joint; previous participation in this or other clinical study within previous month. | NR/washout 3 days | no | NA | NR
Hosie 1996 | OA hip or knee | 7.5 | diclofenac 100 | 336 | 24 | unclear | pain, quality of life | [underlined: 4%] | [underlined: 4%] | No difference | method NR | NR | yes | yes | unclear, reported as double-blind | unclear, reported as double-blind | unclear, reported as double-blind | no/no/no/no | no | yes | NR | fair | NR/NR/336 | Pregnant, lactating or of childbearing potential not using contraception; concomitant clinically unstable disease; clinically relevant lab test abnormalities; clinical evidence of peptic ulceration within previous 6 mos; hypersensitivity to analgesics, antipyretics and/or NSAIDs; required or recently received treatment with any drug or procedure that may interact or obscure the action of the study medication. | NR/washout 3 days | no | NA | NR
Hosie 1997 | OA hip or knee | 15 | piroxicam 20 | 455 | | | overall pain, pain on movement, joint stiffness, global efficacy and quality of life | | | No difference
Linden | OA hip | 15 | piroxicam 20 | | 6 | | | - | - | No difference | method NR | NR | yes | yes | unclear, reported as double-blind | unclear, reported as double-blind | unclear, reported as double-blind | no/no/no/no | no | no | yes (n=29) | fair | NR/NR/285 | NR | NR/washout 3–7 days | no | NA | NR
Valat | OA lumbar spine | 7.5 | diclofenac 100 | 229 | 2 | unclear | pain on motion | [underlined: 0.0%] | [underlined: 0.0%] | No difference | method NR | NR | yes | yes | unclear, reported as double-blind | unclear, reported as double-blind | unclear, reported as double-blind | no/no/no/no | no | yes | no | fair | NR/NR/232 | Symptoms of invertebrate disk herniation with pressure on the nerve roots; former surgery, fracture or trauma in the area of the lumbar spine; severe cardias, hepatic, renal, hematological or metabolic disease, cancer of mental disturbance; any disease that could potentially interfere with the evaluation of safety or efficacy; treatment of the currenty lumbar spine osteoarthritis flare with other NSAIDs (without appropriate washout) muscle relazants or physical therapy; previous concomitant treatment with corticosteroids or with more than 4g/day acetaminophen; evidence of peptic ulcer during the previous 6 mos; bronchial asthma inducible by NSAIDs; known hypersensitivity to analgesics; pregnant or lactating women and women of child-bearing potential who were not using adequate contraception. | NR/washout 3–7 days | no | NA | NR
Wojtulweski | RA | 7.5 | naproxen 750 | 379 | 24 | no | PGA, several others | 23.6% | 14.4% | No difference, trend favored naproxen | method NR | NR | yes | yes | unclear, reported as double-blind | unclear, reported as double-blind | unclear, reported as double-blind | no/no/no/no | no | yes | NR | fair | NR/NR/379 | Previous participation in meloxicam trial; clinical evidence of peptic ulceration; presence of any other rheumatological or non-rheumatological disease which would interfere with the evaluation of efficacy and safety. | NR/washout 3–11 days | no | NA | NR

* Excludes subjects randomized to placebo

** If underlined, for lack of efficacy; otherwise for all reasons

† design identical to Hawkey et al

Bold type - statistically significant; OA - osteoarthritis; PGA - patient global assessment; RA - rheumatoid arthritis

Evidence Table 02[1]

Trials of celecoxib vs NSAIDs

| | | | | | | | | Internal Validity | | | | | | | | | | External Validity
Author year | Subjects | Celecoxib doses (mg) | NSAIDs (mg) | Number of subjects^*^ | Duration (weeks) | Aspirin permitted? | Efficacy measures | Results | Randomization adequate? | Allocation concealment adequate? | Groups similar at baseline? | Eligibility criteria specified? | Outcome assessors masked? | Care provider masked? | Patient masked? | Reporting of attrition, crossovers, adherence, and contamination | Loss to follow-up: differential/high | Intention-to-treat (ITT) analysis | Post-randomization exclusions | Quality Rating | Number screened/eligible/enrolled | Exclusion criteria | Run-in/Washout | Class naïve patients only | Control group standard of care | Funding
Bensen/Zhao | OA of the knee with flare | 50, 100, or 200 bid | naproxen 500 bid | 1004 | 12 | Yes | PGA, WOMAC, withdrawals | No difference | method NR | NR | yes | yes | NR | NR | NR | no/no/no/no | no | yes | no | fair | NR/NR/1003 | Concomitant GI, renal hepatic or coagulation disorder; malignancy; esophageal of gastroduodenal ulceratiion w/in 30 days; inflammatory arthritis, gout acute trauma of the knee; known hypersensitivity to NSAIDs or sulfonamides. | run-in NR/2–7day washout | no | NA | GD Searle
Goldstein | OA and RA with no ulcer on EGD; many had a history of GI disease | 200 bid | naproxen 500 bid | 537 | 12 | Yes | PGA, withdrawals | No difference | yes | NR | yes | yes | NR | NR | NR | no/no/no/no | no | yes | no | fair | NR/NR/537 | Inflammatory arthritis other than OA/RA; gout; GI disease; upper GI ulceration within 30 days of study; naproxen use within 30 days of study; endoscopically confirmed ulcer (>/= 3mm) | run-in NR/1–7day washout | no | NA | GD Searle; Pfizer
Kivitz | OA | 100–400 mg daily | naproxen 1000 mg daily | 1061 | 12 | Yes | PGA, WOMAC | No difference | yes | NR | yes | yes | unclear, reported as “double-masked” | unclear, reported as “double-masked” | yes | no/no/no/no | no | yes | yes (n=1) | good | NR/NR/1061 | Pregnancy; oral, intramuscular, intra-articular, or soft-tissue injections of corticosteroids within 4 wks of study; know hypersensitivity to COX-2s, sulfonamides or NSAIDs; any other investigational medication within 30 days of study; any NSAID or analgesic use within 48 hrs of baseline assessment; concomitant GI, renal, hepatic or coagulation disorder; malignancy within 5 years; esophageal/GI ulceration within 30 days; inflammatory arthritis; gout; acute joint trauma at hip; anticipated need for surgery during study period. | run-in NR/2–4 day washout | no | NA | Pharmacia; Pfizer
McKenna | OA of the knee with flare | 100 bid | diclofenac 50 tid | 400 | 6 | Yes | Index joint pain, WOMAC | No difference | method NR | NR | yes | yes | NR | NR | NR | no/no/no/no | no | yes | no | fair | NR/NR/1940 | Recent treatment with disease-modifying drugs, oral corticosteroids or corticosteroid injections; presence of other rhuematic condition; acute trauma of the joints, peptic ulceration, GI bleeding, inflammatory bowel disease, renal or hepatic failure, significant coagulation defect; malignancy. | NR/NR | no | NA | NR (Pharmacia?)
Silverstein (CLASS) | OA and RA | 400 bid | ibuprofen 800 tid or diclofenac 75 bid | 7968 | 24 | Yes | No efficacy measures reported except withdrawal | Not reported | yes | yes | yes | yes | yes | unclear | yes | no/no/no/no | no | no | yes (n=89) | good | NR/NR/8059 | Active GI, renal hepatic or coagulation disorder; malignancy within 5 yrs; esophageal or gastroduodenal ulceration within 30 days of study; know hypersensitivity to COX-2s, sulfonamides, ibuprofen or diclofenac; pregnant or lactating. | NR/NR | no | NA | Pharmacia

* Excludes subjects randomized to placebo

PGA - patient global asssessment; WOMAC - Western Ontario and McMaster Universities Osteoarthritis Index; OA - osteoarthritis; RA -rheumatoid arthritis; EGD - esophagogastroduodenoscopy; GI - gastrointestinal

Evidence Table 03[1]

Trials of rofecoxib vs NSAIDs

| | | | | | | | | | | Internal Validity | | | | | | | | | | External Validity
Author year | Subjects | Comparison | | Number of subjects^*^ | Duration (weeks) | Aspirin permitted? | Efficacy measures | Withdrawals^**^ | | Outcomes | Randomization adequate? | Allocation concealment adequate? | Groups similar at baseline? | Eligibility criteria specified? | Outcome assessors masked? | Care provider masked? | Patient masked? | Reporting of attrition, crossovers, adherence, and contamination | Loss to follow- up: differential/high | Intention-to- treat (ITT) analysis | Post-randomization exclusions | Quality Rating | Number screened/eligible/enrolled | Exclusion criteria | Run-in/Washout | Class naïve patients only | Control group standard of care | Funding
Author year | Subjects | Rofecoxib dose (mg) | NSAIDs (mg) | Number of subjects^*^ | Duration (weeks) | Aspirin permitted? | Efficacy measures | Rofecoxib dose (mg) | NSAIDs (mg) | Outcomes | Randomization adequate? | Allocation concealment adequate? | Groups similar at baseline? | Eligibility criteria specified? | Outcome assessors masked? | Care provider masked? | Patient masked? | Reporting of attrition, crossovers, adherence, and contamination | Loss to follow- up: differential/high | Intention-to- treat (ITT) analysis | Post-randomization exclusions | Quality Rating | Number screened/eligible/enrolled | Exclusion criteria | Run-in/Washout | Class naïve patients only | Control group standard of care | Funding
Acevado | OA, negative FOBT | 12.5 | diclofenac 50/misoprostol 200 mcg bid | 483 | 6 | No | PGA | 7% | 10.80% | No difference | yes | yes | yes | yes | NR | NR | yes | no/no/no/no | no | yes | NR | good | NR/NR/483 | Inflammatory or post-traumatic arthritis; GI associated diarrhea; infectious disease; malabsorption; uncontrolled diabetes or other serious conditions; bleeding disorder; allergic to NSAIDs/paracetamo; positive test for fecal occult blood; previous use of misoprostol; regular aspirin users; users of corticosteroids; history of sustained use of GI medication. | NR | no | NA | Merck Research Labs
Bombardier (VIGOR) | RA, negative FOBT | 50 | naproxen 500 bid | 8076 | 52 | No | PGA | [underlined: 6.30%] | 6.50% | No difference | method NR | NR | yes | yes | NR | NR | NR | no/no/no/no | no | no | NR | fair | 9539/NR/8076 | History of inflammatory arthritis other than RA; upper GI surgery or inflammatory; estimated creatinine clearance of 30 ml or less/minute; an unstable medical condition; hisotyr of cancer or alcohol or drug abuse within five years of study; history of cerebrovascular events within two years of study; history of MI or coronary bypass in year before study; morbid obesity; patients who required or who had been receiving any of the following drugs: aspirin, ticlopidine, anticoagulants, cyclosporine, misprostol, sucralfate, PPIs, histamine H2-receptor agonists. | 3–14 day NSAID washout | no | NA | Merck Research Labs
Cannon (035) | OA of knee or hip and flare (for NSAID users) or acetominophen user. | 12.5, 25 | diclofenac 50 tid | 784 | 52 | No | WOMAC, PGA, pain while walking | [underlined: 13.9% (12.5 mg) 21.8% (25 mg)] | 16% | Trend favoring diclofenac for 2 of 3 primary measures | yes | NR | yes | yes | NR | NR | NR | no/no/no/no | 448/784 (57.1%) completed study - although no SS differences among the study groups in withdrawal rates | yes | NR | fair | 1,128/NR/784 | Pregnancy or menopausal; significant renal impariment; clinically significant abnormalities on physical of lab exams at baseline; positive results n fecal occult blood test; class III/IV angina or uncontrolled CHF, uncontrolled hypertension, stroke or transient ischemic attack within 2 yrs of study; active hpeatic disease; recent neoplastic disease; allergy to acetaminophen or NSAIDs; required use of aspirin, corticosteroids, warfarin, ticlopidine. | NR | no | NA | Merck Research Labs
Chrubasik | Low back pain | 12.5 | Assalix 1 qid † | 228 | 4 | Yes | Pain | 21% | 18.0% | No difference | yes | NA | yes | yes | NA | NA | NA | no/no/no/no | no | no | NR | fair | NR/NR/228 | Any recent trauma; age >50 or <20; history of cancer or risk factors for spinal infection; unexplained weight loss or recent fever or chills; pain exacerbation when supine; severe nocturnal pain; perineal anesthesia; bladder dysfunction; severe or progressive neurological deficit in a lower extremity. | none | no | NA | NR
Day | OA of knee or hip and flare (for NSAID users) or acetominophen user. | 12.5, 25 | ibuprofen 800 tid | 735 | 6 | No | WOMAC, PGA, pain while walking | [underlined: 3.5% (12.5 mg) 2.8% (25 mg)] | 3% | No difference in 3 primary endpoints, but trend favored rofecoxib 25 mg for 2 of the 3. | yes | yes | yes (placebo group smaller in number with similar characteristics) | yes | NR | NR | yes | no/no/no/no | no | unclear; mean | yes (n=14) | fair | 1023/NR/809 | Significant renal impairment; clinically signficant abnormal results of physical exam or lab screening; positive fecal occult blood test; malabsorption; class III/IV angina or CHF; uncontrolled hypertension; stroke or transient ischemic attack within 2 yrs of study; recent neoplastic disease; allergy of acetaminophen of NSAIDs; required use os aspirin, corticosteriods, warfarin sodium, ticlopidine. | yes - varied depending on NSAID use | no | yes | Merck & Co
Geusens 2002 | RA | 25, 50 | naproxen 500 bid | 1023 | 12 | No | Pain | nr | nr | No difference | method NR | unclear - stratified according to concomitant corticosteroid use | yes (naproxen group smaller than placebo and rofecoxib groups: 114 vs 289/306/286 | yes | NR | NR | NR | no/no/no/no | no | no | yes (n=35) | fair/poor | 1344/NR/10 23 | Presence of: systemic lupus, spondylarthropathy, polymyalgia rheumatica, gout, Paget’s disease, active GI bleeding or ulceration, fecal occult blood, uncontrolled diabetes, MI, angioplasty, coronary bypass surgery within one year, stroke within 2 yrs, active hepatitis, malignancy, hepatic abnomalities, allergy to acetaminophen, aspirin, NSAIDs. | NR | no | yes | Merck Research Labs
Hawkey | OA with no ulcer on EGD | 25, 50 | ibuprofen 800 tid | 581 | 24 | No | PGA | [underlined: 3% (12.5 mg) 1.6% (25 mg)] | 5% | No difference | method NR | allocation stratified by the presence or absence of history of GI events | yes | yes | NR | NR | yes | no/no/no/no | no | no | NR | fair | 1045/NR/77 5 | Previous upper GI surgery; inflammatory bowel disease; elevated creatinine levels; fecal occult blood; unstable medical disease; malignancy within 5 yrs, pregnancy; CV events within 2 yrs; bleeding diathesis; anticoagulant therapy; use of corticosteroids, ticlopidine or aspirin. | 2 wks NSAIDs | no | yes | Merck Research Labs
Kivitz 2004 | OA of knee | 12.5 | nabumetone 1000 | 1042 | 6 | Yes | PGART, WOMAC, SF-36 | 17.50% | 20.7% | Rofecoxib superior for PGART, WOMAC, and | method NR | NR | yes | yes | NR | NR | yes | no/no/no/no | no | unclear for efficacy; yes for safety | no | fair | 1495/NR/10 42 | Concurrent medical/arthritic disease; use of corticosteroids, misoprostol, sucralfate, histamine blockers, antacids, PPIs, analgesics, warfarin, ticlopidine, high-dose aspirin, appetite suprossants, other meds for chronic diseases. | yes - varied depending on NSAID use | no | yes | Merck & Co
Laine | OA with no ulcer or esophagitis on EGD | 25, 50 | ibuprofen 800 tid | 565 | 24 | No | PGA | [underlined: 3% (12.5 mg) 2.1% (25 mg)] | 4.9% | No difference | method NR | allocation stratified by the presence or absence of history of GI events | yes | yes | yes | NR | yes | no/no/no/no | no | no | no | fair/poor | 1102/NR/74 2 | Previous upper GI surgery; inflammatory bowel disease; elevated creatinine levels; fecal occult blood; unstable medical disease; malignancy within 5 yrs; CV events within 2 yrs; bleeding diathesis; anticoagulant therapy; use of corticosteroids, ticlopidine or aspirin. | 2 wks NSAIDs | no | yes | Merck & Co
Lisse | OA of the knee, hip, hand, or spine | 25 | naproxen 500 tid | 5557 | 12 | No | PGA, SF-36 | 11.30% | 12.9% | No difference | yes | yes | yes | yes | NR | NR | yes | no/no/no/no | no | no | yes (n=29) | fair | 6018/NR/55 57 | Existence of potentially confounding concurrent disease (based on investigator opinion) | NR | no | NA | Merck & Co
Myllykangas-Luosujarvi | OA of knee or hip | 12.5 | naproxen 500 bid | 944 | 6 | No | PGA, WOMAC | 27.20% | 28.4% | No difference | yes | NR | yes | yes | NR | NR | yes | no/no/no/no | no | unclear; only mean percentage s reported | no | fair | 1189/NR/94 4 | Inflammatory or post-traumatic arthritis; uncontrolled diabetes or hypertension; angina or CHF; malabsorption; morbid obesity; history of inherited bleeding disorder; elevated creatinine levels; positive test for fecal occult blood; use of corticosteroids, misoprostol, H2 blockers, antacids, PPIs, warfarin, ticlopidine, aspirin >100 mg/day or low-dose aspirin for cardioprophylaxis; history od ulcer or upper GI bleeding. | yes - length NR | no | NA | Merck & Co
Niccoli | OA of the hand, hip or knee | 25 | diclofenac 50 mg tid | 90 | 2 | nr | PGA, pain | nr | nr | No difference | method NR | NR | yes | yes | NR | NR | NR | no/no/no/no | no | unclear; only mean values reported | no | fair | 96/NR/90 | Patients who appeared unreliable/uncooperative; severe CV, hepatic or renal disorders; GI bleeding or peptic ulcer; history of hypersensitivity to NSAIDs; concomitant drugs use such as antihistamines, antibiotics, other NSAIDs, corticosteroids, mucolytics, anticoagulants, antiplatelets or other potentially nephrotoxic drugs; pregnant or lactating; previous abnormalities in renal function. | NR | no | NA | NR
Saag | OA of knee or hip and flare (for NSAID users) or acetominophen user. Excluded aspirin 81mg users. | 12.5, 25 | ibuprofen 800 tid | 667 | 6 | No | WOMAC, PGA, pain while walking | [underlined: 7.8% (12.5 mg) 4.0% (25 mg)] | 8.6% | No difference | yes | yes | yes | yes | NR | NR | yes | no/no/no/no | no | no for efficacy, yes for safety | no | good | 2065/NR/14 29 | Use of corticosteroids, topical analgesics, low-dose aspirin, regular antacid, H2 blocker, PPIs, warfarin, or ticlopidine; significant renal impairment; active GI bleeding; GI malabsorption syndrome; class III/IV angina or CHF; uncontrolled hypertension; stroke; transient ischemic attack; active hepatic disease; allergy to acetaminophen or NSAIDs. | NR | no | NA | Merck & Co
Saag | OA of knee or hip and flare (for NSAID users) or acetominophen user. Excluded aspirin 81mg users. | 12.5, 25 | diclofenac 50 tid | 693 | 52 | No | WOMAC, PGA, pain while walking | [underlined: 12.1% (12.5 mg) 11.2% (25 mg)] | 7.0% | No difference
Truitt | OA of knee or hip | 12.5, 25 | nambumetone 1500 qd | 341 | 6 | No | PGA, WOMAC | 1.7% (12.5 mg) 0% (25 mg) | 1.7% | No differences

OA - osteoarthritis; FOBT - fecal occult blood test; PGA - patient global assessment;PGART Patient Global Response to Therapy Questionnaire WOMAC - Western Ontario and McMaster Universities Osteoarthritis Index; EGD - esophagogastroduodenoscopy; RA - rheumatoid arthritis

* Excludes subjects randomized to placebo

** If underlined, for lack of efficacy; otherwise, for all reasons

† Willow bark extract containing 15% salicin, total dose 240mg of salicin a day

Evidence Table 04[1]

VIGOR vs CLASS Trials

a) Evidence table
Trial | Sites | Patients | Aspirin use | Definition of significant GI events | Number screened/enrolled | Number analyzed | Withdrew for lack of efficacy (Coxib group/NSAID groups)^*^
VIGOR (rofecoxib 50mg qd) | 301 centers, 22 countries | RA, over 50 | Not allowed | Perforation, obstruction, upper GI bleeding, or symptomatic ulcer | 9539/8076 | 8076 | 6.3%/6.5%
CLASS (celecoxib 400mg bid) | 386 centers, US and Canada | RA or OA, 18 or older | 20% | Perforation, obstruction, upper GI bleeding | 9764/8059 | 7968 | 12.6%/14.8%
b) Comparison of outcomes
| VIGOR NSAID group^**^ | CLASS NSAID group^†^ | VIGOR NNT | CLASS NNT †
ulcers | 0.030 | 0.011 | 62 | 265
perforation | 0.001 | 0.000 | no effect | no effect
obstruction | 0.000 | 0.000 | no effect | no effect
bleeding from an ulcer | 0.008 | 0.008 | 268 | 199
Complicated confirmed UGI events | 0.009 | 0.008 | 191 | 199

* In VIGOR, there was no difference

RA - rheumatoid arthritis; GI - gastrointestinal; OA - osteoarthritis; NNT - number needed to treat; UGI - upper gastrointestinal

** average 9 months of followup

† adjusted to replicate 9 months of followup

Evidence Table 05[1]

GI Safety in observational studies

Author, Year Sample size | Population | Duration (days) | Celecoxib mean dose (mg) | Rofecoxib mean dose (mg) | NSAIDs dose (mg) | Aspirin permitted | Outcome | Reference comparison | Celecoxib | Rofecoxib | NSAIDs | Subgroup information? | Notes
Garcia-Rodriguez 2001 UK General Practice Research Database Cases: 2,105 | Patients with codes for upper GI complications | Mean NR | n/a | n/a | Dosage NR | NR | Codes for upper GI complications (bleed/perforation in stomach or duodenum; clinical diagnosis of peptic ulcer with referral to consultant or admitteospd to a hital); Adjusted relative risk (95% CI) | Nonuse | n/a | n/a | Etodolac: 2.2 (0.4–11.3) Ibuprofen: 2.5 (1.9, 3.4) Ketoprofen: 3.3 (1.9, 5.9) Nabumetone: 3.4 (1.1, 10.6) Tenoxicam: 3.4 (0.9, 13.1) Meloxicam: 3.8 (0.8, 17.2) Naproxen: 4.0 (2.8, 5.8) Diclofenac: 4.6 (3.6, 5.8) Flurbiprofen: 4.6 (2.0, 10.9) Indomethacin: 5.2 (3.2, 8.3) Piroxicam: 6.2 (3.7, 10.1) | Dose: All individual NSAIDs presented an RR < 4 when administered at low/medium doses and a greater RR with increasing dose | Etodolac, nabumetone, meloxicam: risk estimates compatible with average NSAID; data were scarce and this resulted in wide CI’s
Hippisley-Cox 2005 Case-control QRESEARCH database (8/1/00- 7/31/04) Cases: 9407 | Aged ≥ 25 with first ever upper GI event and ≥ 3 yrs of recorded medical data | Unclear | NR | NR | (A) Selective NSAIDs (B) Ibuprofen C) Diclofenac (D) Naproxen (E) Non-selective | NR | Complicated GI event (those involving hemorrhage, perforation, or surgery): Adjusted Odds Ratio (95% CI) | No NSAID use | 1.25 (0.91, 1.72) | 1.79 (1.42, 2.26) | (A) 1.72 (1.29, 2.29) (B) 1.58 (1.37, 1.83) (C) 2.07 (1.82, 2.35) (D) 1.97 (1.48, 2.61) | [underlined: Rofecoxib] Aspirin use: 2.98 (2.24, 3.99) No aspirin use: 1.22 (0.97, 1.54) | # pts taking celecoxib was low
Kasliwal 2006 National Health Service prescription data (England)Rofe coxib n=15,268Celec oxib n=17,458 | Patients for whom a completed questionnaire was returned among GP- dispensed prescriptions for rofecoxib between July and November 1999 (mean age=62.5 years) and for celecoxib between May and December 2000 (mean age=62.2 years) | Events occuring whilst taking drug or within 7 days of stopping drug during 9 months since start of treatment; when not known if patient was taking drug at the time of the event, only those events that had occurred within 30 days after treatment was started were included | NR | NR | n/a | Aspirin and antiplatelet/antico agulant agentsRofecoxib =35.3%Celecoxi b=21.9%p<0.000 1 | Complicated upper GI conditions (perforations/bleeding) | Celecoxib | n/a | RR (95% CI) Crude: 1.52 (1.02, 2.27) Adjusted for age, age2 and sex: 1.58 (0.96, 2.58) Adjusted for NSAIDs prescribed within 3 months before starting coxib: 1.55 (1.02, 2.38) Adjusted for age, age2, sex, NSAIDs prescribed within 3 months before starting coxib: 1.60 (0.95, 2.70) | n/a | Increased risk of bleeding with age and use of concomitant drugs that increase risk of bleeding
Laporte 2004 Hospitals in Spain and Italy Cases=2,8 13 | Patients aged > 18 years admitted with primary diagnosis of acute upper GI bleeding | NR | n/a | NR | (A) Diclofenac (B) Ibuprofen (C) Indomethacin (D) Ketoprofen (E) Ketorolac (F) Meloxicam (G) Naproxen (H) Nimesulide (I) Piroxicam | NR | Upper GI bleeding (odds ratio, 95% CI) | Nonuse | n/a | 7.2 (2.3, 23.0) | (A) 3.7 (2.6, 5.4)(B) 3.1 (2.0, 4.9)(C) 10.0 (4.4, 22.6)(D) 10.0 (3.9, 25.8)(E) 24.7 (8.0, 77.0)(F) 5.7 (2.2, 15.0)(G) 10.0 (5.7, 17.6)(H) 3.2 (1.9, 5.6)(I) 15.5 (10.0, 24.2) | Risk increased with dose, history of peptic ulcer and/or upper GI bleeding, and use of antiplatelet drugs | Excluded patients on anticoagulants
Layton 2003a National Health Service prescription data n=34,355 | Patients exposed to meloxicam between 12/1996 and 3/1997 (mean age=60.4 yrs) and rofecoxib between 5/2000 and 12/2000 (mean age 62.5) | 270 | n/a | NR | Meloxicam | NR | Complicated upper GI conditions (perforations/bleeding) (Adjusted Rate Ratio, 95% CI) | Meloxicam | n/a | 0.91 (0.59, 1.42 | n/a | Significant association with age, but not sex or past medical history of upper GI problems
Layton 2003a National Health Service prescription datan=36,545 | Patients exposed to meloxicam between 12/1996 and 3/1997 (mean age=60.4 yrs) and celecoxib between 5/2000 and 12/2000 (mean age 62.2) | 264 | ≤ 200 mg taken by 83.9% pts with complicated upper GI events | n/a | Meloxicam | NR | Perforations/bleeding | Meloxicam | Adjusted RR=0.56, 95% CI 0.32, 0.96 | n/a | n/a
Mamdani 2002 Cohort Ontario healthcare administrative database n=143,969 | Aged ≥ 66 (mean=75.7), NSAID- naïve | 141 | NR >200 mg: 19% | NR >25 mg: 8% | Nonselective NSAIDs Diclofenac+mi soprostol | 13.50% | Upper GI hemorrhage (adjusted risk ratio, 95% CI, NNH) | (A) Treatment vs nonuse (B) Nonselective NSAIDs vs COX-2 (C) Diclofenac+misoprostol vs COX-2 (D) Rofecoxib vs celecoxib | (A) 1.0 (0.7, 1.6) (B) 4.4 (2.3, 8.5) (C) 3.2 (1.6, 6.5) | (A) 1.9 (1.3, 2.8); NNH=1389 (B) 1.9 (1.0, 3.5) (C) 1.4 (0.7, 2.7) (D) vs celecoxib 1.9 (1.2, 2.8) | Nonselective NSAIDs vs nonuse: 4.0 (2.3, 6.9); NNH=403 Diclofenac+misoprostol vs nonuse 3.0 (1.7, 5.5); NNH=592 | Age, gender, and history of GI hemorrhage had no effect | Has income, previous GI hemorrage info
Mann 2004 43 long-term care and assisted living facilities receiving consultative pharmacy services by Cornerstone Pharmacy Services n=1,198 | Use of NSAID or COX-2 inhibitor therapy from 1/2002– 2/2003; mean age=81.2 | 352 | NR | NR | (A) Ibuprofen (B) Naproxen (C) Nabumetone (D ) Meloxicam (E) Salsalate | 26.2% patients | Hospitalization due to GI bleed | None - crude rates only | 6/679 (0.9%) | 6/279 (2.2%) | (A) 0(B) 5/63 (7.9%)(C) 1/22 (4.5%)(D) 0(E) Salsalate (1/17 (5.6%) | | % patients:Anticoagulant use=11.3%Cigarette smoking=4.6%Poor quality; no adjustment for baseline differences
Norgard 2004 County Hospital Discharge Registry of North Jutland County/Pharm aco- Epidemiologica l Prescription Database of North Jutland Cases: 780 | First incident cases of upper gastrointestinal bleeding in patients with previous upper gastrointestinal disorders | Mean NR | NR | NR | NR | NR | First incident upper gastrointestinal bleeding (adjusted odds ratio) | Nonuse | 1.3 (0.7, 2.8) | 2.1 (1.2, 3.5) | “Other NSAIDs”: 3.3 (2.4, 4.4) | Rofecoxib associated with significantly higher risk of GI bleed in men (OR 2.1; 95% CI 1.0, 4.6), but not women (OR 2.0; 95% CI 0.9, 4.4)
Weideman 2004 Dallas Veterans Affairs Medical Center N=16,286 | Patients who received naroxen or etodolac between 1/1/99 and 12/31/01; mean age=56.4 years; 89.5% male | NR | n/a | n/a | (A) Etodolac ≥ 800 mg (average=885 mg) (B) Naproxen ≥ 1000 mg (average=1054 mg) | ≤ 325 mg | Clinically significant upper GI event (perforation, obstruction, bleeding, symptomatic ulcer) (Adjusted odds ratio; 95% CI) | n/a | n/a | n/a | Etodolac vs Naproxen: [underlined: Not taking aspirin] All: 0.24 (95% CI 0.09, 0.63) NSAID-naïve: 0.18 (0.05, 0.61) [underlined: Taking aspirin] All: 0.75 (0.28, 1.99) NSAID-naïve: 1.24 (0.35– 4.42) | See previous cell

Evidence Table 06[1]

CV Safety in observational studies

Author, Year Data source Sample size | Population | Exposure (days) | Celecoxib dose (mg) | Rofecoxib dose (mg) | Other NSAIDs dose (mg) | Aspirin permitted | Outcome | Reference comparison | Celecoxib | Rofecoxib | NSAIDs | Subgroup information? | Notes
Andersohn 2006 UK General Practice Research Database (GPRD) Cases=3,643 | Diagnosis of AMI, death from AMI, or sudden death from coronary heart disease (CHD); aged ≥ 40 years≥ with ensured quality standards of data recording for ≥ 1 year | Average=542 days; exposure defined as quantity of prescribed tablets by the number of tablets to be taken daily; “current”=NSAID prescription lasting into 14- day period before index date; “recent” = supply ended 15–183 days before index date; “past” = supply ended between 184 days and 1 year before index | Mean NR | Mean NR | Etoricoxib Valdecoxib Diclofenac Ibuprofen Naproxen | NR | Diagnosis of AMI, death from AMI, or sudden death from coronary heart disease (CHD) (Adjusted RR; 95% CI) | Nonuse | 1.56 (1.23, 1.98) | 1.33 (1.06, 1.67) | Etoricoxib: 2.02 (1.08, 3.80) Valdecoxib: 4.26 (0.60, 30.27) Diclofenac: 1.36 (1.17, 1.58) Ibuprofen: 1.00 (0.83, 1.21) Naproxen: 1.16 (0.86, 1.58) | Risk increased with dose for celecoxib, etoricoxib, and rofecoxib. No significant interaction with age, gender, or presence of risk factors
Graham 2005 State of California Kaiser Permanente health care database Cases=8,143 | Age 18–84 years who filled ≥ 1 prescription for celecoxib, rofecoxib or any other non- selective NSAID; ≥ 12 months of health plan coverage before index prescription date; 1/1/99- 12/31/01; mean age=66.9; 62% male | Mean=113 days before event | NR | (A) all doses (B) ≤ 25 mg (C) > 25 mg | (A) Ibuprofen (B) Naproxen (C) Other NSAIDs | Random sample of n=817 cases participated in phone interview and 23% reported using cc aspirin | Acute MI requiring admission or sudden cardiac death | Celecoxib | n/a | (A) 1.59 (1.10, 2.32)(B) 1.47 (0.99, 2.17)(C) 3.58 (1.27, 10.11) | (A) 1.26 (1.00, 1.60)(B) 1.36 (1.06, 1.75)(C) 1.35 (1.06, 1.72) | 3.8% taking anticoagulants
Harrison-Woolrych 2005 New Zealand Intensive Medicines Monitoring Programme (IMMP) Interim analysis of 11,149 of 58,849 for who follow-up was complete | All patients who received a prescription between 12/1/00 and 11/30/01; patients who changed medicines were included in both groups | Duration to event (through 11/30/04); period to last follow-up questionnaire; date of stopping medication; or expiration of final prescription | 100 mg=7.1% 200 mg=81.6% 400 mg=10.9% Other=0.4% | 12.5=24.3% 25 mg=64.5% 50 mg=11% Other=0.2% | n/a | NR | Thrombotic cardiovascular events identified from several different sources (questionnaires, hospital admission data, spontaneous reports, prescription data, national morbidity and mortality databases) (Hazard Ratio adjusted for age) | Rofecoxib | 0.94 (95% CI 0.51, 1.70) | n/a | n/a | No dose effect
Hippisley-Cox 2005 Case- control QRESEARCH database (8/1/00- 7/31/04) Cases: 9218 | All patients aged 25 to 100 with a first ever MI; 63.1% male | NR | NR | NR | (A) Other selective NSAIDs (B) Ibuprofen (C) Diclofenac (D) Naproxen (E) Other non- selective NSAIDs | yes, but proportion NR | First ever MI (Adjusted odds ratio, 95% CI) | No use | 1.21 (0.96, 1.54) | 1.32 (1.09, 1.61) | (A) 1.27 (1.00, 1.61)(B) 1.24 (1.11, 1.39)(C) 1.55 (1.39, 1.72)(D) 1.27 (1.01, 1.60)(E) 1.21 (1.02, 1.44) | No interactions between any NSAID and aspirin use or coronary heart disease; smoking and BMI interacted only with naproxen; age 65 and over only interacted with other non-selective NSAIDs | Adjusted for smoking, obesity, deprivation, aspirin
Hudson 2005Database of hospital discharge summaries (4/1/00- 3/31/02)n=1866 | Aged > 66 with known heart failure (no hospitalizations in last 3 years) | 352 | NR | NR | Any NSAID | Yes, in 1006 (53.9%) | Hazard Ratio, 95% CI(A) Recurrent HF (B) Death(C) Death OR recurrent HF (Primary outcome) | COX-2 | NSAIDs vs celecoxib:(A) 1.21 (0.92, 1.60)(B) 1.54 (1.17, 2.04)(C) 1.26 (1.00, 1.57) | NSAIDs vs rofecoxib: (A) 1.04 (0.80, 1.36)(B) 1.07 (0.82, 1.39)(C) 0.99 (0.80, 1.22) | n/a | NR
Johnson 2005 Denmark National Health Service registries Cases=10,280 | First diagnosis of MI; living in counties for ≥ 1 year; aged ≥ 20 years (mean age=69.6 years); 60.4% male; 1/1/00- 12/31/03 | NR | NR | NR | (A) Naproxen (B) other nonaspirin NSAID | 6.9% high dose | Acute MI (Relative risk, 95% CI) | Nonuser | Current user: 1.25 (0.97, 1.62); new user: 2.13 (1.45, 3.13) | Current user: 1.80 (1.47, 2.21); new user: 2.52 (1.45, 3.13) | (A) Current user: 1.50 (0.99, 2.29); new user: 1.65 (0.57, 4.83) (B) Current user: 1.68 (1.52, 1.85); new user: 2.65 (2.00, 3.50) | 13.7% CV disease; 2.2% cc anticoagulant use; rofecoxib was associated with increased risk regardless of baseline risk status
Kasliwal 2006 National Health Service prescription data (England) Rofecoxib n=15,268 Celecoxib n=17,458 | Patients for whom a completed questionnaire was returned among GP- dispensed prescriptions for rofecoxib between July and November 1999 (mean age=62.5 years) and for celecoxib between May and December 2000 (mean age=62.2 years) | Events occuring whilst taking drug or within 7 days of stopping drug during 9 months since start of treatment; when not known if patient was taking drug at the time of the event, only those events that had occurred within 30 days after treatment was started were included | NR | NR | n/a | Aspirin and antiplatelet/anticoagulant agents Rofecoxib=35.3% Celecoxib=21.9% p<0.0001 | (a) Cardiovascular TE (b) Cerebrovascular TE (c) Peripheral venous (DVT/PE) | Celecoxib | n/a | aRR (95% CI) (adjusted for age, age2, sex, and concomitant use of the combination of aspirin and/or antiplatelet/anticoagulant agents (a) 1.04 (0.50, 2.17) (b) 1.43 (0.86, 2.38) (c) 0.36 (0.01, 1.34) | n/a | (a) increased risk associated with age, sex, cc aspirin use, cc antiplatelet/anticoagulant agents (b) increased risk with all but sex (c) increased risk with the cc meds
Kimmel 2005 Hospitals in 5- county region (telephone interview) Cases: 1718 | Persons aged 40 to 75 years hospitalized for first, nonfatal MI | NR | NR | NR | (A) Ibuprofen or diclofenac (B) Naproxen | 33.60% | Nonfatal MIOdds ratio (95% CI) | Nonselective NSAIDS | (A) 0.77 (0.40, 1.48) (in aspirin and nonaspirin users - like CLASS)(B) 0.81 (0.37, 1.77) | (B) 3.30 (1.37, 8.40) (among nonaspirin users - like VIGOR)(A) 2.04 (1.16, 3.60) | n/a
Langman 2004 MediPlus (UK) database of general clinical practices N=18,737 | Men or women aged ≥ 50 years that were new users of any drug-of-interest (with ≥ 1 prescription) during the period 1/1/00 - 12/31/00 | 180 | n/a | NR | (A) diclofenac (B) ibuprofen (C) naproxen | NR | Initiation of antihypertensive medication (odds ratio, 95%) CI) | Rofecoxib | n/a | Combined non-selective NSAIDs vs rofecoxib: Overall=0.93 (0.73, 1.18); chronic and persistent users=1.07 (0.71–1.61)
Layton 2003 National Health Service prescription data N=34,355 | Patients exposed to meloxicam 12/96-3/97 (n=19,087); rofecoxib 7/99- 9/99 (n=15,268) | 270 | NR | NR | Meloxicam | NR | Thromboembolic events: (A) cardiovascular (B) cerebrovascular (C) peripheral venous thrombotic | Meloxicam | n/a | vs meloxicam: (A) 1.38 (0.71, 2.67) (B) 1.68 (1.15, 2.46) (C) 0.29 (o.11, 0.78) | n/a | Significant association between age, sex and time, respectively, and event rates | Only adjusted for age and sex
Levesque 2005 Computerized health insurance and vital statistics databases of Quebec, Canada n=59724 | ≥ 66 years of age prescribed an NSAID or COX-2 who’ve never had an MI | 844.8 | (A) All (B) Low: ≤ 200 mg (C) High: >200 mg | (A) All (B) Low: ≤ 25 mg (C) High: > 25 mg | (A) Naproxen (B) Meloxicam | 22.50% | Acute MI, fatal or nonfatal | NSAID nonusers | (A) 0.99 (0.85, 1.16) (B) 0.98 (0.83, 1.17) (C) 1.00 (0.78, 1.29) | (A) 1.24 (1.05, 1.46) (B) 1.21 (1.02, 1.43) (C) 1.73 (1.09, 2.76) | Naproxen 1.17 (0.75, 1.84) Meloxicam 1.06 (0.49, 2.30) | aspirin mitigates risk for low-but not high-dose rofecoxib use
Mamdani 2003 Ontario healthcare administrative database N=166,964 | NSAID-naïve patients aged ≥ 66 years of age prescribed an NSAID or COX- 2 | 165.6 | NR | NR | (A) Naproxen (B) Nonnaproxen nonselective NSAIDs | 14.70% | Incidence of hospitalization for acute MI | General non-NSAID using population (adjusted risk ratio, 95% CI) | 0.9 (0.7, 1.4) | 1.0 (0.8, 1.4) | (A) 1.0 (0.6–1.7) (B) 1.2 (0.9, 1.4)
Mamdani 2004 Ontario healthcare administrative database 4/17/00-3/31/01 N=145097 | NSAID-naïve patients aged ≥ 66 years of age prescribed an NSAID or COX- 2 | 140 | NR | NR | Non-selective NSAID users | NR | Admission for CHF (risk ratio, 95% CI) | COX-2 | Non-selective NSAID vs celecoxib: 1.4 (1.0, 1.9) | Non-selective NSAID vs rofecoxib: 1.5 (1.1, 2.1) | vs non-NSAID users: 1.4 (1.0–1.9) | History of heart failure admission w/I past 3 years increased risk
Ray 2002Tennessee Medicaid program database1/1/99-6/30/01 | Aged 50–84 (mean=61.5); eligible for TennCare benefits for past 365 days; not in a nursing home; no history of non-CV life-threatening illness; new users | NR | NR | (A) ≤ 25 mg(B) > 25 mg | (A) Ibuprofen(B) Naproxen | NR | Serious CHD (hospital admission for AMI or death from CHD) | Nonusers | 0.96 (0.76–1.21) | (A) 1.03 (0.78, 1.35)(B) 1.70 (0.98, 2.95) | (A) 0.91 (0.78, 1.06(B) 0.93 (0.82, 1.06) | NR
Schlienger 2002 UK General Practice Research Database (GPRD) Cases=3,315 | First-time diagnosis of acute myocardial infarction (AMI) between January 1, 1992 and October 31, 1997; ≤ 75 years of age; free of metabolic or cardiovascular diseases predisposing to AMI; registered on the database for at least 3 years before the index date | NR | n/a | n/a | Ibuprofen Diclofenac Piroxicam Ketoprofen Indomethacin Flubiprofen Naproxen | Yes | First-time diagnosis of acute myocardial infarction (AMI) (Adjusted Odds Ratio; 95% CI) | Nonuse | n/a | n/a | Ibuprofen: 1.17 (0.87, 1.58) Diclofenac: 1.38 (1.08, 1.77) Piroxicam: 1.65 (0.78, 3.49) Fenbufen: 2.06 (0.80, 5.30) Ketoprofen: 1.39 (0.77, 2.51) Indomethacin: 1.03 (0.58, 1.85) Fluriprofen: 2.26 (0.93, 5.46) Naproxen: 0.68 (0.42, 1.13) | Current use of aspirin at the index date and longer-term use of HRT in women interacted with AMI risk; exposure duration, age, and gender did not.
Shaya 2005 Medicaid database N=6,250 | Enrollees who received ≥ 1 prescription for an NSAID between 1/1/00 and 6/30/02; 70% female; 50% African American; 70% were aged 50 years or younger | ≥ 60 prior to event | NR | NR | Other NSAIDs (excluding naproxen) | NR | Cardiovascular thrombotic events (odds ratio, 95% CI) | Other NSAIDs (excluding naproxen) | 1.19 (0.93, 1.51) | 0.99 (0.76, 1.30) | n/a
Solomon 2002 New Jersey Medicaid or Medicare and Pharmaceutical Assistance for the Aged and Disabled programs | Patient hospitalized with a main diagnosis of AMI with continuous use of the aforementioned benefit programs for ≥ 180 days before index date; excluded patients with any diagnoses that might have been managed with aspirin | 6 months prior to index date was primary exposure of interest | n/a | n/a | Naproxen, ibuprofen, ketorolac, indomethacin, sulindac, oxaprozin, diclofenac, fluriprofen, etodolac, ketoprofen, nabumetone, piroxicam, fenoprofen, tolmetin; dosages NR | No | Acute MI - Odds Ratio (95% CI) | Nonuser (control) | n/a | n/a | Comparison of specific NSAID use only reported for: Naproxen: OR 0.84 (0.72–0.98)Etodolac: OR 1.28 (1.00–1.64)Fenoprofen: OR 1.95 (1.16, 3.30)Ibuprofen: OR 1.02 (0.88, 1.18) | No dose-or duration-response relationship
Solomon 2004 Chart review of prescription drug benefit program participants Cases=10,895 | Low-income, elderly, Medicare beneficiaries who had at least 1 healthcare visit in each 6-month period; mean age > 80 years | 1–30 days 31–90 days > 90 days | ≤ 200 mg >200 mg | ≤ 25 mg > 25 mg | (A) Naproxen (B) Ibuprofen (C) Other NSAIDs | NR | Acute MI | NSAID | (A) 0.95 (0.74, 1.21) (B) 0.98 (0.76, 1.26) | (A) 1.17 (0.90, 1.52) (B) 1.21 (0.92, 1.58) | n/a | Dose had an effect for rofecoxib but not celecoxib; couldn't adjust for aspirin use
Solomon 2004 Medicare Prescription Drug Benefit Program databases through Pennslyvania Pharmaceutical Assistance Contract for the Elderly (PACE) or the New Jersey Pharmaceutical Assistance Program for the Aged and Disabled (PAAD) (both programs for elderly individuals with low-moderate income levels) Cases=3,915 | Active users of prescription drug benefit program for 2 consecutive years out of the 3-year period (1998–2000) with no prior diagnosis of hypertension and no use of antihypertensive medications; mean age=79 | Short=1–30 Long=31–90 | Low: ≤ 200 mg High: >20 mg | Low: ≤ 25 mg High: > 25 mg | Nonspecific NSAID | NR | New onset hypertension and the filling of at least 1 antihypertensive medication prescription | (A) nonspecific NSAID (B) no NSAID | (A) 0.9 (0.7, 1.1) (B) 1.0 (0.9, 1.2) | (A) 1.4 (1.1, 1.9) (B) 1.6 (1.3, 2.0) | n/a | Dose, duration had no effect; but presence of renal disease, liver disease, or congestic heart failure appeared in increase risk for rofecoxib users
Velentgas 2005 Insurance claims/administrative records of UnitedHealthcare N=424,584 | Patients aged 40–64 who received at least one dispensing of rofecoxib, celecoxib, naproxen, ibuprofen, or diclofenac in oral tablet or capsul from 1/1/99 to 6/30/01 | Mean=5.1 months | 200 mg (modal) | 25 mg (modal) | Naproxen 1000 mg (modal) | NR | Primary: Combined endpoint of acute coronary syndrome and myocardial infarction (adjusted rate ratio) | Ibuprofen or diclofenac | Current: 1.03 (0.83, 1.27)Recent: 0.91 (0.70, 1.17) | Current: 1.35 (1.09, 1.68)Recent: 1.15 (0.88, 1.50) | NaproxenCurrent: 1.15 (0.93, 1.39)Recent: 0.86 (0.70, 1.04) | No dose-relationship; increased risk for males and for individuals with a cardiac history, peripheral arterial disease, diabetes, beta blocker use, nitrate use

Evidence Table 07[1]

Trials of etoricoxib and lumiracoxib (Safety only)

Author Year (Quality Score) | Eligibility criteria | Interventions (drug, dose, duration) | Run-in/Washout Period | Allowed other medications/interventions | Method of Outcome Assessment | Timing of Outcome Assessment | Age Gender Ethnicity | Other population characteristics (diagnosis, etc) | Number screened/eligible/enrolled | Number withdrawn/lost to fu/analyzed | Results | Notes | Randomization adequate? | Allocation concealment adequate? | Groups similar at baseline? | Eligibility criteria specified? | Outcome assessors masked? | Care provider masked? | Patient masked? | Reporting of attrition, crossovers, adherence, and contamination | Loss to follow-up: differential/high | Intention-to- treat (ITT) analysis | Post- randomization exclusions | Quality Rating | Funding | Number screened/eligible/enrolled | Exclusion criteria | Run-in/Washout | Class naïve patients only | Control group standard of care | Funding
Etoricoxib studies
Baraf, et al 2004 fair (abstract only) | Knee, hip, hand or spine OA patients | etoricoxib 90 mg/day vs diclofenac 50 mg tid | NR | use of "routine" medications allowed - definition of "routine" not specified | Primary: discontinuations due to clinical or lab GI AEs Secondary: patient global assessment using 4-point Likert scale | Baseline and months 1, 4, 8, 12 | mean age 64 yrs gender NR ethnicity NR | | NR/ NR/ 7111 | NR/ NR/ NR | Cumulative discontinuations due to GI events lower with etoricoxib v diclofenac - 9.4 v 19.2 events/100 patient yrs (RR 0.5 95% CI: 0.43, 0.58; p < 0.001)
Curtis, et al 2005 | <40 yrs with clinical and radiographic evidence of knee OA for at least 6 mos | etoricoxib 30, 60 or 90 mg/day dicofenac 150 mg/day | Discontinuation of previous therapy; time-frame not specified | NR | Efficacy: WOMAC and Investigator Global Assessment of Disease Status Safety: Clinical AEs determined by investigator | During active-comparator phase (wks 6–52) assessed at wks 6, 8, 14, 20, 26, 34, 42, 52 | mean age 61.8 yrs 72% women 89% white | 67.4% of patients ARA Function Class II | NR/ 617/ 550 | 262/ NR/ 550 | A higher percentage of diclofenac patients (22.5%) reported GI symptoms and discontinuted (4%) due to GI symptoms vs all etoricoxib doses (13.1% and 0% at 30mg/day, 14.7% and 1 % at 60 mg/day, 13.5% and 1.4% at 90 mg/day respectively) Only other AE which showed difference was lower extremity edema: higher with etoricoxib- 30 mg/day 4.5%; 60 mg/day 3.9%; 90 mg/day 3.4% and lowest with diclofenac 2.0% | | yes | yes | yes | yes | unclear (“study staff” reported as blinded) | unclear (“study staff” reported as blinded) | yes | no/yes/no/no | no | unclear, only mean percentages reported | no | fair | Merck & Co. | NR/NR/550 | Significant renal impairment; clinically significant abnormalities on screening physical or lab examinations; class III/IV angina or uncontrolled CHF; uncontrolled hypertension; stroke or tranisient ischemic heart disease within 2 yrs; active hepatic disease; recent neoplastic disease; acute meniscal injury to the study joint within 2 yrs; arthroscopy in study joint within 6 mos; weight in excess of 280 lbs; allergy to acetaminophen or NSAIDs; use of systemic corticosteroids, warfarin, low-dose aspirin, ticlopidine, intra-articular steroids; previous AE associated with topical analgesic use. | NR/NR | no | NA | Merck & Co.
van der Heijde, et al 2004 | AS patients meeting modified NY criteria; >18 yrs; diagnosis ≥ 6 mos prior to study; previous NSAID responder; routine NSAID use (25 of 30 days preceding study); use of approved antirheumatic therapy at a stable does for 3–6 mos; experiencing AS flare | etoricoxib 90 or 120 mg/day naproxen 1000 mg/day | NSAID washout, time not specified | acetaminophen | Primary endpoints: VAS and Bath Ankylosing Spondylitis Functional Index Secondary endpoints: patient's assessment using 4 pt Likert | Baseline and wks 2, 4, 6, 8, 16, 26, 34, 43, 52 | mean age 43.6 yrs 22.2% women ethnicity NR | History of iritis 33.6%; chronic peripheral arthritis 40.1%; corticosteroid use 25.3%; concomitant DMARD use 22.25% | 500/ 387/ 374^*^ (number of patients who entered second long- term phase of study wks 6- 52) | 90/NR/374 | Rates of serious AEs were similar (7.6%, 7.2% and 7.7% for etoricoxib 90mg, 120mg and naproxen 1000mg respectively) However, 2% of patients experienced serious CV AEs - all were etoricoxib patients (4, 90mg/day; 1, 120 mg/day) | | yes | yes | yes | yes | NR | NR | yes | no/no/no/no | no | no | no | fair | NR | NR/NR/374 | Concurrent rheumatic disease that could confound efficacy; pts with acute peripheral articular disease; chronic peripheral arthritis; use of corticosteroid therapy within 1 mo; use of analgesics within 3 days through wk 6 of study; use of non-study NSAID or COX-2. | NR/washout length not specified | no | NA | NR
Lumiracoxib
Schnitzer, et al 2004 TARGET study good | Patients ≥ 50 yrs with hip, knee or hand OA according to ACR criteria or radiographically confirmed cervical or lumbar spine OA | lumiracoxib 400 mg/day naproxen 500 mg bid ibuprofen 800 mg tid 52 wks | NR | 1) paracetamol ≤2g/day 2) up to 2 two-week periods of systemic corticosteroid therapy 3) one hyaluronic acid injection 4) up to 3 corticosteriod injections at least 8 wks apart and more than 4 wks prior to study assessment 5) up to 2 non-consecutive 3 wk courses of low-dose (equivalent of famotidine 30 mg/day) H2 receptor antagonists at least 4 wks between courses 6) up to 8 antacid tablets/day^*^ | Primary endpoint of study: time-to-event distribution of definite or probable upper GI complications in patients not taking low-dose aspirin Secondary GI endpoint: time-to-event in patients taking low-dose aspirin and time-to-event of other GI events including 1) complicated and symptomatic upper GI ulcers; 2) symptomatic upper GI ulcers; 3) major episodes of GI bleeding; 4) evidence of anemia^*^ CV endpoint: time-to-event of Antiplatelet Trialists' Collaboration (APTC) endpoint (composite of nonfatal MI, nonfatal stroke or CV-related death, adjucated as confirmed or probable)^*^ Renal endpoint: time-to-event of clinically relevant lab abnormalities, defined as serum creatinine elevations ≥100% from baseline and/or proteinuria ≤ 3g/L^*^ Hepatic endpoint: time-to-event of elevations in ALT > 5 x ULN and/or AST > 5 x ULN with total bilirubin elevations > 30 mg/L, adjucated as probably or possibly related to study medication^*^ Tolerability endpoint: all serious and non-serious AEs, lab measures, time to discontinuation for any reason and time to discontinuation due to AEe^*^ | Study visits at wks 4. 13. 26. 39, 52 and 4 wks post-study Patient assessed pain using 5- point Likert scale at wks 13, 26, 39, 52; physician and patient assessed disease activity using 5- point Likert scale | mean age 63.5 yrs 76% women ethnicity NR | | 21,787/ 18,325/ 18,244 | 7161/ 40/ 18,244 | GI: Risk of any upper GI AE - lumiracoxib v NSAIDS (naproxen and ibuprofen) in aspirin and non-aspirin patients: .32 lumiracoxib patients v .91 NSAID patients HR 0.34 (0.22- 0.52) CI 95%; p < 0.0001. CV: No SS differences, however lower risk of MI with naproxen v lumiracoxib (HR 1.77 (0.82–3.84); p=0.1471) and higher risk of MI with ibuprofen v lumiracoxib (HR 0.66 (0.21- 2.09); p = 0.4833) Renal: No SS difference b/t lumiracoxib and NSAIDs for renal endpoint or serious liver AEs. SS difference in transaminase concentrations 3x above upper limit of normal between lumiracoxib and NSAIDs (HR 3.97 (2.96–5.32); p<0.0001) Transaminase concetrations were reversed upon drug discontinuation. | Supratherapeutic dose of lumiracoxib used (2–4 × greater than typical OA dosage) Farkouh ME. Kirshner H. Harrington RA. Ruland S. Verheugt FW. Schnitzer TJ. Burmester GR. Mysler E. Hochberg MC. Doherty M. Ehrsam E. Gitton X. Krammer G. Mellein B. Gimona A. Matchaba P. Hawkey CJ. Chesebro JH. TARGET Study Group. Comparison of lumiracoxib with naproxen and ibuprofen in the Therapeutic Arthritis Research and Gastrointestinal Event Trial (TARGET), cardiovascular outcomes: randomised controlled trial.[see comment]. Lancet. 364(9435):675–84, 2004 Aug 21–27. provides a more detailed analysis of CV events, however same data is used. | yes | yes | yes | yes | yes | yes | yes | no/no/no/no | no | no for efficacy; yes for safety | no | good | Novartis Pharma AG, Switzerland | 21,787/NR/18,325 | Use of PPIs, misoprostol or full-dose H2 agonists; active upper GI ulceration in previous 30 days; upper GI bleeding within 1 yr; history of gastroduodenal perforation or obstruction; history of MI, stroke, coronary bypass graft, invasive coronary revascularization, new- onset angina within previous 6 mos; ECG evidence of recent silent MI; severe CHF. | NR/NR | no | NA | Novartis Pharma AG, Switzerland

* reported in: Hawkey CJ. Farkouh M. Gitton X. Ehrsam E. Huels J. Richardson P. Therapeutic arthritis research and gastrointestinal event trial of lumiracoxib - study design and patient demographics. Alimentary Pharmacology & Therapeutics. 20(1):51–63, 2004 Jul 1.

Evidence Table 08[1]

Systematic reviews of NSAIDs

Author Year | (1) Aims | (2) Time period covered | (3) Eligibility criteria | (4) Number of patients | (5) Characteristics of identified articles: study designs | (6) Characteristics of identified articles: populations | (7) Characteristics of identified articles: interventions | (8) Main results | (9) Subgroups | (10) Comments
Rostom 2005 | To determine the frequency of lab and clinical hepatic side effects associated with NSAID use. | MEDLINE, EMBASE and Cochrane through January 2004. | RCTs (>4 wks, >40 pts) in duration of adults with OA or RA including one of the following drugs: celecoxib, rofecoxib, valdecoxib, meloxicam, diclofenac, naproxen or ibuprofen. | total NR | 64 RCTs: designs not specified | Patients age >18 with a diagnosis of OA or RA | 18 NSAID v placebo; 33 diclofenac studies; 12 ibuprofen studies; 14 naproxen studies; 5 meloxicam studies; 8 rofecoxib studies; 5 celecoxib studies; 1 valdecoxib study. | Safety: Among all comparisons, no NSAID had higher rates of renal serious adverse events, hospitalizations or death. Diclofenac and rofecoxib both showed higher rates of amniotransferase elevations (>3x ULN) when compared to all other NSAIDs (3.55% [95% CI, 3.12–4.03%] and 1.80%[95% CI, 1.52–2.13%] respectively, vs <0.43%) | Use of high dose of diclofenac (>100mg/day) was associated with a higher proportion of patients having amniotransferase elevation >3x ULN. No SS differences for other subgroups (high dose rofecoxib; longer duration for all comparators including placebo) | Assessed adverse events only
Rubenstein 2005 | To systematically review the published literature of population-based epidemiological studies reporting the incidence or comparative risk of NSAIDs for liver injury resulting in clinically significant events (defined as hospitalization or death) | MEDLINE, Pre- MEDLINE and EMBASE through 2004. | Case-control, controlled cohort, single cohort population-based studies. | total NR; 396,392 patient years included in analysis | 1 case-control; 1 nested case- control; 2 retrospective single- cohort w/nested case-control studies; 3 retrospective single- cohort w/out nested case- control. | Patients taking NSAIDs for any indication | 6 studies: unspecified NSAIDs (including any of the folowing: diclofenac, diflunisal, fenbufen, fenoprofen, ibuprofen, indomethacin, ketoprofen, mefenamic acid, naproxen, nimesulide, sulindac, tenoxicam); 2 of these 6 included aspirin. 1 study: diclofenac, naproxen and piroxicam only. | Safety: No SS difference between current NSAID user and past NSAID users in hospitalization rates for liver injury (range 1.2–1.7) Incidence of liver injury resulting in hospitaliztion ranged from 3.1–23.4/100,000 patient years for current NSAID users, compared to 4.8–8.6/100,000 patient years for past NSAID users. | not reported | Assessed adverse events only
Towheed 2004 | To determine which NSAID is most effective and which is most toxic in the treatment of hip OA | 1966 - August, 1994 MEDLINE Cochrane Musculoskeletal Group trials register and CCTR through August 1994 | RCTs published in English; placebo- controlled comparative treatment w/analgesics or NSAIDs; single and double-blinded trials | Total number of patients not specified, however mean number of randomized patients per trial was 95, with a range from 9 to 455. Mean number of patients completing trial was 81, range of 9 to 397. | 43 RCTs: 21 crossover study design and 22 parallel group design. | Eligible participants were any adult (>18) with a diagnosis of primary or secondary OA. 53% of trial participants were women, mean age 63. | Placebo v: etodolac, tenoxicam, ketoprofen, diacerhein Head to head: flurbiprofen v sulindac diclofenac v naproxen proquazone v naproxen piroxicam v naproxen diclofenac v ibuprofen sulindac v ibuprofen carprofen v diclofenac piroxicam v indomethacin naproxen v indomethacin tenoxicam v diacerhein | Efficacy When compared to placebo, all NSAIDs except diacerhein resulted in pain decrease and improvement of global assessment (no RR provided) In head to head trials, no SS difference amongst any of the compared interventions (no RR provided) Low-dose ibuprofen (<1600 mg/day) and low-dose naproxen (<750 mg/day) less efficacious than other NSAIDs An alternative, more sensitive technique of results analysis (Heller, et al) found that indomethacin was more effective than its comparators in 5 of 7 cases. Safety Out of 29 NSAID combinations, 9 revealed clinically relevant differences in toxicity. Indomethacin was found to be more toxic in 7 of these 9 combinations. However, only 6 of the 29 comparisons were tested for SS differences. | not reported | SR limited by lack of standardization of OA diagnosis and OA outcomes Results suggest that best NSAID varies widely depending on a particular patient
Watson 2004 | To determine difference in efficacy of NSAIDs in treatment of knee OA. | 1966 - November, 1996 MEDLINE1980- December, 1995 EMBASE | Double-blind RCTs published in English evaluating two NSAIDs | not stated | 16 RCTs: All double-blind although most failed to report method used to achieve double-blind conditions | Patients age >16 with a confirmed diagnosis of OA of the knee. | Etodolac (600 mg and 800 mg) v diclofenac (100–150 mg), naproxen (1000 mg), piroxicam (20 mg), indomethacin (150 mg), nabumetone (1500 mg)Nabumetone (1000 mg) v diclofenac (100 mg)Tenoxicam (20 mg) v piroxicam (20 mg)Tenoxicam (20 mg) v diclofenac (150 mg)Flurbiprofen (150 mg) v diclofenac (150 mg)Naproxen (750 mg) v diclofenac (150 mg) | Efficacy Withdrawal due to lack of efficacy: Meta-analysis of nine trials showed no SS differences between etodolac, diclofenac or naproxen. Patient Global Assessment: Favored etodolac in two trials however results are questionable due to inequivalent dose comparisons. Pain: Only 2 of 14 trials assessed pain measurement with adequate power (70%) to detect minimum clinical difference between treatments. Both trials favored etodolac over the comparator drug. Again, inequivalent dose comparisons resulted in questionable validity of results. Physical function: Only one trial showed a SS difference in favor of tenoxicam v diclofenac (OR 3.93 CI: 95% 1.07–14.44) | not reported | Poor methodology resulted in little SS evidence favoring one NSAID over anotherOnly 5 of 16 trials compared equivalent dosing of trial and comparators

Author Year | (1) Is there a clear review question? | (2) Were there explicit inclusion/exclusion criteria reported relating to selection of the primary studies? | (3) Is there evidence of a substantial effort to search for all relevant research? | (4) Was the literature search strategy stated? | (5) Is the validity of included studies adequately assessed? | (6) Is sufficient detail of the individual studies presented? | (7) Are there any important studies missing? | (8) Are the primary studies summarized appropriately? | (9) Quality rating
Rostom 2005 | yes | yes | yes | yes | yes | yes | no | yes | good
Rubenstein 2005 | yes | yes | yes | yes | yes | yes | no | yes | good
Towheed 2004 | yes | yes | yes | yes | yes | yes | no | yes | good
Watson 2004 | yes | yes | yes | yes | yes | yes | no | yes | good

Evidence Table 09[1]

COX-2s vs NSAIDs - tolerability

Trial | Focus | Subjects | Coxib dose | NSAIDs (mg) | Number of subjects^*^ | Duration (weeks) | Withdrawals due to adverse events | | Total adverse events | | GI adverse events | | Elevated creatinine, HTN, CHF, or edema | | Comment
Celecoxib | | | | | | | coxib | NSAID | coxib | NSAID | coxib | NSAID | coxib | NSAID
Ekman | efficacy and tolerability | Ankle sprain | 400 mg daily | ibuprofen 2400 mg daily | 445 | 10 days | <1% | 0% | 24.0% | 27.0% | Total GI nr | Total GI nr | nr | nr
Bertin | efficacy and tolerability | Acute shoulder pain | 400 mg daily | naproxen 100 mg daily | 203 | 14 days | nr | nr | 40.4% | 44.7% | 20.2% | 25.2% | nr | nr
Dougados | efficacy | Ankylosing spondylitis with flare | 100 bid | ketoprofen 100 bid | 170 | 6 | 6.3% | 1.1% | 68.0% | 60.0% | 32.2% | 33.8% | nr | nr
McKenna | efficacy and tolerability | OA of the knee with flare | 100 bid | diclofenac 50 tid | 400 | 6 | 7.0% | 11.0% | 50.0% | 54.0% | 18.0% | 25.0% | 5.0% | 3.0% | **
Bensen/Zhao | efficacy | OA of the knee with flare | 200 bid | naproxen 500 bid | 1004 | 12 | 10.0% | 8.0% | 65.0% | 63.0% | 24.0% | 32.0% | 4.0% | 1.0%
Goldstein | endoscopic ulcers | OA and RA with no ulcer on EGD | 200 bid | naproxen 500 bid | 537 | 12 | 7.0% | 9.0% | 70.0% | 70.0% | 34.0% | 40.0% | nr | nr
Simon/Zhao | efficacy and endoscopic ulcers | RA with flare and no ulcer on EGD | 100, 200, or 400 bid | naproxen 500 bid | 918 | 12 | 5.5% | 5.3% | 62%– 68% | 65.0% | 26.0% | 31.0% | 2.0% | 2.0%
Emery | endoscopic ulcers | RA | 200 bid | diclofenac 75 bid | 655 | 24 | nr | nr | 68.0% | 73.0% | 36.0% | 48.0% | nr | nr | 5 NSAID patients admitted for adverse events. Lower hematocrits and higher LFTs in the NSAID group.
Silverstein (CLASS) | serious GI events | OA and RA | 400 bid | ibuprofen 800 tid or diclofenac 75 bid | 7968 | 24 | 18.4% | 20.6% | 48.5% | 56.8% | 31.4%^†^ | 36.8% | 5%^†^ | 6.6%
Kivitz | efficacy and tolerability | OA | 100–400 mg daily | naproxen 100 mg daily | 1061 | 12 | 8% (100 mg); 13% (200 mg); 12% (400 mg) | 14% | 58% (100 mg); 66% (200 mg); 62% (400 mg) | 63.0% | 17% (100mg); 29% (200mg); 30% (400mg) | 35.0% | [underlined: Edema] 1% (100mg); 1% (200mg); 5% (400mg) | [underlined: Edema] 3%
Simon | efficacy and tolerability | RA | 100–400 mg bid | naproxen 500 mg bid | 1149 | 12 | 5% (100mg); 7% (200mg); 6% (400mg) | 5% | 68% (100mg); 63% (200 mg); 62% (400mg) | 65.0% | 28% (100mg); 25% (200mg); 26% (400mg) | 31.0% | [underlined: Edema]1% (100mg); 2% (200mg); 2% (200mg)[underlined: HTN]0% (100mg); <1% (200mg); <1% (400mg) | [underlined: Edema]2%[underlined: HTN]<1%
Etoricoxib
Baraf 2004
Curtis 2005
van der Heijde 2004
Lumiracoxib
Schnitzer 2004
Rofecoxib
Niccoli | tolerability | OA of hand, hip or knee | 25 mg | diclofenac 50 tid | 90 | 2 | 11.7% | 3.2% | 33.3%¦ | 26.6%¦ | nr | nr | 24%\|\|, nr, nr, nr | 5.7%\|\|, nr, nr, nr
Acevado | adverse events | OA, negative FOBT | 12.5 mg | diclofenac 50 mg/misoprostol 200 mcg bid | 483 | 6 | 4.1% | 9.1% | 52.9%^†^ | 73.0% | 28.9% | 48.5% | nr | nr
Saag | efficacy and tolerability | OA of knee or hip with flare (for NSAID users) or acetominophen user. Excluded aspirin 81mg users. | 25 mg | ibuprofen 800 tid | 667 | 6 | no difference (numbers not given) | | nr | nr | 3.5% | 3.2% | 5.3% | 2.3%
Day | efficacy and tolerability | OA of knee or hip with flare (for NSAID users) or acetominophen user | 25 | ibuprofen 800 tid | 735 | 6 | 3.7% | 8.4% | 53.3% | 51.8% | higher for NSAID (numbers not given) | | no difference (numbers not given)
Truitt | efficacy and tolerability | OA knee or hip with flare, >80 years old | 25 | nabumetone 1500 | 250 | 6 | 8.9% | 7.0% | nr | nr | nr | nr | incompletely reported; probably no difference.
Myllykangas- Luosujarvi | efficacy and tolerability | OA of the knee or hip | 12.5 | naproxen 500 bid | 944 | 6 | nr | nr | 43.3% | 48.2% | 13.4%^†^ | 24.1% | nr; 1.9%; nr; 3.4%(lower extremity), 0.2% (peripheral) | nr; 1.7%; nr; 2.3%(lower extremity), 1.4% (peripheral)
Lisse | efficacy and tolerability | OA of the knee, hip, hand, or spine | 25 | naproxen 500 bid | 5557 | 12 | nr | nr | 30.0% | 30.0% | 5.9%^§†^ | 8.1%^§^ | nr, 2.9%, nr, 3.5% | nr, 2.4%, nr, 3.8%
Hawkey | tolerability | RA | 50 | naproxen 500 bid | 660 | 12 | 5%^†^ | 9.1% | 62.1% | 66.4% | 3.7%^§^ | 6.8%^§^ | nr, 6.4%, 0.5%, 1.4% | nr, 0.9%, 0.0%, 0.0%
Hawkey | endoscopic ulcers | OA with no ulcer on EGD | 25 | ibuprofen 800 tid | 581 | 18 | 5.6% | 9.8% | 80.1% | 80.0% | no difference | | nr | nr
Laine (044) | endoscopic ulcers | OA with no ulcer or esophagitis on EGD | 25, 50 | ibuprofen 800 tid | 565 | 24 | 10.3% | 14.0% | 78.3% | 74.7% | nr | nr | nr | nr
Bombadier (VIGOR) | serious GI events | RA, negative FOBT | 50 | naproxen 500 bid | 8076 | 52 | 16,4% | 16.1% | | | 3.5%^§†^ | 4.9% | 1.2% | 0.9%
Cannon (035) | efficacy | OA of knee or hip with flare (for NSAID users) or acetominophen user | 25 | diclofenac 50 tid | 784 | 52 | 12.5% | 15.3% | 84.0% | 86.2% | no difference (numbers not given) | | no differences
Saag | efficacy and tolerability | OA of knee or hip with flare (for NSAID users) or acetominophen user. Excluded aspirin 81 mg users. | 25 | diclofenac 50 tid | 693 | 52 | significantly higher for NSAID (numbers not given) | | nr | nr | 5.2% | 8.3% | no difference (numbers not given) | | Discontinuation for elevated ALT higher in NSAID group.
Valdecoxib
Makarowski | efficacy and tolerability | OA of the hip | 5, 10 | naproxen 500 bid | 349 | 12 | 9% | 12.70% | 53% | 60.20% | no difference | | nr | nr
Pavelka | efficacy and tolerability | RA | 20, 40 | diclofenac 75 mg SR bid | 722 | 26 | 9.8%, 10.5% | 15.20% | 67%, 65% | 73.0% | 39.4%^†^, 40.1% | 49.4% | nr | nr

GI - gastrointestinal; HTN - hypertension; CHF - congestive heart failure; NR - not reported; OA - osteoarthritis; EGD - esophagogastroduodenoscopy; RA - rheumatoid arthritis; FOBT-fecal occult blood test; LFT - liver function test

* Excludes subjects randomized to placebo

** inadequately reported

§ Reported GI adverse events leading to discontinuation, but did not report total GI adverse events

† statistically significant

|| mean change (%); ¦only side effects not causing withdrawal

Evidence Table 10[1]

Systematic reviews of COX-2 inhibitors

Author Year | (1) Aims | (2) Time period covered | (3) Eligibility criteria | (4) Number of patients | (5) Characteristics of identified articles: study designs | (6) Characteristics of identified articles: populations | (7) Characteristics of identified articles: interventions | (8) Main results | (9) Subgroups | (10) Adverse events | (11) Comments
Celecoxib reviews
Garner 2004 (Celecoxib for RA) | To establish the efficacy and safety of celecoxib in the management of RA. | 1966- July, 2002 MEDLINE 1980 - July, 2002 EMBASE CCTR through Issue 3: 2002 | RCTs that used any accepted method to assess disease severity or progression, particularly ACR core set of disease activity measures for RA clinical trials endorsed by EULAR and/or OMERACT. | 4465 | 5 RCTs: 2 placebo-controlled double-blinded studies; 3 active-comparator double- blinded studies | Patients with RA with no restrictions regarding age or sex. Studies that include both RA and OA patients were also eligible for inclusion. | 1 study celecoxib (200mg 2x/day) v diclofenac (75mg 2x/day) 1 study celecoxib (400mg 2x/day) v diclofenac (75 mg 2x/day) or ibuprofen (800mg 3x/day) 1 study celecoxib (200mg 2x/day) v naproxen (500mg 2x/day) 1 study celecoxib at varied doses (40mg, 200mg or 400mg 2x/day each) v placebo 1 study celecoxib at varied doses (100mg, 200mg or 400mg 2x/day each) v naproxen (500 mg 2x/day) or placebo | Efficacy Celecoxib v naproxen: Differences in withdrawal rates according to intervention or dosage were not statistically significant (29% for naproxen, 28%, 21% and 27% respectively for 100mg, 200mg and 400mg.)Percentage of patients showing improvement were also similar regardless of intervention or dosage. When compared to naproxen, RR of improvement were 1.1 (95% CI:0.8, 1.4) at 100mg 1.2 (95% CI: 1.0, 1.5) at 200mg and 1.1 (95% CI: 0.9, 1.4) at 400mg. Celecoxib v diclofenac: Withdrawals due to lack of efficacy were essentially the same for both interventions (8% for celecoxib and 7% for diclofenac). Percentage of patients showing improvement according to ACR 20 responder index was also essentially the same (25% for celecoxib, 22% for diclofenac. RR 1.1 (95% CI: 0.8, 1.5)) Celecoxib v placebo: Withdrawal rates due to lack of efficacy varied widely between the two placebo- controlled studies: Placebo -18% and 45%; 40mg -17%; 100mg -28%; 200mg - 4% and 21%; and 400mg - 6% and 27%. Percentage of patients showing improvement: 100 mg - 40%; 200mg - 44% and 51%; 400mg - 39% and 52%; placebo - 29% for both studies. There was no statistically significant difference between 40mg and placebo. Safety Celecoxib v naproxen: Two studies reported data on endoscoped ulcers at 12 wks at 200mg dose. Pooled RR was 0.2 (95% CI: 0.1, 0.4) For other doses of celecoxib when compared to naproxen the RR of developing an ulcer 3mm or greater was 0.2 at 100mg (95% CI: 0.2, 0.5) and 0.2 at 400mg (95% CI: 0.1, 0.5) Only at 100mg was celecoxib statistically favored over naproxen for GI events (RR 0.3 (95% CI: 0.07, 0.9)) Celecoxib v diclofenac: At 24 wks, 15% of diclofenac and 3% of celecoxib patients had endoscopically detected ulcers of 3mm or greater (RR 0.3 (95% CI: 0.6, 0.9)) Total number of AEs was similar for both interventions (68% of patients taking celecoxib and 73% of patients taking diclofenac) but more diclofenac patients withdrew due to AEs (10% of celecoxib patients v 19% of diclofenac patients (RR 0.5 (95% CI: 0.4, 0.8)). Two diclofenac patients required hospitalization due to gastric erosions/ulcer. Celecoxib v placebo: For one study, only number of patients withdrawn due to AEs was reported. There was no signifcant difference amongst doses or v placebo (40mg - 4%; 200mg - 5%; 400mg - 5%; placebo - 6%.) For the other study, GI AEs were also similar (100mg - 28%, 200mg - 25%, 400mg - 26%, placebo - 19%.) No clinically significant GI events were reported. | Celecoxib v placebo No effect for H. pylori status, concurrent aspirin or corticosteriod use, history of GI tract bleeding and ulcers. No other subgroup analysis reported | Celecoxib v diclofenac Total AEs: 68% v 73% RR 0.9 (95% CI: 0.9, 1.0) GI: 36% v 48% RR 0.8 (95% CI: 0.6, 0.9) Peripheral oedema: 3% v 2% Hypertension: 1% v 2% Celecoxib v naproxen No difference between total AE rate and withdrawal rate due to AEs GI: RR of ulcer 3mm or greater at 200mg of celecoxib 0.2 (95% CI: 0.1, 0.4) Celecoxib v placebo GI: In celecoxib patients, RR of ulcer development 3mm or greater at 12 wks was 1.5 at 100mg (95% CI: 0.5, 4.8); 1.0 at 200mg (95% CI: 0.3, 3.5); and 1.5 at 400mg (95% CI: 0.5, 5.0) | Study design problems with both CLASS and VIGOR studies
Ashcroft 2001 | To evaluate incidence of gastroduodenal ulcers in patients with RA or OA treated with celecoxib | 1988–2000 MEDLINE, EMBASE and CCTR | RCTs of OA or RA patients treated with celecoxib who had scheduled endoscopies. | 4632 | 5 RCTs: All parallel group double-blinded 12wks (4 studies) or 24 wks (one study) in duration. 2 published and 3 unpublished studies. | One unpublished study assessed OA patients only, 2 studies (both published) assessed RA patients only and two studies (both unpublished) assessed OA and RA patients. All patients had at least one endoscopic evaluation at 4, 8, 12 or 24 weeks. In all but one study patients also had baseline evaluation. | Various doses of celecoxib ranging from 50mg – 400 mg/day v naproxen (500mg), diclofenac (75mg) or ibuprofen (800 mg) | Celecoxib v diclofenac (200 mg v 75mg 2x/day) One study found no difference b/t celecoxib v diclofenac at 12 wks (RR 0.73 (95% CI: 0.11–0.52)). However, another trial comparing ulcers at 24 wks found lower rates with celecoxib (RR 0.24 (95% CI 0.11–0.52) Sensitivity analysis revealed that there were significantly fewer endoscopic ulcers w/celecoxib 200mg 2x/day v modified-relsease diclofenac 75mg 2x/day. RR 0.24 (95% CI: 0.16–0.40) Celecoxib v ibuprofen (200mg v 800mg 3x/day) Fewer ulcers were found at 12wks w/celecoxib RR 0.30 (95% CI: 0.20–0.46) Celecoxib v naproxen (doses 100mg – 800mg v 1000 mg) For all doses, fewer ulcers w/celecoxib at 12 wks. Pooled data for dose of celecoxib 100mg resulted in RR 0.22 (95% CI: 0.13–0.37) At 200mg, pooled RR was 0.24 (95% CI: 0.17–0.33) Celecoxib v placebo Doses from 100–800mg/day. Pooled analysis - celecoxib 100mg 2x/day RR 1.96 (95% CI: 0.85–4.55) 200mg 2x.day RR 2.35 (95% CI: 1.02–5.38) | Not reported | Celecoxib v diclofenac Risk of endoscopically detected ulcer - pooled analysis: RR 0.24 (95% CI: 0.16–0.40) Celecoxib v ibuprofen Risk of endoscopically detected ulcer - RR 0.30 (95% CI: 0.20–0.46) Celecoxib v naproxen Pooled analysis - celecoxib 100mg 2x/day RR 0.22 (95% CI: 0.13–0.37) 200mg 2x/day RR 0.24 (95% CI: 0.17–0.33) Celecoxib v placebo Pooled analysis - celecoxib 100mg 2x/day RR 1.96 (95% CI: 0.85–4.55) 200mg 2x.day RR 2.35 (95% CI: 1.02–5.38)
Rofecoxib reviews
Juni 2004 | To establish whether robust evidence, aside from the published findings of the VIGOR trial, on the adverse effects of rofecoxib was available prior to September, 2004. | from “inception” of database through September, 2004 MEDLINE EMBASE, CINAHL and CCTR | RCTs in adults with chronic musculoskeletal disorders that compared rofecoxib with other NSAIDs or placebo and cohort and case- control studies of CV risk and naproxen. | 25,273 | 18 RCTs - 12 OA, 5 RA, 1 low back pain. 3 trails had 2 arms, 7 had 3 arms, 8 had four arms. 11 observational studies. | No restrictions based on age or sex. | Rofecoxib at various doses ranging from 12.5mg to 50mg v diclofenac (150mg), ibuprofen (2400mg), nabumetone (1000mg or 1500mg, naproxen (1000mg) or placebo | All serious CV event risk based on available comparisons: 85 AEs in rofecoxib groups, 38 in control groups. RR 1.55 (95%: CI 1.05–2.29) MI risk based on all comparisons: 52 AEs in rofecoxib groups, 12 in control groups. RR 2.24 (95% CI: 1.24–4.02) Stroke risk for all available comparisons: 25 AEs in rofecoxib group, 19 in control groups. RR 1.02 (95% CI: 0.54–1.93) Cardioprotective effect of naproxen: Meta-analysis of 11 studies showed RR 0.86 (95% CI: 0.75–0.99) No difference compared to non-naproxen NSAIDs RR 0.86 (95% CI: 0.75–0.99) For both analyses there was considerable between-study hetereogeneity (I2 68% and 43% respectively) Studies funded by Merck indicated larger cardioprotective effects (p=0.001 and p=0.056, respectively, by test of interaction.) | Not reported | MI - RR (95% CI) Rofecoxib: 12.5mg: 2.71 (0.99–7.44) 25mg: 1.37 (0.52–3.61) 50mg: 2.83 (1.24–6.43) Naproxen: 2.93 (1.36–6.33) non-Naproxen NSAIDs: 1.55 (0.55–4.36) Placebo: 1.04 (0.34–3.12) | Restricitve inclusion criteria resulted in few study participants with history of CV disease. Other studies (Ray et al, 2002) looking at rofecoxib use in routine clinical settings report that 40% of rofecoxib patients had hisotry of CV disease resulting in an eight-fold increase in MI (11.6 v 1.45 per 1000 patient years)
Garner 2004 (Rofecoxib for RA) | To assess the efficacy and toxicity of rofecoxib in treating RA. | 1966 - December, 2000 MEDLINE 1980 - December 2000 EMBASE CDSR, CCTR though Issue 4: 2000 HTA database (no date supplied) | Parallel design, placebo-controlled and comparative RCTs evaluating efficacy and/or toxicity of rofecoxib in RA. Outcome criteria had to be available to evaluate efficacy and/or toxicity, such as OMERACT outcomes. | 8,734 | 2 RCTs: 1 parallel-group double-blinded placebo controlled and 1 parallel- group double-blinded active comparator. | Both trials assessed patients diagnosed with RA with no restrictions based on age or sex. | 1 8-week trial rofecoxib 5mg, 25mg or 50mg/day v placebo; 1 trial 50mg/day rofecoxib v 500mg naproxen 2x/day. Trial duration 4 weeks to 13 months. | Efficacy Rofecoxib v placebo: No SS difference between 5mg rofecoxib and placebo (10.1% and 14.2% respectively.) ACR 20 responders who received 25mg or 50mg (48% and 53% of patients, respectively) was statistically significantly more than those patients receiving placebo (35%) RR 1.39 CI:1.07, 1.80 and RR 1.55 CI: 1.20, 1.99 respectively.) There were fewer withdrawls due to lack of efficacy in patients taking 25mg (6.4%) or 50mg (6.8%) v placebo (14.3%) RR 0.45 CI: 0.23, 0.89 and RR 0.48 CI 0.24 and 0.94 respectively) and overall at 25 mg (15.2%,) 50mg (16.1%) and placebo (22.0%) (RR 0.69 CI: 0.44, 1.09 and RR 0.72 CI: 0.47, 1.15.) Rofecoxib v naproxen: No statistically significant differences between comparators for withdrawals due to lack of efficacy: rofecoxib withdrawals 6.3% v naproxen withdrawals 6.5% (RR 0.97 CI: 0.82, 1.14) Safety Rofecoxib v placebo: There was no statistically significant difference in the number of withdrawals due to AEs for all doses of rofecoxib and placebo (placebo - 3.0%, 5 mg - 3.2%, 25 mg - 4.7% and 50 mg - 6.2%) except that more patients experienced rash at 50mg. Rofecoxib v naproxen:WIthdrawal rates due to AEs were similar for rofecoxib (16.4% of patients) v naproxen (16.1%) (RR 1.02 CI: 0.92, 1.12) | Patients with previous GI events showed a lower rate of GI events in patients treated with rofecoxib (RR 0.4 CI: 0.2, 0.8) v those with no previous events (RR 0.5 CI: 0.3, 0.7). For patients with very low risk (<65 years of age, H. pylori negative, no history if clinical GI event and not taking glucocoticoids) the RR of clinical GI events was signficantly lower (RR 0.1 CI: 0.02, 1.0) | Rofecoxib v placebo Withdrawals due to GI events: 0% placebo, 1.3% rofecoxib 5mg/day, 1.8% rofecoxib 25 mg/day, 0% rofecoxib 50mg/day. No PUBs reported. Lower extremity oedema: 1.2% placebo, 1.3% rofecoxib 5mg/day, 2.3% rofecoxib 25 mg/day, 2.5% rofecoxib 50mg/day Hypertension: 1.2% placebo, 0% rofecoxib 5 mg/day, 2.9% rofecoxib 25 mg/day. 3.1% rofecoxib 50mg/day Renal: Little reported data, however 1 patient in both 25mg and 50mg groups withdrew due to elevated serum creatinine level Rofecoxib v naproxen Upper GI events incidence: 1.4% rofecoxib, 3.0% naproxen RR 0.43 CI: 0.24, 0.77 Severe GI events incidence: 0.4% rofecoxib, 0.9% naproxen (RR 0.43 CI 0.24, 0.77). Renal AEs: 1.2% rofecoxib, 0.9% naproxen (RR 1.4 CI: 0.9, 2.1) CV events were higher in the rofecoxib group at unspecified doses. CV death rate was 0.2% for both rofecoxib and naproxen. MI rate was 0.45% for rofecoxib v 0.1% for naproxen (RR 5.0 CI: 1.5, 13.2) | In rofecoxib v placebo study, AEs were only reported if experience >3% of patients in any group. Also, no data on mortality was presented in the rofecoxib v placebo study.
Garner2004(Rofe coxib for OA) | To establish the efficacy and safety of rofecoxib in the management of OA. | 1966-August, 2004MEDLINE1980- week 36, 2004EMBASECCTR through Issue 3: 2004 | Published RCTs of parallel design that used any accepted method to assess OA severity or progression. | 21551 | 26 published RCTs: 25 parallel- group double-blinded and 1 single-blinded study | Patients with OA with no restrictions based on age or sex. | Rofecoxib v:-NSAIDsdiclofenac (3 RCTs)ibuprofen (4 RCTs)nabumetone (3 RCTs)naproxen (3 RCTs)nimesulide (2 RCTs)diclofenac+misoprostol (1 RCT)-Other Cox-2scelecoxib and paracetamol (2 studies)celecoxib (10 studies)valdecoxib (1 study)- Placebo (12 RCTs) | EfficacyRofecoxib v NSAIDs: Study design greatly effected the ability to pool data regarding rofecoxib v various NSAIDs. For diclofenac, ibuprofen, naproxen, nabumetone, diclofenac+misoprostol, and nimesulide all studies showed that efficacy was not statistically significantly greater for rofecoxib and the comparator, however nearly all the studies suffered from inconsistent methodologies and data reporting. Rofecoxib v Cox-2s: There was no SS difference between withdrawals due to lack of efficacy between rofecoxiib 25mg and celecoxib 200mg at 6 wks. RR: 0.76 CI: 0.47, 1.24). Patient global response pooled data indicated that patients taking 25mg rofecoxib v celecoxib had good-excellent improvement (RR 1.14 CI: 1.05, 1.24)Rofecoxib v placebo: The result of meta-analysis showed that rofecoxib was superior to placebo for most outcome measures (e.g. WOMAC, patient/investigator ratings.) NNT with rofecoxib v placebo to achieve improvement in patient global assessment was 5 (95% CI: 4, 6)Safety1) GI eventsRofecoxib v NSAIDs: Rates of GI events difficult to interpret due to methodology of included studies and lack of reported data. The only statistically significant difference relating to GI events was that rofecoxib caused less GI pain than diclofenac (0.8% in the rofecoxib group and 5% in the diclofenac group.) Naproxen caused more withdrawals due to GI events. Endoscopic evidence indicates that rofecoxib at 25mg and 50mg caused fewer gastric ulcers and fewer duodenal ulcers at 25mg when compared to ibuprofen. Rofecoxib v placebo: The risk of GI AE was not significantly increased with rofecoxib for most studies, however one study reported increased GI events at doses of 25mg RR 3.39 CI: 1.47, 7.84) Endoscopic evaluation at 18wks showed no difference in ulcers or erosions escept that rofecoxib caused fewer large ulcers/erosions (> 5mm) RR 0.42 CI: 0.20, 0.86.2) CV eventsRofecoxib v NSAIDs: Many studies did not report specific data on CV events. One study of rofecoxib v diclofenac reported withdrawal due to CV events (hypertension: 3/231, palpitation 4/232, TIA 3/230) RR 1.0 (95% CI: 0.2, 4.9) for diclofenac v RR 1.3 (95% CI: 0.3, 5.8) for rofecoxib. For rofecoxib v naproxen, one withdrawal due to CHF was reported in the rofecoxib group of the Naproxen 901 studies. The ADVANTAGE study report 5 patients with MI in the rofecoxib group v 1 in the naproxen group (RR 4.98 CI: 0.58, 42.57) and 6 strokes in the rofecoxib group v 0 in the naproxen group (RR 1.22 CI: 0.89, 1.68.) Higher rates of CV events occured in patient with pre-existing hypertention. Rofecoxib v placebo: Two trials that reported withdrawals due to CV events showed no SS difference between rofecoxib withdrawals and placebo withdrawals.3) Other AEsRofecoxib v NSAIDs: Rofecoxib seems to be associated with increased systolic blood pressure compared to celecoxib, diclofenac and naproxen. One study also reported an increase in diastolic blood pressure. Other reported AEs include oedema (v diclofenac, RR 19.20 CIL 1.17, 314.55), hypertension (v diclofenac 15.54 CI: 0.93, 258.58) and weight gain (v diclofenac RR 19.20 CI: 1.17, 314.55)Rofecoxib v placebo: Overall risk of AEs was statistically significantly higher at 6wks at 12.5mg. RR 3.95 CI: 1.05, 14.63 | Rofecoxib v naproxen-One study analyzed patients receiving concomitant low- dose aspirin which showed no SS difference in GI events | Rofecoxib v diclofenac:Total AEs: Fewer withdrawals due to AEs for 12.5mg and 25mg of rofecoxib (RR 0.71 CI: 0.52, 0.97 and RR 0.70 CI: 0.51, 0.95 respectively). No SS differences for withdrawals due to GI or CV AEs. SS fewer liver function disturbances reported with rofecoxib, but there are no numerical data supplied to support this. Rofecoxib v ibuprofen:GI: Fewer gastric ulcers 25mg RR: 0.15 CI: 0.09, 0.25 and 50mg RR: 0.23 CI: 0.14, 0.36. Fewer duodenal ulcers at 25mg RR 0.24 CI: 0.09, 0.63 but no SS difference at 50mg. Other AEs ambiguously reported. Rofecoxib v naproxen:GI: Study data pooled for 2 of 4 studies. Fewer GI events reported in rofecoxib group for two studies (63/471 v 114/473 RR: 0.55 CI: 0.42, 0.73) No PUBs in rofecoxib group, 3 in naproxen group (RR 0.14 CI: 0.01, 2.77) Serious AEs: 6/17 serious AEs considered drug-related. One CHF in rofecoxib group, 5 other serious AEs in naproxen group. Other discontinuations for hypertension (2/471 v 0/473; RR 5.02 CI: 0.24, 104.31) and oedema (3/471 v 0/473; RR 7.03 CI: 0.36, 135.77)Rofecoxib v nabumetonePooled analysis showed no difference in total or serious AEs (RR 1.09 CI: 0.99, 1.20 and RR 1.28 CI: 0.57, 2.89 respectively)Rofecoxib v placeboSS AEs were for total withdrawals in rofecoxib group 12.5 mg at 6/8 wks. (RR: 2.18 CI: 1.34, 3.55) and 50mg at 12wks (RR 2.04 CI: 1.24, 3.36) | Lack of adequate reporting of outcomes and lack of consideration of variations in NSAID toxicity in many of the included studies severly hampered the ability to draw conclusions regarding efficacy and safety.
Valdecoxib reviews
Eisen 2005 | To compare incidence of upper GI disturbances (abdominal pain, dyspepsia or nausea) with valdecoxib, nonspecific NSAIDs and placebo in patients with OA and RA. | All included studies were published in 2002. Method of identifing included studies was not specified. | Not reported | 4,394 | 5 randomized, double-blind 12-week phase III trials; Three OA studies and 2 RA studies were included. | Patients were eligible if the met ACR criteria for RA or OA. Reasons for patient exclusion included serious concomitant GI, renal, hepatic or coagulation disorders, malignancy or diagnosis with other forms of inflammatory or secondary non- inflammatory arthritis. | OA patients were randomly assigned to one of five treatment groups - placebo, valdecoxib (5, 10 or 20 mg) or nonspecific NSAID (500 mg naproxen, 800 mg ibuprofen, or 75 mg diclofenac.) RA patients were randomly assigned to one of five treatment groups - placebo, valdecoxib (10, 20 or 40 mg) or naproxen (500 mg.)weeks. Low- dose aspirin (< 325 mg/day) and acetaminophen (< 2 g/day) were permitted as concomitant medications. Prednisone up to 10 mg/day was permitted for RA patients. | Cumulative 12-wk incidence of any moderate to severe upper GI AE based on Kaplan-Meier time-to- event estimates were: NSAIDs (n=1185): 15.0 (12.8–17.2) Valdecoxib (n=2236): 9.0 (7.7–10.4) Placebo (n=973): 10.5 (7.3–13.7) GPA users; gender; disease (OA or RA) and ethnicity Pooled analysis demonstrated decrease in dyspepsia and inprovement in GI tolerability for valdecoxib v NSAIDs. | Not reported | AEs estimated using Kaplan-Meier time-to-event analysis Valdecoxib (n=2236) abdominal pain: 4.2 (3.3–5.2) dyspepsia: 3.9 (3.0–4.8) nausea: 2.7 (1.9–3.5) NSAIDs (n=1185) abdominal pain: 6.9 (5.3–8.4) dyspepsia: 6.8 (5.2–8.3) nausea: 4.0 (12.8–17.2) Placebo (n=973) abdominal pain: 4.1 (2.6–5.7) dyspepsia: 3.8 (2.4–5.2) nausea: 4.8 (2.0–7.6) | Patients taking <5mg of valdecoxib were excluded from the final results - final number of participants was 4394.
Etoricoxib (included for safety only)
Ramey, et al 2005 | To determine the incidence of upper GI perforations, symptomatic gastroduodenal ulcers and upper GI bleeding (PUBs) in etoricoib users compared to NSAID users | Trials completed by June 2003 | NR | 5441 | 10 RCTs 9 active- comparator and placebo- controlled, one active- comparator only | OA (4 studies), RA (3 studies), ankylosing spondylitis (1 study), endoscopy trials (2 12- wk studies) | For all PUBs, etoricoxib v NSAIDs RR 0.48% (95% CI).32, 0.73; p<0.001 | Effect in favor of etoricoxib remained across the following subgroups: age; history of PUB; GPA users; gender; disease (OA or RA) and ethnicity
Lumiracoxib (included for safety only)
Matchaba, et al 2005 | To determine the risk of CV events with lumiracoxib through meta- analysis | dates NR | All clinical studies >1wk and <52wks in Novartis Lumiracoxib Clinical Trial Database included | 34,668 | 22 RCTs: 21 published trials, including 8 placebo- controlled and 1 unpublished (also placebo- controlled) | OA (15 trials) and RA (7 tri patients | 15 studies lumiracoxib (200– 1200mg) v celecoxib (200mg), diclofenac (75 mg bid), ibuprofen (800mg tid), naproxen (500mg bid) or rofecoxib (25 mg), 8 studies lumiracoxib (100– 400mg) v placebo | For all comparisons, no SS difference was found in CV event rates with lumiracoxib v comparator. Lumiracoxib compared less favorably with naproxen (0.37% event rate with lumiracoxib v 0.22% event rate with naproxen) but again did not meet statistical significance. | No subgroup analysis | | quality of included studies not considered in meta- analysis
Multiple COX-2s (reported adverse events only)
Kearney, et al 2006 | To assess the effects of selective COX- 2 inhibitors and traditional NSAIDs on the risk of vascular events | January 1966- April 2005 (MEDLINE and Embase) | RCTs at least 4 wks “scheduled treatment” of COX-2 vs placebo or NSAID that reported serious CV events | 145,373 | only described as RCTs (n=138); either placebo (n=121) or active | numerous indications, including: RA, OA, low back pain, ankylosing spondylitis, polyps and Alzheimer’s Disease. | | NA | No subgroup analysis | COX-2 vs placebo short- and long-term studies: COX-2s associated with increase in rate of MI - 0.6%/yr vs 0.3%/yr (RR 1.86 CI 95% 1.33–2.59 p=0.0003) RR or all vascular events increases to 1.45 (95% CI 1.12–1.80, p=0.0003) when only long- term (>1 yr) were analyzed. COX-2 vs NSAID: Overall RR of any vascular event among heterogeneous studies 1.0%/yr vs 0.9%/yr was 1.16 (CI 95% 0.97–1.38, p=0.1) | quality of included studies not considered of 121 placebo trials, nine were long-term. 2/3 of CV events occurred in long-term trials.

Author Year | (1) Is there a clear review question? | (2) Were there explicit inclusion/exclusion criteria reported relating to selection of the primary studies? | (3) Is there evidence of a substantial effort to search for all relevant research? | (4) Was the literature search strategy stated? | (5) Is the validity of included studies adequately assessed? | (6) Is sufficient detail of the individual studies presented? | (7) Are there any important studies missing? | (8) Are the primary studies summarized appropriately? | (9) Quality rating
Celecoxib reviews
Garner 2004 (Celecoxib for RA) | yes | yes | yes | yes | yes | yes | no | yes | good
Ashcroft 2001 | yes | yes | yes | partially | yes | yes | no (2001 publication) | yes | good
Rofecoxib reviews
Juni 2004 | yes | yes | yes | partially | yes | yes | no | yes | good
Garner 2004 (Rofecoxib for RA) | yes | yes | yes | yes | yes | yes | no | yes | good
Garner 2004 (Rofecoxib for OA) | yes | yes | yes | yes | yes | yes | no | yes | good
Valdecoxib reviews
Eisen 2005 | yes | yes | no | no | no | yes | no | yes | fair
Etoricoxib (included for safety only)
Ramey, et al 2005 | yes | no | no | no | no | yes | no | yes | fair
Lumiracoxib (included for safety only)
Matchaba, et al 2005 | yes | yes | yes | no | no | yes | no | yes | fair
Multiple COX-2s (reported adverse events only)
Kearney, et al 2006 | yes | yes | yes | yes | no | yes | no | yes | good

Evidence Table 11[1]

Systematic reviews of acetaminophen

Author Year | (1) Aims | (2) Time period covered | (3) Eligibility criteria | (4) Number of patients | (5) Characteristics of identified articles: study designs | (6) Characteristics of identified articles: populations | (7) Characteristics of identified articles: interventions | (8) Main results | (9) Subgroups | (10) Adverse events | (11) Comments
Lee, 2004 | To compare efficacy and safety of recommended doses of NSAIDs, including Cox 2 inhibitors, vs acetaminophen in the treatment of symptomatic hip and knee osteoarthritis | 1966 through February 2003 MEDLINE 1991 to 1st quarter 2003 EMBASE Drugs and Pharmacy database | Original clinical trials with direct comparisons of an NSAID with acetaminophen or paracetamol without combination with a nonnarcotic analgesic or narcotic agent. Duration of NSAID exposure ≥ 7 days. Sufficient analyzable data | 1252 | 7 clinical trials: 2 randomized active comparator trials without placebo arms, 2 randomized parallel- group double-blinded trials, 2 randomized crossover trials, and 1 randomized placebo- controlled double-blinded trial. | All trials included patients with knee OA, and 2 also included patients with hip OA. 71% were women. | 1 study compared actetaminophen to placebo, and 5 compared acetaminophen to NSAIDs. Acetaminophen dose ranged from 2600 mg/d (1 study) to 4000 mg/d (5 studies). Mean duration of trials was 22 weeks, with a range from 6 days to 2 years. If outlier study (104 weeks) removed, mean duration was 5.8 weeks. | Acetaminophen vs Placebo Based on 1 cross-over, double-blind RCT Improvement in rest pain: 16/22 (73%) vs 2/22 (9%) Improvement in pain on motion:15/22 (68%) vs 4/22 (18%) Physician global assessment: 20/21 (95%) vs 1/21 (5%) Patient global assessment:10/10 (100%) vs 1/10 (10%) Acetaminophen vs NSAIDS : absolute values not available except for global assessment Rest pain and HAQ pain: NSAIDs superior to acetaminophen. Rest pain effect sizes measured by standard mean difference (SMD): 0.32(95% CI, 0.08 –0.56) and 0.34 (95% CI, 0.10 – 0.58). HAQ pain: 0.27 (95% CI, 0.05 – 0.48) and 0.24 (95% CI, 0.03 – 0.45). Pain on motion: SMDs not significant. Physical function: Neither 50 foot walk time nor HAQ showed significant differences between NSAIDs and acetaminophen. Group 1 (ibuprofen 2400 mg, arthrotec, celecoxib, naproxen) Physician global assessment: 23/61 (38%) vs 23/61 (38%) Patient global assessment: 37/94(39%) vs 45/97(46%) Group 2 (ibuprofen 1200 mg, arthrotec, rofecoxib 25 mg, naproxen) Physician global assessment: 23/61(38%) vs 27/62 (44%) Patient global assessment: 37/94 (39%) vs 57/95 (60%) Group 3 (ibuprofen 1200 mg, arthotec, rofecoxib 12.5 mg, naproxen) Physician global assessment: not reported Patient global assessment: 37/94 (39%) vs 54/96 (56%) | Not reported | Acetaminophen vs Placebo No participant removed from study due to side effects. Withdrawals/total number of AEs: 10/25 (40%) acetaminophen vs 8/25 (32%) placebo. Acetaminophen vs NSAIDS Group 1: Total # of AEs: 164/360 (46%) vs 179/353 (51%). Withdrawals due to toxicity: 35/448 (8%) vs 38/443 (8%). Group 2: Total # of AEs: 164/360 (46%) vs 170/352 (48%). Withdrawals due to toxicity: 35/448 (8%) vs 38/442 (9%). Group 3: Total # of AEs: 164/360 (46%) vs 180/353 (51%). Withdrawals due to toxicity: 35/448 (8% ) vs 39/443 (9%). GI events, acetaminophen vs traditional NSAIDs 10/148 (7%) vs 38/212 (18%) GI events, acetaminophen vs Coxib NSAIDs 16/94 (17%) vs 47/288 (16%) GI withdrawals, acetaminophen vs traditional NSAIDS 9/151 (6%) vs 24/213 (11%)GI events, acetaminophen vs traditional NSAIDs 10/148 (7%) vs 38/212 (18%) GI events, acetaminophen vs Coxib NSAIDs 16/94 (17%) vs 47/288 (16%) GI withdrawals, acetaminophen vs traditional NSAIDS 9/151 (6%) vs 24/213 (11%) | Results do not account for differences in baseline pain Most trials had short follow-up periods. 1 included trial was an abstract only (Altman1999)
Towheed, 2005 Cochrane review: most recent substantive update 9/16/02 | 1) To assess the efficacy and safety of acetaminophen (or paracetamol) vs placebo and 2) vs NSAIDS (ibuprofen, arthrotec, celecoxib, naproxen and rofecoxib) for treating osteoarthritis (OA) | 1966 – July 2002 MEDLINE Through March 2002 Current contents To August 2002 Cochrane Controlled Trials Registry | Published RCTs evaluating efficacy and safety of acetaminophen alone in OA for adults with a diagnosis of primary or secondary OA at any site. | 1689 | 6 RCTs, including 2 with crossover and 4 with parallel-group designs | All trials were of patients with OA of the knee, with one also including OA of the hip | 2 trials of paracetamol vs placebo, 4000 mg/d and 3000 mg/d. 2 trials of NSAIDs vs paracetamol vs placebo, 150 – 200 mg, and 4000 mg, respectively. 6 trials of NSAIDs vs paracetamol, 12.5 mg/d – 2400 mg/d and 2000 mg/d – 4000 mg/d respectively. Duration of trials 1 week to 2 years. | Pain reduction 2 placebo controlled trials provided pain intensity at baseline and end point. Pooled ES 0.21 (95% CI 0.02–0.41, p=0.02), favoring paracetamol. 8 trials of NSAIDs vs paracetamol. Pooled ES 0.20 (95% CI 0.10–0.30, p=0.000) indicating NSAIDS better than paracetamol for OA pain relief. Overall Western Ontario and McMaster Universities OA Index (WOMAC) In the 2 placebo controlled trials, no significant difference between paracetamol and placebo (pooled ES 0.14, 95% CI −0.06–0.34). In the 8 other trials, NSAIDs significantly better than placebo (pooled ES 0.34, 95% CI 0.14–0.54) or paracetamol (pooled ES 0.3, 95% CI 0.17–0.44). Clinical response rate The 2 placebo controlled trials showed paracetamol better than placebo, but results were heterogeneous (Q=4.93; p=0.03). Clinical response RRs were 16 (95% CI 2.32–110.45; p=0.02) and 1.67 (95% CI 1.00–2.76; p=0.05). Trials comparing NSAIDs and paracetamol were homogeneous and showed NSAIDs superior to paracetamol. Pooled response RR 1.24 (95% CI 1.08–1.41, p=0.001). NNT was 8 (95% CI 5–19, p<0.001), indicating 8 persons needed to be treated before NSAID showed benefit over paracetamol for moderate to excellent pain relief. Patient preference for NSAIDs or paracetamol Examined in 3 trials in crossover or n of 1 design. More patients preferred NSAIDs (61% vs 20%). Pooled RR 2.46 (95% CI 1.51–4.12, p<0.001) and NNT was 3 (95% CI 2–7, p<0.001). Percentage of patients preferring paracetamol similar to that preferring neither treatment (18%). Pooled RR 0.96 (95% CI 0.79–1.32). | Not reported | Paracetamol vs placebo GI discomfort: 5/55 (9.1%) vs 6/55 (10.9%) Nausea: 1/25 (4.0%) vs 0/25 (0) Headache: 2/55 (3.6%) vs 2/55 (3.6%) Dizziness: 1/55 (1.8%) vs 7/55 (12.7%) NSAIDs overall vs paracetamol GI discomfort: 108/704 (15.3%) vs 82/702 (11.7%) RR 1.35 (95%CI 1.05–1.75) Nausea: 29/491(5.9%) vs 23/492 (4.7%) Headache: 27/581(4.6%) vs 32/580 (5.5%) Dizziness: 5/288 (1.7%) vs 3/282 (1.1%) Conventional NSAIDs vs paracetamol GI discomfort: 105/416 (25.2%) vs 76/420 (18.1%) RR 1.39, 95% CI 1.07–1.80 Nausea: 15/203 (7.4%) vs 8/210 (3.8%) Headache: 5/293 (1.7%) vs 8/298 (2.7%) Dizziness: - Coxibs vs paracetamol GI discomfort: 3/288 (1.0%) vs 6/282 (2.1%) RR 0.65, 95% CI 0.17–2.52 Nausea: 14/288 (4.9%) vs 15/282 (5.3%) Headache: 22/288 (7.6%) vs 24/282 (8.5%) Dizziness: 5/288 (1.7%) vs 3/282 (1.1%) | Only the 2 placebo controlled studies considered baseline pain levels Most trials had short follow-up periods of approximately 6 weeks 1 included trial was an abstract only (Shen 2003) One RCT was an”n of 1′ design
Wegman, 2004 | To systematically evaluate RCT evidence on short and long term efficacy of NSAID compared to acetaminophen for OA of the hip or knee. To critically appraise the quality of guidelines for management of OA, and compare content of recommendation s in these guidelines on treatment of OA with NSAID or acetaminophen. | To December2001 | For evidence review: RCTs published as full reports comparing NSAIDs with acetaminophen for patients with pain and/or disability related to OA of the hip or knee. At least one of the following outcomes included: overall change, pain or disability. Random allocation of interventions. For guidelines: Guidelines developed by a professional working working group of experts. Recommendations on pharmacological management of hip or knee OA. | 655 | 7 publications describing 5 RCTs, two of which were of cross-over design9 guidelines | All trials included patients with knee OA, and two included those with hip or knee OA. | 7 different types of NSAIDs, including 3 coxibs within recommended dose ranges were compared to acetaminophen with daily doses ranging from 2600 mg to 4000 mg. Mean duration of trail period from which data were drawn was 49 ± 25 days, with a range of 24 – 84 days. | Rest pain (Based on 5 trials with 1208 subjects)Overall improvement using pooled data: inverse-variance-weighted mean difference (WMD) = −6.33 (95%CI −9.24, −3.41) and an average ES of 0.23 favoring NSAID-treated groups. In 3/6 studies, there was a reduction in rest pain favoring NSAIDs (p<0.05)Walking pain (Based on 6 trials with 1051 subjects)Pooled data demonstrated a WMD of −5.76 (95% CI −8.99, −2.52) and an average ES of 0.23 favoring NSAID-treated groups. | Not reported | Dropouts due to adverse eventsAll NSAID groups: 63/752 (8.4%)High dose NSAID groups only: 48/497 (9.7%)Acetaminophen: 32/500 (6.4%)The overall safety measure derived from pooled data for dropouts due to AEs showed no statistically significant difference between NSAID vs acetaminophen (OR 1.45; 95% CI 0.93, 2.27). Specific types of AEs resulting in withdrawal were not discernable due to lack of data in primary studies. | No data on specific AEs
Zhang, 2004 | To assess best available the evidence for efficacy of paracetamol (acetaminophen) in the treatment of osteoarthiritis (OA). | 1966 through July, 2003 | RCTs comparing paracetamol with placebo or NSAIDs for treatment of OA (radiographic evidence or ACR clinical criteria) or OA pain. | 1712 | 10 RCTs: 5 double blind parallel, 3 double blind crossover, one “n of 1′ and one undefined RCT(abstract only) design | Patients with either symptomatic OA of the knee (6 trials) or hip/knee (3 trials) or multiple joints (1 trial). | 5 types of NSAIDs were compared to acetaminophen with daily doses ranging from 2600 mg/d to 6000 mg/d. Trial periods ranged from 7 days to 2 years. | General pain/rest pain (Based on 3 trials, OA of hip or knee, 4 – 6 weeks follow-up) Pooled standardized mean difference of 0.33 (95% CI 0.15 – 0.51), indicating a small effect in favor of NSAIDs. Pain on motion, comparison with high dose ibuprofen: 0.24 (0.00, 0.48); with low dose: 0.18 (−0.06, 0.42) Functional disability, comparison with high dose ibuprofen: 0.19 (0.01, 0.37); with low dose: 0.18 (0.00, 0.35) Overall change (physician assessment): 0.22 (0.02, 0.43) 3/9 guidelines satisfied more AGREE criteria than others, especially rigor of development. Most guidelines had poor descriptions of stakeholder involvement, applicability and editorial independence were poorly described in most guidelines. The recommendations on use of NSAIDs or acetaminophen was fairly consistent. | Not reported | Not reported | Main results based on 3 trials with a total n of 589 Baseline pain levels not accounted for in analysis

Author Year | (1) Is there a clear review question? | (2) Were there explicit inclusion/exclu sion criteria reported relating to selection of the primary studies? | (3) Is there evidence of a substantial effort to search for all relevant research? | (4) Was the literature search strategy stated? | (5) Is the validity of included studies adequately assessed? | (6) Is there sufficient detail of the individual studies presented? | (7) Are there any important studies missing? | (8) Are the primary study summarized appropriately?
Lee 2004 | Yes | yes | yes | yes | yes | yes | Amadio 1983, Bradley 1992, Zoppi 1995 | Yes
Towheed 2005 | yes | yes | yes | yes | yes | yes | March 1994 awaiting assessment, Bradley 1992, Solomon 1974, Zoppi 1995 not included. Specific information on excluded studies not provided | Baseline pain levels not controlled. Specific data on how pooled SMDs were derived was not provided on tables
Wegman 2004 | yes | yes | yes | yes | yes | yes, although not much detail on study designs | Amadio 1983 March 1994 Zoppi 1995 Specific information on excluded studies not provided | yes Baseline pain levels not controlled
Zhang 2004 | yes | yes | yes | yes | Not sure - method of randomization not assessed, and only randomization, masking & withdrawal considered | One was abstract only | Altman 1999 Bradley 1992 Solomon 1974 Specific information on excluded studies not provided. | An “n of 1′ study included, as well as an abstract only study

Evidence Table 12[1]

Topical NSAIDs trials

| | | | | | | | | | | | | | Internal Validity | | | | | | External Validity
Author Year (Quality Score) | Eligibility criteria | Interventions (drug, dose, duration) | Run-in/Washout Period | Allowed other medications/interventions | Method of Outcome Assessment and Timing of Assessment | Age Gender Ethnicity | Other population characteristics (diagnosis, etc) | Number screened/ eligible/ enrolled | Number withdrawn/ lost to fu/ analyzed | Results | Method of adverse effects assessment? | Adverse Effects Reported | Total withdrawals; withdrawals due to adverse events | Randomization adequate? | Allocation concealment adequate? | Groups similar at baseline? | Eligibility criteria specified? | Outcome assessors masked? | Care provider masked? | Patient masked? | Reporting of attrition, crossovers, adherence, and contamination | Loss to follow-up: differential/high | Intention- to-treat (ITT) analysis | Post- randomization exclusions | Quality Rating | Number screened/eligible/enrolled | Exclusion criteria | Run-in/Washout | Class naïve patients only | Control group standard of care | Funding
Tugwell 2004 | Men and nonpregnant women 40 to 85 years old, with symptomatic primary OA of the knee and recent (<3 months) x-ray showing osteoarthritis (confirmed by radiologist) | Topical diclofenac solution (Pennsaid, 1.5% diclofenac sodium + 45.5% DMSO) tid Oral diclofenac 50 mg po tid 12 weeks | 3–10 days | Aspirin up to 325 mg/day for cardiovascular prophylaxis | Pain and physical function (WOMAC VA3.1 OA Index) Patient Global Assessment (100 mm VAS) Stiffness by WOMAC stiffness dimension Responder defined as >50% improvement in pain or function of >20 mm on VAS or >20% improvement in at least two of pain, function, or patient global assessment of >10 mm on VAS All assessments at baseline and week 12 | Mean age=63.5 57% female 94% white | Mean OA duration not reported Total x-ray score 6.4 vs. 6.2 WOMAC composite indes (pain): 288 vs. 289 | 1057/NR/622 | 18 not included in ITT analysis b/c they did not have primary OA or did not take any medication 39% (245) withdrawn/10 lost to follow-up/604 analyzed in ITT analysis and 492 in per-protocol analysis | Topical vs. oral diclofenac (intention-to-treat analyses) Mean changes from baseline WOMAC pain (0–500 mm): −134 vs. −118, NS WOMAC physical function (0–1700 mm): −348. - 438p=0.06 WOMAC stiffness (0–200 mm): −45 vs. −52, NS Patient global assessment (0–100 mm): −27 vs. −32, NS Number of responders: 66% vs. 70%, NS | Not clear how adverse events identified; categorized according to COSTART, severe AE pre-defined as one causing significant impairment of function or incapaciation and definite hazard to patient’s health; adverse events defined according to Compendium of Pharmaceuticals and Specialties | Topical (n=311) vs. oral (n=311) diclofenac All GI events: 35% vs. 48%, p=0.0006 Abdominal pain: 12% vs. 22%, p=0.0008 Diarrhea: 9% vs. 17%, p=0.001 Dyspepsia: 15% vs. 26%, p=0.001 Flatulence: 10% vs. 17%, p=0.009 Melena: 1% vs. 2%, NS Nausea: 25% vs. 41%, p=0.4 Dry skin: 27% vs. 1%; p<0.0001 Rash: 12% vs. 2%, p<0.0001 Vesiculobullous rash: 5% vs. 0%, p<0.0001 Asthma: 0.6% vs. 3%, p=0.02 Dizziness: 0.6% vs. 4%, p=0.002 Dyspnea: 0% vs. 2%, p=0.01 | 30% vs. 30% withdrawals due to AE or lack of effect 21% vs. 26% withdrawal due to adverse events | yes | yes | yes | yes | yes | yes | yes | no/no/no/no | no | yes | no | good | 1057/NR/622 | Secondary arthritis related to syphilitic neuropathy; ochronosis; psoriasis; metabolic bone disease; acute trauma; chondrocalcinosis with a history of pseudogout; fibromyalgia; previous major surgery to the knee or recommendation for knee replacement/reconstruction; recent intra-articular viscosupplementation; current or recent corticosteroid use; topical product use at the application site; history of sensitivity to any of the study drugs, acetylsalicylic acid or other NSAID; severe, uncontrolled cardia, renal hepatic or other systemic disease; documented recent gastroduodenal ulcer or GI bleedind; history of alcohol of other drug abuse; lactationl concomitant skin diseases at the application site; clinically significant elevation of serum creatinine or of AST or ALT; previous participation in a clinical trial within 30 days. | run-in NR/washout 3–10 days | no | NA | Dimethaid Healthcare Ltd.
Bookman 2004 | Primary OA in at least 1 knee, verified radiologically with previous 6 months and at least moderate pain in 2 weeks before randomization | Topical diclofenac solution (Pennsaid, 1.5% diclofenac sodium + 45.5% DMSO) qid DMSO solution qid Placebo solution qid4 weeks | 1-week washout for patients on NSAIDs | Aspirin up to 325 mg/day for cardiovascular prophylaxis Acetaminophen up to 650 mg qid except during 24 hours prior to baseline and final WOMAC assessments | Patient Global Assessment of arthritis (0=very good to 4=very poor): Weekly Western Ontario and McMaster Universities Osteoarthritis (WOMAC): Daily Pain on walking (first question of WOMAC pain dimenstion): Daily | Mean age=62 63% female Race not reported | Mean OA duration NR Baseline WOMAC pain score (mean VAS):9.1 vs. 9.3 vs. 9.4 | 267/262/248 | 14% (35) withdrawn/lost to f/u not reported/247 analyzed | Topical diclofenac (A) vs. DMSO control (B) vs. placebo control (C) (intention-to-treat analyses) Mean changes from baseline WOMAC pain: −4 vs. −2.5 vs −2.5, p<0.05 for A vs. C WOMAC physical function: −11.6 vs. −5.7 vs. −7.1, p<05 for A vs. C, p<0.01 for A vs. B WOMAC stiffness: −1.5 vs. −0.7 vs. −0.6, p<0.01 for A vs. C, p<0.05 for A vs. B Pain on walking: −0.8 vs. −0.4 vs. −0.6, p<0.05 for A vs. C, p<0.01 for A vs. B Patient global assessment (mean summary score from weeks 1, 2, 3, and 4): 6.7 vs. 7.8 vs. 7.8, p<0.05 for A vs. C and A vs. B Mean acetaminophen use (tablets): 36.2 vs. 49.5 vs. 54.9, NS | Patient-recorded, GI complaints assessed by investigators weekly using checklist and dermatological exam performed | Topical diclofenac (n=84) vs. DMSO control (n=80) vs. placebo control (n=80) Minor skin dryness or flakiness: 36% vs. 14% vs. 1% Rash: 13% vs. 8% vs. 4% Paresthesia: 14% vs. 22% vs. 6% GI side effects: No differences | 12% vs. 18% vs. 18% withdrawals 6% vs. 4% vs. 0% withdrawal due to adverse events | yes | yes | yes | yes | yes | yes | yes | no/no/no/no | no | yes | no | good | 267/262/248 | Secondary arthritis related to syphilitic neuropathy; ochronosis; psoriasis; metabolic bone disease; acute trauma; sensitivity to diclofenac, ASA or other NSAID, DMSO, propylene glycol, glycerin or ethanol; clinically active renal, hepatic or peptic ulcer disease; history of alcohol or drug abuse; lactation; concomitant skin disease at application site; corticosteroid use; use of another topical product at the application site; oral use of analgesic or glucosamine. | run-in NR/ washout 7 days (NSAIDs) | no | yes | Dimethaid Healthcare Ltd.
Roth2004 | Men and nonpregnant women 40 to 85 years old, with symptomatic primary OA of the knee and recent (<3 months) x-ray showing osteoarthritis who had flare of pain after washout of stable therapy | Topical diclofenac solution (Pennsaid, 1.5% diclofenac sodium + 45.5% DMSO) qidDMSO solution qid12 weeks | Washout with flare (at least 3 days per week for 1 month) required for enrollment | Aspirin up to 325 mg/day for cardiovascular prophylaxisAcetaminophen up to 4 325 mg tabs/day allowed except for 3 days prior to prior to scheduled final assessment | Patient Global Assessment (0=very good to 4=very poor)Western Ontario and McMaster Universities Osteoarthritis (WOMAC) pain, physical function, stiffness subscalesPain on walking (first question of WOMAC pain dimenstion)Timing of outcome assessment not clear | Mean age=64.168% femaleRace not reported | Mean OA duration NRBaseline WOMAC pain score (mean VAS): 13 vs. 13 | 568/466/326 | 30% (98) withdrawn/3 lost to FU/322 analyzed | Topical diclofenac vs. DMSO control (intention- to-treat analyses)Mean changes from baselineWOMAC pain: −5.9 vs. −4.3, p<0.005WOMAC physical function: −15.4 vs. −10.1, p<0.005Patient global assessment: −1.3 vs. −0.9, p<0.005WOMAC stiffness: −1.8 vs. −1.3, p<0.01 | Open-ended questions and checklist questionnaire used at each clinic visit and with telephone visits. Dermatological assessment at clinic visits. | Topical diclofenac (n=164) vs. DMSO control (n=162)GI side effects: No differencesDry skin: 37% vs. 25%, p<0.05Rash: 11% vs. 5%, p<0.05 | 27% vs. 33% withdrawals4.8% vs. 2.5% withdrawal due to adverse events | yes | yes | yes | yes | yes | unclear | yes | no/no/no/no | no | yes | no | good | 568/428/326 | Secondary arthritis related to systemic inflammatory arthritis; sensitivity to diclofenac, aspirin or any other NSAID, dimethyl sulfoxide, propylene glycol, glycerin, or ethanol; clinically active renal, hepatic, or peptic ulcer disease; a history of alcohol or other drug abuse; lactation; concomitant skin disease at the application site; corticosteroid use, including oral corticosteroid within 14 days, intramuscular corticosteroid within 30 days, intra-articular corticosteroid into the study knee within 90 days, intra-articular corticosteroid into any other joint within 30 days of study entry, or ongoing use of topical corticosteroid at the site of application; use of a topical product, treatment, or device at the application site for the relief of OA; ongoing use of prohibited medication, including NSAIDs, oral analgesic, muscle relaxant, or low-dose antidepressant; ongoing use of glucosamine or chondroitin sulfate sodium (unless used continuously for 90 days before study entry); intra-articular viscosupplementation (eg, hyaluronate sodium derivative) into the study knee in the preceding 90 days; current application for disability benefits on the basis of OA of the knee; fibromyalgia; and other painful or disabling condition affecting the knee. | run-in NR/washout 3 days | no | yes | Dimethaid Healthcare Ltd.
Trnavsky 2004 | Men and women 40 to 75 years old with primary knee osteoarthritis, chronic and decompensated accordignt to classification criteria of the American College of Rheumatology | Topical ibuprofen (Dolgit 5% ibuprofen cream) tid Placebo tid 7 days | Washout of 1 to 60 days if patients were on other drugs for OA | Acetaminophen only allowed during washout | Percent responder (reduction of at least 18 mm on 100 point VAS for pain, or at least 23% from baseline) Pain with motion (0 to 100 mm VAS) Pain at rest and overall pain (0 to 100 mm VAS) Lequesne index (measures pain, maximum distance walked, and activities of daily living) (maximum score 24) Patient/investigator global assessment of efficacy (0=bad to 4=very good) | Mean age=67 78% female Race not reported | Mean OA duration NR Baseline pain (0 to 100 mm VAS) score: 63 vs. 59 | Not clear/not clear/50 | None withdrawn/lost to follow-up/50 analyzed in intention-to-treat analysis | Topical ibuprofen vs. placebo (intention-to-treat analysis) Proportion of responders: 21/25 (84%) vs. 10/25 (40%), p<0.0001 Patient global assessment (good or very good): 17/25 (68%) vs. 4/26 (16%), p not reported Mean changes from baseline (100 mm VAS) Pain on motion: −31.4 vs. −6.9 Pain on rest: −23.5 vs. −10.3 Overall pain: −22.6 vs. −12.3 Mean change from baseline (24 point scale) Lequesne index: −2.9 vs. −0.9 | Not reported | No adverse events recorded | 4% vs. 0% withdrawals No withdrawals due to adverse events | yes | yes | yes | yes | yes | yes | yes | no/no/no/no | no | yes | no | good | 50/NR/50 | Secondary OA; obesity (body mass index ≥ 30 kg/m2); chronic painful disease of the hip or the ankle joint; allergic diathesis, bronchial asthma, or known hypersensitivity to NSAID; eczematous skin eruption; any physiotherapy. | run-in NR/ no washout (exception: 1–60 day washout for pts with previous treatment with drugs having a therapeutic effecton the knee joint) | no | yes | Dolorgiet Pharmaceuticals (Germany