# Exact Search Strings

Ovid MEDLINE® searches (1966 to July Week 3 2005)

I. Search Strategy: NSAIDs, focus on efficacy (OA)
1 | exp OSTEOARTHRITIS/(26153)
2 | limit 1 to (humans and english language) (18162)
3 | celecoxib.mp. (1545)
4 | choline magnesium trisalicylate.mp. (38)
5 | DICLOFENAC/(3399)
6 | DIFLUNISAL/(380)
7 | ETODOLAC/(284)
8 | FENOPROFEN/(257)
9 | FLURBIPROFEN/(1184)
10 | IBUPROFEN/(4177)
11 | INDOMETHACIN/(23527)
12 | KETOPROFEN/(1443)
13 | KETOROLAC/(723)
14 | meclofenamate sodium.mp. (51)
15 | Mefenamic Acid/(764)
16 | meloxicam.mp. (522)
17 | nabumetone.mp. (350)
18 | NAPROXEN/(2378)
19 | oxaprozin.mp. (121)
20 | PIROXICAM/(1920)
21 | salsalate.mp. (74)
22 | SULINDAC/(923)
23 | TOLMETIN/(1255)
24 | valdecoxib.mp. (183)
25 | 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 (40472)
26 | limit 25 to (humans and english language) (17770)
27 | 2 and 26 (1094)
28 | Comparative Study/(1202473)
29 | Cohort Studies/(57012)
30 | Randomized Controlled Trials/(38090)
31 | 27 and (28 or 29 or 30) (532)
32 | from 31 keep 1–532 (532)

II. Search Strategy: NSAIDs, focus on adverse events (OA & RA)
1 | Arthritis, Rheumatoid/(53548)
2 | limit 1 to (humans and english language) (37493)
3 | celecoxib.mp. (1545)
4 | choline magnesium trisalicylate.mp. (38)
5 | *DICLOFENAC/ae [Adverse Effects] (374)
6 | *DIFLUNISAL/ae [Adverse Effects] (27)
7 | *ETODOLAC/ae [Adverse Effects] (19)
8 | *FENOPROFEN/ae [Adverse Effects] (41)
9 | *FLURBIPROFEN/ae [Adverse Effects] (41)
10 | *IBUPROFEN/ae [Adverse Effects] (356)
11 | *INDOMETHACIN/ae [Adverse Effects] (678)
12 | *KETOPROFEN/ae [Adverse Effects] (109)
13 | *KETOROLAC/ae [Adverse Effects] (16)
14 | meclofenamate sodium.mp. (51)
15 | *Mefenamic Acid/ae [Adverse Effects] (67)
16 | meloxicam.mp. (522)
17 | nabumetone.mp. (350)
18 | *NAPROXEN/ae [Adverse Effects] (269)
19 | oxaprozin.mp. (121)
20 | *PIROXICAM/ae [Adverse Effects] (130)
21 | salsalate.mp. (74)
22 | *SULINDAC/ae [Adverse Effects] (116)
23 | *TOLMETIN/ae [Adverse Effects] (74)
24 | valdecoxib.mp. (183)
25 | 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 (4875)
26 | limit 25 to (humans and english language) (3433)
27 | 2 and 26 (357)
28 | Cohort Studies/(57012)
29 | Comparative Study/(1202473)
30 | Randomized Controlled Trials/(38090)
31 | 27 and (28 or 29 or 30) (128)
32 | from 31 keep 1–128 (128)

III. Search Strategy: Aspirin/acetaminophen
1 | exp OSTEOARTHRITIS/(26153)
2 | limit 1 to (humans and english language) (18162)
3 | ASPIRIN/(26642)
4 | ACETAMINOPHEN/(8992)
5 | 2 and (3 or 4) (323)
6 | exp Arthritis, Rheumatoid/(71858)
7 | limit 6 to (humans and english language) (50057)
8 | *ASPIRIN/ae [Adverse Effects] (2386)
9 | *ACETAMINOPHEN/ae [Adverse Effects] (719)
10 | 7 and (8 or 9) (81)
11 | 5 or 10 (400)
12 | Cohort Studies/(57012)
13 | Comparative Study/(1202473)
14 | Randomized Controlled Trials/(38090)
15 | 11 and (12 or 13 or 14) (158)
16 | from 15 keep 1–158 (158)

IV. Search Strategy: Topical analgesics
1 | exp OSTEOARTHRITIS/(26153)
2 | limit 1 to (humans and english language) (18162)
3 | (topical and capsaicin).mp. [mp=title, original title, abstract, name of substance word, subject heading word] (614)
4 | (topical and diclofenac).mp. [mp=title, original title, abstract, name of substance word, subject heading word] (356)
5 | (topical and ibuprofen).mp. [mp=title, original title, abstract, name of substance word, subject heading word] (137)
6 | (topical and ketoprofen).mp. [mp=title, original title, abstract, name of substance word, subject heading word] (114)
7 | (topical and salicylate).mp. [mp=title, original title, abstract, name of substance word, subject heading word] (160)
8 | 2 and (3 or 4 or 5 or 6 or 7) (40)
9 | exp Arthritis, Rheumatoid/(71858)
10 | 9 and (3 or 4 or 5 or 6 or 7) (11)
11 | 8 or 10 (49)
12 | from 11 keep 1–49 (49)

CDSR/CRCT searches (through 3 ^rd^ Quarter 2005)

I. Search Strategy: NSAIDs, focus on efficacy (OA)
1 | exp OSTEOARTHRITIS/(1546)
2 | limit 1 to (humans and english language) (1546)
3 | celecoxib.mp. (219)
4 | choline magnesium trisalicylate.mp. (29)
5 | DICLOFENAC/(878)
6 | DIFLUNISAL/(90)
7 | ETODOLAC/(70)
8 | FENOPROFEN/(35)
9 | FLURBIPROFEN/(272)
10 | IBUPROFEN/(776)
11 | INDOMETHACIN/(1224)
12 | KETOPROFEN/(299)
13 | KETOROLAC/(279)
14 | meclofenamate sodium.mp. (37)
15 | Mefenamic Acid/(92)
16 | meloxicam.mp. (133)
17 | nabumetone.mp. (141)
18 | NAPROXEN/(645)
19 | oxaprozin.mp. (47)
20 | PIROXICAM/(447)
21 | salsalate.mp. (31)
22 | SULINDAC/(119)
23 | TOLMETIN/(360)
24 | valdecoxib.mp. (56)
25 | 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 (5040)
26 | limit 25 to (humans and english language)(5040)
27 | 2 and 26 (555)
28 | Comparative Study/(96540)
29 | Cohort Studies/(2139)
30 | Randomized Controlled Trials/(4538)
31 | 27 and (28 or 29 or 30) (402)

II. Search Strategy: NSAIDs, focus on adverse events (OA & RA)
1 | Arthritis, Rheumatoid/(2385)
2 | limit 1 to (humans and english language) (2385)
3 | celecoxib.mp. (219)
4 | choline magnesium trisalicylate.mp. (29)
5 | *DICLOFENAC/ae [Adverse Effects] (39)
6 | *DIFLUNISAL/ae [Adverse Effects] (6)
7 | *ETODOLAC/ae [Adverse Effects] (3)
8 | *FENOPROFEN/ae [Adverse Effects] (2)
9 | *FLURBIPROFEN/ae [Adverse Effects] (5)
10 | *IBUPROFEN/ae [Adverse Effects] (40)
11 | *INDOMETHACIN/ae [Adverse Effects] (61)
12 | *KETOPROFEN/ae [Adverse Effects] (9)
13 | *KETOROLAC/ae [Adverse Effects] (6)
14 | meclofenamate sodium.mp. (37)
15 | *Mefenamic Acid/ae [Adverse Effects] (0)
16 | meloxicam.mp. (133)
17 | nabumetone.mp. (141)
18 | *NAPROXEN/ae [Adverse Effects] (62)
19 | oxaprozin.mp. (47)
20 | *PIROXICAM/ae [Adverse Effects] (19)
21 | salsalate.mp. (31)
22 | *SULINDAC/ae [Adverse Effects] (11)
23 | *TOLMETIN/ae [Adverse Effects] (0)
24 | valdecoxib.mp. (56)
25 | 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 (846)
26 | limit 25 to (humans and english language) [Limit not valid in: CDSR,ACP Journal Club,DARE,CCTR; records were retained] (846)
27 | 2 and 26 (98)
28 | Cohort Studies/(2139)
29 | Comparative Study/(96540)
30 | Randomized Controlled Trials/(4538)
31 | 27 and (28 or 29 or 30) (73)

III. Search Strategy: Aspirin/acetaminophen
1 | exp OSTEOARTHRITIS/(1546)
2 | limit 1 to (humans and english language) (1546)
3 | ASPIRIN/(3028)
4 | ACETAMINOPHEN/(1128)
5 | 2 and (3 or 4) (115)
6 | exp Arthritis, Rheumatoid/(2730)
7 | limit 6 to (humans and english language) (2730)
8 | *ASPIRIN/ae [Adverse Effects] (271)
9 | *ACETAMINOPHEN/ae [Adverse Effects] (32)
10 | 7 and (8 or 9) (10)
11 | 5 or 10 (124)
12 | Cohort Studies/(2139)
13 | Comparative Study/(96540)
14 | Randomized Controlled Trials/(4538)
15 | 11 and (12 or 13 or 14) (90)

IV. Search Strategy: Topicals
1 | exp OSTEOARTHRITIS/(1546)
2 | limit 1 to (humans and english language) (1546)
3 | (topical and capsaicin).mp. [mp=ti, ab, tx, kw, ct, ot, sh, hw] (123)
4 | (topical and diclofenac).mp. [mp=ti, ab, tx, kw, ct, ot, sh, hw] (199)
5 | (topical and ibuprofen).mp. [mp=ti, ab, tx, kw, ct, ot, sh, hw] (69)
6 | (topical and ketoprofen).mp. [mp=ti, ab, tx, kw, ct, ot, sh, hw] (46)
7 | (topical and salicylate).mp. [mp=ti, ab, tx, kw, ct, ot, sh, hw] (44)
8 | 2 and (3 or 4 or 5 or 6 or 7) (18)
9 | exp Arthritis, Rheumatoid/(2730)
10 | 9 and (3 or 4 or 5 or 6 or 7) (6)
11 | 8 or 10 (22)