# Comparable NSAID Dose Levels

Non-selective NSAIDs | Low Dose | Medium Dose | High or Max Dose
Diclofenac potassium | 50mg bid | 50mg tid | 50mg qid (in OA/RA only)
Diclofenac sodium | 50mg bid | 75mg bid | 50mg qid or 100mg SR bid (in RA only)
Fenoprofen | 200–300mg qid | 600mg tid-qid | 800mg qid
Flubriprofen | 50mg bid | 50mg tid-qid | 100mg tid
Ibuprofen | 400mg tid | 600mg tid-qid | 800mg qid^*,*^
Ketoprofen | 25–50mg tid | 75mg tid | IR =300mg/day (divide), SR =200mg/day
Naproxen | 250mg tid | 500mg bid | 1250mg/day (divided)
Naproxen sodium | 275mg tid | 550mg bid | 1375mg/day (divided)
Oxaprozin | 600mg qd | 1200mg qd | 1200mg qd
Sulindac | 150mg bid | 200mg bid | 200g bid
Piroxicam | 10mg qd | 20mg qd | 40mg per day (not indicated for OA or RA)
Partially-selective NSAIDs | Low Dose | Medium Dose | High or Max Dose
Etodolac | 200mg tid | 400mg bid | 1200mg max (IR or SR divided doses)
Meloxicam/Mobic | 7.5mg qd | 7.5mg qd | 15mg qd
Nabumetone | 1000mg qd | 1000mg bid | 2000mg/day (qd or divided bid)
Cox-2 inhibitors | Low Dose | Medium Dose | High or Max Dose
Celecoxib/Celebrex | 200mg qd | 200mg bid | 200mg bid
Rofecoxib/Vioxx | 12.5mg qd | 25mg qd | 50mg qd for max of 5 days (acute pain)
Valdecoxib/Bextra | 10mg qd | 10mg qd | 20mg bid (primary dysmenorrhea only)

* This table does not represent exact or equivalent dosing conversions. It is based on FDA approved dosing ranges and comparative doses from clinical trials.

Source: http://www.ashp.org/emplibrary/NSAIDsConversiontools.pdf