# Cyclooxygenase Selectivity of NSAIDs

NSAID | Ratio^*^
Flurbiprofen | 10.27
Ketoprofen | 8.16
Fenoprofen | 5.14
Tolmetin | 3.93
Aspirin | 3.12
Oxaprozin | 2.52
Naproxen | 1.79
Indomethacin | 1.78
Ibuprofen | 1.69
Ketorolac | 1.64
Piroxicam | 0.79
Nabumetone | 0.64
Etodolac | 0.11
Celecoxib | 0.11
Meloxicam | 0.09
Mefenamic acid | 0.08
Diclofenac | 0.05
Rofecoxib | 0.05
Nimesulide | 0.04

* Expressed as the ratio of the 50% inhibitory concentration of cycloogenase-2 to the 50% inhibitory concentration of cyclooxygenase-1 in whole blood. NSAIDs with a ratio of <1 indicate selectivity for cyclooxygenase-2.

Adapted from: Feldman M, McMahon AT. Do cyclooxygenase-2 inhibitors provide benefits similar to those of traditional nonsteroidal anti-inflammatory drugs, with less gastrointestinal toxicity? Annals of Internal Medicine 2000;132:134–43.