# Pharmacokinetics, Indications and Dosing of Included Drugs

Drug and Trade Name (Trade names provided only for drugs under patent.) | Half-life or other relevant pharmacokinetic feature | Labeled indications | Dosing (oral doses) | Dose adjustments for special populations
acetaminophen | Elimination half-life normally 2–4 hours, longer in children and possibly elderly. | Fever;Pain | Pain: 650–1000 mg up to 4g/day | Peds: 10–15 mg/kg/dose up to 5 doses/day
aspirin | Elimination half-life 4.7 to 9 hours Low dose (< 1gm) shortens half-life to 2.5 to 7 hours, high dose of (>10gm) half-life increases to as much as 19 hours | Arthritis; Cerebrovascular accident; Transient ischemia; Coronary artery bypass graft; Disorder of joint of spine; Fever; Juvenile rheumatoid arthritis; Myocardial infarction; Myocardial infarction; Prophylaxis; Osteoarthritis; Pain; Percutaneous coronary intervention; Pleurisy; Systemic lupus erythematosus; Rheumatoid arthritis; Stable angina, chronic; Unstable angina | OA and RA: 3g/day divided into 4–6 doses | Peds: 40–130 mg/kg/day depending on condition
celecoxib (Celebrex®) | Elimination half-life - 11 hrs. | Ankylosing spondylitis; Familial multiple polyposis; syndrome Osteoarthritis; Pain; Primary dysmenorrheal; Rheumatoid arthritis | OA: 200mg/day RA: 200–400 mg/day | Renal impairment: reduce dosage by 50%; Elderly patients (weight <50 kg): initiate at lowest dosage
choline magnesium trisalicylate | Elimination half-life: 9–17 hrs | Rheumatoid arthritis; Osteoarthritis; Acute shoulder pain; Fever | OA and RA: 1,500 mg 2x/day or 3,000 mg 1x/day | Renal impairment: initiate with lowest recommended dosage, monitor closely
diclofenac | Elimination half-life - 2 hours | Ankylosing spondylitis; Extraction of cataract; Inflammatory disorder of the eye; Light intolerance; Pain in eye; Refractive keratoplasty; Osteoarthritis; Pain; Rheumatoid arthritis | OA: Delayed- release, 100–150 mg/day in 2–3 doses; Extended- release, 100–200 mg/day RA: Delayed- release, 100–200 mg/day in 3–4 doses; Extended- release, 75–225 mg/day | Renal impairment: initiate with lowest recommended dosage, monitor closely
diflunisal | Elimination half-life: 8 – 12 hrs (dose dependent) | Osteoarthritis; Pain (Mild to Moderate); Rheumatoid arthritis | OA and RA: 500–1000 mg/day in 2 divided doses; max dose/day 1500 mg | Renal impairment and elderly: begin at lowest dose possible and monitor closely
etodolac | Elimination half-life - 6–7 hrs | Juvenile rheumatoid arthritis; Osteoarthritis; Pain, acute; Rheumatoid arthritis | OA and RA initial treatment: immediate release, 300 mg 2–3x/day or 400–500 mg 2x/day OA and RA maintenance: extended release, 400–1000 mg/day; immediate release, 600–1000 mg/day 2–4x/day with max. dose of 1200 mg/day | Juvenile RA: extended release- 20–30 kg: 400 mg once a day; 31–45 kg: 600 mg once a day; 46–60 kg: 800 mg once a day; greater than 60 kg: 1000 mg once a day
fenoprofen | Elimination half-life - 3 hrs | Migraine; Osteoarthritis; Pain (Mild to Moderate); Rheumatoid arthritis | OA and RA: 300 to 600 mg, divided 3–4x/day to max dose 3200 mg/day | Elderly: smaller dose recommended (300 mg 3x/day) Renal impairment: no dosage adjustment necessary
flurbiprofen | Elimination half-life range- 3.36 to 11.55 hrs | Constricted pupil, intraoperative prophylaxis; Osteoarthritis; Rheumatoid arthritis | OA and RA: 200–300 mg divided 2–4x/day; max 300 mg/day | Renal impairment, liver disease and geriatric patients: start with the lowest recommended dosage; monitor patient closely
ibuprofen | Elimination half-life 1.8 to 2 hrs (1.6 hrs peds); prolonged in patients with cirrhosis | Fever; Juvenile rheumatoid arthritis; Osteoarthritis; Pain, Minor; Pain (Mild to Moderate); Primary dysmenorrheal; Rheumatoid arthritis | OA and RA: 1200–3200 mg/day divided in 3–4 doses | Renal impairment: initiate with the lowest recommended dosage, monitor patient closely
indomethacin | Elimination half-life 4.5 hrs, 3.2 hrs in elderly | Ankylosing spondylitis; Bursitis of shoulder – Pain, acute – Shoulder pain; Gouty arthritis, acute; Osteoarthritis; Pain, acute – Shoulder pain – Tendinitis; Patent ductus arteriosus; Rheumatoid arthritis | OA and RA: 25–50 mg 2–3x/day max 200 mg/day, 100 mg/dose; sustained-release product, 75 mg 1–2/day | Severe renal impairment: (CrCL less than 15 mL/min), liver disease (Child-Pugh Class III), elderly & peds: initiate with lowest recommended dosage, monitor patient closely
ketoprofen | Elimination half-life – 2 to 4 hours. Controlled release, the elimination half- life is 5.4 +/− 2.2 hours. The half-life increases in elderly and in patients with decreased creatinine clearances | Fever; Osteoarthritis; Pain, Minor; Pain (Mild to Moderate); Primary impairment al; Rheumatoid arthritis | OA and RA: immediate- release: 150–300 mg/day divided 3–4x; extended- release: 100–200 mg 1x/day | Mild renal impairment(CrCl >25 mL/min) max 150 mg/day; Moderate renal impairment (CrCl l<25 mL/min) max 100 mg/day; Geriatric(> 75 yrs) initiate with doses of 75–150 mg/day; Liver disease and serum albumin less than 3.5 g/dL maximum initial dose 100 mg/day
ketorolac | Elimination half-life – 5.6 hours. Elderly – 4.3 to 7.6 hours; Hepatic dysfunction – 1.6 to 7.6 hours; Renal impairment – 3.4 to 18.9 hours Pediatric (4–8yrs) – 6.1 hours | Extraction of cataract – Inflammatory disorder of the eye; Light intolerance – Pain in eye – Refractive keratoplasty; Pain, acute (Moderate to Severe); Seasonal allergic conjunctivitis | Pain, acute (Moderate to Severe): <65 yrs initiate with 20 mg followed by 10 mg every 4–6 hours, max 40 mg/day | Peds: use lowest effective dose for shortest possible duration >65 yrs or weight <50kg or renal impairment: 10 mg every 4–6 hours as needed, max 40 mg/day
meclofenamate sodium | Elimination half-life : 0.8 – 5.3 hrs | Dysmenorrhea; Menorrhagia; Osteoarthritis; Pain; Rheumatoid arthritis | OA and RA: 200 – 400 mg/day in 3 to 4 equally divided doses, max 400 mg/day | Elderly and renal impairment: lowest effective dose for shortest possible duration
mefenamic acid | Elimination half-life: 2 – 3 hrs | Dysmenorrhea; Pain | Pain (children >14yrs and adults): 500mg initially, followed by 250 mg every 6 hours; use beyond one week is not recommended | Renal impairment: do not use Peds: use not studied
meloxicam | Elimination half-life: 15–20 hrs | Juvenile rheumatoid arthritis, polyarticular - Pauciarticular juvenile rheumatoid arthritis; Osteoarthritis; Rheumatoid arthritis | OA and RA: 7.5 mg 1x/day day, max 15 mg 1x/day | Elderly, renal impairment, liver disease (Child-Pugh Class III): initiate with the lowest recommended dosage, monitor patient closely,
nabumetone | Elimination half-life unknown | Osteoarthritis; Rheumatoid arthritis | OA and RA: initial 1000 mg/day; maintenance 1000–2000 mg/day divided 1–2 times | Renal impairment and liver disease: monitor closely and reduce dosage if necessary
naproxen | Elimination half-life: 12–15 hrs | Ankylosing spondylitis; Bursitis; Fever; Gout, acute; Juvenile rheumatoid arthritis; Osteoarthritis; Pain; Pain, Minor; Primary dysmenorrheal; Rheumatoid arthritis; Tendinitis | OA and RA: 250–500 mg 2x/day mAX 1500 mg/day for up to 6 months; over- the-counter dosing, do not take longer than 10 days | Juvenile RA: 10 mg/kg/day given in 2 divided doses; Renal impairment and liver disease: monitor patient closely and reduce dosage if necessary
oxaprozin | Elimination half-life: 24–69 hours | Juvenile rheumatoid arthritis; Osteoarthritis; Rheumatoid arthritis | OA and RA: 1200 mg 1x/day, max 1800 mg/day or 26 mg/kg/day | Juvenile RA: 22–31 kg, 600 mg 1x/day; 32–54 kg, 900 mg 1x/day; >55 kg 1200 mg 1x/day Renal impairment or weight <50kg: initial, 600 mg 1x/day monitor closely
piroxicam | Elimination half-life: 30–86 hrs | Osteoarthritis; Rheumatoid arthritis | OA and RA: 20 mg/day 1x/day or divide and give 2x/day | Renal impairment or liver disease: monitor patient closely and reduce dosage if necessary
rofecoxib (Vioxx®) | Elimination half-life: 17 hrs | Migraine, with or without aura, acute treatment; Osteoarthritis Pain Primary dysmenorrhea Rheumatoid arthritis | OA: 12.5 mg 1x/day, max 25 mg/day RA: 25 mg 1x/day | Hepatic impairment and elderly: lowest possible dose up to 12.5mg/day for hepatic patients Peds: 0.6mg/kg/day to max of 25 mg/day
salsalate | Elimination half-life: 1 hr | Inflammatory disorder of musculoskeletal system, Rheumatic; Osteoarthritis; Rheumatoid arthritis | OA and RA: 3000 mg/day in 2–3 divided doses | Elderly: lower dosages may be required for elderly patients Peds: safety and efficacy not established in pediatric patients
sulindac | Elimination half-life: 7.8 hrs | Bursitis of shoulder - Pain, acute - Shoulder pain; Gouty arthritis, acute; Osteoarthritis; Pain, acute - Shoulder pain – Tendinitis; Rheumatoid arthritis | OA and RA: 150 mg 2x/day max 400 mg/day | Renal impairment and liver disease: monitor closely and reduce dosage if necessary
tolmetin | Elimination half-life: 5 hrs | Juvenile rheumatoid arthritis; Osteoarthritis; Rheumatoid arthritis | OA and RA: initial, 400 mg 3x/day for 1–2 weeks OA and RA: maintenance, 200–600 mg 3x/day max 1800 mg/day | Renal impairment: initiate with the lowest recommended dosage, monitor closely and reduce dosage if necessary Juvenile RA: 2 yrs and older- initial, 20 mg/kg/day divided in 3 or 4 doses; maintenance, 15–30 mg/kg/day divided in 3 or 4 doses
topical capsaicin | n/a | Arthritis; Diabetic neuropathy; Postherpetic neuralgia | Arthritis: apply thin film 3–5x/day | Peds (>2 yrs): apply thin film 3–4x/day
valdecoxib (Bextra®) | Elimination half-life: 8–11 hrs | Osteoarthritis; Rheumatoid arthritis; Dysmenorrhoea. | OA and RA: 10 mg 1x/day | Moderate hepatic impairment (Child-Pugh Class B): treat with the lowest possible dosage not exceeding 10 mg with close monitoring. Avoid use in patients with severe liver dysfunction.