# Appendixes

Appendix A Pharmacokinetics, Indications and Dosing of Included Drugs

Appendix B Cyclooxygenase Selectivity of NSAIDs

Appendix C Comparable NSAID Dose Levels

Appendix D Exact Search Strings

Appendix E Quality Assessment Methods

Appendix F Evidence Tables