# Technical Expert Panel

Dr. Jana Davidson

Clinical Associate Professor of Psychiatry

University of British Columbia

Vancouver, BC

Dr. Fay Kagan

Pediatric/Adolescent Psychiatrist

Hathaway-Sycamore Child and Family Services

Pacoima, CA

Dr. Syed Naqvi

Director

Pediatric Psychopharmacology Clinic

Cedars-Sinai Medical Center

Los Angeles, CA

Dr. Dina Panagiotopoulos

Assistant Professor

Division of Endocrinology

Department of Pediatrics

University of British Columbia

Vancouver, BC

Dr. Adelaide S. Robb

Associate Professor

Psychiatry and Behavioral Sciences and Pediatrics

School of Medicine and Health Sciences

George Washington University

Washington, DC