# Results

This chapter reports on the results of our literature review and synthesis. First, we describe the results of our literature search and selection process. Description of the characteristics and methodological quality of the studies follow. We present our analysis of the study results by Key Question. We present the results for symptoms (Key Question 1) and other short- and long-term outcomes (Key Question 3) first, followed by adverse events (Key Question 2) and subpopulations (Key Question 4). Key Questions 1, 3, and 4 are organized by condition; Key Question 2 is organized by drug class comparison. Metagraphs and tables reporting the strength of evidence for key outcomes are available within each applicable section. Within each metagraph, the studies that provided data are indexed by the name of the first author. Information on the domains, scoring, and psychometric properties of common scales evaluating outcomes and extrapyramidal side effects is provided in Table 3 and Table 4 above. A list of abbreviations is provided at the end of the report.

Several appendixes provide supporting information to the findings presented in this section. Appendix C provides the quality assessment ratings by domain for each study. Appendix D contains a detailed evidence table describing the study, participant, and treatment characteristics, outcomes, and conclusions for each study. A list of citations for the excluded and unobtained studies is available in Appendix E. Appendixes are available at the Agency for Healthcare Research and Quality Web site at www.effectivehealthcare.ahrq.gov/reports/final.cfm.

## Literature Search

The search strategy identified 10,745 citations from electronic databases. Screening based on titles and abstracts identified 1,273 potentially relevant studies. We identified 17 additional studies by hand searching the reference lists from included studies, conference proceedings, and clinical trial registries. The full text of 35 studies could not be retrieved through the university interlibrary loan service (Appendix E). Therefore, the full texts of 1,255 potentially relevant reports were retrieved and evaluated for inclusion in the review. Using the detailed selection criteria, 140 studies were included, and 1,115 were excluded. Of the 140 included studies, 59 were identified as companion publications; therefore, we included 81 unique studies (Figure 2). A list of companion articles is provided in a reference list at the end of this report.

Figure 2 Flow diagram of study retrieval and selection

ADHD = attention deficit hyperactivity disorder

*One study provided separate data for both bipolar disorder and schizophrenia.

Figure 2 is a flow diagram that outlines the study retrieval and selection process. It consists of boxes with text that describes the study selection process from the total number of citations retrieved from the literature searches to the number of studies that satisfied the inclusion criteria of the report. This figure is described further in page 25 of the results section as follows: “The search strategy identified 10,745 citations from electronic databases. Screening based on titles and abstracts identified 1,273 potentially relevant studies. We identified 17 additional studies by hand searching the reference lists from included studies, conference proceedings, and clinical trial registries. The full text of 35 studies could not be retrieved through the university interlibrary loan service. Therefore, the full texts of 1,255 potentially relevant reports were retrieved and evaluated for inclusion in the review. Using the detailed selection criteria, 140 studies were included, and 1,115 were excluded. Of the 140 included studies, 59 were identified as companion publications; therefore, 81 unique studies were included. The most frequent reasons for exclusion were: 1) ineligible age of study participants (N = 824); 2) the article did not report on primary research (N = 95); 3) ineligible study design (N = 82); 4) the study did not compare two antipsychotic drugs or an antipsychotic drug with placebo (N = 45); 5) no outcome data of interest were reported (N = 29); and 6) study participants were not diagnosed with any of the conditions of interest (N = 20). Twenty studies were excluded for other reasons.”

The most frequent reasons for exclusion were: (1) ineligible age of study participants (N = 824); (2) the article did not report on primary research (N = 95); (3) ineligible study design (N = 82); (4) the study did not compare two antipsychotic drugs or an antipsychotic drug with placebo (N = 45); (5) no outcome data of interest (N = 29); and (6) study participants were not diagnosed with any of the conditions of interest (N = 20). Twenty studies were excluded for other reasons (Figure 2). A complete list of excluded studies and reasons for exclusion is provided in Appendix E.

## Description of Included Studies

A total of 81 unique studies met the eligibility criteria for this review. The evidence table describes the characteristics of the studies (Appendix D). The studies were published between 1989 and 2010 (median = 2006 [interquartile range (IQR), 2002 to 2008]). Most of the studies (89 percent) were published in peer-reviewed publications. Studies were conducted in the U.S. (52 percent), Europe (18 percent), Israel (4 percent), Canada (2 percent), other regions (10 percent), or in multiple countries (14 percent).

A total of 63 studies (78 percent) and 55 studies (68 percent) examined the effectiveness of antipsychotics for treating symptoms (Key Question 1) or other short- and long-term outcomes (Key Question 3), respectively. Adverse events (Key Question 2) were reported in 78 studies (96 percent). In addition, 37 studies (46 percent) reported whether outcomes differed across subpopulations (Key Question 4).

Of the 81 studies, 62 (77 percent) were randomized controlled trials (RCTs) and 2 were nonrandomized controlled trials (NRCTs) (2 percent). Most of the trials had a parallel design and two treatment arms. Five trials used a crossover design; 15 trials had three or four arms. A total of 17 cohort studies (9 prospective and 8 retrospective) were included.

The studies examined the following conditions: pervasive developmental disorders (12 studies); attention deficit hyperactivity disorder (ADHD) or disruptive behavior disorders (8 studies); bipolar disorder (11 studies); schizophrenia or schizophrenia-related psychosis (31 studies); Tourette syndrome (7 studies); behavioral issues (4 studies); and patients diagnosed with various psychiatric and behavioral conditions (9 studies). One study provided separate data for both pediatric bipolar disorder and schizophrenia.42

None of the included studies examined obsessive-compulsive disorder, post-traumatic stress disorder, or anorexia nervosa.

The number of enrolled participants ranged from 8 to 335 (median = 42 [IQR, 25 to 100]). The mean age of study participants ranged from 4.0 to 21.5 years (median = 13.6 years [IQR, 10.6 to 15.2 years]). The mean age was lower than 12 years in 31 studies (38 percent).

Overall, 38 studies provided one or more head-to-head comparisons of different first- (FGAs) or second-generation antipsychotics (SGAs) (Table 9). A total of 17 studies compared different doses of the same antipsychotic, and 26 studies compared one antipsychotic with placebo.

Table 9 Head-to-head comparisons examined in the review

Comparison | Number of Studies | Comparison | Number of Studies
FGAs vs. SGAs | | SGAs vs. SGAs
Haloperidol vs. clozapine | 2 | Aripiprazole vs. olanzapine | 1
Haloperidol vs. olanzapine | 6 | Aripiprazole vs. quetiapine | 1
Haloperidol vs. risperidone | 4 | Aripiprazole vs. risperidone | 1
Pimozide vs. risperidone | 2 | Aripiprazole vs. ziprasidone | 1
Various FGAs vs. various SGAs | 3 | Clozapine vs. olanzapine | 6
| | Clozapine vs. quetiapine | 1
FGA vs. FGAs | | Clozapine vs. risperidone | 2
Haloperidol vs. pimozide | 2 | Olanzapine vs. quetiapine | 7
| | Olanzapine vs. risperidone | 16
| | Olanzapine vs. ziprasidone | 2
| | Quetiapine vs. risperidone | 6
| | Quetiapine vs. ziprasidone | 1
| | Risperidone vs. ziprasidone | 1

FGA = first-generation antipsychotic; SGA = second-generation antipsychotic

## Methodological Quality of Included Studies

The methodological quality of each study was assessed by two independent reviewers. Our approach to assessing study quality is described in the methods section. The consensus ratings for each study and domain are presented in Appendix C, Tables C1 and C2.

### Randomized and Nonrandomized Controlled Trials

The risk of bias assessments for the 62 RCTs and 2 NRCTs are presented in Appendix C, Table C1. The majority of the RCTs were considered to have a high risk of bias for both subjective and objective outcomes (N = 56, 90 percent). Sequence generation was adequate in 33 trials (53 percent), and allocation concealment was adequate in 23 studies (37 percent). Blinding was considered adequate for subjective outcomes in 31 studies (50 percent) and for objective outcomes in 43 studies (69 percent). Half of the studies either had no missing outcome data or adequately addressed missing data (31 studies reporting subjective outcomes and 30 reporting objective outcomes). Fifty studies (81 percent) were free of selective outcome reporting. Seven studies (11 percent) were considered free of other potential sources of bias, including industry funding and baseline imbalances between groups.

The two NRCTs were both considered at high risk of bias. Sequence generation and allocation concealment were inadequate in both studies, blinding was adequate in one study, and incomplete outcome data was adequate in another. Both studies were free of selective outcome reporting and were rated unclear for other sources of bias.

The most common source of funding was industry (50 trials, 78 percent), followed by government (15 trials, 23 percent). Other sources of funding were academic institutions (three trials, 5 percent), foundations (seven trials, 11 percent), and other private sources (four trials, 6 percent). One trial reported receiving no funding, and funding was not described in seven trials. Eighteen trials received funding from multiple sources.

### Cohort Studies

The detailed results of the quality assessment of the 17 cohort studies using the Newcastle-Ottawa scale are presented in Appendix C, Table C2. Data were prospectively collected in nine studies and retrospectively collected in eight. Overall, the methodological quality of the cohort studies was moderate (median score = 5/8 stars; IQR, 4 to 6).

More than half of the studies enrolled patients that were rated to be truly or somewhat representative of average patients in the community (11 studies, 65 percent). The nonexposed cohort was drawn from the same community as the exposed cohort in 13 studies (76 percent). In all studies, the exposure status was based on data from a secure source, most commonly from medical records. Six studies controlled for potential confounding variables in their design or analysis. Half of the studies (nine studies, 53 percent) used independent blind assessment or record linkage to determine outcomes. All except one study had sufficient followup duration for outcomes to occur. The rate of followup was considered unlikely to introduce bias in the majority of studies (12 studies, 71 percent).

Several cohort studies received funding from government (six studies, 35 percent). Two studies (12 percent) reported receiving funding from each of the following sources: industry, academic institutions, foundations, or other private sponsors. Seven studies (41 percent) did not report their source of funding.

## Key Questions 1 and 3 Disorder-Specific and Nonspecific Symptoms and Other Short- and Long-Term Outcomes

This section reviews the evidence of the effect of antipsychotics on symptoms (Key Question 1) and other short- and long-term outcomes (Key Question 3). For each condition of interest, we describe the studies that provided data for this review and present the results of studies individually and collectively. Throughout this report, a “significant” result refers to a finding that is statistically significant. We do not infer that statistically significant results are necessarily clinically meaningful.

### Pervasive Developmental Disorders: Overview

Eleven RCTs43-53 and one retrospective cohort study54 examined the effectiveness of FGAs and SGAs in treating patients with pervasive developmental disorders. The majority of the studies reported both symptom improvement and other short- and long-term outcomes, with four exceptions: three RCTs44,48,50 reported only symptom improvement, and one retrospective cohort study54 reported only other outcomes.

Table 10 provides selected information on the characteristics of the individual studies. The studies are grouped according to the drug class comparisons. Studies that include both head-to-head and placebo comparisons are listed under the head-to-head category. Within each comparison, studies are listed alphabetically by the specific drugs compared. A detailed evidence table is available in Appendix D.

Table 10 Characteristics of studies examining pervasive developmental disorders

Author, Year, Study Design, Duration, KQ | Intervention (N Enrolled), Dosage (mg/day) Mean±SD | Age, Mean±SD (Range) / Males (%) / White (%) Comorbidities | Diagnosis Breakdown (n) Quality Rating
FGAs vs. SGAs
Malone et al., 2001^45^ RCT, 6 wk KQ1, KQ3 | G1: Haloperidol (6), 1.4±0.7 mg/day G2: Olanzapine (6), 7.9±2.5 mg/day | G1: 7.3±1.9 yr / Male: 67% / White: 67% G2: 8.5±2.4 yr / Male: 67% / White: 50% Comorbidities: MR (mild (1), moderate (5), severe (5)) | autistic disorder (11), PDD NOS (1) High ROB
Miral et al., 2008^48^ RCT, 12 wk (12 wk extension) KQ1 | G1: Haloperidol (15), 2.6±1.3 mg/day G2: Risperidone (15), 2.6±0.8 mg/day | G1: 10.9±2.9 yr / Male: 87% / White: NR G2: 10.0±2.7 yr / Male: 73% / White: NR Comorbidities: NR | autistic disorder (all) High ROB
Novaes et al., 2008^54^ Retrospective cohort, 17 mo KQ3 | G1: FGA (1), NR G2: Risperidone or Risperidone and FGA (13 and 5), NR G3: SGA (except risperidone) (4), NR G4: FGA and SGA (3), NR | All groups: 4–21 yr / Male: 89 / White: NR Comorbidities: aggression/ agitation (all), MR (20) | autistic disorder (all) 6/8 stars
FGAs vs. FGAs
Perry et al., 1989^51^ RCT, 6 mo KQ1, KQ3 | G1: Haloperidol (continuous) (34), 1.2 mg/day G2: Haloperidol (discontinuous) (36), 1 mg/day | G1 and G2: 2.3–7.9 yr / Male: 69 / White: NR Comorbidities: NR | autistic disorder (all) High ROB
SGAs vs. SGAs
Marcus et al., 2009^46^ RCT, 8 wk KQ1, KQ3 | G1: Aripiprazole (low) (53), target: 5 mg/day G2: Aripiprazole (medium) (59), target: 10 mg/day G3: Aripiprazole (high) (54), target: 15 mg/day G4: Placebo (52) | G1: 9.0±2.8 yr / Male: 89% / White: 70% G2: 10.0±3.2 yr / Male: 85% / White: 70% G3: 9.5±3.1 yr / Male: 93% / White: 78% G4: 10.2±3.1 yr / Male: 92% / 67% Comorbidities: behavior issues (e.g., tantrums, aggression, self-injury; all) | autistic disorder (all) High ROB
NCT00576732, 2010^50^ RCT, 6 wk (26 wk extension) KQ1 | G1: Risperidone (low) (30), 0.125–0.175 mg/day G2: Risperidone (high) (31), 1.25–1.75 mg/day G3: Placebo (35) | All groups: NR / Male: 88% G1: White: 70% G2: White: 81% G2: White: 57% Comorbidities: NR | autistic disorder (all) High ROB
SGA vs. Placebo
Hollander et al., 2006^43^ RCT, 8 wk KQ1, KQ3 | G1: Olanzapine (6), 10±2 mg/day G2: Placebo (5) | G1: 9.3±2.9 yr / Male: all / White: 50% G2: 8.9±2.1 yr / Male: 60% / White: 80% Comorbidities: MR [mild (5), severe (2)] | Asperger syndrome (1), autism (6), PDD NOS (4) High ROB
Luby et al., 2006^44^ RCT, 6 mo KQ1 | G1: Risperidone (12), 1.1±0.3 mg/day G2: Placebo (12) | G1: 4.1±0.9 yr / Male: 75% / White: 91% G2: 4.0±1.1 yr / Male: 67% / White: 92% Comorbidities: NR | autistic disorder (NR), PDD NOS (NR) High ROB
McCracken et al., 2002^47^ RCT, 8 wk (4 mo extension) KQ1, KQ3 | G1: Risperidone (49), 1.8±0.7 mg/day G2: Placebo (52) | G1: NR / Male: 80% / White: NR G2: NR / Male: 83% / White: NR Comorbidities: MR (borderline (12), mild or moderate (43), severe (31)), serious behavior issues (all) | autistic disorder (all) Unclear ROB
Nagaraj et al., 2006^49^ RCT, 6 mo KQ1, KQ3 | G1: Risperidone (19), 1 mg/day G2: Placebo (21) | G1: 4.8±1.7 yr / Male: 84% / White: NR G2: 5.3±1.7 yr / Male: 90% / White: NR Comorbidities: Aggression (20), irritability (36), self-injurious behavior (12), seizures (8) | autistic disorder (all) Unclear ROB
Shea et al., 2004^52^ RCT, 8 wk KQ1, KQ3 | G1: Risperidone (41), 1.2 mg/day G2: Placebo (39) | G1: 7.6 yr / Male: 73% / White: NR G2: 7.3 yr / Male: 82% / White: NR Comorbidities: MR (27) | Asperger syndrome (12), autistic disorder (55), childhood disintegrative disorder (1), PDD NOS (11) High ROB
Troost et al., 2005^53^ RCT, 6 mo KQ1, KQ3 | G1: Risperidone (12), 1.9±0.7 mg/day G2: Placebo (12) | G1: 9.4±3.4 yr / Male: 92% / White: 100% G2: 8.7±1.2 yr / Male: 92% / White: 83% Comorbidities: behavior issues (e.g., tantrums, aggression, or self-injury; all), MR (2) | Asperger syndrome (2), autistic disorder (6), PDD NOS (16) High ROB

FGA = first-generation antipsychotic; G = group; KQ = key question; Mg = milligram; mo = month; MR = mental retardation; N = number; NOS = not otherwise specified; NR = not reported; PDD = pervasive developmental disorder; RCT = randomized controlled trial; ROB = risk of bias; SD = standard deviation; SGA = second-generation antipsychotic; wk = week; yr = year

Overall, the average age of patients was 8.3 years. Patients were predominantly male (average 79 percent) and white. A diagnosis of pervasive developmental disorder was based on the Diagnostic and Statistical Manual of Mental Disorders (DSM, either third edition [DSM–III], fourth edition [DSM–IV], or text revised fourth edition [DSM–IV–TR]). All studies included patients with autistic disorder. Five studies also included patients with other pervasive developmental disorders, including Asperger syndrome, childhood disintegrative disorder, and pervasive developmental disorder not otherwise specified. In four studies, all enrolled patients had behavioral issues, such as tantrums, aggression, or self-injury.46,47,53,54 Mental retardation was present in 24 percent of all patients across the studies.

Three studies45,48,54 provided head-to-head evidence for comparisons of a FGA (haloperidol) with SGAs (olanzapine or risperidone). One RCT51 compared the effectiveness of continuous versus discontinuous administration of haloperidol. Most of the studies (N = 8, 67 percent) compared a SGA, usually risperidone, with placebo.

The duration of followup varied widely across studies (range, 6 weeks to 17 months). On average, studies were 4.5 months in duration. Most of the RCTs had a high risk of bias due to industry sponsorship. Six studies also had unclear allocation concealment (55 percent). The one cohort study54 was of high quality (6 out of 8 stars).

### Pervasive Developmental Disorders: Disorder-Specific and Nonspecific Symptoms (Key Question 1)

Eleven RCTs compared the effectiveness of FGAs and SGAs for treating disorder-specific and nonspecific symptoms in patients with pervasive developmental disorders. A summary of the results by comparison is presented below. Table 11 provides the strength of evidence grades for all key outcomes that were reported by at least one study.

Table 11 Strength of evidence for pervasive developmental disorders (Key Question 1)

Comparison | Outcome (N Studies; N Patients) | Strength of Evidence Domains | | | | Strength of Evidence
Comparison | Outcome (N Studies; N Patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
FGA vs. SGA | Autistic symptoms (2; 40) | Moderate | Consistent | Direct | Not pooled | Low
FGA vs. SGA | Clinical global impressions (2; 40) | Moderate | Inconsistent | Direct | Not pooled | Insufficient
Haloperidol–continuous vs. discontinuous | Clinical global impressions (1; 70) | Moderate | Unknown | Direct | Imprecise | Insufficient
Aripiprazole–low- vs. medium- vs. high-dose | Autistic symptoms (1; 218) | Moderate | Unknown | Direct | Imprecise | Insufficient
Aripiprazole–low- vs. medium- vs. high-dose | Clinical global impressions (1; 218) | Moderate | Unknown | Direct | Imprecise | Insufficient
Aripiprazole–low- vs. medium- vs. high-dose | Obsessive compulsive (1; 218) | Moderate | Unknown | Direct | Imprecise | Insufficient
SGA vs. placebo | Anxiety (1; 80) | Moderate | Unknown | Direct | Imprecise | Insufficient
SGA vs. placebo | Autistic symptoms (7; 583) | Moderate | Consistent | Direct | Precise | Low
SGA vs. placebo | Clinical global impressions (3; 330) | Moderate | Consistent | Direct | Imprecise | Low
SGA vs. placebo | Obsessive compulsive (3; 330) | Moderate | Inconsistent | Direct | Precise | Low

FGA = first-generation antipsychotic; N = number; ROB = risk of bias; SGA = second-generation antipsychotic

- Haloperidol versus olanzapine (one RCT45): Patients treated with olanzapine had a significantly greater reduction in anger and hyperactivity than patients on haloperidol (p ≤0.05).
- Haloperidol versus risperidone (one RCT48): Patients on risperidone had a significantly greater reduction in the Aberrant Behavior Checklist (ABC) at 12 weeks (p = 0.006) and greater improvement on the Clinical Global Impressions (CGI) scale (p = 0.02) and language (p = 0.04) at 24 weeks than patients on haloperidol.
- Haloperidol–continuous versus discontinuous (5 days on haloperidol with 2 days on placebo) administration (one RCT51): There was no significant difference in Clinical Global Impressions of Improvement (CGI–I) between the administration schedules.
- Aripiprazole–dosing (one RCT46): High-dose (15 mg/day) aripiprazole resulted in significantly greater improvement in the ABC lethargy/social withdrawal subscale (p = 0.05) than medium-dose (10 mg/day) aripiprazole.
- SGAs versus placebo (eight RCTs43,44,46,47,49,50,52,53): Meta-analysis found SGAs to be superior to placebo for aberrant behavior on the ABC (mean difference [MD] = -18.29; 95% confidence interval [CI], -27.08 to -9.51), autism symptoms on the Childhood Autism Rating Scale (CARS) (MD = -4.94; 95% CI, -8.52 to -1.36), obsessive-compulsive symptoms on the Children's Yale-Brown Obsessive Compulsive Scale (CYBOCS) (MD = -1.71; 95% CI, -3.17 to -0.25), but not for the CGI–I.
- Single studies found significant improvement favoring risperidone over placebo for the ABC–I (irritability subscale),50 Ritvo-Freeman Real Life Rating Score and maladaptive behavior,47 Children's Global Assessment Score (CGAS),49 behavior subscales (parent-rated Nisonger Child Behavior Rating Form [NCBRF]), and improvement of the most troublesome symptom.52

We provide a detailed analysis of the results below. This section is organized by comparison, beginning with head-to-head evidence (FGAs vs. SGAs, FGAs vs. FGAs, and SGAs vs. SGAs) and followed by placebo comparisons for FGAs and SGAs.

#### FGAs Versus SGAs

Two RCTs compared FGAs versus SGAs.45,48

##### Haloperidol Versus Olanzapine

A 6-week RCT (N = 12) compared haloperidol (mean dose, 1.4±0.7 mg/day) with olanzapine (mean dose, 7.9±2.5 mg/day) in children ages 5 to 17 years.45 Patients on olanzapine showed significantly greater improvement on the Children's Psychiatric Rating Scale (CPRS) anger and hyperactivity subscales (p = 0.05 and p = 0.01, respectively). Clinical Global Impressions of Severity (CGI–S) and other CPRS subscales did not significantly differ between groups.

##### Haloperidol Versus Risperidone

A 12-week RCT (N = 30) with a 12-week extension assessed the comparative effectiveness of haloperidol (mean dose, 2.6±0.8 mg/day) and risperidone (mean dose, 2.6±1.3 mg/day) in children ages 8 to 18 years.48 Risperidone led to significantly greater improvement in ABC scores at 12 weeks (p = 0.006), CGI scores at 24 weeks (p = 0.02), and the language subscale of the Ritvo-Freeman Real Life Rating Score at 24 weeks (p = 0.04).

#### FGAs Versus FGAs

##### Haloperidol–Continuous Versus Discontinuous Administration

A 6-month RCT (N = 70) randomized patients ages 2.3 to 7.9 years to continuous or discontinuous drug administration of haloperidol.51 The discontinuous drug schedule consisted of 5 days on haloperidol with 2 days on placebo. The prescribed dose of haloperidol was similar between the groups (1.2 mg/day in the continuous group, and 1.0 mg/day in the discontinuous group). CGI scores were not significantly different between groups at endpoint.

#### SGAs Versus SGAs

##### Aripiprazole–Low- Versus Medium- Versus High-Dose

An 8-month, placebo-controlled RCT (N = 218) evaluated the effect of daily fixed-dose regimens of aripiprazole at 5 mg, 10 mg, and 15 mg on irritability associated with autistic disorder.46 Patients were children ages 6 to 17 years with behaviors such as tantrums, agitation, or self-injury. The high-dose aripiprazole group had significantly greater improvement in the ABC lethargy/social withdrawal subscale than the medium-dose group (p = 0.05). No differences were found on the other ABC subscales, the CYBOCS, or CGI.

##### Risperidone–Low- Versus Medium- Versus High-Dose

A 6-week, placebo-controlled RCT (N = 96) compared low-dose (0.125–0.175 mg/day) and high-dose (1.25–1.75 mg/day) risperidone.50 Patients were assessed using the ABC–I; however, the article provided no numeric data for this dosing comparison.

#### SGAs Versus Placebo

Eight studies compared SGAs with placebo.43,44,46,47,49,50,52,53

##### Aripiprazole Versus Placebo

An 8-week RCT (N = 218) compared three doses of aripiprazole (5 mg, 10 mg, and 15 mg) with placebo in patients ages 6 to 17 years.46 Aripiprazole led to significantly greater improvement in the irritability (p<0.05), stereotypy (p≤0.01), and hyperactivity (p≤0.01) ABC subscales, the CGI–I (p<0.005), and CYBOCS (p = 0.03, for high-dose aripiprazole only). Groups were not significantly different on the ABC lethargy/social withdrawal or inappropriate speech subscales.

##### Olanzapine Versus Placebo

An 8-week RCT (N = 11) randomized children ages 6 to 14 years to olanzapine (mean dose, 10±2.04 mg/day) and placebo.43 Patients treated with olanzapine had significantly greater improvement on the CGI–I (p = 0.01).

##### Risperidone Versus Placebo

Six RCTs compared risperidone and placebo.44,47,49,50,52,53 The duration of studies ranged from 6 weeks to 6 months. A total of 365 children ages 2 to 17 years were enrolled in the trials. Three studies included patients with mental retardation,47,52,53 and two studies enrolled only patients with various behavioral issues.47,53 Symptoms were assessed using the ABC, CARS, CGAS, CGI–I, CYBOCS, NCBRF–P, Ritvo-Freeman Real Life Rating Score, Vineland Adaptive Behavior Scale, and visual analogue scale (VAS) of the most troublesome symptom.

A meta-analysis of three studies47,52,53 found that risperidone was superior to placebo for improvement in ABC scores (MD = -22.15; 95% CI, -30.84 to -13.46) (Figure 3). Heterogeneity was moderate (p = 0.23, I2 = 32%) and may be attributable to differences in the proportion of patients with intellectual disabilities who were enrolled in the studies.

Figure 3 SGAs versus placebo on ABC in pervasive developmental disorders

ABC = Aberrant Behavior Checklist; CI = confidence interval; df = degrees of freedom; IV = inverse variance; SD = standard deviation; SGA = second-generation antipsychotic

Figure 3 is a metagraph depicting the effect of SGAs on ABC scores for pervasive developmental disorders. Pooled results are displayed overall and for two subgroups: aripiprazole versus placebo and risperidone versus placebo. The one study comparing aripiprazole with placebo favored aripiprazole (MD = -11.26; 95 percent CI, -18.60 to -3.93). For the three studies comparing risperidone with placebo, the pooled estimate showed risperidone to be superior to placebo on change in ABC scores (MD = -22.15; 95 percent CI, -30.84 to -13.46) with moderate heterogeneity present (p = 0.23, I2 = 32 percent). The total combined estimate for all studies (415 patients) similarly favored SGAs over placebo (MD = -18.29; 95 percent CI, -27.08 to -9.51) with substantial heterogeneity present (p = 0.05, I2 = 62 percent).

A meta-analysis of two RCTs44,49 examining autistic behaviors on the CARS compared risperidone with placebo (Figure 4). The pooled estimate indicated significantly greater improvement of autism symptoms in the risperidone groups than placebo (MD = -4.94; 95% CI, -8.52 to -1.36). There was substantial heterogeneity (p = 0.10, I^2^ = 64%). The study by Nagaraj et al.49 included patients who were slightly older and had a higher proportion of male participants than Luby et al.44

Figure 4 Risperidone versus placebo on CARS in pervasive developmental disorders

CARS = Childhood Autism Rating Scale; CI = confidence interval; df = degrees of freedom; IV = inverse variance; SD = standard deviation; SGA = second-generation antipsychotic

Figure 4 is a metagraph depicting the effect of risperidone on CARS scores for pervasive developmental disorders. Two studies contributed data from 62 participants. The pooled estimate indicated significantly greater improvement of autism symptoms in the risperidone groups than placebo (MD = -4.94; 95 percent CI, -8.52 to -1.36). Substantial heterogeneity was present (p = 0.10, I2 = 64 percent).

Individual studies found that risperidone improved symptoms more than placebo for the following measures: CGAS (p<0.001),49 CGI–I (p<0.001),47 CYBOCS (p = 0.005),47 the conduct problem, hyperactive, insecure, and overly sensitive subscales of the NCBRF parent version (p<0.05),52 Ritvo-Freeman Real Life Rating Score (p<0.001),47 Vineland Adaptive Behavior Scale–maladaptive subscale (<0.001),47 and VAS of the most troublesome symptom (p≤0.05).52 One RCT50 found a significant reduction in irritability on the ABC–I subscale for patients who received high-dose, but not low-dose, risperidone compared with placebo.

##### Meta-analyses Comparing Various SGAs With Placebo

Meta-analyses were conducted to compare various SGAs with placebo for the ABC, CGI–I, and CYBOCS.

Four RCTs46,47,52,53 contributed data to a meta-analysis comparing SGAs with placebo on ABC scores (see Figure 3 above). The pooled estimate favored SGAs over placebo (MD = -18.29; 95% CI, -27.08 to -9.51). Heterogeneity was substantial (p = 0.05, I^2^ = 62%) and may be a result of differences in the SGA used as the comparator.

Three RCTs43,46,47 were combined in a meta-analysis comparing SGAs and placebo for obsessive-compulsive behaviors on the CYBOCS (Figure 5). The effect estimate showed a significantly greater decrease in obsessive-compulsive symptoms with use of SGAs than with placebo (MD = -1.71; 95% CI, -3.17 to -0.25). Heterogeneity was high (p = 0.14, I^2^ = 49%) and may be attributable to differences in the SGAs.

Figure 5 SGAs versus placebo on CYBOCS in pervasive developmental disorders

CI = confidence interval; CYBOCS = Children's Yale-Brown Obsessive-Compulsive Scale; df = degrees of freedom; IV = inverse variance; SD = standard deviation; SGA = second-generation antipsychotic

Figure 5 is a metagraph depicting the effect of SGAs on CYBOCS scores for pervasive developmental disorders. This metagraph pooled three studies with a total of 325 patients that compared three difference SGAs with placebo: aripiprazole, olanzapine, and risperidone. The effect estimate showed a significantly greater decrease in obsessive-compulsive symptoms with use of SGAs than with placebo (MD = -1.71; 95 percent CI, -3.17 to -0.25). Considerable heterogeneity was present (p = 0.14, I2 = 49 percent).

Two RCTs43,46 provided data for a meta-analysis comparing SGAs with placebo on CGI–I rating (Figure 6). Although the combined estimate favored SGAs, the result was not statistically significant (MD = -1.22; 95% CI, -2.50 to 0.06). There was substantial heterogeneity (p = 0.11, I^2^ = 61%). Nearly all of the patients in the study by Hollander43 had mild to severe mental retardation, which may account for some of the observed heterogeneity.

Figure 6 SGAs versus placebo on CGI–I in pervasive developmental disorders

CGI–I = Clinical Global Impressions–Improvement; CI = confidence interval; df = degrees of freedom; IV = inverse variance; SD = standard deviation; SGA = second-generation antipsychotic

Figure 6 is a metagraph depicting the effect of SGAs on CGI–I scores in pervasive developmental disorders. Pooled results of two studies contributed data on 224 patients. The studies examined aripiprazole and olanzapine versus placebo. Although the combined estimate favored SGAs, the result was not statistically significant (MD = -1.22; 95 percent CI, -2.50 to 0.06). Substantial heterogeneity was present (p = 0.11, I2 = 61 percent).

### Pervasive Developmental Disorders: Short- and Long-Term Outcomes (Key Question 3)

Nine studies provided data on a variety of short- and long-term outcomes for patients with pervasive developmental disorders. A summary of the results is presented by outcome below. Table 12 provides the strength of evidence grades for all key outcomes that were reported by at least one study.

Table 12 Strength of evidence for pervasive developmental disorders (Key Question 3)

Comparison | Outcome (N Studies; N Patients) | Strength of Evidence Domains | | | | Strength of Evidence
Comparison | Outcome (N Studies; N Patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
Aripiprazole–low- vs. medium- vs. high-dose | Medication adherence (1; 218) | Moderate | Unknown | Direct | Imprecise | Insufficient
Aripiprazole–low- vs. medium- vs. high-dose | Suicide (1; 218) | Moderate | Unknown | Indirect | Imprecise | Insufficient
SGA vs. placebo | Medication adherence (2; 319) | Moderate | Consistent | Direct | Imprecise | Low
SGA vs. placebo | Patient-, parent-, or care provider-reported outcomes: sleep, food frequency (1; 101) | Moderate | Unknown | Direct | Imprecise | Insufficient
SGA vs. placebo | Suicide (1; 218) | Moderate | Unknown | Indirect | Precise | Insufficient

N = number; ROB = risk of bias; SGA = second-generation antipsychotic

- Response and relapse: Response rate did not differ between haloperidol and olanzapine in one RCT45 or between continuous and discontinuous administration of haloperidol in another.51 A meta-analysis of five RCTs43,46,47,49,52 comparing SGAs with placebo found a significantly higher response rate in patients receiving SGAs (relative risk [RR] = 2.69; 95% CI, 1.52 to 4.74). The relapse rate was significantly lower for risperidone than placebo in two RCTs (RR = 0.31; 95% CI, 0.13 to 0.73), as was the time to relapse (p = 0.01).47,53
- Cognitive and emotional development: Two RCTs47,53 comparing risperidone and placebo reported patients' performance on various cognitive tasks. Risperidone was superior to placebo on a visuospatial (“dot”) task; no differences were found between groups for cancellation tasks, word recognition, and hand-eye coordination.47 Similarly, reaction time did not differ between groups.53
- Suicide-related behaviors: In an RCT46 comparing three doses of aripiprazole with placebo, three patients in the placebo group experienced suicide-related behaviors compared to no patients in the aripiprazole groups. This finding was statistically significant (p = 0.04).
- Medication adherence: Two RCTs46,47 reporting medication adherence found no difference between SGAs and placebo.
- Patient-, parent-, or care provider–reported outcomes: One RCT47 found no significant difference between risperidone and placebo for sleep duration. There was a significant increase in vitamin K intake after 2 months of risperidone treatment compared with placebo (p<0.05).
- Other outcomes: No studies provided data for the following outcome categories: growth and maturation, school performance, work-related functional capacity, patient insight into illness, health-related quality of life, legal system interaction, or health care system utilization.

A detailed analysis of the results is provided below. This section is organized by comparison, beginning with head-to-head evidence (FGAs vs. SGAs, FGAs vs. FGAs, and SGAs vs. SGAs) and followed by placebo comparisons for FGAs and SGAs.

#### FGAs Versus SGAs

Two studies compared FGAs with SGAs.45,54 However, one study54 was not included in the analysis because only one patient received a FGA alone. All other patients in this study either received a SGA or combination treatment of a FGA and a SGA.

##### Haloperidol Versus Olanzapine

A 6-week RCT (N = 12) examined the comparative effectiveness of haloperidol (mean dose, 1.4±0.7 mg/day) and olanzapine (mean dose, 7.9±2.5 mg/day) in children ages 5 to 17 years.45 Response rates did not differ between groups.

#### FGAs Versus FGAs

##### Haloperidol–Continuous Versus Discontinuous Administration

A 6-month RCT (N = 70) compared continuous and discontinuous (i.e., 5 days haloperidol and 2 days placebo) administration of haloperidol in children ages 2.3 to 7.9 years.51 Treatment response, defined as CGI–I≤2 and CGI–S≤2, was not significantly different between groups.

#### SGAs Versus SGAs

##### Aripiprazole–Low- Versus Medium- Versus High-Dose

An 8-week RCT (N = 218) examined the comparative effectiveness of three doses of aripiprazole (5 mg, 10 mg, and 15 mg) in children ages 6 to 17 years with irritability associated with autism.46 There was no significant difference between the aripiprazole doses for treatment response, suicide-related behaviors, or adherence rate.

##### Risperidone Versus Other SGAs

A 17-month retrospective cohort study (N = 26) compared the effect of risperidone versus other SGAs in children and young adults ages 4 to 21 years. Eight patients received combination treatment with a FGA (five in the risperidone group, three in the other SGA group). Response rate (defined as CGI–I≤2) was not significantly different between patients treated with risperidone (with or without a FGA) and patients treated with SGAs other than risperidone (with or without a FGA).

#### SGAs Versus Placebo

Six RCTs compared SGAs with placebo.43,46,47,49,52,53

##### Aripiprazole Versus Placebo

An 8-week RCT (N = 218) compared three doses of aripiprazole with placebo.46 Treatment response rate (defined as ≥25 percent reduction in ABC–I and CGI–I≤2) was significantly greater with 5 mg/day aripiprazole than placebo (p = 0.04), but there was no difference between the 10 mg/day and 15 mg/day groups versus placebo. Suicide-related behaviors were reported by three patients in the placebo group and no patients in the aripiprazole groups; this result significantly favored the aripiprazole groups (p = 0.04). Medication adherence did not differ between the groups.

##### Olanzapine Versus Placebo

An 8-week RCT (N = 11) assessed the effectiveness of olanzapine (mean dose, 10±2 mg/day) versus placebo in children ages 6 to 14 years.43 Response rate, based on CGI–I and CPRS ratings, was not significantly different between groups.

##### Risperidone Versus Placebo

Four placebo-controlled RCTs examined the effectiveness of risperidone.47,49,52,53 Study duration ranged from 8 weeks to 6 months. Overall, 245 children were enrolled in the studies. All of the studies included school-aged children, one included preschoolers,49 and two included adolescents.47,53 Three studies enrolled patients with mental retardation,47,52,53 and two examined children with behavior problems (i.e., aggression, irritability, tantrums, or self-injurious behaviors).47,53 Mean daily risperidone doses ranged from 1 to 1.9 mg/day. Outcomes included response, relapse, time to relapse, various cognitive tasks (cancellation task, classroom analogue task, Purdue pegboard task, dot test, verbal learning task, and focused attention reaction time), medication adherence, Food Frequency Questionnaire, and sleep duration.

Three RCTs reporting response rate were pooled (Figure 7, analysis 6.1.3).47,49,52 Patients on risperidone showed significantly higher response rates than placebo (RR = 3.54; 95% CI, 2.06 to 6.10). Heterogeneity was moderate (p = 0.22, I^2^ = 34%).

Figure 7 SGAs versus placebo on response rate in pervasive developmental disorders

CI = confidence interval; df = degrees of freedom; M–H = Mantel–Haenszel; SGA = second-generation antipsychotic

Figure 7 is a metagraph depicting the effect of SGAs on response rate for pervasive developmental disorders. Pooled results are displayed for SGAs (aripiprazole, olanzapine, and risperidone) versus placebo. A total of five studies contributed data from 443 patients. No significant effect was observed for aripiprazole or olanzapine compared with placebo (one study each). Patients on risperidone showed significantly higher response rates than placebo (RR = 3.54; 95 percent CI, 2.06 to 6.10). Heterogeneity was moderate (p = 0.22, I2 = 34 percent). The total combined estimate for all studies favored SGAs over placebo (MD = 2.69; 95 percent CI, 1.52 to 4.74) with substantial heterogeneity present (p = 0.03, I2 = 64 percent).

Two RCTs comparing risperidone with placebo provided data for a meta-analysis on relapse rate (Figure 8).47,53 The pooled estimate showed significantly lower rate of relapse in the risperidone group (RR = 0.31; 95% CI, 0.13 to 0.73). There was no evidence of heterogeneity (p = 0.52, I^2^ = 0%).

Figure 8 Risperidone versus placebo on relapse rate in pervasive developmental disorders

CI = confidence interval; df = degrees of freedom; M–H = Mantel–Haenszel; SGA = second-generation antipsychotic

Figure 8 is a metagraph depicting the effect of risperidone on relapse rate for pervasive developmental disorders. Two studies provided data from 125 participants. The pooled estimate showed significantly lower rate of relapse in the risperidone group (RR = 0.31; 95 percent CI, 0.13 to 0.73). There was no evidence of heterogeneity (p = 0.52, I2 = 0 percent).

One study found no difference between groups for medication adherence.47 Two studies found a longer mean time to relapse for patients treated with risperidone than those receiving placebo; the result was significant in one study (p = 0.01)53 and could not be calculated in the second study (34 days for placebo versus 57 days for risperidone; standard deviations not reported).47 Cognitive effects were evaluated in a subset of patients in one study.47 Compared with placebo, no significant declines were noted in the risperidone group for attention, hand-eye coordination, or short-term verbal memory. There was an increase in vitamin K intake after 2 months of risperidone treatment compared with placebo (p<0.05).47 No significant differences in sleep time increases between the risperidone and placebo groups were found.47

##### Meta-analyses Comparing Various SGAs With Placebo

Meta-analyses were conducted to compare various SGAs with placebo for response rate and adherence rate.

Five RCTs contributed data on response rate (Figure 7 above). SGAs included aripiprazole,46 olanzapine,43 and risperidone.47,49,52 The combined estimate showed a significantly higher response rate in patients receiving SGAs than placebo (RR = 2.69; 95% CI, 1.52 to 4.74). There was substantial heterogeneity (p = 0.03, I^2^ = 64%), which may be attributable to differences in drug comparator and dosing, as well as differences in patient ages.

Two RCTs comparing aripiprazole46 and risperidone47 with placebo were combined in a meta-analysis for adherence rate (Figure 9). No significant difference in adherence to study medication was found (RR = 0.66; 95% CI, 0.11 to 4.11) with no evidence of heterogeneity (p = 0.64, I^2^ = 0%).

Figure 9 SGAs versus placebo on adherence rate in pervasive developmental disorders

CI = confidence interval; df = degrees of freedom; M–H = Mantel–Haenszel; SGA = second-generation antipsychotic

Figure 9 is a metagraph depicting the effect of SGAs (aripiprazole and risperidone) versus placebo on adherence rate for pervasive developmental disorders. Two studies provided data from 314 patients. No statistically significant difference in adherence to study medication was found (RR = 0.66; 95 percent CI, 0.11 to 4.11) with no evidence of heterogeneity (p = 0.64, I2 = 0 percent).

### ADHD and Disruptive Behavior Disorders: Overview

Eight RCTs examined the effectiveness of antipsychotics for treating symptoms and other short- and long-term outcomes in patients with ADHD with aggression55 and disruptive behavior disorders.56-62 Table 13 provides selected information on the characteristics of the individual studies. Studies are organized alphabetically by drug, then by author. There were no head-to-head drug comparisons. All of the studies compared a SGA, usually risperidone, with placebo. A detailed evidence table is available in Appendix D.

Table 13 Characteristics of studies examining ADHD and disruptive behavior disorders

Author, Year, Study Design, Duration, KQ | Intervention (N Enrolled), Dosage (mg/day) Mean±SD | Age, Mean±SD (Range) / Males (%) / White (%) Comorbidities | Diagnosis Breakdown (n) Quality Rating
SGAs vs. Placebo
Connor et al., 2008^59^ RCT, 6 wk KQ1, KQ3 | G1: Quetiapine (9), 294±78 mg/day G2: Placebo (10) | G1: 13.1±1.2 yr / Male: 78% / White: 78% G2: 15±1.4 yr / Male: 70% / White: 70% Comorbidities: ADHD (15), depression (4), dysthymia (5), GAD (3), OCD (3), ODD (18), panic disorder (1), PTSD (3), SA (6), separation anxiety (3), social phobia (3) | CD with moderate to severe aggression (all) High ROB
Aman et al., 2009^56^ RCT (crossover), 4 wk KQ1, KQ3 | G1: Risperidone (16),^*^ 1.7±1.3 mg/day G2: Placebo (16)^*^ | All groups: 8.6±2.6 yr / Male : 88% / White: 81% Comorbidities: MR [borderline (10), mild (4), moderate (1)] | ADHD with CD (2), ADHD with ODD (6), ADHD only (1), ASD (3), CD (1), ODD (3) High ROB
Aman et al., 2002^57^ RCT, 6 wk (48 wk extension) KQ1, KQ3 | G1: Risperidone (55), 1.2±0.6 mg/day G2: Placebo (63) | G1: 8.7±2.1 yr / Male: 85% / White: 51% G2: 8.1±2.3 yr / Male: 79% / White: 62% Comorbidities: ADHD (70), MR [all; borderline (60), mild (38), moderate (20)] | CD (47), DBD (8), ODD (63) High ROB
Armenteros et al., 2007^55^ RCT, 4 wk KQ1, KQ3 | G1: Risperidone (12), 1.1±0.6 mg/day G2: Placebo (13) | G1: 7.3±3.7 yr / Male: 83% / White: 50% G2: 8.8±3.1yr / Male: 92% / White: 46% Comorbidities: GAD (1), ODD (13), separation anxiety disorder (3) | ADHD with aggression (all) High ROB
Buitelaar et al., 2001^58^ RCT, 6 wk KQ1, KQ3 | G1: Risperidone (19), 2.9 mg/day G2: Placebo (19) | G1: 14.0±1.5 yr / Male: 90% / White: NR G2: 13.7±2 yr / Male: 84% / White: NR Comorbidities: ADHD (26), anxiety disorder (3), MR (14) | CD (30), DBD NOS (2), ODD (6), aggression (all) High ROB
Findling et al., 2000^60^ RCT, 10 wk KQ1, KQ3 | G1: Risperidone (10), 0.028±0.004 mg/kg/day G2: Placebo (10) | G1: 10.7±3.4 yr / Male: NR / White: NR G2: 8.2±1.9 yr / Male: NR / White: NR Comorbidities: NR | CD with aggression (all) High ROB
Reyes et al., 2006^61^ RCT, 6 mo KQ1, KQ3 | G1: Risperidone (172), 0.81±0.34 mg/day (<50 kg), 1.22±0.36 mg/day (≥50 kg) G2: Placebo (163) | G1: 10.9±2.9 yr / Male: 82% / White: NR G2: 10.8±2.9 yr / Male: 91% / White: NR Comorbidities: ADHD (227) | CD (123), DBD NOS (8), ODD (204) High ROB
SGAs vs. Placebo
Snyder et al, 2002^62^ RCT, 6 wk (48 wk extension) KQ1, KQ3 | G1: Risperidone (53), 1±0.73 mg/day G2: Placebo (57) | G1: 8.6±0.3 yr / Male: 77% / White: 79% G2: 8.8±0.3 yr / Male: 74% / White: 74% Comorbidities: ADHD (84), MR (all; borderline (53), mild (42), moderate (15)) | CD (41), ODD (69) High ROB

ADHD = attention deficit hyperactivity disorder; ASD = autism spectrum disorder; CD = conduct disorder; DBD = disruptive behavior disorder; G = group; GAD = general anxiety disorder; KQ = key question; mg = milligrams; mo = month; MR = mental retardation; N = number; NOS = not otherwise specified; NR = not reported; OCD = obsessive-compulsive disorder; ODD = oppositional defiant disorder; PTSD = post-traumatic stress disorder; RCT = randomized controlled trial; ROB = risk of bias; SA = substance abuse; SD = standard deviation; wk = week

* All patients experienced each of the treatment arms in this crossover study

Patients had an average age of 10.2 years and were predominantly male (84 percent). Among the studies that reported race, the majority of patients were white. Diagnosis of disruptive behavior disorders and ADHD were confirmed using the DSM–IV in all but one RCT, which used the Kiddie Schedule for Affective Disorders and Schizophrenia (K–SADS). Across the trials, patients most frequently had a primary diagnosis of oppositional defiant disorder (51 percent) or conduct disorder (41 percent). Patients were required to have aggression to be included in four of the trials.55,58-60 Common comorbidities included ADHD in patients with a primary diagnosis of a disruptive behavior disorder, mental retardation, and anxiety disorders.

The duration of followup ranged from 4 weeks to 6 months. On average, the studies were 8.5±7.3 weeks. Two studies had a 48-week open-label extension of risperidone.57,62 All of the trials had a high risk of bias. Five trials had incomplete outcome data, and all had potential bias due to involvement of industry.

### ADHD and Disruptive Behavior Disorders: Disorder-Specific and Nonspecific Symptoms (Key Question 1)

Eight placebo-controlled RCTs evaluated the efficacy of SGAs in treating symptoms of patients with ADHD and disruptive behavior disorders. A summary of the results by outcome is presented below. Table 14 provides the strength of evidence grades for all key outcomes that were reported by at least one study.

Table 14 Strength of evidence for ADHD and disruptive behavior disorders (Key Question 1)

Comparison | Outcome (N Studies; N Patients) | Strength of Evidence Domains | | | | Strength of Evidence
Comparison | Outcome (N Studies; N Patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
SGA vs. placebo | Aggression (5; 302) | Moderate | Consistent | Direct | Imprecise | Low
SGA vs. placebo | Anxiety (4; 580) | Moderate | Inconsistent | Direct | Not pooled | Low
SGA vs. placebo | Behavior symptoms (7; 669) | Moderate | Consistent | Direct | Precise | Moderate
SGA vs. placebo | Clinical global impressions (7; 662) | Moderate | Consistent | Direct | Precise | Moderate

N = number; ROB = risk of bias; SGA = second-generation antipsychotic

- Behavior symptoms: Patients treated with risperidone had a significantly greater reduction in behavior problems than patients on placebo. Three meta-analyses supported this finding using various measures: ABC in four RCTs56-58,62 (MD = -20.97; 95% CI, -31.11 to -10.83), Behavior Problem Inventory in two RCTs57,62 (MD = -3.77; -6.16 to -1.39), and NCBRF in four RCTs56,57,61,62 (MD = -6.93; -10.38 to -3.49). One RCT60 found a significant reduction in delinquent behavior for patients treated with risperidone versus placebo.
- Conners Parent Rating Scale: SGAs (risperidone60 and quetiapine59) were significantly favored over placebo for parent rating scores in two RCTs examining patients with conduct disorder (studies were not pooled due to heterogeneity). The effect was greater in patients treated with risperidone.60
- Clinical global impressions: Patients treated with SGAs versus placebo had significantly better scores on the CGI–S (MD = -1.33; 95% CI, -2.15 to -0.50) in a meta-analysis of five studies55,58-61) and CGI–I (MD = -0.95; 95% CI, -1.66 to -0.25) in a meta-analysis of three studies55,60,61).
- VAS: Three RCTs57,61,62 found significantly greater improvement in clinical symptoms on a VAS for risperidone compared with placebo (studies were not pooled due to heterogeneity).
- Aggression: A meta-analysis of two RCTs (risperidone58 and quetiapine59) found no difference between either of these two SGAs and placebo for aggression (MD= -15.81, 95% CI, -51.56 to 19.94).

A detailed analysis for the comparative effectiveness of SGAs versus placebo is presented below.

#### SGAs Versus Placebo

##### Quetiapine Versus Placebo

A 6-week, placebo-controlled RCT (N = 19) assessed the effectiveness of quetiapine (mean dose, 294±78 mg/day) for treating adolescents ages 12 to 17 years with conduct disorder and aggression.59 Quetiapine significantly improved on the CGI compared with placebo (CGI–I scores, p<0.001; CGI–S, p<0.01). No significant differences were observed in the Overt Aggression Scale (OAS) and Conners Parent Rating Scale.

##### Risperidone Versus Placebo

Seven RCTs compared risperidone and placebo in patients with ADHD and aggression55 and disruptive behavior disorders.56-58,60-62 The duration of studies ranged from 4 weeks to 6 months. Overall, 662 children ranging from age 4 to 17 years participated in the trials. The average age of participants was between 8 and 10 years, with the exception of one study with an average age around 14 years.58 Mean daily risperidone doses ranged from 0.8 to 2.9 mg/day. Symptoms were assessed using the following scales: ABC, Behavior Problem Inventory, Child Behavior Checklist, CGAS, CGI–I, CGI–S, Conners Parent Rating Scale, NCBRF, OAS, Rating of Aggression Against People and/or Property scale, and VAS.

Four RCTs56-58,62 comparing risperidone with placebo for ABC scores were pooled (Figure 10). The study by Buitelaar58 that included only patients with ADHD and aggression was presented separately from the remaining studies that examined participants with disruptive behavior disorders. In all studies, risperidone was favored over placebo. The combined analysis showed a significantly greater reduction in aberrant behavior for patients treated with risperidone (MD = -20.97; 95% CI, -31.11 to -10.83). Heterogeneity was substantial (p = 0.05, I^2^ = 62%). Studies were similar in terms of design, followup duration, and comorbidities. Patients in the study by Buitelaar58 were older than those enrolled in the other studies.

Figure 10 Risperidone versus placebo on ABC in disruptive behavior disorders

ABC = Aberrant Behavior Checklist; ADHD = attention deficit hyperactivity disorder; CI = confidence interval; DBD = disruptive behavior disorder; df = degrees of freedom; IV = inverse variance; SD = standard deviation; SGA = second-generation antipsychotic

Figure 10 is a metagraph depicting the effect of risperidone on ABC scores in disruptive behavior disorders. Four studies with 293 patients were pooled. The study by Buitelaar58 that included only patients with ADHD and aggression was presented separately from the remaining studies that examined participants with disruptive behavior disorders. In all studies, risperidone was favored over placebo. The combined analysis showed a significantly greater reduction in aberrant behavior for patients treated with risperidone (MD = -20.97; 95 percent CI, -31.11 to -10.83). Heterogeneity between the studies was substantial (p = 0.05, I2 = 62 percent).

Two RCTs57,62 were pooled in a meta-analysis examining risperidone versus placebo on the Behavior Problem Inventory (Figure 11). The combined estimate showed a significant difference favoring risperidone for behavior problems (MD = -3.77; -6.16 to -1.39) with no evidence of heterogeneity (p = 0.57, I^2^ = 0%).

Figure 11 Risperidone versus placebo on BPI in disruptive behavior disorders

BPI = Behavior Problems Inventory; CI = confidence interval; DBD = disruptive behavior disorder; df = degrees of freedom; IV = inverse variance; SD = standard deviation; SGA = second-generation antipsychotic

Figure 11 is a metagraph depicting the effect of risperidone on BPI scores in disruptive behavior disorders. Two studies with 225 patients were pooled. The combined estimate showed a significant difference favoring risperidone for behavior problems (MD = -3.77; -6.16 to -1.39) with no evidence of heterogeneity (p = 0.57, I2 = 0 percent).

Three RCTs55,60,61 provided data for a meta-analysis comparing CGI–I scores in patients receiving treatment with risperidone versus placebo (Figure 12). The pooled estimate showed a significant difference between groups favoring risperidone (MD = -0.95; 95% CI, -1.66 to -0.25); however, considerable heterogeneity was evident (p = 0.16, I^2^ = 45%). The studies differed in patients' diagnoses (one study55 enrolled patients with ADHD and aggression, the others examined disruptive behavior disorders) and followup duration, which ranged from 4 weeks to 6 months.

Figure 12 Risperidone versus placebo on CGI–I in disruptive behavior disorders

ADHD = attention deficit hyperactivity disorder; CGI–I = Clinical Global Impressions–Improvement; CI = confidence interval; DBD = disruptive behavior disorder; df = degrees of freedom; IV = inverse variance; SD = standard deviation; SGA = second-generation antipsychotic

Figure 12 is a metagraph depicting the effect of risperidone on CGI–I scores in disruptive behavior disorders. One study examining patients with ADHD found no significant difference between risperidone and placebo (MD = -0.50; 95 percent CI, -1.99 to 0.99). Two studies examining patients with a disruptive behavior disorder found risperidone to be superior to placebo (MD = -1.13; 95 percent CI, -2.18 to -0.08). The pooled estimate of three studies with 380 patients showed a significant difference between groups favoring risperidone (MD = -0.95; 95 percent CI, -1.66 to -0.25); however, considerable heterogeneity was evident (p = 0.16, I2 = 45 percent).

A significantly greater proportion of patients treated with risperidone had a rating of “very much improved” or “much improved” (CGI–I≤2) than placebo in three trials.57,59,62

Four RCTs56,57,61,62 provided data comparing risperidone with placebo for behavior scores on the NCBRF (Figure 13). The pooled estimate showed a significantly greater reduction in problem behaviors for the risperidone group (MD = -6.93; 95% CI, -10.38 to -3.49). There was substantial heterogeneity (p = 0.05, I^2^ = 62%). The study with the largest sample size61 showed the most precision, and the confidence intervals of the smaller studies overlapped with the effect estimate of this study.

Figure 13 Risperidone versus placebo on NCBRF in disruptive behavior disorders

CI = confidence interval; DBD = disruptive behavior disorders; df = degrees of freedom; IV = inverse variance; NCBRF = Nisonger Child Behavior Rating Form; SD = standard deviation; SGA = second-generation antipsychotic

Figure 13 is a metagraph depicting the effect of risperidone on NCBRF scores in disruptive behavior disorders. Four studies with 590 patients were pooled. The pooled estimate showed a significantly greater reduction in problem behaviors for the risperidone group (MD = -6.93; 95 percent CI, -10.38 to -3.49). There was substantial heterogeneity (p = 0.05, I2 = 62 percent).

Three RCTs57,61,62 compared risperidone with placebo on a VAS for symptom improvement (Figure 14). There was considerable heterogeneity; therefore, we did not pool the studies. All trials showed a significantly greater improvement in symptoms with risperidone than placebo.

Figure 14 Risperidone versus placebo on VAS in disruptive behavior disorders

CI = confidence interval; DBD = disruptive behavior disorders; IV = inverse variance; SD = standard deviation; SGA = second-generation antipsychotic; VAS = visual analogue scale

Figure 14 is a metagraph depicting the effect of risperidone on VAS for symptom improvement in disruptive behavior disorders. Three studies with 560 patients were available but they were not pooled due to substantial heterogeneity. All trials showed a significantly greater improvement in symptoms for risperidone compared with placebo.

Four RCTs55,58,60,61 provided data for a comparison of CGI–S scores (Figure 15; analysis 1.4.1 and 1.4.2). No difference was found between the groups in one study examining patients with ADHD and aggression.55 Risperidone was favored over placebo in three studies examining patients with disruptive behavior disorders. There was considerable heterogeneity, which may be due to the lower dosing of risperidone used and longer followup period in Reyes et al.61

Figure 15 SGAs versus placebo on CGI–S in disruptive behavior disorders

ADHD = attention deficit hyperactivity disorder; CGI–S = Clinical Global Impressions–Severity; CI = confidence interval; DBD = disruptive behavior disorder; df = degrees of freedom; IV = inverse variance; SD = standard deviation; SGA = second-generation antipsychotic

Figure 15 is a metagraph depicting the effect of SGAs on CGI–S in disruptive behavior disorders. Four studies compared risperidone with placebo, and one study compared quetiapine with placebo. A total of 435 patients provided data for the meta-analysis. Each of the studies found a significant difference in favor of the SGA, with the exception of one study comparing risperidone and placebo in patients with ADHD. Overall, the combined estimate showed a significant difference in symptom severity between the groups favoring SGAs (MD = -1.33; 95 percent CI, -2.15 to -0.50). However, there was substantial heterogeneity between the studies (p = 0.001, I2 = 78 percent).

Single studies found a significant difference favoring risperidone over placebo for the Child Behavior Checklist (CBCL) delinquent behavior subscale (p = 0.04),60 the Rating of Aggression Against People and/or Property scale (p = 0.03),60 and the CGAS (p<0.001).61

##### Meta-analyses Comparing Various SGAs With Placebo

Meta-analyses were conducted to compare various SGAs with placebo for the CGI–S, Conners Parent Rating Scale, and OAS.

Five RCTs55,58-61 provided data for a comparison of CGI–S scores (Figure 15 above). All but one study55 favored SGAs. The combined estimate showed a significant difference in symptom severity between the groups favoring SGAs (MD = -1.33; 95% CI, -2.15 to -0.50); however, there was substantial heterogeneity between the studies (p = 0.001, I^2^ = 78%). Reyes et al.61 indicated a smaller difference between risperidone and placebo than the other studies. This difference may be due to the lower dose of risperidone used or the longer followup time (6 months vs. 10 weeks); it is possible that the medication effects were reduced over time. In addition, differences in the conditions being treated may have contributed to the difference in effect: Armenteros et al.55 examined patients with ADHD and aggression, whereas the remaining four studies examined patients with disruptive behavior disorders with or without ADHD comorbidity.

Two RCTs59,60 examining risperidone and quetiapine evaluated patients on Conners Parent Rating Scale (Figure 16). The studies were not pooled due to considerable heterogeneity (p = 0.01, I^2^ = 84%). Patients in the study by Findling et al.60 were predominantly treatment naïve and were younger than those in the study by Connor et al.59 Both studies significantly favored the SGA; however, the effect was greater in patients treated with risperidone.60

Figure 16 SGAs versus placebo on Conners Parent Rating Scale in disruptive behavior disorders

CI = confidence interval; DBD = disruptive behavior disorder; IV = inverse variance; SD = standard deviation; SGA = second-generation antipsychotic

Figure 16 is a metagraph depicting the effect of SGAs on Conners Parent Rating Scale in disruptive behavior disorders. Risperidone and quetiapine were each examined in one study, with a total of 39 patients. The studies were not pooled due to substantial heterogeneity. Both studies significantly favored the SGA; however, the effect was greater in patients treated with risperidone.

Two RCTs compared a SGA, risperidone58 or quetiapine,59 with placebo for aggression on the OAS (Figure 17). The pooled estimate showed no difference (MD = -15.81, 95% CI, -51.56 to 19.94), and there was substantial heterogeneity (p = 0.04, I^2^ = 76%). The studies were similar in length of followup, patient age, and comorbidities; the heterogeneity may be explained by differences between the SGAs used in the studies.

Figure 17 SGAs versus placebo on OAS in disruptive behavior disorders

ADHD = attention deficit hyperactivity disorder; CI = confidence interval; DBD = disruptive behavior disorders; df = degrees of freedom; IV = inverse variance; OAS = Overt Aggression Scale; SD = standard deviation; SGA = second-generation antipsychotic

Figure 17 is a metagraph depicting the effect of SGAs (quetiapine and risperidone) for aggression on OAS in disruptive behavior disorders. Two studies with a total of 57 patients provided data for the meta-analysis. The pooled estimate showed no difference (MD = -15.81, 95 percent CI, -51.56 to 19.94), and there was substantial heterogeneity (p = 0.04, I2 = 76 percent).

### ADHD and Disruptive Behavior Disorders: Short- and Long-Term Outcomes (Key Question 3)

Eight studies provided data on a variety of short- and long-term outcomes for patients with ADHD and disruptive behavior disorders. A summary of the results is presented by outcome below. Table 15 provides the strength of evidence grades for all key outcomes that were reported by at least one study.

Table 15 Strength of evidence for ADHD and disruptive behavior disorders (Key Question 3)

Comparison | Outcome (N Studies; N Patients) | Strength of Evidence Domains | | | | Strength of Evidence
Comparison | Outcome (N Studies; N Patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
SGA vs. placebo | HRQL (1; 19) | Moderate | Unknown | Direct | Precise | Insufficient
SGA vs. placebo | Medication adherence (5; 311) | Moderate | Inconsistent | Direct | Imprecise | Low

ADHD = attention deficit hyperactivity disorder; HRQL = health-related quality of life; N = number; ROB = risk of bias; SGA = second-generation antipsychotic

- Response and relapse: Two RCTs comparing risperidone and placebo reported treatment response rate. One study57 found a significant difference in response favoring risperidone (p<0.001), whereas another study55 found no significant difference between the groups. One RCT61 found risperidone to be significantly superior to placebo for relapse, symptom recurrence, and time-to-symptom recurrence (p≤0.002).
- Growth and maturation: One RCT61 compared changes in Tanner stages from baseline for patients treated with risperidone or placebo. No group differences in the distribution of stages were observed.
- Cognitive and emotional development: Two RCTs compared risperidone and placebo for performance on cognitive tasks. Risperidone resulted in faster response time, fewer seat movements on a short-term memory task, and fewer contacts (less tremor) on a graduated holes task (p≤0.05).56 Reyes et al.61 found no difference between groups on verbal learning and continuous performance tasks.
- Medication adherence: A meta-analysis of four studies55,57,60,62 comparing risperidone with placebo showed no significant difference between the study groups (RR = 1.43; 95% CI, 0.35 to 5.83) for adherence rate.
- School performance: School refusal was assessed in one RCT59 comparing quetiapine and placebo; no significant difference was found between groups.
- Patient-, parent-, or care provider-reported outcomes: Social withdrawal was assessed in an RCT59 comparing quetiapine and placebo; no difference was found between treatment arms.
- Health-related quality of life: One RCT59 assessed patients on the Quality of Life Enjoyment and Satisfaction Questionnaire and found a significant difference favoring treatment with quetiapine over placebo (p = 0.005).
- Other outcomes: No studies provided data for the following outcome categories: suicide-related behaviors, work-related functional capacity, patient insight into illness, legal system interaction, or health care system utilization.

A detailed analysis comparing SGAs and placebo is provided below.

#### SGA Versus Placebo

##### Quetiapine Versus Placebo

A 6-week RCT (N = 19) compared the effectiveness of quetiapine (mean dose, 294±78 mg/day) versus placebo in adolescents ages 12 to 17 with conduct disorder and aggression. Scores on the Quality of Life Enjoyment and Satisfaction Questionnaire improved significantly in the quetiapine group compared with the placebo group (p = 0.005); however, no significant differences between groups were found for school refusal or social withdrawal.

##### Risperidone Versus Placebo

Seven placebo-controlled RCTs evaluated the effects of risperidone on other short- and long-term outcomes in patients with ADHD with aggression55 and disruptive behavior disorders.56-58,60-62 The characteristics of these studies are described in Key Question 1 above. The studies reported the following outcomes: response, relapse, symptom recurrence, adherence, maturation (i.e., Tanner staging), and cognitive tasks (i.e., match to sample, short-tIn Ierm memory recognition, graduated holes, and continuous performance tasks).

Two studies55,57 comparing risperidone versus placebo-reported treatment response rates (Figure 18). The results of two studies were not pooled due to considerable heterogeneity (p = 0.02, I^2^ = 81%). All patients in one study57 had mental retardation, and mental retardation was an exclusion criteria in the second study.55 This may account for the difference in response rates. Aman et al.57 found a significant difference in favor of risperidone.

Figure 18 Risperidone versus placebo on response rate in disruptive behavior disorders

CI = confidence interval; M–H = Mantel–Haenszel; SGA = second-generation antipsychotic

Figure 18 is a metagraph depicting the effect of risperidone on response rate in disruptive behavior disorder. The two studies in this graph both favored risperidone. The total sample size was 140 patients. The results of studies were not pooled due to substantial heterogeneity (p = 0.02, I2 = 81 percent).

Four studies55,57,60,62 contributed data for a meta-analysis comparing adherence rate for patients receiving risperidone and placebo (Figure 19). There was no significant difference between the study groups (RR = 1.43; 95% CI, 0.35 to 5.83) and little evidence of heterogeneity (p = 0.35, I^2^ = 9%).

Figure 19 Risperidone versus placebo on adherence rate in disruptive behavior disorders

CI = confidence interval; df = degrees of freedom; M–H = Mantel–Haenszel; SGA = second-generation antipsychotic

Figure 19 is a metagraph depicting the effect of risperidone on adherence rate in disruptive behavior disorder. Four studies contributed data from 237 participants. There was no significant difference between the study groups (RR = 1.43; 95 percent CI, 0.35 to 5.83) and little evidence of heterogeneity between the studies (p = 0.35, I2 = 9 percent).

One study58 reported treatment adherence using plasma samples. The mean plasma concentration of risperidone in the treatment group was 18±24 ng/mL; no risperidone was detected in patients in the placebo group.

Two trials reported performance on various cognitive tasks. Seat movements and response time on the short-term recognition memory task and contacts on the graduated holes task favored the risperidone group (p≤0.05 for both) in one study.56 The following outcomes were not significantly different between groups: match to sample task,56 the continuous performance task,56,61 and the Modified California Verbal Learning Questionnaire.61

One RCT61 found risperidone to be significantly superior to placebo for symptom recurrence, time to symptom recurrence, 6-month recurrence, and relapse (p≤0.002). Tanner stages showed no significant difference.

### Bipolar Disorder: Overview

Eleven RCTs evaluated the effectiveness of SGA with other drugs of the same class or placebo for treating symptoms and other short- and long-term outcomes in children and adolescents with bipolar disorder.42,63-72 Table 16 provides selected information on the characteristics of the individual studies. Studies that include both head-to-head and placebo comparisons are listed under the head-to-head category. Head-to-head drug comparison were made in two studies.63,64 Different doses of the same SGA were compared in four trials.42,67,68,73 The majority of the studies were placebo controlled. A detailed evidence table is available in Appendix D.

Table 16 Characteristics of studies examining bipolar disorder

Author, Year, Study Design, Duration, KQ | Intervention (N Enrolled), Dosage (mg/day) Mean±SD | Age, Mean±SD (Range) / Males (%) / White (%) Comorbidities | Diagnosis Breakdown (n) Quality Rating
SGAs vs. SGAs
Findling et al, 2009^67^ RCT, 4 wk KQ1, KQ3 | G1: Aripiprazole (low) (98), range: 2–10 mg/day G2: Aripiprazole (high) (99), range: 2–30 mg/day G3: Placebo (99) | G1: 13.7±2.2 yr / Male: 53% / White: 66% G2: 13.3±2.3 yr / Male: 52% / White: 69% G3: 13.3±2.1 yr / Male: 57% / White: 61% Comorbidities: ADHD (153), DBD (93), psychosis (14) | Bipolar I (all), mania (119), mixed (125), unknown (52) High ROB
Biederman, 2004^64^ RCT, 8 wk KQ1, KQ3 | G1: Olanzapine (19), 8.5±3.2 mg/day G2: Quetiapine (19), 213.1±150.5 mg/day G3: Risperidone (42), 1.36±0.7 mg/day G4: Ziprasidone (21), 56.2±34.3 | All groups: 10.2±2.7 yr / Male: 67% / White: NR Comorbidities: NR | mania (all) High ROB
Biederman et al, 2005^63^ RCT, 8 wk KQ1, KQ3 | G1: Olanzapine (15), 6.3±2.3 mg/day G2: Risperidone (16), 1.4±0.5 mg/day | G1: 5.0±0.8 yr / Male: 67% / White: 100% G2: 5.3±0.8 yr / Male: 75% / White: 94% Comorbidities: ADHD (19), CD (13), MDD (22) | Bipolar I (27), bipolar NOS (4), mania (all) High ROB
NCT00090311, 2008 73 RCT, 3 wk KQ1, KQ3 | G1: Quetiapine, low dose (93), 400 mg/day G2: Quetiapine, high dose (95), 600 mg/day G3: Placebo (89) | G1: 13.1±2.2 yr / Male: 51% / White: 79% G2: 13.2±2.2 yr / Male: 58% / White: 77% G3: 13.3±2.1 yr / Male: 61% / White: 75% Comorbidities: ADHD (124) | Manic (272), Mixed (5) High ROB
Haas et al, 2009^68^ RCT, 3 wk KQ1, KQ3 | G1: Risperidone (low) (50), range: 0.5–2.5 mg/day G2: Risperidone (high) (61), range: 3–6 mg/day G3: Placebo (58) | G1: NR / Male: 56% / White: 70% G2: NR / Male: 43% / White: 82% G3: NR / Male: 48% / White: 78% Comorbidities: ADHD (85), DBD (101) | Bipolar I (all), manic episode (60), mixed episode (109) High ROB
DelBello et al, 2008^42^ RCT, 3 wk (24 wk extension) KQ1, KQ3 | G1: Ziprasidone (low) (15), target: 80 mg/day G2: Ziprasidone (high) (31), target: 160 mg/day | G1: 13.2±2.1 yr / Male: 47% / White: NR G2: 13.8±2.4 yr / Male: 77% / White: NR Comorbidities: NR | Bipolar I (all) High ROB
SGA vs. Placebo
Tramontina et al, 2009^72^ RCT, 6 wk KQ1, KQ3 | G1: Aripiprazole (18), 13.6±5.4 mg/day G2: Placebo (25) | G1: 11.7±2.7 yr / Male: 33% / White: 83% G2: 12.2±2.8 yr / Male: 56% / White: 96% Comorbidities: ADHD (all), anxiety disorders (21), DBD (35), psychosis (16) | Bipolar I (35), bipolar II (8) High ROB
Tohen et al, 2007^71^ RCT, 3 wk (6 mo extension) KQ1, KQ3 | G1: Olanzapine (107), 8.9 mg/day G2: Placebo (54) | G1: 15.1±1.3 yr / Male: 57% / White: 66% G2: 15.4±1.2 yr / Male: 44% / White: 76% Comorbidities: ADHD (58), DBD (49) | Bipolar I (all), mixed (86), psychotic features (29), rapid cycling (30) High ROB
DelBello et al, 2009^65^ RCT, 8 wk KQ1, KQ3 | G1: Quetiapine (17), 403±133 mg/day G2: Placebo (15) | G1: 16.0±2 yr / Male: 29% / White: 82% G2: 15±2 yr / Male: 33% / White: 80% Comorbidities: ADHD (4), anxiety disorder (8), DBD (8), psychosis (3) | Bipolar I with depressive episode (all) High ROB
DelBello et al, 2002^66^ RCT, 6 wk KQ1, KQ3 | G1: Quetiapine (15), 432 mg/day G2: Placebo (15) | G1: 14.1±2 yr / Male: 53% / White: 80% G2: 14.5±2 yr / Male: 53% / White: 87% Comorbidities: ADHD (18), psychosis (14) | Bipolar I (all), mixed episode (23) High ROB
NCT00257166, 2008^70^ RCT, 4 wk KQ1, KQ3 | G1: Ziprasidone (149), target: 60–80 mg/day (<45 kg), 120–160 mg/day (>45 kg) G2: Placebo (88) | G1: 13.6 yr / Male: NR / White: NR G2: 13.7 yr / Male: NR / White: NR Comorbidities: NR | Bipolar I (all) High ROB

ADHD = attention deficit hyperactivity disorder; CD = conduct disorder; DBD = disruptive behavior disorder; G = group; KQ = key question; MDD = major depressive disorder; mg = milligrams; mo = month; N = number; NOS = not otherwise specified; NR = not reported; RCT = randomized controlled trial; ROB = risk of bias; SD = standard deviation; SGA = second-generation antipsychotic; wk = week; yr = year

The average age of patients was 12.6 years. Both sexes were equally represented across the studies (55 percent male). The majority of patients were of white race. Diagnosis of bipolar disorder was established using the DSM–IV or DSM–IV–TR. Nearly all of the patients enrolled in the studies were classified as having bipolar I disorder; one study included eight patients with bipolar II disorder,72 and another study included four patients with bipolar disorder not-otherwise-specified.63 As noted earlier, the diagnosis of bipolar disorder in children is controversial, particularly in young children (e.g., preschoolers in Biederman et al.63). The majority of children had secondary diagnoses, including ADHD, disruptive behavior disorders, anxiety, and psychosis.

The studies had short followup periods, ranging from 3 to 8 weeks. Two trials had extension phases of 24 weeks42 and 6 months.71 All of the trials had a high risk of bias. The most common sources of potential bias were involvement of industry and incomplete outcome data.

### Bipolar Disorder: Disorder-Specific and Nonspecific Symptoms (Key Question 1)

Eleven RCTs compared the efficacy of SGAs for the treatment of disorder-specific and nonspecific symptoms in children with bipolar disorder. A summary of the results by comparison is presented below. Table 17 provides the strength of evidence grades for all key outcomes that were reported by at least one study.

Table 17 Strength of evidence for bipolar disorder (Key Question 1)

Comparison | Outcome (N Studies; N Patients) | Strength of Evidence Domains | | | | Strength of Evidence
Comparison | Outcome (N Studies; N Patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
Olanzapine vs. quetiapine | Manic symptoms (1; 38) | Moderate | Unknown | Direct | Imprecise | Insufficient
Olanzapine vs. risperidone | Depression (1; 31) | Moderate | Unknown | Direct | Imprecise | Insufficient
Olanzapine vs. risperidone | Manic symptoms (2; 92) | Moderate | Unknown | Direct | Imprecise | Insufficient
Olanzapine vs. ziprasidone | Manic symptoms (1; 40) | Moderate | Unknown | Direct | Imprecise | Insufficient
Quetiapine vs. risperidone | Manic symptoms (1; 61) | Moderate | Unknown | Direct | Imprecise | Insufficient
Quetiapine vs. ziprasidone | Manic symptoms (1; 40) | Moderate | Unknown | Direct | Imprecise | Insufficient
Risperidone vs. ziprasidone | Manic symptoms (1; 63) | Moderate | Unknown | Direct | Precise | Insufficient
Aripiprazole–low- vs. high-dose | Clinical global impressions (1; 296) | Moderate | Unknown | Direct | Imprecise | Insufficient
Aripiprazole–low- vs. high-dose | Depression (1; 296) | Moderate | Unknown | Direct | Imprecise | Insufficient
Aripiprazole–low- vs. high-dose | Manic symptoms (1; 296) | Moderate | Unknown | Direct | Imprecise | Insufficient
Quetiapine–low- vs. high-dose | Manic symptoms (1; 188) | Moderate | Unknown | Direct | Imprecise | Insufficient
Risperidone–low- vs. high-dose | Clinical global impressions (1; 169) | Moderate | Unknown | Direct | Imprecise | Insufficient
Risperidone–low- vs. high-dose | Manic symptoms (1; 169) | Moderate | Unknown | Direct | Imprecise | Insufficient
Ziprasidone–low- vs. high-dose | Clinical global impressions (1; 46) | Moderate | Unknown | Direct | Imprecise | Insufficient
Ziprasidone–low- vs. high-dose | Manic symptoms (1; 46) | Moderate | Unknown | Direct | Imprecise | Insufficient
SGA vs. placebo | Aggression (1; 161) | Moderate | Unknown | Direct | Imprecise | Insufficient
SGA vs. placebo | Clinical global impressions (6; 978) | Moderate | Consistent | Direct | Precise | Moderate
SGA vs. placebo | Depression (4; 532) | Moderate | Inconsistent | Direct | Imprecise | Low
SGA vs. placebo | Manic symptoms (8; 1245) | Moderate | Inconsistent | Direct | Not pooled | Low

N = number; ROB = risk of bias; SGA = second-generation antipsychotic

- Olanzapine versus risperidone (two RCT63,64): Patients treated with risperidone had significantly fewer mania symptoms on the Young Mania Rating Scale (YMRS) than patients treated with olanzapine (MD = 6.83; 95% CI, 1.97 to 11.69).
- Olanzapine versus quetiapine versus risperidone versus ziprasidone (one RCT64): Risperidone was superior to ziprasidone for change in YMRS scores. All other comparisons of SGAs showed no significant differences.
- SGAs dosing (four RCTs comparing low- versus high-dose aripiprazole,67 quetiapine,73 risperidone,68 and ziprasidone42): No significant differences were found between the dosing regimens for any of the antipsychotics.
- SGAs versus placebo (eight RCTs65-68,70-73): All but one study examining quetiapine65 found a significant difference in favor of the SGAs on the YMRS (studies not pooled due to heterogeneity). SGAs were significantly favored over placebo for the CGI (MD = -0.67; 95% CI, -0.84 to -0.51). Four studies found no significant difference between SGAs and placebo for improving depression on the Children's Depression Rating Scale (CDRS) (studies not pooled due to clinical heterogeneity).

A detailed analysis for the comparative effectiveness of SGAs and placebo is presented below. The section is organized by comparison (SGAs head-to-head, dosing, and placebo comparisons).

#### SGAs Versus SGAs

##### Olanzapine Versus Risperidone

An 8-week RCT (N = 31) compared olanzapine (6.3±2.3 mg/day) with risperidone (1.4±0.5 mg/day) in children ages 4 to 6.^63^ No significant differences were found between the groups on the Brief Psychiatric Rating Scale (BPRS), CDRS, or YMRS.

##### Olanzapine Versus Quetiapine Versus Risperidone Versus Ziprasidone

An 8-week open-label RCT compared four SGAs [olanzapine (N = 19), quetiapine (N = 19), risperidone (N = 42), and ziprasidone (N =42)] for the treatment of mania in children and youth with bipolar disorder. Change in YMRS scores differed significantly between the risperidone and ziprasidone groups (p = 0.03), favoring risperidone. All other SGAs comparisons were not significantly different on the YMRS.

Two RCTs provided data for a meta-analysis of the efficacy of olanzapine versus risperidone on YMRS (Figure 20). The combined estimate favored risperidone (MD = 6.83; 95% CI, 1.97 to 11.69). There was no evidence of heterogeneity (p = 0.95, I^2^ = 0%).

Figure 20 Olanzapine versus risperidone on YMRS in bipolar disorder

CI = confidence interval; df = degrees of freedom; IV = inverse variance; SD = standard deviation; YMRS = Young Mania Rating Scale

Figure 20 is a metagraph depicting the effect of olanzapine and risperidone on YMRS in patients with bipolar disorder. Two studies with 92 patients were pooled in this analysis. The pooled estimate of the mean difference was 6.83 (95 percent CI, 1.97 to 11.69). There was no evidence of heterogeneity (p = 0.95, I2 = 0 percent).

##### Aripiprazole–Low- Versus High-Dose

A 4-week RCT (N = 296) randomized children ages 10 to 17 to two doses of aripiprazole (10 mg/day and 30 mg/day) and placebo.67 No significant differences were observed between the two aripiprazole doses on the CDRS, CGAS, CGI–BP, General Behavior Inventory, or YMRS.

##### Quetiapine–Low- Versus High-Dose

A 3-week placebo-controlled RCT compared the efficacy of low-dose (400 mg/day) and high-dose (600 mg/day) quetiapine in the treatment of children and adolescents ages 10 to 17 with bipolar I mania.73 No significant differences were observed between the two quetiapine dose regimens for CGAS, CGI–BP, or YMRS.

##### Risperidone–Low- Versus High-Dose

A 3-week placebo-controlled RCT (N = 169) compared the effectiveness of low-dose (0.5–2.5 mg/day) and high-dose (3–6 mg/day) risperidone in children ages 10 to 17.^68^ The following outcomes showed no significant differences between the low- and high-dose groups: YMRS, CGI–BP, or BPRS for Children (BPRS–C) change scores.

##### Ziprasidone–Low- Versus High-Dose

Children ages 10 to 17 years with bipolar disorder or schizophrenia were randomized to low-dose (80 mg/day) and high-dose (160 mg/day) ziprasidone in a 3-week RCT.42 Separate analyses were provided for patients with bipolar disorder (N = 46). No significant differences were found between the two groups on the CGI–S or YMRS scores.

#### SGAs Versus Placebo

Eight RCTs compared various SGAs with placebo for alleviating bipolar symptoms: aripiprazole,67,72 olanzapine,71 quetiapine,65,66,73 risperidone,68 and ziprasidone.70 Study duration ranged from 3 to 8 weeks. A total of 1,253 patients between the ages of 10 and 18 years were enrolled in the trials. All patients had a diagnosis of bipolar I disorder with the exception of eight patients in one trial.72 Symptoms were assessed using the BPRS–C, CDRS, CGAS, CGI–BP, Child Mania Rating Scale, General Behavior Inventory, Hamilton Anxiety Rating Scale, OAS, and YMRS.

Four RCTs65,67,71,72 compared various SGAs versus placebo on the CDRS (Figure 21). The studies were not pooled due to clinical heterogeneity: Delbello et al.65 included only patients with a depressive episode, whereas the other studies enrolled predominantly patients with mania or mixed episodes. None of the studies found a statistically significant difference between SGA and placebo.

Figure 21 SGAs versus placebo on CDRS in bipolar disorder

CDRS = Children's Depression Rating Scale; CI = confidence interval; df = degrees of freedom; IV = inverse variance; SD = standard deviation; SGA = second-generation antipsychotic

Figure 21 depicts the effect of SGAs on depressive symptoms as measured by the CDRS in bipolar disorder. Four studies compared various SGAs (aripiprazole, olanzapine, and quetiapine) with placebo. The results were not pooled due to clinical heterogeneity: Delbello et al. included only patients with a depressive episode, whereas the other studies enrolled predominantly patients with mania or mixed episodes. None of the studies found a statistically significant difference between groups.

Six RCTs65,67,68,71-73 provided data for a meta-analysis of the efficacy of SGAs versus placebo for CGI (Figure 22). One study used the CGI–S,72 and five studies used the CGI–BP. Two studies67,72 comparing aripiprazole versus placebo showed a pooled estimate that significantly favored aripiprazole (MD = -0.71; 95% CI, -1.29 to -0.13); there was substantial heterogeneity (p = 0.03, I2 = 79%). The heterogeneity may be related to variability in the followup duration (4 weeks67 versus 6 weeks72) and the proportion of patients with comorbid ADHD. Two studies65,73 comparing quetiapine versus placebo had a pooled estimate that significantly favored quetiapine (MD = -0.59; 95% CI, -0.75 to -0.42), with no evidence of heterogeneity (p = 0.43, I2 = 0%). The combined estimate favored SGAs (MD = -0.67; 95% CI, -0.84 to -0.51). There was moderate heterogeneity (p = 0.16, I2 = 36%).

Figure 22 SGAs versus placebo on CGI in bipolar disorder

CGI = Clinical Global Impressions; CI = confidence interval; df = degrees of freedom; IV = inverse variance; SD = standard deviation; SGA = second-generation antipsychotic

Figure 22 is a metagraph depicting the effect of SGAs on CGI in bipolar disorder. Five studies with 962 patients compared SGAs (aripiprazole, olanzapine, quetiapine, and risperidone) with placebo and were pooled. The combined estimate of all studies favored SGAs (MD = -0.67; 95 percent CI, -0.84 to -0.51). There was moderate heterogeneity (p = 0.16, I2 = 36 percent).

Eight RCTs65-68,70-73 evaluated the efficacy of SGAs versus placebo for manic symptoms, as measured by the YMRS (Figure 23). A meta-analysis of two studies67,72 comparing aripiprazole with placebo showed a significant difference favoring aripiprazole (MD = -7.22; 95% CI, -9.28 to -5.17); there was no evidence of heterogeneity (p = 0.88, I^2^ = 0%). Three studies65,66,73 compared quetiapine with placebo; the studies were not pooled due to considerable heterogeneity (p<0.001, I^2^ = 93%). One study examined patients experiencing a depressive episode.65 Patients with bipolar depression can switch to mania or a mixed episode. All other SGAs were significantly favored over placebo. We did not pool the seven studies due to the considerable heterogeneity (I^2^>80%), which may be attributed to the quetiapine studies.65,66,73

Figure 23 SGAs versus placebo on YMRS in bipolar disorder

CI = confidence interval; df = degrees of freedom; IV = inverse variance; SD = standard deviation; SGA = second-generation antipsychotic; YMRS = Young Mania Rating Scale

Figure 23 is a metagraph depicting the effect of SGAs (aripiprazole, olanzapine, quetiapine, risperidone, and ziprasidone) on YMRS in bipolar disorder. Eight studies provided data on a total of 1209 patients. A meta-analysis of two studies comparing aripiprazole with placebo showed a statistically significant difference favoring aripiprazole (MD = -7.22; 95 percent CI, -9.28 to -5.17); there was no evidence of heterogeneity (p = 0.88, I2 = 0 percent). ). Three studies compared quetiapine with placebo; the studies were not pooled due to substantial heterogeneity (p<0.001, I2 = 93 percent). Single studies examining olanzapine, risperidone, and ziprasidone each significantly favored the SGA. The studies were not pooled due to substantial heterogeneity (I2>80 percent).

Single studies favored aripiprazole over placebo on the CGAS,67 Child Mania Rating Scale,72 and General Behavior Inventory.67 Patients using olanzapine showed significantly greater improvement in aggression on the OAS than patients on placebo.71 Risperidone was favored over placebo on the BPRS.68 Quetiapine was superior to placebo on CGAS in one study,73 but there was no significant difference between quetiapine and placebo on the Hamilton Anxiety Rating Scale in another study.65

### Bipolar Disorder: Short- and Long-Term Outcomes (Key Question 3)

Eleven studies provided data on a variety of short- and long-term outcomes for patients with bipolar disorder receiving treatment with SGAs. A summary of the results is presented by outcome below. Table 18 provides the strength of evidence grades for all key outcomes that were reported by at least one study.

Table 18 Strength of evidence for bipolar disorder (Key Question 3)

Comparison | Outcome (N Studies; N Patients) | Strength of Evidence Domains | | | | Strength of Evidence
Comparison | Outcome (N Studies; N Patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
Aripiprazole–low- vs. high-dose | Suicide (1; 296) | Moderate | Unknown | Direct | Imprecise | Insufficient
Risperidone–low- vs. high-dose | Medication adherence (1; 169) | Moderate | Unknown | Direct | Imprecise | Insufficient
Risperidone–low- vs. high-dose | Suicide (1; 169) | Moderate | Unknown | Direct | Imprecise | Insufficient
Ziprasidone–low- vs. high-dose | Suicide (1; 46) | Moderate | Unknown | Indirect | Imprecise | Insufficient
SGA vs. placebo | Medication adherence (2; 73) | Moderate | Consistent | Direct | Imprecise | Low
SGA vs. placebo | Patient-reported outcome: Switch to depression (1; 161) | Moderate | Unknown | Direct | Imprecise | Insufficient
SGA vs. placebo | Care provider-reported outcomes: CGSQ (1; 277) | Moderate | Unknown | Direct | Imprecise | Insufficient
SGA vs. placebo | Suicide (7; 1245) | Moderate | Consistent | Direct | Imprecise | Moderate

CGSQ = Caregiver Strain Questionnaire; N = number; ROB = risk of bias; SGA = second-generation antipsychotic

- Response rate: Response rate was reported in nine studies. High-dose aripiprazole was favored over low-dose aripiprazole.67 No significant differences in response rates were observed between olanzapine and risperidone in a meta-analysis of two studies63,64 (RR = 0.72; 95% CI, 0.50 to 1.03) or low- and high-dose risperidone.68 A meta-analysis of seven studies65-68,71-73 that compared a SGA with placebo showed a significant difference favoring SGAs (RR = 1.76; 95% CI, 1.46 to 2.13).
- Remission rate: The remission rate was significantly higher for high-dose aripiprazole than low-dose aripiprazole.67 No differences were observed in a study comparing low- and high-dose risperidone.68 A meta-analysis of five placebo-controlled studies65,67,68,71-73 examining SGAs showed a significant difference favoring SGAs (RR = 2.40; 95% CI, 1.50 to 3.83) for remission rate.
- Cognitive and emotional development: One RCT70 found a lower speed of processing score in patients receiving ziprasidone than placebo; however, the level of significance was not reported.
- Suicide-related behaviors: Three RCTs found no deaths by suicide.67,68,70 No differences were found in suicidal ideation42,67,68,70-73 and suicide attempts65,68,70,71 between SGAs.
- Medication adherence: One RCT comparing two doses of risperidone found no difference in adherence rate between groups.68 A meta-analysis of three RCTs66,68,72 found a significant difference between groups favoring placebo over SGAs.
- Patient-, parent-, or care provider–reported outcomes: One RCT found no difference between olanzapine and placebo in the incidence of switch to depression during the trial.71 A second RCT73 found no difference between low- and high-dose quetiapine or quetiapine and placebo on the Caregiver Strain Questionnaire (CSQ).
- Other outcomes: No studies provided data for the following outcome categories: growth and maturation, school performance, work-related functional capacity, patient insight into illness, health-related quality of life, legal system interactions, or health care system utilization.

Data on the effectiveness of SGAs and placebo on short- and long-term outcomes are presented in detail below.

#### SGAs Versus SGAs

##### Olanzapine Versus Risperidone

A 4-week RCT (N = 31) compared the effectiveness of olanzapine (6.3±2.3 mg/day) and risperidone (1.4±0.5 mg/day) in children ages 4 to 6 years with bipolar I disorder.63 As noted earlier, bipolar I is a controversial diagnosis in young children. No significant difference was found between groups in response rate, defined as a greater than 30 percent reduction in YMRS or CGI–I≤2.

##### Olanzapine Versus Quetiapine Versus Risperidone Versus Ziprasidone

An 8-week open-label RCT evaluated the relative effectiveness of four SGA monotherapy regimens on children and adolescents with bipolar disorder.64 No significant differences in response rates was found among the SGAs.

Two studies63,64 provided data for a meta-analysis of olanzapine versus risperidone on response rate (Figure 24). The combined estimate favored risperidone but was not significant (RR = 0.72; 95% CI, 0.50 to 1.03). There was no evidence of heterogeneity (p = 0.76, I^2^ = 0%).

Figure 24 Olanzapine versus risperidone on response rate in bipolar disorder

CI = confidence interval; df = degrees of freedom; IV = inverse variance

Figure 24 is a metagraph depicting the effect of olanzapine versus risperidone on response rate in patients with bipolar disorder. Two studies with 92 patients were pooled in the meta-analysis. The combined estimate favored risperidone but was not statistically significant (RR = 0.72; 95 percent CI, 0.50 to 1.03). There was no evidence of heterogeneity (p = 0.76, I2 = 0 percent).

##### Aripiprazole–Low- Versus High-Dose

Findling et al. compared two doses of aripiprazole (10 mg/day and 30 mg/day) and placebo in a 4-week RCT (N = 296) of children ages 10 to 17.^67^ Treatment response was defined as a 50 percent or greater reduction in YMRS score. Remission was defined as YMRS≤12 points and CGI–BP≤2 points at endpoint. Response and remission rates were significantly higher in high-dose aripiprazole than low-dose aripiprazole (p = 0.01 and p = 0.002, respectively). No deaths by suicide occurred during the study; however, one patient in the low-dose aripiprazole group reported suicidal ideation.

##### Quetiapine–Low- Versus High-Dose

A 3-week placebo-controlled RCT compared the efficacy of low-dose (400 mg/day) and high-dose (600 mg/day) quetiapine in the treatment of children and adolescents ages 10 to 17 with bipolar I mania.73 No significant differences were observed between the dosing groups for response rate, remission rate, or the CSQ.

##### Risperidone–Low- Versus High-Dose

Low-dose (0.5–2.5 mg/day) and high-dose (3–6 mg/day) risperidone were compared in a 3-week placebo-controlled RCT (N = 169) of children ages 10 to 17 years.68 No significant differences were observed between the risperidone groups for response (defined as a ≥50 percent reduction in YMRS) and remission (defined as YMRS≤12 and CGI–BP ≤2). No deaths by suicide occurred during the study. Rates of suicide attempt and suicidal ideation were not significantly different between groups.

##### Ziprasidone–Low- Versus High-Dose

A 3-week RCT (N = 46) randomized children ages 10 to 17 with bipolar disorder or with schizophrenia or schizoaffective disorder to low-dose (80 mg/day) and high-dose (160 mg/day) ziprasidone.42 One patient in the high-dose group reported suicidal ideation; it was unclear whether this patient had bipolar disorder or schizophrenia.

#### SGAs Versus Placebo

Eight RCTs provided data on five comparisons with placebo: aripiprazole,67,72 olanzapine,71 quetiapine,65,66,73 risperidone,68 and ziprasidone.70 A summary of the characteristics of these studies is presented in Key Question 1 above. The following outcomes were examined by the studies: response, remission, medication adherence, suicide-related behaviors, self-injurious behavior, speed of processing, switch to depression, and caregiver strain.

Seven RCTs65-68,71-73 provided data for a meta-analysis comparing SGAs with placebo for treatment response rate (Figure 25). The combined estimate showed a significant difference between treatments favoring SGAs (RR = 1.76; 95% CI, 1.46 to 2.13). There was moderate heterogeneity (p = 0.20, I^2^ = 30%). The heterogeneity may be attributable to one study65 that enrolled patients who were older and were experiencing a depressive episode during the study.

Figure 25 SGAs versus placebo on response rate in bipolar disorder

CI = confidence interval; df = degrees of freedom; M-H = Mantel-Haenszel; SGA = second-generation antipsychotic

Figure 25 is a metagraph depicting the effect of SGAs on response rate in bipolar disorder. Seven RCTs with 499 patients were pooled to compare SGAs (aripiprazole, olanzapine, quetiapine, and risperidone) with placebo. All of the studies, with the exception of one study comparing quetiapine and placebo, favored the SGA. The combined estimate showed a statistically significant difference between treatments favoring SGAs (RR = 1.76; 95 percent CI, 1.46 to 2.13). There was moderate heterogeneity among the pooled studies (p = 0.20, I2 = 30 percent).

Six RCTs65,67,68,71-73 provided data for a meta-analysis comparing SGAs with placebo for remission rate (Figure 26). The pooled estimate showed a significant difference between treatments favoring SGAs (RR = 2.40; 95% CI, 1.50 to 3.83). There was substantial heterogeneity (p = 0.009, I^2^ = 68 percent), which was mostly a result of one study65 that included only patients experiencing a depressive episode.

Figure 26 SGAs versus placebo on remission rate in bipolar disorder

CI = confidence interval; df = degrees of freedom; M-H = Mantel-Haenszel; SGA = second-generation antipsychotic

Figure 26 is a metagraph depicting the effect of SGAs (aripiprazole, olanzapine, quetiapine, and risperidone) on remission rate in bipolar disorder. Six studies with 976 patients were pooled. The pooled estimate showed a statistically significant difference between treatments favoring SGAs over placebo (RR = 2.40; 95 percent CI, 1.50 to 3.83). There was substantial heterogeneity among the pooled studies (p = 0.009, I2 = 68 percent).

Three RCTs66,68,72 contributed to a meta-analysis comparing adherence rate for SGAs versus placebo (Figure 27). The pooled risk ratio showed a significant difference favoring placebo (RR = 2.02; 95% CI, 1.02 to 4.01). There was no evidence of heterogeneity (p = 0.35, I^2^ = 0%).

Figure 27 SGAs versus placebo on adherence rate in bipolar disorder

CI = confidence interval; df = degrees of freedom; M-H = Mantel-Haenszel; SGA = second-generation antipsychotic

Figure 27 is a metagraph depicting the effect of SGAs (aripiprazole, quetiapine, and risperidone) on adherence rate in bipolar disorder. The risperidone study did not provide data for the meta-analysis because there were no events in either group. The pooled risk ratio showed a significant difference favoring placebo (RR = 2.02; 95 percent CI, 1.02 to 4.01). There was no evidence of heterogeneity among the studies (p = 0.35, I2 = 0 percent).

Three RCTs67,68,70 reported suicide rates for SGAs versus placebo comparisons. No deaths by suicide occurred in either of the groups across all studies; therefore, a meta-analysis could not be conducted.

Six RCTs67,68,70-73 comparing SGAs with placebo reported rate of suicidal ideation (Figure 28). The pooled estimate showed no significant difference between the groups (RR = 1.67; 95% CI, 0.66 to 4.20). There was no evidence of heterogeneity (p = 0.99, I^2^ = 0%).

Figure 28 SGAs versus placebo on suicidal ideation in bipolar disorder

CI = confidence interval; df = degrees of freedom; M-H = Mantel-Haenszel; SGA = second-generation antipsychotic

Figure 28 is a metagraph depicting the effect of SGAs (aripiprazole, olanzapine, quetiapine, risperidone, and ziprasidone) on rate of suicidal ideation in bipolar disorder. Six studies with 1181 patients provided data for this comparison. The study comparing ziprasidone with placebo could not be pooled in the analysis because no events occurred in either group. The pooled estimate showed no significant difference between the groups (RR = 1.67; 95 percent CI, 0.66 to 4.20). There was no evidence of heterogeneity among the studies (p = 0.99, I2 = 0 percent).

The suicide attempt rate was pooled for four RCTs65,68,70,71 comparing SGAs with placebo (Figure 29). There was no significant difference between the groups (RR = 1.52; 95% CI, 0.34 to 6.81) and no evidence of heterogeneity (p = 0.72, I^2^ = 0%).

Figure 29 SGAs versus placebo on suicide attempts in bipolar disorder

CI = confidence interval; df = degrees of freedom; M-H = Mantel-Haenszel; SGA = second-generation antipsychotic

Figure 29 is a metagraph depicting the effect of SGAs (olanzapine, quetiapine, risperidone, and ziprasidone) on suicidal ideation in bipolar disorder. Four studies provided data from 599 patients. No events occurred in either group in the olanzapine study. The pooled estimate showed no significant difference between the groups (RR = 1.52; 95 percent CI, 0.34 to 6.81) and no evidence of heterogeneity (p = 0.72, I2 = 0 percent).

One study found no difference between ziprasidone and placebo on self-injurious behavior.70 Speed of processing score was lower in patients treated with ziprasidone than with placebo; however, the level of significance was not reported.70 The incidence of switch to depression (CGI depression score ≤3 at baseline and ≥4 points at any time during the double-blind phase) did not differ significantly between olanzapine and placebo.71 One study found no significant difference between quetiapine and placebo in relieving caregiver burden, as assessed by the CSQ.73

### Schizophrenia and Related Psychosis: Overview

Twenty-five studies (23 RCTs42,69,74-94 and 2 prospective cohort studies95,96) examined the efficacy of FGAs and SGAs for treating symptoms in patients with schizophrenia and schizophrenia-related psychosis. All studies reported on symptom improvement measures, and all except for three studies82,90,94 reported on other short- and long-term outcomes.

Table 19 highlights key characteristics of the studies. Individual studies are presented in order of drug comparison, with head-to-head evidence preceding placebo comparisons, and then alphabetically by drug name. Several studies included both head-to-head comparisons and a placebo control; these studies are classified under the head-to-head category. A detailed evidence table is available in Appendix D.

Table 19 Characteristics of studies examining schizophrenia and related psychosis

Author, Year, Study Design, Duration, KQ | Intervention (N Enrolled), Dosage (mg/day) Mean±SD | Age, Mean±SD (Range) / Males (%) / White (%) Comorbidities | Diagnosis Breakdown (n) Quality Rating
FGAs vs. SGAs
Kumra et al, 1996^82^ RCT, 6 wk KQ1 | G1: Haloperidol (11), 16±8 mg/day G2: Clozapine (10), 176±149 mg/day | G1: 13.7±1.6 yr / Male: 55% / White: NR G2: 14.4±2.9 yr / Male: 50% / White: NR Comorbidities: NR | disorganized (10), paranoid (1), undifferentiated (10) High ROB
de Haan et al, 2003^76^ RCT, 6 wk KQ1, KQ3 | G1: Haloperidol (12), 2.5 mg/day G2: Olanzapine (12), 7.5 mg/day | G1: 21.0±2.8 yr / Male: NR / White: NR G2: 21±2.3 yr / Male: NR / White: NR Comorbidities: NR | disorganized (6), paranoid (13), undifferentiated (5) High ROB
Ratzoni et al, 2002^96^ Prospective cohort, 12 wk KQ1, KQ3 | G1: Haloperidol (8), 7.6±4 mg/day G2: Olanzapine (21), 12.7±3.1 mg/day G3: Risperidone (21), 3.2±1.1 mg/day | G1: 17.3±1.3 yr / Male: 63% / White: NR G2: 17±1.6 yr / Male: 67% / White: NR G3: 17.1±2.1 yr / Male: 57% / White: NR Comorbidities: NR | CD (2), schizoaffective disorder (2), schizophrenia (46) 3/8 stars
Sikich et al, 2004^89^ RCT, 8 wk (12 wk extension) KQ1, KQ3 | G1: Haloperidol (15), 5±2 mg/day G2: Olanzapine (16), 12.3±3.5 mg/day G3: Risperidone (19), 4±1.2 mg/day | G1: 15.4±2.2 yr / Male: 53% / White: 73% G2: 14.6±3.1 yr / Male: 56% / White: 63% G3: 14.6±2.9 yr / Male: 68% / White: 47% Comorbidities: NR | affective disorders (24), schizophrenia spectrum (26) High ROB
Yen et al, 2004^94^ RCT, 12 wk KQ1 | G1: Haloperidol (2), 11.2±6.9 mg/day G2: Risperidone (6), 4.4±2.6 mg/day | G1: 24 yr / Male: 0 / White: NR G2: 20.7 yr / Male: 67% / White: NR Comorbidities: NR | NR High ROB
SGAs vs. SGAs
Findling et al, 2008^77^ RCT, 6 wk KQ1, KQ3 | G1: Aripiprazole (low) (100), 9.8 mg/day G2: Aripiprazole (high) (102), 28.9 mg/day G3: Placebo (100) | G1: 15.6±1.3 yr / Male: 45% / White: 54% G2: 15.4±1.4 yr / Male: 64% / White: 61% G3: 15.4 ±1.4 yr / Male: 61% / White: 64% Comorbidities: NR | NR High ROB
Kumra et al, 2008^81^ RCT, 12 wk (12 wk extension) KQ1, KQ3 | G1: Clozapine (18), 403.1±201.8 mg/day G2: Olanzapine (21), 26.2±6.5 mg/day | G1: 15.8±2.2 yr / Male: 44% / White: 11% G2: 15.5±2.1 yr / Male: 62% / White: 29% Comorbidities: NR | schizoaffective disorder (14), schizophrenia (25) High ROB
Kumra et al, 1998^95^ Prospective cohort, G1: 6 wk, G2: 8 wk KQ1, KQ3 | G1: Clozapine (15), 317±147 mg/day G2: Olanzapine (8), 17.5±2.3 mg/day | G1: 13.6±1.5 yr / Male: 53% / White: NR G2: 15.3±2.3 yr / Male: 50% / White: NR Comorbidities: NR | disorganized (11), paranoid (3), undifferentiated (9) 5/8 stars
Shaw et al, 2006^87^ RCT, 8 wk (2 yr extension) KQ1, KQ3 | G1: Clozapine (12), 327±113 mg/day G2: Olanzapine (13), 18.1±4.3 mg/day | G1: 11.7±2.3 yr / Male: 67% / White: 58% G2: 12.8±2.4 yr / Male: 54% / White: 54% Comorbidities: ADHD/ODD/CD (7), anxiety disorders (7) | NR Unclear ROB
Arango et al, 2009^74^ RCT, 6 mo KQ1, KQ3 | G1: Olanzapine (26), 9.7±6.6 mg/day G2: Quetiapine (24), 532.8±459.6 mg/day | G1: 15.7±1.4 yr / Male: 76% / White: 77% G2: 16.3±1.1 yr / Male: 79% / White: 88% Comorbidities: NR | BD (13), schizophrenia (17), other psychoses (20) High ROB
Jensen et al, 2008^79^ RCT, 12 wk KQ1, KQ3 | G1: Olanzapine (10), 14±4.6 mg/day G2: Quetiapine (10), 611±253.4 mg/day G3: Risperidone (10), 3.4±1.5 mg/day | G1: 15.3±1.5 yr / Male: 50% / White: 50% G2: 14.8±2.3 yr / Male: 70% / White: 60% G3: 15.6±2.5 yr / Male: 80% / White: 70% Comorbidities: NR | psychotic disorder NOS (9), schizophrenia/ schizoaffective disorder (16), schizophreniform disorder (5) High ROB
Mozes et al, 2006^83^ RCT, 12 wk KQ1, KQ3 | G1: Olanzapine (12), 8.2±4.4 mg/day G2: Risperidone (13), 1.6±1 mg/day | G1: 11.5±1.6 yr / Male: 42% / White: NR G2: 10.7±1.4 yr / Male: 39% / White: NR Comorbidities: ADHD (3), epilepsy (2), familial mediterranean fever (1), neurofibromatosis (1), OCD (3), tic disorder (1) | disorganized schizophrenia (7), paranoid schizophrenia (6), schizophreniform disorder (10), unspecified schizoprehenia (2) High ROB
Sikich et al, 2008^88^ RCT, 8 wk (44 wk extension) KQ1, KQ3 | G1: Olanzapine (36), 11.4±5 mg/day G2: Rispiradone (42), 2.8±1.4 mg/day | G1: NR / Male: 71% / White: 60% G2: NR / Male: 66% / White: 61% Comorbidities: ADHD (22), affective disorder (19), anxiety disorder (21), ASD (5), DBD (16), learning disability (3), psychosis (10), SA (4) | schizoaffective disorder (26), schizophrenia (50) Unclear ROB
van Bruggen et al, 2003^92^ RCT, olanzapine 9.8 wk, risperidone 6.7 wk KQ1, KQ3 | G1: Olanzapine (18), 15.6±4 mg/day G2: Risperidone (26), 4.4±1.5 mg/day | G1: 21±2.8 yr / Male: 72% / White: NR G2: 20.6±3 yr / Male: 85% / White: NR Comorbidities: NR | NR High ROB
Robb et al, 2009^86^ RCT, 6 wk KQ1, KQ3 | G1: Paliperidone ER (low) (54), NR G2: Paliperidone ER (medium) (48), NR G3: Paliperidone ER (high) (48), NR G4: Placebo (51) | All groups: NR / Male: NR / White: NR Comorbidities: NR | paranoid schizophrenia (143), other (58) High ROB
Berger et al, 2008^75^ RCT, 4 wk (8 wk extension) KQ1, KQ3 | G1: Quetiapine (low) (69), 200 mg/day G2: Quetiapine (high) (72), 400 mg/day | G1: 19.7±2.6 yr / Male: 71% / White: NR G2: 19±2.9 yr / Male: 64% / White: NR Comorbidities: SA (58) | nonaffective psychosis (95), affective psychosis (31) High ROB
NCT00090324, 2008^84^ RCT, 6 wk KQ1, KQ3 | G1: Quetiapine (low) (73), 400 mg/day G2: Quetiapine (high) (74), 800 mg/day G3: Placebo (75) | G1: 15.5±1.3 yr / Male: 59% / White: 62% G2: 15.5±1.3 yr / Male: 60% / White: 60% G3: 15.3±1.4 yr / Male: 58% / White: 63% Comorbidities: NR | disorganized (16), paranoid (155), residual (1), undifferentiated (48) High ROB
Swadi et al, 2010^91^ RCT, 6 wk KQ1, KQ3 | G1: Quetiapine (11), 607 mg/day G2: Risperidone (11), 2.9 mg/day | G1: NR / Male: 55% / White: NR G2: NR / Male: 64% / White: NR Comorbidities: NR | NR High ROB
Haas et al, 2009^78^ RCT, 8 wk KQ1, KQ3 | G1: Risperidone (low) (132), 0.4 mg/day G2: Risperidone (high) (125), 4 mg/day | G1: 15.6±1.3 (13–17) yr / Male: 61% / White: 85% G2: 15.7±1.3 (13–17) yr / Male: 52% / White: 85% Comorbidities: NR | catatonic (7), disorganized (19), paranoid (175), residual (7), undifferentiated (49) High ROB
Haas, 2009^69^ RCT, 6 wk KQ1, KQ3 | G1: Risperidone, 1–3 mg/day (54) G2: Risperidone, 4–6 mg/day (50) G3: Placebo (54) | G1: 15.7±1.3 yr / Male: 55% / White: 60% G2: 15.6±1.3 yr / Male: 73% / White: 47% G3: 15.5±1.4 yr / Male: 65% / White: 50% Comorbidities: NR | paranoid (110), undifferentiated (33), disorganized (15), catatonic (1), residual (1) High ROB
DelBello et al, 2008^42^ RCT, 3 wk (24 wk extension) KQ1, KQ3 | G1: Ziprasidone (low) (8), target: 80 mg/day G2: Ziprasidone (high) (9), target: 160 mg/day | G1: 14.4±2.3 yr / Male: 52% / White: NR G2: 14.7±2.0 yr / Male: 75% / White: NR Comorbidities: NR | bipolar I disorder (46), schizophrenia or schizoaffective disorder (17) High ROB
FGAs vs. Placebo
Spencer et al, 1994^90^ RCT (crossover), 8 wk KQ1 | G1: Haloperidol (16),^*^ 2 mg/day G2: Placebo (16)^*^ | All groups: NR / Male: NR / White: NR Comorbidities: Prior diagnoses: atypical PDD (5), atypical psychosis (3), borderline personality disorder (1), CD (1), pica (1) | NR Unclear ROB
SGA vs. Placebo
Kryzhanovskaya et al, 2009^80^ RCT, 6 wk (6 mo extension) KQ1, KQ3 | G1: Olanzapine (72), 11.1 mg/day G2: Placebo (35) | G1: 16.1±1.3 yr / Male: 71% / White: 72% G2: 16.3±1.6 yr / Male: 69% / White: 71% Comorbidities: NR | NR High ROB
Woods et al, 2003^93^ RCT, 8 wk (12 mo extension) KQ1, KQ3 | G1: Olanzapine (31), 8±3.1 mg/day G2: Placebo (29) | G1: 18.2±5.5 yr / Male: 68% / White: 74% G2: 17.2±4 yr / Male: 62% / White: 59% Comorbidities: SA [marijuana (16), other (11)] | NR High ROB
NCT00257192, 2010^85^ RCT, 6 wk KQ1, KQ3 | G1: Ziprasidone (NR), target: 60–80 mg/day (<45 kg), 120–160 mg/day (≥45 kg) G2: Placebo (NR) | G1: 15.3 yr / Male: NR / White: NR G2: 15.4 yr / Male: NR / White: NR Comorbidities: NR | paranoid (184) High ROB

ADHD = attention deficit hyperactivity disorder; ASD = autism spectrum disorder; BD = bipolar disorder; CD = conduct disorder; DBD = disruptive behavior disorder; ER = extended release; G = group; FGA = first-generation antipsychotic; KQ = key question; mg = milligram; mo = month; N = number; NOS = not otherwise specified; NR = not reported; OCD = obsessive-compulsive disorder; ODD = oppositional defiant disorder; PDD = pervasive developmental disorder; RCT = randomized controlled trial; ROB = risk of bias; SA = substance abuse; SD = standard deviation; SGA = second-generation antipsychotic; wk = week; yr = year

* All patients received each of the treatments in this crossover study.

The average age of patients across the studies was 15.7 years. Sexes were equally represented across the studies (54 percent male). Among the studies that reported race, the majority of patients were white, with the exception of one study of African Americans.81 Diagnoses were established using the DSM–IV in the majority of studies (N = 19, 76 percent). Three studies enrolled only patients experiencing a first episode of psychosis,74,75,91 and one study enrolled patients with psychosis related to bipolar disorder and schizophrenia (results were not presented separately for these conditions).89 All other patients had a disorder along the schizophrenia spectrum. The most common comorbidities included substance abuse (89 patients), ADHD (32 patients), and anxiety disorder (28 patients); however, each of these were reported in less than 5 percent of the total number of patients.

Haloperidol was compared with various SGAs (clozapine, olanzapine, and risperidone) in five studies. Sixteen studies compared SGAs. Of these, nine studies compared different SGAs (clozapine vs. olanzapine, olanzapine vs. quetiapine, olanzapine vs. risperidone, and quetiapine vs. risperidone), and seven compared two doses of the same SGA. Haloperidol was compared with placebo in one study. SGAs were compared with placebo in seven studies.

The studies were generally of short duration, ranging from 3 weeks to 6 months (average of 7.7 weeks). The majority of the trials had a high risk of bias. The most common sources of potential bias were incomplete outcome data and industry sponsorship. Three trials had an unclear risk of bias.87,88,90 The two prospective cohort studies had low96 and moderate quality.95

### Schizophrenia and Related Psychosis: Disorder-Specific and Nonspecific Symptoms (Key Question 1)

Twenty-five studies compared the efficacy of FGAs and SGAs for the treatment of symptoms in patients with schizophrenia and related psychosis. A summary of the results by comparison is presented below. Table 20 provides the strength of evidence grades for all key outcomes that were reported by at least one study.

Table 20 Strength of evidence for schizophrenia and related psychosis (Key Question 1)

Comparison | Outcome (N Studies; N Patients) | Strength of evidence domains | | | | Strength of Evidence
Comparison | Outcome (N Studies; N Patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
FGAs vs. SGAs | Clinical global impressions (3; 95) | Moderate | Consistent | Direct | Imprecise | Low
FGAs vs. SGAs | Positive and negative symptoms (4; 103) | Moderate | Inconsistent | Direct | Imprecise | Low
Clozapine vs. olanzapine | Clinical global impressions (2; 65) | Moderate | Consistent | Direct | Imprecise | Low
Clozapine vs. olanzapine | Positive and negative symptoms (3; 88) | Moderate | Consistent | Direct | Imprecise | Low
Olanzapine vs. quetiapine | Clinical global impressions (2; 80) | Moderate | Inconsistent | Direct | Imprecise | Insufficient
Olanzapine vs. quetiapine | Positive and negative symptoms (1; 50) | Moderate | Unknown | Direct | Imprecise | Insufficient
Olanzapine vs. risperidone | Clinical global impressions (3; 143) | Moderate | Consistent | Direct | Not pooled | Low
Olanzapine vs. risperidone | Positive and negative symptoms (4; 197) | Moderate | Consistent | Direct | Imprecise | Low
Quetiapine vs. risperidone | Positive and negative symptoms (1; 22) | Moderate | Unknown | Direct | Imprecise | Insufficient
Low- vs. high-dose aripiprazole | Clinical global impressions (1; 302) | Moderate | Unknown | Direct | Imprecise | Insufficient
Low- vs. high-dose aripiprazole | Positive and negative symptoms (1; 302) | Moderate | Unknown | Direct | Imprecise | Insufficient
Low- vs. high-dose paliperidone | Clinical global impressions (1; 201) | Moderate | Unknown | Direct | Precise | Insufficient
Low- vs. high-dose paliperidone | Positive and negative symptoms (1; 201) | Moderate | Unknown | Direct | Imprecise | Insufficient
Low- vs. high-dose quetiapine | Clinical global impressions (2; 363) | Moderate | Inconsistent | Direct | Not pooled | Insufficient
Low- vs. high-dose quetiapine | Manic symptoms (1; 141) | Moderate | Unknown | Direct | Imprecise | Insufficient
Low- vs. high-dose quetiapine | Positive and negative symptoms (2; 363) | Moderate | Consistent | Direct | Not pooled | Insufficient
Low- vs. high-dose quetiapine | Social and occupational functioning (1; 141) | Moderate | Unknown | Direct | Imprecise | Insufficient
Low- vs. high-dose risperidone | Clinical global impressions (2; 361) | Moderate | Inconsistent | Direct | Not pooled | Insufficient
Low- vs. high-dose risperidone | Positive and negative symptoms (2; 361) | Moderate | Inconsistent | Direct | Not pooled | Insufficient
Low- vs. high-dose ziprasidone | Clinical global impressions (1; 17) | Moderate | Unknown | Direct | Imprecise | Insufficient
Haloperidol vs. placebo | Clinical global impressions (1; 32) | Moderate | Unknown | Direct | Imprecise | Insufficient
Haloperidol vs. placebo | Positive and negative symptoms (1; 32) | Moderate | Unknown | Direct | Imprecise | Insufficient
SGA vs. placebo | Aggression (1; 107) | Moderate | Unknown | Direct | Imprecise | Insufficient
SGA vs. placebo | Clinical global impressions (6; 1050) | Moderate | Consistent | Direct | Precise | Moderate
SGA vs. placebo | Manic symptoms (1; 60) | Moderate | Unknown | Direct | Imprecise | Insufficient
SGA vs. placebo | Positive and negative symptoms (6; 1068) | Moderate | Consistent | Direct | Precise | Moderate

FGA = first-generation antipsychotic; N = number; ROB = risk of bias; SGA = second-generation antipsychotic

- FGAs versus SGAs (four RCTs76,82,89,94 and one prospective cohort study96): Haloperidol was compared with clozapine,82 olanzapine,76,89,96 and risperidone.89,94,96 SGAs were significantly favored in meta-analyses of the BPRS (MD = -11.44; 95% CI, -19.35 to -3.52) and CGI–I (MD = -0.76; 95% CI, -1.25 to -0.26). There was no significant difference between the drug classes on the Positive and Negative Syndrome Scale (PANSS).
- Clozapine versus olanzapine (two RCTs81,87 and one prospective cohort study 95): Meta-analyses showed no significant differences between these SGAs on the BPRS, CGI–S, or Scale for the Assessment of Negative Symptoms (SANS).
- Olanzapine versus quetiapine (two RCTs74,79): There was a significant difference favoring olanzapine for Strengths and Difficulties Questionnaire as rated by patients in one study (p = 0.03).74
- Olanzapine versus risperidone (five RCTs79,83,88,89,92 and one prospective cohort study96): Meta-analyses showed no significant differences between olanzapine and risperidone on the BPRS, CGI–S, or PANSS.
- Quetiapine versus risperidone (one RCT91): There was no significant difference between groups in positive and negative symptoms.
- SGAs–Dosing (seven RCTs; aripiprazole,77 paliperidone,86 quetiapine,75,84 risperidone,69,78 and ziprasidone.42): The high-dose (4.0 mg/day) risperidone group showed greater symptom improvement than the low-dose (0.4 mg/day) group on the CGI–I, CGI–S, and PANSS in one study.78 A second study found no significant differences between low- (1–3 mg/day) and high-dose (4–6 mg/day) risperidone on the CGAS, CGI–I, CGI–S, or PANSS.69 No other significant differences were found between doses.
- Haloperidol versus placebo (one crossover RCT90): Positive and negative syndrome scores on the CPRS improved significantly in the haloperidol group compared with placebo (p<0.01).
- SGAs versus placebo (seven RCTs; aripiprazole,77 olanzapine,80,93 paliperidone,86 quetiapine,84 risperidone,69 and ziprasidone85): A significant difference was found favoring SGAs on the CGAS, CGI–I, CGI–S, and PANSS. No difference was found for BPRS.

A detailed analysis is presented by comparison below.

#### FGAs Versus SGAs

Five studies provided data on the following FGAs versus SGAs comparisons: haloperidol versus clozapine,82 haloperidol versus olanzapine,76,89,96 and haloperidol versus risperidone.89,94,96

##### Haloperidol Versus Clozapine

A 6-week RCT (N = 21) compared the efficacy of haloperidol (16±8 mg/day) and clozapine (176±149 mg/day) in patients ages 6 to 18 with schizophrenia.82 Patients were assessed using the BPRS–C, CGAS, CGI–I, SANS, and the Scale for the Assessment of Positive Symptoms. Symptoms improved to a greater extent in the clozapine group than the haloperidol group across all outcome measures (p<0.05).

##### Haloperidol Versus Olanzapine

Three studies compared the effect of haloperidol versus olanzapine on schizophrenia symptoms. A 6-week RCT (N = 24) examined adolescents and young adults ages 17 to 26.^76^ The mean drug dose was 2.5 mg/day and 7.5 mg/day for haloperidol and olanzapine, respectively. Patients were assessed using the CGI–I and PANSS. Symptoms improved from baseline to endpoint in both groups; however, there were no significant differences between the groups.

A 12-week prospective cohort study compared the efficacy of haloperidol (7.6±4 mg/day), olanzapine (12.7±3.1 mg/day), and risperidone (3.2±1.1 mg/day) in adolescents ages 14 to 20 with schizophrenia (n = 46), schizoaffective disorder (n = 2), and conduct disorder (n = 2).96 Changes in the PANSS did not differ significantly between groups from baseline to endpoint.

An 8-week RCT (N = 50) compared the efficacy of haloperidol (5±2 mg/day) with olanzapine (12.3±3.5 mg/day) and risperidone (4±1.2 mg/day) in children with psychosis (24 with affective disorders and 26 with schizophrenia spectrum).89 There was no significant difference between the groups for the CGI–I. However, olanzapine was significantly favored over haloperidol on the BPRS (p = 0.02).

##### Haloperidol Versus Risperidone

Three studies compared haloperidol with risperidone. Two of the studies are described above. Ratzoni et al. found no significant difference between haloperidol and risperidone on the PANSS.96 Sikich et al. found a significant difference favoring risperidone over haloperidol for the CGI–S and CPRS (p = 0.03 for both outcomes), but no difference on the CGI–I.89

A 12-week RCT compared the efficacy of haloperidol (11.2±6.9 mg/day) and risperidone (4.4±2.6 mg/day) in adult patients with schizophrenia.94 Data for eight patients ages ≤24 were presented separately. Patients were assessed using the PANSS. The risperidone group demonstrated significantly greater improvement in the PANSS score than the haloperidol group (p = 0.03).

##### Meta-analyses Comparing FGAs Versus SGAs

Meta-analyses were conducted to compare FGAs and SGAs for the BPRS, CGI–I, and PANSS.

A meta-analysis of two studies82,89 found a significant difference favoring SGAs over haloperidol on the BPRS (MD = -11.44; 95% CI, -19.35 to -3.52) (Figure 30). There was no evidence of heterogeneity (p = 0.99, I^2^ = 0%).

Figure 30 FGAs versus SGAs on BPRS in schizophrenia and related psychosis

BPRS = Brief Psychiatric Rating Scale; CI = confidence interval; df = degrees of freedom; FGA = first-generation antipsychotics; IV = inverse variance; SD = standard deviation; SGA = second-generation antipsychotic

Figure 30 is a metagraph depicting the effect of haloperidol versus SGAs on BPRS in schizophrenia and related psychosis. One study compared haloperidol and clozapine; another compared haloperidol with olanzapine and risperidone. A total of 71 patients were included in these studies. A meta-analysis of two studies found a significant difference favoring SGAs over haloperidol on the BPRS (MD = -11.44; 95 percent CI, -19.35 to -3.52). There was no evidence of heterogeneity between the studies (p = 0.99, I2 = 0 percent).

Three RCTs76,82,89 provided data for a meta-analysis on the efficacy of FGAs versus SGAs on CGI–I (Figure 31). A pooled estimate of the change scores was significant, favoring SGAs over haloperidol (MD = -0.76; 95% CI, -1.25 to -0.26). There was no evidence of heterogeneity (p = 0.67, I^2^ = 0%).

Figure 31 FGAs versus SGAs on CGI–I in schizophrenia and related psychosis

CGI–I = Clinical Global Impressions–Improvement; CI = confidence interval; df = degrees of freedom; FGA = first-generation antipsychotics; IV = inverse variance; SD = standard deviation; SGA = second-generation antipsychotic

Figure 31 is a metagraph depicting the effect of haloperidol versus SGAs (clozapine, olanzapine, and risperidone) on CGI–I in patients with schizophrenia and related psychosis. Three RCTs provided data from 87 participants. The pooled estimate of the clinical global impression was statistically significant, favoring SGAs over haloperidol (MD = -0.76; 95 percent CI, -1.25 to -0.26). There was no evidence of heterogeneity (p = 0.67, I2 = 0 percent).

Two RCTs76,94 provided data for a meta-analysis on the efficacy of FGAs versus SGAs on positive and negative symptoms as measured by the PANSS (Figure 32). There was no significant difference between groups (MD = -9.89; 95% CI, -33.85 to 14.08); however, there was substantial heterogeneity (p = 0.09, I^2^ = 65%), which may be attributable to the use of different SGAs. A higher dose of the FGA in one study94 may also have contributed to the heterogeneity.

Figure 32 FGAs versus SGAs on PANSS in schizophrenia and related psychosis

CI = confidence interval; df = degrees of freedom; FGA = first-generation antipsychotic; IV = inverse variance; PANSS = Positive and Negative Syndrome Scale; SD = standard deviation; SGA = second-generation antipsychotic

Figure 32 is a metagraph depicting the effect of haloperidol versus SGAs (olanzapine and risperidone) on PANSS in patients with schizophrenia and related psychosis. Two RCTs with a total of 27 participants were pooled. There was no significant difference between groups (MD = -9.89; 95 percent CI, -33.85 to 14.08); however, there was substantial heterogeneity (p = 0.09, I2 = 65 percent).

#### SGAs Versus SGAs

Eighteen studies examined the efficacy of SGAs. Eleven of these studies provided head-to-head comparisons of different SGAs, and seven studies compared different doses of the same SGA.

##### Clozapine Versus Olanzapine

Three studies compared clozapine with olanzapine.81,87,95 A 12-week RCT (N = 40) with a 12-week extension examined children ages 10 to 18 with schizophrenia or schizoaffective disorder.81 The mean dosage was 403.1±201.8 mg/day and 26.2±6.5 mg/day for the clozapine and olanzapine groups, respectively. Negative symptoms as measured by the SANS showed significantly greater improvement in the clozapine group than in the olanzapine group at 12 weeks (p = 0.02) and at 24 weeks (p = 0.06). There was significantly greater improvement in CGI–I with olanzapine than with clozapine at 24 weeks (p = 0.007). No significant differences were observed between the groups for the BPRS, CGAS, or CGI–S.

An 8-week prospective cohort study (N = 23) compared the efficacy of clozapine (317±147 mg/day) and olanzapine (17.5±2.3 mg/day) in children ages 6 to 18 with schizophrenia.95 Patients were assessed using the BPRS, SANS, and Scale for the Assessment of Positive Symptoms. The clozapine group showed a greater change from baseline on all outcome scales; however, statistical comparisons between the groups were not reported.

Twenty-five children ages 7 to 16 with schizophrenia were randomized to receive clozapine (327±113 mg/day) or olanzapine (18.1±4.3 mg/day) in an 8-week RCT with a 2-year extension.87 The clozapine group showed significantly greater improvement on the CGI–S (p = 0.04) and SANS (p = 0.003) than the olanzapine group. There was no difference between groups in the BPRS–24 or Scale for the Assessment of Positive Symptoms.

Three studies (two RCTs81,87 and one prospective cohort study95) provided data for a meta-analysis comparing clozapine with olanzapine on the BPRS (Figure 33). The pooled mean difference of the trials and the cohort study showed no significant difference between the drugs.

Figure 33 Clozapine versus olanzapine on BPRS in schizophrenia and related psychosis

BPRS = Brief Psychiatric Rating Scale; CI = confidence interval; df = degrees of freedom; IV = inverse variance; RCT = randomized controlled trial; SD = standard deviation

Figure 33 is a metagraph depicting the effect of clozapine versus olanzapine on BPRS in schizophrenia and related psychosis. Three studies (two RCTs and one cohort study) with a total of 87 patients provided data for the meta-analysis. The pooled mean difference of the trials showed no statistically significant difference between the two SGAs (MD = -5.09; 95 percent CI, -10.82 to 0.64). Similarly, the cohort study showed no significant difference between the drugs.

The two trials81,87 comparing clozapine with olanzapine were pooled for CGI–S (Figure 34). The pooled estimate favored clozapine for reduction in symptom severity; however, the finding was not significant (MD = -0.46; 95% CI, -1.01 to 0.08). There was no evidence of heterogeneity (p = 0.74, I^2^ = 0%).

Figure 34 Clozapine versus olanzapine on CGI–S in schizophrenia and related psychosis

CGI–S = Clinical Global Impressions–Severity; CI = confidence interval; df = degrees of freedom; IV = inverse variance; SD = standard deviation

Figure 34 is a metagraph depicting the effect of clozapine versus olanzapine on CGI–S in schizophrenia and related psychosis. Two trials with 64 patients were pooled. The pooled estimate favored clozapine for reduction in symptom severity; however, this was not statistically significant (MD = -0.46; 95 percent CI, -1.01, 0.08). There was no evidence of heterogeneity (p = 0.74, I2 = 0 percent).

The same trials81,87 also provided data for a meta-analysis of negative symptoms, as measured by the SANS (Figure 35). The pooled analysis showed no significant difference between the two SGAs on improvement in negative symptoms (MD = -5.05, 95% CI, -15.45 to 5.36). There was substantial heterogeneity between the two trials (p = 0.16, I^2^ = 50%), which may be attributable to the higher mean dose of olanzapine in the study by Kumra et al.81

Figure 35 Clozapine versus olanzapine on SANS in schizophrenia and related psychosis

CI = confidence interval; df = degrees of freedom; IV = inverse variance; RCT = randomized controlled trial; SANS = Scale for the Assessment of Negative Symptoms; SD = standard deviation

Figure 35 is a metagraph depicting the effect of clozapine versus olanzapine on negative symptoms as measured by SANS in schizophrenia and related psychosis. Two trials provided data for meta-analysis from 64 participants. The pooled analysis showed no significant difference between the two SGAs on improvement in negative symptoms (MD = -5.05, 95 percent CI, -15.45 to 5.36). There was substantial heterogeneity between the two trials (p = 0.16, I2 = 50 percent).

##### Olanzapine Versus Quetiapine

Two studies compared olanzapine with quetiapine.74,79 A 6-month RCT (N = 50) enrolled adolescents experiencing a first episode of psychosis.74 Patients had a variety of diagnoses, including bipolar disorder, schizophrenia, major depressive episode with psychotic features, schizoaffective disorder, schizophreniform disorder, and psychosis not otherwise specified. The mean dosage of the drugs was 9.7±6.6 mg/day and 532.8±459.6 mg/day for olanzapine and quetiapine, respectively. There was a significant difference between the groups for Strengths and Difficulties Questionnaire as rated by patients favoring olanzapine (p = 0.03). No differences were found for the CGAS, CGI–S, PANSS, or YMRS.

A 12-week RCT (N = 30) compared the efficacy of olanzapine (14±4.6 mg/day), quetiapine (611±253.4 mg/day), and risperidone (3.4±1.5 mg/day) in children ages 10 to 18 with schizophrenia-related conditions.79 Patients had schizophrenia, schizoaffective disorder, schizophreniform disorder, and psychotic disorder not otherwise specified. Patients were assessed using the CGI–S, and no difference was found among groups.

##### Olanzapine Versus Risperidone

Olanzapine was compared with risperidone in six studies.79,83,88,89,92,96 One 12-week RCT (N = 30) described above compared the efficacy of olanzapine, quetiapine, and risperidone in children ages 10 to 18 with schizophrenia-related conditions.79 There was no difference between the groups in CGI–S scores at endpoint.

A 12-week RCT (N = 25) compared the efficacy of olanzapine (8.2±4.4 mg/day) and risperidone (1.6±1 mg/day) in children ages 8 to 14 with schizophrenia.83 No significant differences were found between groups on the BPRS, CGAS, or PANSS.

Ratzoni et al.96 conducted a 12-week, three-arm prospective cohort study (N = 50) comparing olanzapine (12.7±3.1 mg/day), risperidone (3.2±1.1 mg/day), and haloperidol (7.6±4 mg/day) (described previously). Changes in positive and negative symptoms did not differ significantly between olanzapine and risperidone on the PANSS.

An 8-week RCT (N = 78) with a 44-week extension compared olanzapine (11.4±5 mg/day) and risperidone (2.8±1.4 mg/day) in children and adolescents ages 8 to 19 with schizophrenia-related disorders.88 Patients had a variety of comorbidities, including ADHD (n = 22), anxiety disorder (n = 21), affective disorder (n = 19), and disruptive behavior disorders (n = 16). No significant differences were observed between the groups for the BPRS–C, CGI–I, CGI–S, or PANSS.

An 8-week RCT (N = 50) described previously compared olanzapine (12.3±3.5 mg/day), risperidone (4±1.2 mg/day), and haloperidol (5±2 mg/day) in children with psychosis.89 No significant differences were observed between olanzapine and risperidone for the BPRS–C, CPRS, CGI–I, or CGI–S.

An RCT (N = 44) by van Bruggen et al.92 compared the efficacy of olanzapine (15.6±4 mg/day) and risperidone (4.4±1.5 mg/day) in patients ages 16 to 28 with schizophrenia, schizophreniform disorder, or schizoaffective disorder who were experiencing a first or second psychotic episode. Change in positive and negative symptoms on the PANSS was not significantly different between the groups.

Three studies83,88,89 comparing olanzapine with risperidone reported data for the BPRS (Figure 36). The meta-analysis showed no significant difference between the two SGAs (MD = -2.45; 95% CI, -7.50 to 2.60). There was no evidence of heterogeneity (p = 0.80, I^2^ = 0%).

Figure 36 Olanzapine versus risperidone on BPRS in schizophrenia and related psychosis

BPRS = Brief Psychiatric Rating Scale; CI = confidence interval; df = degrees of freedom; IV = inverse variance; SD = standard deviation

Figure 36 is a metagraph depicting the effect of olanzapine versus risperidone on BPRS in schizophrenia and related psychosis. Three trials with a total of 136 participants were meta-analyzed. The meta-analysis showed no significant difference between the two SGAs (MD = -2.45; 95 percent CI, -7.50 to 2.60). There was no evidence of heterogeneity (p = 0.80, I2 = 0 percent).

Two RCTs88,89 provided data for a meta-analysis of CGI–S scores (Figure 37). A study by Jensen et al.79 could not be included in this analysis because it reported the proportion of patients who attained a certain CGI–S threshold instead of the change scores. No significant difference between olanzapine and risperidone was found (MD = 0.30; 95% CI, -0.24 to 0.84). There was no evidence of heterogeneity (p = 1.00, I^2^ = 0%).

Figure 37 Olanzapine versus risperidone on CGI–S in schizophrenia and related psychosis

CGI–S = Clinical Global Impressions–Severity; CI = confidence interval; df = degrees of freedom; IV = inverse variance; SD = standard deviation

Figure 37 is a metagraph depicting the effect of olanzapine versus risperidone on the CGI–S in schizophrenia and related psychosis. Two studies with 111 participants were pooled. There was no significant difference between olanzapine and risperidone in the pooled analysis (MD = 0.30; 95 percent CI, -0.24 to 0.84). There was no evidence of heterogeneity between the studies (p = 1.00, I2 = 0 percent).

Four studies (three RCTs83,88,92 and one prospective cohort study96) compared olanzapine and risperidone for treating positive and negative symptoms (Figure 38). The pooled results of the three trials showed no significant difference between the SGAs (MD = -3.20; 95% CI, -10.26, 3.86) and no evidence of heterogeneity (p = 0.59, I^2^ = 0%). A similar nonsignificant finding was observed in the cohort study.

Figure 38 Olanzapine versus risperidone on PANSS in schizophrenia and related psychosis

CI = confidence interval; df = degrees of freedom; IV = inverse variance; PANSS = Positive and Negative Syndrome Scale; RCT = randomized controlled trial; SD = standard deviation

Figure 38 is a metagraph depicting the effect of olanzapine versus risperidone on PANSS in schizophrenia and related psychosis. Four studies with 175 patients, including three RCTs and one cohort study, provided data on this comparison. The pooled results of the three trials showed no significant difference between the SGAs (MD = -3.20; 95 percent CI, -10.26 to 3.86) and no evidence of heterogeneity between the trials (p = 0.59, I2 = 0 percent). A similar, nonsignificant finding was observed in the cohort study.

##### Quetiapine Versus Risperidone

A 6-week RCT (N = 22) compared quetiapine (607 mg/day) and risperidone (2.9 mg/day) in adolescents 19 and younger experiencing a first episode of psychosis.91 No significant difference between the risperidone and quetiapine groups for improvement in total positive and negative symptoms was found.

##### Aripiprazole–Low- Versus High-Dose

A total of 302 adolescents with schizophrenia ages 13 to 17 were randomized to low- or high-dose aripiprazole or placebo in a 6-week RCT.77 The mean dose of the drugs was 9.8 mg/day and 28.9 mg/day for the low- and high-dose aripiprazole groups, respectively. No significant differences occurred between the low- and high-dose aripiprazole groups on the CGAS, CGI–I, CGI–S, or PANSS.

##### Paliperidone–Low- Versus Medium- Versus High-Dose

Robb et al.86 compared three doses of extended-release paliperidone and placebo in a 6-week RCT (N = 201) of adolescents ages 12 to 17 with schizophrenia. Patients weighing less than 51 kg received 1.5, 3, or 6 mg, whereas patients weighing at least 51 pounds received 1.5, 6, or 12 mg in the low-, medium-, and high-dose groups, respectively. No significant differences occurred between the drug doses on the CGAS, CGI–S, PANSS, or VAS for sleep.

##### Quetiapine–Low- Versus High-Dose

Two RCTs compared two doses of quetiapine. Berger et al.75 examined 141 patients ages 15 to 25 with first-episode psychosis in a 4-week RCT. The mean drug dose was 200 mg/day and 400 mg/day for low- and high-dose quetiapine, respectively. Symptom severity decreased in both the low- and high-dose groups following the 8-week extension period, but the reduction was significantly greater in the high-dose quetiapine group (CGI–S, p = 0.03). No significant differences between groups occurred for the BPRS, Global Assessment of Functioning, SANS, Social and Occupational Functioning Assessment Scale, or YMRS.

A 6-week placebo-controlled RCT (N = 222) examined the efficacy of low- (400 mg/day) and high-dose (800 mg/day) quetiapine in adolescents ages 13 to 17 with schizophrenia.84 No significant differences between the dosing groups occurred on the CGAS, CGI–I, CGI–S, or PANSS.

##### Risperidone–Low- Versus High-Dose

An 8-week RCT (N = 275) compared the efficacy of low- (0.4 mg/day) and high-dose (4 mg/day) risperidone in adolescents ages 13 to 17.^78^ Patients were assessed using the CGI–I, CGI–S, and PANSS. The high-dose risperidone group showed greater symptom improvement than the low-dose group on all three scales (p<0.001).

A 6-week placebo-controlled RCT (N = 158) compared the efficacy of low- (1–3 mg/day) and high-dose (4–6 mg/day) risperidone in adolescents ages 13 to 17.^69^ Patients were assessed using the CGAS, CGI–I, CGI–S, and PANSS. No significant differences were observed between the two dosing groups for any of the outcomes.

We did not pool the results of these two studies in a meta-analysis because the doses used in the studies were not equivalent.

##### Ziprasidone–Low- Versus High-Dose

DelBello et al.42 conducted a 3-week RCT comparing the efficacy of low- (80 mg/day) and high-dose (160 mg/day) ziprasidone for treating children ages 10 to 17 with bipolar mania, schizophrenia, and schizoaffective disorder. Separate analyses were provided for the 17 patients with schizophrenia. Patients were assessed using the BPRS and CGI–S. No significant differences were found between the groups.

#### FGAs Versus Placebo

An 8-week crossover RCT (N = 16) compared haloperidol (2 mg/day) with placebo in children ages 5 to 11 with schizophrenia.90 Patients were assessed using the BPRS–C, CGI–I, CGI–S, and CPRS. Both the positive and negative syndrome scores on the CPRS improved significantly in the haloperidol group compared with the placebo group (p<0.01). Statistical comparisons between the two groups were not reported for the remaining outcome measures.

#### SGAs Versus Placebo

Seven studies compared a SGA with placebo: aripiprazole,77 olanzapine,80,93 paliperidone,86 quetiapine,84 risperidone,69 and ziprasidone.85

##### Aripiprazole Versus Placebo

Findling et al.77 conducted an RCT (N = 302) to compare the efficacy of low- and high-dose aripiprazole with placebo (described previously). Patients were assessed using the CGAS, CGI–I, CGI–S, and PANSS. Both the low- and high-dose aripiprazole groups were significantly more effective in improving symptoms than placebo for all outcomes (p≤0.05).

##### Olanzapine Versus Placebo

A 6-week placebo-controlled RCT (N = 107) with a 6-month extension phase examined the efficacy of olanzapine (11.1 mg/day) in adolescents ages 13 to 18 years with schizophrenia.80 The olanzapine group showed significant improvements over placebo for the BPRS–C, CGI–I, CGI–S, OAS, and PANSS (p≤0.05).

A second RCT (N = 60) compared olanzapine (8±3.1 mg/day) with placebo in patients (ages 12 to 45 years, mean age of 17.7 years) with prodromal syndrome.93 The study endpoint was 1 year, with a 1-year extension. No significant differences were found between the groups on the CGI–S, Global Assessment of Functioning, PANSS, or YMRS.

##### Paliperidone Versus Placebo

A 6-week RCT (N = 201) compared the efficacy of three doses of extended-release paliperidone and placebo in adolescents ages 12 to 17.^86^ One hundred forty-three patients had a diagnosis of paranoid schizophrenia, and 58 had other schizophrenia spectrum diagnoses. The medium-dose paliperidone group showed statistical superiority compared with the placebo group on the CGAS (p<0.001). There were no significant differences on the CGI–S, PANSS, or VAS sleep.

##### Quetiapine Versus Placebo

A 6-week RCT (N = 222) compared the efficacy of low- and high-dose quetiapine and placebo (described previously).84 Patients were assessed using the CGAS, CGI–I, CGI–S, and PANSS. Compared with the placebo group, both low- and high-dose quetiapine showed significantly greater improvement for the CGI–I and PANSS (p<0.05). The high-dose group was superior to placebo for the CGAS (p = 0.02) and CGI–S (p = 0.02).

##### Risperidone Versus Placebo

A 6-week RCT (N = 158) compared the efficacy of low- (1–3 mg/day) and high-dose (4–6 mg/day) risperidone with placebo (described previously).69 Patients receiving risperidone had significantly greater improvement on the CGAS, CGI–I, CGI–S, and PANSS than patients receiving placebo.

##### Ziprasidone Versus Placebo

A 6-week placebo-controlled RCT examined treatment with ziprasidone in 284 adolescents ages 13 to 17 years with schizophrenia.85 The target dose was 60 to 80 mg/day for patients <45 kg and 120 to 160 mg/day for patients ≥45 kg. There was no difference in symptom change on the BPRS–anchored version between the groups.

##### Meta-analyses Comparing Various SGAs With Placebo

Meta-analyses were conducted to compare various SGAs with placebo for the BPRS, CGAS, CGI–I, CGI–S, and PANSS.

Two RCTs compared two SGAs (olanzapine80 and ziprasidone85) with placebo using BPRS scores (Figure 39). Results were not pooled because of considerable heterogeneity (p = 0.02, I^2^ = 81%). The heterogeneity is possibly attributable to the use of different SGAs.

Figure 39 SGAs versus placebo on BPRS in schizophrenia and related psychosis

BPRS = Brief Psychiatric Rating Scale; CI = confidence interval; IV = inverse variance; SD = standard deviation; SGA = second-generation antipsychotic

Figure 39 is a metagraph depicting the effect of SGAs versus placebo on BPRS in schizophrenia and related psychosis. Two RCTs with a total of 213 patients compared two SGAs (olanzapine and ziprasidone) with placebo using BPRS scores. Results were not pooled because of substantial heterogeneity. One study found a significant difference favoring olanzapine over placebo. The second study found no difference between ziprasidone and placebo.

Five RCTs69,77,84,86,93 contributed data to a meta-analysis comparing SGAs with placebo on the CGAS (Figure 40). With the exception of one study examining olanzapine,93 all trials significantly favored the SGAs. The pooled estimate showed a significant improvement in CGAS scores for SGAs compared with placebo (MD = 4.56; 95% CI, 2.55 to 6.57). Heterogeneity was minimal (p = 0.27, I^2^ = 22%).

Figure 40 SGAs versus placebo on CGAS in schizophrenia and related psychosis

CI = confidence interval; CGAS = Children's Global Assessment Scale; df = degrees of freedom; IV = inverse variance; SD = standard deviation; SGA = second-generation antipsychotic

Figure 40 is a metagraph depicting the effect of SGAs (aripiprazole, olanzapine, paliperidone, quetiapine, and risperidone) on CGAS in schizophrenia and related psychosis. Five studies with a total of 880 patients were included in a meta-analysis. With the exception of one study examining olanzapine, all trials significantly favored the SGAs. The pooled estimate showed a statistically significant improvement in CGAS scores for SGAs compared with placebo (MD = 4.56; 95 percent CI, 2.55 to 6.57). Heterogeneity between the studies was minimal (p = 0.27, I2 = 22 percent).

Three RCTs comparing aripiprazole,77 olanzapine,80 and risperidone69 with placebo reported CGI–I scores (Figure 41). The pooled estimate significantly favored SGAs over placebo (MD = -0.75; 95% CI, -1.12 to -0.38). There was substantial heterogeneity between the studies (p = 0.11, I^2^ = 55%), which was driven by differences between the SGA comparators.

Figure 41 SGAs versus placebo on CGI–I in schizophrenia and related psychosis

CGI–I = Clinical Global Impressions–Improvement; CI = confidence interval; df = degrees of freedom; IV = inverse variance; SD = standard deviation; SGA = second-generation antipsychotic

Figure 41 is a metagraph depicting the effect of SGAs on CGI–I in schizophrenia and related psychosis. Three RCTs with a total of 505 patients each compared one of the following SGAs: aripiprazole, olanzapine, and risperidone. The pooled estimate significantly favored SGAs over placebo (MD = -0.75; 95 percent CI, -1.12 to -0.38). There was substantial heterogeneity between the studies (p = 0.11, I2 = 55 percent).

Six RCTs69,77,80,84,86,93 provided data for a meta-analysis comparing SGAs with placebo for global impression of severity (Figure 42). Patients treated with SGAs had a statistically greater reduction in symptom severity than those receiving placebo (MD = -0.50; 95% CI, -0.69 to -0.32). There was evidence of moderate heterogeneity due to differences in the SGAs (p = 0.22, I^2^ = 28%).

Figure 42 SGAs versus placebo on CGI–S in schizophrenia and related psychosis

CGI–S = Clinical Global Impressions–Severity; CI = confidence interval; df = degrees of freedom; SD = standard deviation; SGA = second-generation antipsychotic

Figure 42 is a metagraph depicting the effect of SGAs (aripiprazole, olanzapine, paliperidone, quetiapine, and risperidone) on CGI–S in schizophrenia and related psychosis. A total of six RCTs with 987 patients were pooled. Patients treated with SGAs had a statistically greater reduction in symptom severity than those receiving placebo (MD = -0.50; 95 percent CI, -0.69 to -0.32). There was evidence of moderate heterogeneity due to differences in the SGAs examined across the studies (p = 0.22, I2 = 28 percent).

The results of six RCTs69,77,80,84,86,93 reporting positive and negative symptoms of schizophrenia using the PANSS were combined in a meta-analysis (Figure 43). The pooled estimate found SGAs to be superior to placebo in reducing positive and negative symptoms (MD= -8.69; 95% CI, -11.76 to -5.61). There was evidence of moderate heterogeneity due to the different SGAs (p = 0.15, I^2^ = 38%).

Figure 43 SGAs versus placebo on PANSS in schizophrenia and related psychosis

CI = confidence interval; df = degrees of freedom; IV = inverse variance; PANSS = Positive and Negative Syndrome Scale; SD = standard deviation; SGA = second-generation antipsychotic

Figure 43 is a metagraph depicting the effect of SGAs on PANSS in schizophrenia and related psychosis. Six studies with 987 patients compared a variety of SGAs (aripiprazole, olanzapine, paliperidone, quetiapine, and risperidone) with placebo. The pooled estimate found SGAs to be superior to placebo in reducing positive and negative symptoms (MD= -8.69; 95 percent CI, -11.76 to -5.61). There was evidence of moderate heterogeneity due to the different SGAs examined across the studies (p = 0.15, I2 = 38 percent).

### Schizophrenia and Related Psychosis: Short- and Long-Term Outcomes (Key Question 3)

Twenty-two studies provided data on a variety of short- and long-term outcomes for patients with schizophrenia and related psychosis. A summary of the results is presented by outcome below. Table 21 provides the strength of evidence grades for all key outcomes that were reported by at least one study.

Table 21 Strength of evidence for schizophrenia and related psychosis (Key Question 3)

Comparison | Outcome (N Studies; N Patients) | Strength of Evidence Domains | | | | Strength of Evidence
Comparison | Outcome (N Studies; N Patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
FGAs vs. SGAs | HRQL (1; 24) | Moderate | Unknown | Direct | Imprecise | Insufficient
FGAs vs. SGAs | Medication adherence (3; 124) | Moderate | Consistent | Direct | Imprecise | Low
Olanzapine vs. quetiapine | Medication adherence (2; 80) | Moderate | Consistent | Direct | Imprecise | Low
Olanzapine vs. risperidone | Medication adherence (5; 237) | Moderate | Consistent | Direct | Imprecise | Low
Olanzapine vs. risperidone | Suicide (1; 78) | Moderate | Unknown | Direct | Imprecise | Insufficient
Low- vs. high-dose aripiprazole | HRQL (1; 302) | Moderate | Unknown | Direct | Imprecise | Insufficient
Low- vs. high-dose aripiprazole | Suicide (1; 302) | Moderate | Unknown | Direct | Imprecise | Insufficient
Low- vs. high-dose paliperidone | Suicide (1; 201) | Moderate | Unknown | Indirect | Imprecise | Insufficient
Low- vs. high-dose quetiapine | Legal system interactions (1; 141) | Moderate | Unknown | Direct | Imprecise | Insufficient
Low- vs. high-dose quetiapine | Medication adherence (1; 141) | Moderate | Unknown | Direct | Imprecise | Insufficient
Low- vs. high-dose quetiapine | Patient-, parent-, or care provider–reported outcomes (1; 222) | Moderate | Unknown | Direct | Imprecise | Insufficient
Low- vs. high-dose quetiapine | Suicide (1; 141) | Moderate | Unknown | Direct | Imprecise | Insufficient
Low- vs. high-dose risperidone | Medication adherence (1; 257) | Moderate | Unknown | Direct | Imprecise | Insufficient
Low- vs. high-dose risperidone | Suicide (2; 361) | Moderate | Consistent | Direct | Not pooled | Insufficient
Low- vs. high-dose ziprasidone | Suicide (1; 17) | Moderate | Unknown | Indirect | Imprecise | Insufficient
SGA vs. placebo | HRQL (1; 302) | Moderate | Unknown | Direct | Imprecise | Insufficient
SGA vs. placebo | Medication adherence (2; 167) | Moderate | Consistent | Direct | Imprecise | Low
SGA vs. placebo | Patient-, parent-, or care provider–reported outcomes: Caregiver strain (1; 222) | Moderate | Unknown | Direct | Precise | Insufficient
SGA vs. placebo | Suicide (5; 990) | Moderate | Consistent | Direct | Not pooled | Low

FGA = first-generation antipsychotic; HRQL = health-related quality of life; N = number; ROB = risk of bias; SGA = second-generation antipsychotic

- Response and remission: Treatment response was reported in 14 studies and defined variably across the studies.69,75,78-81,83,84,87-89,91,92,95 Two RCTs69,78 compared low- and high-dose risperidone. One study78 found a significantly greater response rate in patients receiving high-dose risperidone (p<0.001); however, the second study69 found no difference between the dosing groups. A meta-analysis of two studies found a significant difference favoring SGAs over placebo (RR = 1.64; 95% CI, 1.26 to 2.13). One study77 found a significantly higher remission rate in patients treated with aripiprazole than placebo.
- Cognitive and emotional development: An RCT74 comparing olanzapine and quetiapine reported no significant differences between groups on cognitive functioning, including attention, working memory, learning, memory, and executive functions.
- Suicide-related behaviors: Four studies69,75,77,88 reported suicide rates. One death by suicide occurred in each of two studies.75,88 Three studies78,80,86 examining SGAs reported that no suicide-related behaviors occurred. Suicidal ideation was also rare in four studies42,78,85,88 and did not differ between groups.
- Medication adherence and persistence: Eleven studies74-76,78-80,88,89,92,93,96 reported patient adherence to medication. All studies found no significant difference between groups for adherence rate.
- Legal or justice system interaction: One RCT75 comparing low- and high-dose quetiapine reported incarceration, which occurred in one patient in the high-dose group. The difference between the groups was not significant.
- Patient-, parent-, or care provider–reported outcomes: One RCT84 found a significant improvement on CSQ favoring low-dose quetiapine over placebo. No significant difference was observed between high-dose quetiapine and placebo.
- Health-related quality of life: One small RCT76 comparing haloperidol with olanzapine found no significant differences between groups on the Subjective Wellbeing under Neuroleptics scale. A second RCT comparing two doses of aripiprazole and placebo found no difference between groups on the Pediatric Quality of Life Enjoyment and Satisfaction Questionnaire.77
- Health care system utilization: One RCT75 reported the hospital admission rate and number of days in hospital for patients treated with low- or high-dose quetiapine. The hospital admission rate was significantly higher in the low-dose quetiapine group (p = 0.005). The duration of hospital stay did not differ significantly between groups.
- Other outcomes: No studies provided data for the following outcome categories: growth and maturation, school performance, work-related functional capacity, or patient insight into illness.

A detailed analysis of the results is provided below. Data from head-to-head comparisons are presented, followed by placebo comparisons.

#### FGAs Versus SGAs

Three studies (two RCTs76,89 and one prospective cohort study96) compared FGAs and SGAs. Haloperidol was compared with olanzapine76,89,96 and risperidone.89,96

##### Haloperidol Versus Olanzapine

A 6-week RCT (N = 24) compared the efficacy of haloperidol (2.5 mg/day) and olanzapine (7.5 mg/day) in adolescents and young adults ages 17 to 26 years with schizophrenia.76 No significant differences between groups were found for the Subjective Well-being Under Neuroleptics scale or medication adherence.

##### Haloperidol Versus Olanzapine Versus Risperidone

A 12-week prospective cohort study (N = 50) compared the effectiveness of haloperidol (7.6±4 mg/day), olanzapine (12.7±3.1 mg/day), and risperidone (3.2±1.1 mg/day) in adolescents ages 13 to 20 years.96 Nonadherence did not differ significantly among the three groups.

Patients ages 8 to 19 years with affective disorders (n = 24) and schizophrenia spectrum disorder (n = 26) were randomized to haloperidol (5±2 mg/day), olanzapine (12.3±3.5 mg/day), and risperidone (4±1.2 mg/day) in an 8-week RCT.89 Patients were assessed for treatment response (CGI–I≤2 and a reduction of ≥20 percent on the BPRS–C total score) and nonadherence. No significant differences between the groups were observed.

#### SGAs Versus SGAs

A total of 18 studies evaluated SGAs, of which 11 examined head-to-head comparisons of different SGAs, and 7 compared doses of the same SGA.

##### Clozapine Versus Olanzapine

Three studies compared the effect of clozapine and olanzapine on short- and long-term outcomes. A 12-week RCT (N = 40) with a 12-week extension phase compared the efficacy of clozapine (403.1±201.8 mg/day) and olanzapine (26.2±6.5 mg/day) in children ages 10 to 18 years with schizophrenia or schizoaffective disorder.81 Treatment response was defined as a reduction greater than 30 percent in BPRS score and CGI–I<2 points at endpoint. Significantly more patients responded to treatment in the clozapine group than in the olanzapine group (p = 0.038).

A prospective cohort study compared the efficacy of clozapine (317±147 mg/day) and olanzapine (17.5±2.3 mg/day) in 23 patients ages 6 to 18 years with schizophrenia.95 The duration of followup was 6 weeks in the clozapine group and 8 weeks in the olanzapine group. Rates of response, partial response at 6 weeks, and full or partial response at 8 weeks did not significantly differ between groups.

Shaw et al.87 compared the efficacy of clozapine (327±113 mg/day) and olanzapine (18.1±4.3 mg/day) for the treatment of children ages 7 to 16 years in an 8-week RCT with a 2-year extension phase (N = 25). Treatment response was assessed as either full response (20 percent reduction in BPRS–24 score and CGI–S<3 or BPRS total score<35) or partial response (20 percent reduction in BPRS–24 score) and did not differ significantly between groups.

Two RCTs81,87 provided data for a meta-analysis comparing clozapine and olanzapine for treatment response rate (Figure 44). The pooled estimate of the trials showed no significant difference between the two SGAs (RR = 1.64; 95% CI, 0.55 to 4.93). Heterogeneity was minimal (p = 0.28, I^2^ = 15%).

Figure 44 Clozapine versus olanzapine on response rate in schizophrenia and related psychosis

CI = confidence interval; df = degrees of freedom; M–H = Mantel–Haenszel

Figure 44 is a metagraph depicting the effect of clozapine versus olanzapine on response rate in schizophrenia and related psychosis. Two RCTs with a total of 64 patients were pooled in a meta-analysis. The pooled estimate of the trials showed no statistically significant difference between clozapine and olanzapine (RR = 1.64; 95 percent CI, 0.55 to 4.93). Heterogeneity among the two studies was minimal (p = 0.28, I2 = 15 percent).

##### Olanzapine Versus Quetiapine

Two RCT compared olanzapine and quetiapine. An RCT conducted by Arango et al.74 examined 50 adolescents ages 12 to 18 with psychosis for 6 months. Diagnoses included bipolar disorder (n = 13), schizophrenia (n = 17), and other psychoses. The mean dose of the drugs was 9.7±6.6 mg/day and 532.8±459.6 mg/day for the olanzapine and quetiapine groups, respectively. Adherence and performance on various cognitive domains (attention, working memory, learning and memory, and executive functions) were compared. No significant differences between the olanzapine and quetiapine groups were found for any of the outcomes.

Jensen et al.79 randomized 30 patients ages 10 to 18 with schizophrenia-related disorders to olanzapine (14±4.6 mg/day), quetiapine (611±253.4 mg/day), and risperidone (3.4±1.5 mg/day). The study endpoint was 12 weeks. Response (>40 percent reduction in PANSS scores) and medication adherence did not differ significantly among the groups.

##### Olanzapine Versus Risperidone

Olanzapine was compared with risperidone in six studies.79,83,88,89,92,96 One study described above found no difference in response (>40 percent reduction in PANSS scores) or medication adherence between groups.79

A 12-week RCT (N = 25) compared olanzapine (8.2±4.4 mg/day) and risperidone (1.6±1 mg/day) in children ages 8 to 14 years with schizophrenia.83 Patients were assessed using a symptom reduction of 50 percent on both the PANSS and BPRS; neither outcome was significantly different between groups.

Olanzapine (7.6±4 mg/day), risperidone (12.7±3.1 mg/day), and haloperidol (3.2±1.1 mg/day) were compared in a 12-week prospective cohort study (N = 50) of adolescents ages 14 to 20.^96^ Nonadherence did not differ among groups.

An 8-week RCT (N = 78) with a 44-week extension phase examined the efficacy of olanzapine (11.4±5 mg/day) and risperidone (2.8±1.4 mg/day) in children and adolescents ages 8 to 19 with schizophrenia-related disorders.88 Rate of treatment response (CGI–I<2 and >20 percent reduction in PANSS score after 8 weeks of treatment) and nonadherence did not differ significantly between groups. Other criteria for response based on the CGI–I, Hamilton Rating Scale for Depression, and YMRS similarly showed no difference between groups. In the risperidone group, one patient reported suicidal ideation, and one patient died by suicide.

Sikich et al.89 conducted an RCT to compare the efficacy of olanzapine, risperidone, and haloperidol (described previously). Olanzapine and risperidone were not significant different for response or medication adherence.

An RCT (N = 44) conducted by van Bruggen et al.92 compared the efficacy of olanzapine (15.6±4 mg/day) and risperidone (4.4±1.5 mg/day) in patients ages 16 to 28 with schizophrenia, schizophreniform disorder, or schizoaffective disorder. The mean followup period was 9.8 weeks in the olanzapine group and 6.7 weeks in the risperidone group. Treatment response was defined as a PANSS score of less than mild at endpoint. No significant differences were found between the groups for response, time to response, or medication adherence.

Three RCTs83,88,92 compared olanzapine and risperidone for treatment response rate (Figure 45). The pooled result showed no difference between the SGAs (RR = 0.95; 95% CI, 0.59 to 1.53). Heterogeneity was negligible (p = 0.35, I^2^ = 4%).

Figure 45 Olanzapine versus risperidone on response rate in schizophrenia and related psychosis

CI = confidence interval; df = degrees of freedom; IV = inverse variance; M–H = Mantel–Haenszel

Figure 45 is a metagraph depicting the effect of olanzapine versus risperidone on response rate in schizophrenia and related psychosis. Three RCTs with a total of 143 patients were pooled. The pooled result showed no difference between the SGAs (RR = 0.95; 95 percent CI, 0.59 to 1.53). Heterogeneity among the studies was negligible (p = 0.35, I2 = 4 percent).

##### Quetiapine Versus Risperidone

An RCT (N = 22) evaluated the efficacy of quetiapine (607 mg/day) and risperidone (2.9 mg/day) in adolescents under 19 years old with first onset psychosis.91 Patients were assessed for response using a 30 percent reduction criterion on each of following scales at 3 and 6 weeks: PANSS, BPRS, CGI–S, Hamilton Rating Scale for Depression, and YMRS. No significant difference was found between the groups for treatment response or medication adherence.

##### Aripiprazole–Low- Versus High-Dose

A 6-week RCT (N = 302) compared low- (9.8 mg/day) and high-dose (28.9 mg/day) aripiprazole and placebo in adolescents ages 13 to 17 with schizophrenia.77 The two doses of aripiprazole were not significantly different for remission rate (PANSS<3 for specific items) or quality of life. No patients died by suicide.

##### Paliperidone–Low- Versus Medium- Versus High-Dose

Low-, medium-, and high-dose extended release paliperidone were compared in a placebo-controlled 6-week RCT (N = 201) of adolescents ages 12 to 17 with schizophrenia.86 No patients exhibited suicidal behavior.

##### Quetiapine–Low-Versus High-Dose

Two RCTs compared two doses of quetiapine. Doses of 400 mg/day and 800 mg/day were compared in a 6-week RCT (N = 222) of adolescents ages 13 to 17 with schizophrenia.84 Treatment response (reduction >30 percent from baseline in PANSS total score) did not differ significantly between the groups. There was also no difference between the groups on the CSQ scores.

A 4-week RCT (N = 141) compared 200 mg/day and 400 mg/day doses of quetiapine in patients ages 15 to 25 years experiencing a first episode of psychosis.75 Treatment response (BPRS psychotic subscales<3 and CGI–I<2) and remission (BPRS psychotic subscales<3, CGI–S<3, and CGI–I<2) did not differ between groups. Hospital admission rate was significantly lower in the high-dose group (p = 0.005). Deaths by suicide, imprisonments, days in hospital, and medication adherence did not differ significantly between groups.

##### Risperidone–Low- Versus High-Dose

An 8-week RCT (N = 275) compared the efficacy of low- (0.4 mg/day) and high-dose (4 mg/day) risperidone in adolescents ages 13 to 17 years with schizophrenia.78 Sustained response (time until >20 percent change in PANSS score) was significantly higher in the high-dose risperidone group. No patients had a suicide attempt; however, two patients in the low-dose risperidone group reported suicidal ideation. One patient receiving high-dose risperidone was nonadherent.

A 6-week placebo-controlled RCT (N = 158) compared the efficacy of low- (1–3 mg/day) and high-dose (4–6 mg/day) risperidone in adolescents ages 13 to 17 years.69 The treatment response rate was not significantly different between the dosing groups. No deaths by suicide occurred.

##### Ziprasidone–Low- Versus High-Dose

A 3-week RCT compared the efficacy of low- (80 mg/day) and high-dose (160 mg/day) ziprasidone in treating children and adolescents ages 10 to 17 years with bipolar mania, schizophrenia, and schizoaffective disorder.42 Separate analyses were provided for patients with schizophrenia. One patient in the high-dose group reported suicidal ideation; however, it is unclear whether this patient had bipolar disorder or schizophrenia.

#### SGAs Versus Placebo

Seven placebo-controlled studies evaluated the efficacy of SGAs on short- and long-term outcome in patients with schizophrenia. The studies evaluated aripiprazole,77 olanzapine,80,93 paliperidone,86 quetiapine,84 risperidone,69 and ziprasidone.85

##### Aripiprazole Versus Placebo

Findling et al.77 conducted a RCT to compare the efficacy of low- and high-dose aripiprazole and placebo in adolescents ages 13 to 17 years with schizophrenia (described previously). Remission rate (PANSS<3 for specific items) was significantly higher in both the low- and high-dose aripiprazole groups than placebo (p = 0.02 and p = 0.003, respectively). There was no significant difference between aripiprazole and placebo for time to discontinuation or quality of life.

##### Olanzapine Versus Placebo

A 6-week RCT (N = 107) with a 6-month extension compared olanzapine (11.1 mg/day) with placebo in adolescents ages 13 to 18 years with schizophrenia.80 Treatment response (reduction >30 percent in BPRS from baseline and CGI–S<3) and time to response did not differ significantly between the groups. No suicide-related behaviors occurred in either group. Nonadherence did not differ between the groups.

##### Paliperidone Versus Placebo

Robb et al.86 conducted an RCT to compare the efficacy of low-, medium- and high-dose extended release paliperidone and placebo in adolescents ages 12 to 17 with schizophrenia (described previously). None of the patients exhibited suicide-related behaviors.

##### Quetiapine Versus Placebo

One RCT84 compared the efficacy of low- and high-dose quetiapine and placebo in adolescents ages 13 to 17 with schizophrenia (described previously). Compared with the placebo group, scores on the CSQ showed significantly greater improvement in the low-dose quetiapine group (p = 0.01). The groups did not differ significantly on rate of treatment response.

##### Risperidone Versus Placebo

In a 6-week placebo-controlled RCT (N = 158) of adolescents ages 13 to 17 years (described previously), both low- (1–3 mg/day) and high-dose (4–6 mg/day) risperidone had significantly higher response rates than placebo.69 No deaths by suicide occurred in any of the study groups.

##### Ziprasidone Versus Placebo

A 6-week RCT85 (N = 284) evaluated the efficacy of ziprasidone compared with placebo in adolescents ages 13 to 17 years with schizophrenia. The target dose was 60 to 80 mg/day for patients <45 kg and 120 to 160 mg/day for patients ≥45 kg. Three patients reported suicidal ideation in the ziprasidone group, and no patients reported suicide ideation in the placebo group; however, this difference was not significant.

An 8-week placebo-controlled RCT (N = 60) examined the efficacy of olanzapine (8±3.1 mg/day) in patients ages 12 to 45 (mean age of 17.7 years) with prodromal syndrome.93 Rate of conversion to psychosis and medication adherence were not significantly different between groups.

Three RCTs reported response rate for SGAs versus placebo (Figure 46).69,80,84 The studies examined olanzapine,80 quetiapine,84 and risperidone.69 The pooled result was significant in favor of SGAs (RR = 1.64; 95% CI, 1.26 to 2.13), and there was no evidence of heterogeneity (p = 0.50, I^2^ = 0%).

Figure 46 SGAs versus placebo on response rate in schizophrenia and related psychosis

CI = confidence interval; df = degrees of freedom; M–H = Mantel–Haenszel; SGA = second-generation antipsychotic

Figure 46 is a metagraph depicting the effect of SGAs on response rate in schizophrenia and related psychosis. Three studies with a total of 201 patients compared the following SGAs: olanzapine, quetiapine, and risperidone. The pooled result was statistically significant in favor of SGAs (RR = 1.64; 95 percent CI, 1.26 to 2.13), and there was no evidence of heterogeneity (p = 0.50, I2 = 0 percent).

Two RCTs reported medication adherence rate for olanzapine versus placebo (Figure 47).80,93 No significant difference in the proportion of patients who were nonadherent was found between the groups (RR = 1.20; 95% CI, 0.36 to 4.01), and there was no evidence of heterogeneity (p = 0.84, I^2^ = 0%).

Figure 47 Olanzapine versus placebo on adherence rate in schizophrenia and related psychosis

CI = confidence interval; df = degrees of freedom; M–H = Mantel–Haenszel; SGA = second-generation antipsychotic

Figure 47 is a metagraph depicting the effect of olanzapine on adherence rate in schizophrenia and related psychosis. Two studies provided data from 166 patients. No significant difference in the proportion of patients who were nonadherent was found between the groups (RR = 1.20; 95 percent CI, 0.36 to 4.01), and there was no evidence of heterogeneity (p = 0.84, I2 = 0 percent).

Three RCTs provided data on the rate of suicide-related behavior comparing SGAs and placebo.69,80,86 No events occurred in any of the studies; therefore, meta-analysis was not possible.

### Tourette Syndrome: Overview

Six RCTs97-102 assessed the effectiveness of antipsychotics for treating children with Tourette syndrome. Half of the studies reported both symptom improvement and other short- and long-term outcomes.99-101 Two studies reported only symptom improvement (Key Question 1),97,98 and one study reported only other short- and long-term outcomes (Key Question 3).102

Table 22 provides selected information on the characteristics of the individual studies. The studies are grouped according to the drug class comparisons. Studies that included both head-to-head and placebo comparisons are listed under the head-to-head category. Within each comparison, studies are listed alphabetically by the specific drugs compared. A detailed evidence table is available in Appendix D.

Table 22 Characteristics of studies examining Tourette syndrome

Author, Year, Study Design, Duration, KQ | Intervention (N Enrolled), Dosage (mg/day) Mean±SD | Age, Mean±SD (Range) / Males (%) / White (%) Comorbidities | Diagnosis Breakdown (n) Quality Rating
FGAs vs. SGAs
Gilbert et al, 2004^97^ RCT (crossover^*^), 8 wk KQ1 | G1: Pimozide (7), 2.4 mg/day G2: Risperidone (12), 2.5 mg/day | All groups: NR / Male: NR / White: NR Comorbidities: ADHD (7), CD (1), learning disorder (3), OCD (2), ODD (2) | Chronic tic disorder (3), Tourette syndrome (16) High ROB
FGAs vs. FGAs
Sallee et al, 1997^99^ RCT (crossover), 24 wk KQ1, KQ3 | G1: Haloperidol (22)^*^, 3.5±2.2 mg/day G2: Pimozide (22)^*^, 3.4±1.6 mg/day G3: Placebo (22)^*^ | All groups: NR / Male: NR / White: NR Comorbidities: ADHD (13), OCD (5) | NR Unclear ROB
Sallee et al, 1994^100^ RCT, 6 wk (3 wk extension) KQ1, KQ3 | G1: Haloperidol (17), 1.5±0.6 mg/day G2: Pimozide (24), 3.7±1.4 mg/day | G1: 10.4 yr / Male: NR / White: NR G2: 10.8 yr / Male: NR / White: NR Comorbidities: ADHD (13) | NR High ROB
Sehgal et al, 1999^102^ RCT, 8 mo KQ3 | G1: Pimozide (short-term) (4), 3.8 mg/day G2: Pimozide (long-term) (6), 3.5 mg/day | All groups: NR / Male: NR / White: NR Comorbidities: NR | NR High ROB
SGAs vs. Placebo
Scahill et al, 2003^101^ RCT, 8 wk KQ1, KQ3 | G1: Risperidone (12), 2.5±0.9 mg/day G2: Placebo (14) | All groups: NR / Male: NR / White: NR Comorbidities: ADHD (11), OCD (4) | NR High ROB
Sallee et al, 2000^98^ RCT, 8 wk KQ1 | G1: Ziprasidone (16), 28.2±9.6 mg/day G2: Placebo (12) | G1: 11.3 yr / Male: 87.5% / White: NR G2: 11.8 yr / Male: 66.7% / White: NR Comorbidities: ADHD (15), DBD (5), learning disability (2), OCD (10) | NR High ROB

ADHD = attention deficit hyperactivity disorder; CD = conduct disorder; DBD = disruptive behavior disorder; FGA = first-generation antipsychotic; G = group; mg = milligrams; KQ = key question; mo = month; N = number; NR = not reported; OCD = obsessive-compulsive disorder; ODD = oppositional defiant disorder; RCT = randomized controlled trial; ROB = risk of bias; SD = standard deviation; SGA = second-generation antipsychotic; wk = week

* All patients experienced each of the treatment arms in this crossover study; 11 patients had haloperidol before pimozide, whereas another 11 patients had pimozide before haloperidol

Patients enrolled in the study had an average age of 10.6 years and were predominantly male (86 percent). The distribution of patient race was not reported in any of the trials. The diagnosis of Tourette syndrome was based on the DSM–III–TR, DSM–IV, and DSM–IV–TR criteria. Patients had a variety of comorbidities, including ADHD (40 percent), obsessive-compulsive disorder (14 percent), disruptive behavior disorders (5 percent), and learning disorders (3 percent).

One trial compared a FGA (pimozide) with a SGA (risperidone).97 Two studies99,100 provided data on the comparative effectiveness of two FGAs, haloperidol and pimozide, one of which included a placebo comparator.99 A placebo withdrawal study compared short-term and long-term outcomes of treatment of pimozide.102 Two trials compared SGAs risperidone101 and ziprasidone98 with placebo.

Two of the RCTs had a crossover design.97,99 The duration of treatment ranged from 6 weeks to 8 months. All trials had a high risk of bias, with the exception of one study that had an unclear risk of bias.99 Sources of possible bias included industry sponsorship, selective outcome reporting, and incomplete outcome data.

### Tourette Syndrome: Disorder-Specific and Nonspecific Symptoms (Key Question 1)

Five RCTs reported the effects of FGAs and SGAs on treating disorder-specific and nonspecific symptoms of children with Tourette syndrome. A summary of the results by comparison is presented below. Strength of evidence grades for all key outcomes that were reported by at least one study are provided in Table 23.

Table 23 Strength of evidence for Tourette syndrome (Key Question 1)

Comparison | Outcome (N Studies; N Patients) | Strength of Evidence Domains | | | | Strength of Evidence
Comparison | Outcome (N Studies; N Patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
Pimozide vs. risperidone | Clinical global impressions (1; 19) | Moderate | Unknown | Direct | Imprecise | Insufficient
Pimozide vs. risperidone | Tics (1; 19) | Moderate | Unknown | Direct | Imprecise | Insufficient
Haloperidol vs. pimozide | Clinical global impressions (1; 22) | Moderate | Unknown | Direct | Imprecise | Insufficient
Haloperidol vs. pimozide | Social/occupational functioning (1; 41) | Moderate | Unknown | Direct | Imprecise | Insufficient
FGAs vs. placebo | Clinical global impressions (1; 22) | Moderate | Unknown | Direct | Precise | Insufficient
SGA vs. placebo | Clinical global impressions (2; 54) | Moderate | Inconsistent | Direct | Not pooled | Insufficient
SGA vs. placebo | Obsessive compulsive (1; 27) | Moderate | Unknown | Direct | Precise | Insufficient
SGA vs. placebo | Tics (2; 54) | Moderate | Consistent | Direct | Precise | Moderate

FGA = first-generation antipsychotic; N = number; ROB = risk of bias; SGA = second-generation antipsychotic

- Pimozide versus risperidone (one RCT97): Risperidone was shown to be significantly more effective in reducing tic severity than pimozide.
- Haloperidol versus pimozide (two RCTs99,100): One study100 found greater improvement favoring pimozide for the Child Behavior Checklist working hard subscale. A second study found no difference between groups on the CGI or Tic Symptom Self-Report.99
- FGAs (haloperidol and pimozide) versus placebo (one RCT99): Patients treated with FGAs showed significantly greater improvement in symptom severity and in global assessment compared with placebo.
- SGAs versus placebo (two RCTs examining risperidone101 and ziprasidone98): Treatment with SGAs resulted in greater improvement in tic symptoms than placebo.98,101 Significant differences were also found in favor of SGAs for global impression of improvement101 and obsessive-compulsive symptoms.98 There was no difference between groups for global impressions of severity.

A detailed analysis of the data on symptom improvement is provided by study below. This section is organized by comparison, with head-to-head data preceding placebo comparisons.

#### FGAs Versus SGAs

##### Pimozide Versus Risperidone

A crossover RCT (N = 19) compared the effectiveness of pimozide (2.4 mg/day) and risperidone (2.5 mg/day) in children ages 7 to 17 years with Tourette syndrome.97 The study duration was 8 weeks, and patients received each drug for 4 weeks. Risperidone was significantly more effective than pimozide at reducing tic severity on the Yale Global Tic Severity Score (YGTSS) (p = 0.05). No significant differences between the groups were observed for the CGI or Tic Symptom Self-Report.

#### FGAs Versus FGAs

##### Haloperidol Versus Pimozide

Two RCTs compared the effect of haloperidol and pimozide on symptoms in children ages 7 to 16 with Tourette syndrome. Sallee et al.99 conducted a placebo-controlled crossover RCT (N = 22) to compare the effectiveness of haloperidol (3.5±2.2 mg/day) and pimozide (3.4±1.6 mg/day). Patients initially underwent 2 weeks of placebo treatment and subsequently received 6 weeks of each active treatment in the sequence to which they were assigned. No significant differences were found between groups on the CGAS or CGI–S.

A second RCT (N = 41) by Sallee et al.100 randomized patients to haloperidol (1.5±0.6 mg/day) or pimozide (3.7±1.4 mg/day) for 8 weeks. Patients were assessed using the school performance, working hard, learning, and function subscales of the Child Behavior Checklist. The pimozide group showed significantly greater improvement on the working hard subscale compared with the haloperidol group (p<0.05). No significant differences were found between the groups for any of the other subscales.

#### FGAs Versus Placebo

A crossover RCT compared the efficacy of both haloperidol and pimozide with placebo (described previously).99 Symptoms significantly improved from baseline to endpoint in both the haloperidol and pimozide groups compared with the placebo group (CGAS, p<0.05; CGI–S, p = 0.01).

#### SGAs Versus Placebo

Two placebo-controlled RCTs evaluated SGAs.98,101

##### Risperidone Versus Placebo

An 8-week RCT compared risperidone (2.5±0.9 mg/day) with placebo in children and adults ages 7 to 65 years with Tourette syndrome.101 Data were provided separately for a subgroup of 26 pediatric patients (mean age of 11.1±2.2 years). The study found a significant improvement in symptoms in the risperidone group compared with placebo for the CGI–I (p = 0.003) and YGTSS (p = 0.002).

##### Ziprasidone Versus Placebo

An 8-week RCT (N = 28) evaluated the efficacy of ziprasidone (28.2±9.6 mg/day) compared with placebo in children ages 7 to 17 years with Tourette syndrome or chronic tic disorder.98 Tic symptoms and obsessive-compulsive symptoms improved significantly in the ziprasidone group compared with placebo (YGTSS total tic score, p = 0.008; YGTSS global severity score, p = 0.016; CYBOCS, p = 0.0003). There was no significant difference between groups on the CGI–Tourette Syndrome score.

The results of the two RCTs98,101 comparing SGAs with placebo were pooled for the YGTSS (Figure 48). The combined estimate of change from baseline in tic score shows a significant difference favoring SGAs (MD = -6.98; 95% CI, -10.34 to -3.62). There was no evidence of heterogeneity (p = 0.95, I^2^ = 0%).

Figure 48 SGAs versus placebo on YGTSS in Tourette syndrome

CI = confidence interval; df = degrees of freedom; IV = inverse variance; SD = standard deviation; SGA = second-generation antipsychotic; YGTSS = Yale Global Tic Severity Scale

Figure 48 is a metagraph depicting the effect of SGAs (risperidone and ziprasidone) on YGTSS in Tourette syndrome. Two studies with a total of 53 patients were pooled. The combined estimate of change from baseline in tic score shows a significant difference between the groups favoring SGAs (MD = -6.98; 95 percent CI, -10.34 to -3.62). There was no evidence of heterogeneity (p = 0.95, I2 = 0 percent).

### Tourette Syndrome: Short- and Long-Term Outcomes (Key Question 3)

Four RCTs assessed the efficacy of antipsychotics for treating a variety of short- and long-term outcomes in patients with Tourette syndrome. Below is a summary of the results by outcome. Table 24 summarizes the strength of evidence for all key outcomes that were reported by at least one study. Evidence was insufficient to draw conclusions for any comparisons or outcomes.

Table 24 Strength of evidence for Tourette syndrome (Key Question 3)

Comparison | Outcome (N Studies; N Patients) | Strength of Evidence Domains | | | | Strength of Evidence
Comparison | Outcome (N Studies; N Patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
Haloperidol vs. pimozide | Medication adherence (1; 22) | Moderate | Unknown | Direct | Imprecise | Insufficient
Short- vs. long-term pimozide | Patient-, parent-, or care provider–reported outcomes (1; 10) | Moderate | Unknown | Direct | Imprecise | Insufficient
FGA vs. placebo | Medication adherence (1; 22) | Moderate | Unknown | Direct | Imprecise | Insufficient

FGA = first-generation antipsychotic; N = number; ROB = risk of bias

- Response and remission: Treatment response rate was reported in two RCTs. One99 found no significant difference in response rate between haloperidol and pimozide; the second101 found a significantly higher response rate in patients treated with risperidone than placebo. One RCT102 comparing short- and long-term treatment with pimozide found that patients receiving long-term treatment had a longer time until dose increases were required to treat tic exacerbation.
- Cognitive and emotional development: One RCT comparing haloperidol with pimozide found significantly fewer commission and omission errors on a continuous performance task in the pimozide group.100 Reaction time did not significantly differ between groups.
- Medication adherence: Adherence was assessed in one RCT99 comparing haloperidol, pimozide, and placebo. Treatment adherence was high in all groups, with no significant difference.
- Other outcomes: No studies provided data for the following outcome categories: growth and maturation, suicide-related behaviors, school performance, work-related functional capacity, patient insight into illness, patient-, parent-, or care provider–reported outcomes, health-related quality of life, legal system interactions, or health care system utilization.

A detailed analysis by comparisons is presented below.

#### FGAs Versus FGAs

Three studies provided data on the comparison of FGAs for short- and long-term outcomes.

##### Haloperidol Versus Pimozide

A 24-month, placebo-controlled crossover RCT (N = 22) compared haloperidol (3.5±2.2 mg/day) and pimozide (3.4±1.6 mg/day) in children ages 7 to 16.^99^ The rate of treatment response (≥50 percent reduction in Tourette Syndrome Global Scale scores) was not significantly different between the groups. All patients adhered to treatment.

A 6-week RCT (N = 41) evaluated the relative effects of haloperidol (1.5±0.6 mg/day) versus pimozide (3.7±1.4 mg/day) on cognition in children ages 7 to 16.^100^ Mean omission and commission errors on continuous performance task were significantly lower in patients treated with pimozide than those treated with haloperidol (p<0.05 for both). Mean reaction times at the highest memory load on a memory search task did not differ between groups.

##### Short- Versus Long-Term Pimozide

A placebo-withdrawal study (N = 10) compared the efficacy of short- and long-term treatment with pimozide in patients ages 7 to 13.^102^ Patients were randomly assigned to remain on pimozide or gradual placebo withdrawal for 8 months or until a dose increase was required. The mean doses were 3.8 mg/day and 3.5 mg/day for the short- and long-term pimozide groups, respectively. Time to dose increase due to tic exacerbation was significantly longer in patients treated with long-term, continuous pimozide than short-term pimozide (p = 0.02).

#### FGAs Versus Placebo

One RCT compared haloperidol, pimozide, and placebo for response rate and adherence (described previously).99 Response rate was significantly higher in both the haloperidol and pimozide groups than placebo (p = 0.003 and p = 0.002, respectively). Patients in all groups adhered to treatment protocol.

#### SGAs Versus Placebo

An 8-week, placebo-controlled RCT evaluated the efficacy of risperidone (2.5±0.9 mg/day) in patients ages 7 to 65 years.101 Data were provided separately for 26 pediatric patients. The treatment response rate (defined as CGI–I≤2) was significantly higher with risperidone than with placebo (p<0.003).

### Behavioral Issues: Overview

Four studies (two RCTs103,104 and two retrospective cohort studies105,106) examined the effect of antipsychotics for treating behavioral disturbances in children and adolescents. All studies reported symptoms, and two studies103,106 also reported other short- or long-term outcomes.

Table 25 provides selected information on the characteristics of the individual studies. The studies are grouped according to the drug class comparisons: SGAs versus SGAs and SGAs versus placebo. Within each comparison, studies are listed alphabetically by the specific drugs compared. Studies that include both head-to-head and placebo comparisons are listed under the head-to-head category. A detailed evidence table is available in Appendix D.

Table 25 Characteristics of studies examining behavioral issues

Author, Year, Study Design, Duration, KQ | Intervention (N Enrolled), Dosage (mg/day) Mean±SD | Age, Mean±SD (range) / Males (%) / White (%) Comorbidities | Diagnosis Breakdown (n) Quality Rating
SGAs vs. SGAs
Bastiaens et al, 2009^103^ Retrospective cohort, 2 mo KQ1, KQ3 | G1: Aripiprazole (24), 4.5±2.3 mg/day G2: Ziprasidone (22), 42.9±18 mg/day | G1: 11.7±2.4 yr / Male: 83% / White: NR G2: 12.1±2.9 yr / Male: 91% / White: NR Comorbidities: NR | Bipolar (12), CD (14), depressive disorder (6), mood disorder NOS (8), PDD (2), psychotic disorder (4) 4/8 stars
Khan et al, 2006^106^ Retrospective cohort, 1 mo KQ1, KQ3 | G1: Olanzapine (50), 8.2±2.4 mg/day G2: Ziprasidone (50), 19.1±2.6 mg/day | G1: 13.7±2.4 yr / Male: 68% / White: 60% G2: 14.6±2.1 yr / Male: 32% / White: 68% Comorbidities: PTSD (18), SA (27) | Psychosis (34) 6/8 stars
Hellings et al, 2006^105^ RCT (crossover), 22 wk (24 wk extension) KQ1 | G1: Risperidone (low) (26),^*^ 1 mg/day G2: Risperidone (high) (26),^*^ 2 mg/day G3: Placebo (26)^*^ | All groups: NR / Male: NR / White: NR Comorbidities: ASD (NR), MR (all) [mild (8), moderate (6), severe (8), profound (4)] | NR High ROB
SGAs vs. Placebo
van Bellinghen et al, 2001^104^ RCT, 4 wk KQ1 | G1: Risperidone (6), 1.2 mg/day G2: Placebo (7) | G1: NR / Male: 33% / White: NR G2: NR / Male: 43% / White: NR Comorbidities: MR (all) | NR High ROB

ASD = autism spectrum disorder; CD = conduct disorder; G = group; KQ = key question; mg = milligrams; mo = month; MR = mental retardation; N = number; NOS = not otherwise specified; NR = not reported; PDD = pervasive developmental disorder; PTSD = post-traumatic stress disorder; RCT = randomized controlled trial; ROB = risk of bias; SA = substance abuse; SD = standard deviation; SGA = second-generation antipsychotic; wk = week

* All patients experienced each of the treatment arms in this crossover study

Based on three studies that reported age, the average patient age was 13.3 years. Overall, 58 percent of patients were male. In the one study that reported race, 64 percent of patients were white. To be enrolled in the studies, patients were required to exhibit behavioral disturbances including aggression,103,105,106 agitation,106 self-injury,105 or property destruction105 (one study did not specify the types of behavioral symptoms included104). Diagnoses were based on the DSM–IV in two studies103,105 and not reported in the remaining two. All patients in two studies had mental retardation.104,105 Other comorbidities included post-traumatic stress disorder and substance abuse.

Two studies provided head-to-head comparisons of different SGAs: aripiprazole versus ziprasidone103 and olanzapine versus ziprasidone.106 Risperidone was compared with placebo in two studies,104,105 one of which also compared two doses of risperidone.105

The durations of study followup ranged from 4 to 22 weeks. The RCTs had a high risk of bias due to incomplete outcome data and industry funding. The quality of the retrospective cohort studies was moderate to high.

### Behavioral Issues: Disorder-Specific and Nonspecific Symptoms (Key Question 1)

Four studies provided data on symptom improvement in patients with behavioral issues. Below is a summary of the results by comparison. For key outcomes that were reported by at least one study, strength of evidence grades are provided in Table 26.

Table 26 Strength of evidence for behavioral issues (Key Question 1)

Comparison | Outcome (N Studies; N Patients) | Strength of Evidence Domains | | | | Strength of Evidence
Comparison | Outcome (N Studies; N Patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
Aripiprazole vs. ziprasidone | Aggression (1; 46) | Moderate | Unknown | Direct | Imprecise | Insufficient
Aripiprazole vs. ziprasidone | Clinical global impressions (1; 46) | Moderate | Unknown | Direct | Imprecise | Insufficient
Aripiprazole vs. ziprasidone | Manic symptoms (1; 46) | Moderate | Unknown | Direct | Imprecise | Insufficient
Olanzapine vs. ziprasidone | Aggression (1; 100) | Low | Unknown | Direct | Imprecise | Insufficient
Risperidone–low- vs. high-dose | Autistic symptoms (1; 26) | Moderate | Unknown | Direct | Imprecise | Insufficient
Risperidone vs. placebo | Autistic symptoms (2; 39) | Moderate | Consistent | Direct | Not pooled | Low
Risperidone vs. placebo | Clinical global impressions (1; 13) | Moderate | Unknown | Direct | Imprecise | Insufficient

N = number; ROB = risk of bias

- Aripiprazole versus ziprasidone (one RCT103): Global impressions of functioning and improvement, aggression, and manic symptoms did not differ significantly between groups.
- Olanzapine versus ziprasidone (one retrospective cohort study106): The number of aggressive episodes did not significantly differ between groups.
- Risperidone–dosing (one crossover RCT105): There was no difference in aberrant behavior scores between the two dosing groups.
- Risperidone versus placebo (two RCTs104,105): One RCT showed a significant difference favoring risperidone for improving symptoms on the ABC, CGI, VAS, and the social relationship and occupational attitude subscales of the Personal Assessment Checklist (p<0.05).104

The findings of individual comparisons and studies are provided below.

#### SGAs Versus SGAs

Two studies provided data on the comparative effectiveness of two SGAs in the treatment of behavioral issues.

##### Aripiprazole Versus Ziprasidone

A 2-month retrospective cohort study (N = 46) evaluated the effectiveness of aripiprazole (4.5±2.3 mg/day) and ziprasidone (42.9±18 mg/day) in treating children ages 6 to 17 years with aggressive behavior.103 There was no significant difference between the drugs for the CGI–I, Global Assessment of Functioning, OAS, or YMRS–P.

##### Olanzapine Versus Ziprasidone

A retrospective cohort study (N = 100) compared the effectiveness of olanzapine and ziprasidone for treating agitation and aggression in children and youth under 18 years of age.106 Length of stay in hospital averaged 26 days in the olanzapine group and 34 days in the ziprasidone group. During this time, patients received an average of 3±4 and 5±8 intramuscular injections of olanzapine and ziprasidone, respectively. The mean study dose was 8.2±2.4 mg for olanzapine and 19.1±2.6 mg for ziprasidone. No significant difference was found in the number of aggressive episodes between the two groups.

##### Risperidone–Low- Versus High-Dose

A crossover RCT investigated the efficacy of low- (1 mg) versus high-dose (2 mg) risperidone for treating aggression, self-injury, and destructive behaviors in children and adults ages 8 to 56 years with mental retardation.105 Data were available for 26 pediatric patients. Patients received each dose for 4 weeks. Dosage was tapered between risperidone doses for a 2-week period. All patients were given placebo for 3 to 5 weeks after receiving the two doses of risperidone. Low- and high-dose groups did not significantly differ on endpoint scores of the ABC subscales.

#### SGAs Versus Placebo

A crossover RCT compared two doses of risperidone with placebo (described above).105 All ABC subscales were lower in the risperidone groups than placebo (p-values were not reported and could not be calculated).

A 4-week RCT (N = 13) compared risperidone (1.2 mg/day) with placebo in treating behavioral disturbances in patients ages 6 to 18 years with mental retardation.104 Risperidone was significantly favored for improvement on ABC (p<0.001), CGI (p<0.05), VAS (p<0.001), and the social relationship and occupational attitude subscales of the Personal Assessment Checklist (p<0.05).

### Behavioral Issues: Short- and Long-Term Outcomes (Key Question 3)

Two retrospective cohort studies examined the relative effectiveness of different SGAs for treating patients with behavioral disturbances on various short- and long-term outcomes. A study103 comparing aripiprazole with ziprasidone found no difference between the treatment groups for quality of life at 2 months. Similarly, no difference was found between olanzapine and ziprasidone for length of hospital stay, number of physical restraints needed, and duration of restraints when antipsychotics were used to treat patients with acute aggression.106 Strength of evidence was evaluated for health-related quality of life (Table 27).

Table 27 Strength of evidence for behavioral issues (Key Question 3)

Comparison | Outcome (N Studies; N Patients) | Strength of Evidence Domains | | | | Strength of Evidence
Comparison | Outcome (N Studies; N Patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
Aripiprazole vs. ziprasidone | HRQL (1; 46) | Moderate | Unknown | Direct | Imprecise | Insufficient

HRQL = health-related quality of life; N = number; ROB = risk of bias

#### SGAs Versus SGAs

##### Aripiprazole Versus Ziprasidone

The efficacy of aripiprazole (4.5±2.3 mg/day) and ziprasidone (42.9±18 mg/day) was compared in 46 children ages 6 to 17 with aggressive behavior.103 Quality of life improved in both groups; however, there was no significant difference.

##### Olanzapine Versus Ziprasidone

A retrospective cohort study (N = 100) compared the effectiveness of olanzapine and ziprasidone for treating aggression in patients younger than 18 years of age. Patients received an average of 3±4 and 5±8 injections of olanzapine and risperidone, respectively. The mean study dose was 8.2±2.4 mg for olanzapine and 19.1±2.6 mg for ziprasidone. No significant differences between the groups were noted for length of hospital stay, number of physical restraints, and duration of restraints after use of medication.

## Key Question 2 Adverse Events

This section reviews the evidence on comparative harms of FGAs and SGAs. The results are organized by drug class comparison, with head-to-head comparisons (FGAs vs. SGAs, FGAs vs. FGAs, SGAs vs. SGAs) preceding placebo comparisons. Data are not presented separately for each of the conditions of interest because adverse events associated with an antipsychotic are likely to be consistent regardless of the indication for which a drug is being taken.

For each comparison, we report data on 19 adverse event categories: mortality, cerebrovascular events, weight gain and body composition, dyslipidemia, insulin resistance and diabetes, prolactin-related and sexual events, neuromotor events including tardive dyskinesia, cardiac events, sedation, liver toxicity, neutropenia and agranulocytosis, thyroid dysfunction, seizures, neuroleptic malignant syndrome, constipation, exercise intolerance, precocious puberty, behavioral effects (e.g., aggression, agitation), and dermatological effects. Data on cardiomyopathies was not available in any of the included studies.

### FGAs Versus SGAs

Twelve studies compared the adverse event profile of FGAs and SGAs. Comparisons included various FGAs versus various SGAs,107 various FGAs versus clozapine,108 haloperidol versus clozapine,82,109 haloperidol versus olanzapine,45,76,89,96,109,110 haloperidol versus risperidone,48,89,96 and pimozide versus risperidone.97,111 The findings for each adverse event are provided below. No data were available for the following adverse events: mortality, cerebrovascular events, thyroid dysfunction, exercise intolerance, and precocious puberty. The effect estimates and 95 percent confidence intervals of results that showed a significant difference between FGAs and SGAs are presented in Table 28.

Table 28 Significant findings for adverse events: FGAs versus SGAs

Adverse Event | # Studies | N (Drug 1) | N (Drug 2) | Effect Estimate | 95% CI | Favors^*^
FGA (Drug 1) Versus Clozapine (Drug 2)
Prolactin | 1 | 20 | 20 | MD = 15.5 | (8.0, 23.0) | FGA
Haloperidol (Drug 1) Versus Clozapine (Drug 2)
Drowsiness | 1 | 11 | 10 | RR = 0.30 | (0.1, 0.8) | Haloperidol
Prolactin (ng/mL) | 1 | 10 | 15 | MD = 36.6 | (17.5, 55.7) | Clozapine
Haloperidol (Drug 1) Versus Olanzapine (Drug 2)
Weight (kg) | 4 | 39 | 53 | MD = -5.79 | (-8.6, -3.0) | Haloperidol
Weight–gain ≥7% | 1 | 8 | 21 | RR = 0.14 | (0.02, 0.9) | Haloperidol
Glucose (mg/dL) | 1 | 15 | 16 | MD = -9.7 | (-19.3, -0.1) | Haloperidol
Dystonia | 2 | 22 | 35 | RR = 8.19 | (1.0, 65.5) | Olanzapine
EPS | 2 | 13 | 25 | RR = 3.53 | (1.1, 10.9) | Olanzapine
EPS (SAS) | 1 | 15 | 16 | MD = 3.3 | (0.3, 6.31) | Olanzapine
AST (U/L) | 1 | 15 | 16 | MD = -11.7 | (-22.7, -0.7) | Olanzapine
Depression | 1 | 7 | 19 | RR = 2.71 | (1.1, 6.6) | Olanzapine
Haloperidol (Drug 1) Versus Risperidone (Drug 2)
Akathisia | 2 | 22 | 36 | RR = 6.93 | (1.3, 38.1) | Risperidone
Fatigue | 1 | 7 | 17 | RR = 6.07 | (1.5, 24.2) | Risperidone
EPS (ESRS) | 1 | 15 | 15 | MD = 1.12 | (0.21, 2.03) | Risperidone
EPS (SAS) | 1 | 15 | 19 | MD = 3.1 | (0.003, 6.2) | Risperidone
AST (U/L) | 1 | 15 | 19 | MD = -7.4 | (-13.8, -1.01) | Risperidone
Depression | 1 | 7 | 17 | RR = 6.07 | (1.5, 24.2) | Risperidone

AST = aspartate aminotransferase; CI = confidence interval; dL = deciliter; EPS = extrapyramidal symptom; ESRS = extrapyramidal symptom rating scale; FGA = first-generation antipsychotic; kg = kilogram; MD = mean difference; mg = milligram; mL = milliliter; N = number; ng = nanogram; RR = relative risk; SAS = Simpson Angus Scale; SGA = second-generation antipsychotic; U/L = international units per liter

* Denotes the drug with the better adverse event profile.

#### Total Adverse Events

One study reported that no severe adverse events occurred for either haloperidol or risperidone.48

#### Weight Gain/Body Composition

In a study comparing haloperidol and olanzapine, weight gain greater than seven percent occurred significantly more frequently in the olanzapine group.45 A meta-analysis of four studies45,89,96,110 comparing haloperidol with olanzapine found significantly less weight gain in patients receiving haloperidol (MD = -5.79 kg; 95% CI, -8.61 to -2.98 kg) (Figure 49). No significant difference between the other FGAs and SGAs was found.

Figure 49 FGAs versus SGAs for mean weight gain (kg)

CI = confidence interval; df = degrees of freedom; IV = inverse variance; kg = kilogram; FGA = first-generation antipsychotic; SD = standard deviation; SGA = second-generation antipsychotic

Figure 49 is a metagraph depicting the effect of FGAs and SGAs on mean weight gain. A meta-analysis of four studies comparing haloperidol with olanzapine found significantly less weight gain in patients receiving haloperidol (MD = -5.79 kg; 95 percent CI, -8.61 to -2.98 kg). No significant difference between haloperidol and risperidone (three studies with 91 patients) or between pimozide and risperidone (two studies with 19 patients) were found.

#### Dyslipidemia

One study found no significant differences between haloperidol and olanzapine or risperidone in low-density lipoprotein, high-density lipoprotein, or triglyceride levels.89

#### Insulin Resistance and Diabetes

One study found significantly higher glucose levels for olanzapine than for haloperidol.89

#### Prolactin-Related and Sexual Adverse Events

Prolactin levels were significantly higher in patients receiving various FGAs than those receiving clozapine in one study.108 A second study109 found prolactin levels to be higher for haloperidol than clozapine.

#### Neuromotor Adverse Events

None of the studies reported rates of tardive dyskinesia. Significantly more patients experienced dystonia89,96 and any extrapyramidal side effects45,96 in the haloperidol group than olanzapine. Similarly, one study89 found extrapyramidal symptoms as measured by the Simpson Angus Scale to be significantly more severe for patients treated with haloperidol than for those treated with olanzapine. Akathisia occurred significantly more frequently among patients treated with haloperidol than those treated with risperidone in a meta-analysis of two studies.89,96 Similarly, extrapyramidal symptoms as measured by the Extrapyramidal Symptom Rating Scale and the Simpson Angus Scale were significantly more severe in patients treated with haloperidol than for those treated with risperidone in two studies.48,89

#### Cardiac Adverse Events

No significant differences were found between haloperidol and olanzapine45,96 or risperidone96 for tachycardia, and between haloperidol and risperidone for pulse.48 Similarly, QTc intervals did not significantly differ between haloperidol and olanzapine or risperidone89 and between pimozide and risperidone.97

#### Sedation

A significantly greater proportion of patients receiving clozapine reported drowsiness than those receiving haloperidol in one study.82 A single study found the rate of fatigue was significantly greater in patients receiving haloperidol than those receiving risperidone.96

#### Liver Toxicity

Aspartate amino transferase levels were significantly higher for patients treated with olanzapine and risperidone than those receiving haloperidol in one study.89

#### Neutropenia and Agranulocytosis

One study found no significant differences between haloperidol and clozapine in neutrophil counts and incidence of agranulocytosis.82

#### Seizures

No seizures occurred in a study comparing haloperidol with olanzapine and risperidone.96 In a study comparing haloperidol and clozapine, one seizure occurred in a patient treated with clozapine; the difference between groups was not significant.82

#### Neuroleptic Malignant Syndrome

One study found no significant difference in the incidence of neuroleptic malignant syndrome between haloperidol (one event) and clozapine (no events).82

#### Constipation

Two meta-analyses comparing haloperidol with olanzapine89,96 and haloperidol with risperidone48,89,96 found no significant differences between groups in constipation.

#### Behavioral Side Effects

The rate of depression as measured on the Udvalg for Kliniske Undersogelser Side Effect Rating Scale was found to be significantly higher in patients receiving haloperidol than in those receiving olanzapine or risperidone in one study.96

#### Dermatological Adverse Events

The incidence of itching was not significantly different between haloperidol and olanzapine or risperidone.89,96 The incidence of rash did not differ between haloperidol and olanzapine45,89 or haloperidol and risperidone.89

Strength of evidence grades for key adverse events that were reported by at least one study are provided in Table 29. For all key adverse events, the strength of evidence for FGAs versus SGAs was low or insufficient.

Table 29 Strength of evidence for adverse events: FGAs versus SGAs (Key Question 2)

Comparison | Outcome (N Studies; N Patients) | Strength of Evidence Domains | | | | Strength of Evidence
Comparison | Outcome (N Studies; N Patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
FGAs vs. SGAs | Weight (1; 109) | Moderate | Unknown | Direct | Imprecise | Insufficient
FGAs vs. clozapine | Prolactin-related / sexual AE (1; 40) | High | Unknown | Direct | Precise | Insufficient
Haloperidol vs. clozapine | EPS (1; 21) | Moderate | Unknown | Direct | Imprecise | Insufficient
Haloperidol vs. clozapine | Prolactin-related / sexual AE (1; 47) | Moderate | Unknown | Direct | Precise | Insufficient
Haloperidol vs. clozapine | Sedation (1; 21) | Moderate | Unknown | Indirect | Precise | Insufficient
Haloperidol vs. clozapine | Weight (1; 21) | Moderate | Unknown | Direct | Imprecise | Insufficient
Haloperidol vs. olanzapine | Dyslipidemia (1; 50) | Moderate | Unknown | Direct | Imprecise | Insufficient
Haloperidol vs. olanzapine | EPS (3; 62) | High | Inconsistent | Direct | Precise | Low
Haloperidol vs. olanzapine | Insulin resistance (1; 50) | Moderate | Unknown | Direct | Precise | Insufficient
Haloperidol vs. olanzapine | Prolactin-related / sexual AE (2; 97) | Moderate | Inconsistent | Direct | Imprecise | Low
Haloperidol vs. olanzapine | Sedation (3; 112) | High | Consistent | Direct | Imprecise | Low
Haloperidol vs. olanzapine | Weight (4; 132) | High | Inconsistent | Direct | Precise | Low
Haloperidol vs. risperidone | Dyslipidemia (1; 50) | Moderate | Unknown | Direct | Imprecise | Insufficient
Haloperidol vs. risperidone | EPS (3; 130) | High | Consistent | Direct | Imprecise | Low
Haloperidol vs. risperidone | Insulin resistance (1; 50) | Moderate | Unknown | Direct | Imprecise | Insufficient
Haloperidol vs. risperidone | Prolactin-related / sexual AE (2; 80) | Moderate | Consistent | Direct | Imprecise | Low
Haloperidol vs. risperidone | Sedation (2; 100) | High | Inconsistent | Direct | Imprecise | Low
Haloperidol vs. risperidone | Weight (3; 130) | High | Consistent | Direct | Imprecise | Low
Pimozide vs. risperidone | EPS (1; 19) | Moderate | Unknown | Direct | Imprecise | Insufficient
Pimozide vs. risperidone | Weight (1; 19) | Moderate | Unknown | Direct | Imprecise | Insufficient
Haloperidol vs. pimozide | EPS (1; 22) | Moderate | Unknown | Direct | Imprecise | Insufficient
Haloperidol vs. pimozide | Prolactin-related / sexual AE (1; 22) | Moderate | Unknown | Direct | Precise | Insufficient
Haloperidol vs. pimozide | Weight (1; 22) | Moderate | Unknown | Direct | Imprecise | Insufficient

AE = adverse event; EPS = extrapyramidal symptom; FGA = first-generation antipsychotic; N = number; ROB = risk of bias; SGA = second-generation antipsychotic

### FGAs Versus FGAs

Three studies reported on the relative rates of adverse events between different FGAs. Comparisons included haloperidol versus haloperidol,51 haloperidol versus pimozide,99 and pimozide versus pimozide.102 The findings for each adverse event are provided below. The following adverse event categories were not reported: mortality, cerebrovascular events, dyslipidemia, insulin resistance and diabetes, liver toxicity, neutropenia and agranulocytosis, thyroid dysfunction, seizures, neuroleptic malignant syndrome, constipation, exercise intolerance, precocious puberty, and dermatological adverse events. Effect estimates and 95 percent confidence intervals for the significant findings are presented in Table 30.

Table 30 Significant findings for adverse events: FGAs versus FGAs

Adverse Event | # Studies | N (Drug 1) | N (Drug 2) | Effect Estimate | 95% CI | Favors^*^
Haloperidol (Continuous) (Drug 1) Versus Haloperidol (discontinuous) (Drug 2)
Dyskinesias | 1 | 30 | 22 | RR = 0.24 | (0.07, 0.8) | Continuous Haloperidol
Haloperidol (Drug 1) Versus Pimozide (Drug 2)
Prolactin | 1 | 19 | 25 | MD = -8.7 | (-17.2, -0.2) | Haloperidol

CI = confidence interval; FGA = first-generation antipsychotic; MD = mean difference; N = number; RR = relative risk

* Denotes the drug with the better adverse event profile.

#### Total Adverse Events

One study found no significant differences between haloperidol and pimozide in treatment-limiting side effects or withdrawal due to adverse events.99

#### Weight Gain/Body Composition

One study found no difference in weight gain between haloperidol and pimozide.99

#### Prolactin-Related and Sexual Adverse Events

Prolactin levels were significantly higher in patients receiving pimozide than patients receiving haloperidol.99

#### Neuromotor Adverse Events

One study reported no tardive dyskinesia events in either the short- and long-term pimozide groups.107 A significantly higher rate of withdrawal dyskinesia was reported in patients receiving discontinuous haloperidol versus continuous haloperidol.51

#### Cardiac Adverse Events

No significant differences were found between haloperidol and pimozide in heart rate, rhythm, and waveform in one study.99

#### Sedation

No patients reported experiencing sedation in a study comparing continuous versus discontinuous administration of haloperidol.51

#### Behavioral Side Effects

No significant differences in the proportion of patients who experienced treatment-emergent anxiety or depression were observed between haloperidol and pimozide in one study.99

Strength of evidence grades for key adverse events that were reported by at least one study are provided in Table 31. The strength of evidence was insufficient for all key adverse events.

Table 31 Strength of evidence for adverse events: FGAs versus FGAs (Key Question 2)

Comparison | Outcome (N Studies; N Patients) | Strength of Evidence Domains | | | | Strength of Evidence
Comparison | Outcome (N Studies; N Patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
Haloperidol vs. pimozide | EPS (1; 22) | Moderate | Unknown | Direct | Imprecise | Insufficient
Haloperidol vs. pimozide | Prolactin-related / sexual AE (1; 22) | Moderate | Unknown | Direct | Precise | Insufficient
Haloperidol vs. pimozide | Weight (1; 22) | Moderate | Unknown | Direct | Imprecise | Insufficient

AE = adverse event; EPS = extrapyramidal symptom; FGA = first-generation antipsychotic; N = number; ROB = risk of bias

### SGAs Versus SGAs: Comparison of Different Drugs

A total of 25 studies compared adverse event rates among different SGAs. The following comparisons were made (presented alphabetically by drug name): aripiprazole versus olanzapine,112 aripiprazole versus quetiapine,112 aripiprazole versus risperidone,112 aripiprazole versus ziprasidone,103 clozapine versus olanzapine,81,87,95,109,113,114 clozapine versus quetiapine,113 clozapine versus risperidone,113,114 olanzapine versus quetiapine,64,74,79,112,113,115,116 olanzapine versus risperidone,63,64,79,83,88,89,92,96,112-120 olanzapine versus ziprasidone,64,106 quetiapine versus risperidone,64,79,91,112,113,115,116 quetiapine versus ziprasidone,64 and risperidone versus ziprasidone.64 The findings for each adverse event are provided below.

The following adverse event categories were not reported in any of the studies: mortality, cerebrovascular events, neuroleptic malignant syndrome, and exercise intolerance. The effect estimates and 95 percent confidence intervals of results that showed a significant difference between various SGAs are presented in Table 32.

Table 32 Significant findings for adverse events: SGAs versus SGAs

Adverse Event | # Studies | N (Drug 1) | N (Drug 2) | Effect estimate | 95% CI | Favors^*^
Aripiprazole (Drug 1) Versus Olanzapine (Drug 2)
Weight (kg) | 1 | 47 | 52 | MD = -4.1 | (-5.5, -2.7) | Aripiprazole
Weight–gain ≥7% | 1 | 41 | 45 | RR = 0.69 | (0.5, 0.9) | Aripiprazole
Weight, % change from baseline | 1 | 47 | 52 | MD = -7.06 | (-9.4, -4.7) | Aripiprazole
Fat mass (kg) | 1 | 47 | 52 | MD = -1.69 | (-2.7, -0.7) | Aripiprazole
BMI | 1 | 47 | 52 | MD = -1.34 | (-1.9, -0.8) | Aripiprazole
BMI>10% | 1 | 41 | 45 | RR = 0.33 | (0.2, 0.6) | Aripiprazole
Waist circumference (cm) | 1 | 47 | 52 | MD = -3.15 | (-5.9, -0.4) | Aripiprazole
Total cholesterol (mg/dL) | 1 | 47 | 52 | MD = -11.9 | (-23.4, -0.3) | Aripiprazole
Cholesterol, high | 1 | 41 | 45 | RR = 0.27 | (0.08, 0.9) | Aripiprazole
Dyslipidemia | 1 | 41 | 45 | RR = 0.25 | (0.08, 0.8) | Aripiprazole
Triglycerides (mg/dL) | 1 | 47 | 52 | MD = -26.74 | (-49.4, -4.1) | Aripiprazole
Ratio of triglycerides to HDL (mg/dL) | 1 | 47 | 52 | MD = -0.78 | (-1.4, -0.2) | Aripiprazole
Aripiprazole (Drug 1) Versus Quetiapine (Drug 2)
Weight (kg) | 1 | 47 | 45 | MD = -1.62 | (-3.0, -0.3) | Aripiprazole
Transition to overweight or obese category | 1 | 19 | 25 | RR = 0.27 | (0.1, 0.8) | Aripiprazole
Triglycerides (mg/dL) | 1 | 47 | 45 | MD = -39.4 | (-71.3, -7.4) | Aripiprazole
Ratio of triglycerides to HDL (mg/dL) | 1 | 47 | 45 | MD = -1.41 | (-2.3, -0.5) | Aripiprazole
Aripiprazole (Drug 1) Versus Risperidone (Drug 2)
Weight, % change from baseline | 1 | 47 | 168 | MD = -2.26 | (-3.9, -0.7) | Aripiprazole
Aripiprazole (Drug 1) Versus Ziprasidone (Drug 2)
WAE | 1 | 20 | 14 | RR = 0.23 | (0.05, 0.99) | Aripiprazole
Clozapine (Drug 1) Versus Olanzapine (Drug 2)
Hypertension | 2 | 27 | 27 | RR = 6.34 | (1.3, 31.8) | Olanzapine
Prolactin (ng/mL) | 2 | 29 | 25 | MD = -10.8 | (-16.7, -4.8) | Clozapine
Olanzapine ODT (Drug 1) Versus Olanzapine SOT (Drug 2)
Weight (kg) | 1 | 16 | 10 | MD = -5.9 | (-9.2, -2.6) | Olanzapine ODT
BMI | 1 | 16 | 10 | MD = -0.8 | (-1.3, -0.3) | Olanzapine ODT
Olanzapine (Drug 1) Versus Quetiapine (Drug 2)
Weight–gain ≥7% | 2 | 55 | 46 | RR = 1.47 | (1.1, 2.0) | Quetiapine
BMI>10% increase | 1 | 45 | 36 | RR = 1.71 | (1.1, 2.7) | Quetiapine
BMI≥85^th^ percentile | 1 | 45 | 36 | RR = 2.88 | (1.2, 6.8) | Quetiapine
Fat mass (kg) | 1 | 52 | 45 | MD = 1.3 | (0.1, 2.5) | Quetiapine
Waist circumference (cm) | 1 | 52 | 45 | MD = 3.28 | (1.6, 4.9) | Quetiapine
Dyslipidemia | 1 | 45 | 36 | RR = 3.47 | (1.1, 11.2) | Quetiapine
Dyskinesia | 1 | 24 | 2 | RR = 0.04 | (0.0, 0.8) | Olanzapine
Prolactin (ng/mL) | 2 | 32 | 25 | MD = 4.33 | (1.9, 6.8) | Quetiapine
Olanzapine (Drug 1) Versus Risperidone (Drug 2)
Total AE | 3 | 73 | 126 | RR = 0.87 | (0.7, 1.0) | Olanzapine
Weight (kg) | 11 | 245 | 395 | MD = 2.39 | (1.5, 3.3) | Risperidone
Weight–% change | 3 | 93 | 210 | MD = 5.02 | (3.5, 6.6) | Risperidone
Weight gain | 4 | 89 | 145 | RR = 1.86 | (1.0, 3.4) | Risperidone
Fat mass | 1 | 52 | 168 | MD = 1.67 | (0.8, 2.6) | Risperidone
BMI | 7 | 175 | 312 | MD = 0.95 | (0.7, 1.2) | Risperidone
BMI percentile change | 2 | 87 | 209 | MD = 5.93 | (1.9, 9.9) | Risperidone
BMI>10% increase | 1 | 45 | 135 | RR = 1.88 | (1.4, 2.6) | Risperidone
Waist circumference (cm) | 1 | 52 | 168 | MD = 3.45 | (2.2, 4.7) | Risperidone
Total cholesterol (mg/dL) | 4 | 100 | 227 | MD = 10.2 | (3.1, 17.2) | Risperidone
Triglycerides (mg/dL) | 5 | 116 | 246 | MD = 17.3 | (3.5, 31.1) | Risperidone
Insulin, high | 1 | 45 | 135 | RR = 2.67 | (1.1, 6.5) | Risperidone
Prolactin, high | 4 | 64 | 91 | RR = 0.38 | (0.2, 0.6) | Olanzapine
ALT (U/L) | 2 | 51 | 60 | MD = 12.4 | (3.2, 21.5) | Risperidone
AST (U/L) | 2 | 51 | 60 | MD = 7.17 | (3.5, 10.8) | Risperidone
Somnolence | 1 | 12 | 19 | RR = 0.37 | (0.1, 1.0) | Olanzapine
Aripiprazole (Drug 1) Versus Quetiapine (Drug 2)
Weight (kg) | 1 | 47 | 45 | MD = -1.62 | (-3.0, -0.3) | Aripiprazole
Transition to overweight or obese category | 1 | 19 | 25 | RR = 0.27 | (0.1, 0.8) | Aripiprazole
Triglycerides (mg/dL) | 1 | 47 | 45 | MD = -39.4 | (-71.3, -7.4) | Aripiprazole
Ratio of triglycerides to HDL (mg/dL) | 1 | 47 | 45 | MD = -1.41 | (-2.3, -0.5) | Aripiprazole
Aripiprazole (Drug 1) Versus Risperidone (Drug 2)
Weight, % change from baseline | 1 | 47 | 168 | MD = -2.26 | (-3.9, -0.7) | Aripiprazole
Aripiprazole (Drug 1) Versus Ziprasidone (Drug 2)
WAE | 1 | 20 | 14 | RR = 0.23 | (0.05, 0.99) | Aripiprazole
Clozapine (Drug 1) Versus Olanzapine (Drug 2)
Hypertension | 2 | 27 | 27 | RR = 6.34 | (1.3, 31.8) | Olanzapine
Prolactin (ng/mL) | 2 | 29 | 25 | MD = -10.8 | (-16.7, -4.8) | Clozapine
Olanzapine ODT (Drug 1) Versus Olanzapine SOT (Drug 2)
Weight (kg) | 1 | 16 | 10 | MD = -5.9 | (-9.2, -2.6) | Olanzapine ODT
BMI | 1 | 16 | 10 | MD = -0.8 | (-1.3, -0.3) | Olanzapine ODT
Olanzapine (Drug 1) Versus Quetiapine (Drug 2)
Weight–gain ≥7% | 2 | 55 | 46 | RR = 1.47 | (1.1, 2.0) | Quetiapine
BMI>10% increase | 1 | 45 | 36 | RR = 1.71 | (1.1, 2.7) | Quetiapine
BMI≥85^th^ percentile | 1 | 45 | 36 | RR = 2.88 | (1.2, 6.8) | Quetiapine
Fat mass (kg) | 1 | 52 | 45 | MD = 1.3 | (0.1, 2.5) | Quetiapine
Waist circumference (cm) | 1 | 52 | 45 | MD = 3.28 | (1.6, 4.9) | Quetiapine
Dyslipidemia | 1 | 45 | 36 | RR = 3.47 | (1.1, 11.2) | Quetiapine
Dyskinesia | 1 | 24 | 2 | RR = 0.04 | (0.0, 0.8) | Olanzapine
Prolactin (ng/mL) | 2 | 32 | 25 | MD = 4.33 | (1.9, 6.8) | Quetiapine
Olanzapine (Drug 1) Versus Risperidone (Drug 2)
Total AE | 3 | 73 | 126 | RR = 0.87 | (0.7, 1.0) | Olanzapine
Weight (kg) | 11 | 245 | 395 | MD = 2.39 | (1.5, 3.3) | Risperidone
Weight–% change | 3 | 93 | 210 | MD = 5.02 | (3.5, 6.6) | Risperidone
Weight gain | 4 | 89 | 145 | RR = 1.86 | (1.0, 3.4) | Risperidone
Fat mass | 1 | 52 | 168 | MD = 1.67 | (0.8, 2.6) | Risperidone
BMI | 7 | 175 | 312 | MD = 0.95 | (0.7, 1.2) | Risperidone
BMI percentile change | 2 | 87 | 209 | MD = 5.93 | (1.9, 9.9) | Risperidone
BMI>10% increase | 1 | 45 | 135 | RR = 1.88 | (1.4, 2.6) | Risperidone
Waist circumference (cm) | 1 | 52 | 168 | MD = 3.45 | (2.2, 4.7) | Risperidone
Total cholesterol (mg/dL) | 4 | 100 | 227 | MD = 10.2 | (3.1, 17.2) | Risperidone
Triglycerides (mg/dL) | 5 | 116 | 246 | MD = 17.3 | (3.5, 31.1) | Risperidone
Insulin, high | 1 | 45 | 135 | RR = 2.67 | (1.1, 6.5) | Risperidone
Prolactin, high | 4 | 64 | 91 | RR = 0.38 | (0.2, 0.6) | Olanzapine
ALT (U/L) | 2 | 51 | 60 | MD = 12.4 | (3.2, 21.5) | Risperidone
AST (U/L) | 2 | 51 | 60 | MD = 7.17 | (3.5, 10.8) | Risperidone
Somnolence | 1 | 12 | 19 | RR = 0.37 | (0.1, 1.0) | Olanzapine
Olanzapine (Drug 1) Versus Ziprasidone (Drug 2)
Weight (kg) | 1 | 19 | 21 | MD = 4.3 | (3.0, 5.6) | Ziprasidone
Prolactin (ng/dL) | 1 | 19 | 21 | MD = -2.1 | (-2.5, -6.7) | Ziprasidone
Quetiapine (Drug 1) Versus Risperidone (Drug 2)
Transition to overweight or obese | 1 | 36 | 135 | RR = 2.57 | (1.4, 4.7) | Risperidone
Ratio of triglycerides to HDL (mg/dL) | 1 | 45 | 168 | MD = 1.02 | (0.2, 1.8) | Risperidone
Prolactin, high | 3 | 19 | 77 | RR = 0.21 | (0.07, 0.7) | Quetiapine
Prolactin (ng/dL) | 2 | 25 | 63 | MD = -31.2 | (-37.0, -25.3) | Quetiapine
Dyskinesia | 1 | 2 | 45 | RR = 46.0 | (2.4, 905.6) | Risperidone
TSH (mlU/L) | 1 | 24 | 22 | MD = 0.9 | (0.2, 1.6) | Risperidone

AE = adverse event; ALT = alanine transaminase; AST = aspartate aminotransferase; BMI = body mass index; CI = confidence interval; cm = centimeter; dL = deciliter; HDL = high density lipoproteins; kg = kilogram; MD = mean difference; mg = milligram; mL = milliliter; N = number; ng = nanogram; ODT = orally disintegrating tablet; RR = relative risk; SGA = second-generation antipsychotic; SOT = standard oral tablet; TSH = thyroid stimulating hormone; WAE = withdrawal due to adverse event; U/L = international units per liter

* Denotes the drug with the better adverse event profile.

#### Total Adverse Events

Withdrawal due to adverse events was more common for patients treated with ziprasidone than for those treated with aripiprazole in one study.103 A meta-analysis of three studies88,113,118 found no significant difference between olanzapine and risperidone (Figure 50).

Figure 50 Olanzapine versus risperidone for total adverse events

CI = confidence interval; df = degrees of freedom; M–H = Mantel–Haenszel

Figure 50 is a metagraph depicting the effect of olanzapine versus risperidone for total adverse events. Three RCTs with 199 patients were pooled. A meta-analysis found that a significantly greater proportion of patients receiving risperidone experienced any adverse events than olanzapine (MD = 0.87; 95 percent CI, 0.73 to 1.04). There was no evidence of heterogeneity (p = 0.99, I2 = 0 percent).

#### Weight Gain/Body Composition

Weight gain greater than 7 percent and body mass index (BMI) increase greater than 10 percent occurred significantly more frequently in patients receiving olanzapine than those receiving aripiprazole in one study.112 Similarly, olanzapine resulted in significantly greater mean increase in weight, percent change from baseline weight, fat mass, BMI, and waist circumference than aripiprazole.112 Transition from normal weight to overweight or obese categories occurred in a significantly greater proportion of patients in the quetiapine group than the aripiprazole group.112 In addition, increase in mean weight was significantly greater for quetiapine than for aripiprazole. Percent weight change from baseline was significantly greater for risperidone than with aripiprazole.112

Weight gain greater than 7 percent,79,112 BMI increase greater than 10 percent,112 and BMI greater than the 85^th^ percentile115 occurred in a greater proportion of patients in the olanzapine group than the quetiapine group. Similarly, the olanzapine group experienced significantly greater increase in fat mass112 and waist circumference than quetiapine.112 Patients on olanzapine consistently experienced significantly less mean weight gain64,74,112,115 and increase in BMI;74,112,115 however, the studies could not be pooled due to heterogeneity.

Significantly more patients receiving olanzapine experienced any weight gain88,113,114,118 and BMI increase greater than 10 percent112 than those receiving risperidone. Similarly, a meta-analysis of 11 studies63,64,83,88,89,92,96,112,114,115,117 (Figure 51) found a greater increase in mean weight for olanzapine than risperidone (MD = 2.39; 95% CI, 1.45 to 3.32). Studies also found a greater increase for olanzapine than risperidone in weight,63,112,117 fat mass,112 BMI,88,89,96,112,114,115,117 BMI percentile,88,112 and waist circumference.112 Fewer patients treated with risperidone had a transition from normal weight to overweight to obese than those treated with quetiapine.112

Figure 51 Olanzapine versus risperidone for mean weight gain (kg)

CI = confidence interval; df = degrees of freedom; IV = inverse variance; kg = kilogram; SD = standard deviation

Figure 51 is a metagraph depicting the effect of olanzapine versus risperidone for mean weight gain. Eleven studies with 640 patients were pooled. The meta-analysis found a significant difference favoring risperidone over olanzapine (MD = 2.39; 95 percent CI: 1.45 to 3.32).

One study found a significantly greater mean increase in weight for olanzapine than ziprasidone.64

#### Dyslipidemia

The proportion of patients with elevated total cholesterol, incidence of dyslipidemia, as well as the increase in mean total cholesterol, mean triglycerides, and ratio of triglycerides to high-density lipoprotein cholesterol were significantly greater in patients receiving olanzapine than those receiving aripiprazole in one study.112 There was a significantly greater increase in mean triglycerides and in the ratio of triglycerides to high-density lipoprotein cholesterol for quetiapine than aripiprazole.112 Olanzapine-treated patients experienced significantly more dyslipidemia than quetiapine-treated patients in one study.112 Abnormal lipid profile favored risperidone over quetiapine in one small study.91 Mean total cholesterol and mean triglycerides were found to be significantly higher for patients treated with olanzapine than risperidone in a meta-analysis of four studies63,88,112,115 and five studies,63,88,89,112,115 respectively. Ratio of triglycerides to high-density lipoprotein cholesterol was also significantly higher for quetiapine than risperidone in one study.115

#### Insulin Resistance and Diabetes

One study112 reported high insulin levels in a significantly greater proportion of patients receiving olanzapine than those receiving risperidone.

#### Prolactin-Related and Sexual Adverse Events

Increase in mean prolactin level was significantly higher for patients treated with olanzapine than those treated with clozapine in a meta-analysis of two studies.81,109 Patients treated with olanzapine had significantly higher prolactin levels than patients treated with quetiapine64,116 or ziprasidone.64 Prolactin levels were high in a greater proportion of patients83,92,113,116 treated with risperidone than in patients treated with olanzapine. The proportion of patients with high prolactin levels91,113,116 and mean prolactin levels64,116 were higher with risperidone than quetiapine.

#### Neuromotor Adverse Events

Tardive dyskinesia was not significantly different between clozapine and olanzapine,114 clozapine and risperidone,114 or olanzapine and risperidone.88,92,114,119 Dyskinesia was experienced in a significantly greater proportion of patients treated with quetiapine than olanzapine or risperidone in one small study.113

#### Cardiac Adverse Events

Hypertension was significantly more common in the clozapine group than in the olanzapine group in two studies.87,114

#### Sedation

One study92 found somnolence to occur significantly more frequently for patients receiving risperidone than for those receiving olanzapine.

#### Liver Toxicity

Mean alanine transaminase and aspartate amino transferase levels were significantly higher for patients treated with olanzapine than for those treated with risperidone in meta-analyses of two studies.88,89

#### Neutropenia and Agranulocytosis

A meta-analysis of three studies found no difference between clozapine and olanzapine for neutropenia.81,87,95 No difference was found between clozapine, olanzapine, or risperidone for leucopenia in one study.114 White blood cell counts were not significantly different between olanzapine and risperidone.89

#### Thyroid Dysfunction

Thyroid stimulating hormone levels were significantly higher in patients receiving quetiapine than in patients receiving risperidone based on one study.115

#### Seizures

Two studies found no significant difference in the rates of seizures for clozapine and olanzapine.87,95 Similarly, no difference was found in seizure rates for olanzapine and risperidone.92,96

#### Constipation

No difference was found in constipation rates for the following comparisons: clozapine and olanzapine,81,87,95,114 clozapine and risperidone,114 olanzapine and quetiapine,74 or olanzapine and risperidone.88,89,96,114

#### Behavioral Side Effects

No significant differences in behavioral side effects were found in the following comparisons: aripiprazole versus ziprasidone,103 clozapine versus olanzapine,87,95,113,114 clozapine versus quetiapine,113 clozapine versus risperidone,113,114 olanzapine versus quetiapine,74,79,113 olanzapine versus risperidone,63,79,88,96,113,114 or quetiapine versus risperidone.79,113 Agitation, anxiety, depression, irritability, and worsening psychosis were examined.

Strength of evidence for key adverse events that were reported by at least one study are provided in Table 33. The strength of evidence was moderate for the following outcomes: weight for olanzapine versus quetiapine, and dyslipidemia, prolactin-related and sexual adverse events, and weight for olanzapine versus risperidone. For all other key adverse events, the strength of evidence for SGAs versus SGAs was low or insufficient.

Table 33 Strength of evidence for adverse events: SGAs versus SGAs (Key Question 2)

Comparison | Outcome (N Studies; N Patients) | Strength of Evidence Domains | | | | Strength of Evidence
Comparison | Outcome (N Studies; N Patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
Aripiprazole vs. olanzapine | Dyslipidemia (1; 312) | Moderate | Unknown | Direct | Precise | Low
Aripiprazole vs. olanzapine | Insulin resistance (1; 312) | Moderate | Unknown | Direct | Imprecise | Insufficient
Aripiprazole vs. olanzapine | Weight (1; 312) | Moderate | Unknown | Direct | Precise | Low
Aripiprazole vs. quetiapine | Dyslipidemia (1; 312) | Moderate | Unknown | Direct | Precise | Low
Aripiprazole vs. quetiapine | Insulin resistance (1; 312) | Moderate | Unknown | Direct | Imprecise | Insufficient
Aripiprazole vs. quetiapine | Weight (1; 312) | Moderate | Unknown | Direct | Precise | Low
Aripiprazole vs. risperidone | Dyslipidemia (1; 312) | Moderate | Unknown | Direct | Imprecise | Insufficient
Aripiprazole vs. risperidone | Insulin resistance (1; 312) | Moderate | Unknown | Direct | Imprecise | Insufficient
Aripiprazole vs. risperidone | Weight (1; 312) | Moderate | Unknown | Direct | Precise | Low
Aripiprazole vs. ziprasidone | EPS (1; 46) | Moderate | Unknown | Direct | Imprecise | Insufficient
Aripiprazole vs. ziprasidone | Sedation (1; 46) | Moderate | Unknown | Direct | Imprecise | Insufficient
Aripiprazole vs. ziprasidone | Weight (1; 46) | Moderate | Unknown | Direct | Imprecise | Insufficient
Clozapine vs. olanzapine | Dyslipidemia (2; 65) | Moderate | Inconsistent | Direct | Imprecise | Low
Clozapine vs. olanzapine | EPS (3; 98) | High | Inconsistent | Direct | Imprecise | Low
Clozapine vs. olanzapine | Insulin resistance (1; 40) | Moderate | Consistent | Direct | Imprecise | Insufficient
Clozapine vs. olanzapine | Prolactin-related / sexual AE (3; 113) | Moderate | Consistent | Direct | Precise | Low
Clozapine vs. olanzapine | Sedation (3; 74) | Moderate | Consistent | Direct | Imprecise | Low
Clozapine vs. olanzapine | Weight (5; 146) | Moderate | Inconsistent | Direct | Imprecise | Low
Clozapine vs. quetiapine | EPS (1; 26) | Moderate | Unknown | Direct | Imprecise | Insufficient
Clozapine vs. quetiapine | Prolactin-related / sexual AE (1; 26) | Moderate | Unknown | Direct | Imprecise | Insufficient
Clozapine vs. quetiapine | Sedation (1; 26) | Moderate | Unknown | Direct | Imprecise | Insufficient
Clozapine vs. quetiapine | Weight (1; 26) | Moderate | Unknown | Direct | Imprecise | Insufficient
Clozapine vs. risperidone | EPS (2; 58) | High | Consistent | Direct | Imprecise | Low
Clozapine vs. risperidone | Prolactin-related / sexual AE (1; 26) | Moderate | Unknown | Direct | Imprecise | Insufficient
Clozapine vs. risperidone | Sedation (1; 26) | Moderate | Unknown | Direct | Imprecise | Insufficient
Clozapine vs. risperidone | Weight (2; 58) | High | Consistent | Direct | Imprecise | Low
Olanzapine vs. quetiapine | Dyslipidemia (2; 366) | Moderate | Inconsistent | Direct | Imprecise | Low
Olanzapine vs. quetiapine | EPS (3; 96) | Moderate | Inconsistent | Direct | Imprecise | Low
Olanzapine vs. quetiapine | Insulin resistance (2; 366) | Moderate | Consistent | Direct | Imprecise | Low
Olanzapine vs. quetiapine | Prolactin-related / sexual AE (4; 130) | Moderate | Inconsistent | Direct | Imprecise | Insufficient
Olanzapine vs. quetiapine | Sedation (3; 96) | Moderate | Consistent | Direct | Imprecise | Low
Olanzapine vs. quetiapine | Weight (5; 259) | Moderate | Consistent | Direct | Precise | Moderate
Olanzapine vs. risperidone | Dyslipidemia (5; 418) | Moderate | Consistent | Direct | Precise | Moderate
Olanzapine vs. risperidone | EPS (11; 533) | Moderate | Consistent | Direct | Imprecise | Low
Olanzapine vs. risperidone | Insulin resistance (5; 418) | Moderate | Consistent | Direct | Imprecise | Low
Olanzapine vs. risperidone | Prolactin-related / sexual AE (12; 609) | Moderate | Consistent | Direct | Precise | Moderate
Olanzapine vs. risperidone | Sedation (9; 473) | Moderate | Inconsistent | Direct | Imprecise | Low
Olanzapine vs. risperidone | Weight (14; 901) | Moderate | Consistent | Direct | Precise | Moderate
Olanzapine vs. ziprasidone | EPS (1; 100) | High | Unknown | Direct | Imprecise | Insufficient
Olanzapine vs. ziprasidone | Sedation (1; 100) | Moderate | Unknown | Direct | Imprecise | Insufficient
Olanzapine vs. ziprasidone | Prolactin-related / sexual AE (1; 40) | Moderate | Unknown | Direct | Precise | Insufficient
Olanzapine vs. ziprasidone | Weight (1; 40) | Moderate | Unknown | Direct | Precise | Insufficient
Quetiapine vs. risperidone | Dyslipidemia (3; 302) | Moderate | Consistent | Direct | Imprecise | Low
Quetiapine vs. risperidone | EPS (3; 87) | Moderate | Inconsistent | Direct | Imprecise | Low
Quetiapine vs. risperidone | Insulin resistance (2; 280) | Moderate | Consistent | Direct | Imprecise | Low
Quetiapine vs. risperidone | Prolactin-related / sexual AE (5; 175) | Moderate | Consistent | Direct | Precise | Low
Quetiapine vs. risperidone | Sedation (3; 87) | Moderate | Inconsistent | Direct | Imprecise | Low
Quetiapine vs. risperidone | Weight (5; 369) | Moderate | Inconsistent | Direct | Imprecise | Low

AE = adverse event; EPS = extrapyramidal symptom; N = number; ROB = risk of bias; SGA = second-generation antipsychotic

### SGAs Versus SGAs: Comparison of Doses and Formulations

Adverse event data were provided for dosing comparisons of the following drugs: aripiprazole,46,67,77,121 paliperidone,86,122 quetiapine,73,75,84 risperidone,50,68,69,78 and ziprasidone.42 In addition, one study117 compared orally disintegrating versus standard oral olanzapine tablets.

Four studies provided data on adverse events for comparisons of aripiprazole dosing.46,67,77,121 One study46 found a greater proportion of patients experiencing weight gain in the moderate-dose (10 mg/day) than low-dose (5 mg/day) aripiprazole group. Extrapyramidal side effects were found to be significantly more frequent in patients receiving higher aripiprazole doses (30 mg) than those receiving lower aripiprazole doses (10 mg) in two studies.67,77 In addition, QTc intervals showed a significant decrease in the high-dose aripiprazole (30 mg/day) group compared with low-dose (10 mg/day) group (p = 0.045); however, the authors concluded that this difference was not clinically relevant.77 One study46 found higher incidence of fatigue in patients receiving moderate- or high-dose aripiprazole (15 mg/day) than low-dose (5 mg/day) aripiprazole. No other significant differences were found.

Two studies86,122 compared three doses of paliperidone. Total adverse events were significantly more common for the high-dose group versus the low/medium-dose group in one study86 but not in the other.122 No other significant differences were found.

Two drug formulations for olanzapine were compared in one study.117 Weight and BMI increased significantly more in patients receiving the standard oral tablet than in patients receiving the orally disintegrating tablet.

Three studies73,75,84 reported adverse events comparing low- and high-dose quetiapine. No significant differences were found.

Four studies50,68,69,78 compared low- and high-dose risperidone. In one RCT,78 weight gain occurred significantly more frequently in patients receiving high-dose risperidone (1.5–6.0 mg/day) than in those receiving low-dose risperidone (0.15–0.6 mg/day). Another study found no significant difference in the frequency of weight gain in patients given risperidone at daily doses of 0.5–2.5 mg and 3–6 mg.68 Prolactin elevation was greater for patients receiving the higher dose in two studies.69,78 Two studies reported no incidence of tardive dyskinesia in either dosing groups.68,78 Three studies68,69,78 reported that extrapyramidal symptoms occurred significantly more frequently in patients given higher doses of risperidone than those given lower doses. Significantly more patients experienced somnolence when receiving higher doses of risperidone than lower doses in all three studies.

One study42 compared two doses of ziprasidone. The only significant difference in adverse events between the groups was in the proportion of patients withdrawing due to adverse events, which occurred more in the high-dose ziprasidone (160 mg/day) group than the low-dose (80 mg/day) group.

#### Persistence of Adverse Events

Overall, resolution of adverse events was investigated in three studies.59,96,98 In two studies, mean time to adverse event resolution was reported for akathisia59,98 and somnolence.98 Akathisia resolved in 48 hours for quetiapine-treated patients59 in one study and ziprasidone-treated patients in another study.98 In ziprasidone-treated patients, somnolence resolved in 20 days.98 In one study comparing haloperidol, olanzapine, and risperidone, the relative rates of adverse events resolution were compared at the end of the study (8 weeks) for fatigability, constipation, depression, palpitations, pruritus, and sedation. No significant differences were found.96

### FGAs Versus Placebo

Two studies reported the relative rates of adverse events between FGAs and placebo: haloperidol in two studies90,99 and pimozide in one study.99 Data were not reported for the following adverse event categories: mortality, cerebrovascular events, dyslipidemia, insulin resistance and diabetes, liver toxicity, neutropenia and agranulocytosis, thyroid dysfunction, seizures, neuroleptic malignant syndrome, constipation, exercise intolerance, precocious puberty, and dermatological adverse events. Effect estimates and 95 percent confidence intervals for the significant findings are presented in Table 34.

Table 34 Significant findings for adverse events: FGAs versus placebo

Adverse Event | # Studies | N (Drug 1) | N (Drug 2) | Effect Estimate | 95% CI | Favors^*^
Haloperidol (Drug 1) Versus Placebo (Drug 2)
Treatment-limiting SE | 1 | 22 | 22 | RR = 19.00 | (1.2, 307.6) | Placebo
Prolactin | 1 | 19 | 25 | MD = 6.1 | (2.2, 10.0) | Placebo
Drowsiness | 1 | 22 | 22 | RR = 17.00 | (1.0, 277.6) | Placebo
Pimozide (Drug 1) Versus Placebo (Drug 2)
Prolactin | 1 | 25 | 25 | MD = 14.8 | (7.1, 22.5) | Placebo

CI = confidence interval; FGA = first-generation antipsychotic; MD = mean difference; N = number; RR = relative risk; SE = side effect

* Denotes the drug with the better adverse event profile.

#### Total Adverse Events

Treatment-limiting adverse events occurred in a significantly greater proportion of patients treated with haloperidol than placebo.99

#### Weight Gain/Body Composition

One study showed no significant difference between placebo and haloperidol or pimozide for weight gain.99

#### Prolactin-Related and Sexual Adverse Events

Prolactin levels were significantly higher in patients treated with haloperidol and pimozide than placebo.99

#### Neuromotor Adverse Events

Tardive dyskinesia was not reported in studies. No significant difference was found in extrapyramidal events between haloperidol versus placebo90,99 and pimozide versus placebo.99

#### Cardiac Adverse Events

One study showed no significant difference in electrocardiovascular measures between haloperidol or pimozide and placebo.99

#### Sedation

One study99 found a significantly greater rate of drowsiness in the haloperidol group than placebo.

#### Behavioral Side Effects

There was no significant difference in anxiety or depression between haloperidol and placebo or pimozide and placebo in one study.99

Strength of evidence grades for key adverse events that were reported by at least one study are provided in Table 35. The strength of evidence was insufficient for all key adverse events.

Table 35 Strength of evidence for adverse events: FGAs versus placebo (Key Question 2)

Comparison | Outcome (N Studies; N Patients) | Strength of Evidence Domains | | | | Strength of Evidence
Comparison | Outcome (N Studies; N Patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
FGA vs. placebo | EPS (2; 38) | Moderate | Consistent | Direct | Imprecise | Insufficient
FGA vs. placebo | Prolactin-related / sexual AE (1; 22) | Moderate | Unknown | Direct | Precise | Insufficient
FGA vs. placebo | Sedation (1; 16) | Moderate | Unknown | Indirect | Precise | Insufficient
FGA vs. placebo | Weight (1; 22) | Moderate | Unknown | Direct | Imprecise | Insufficient

AE = adverse event; EPS = extrapyramidal symptom; FGA = first-generation antipsychotic; N = number; ROB = risk of bias

### SGAs Versus Placebo

A total of 36 studies reported the relative rates of adverse events between SGAs and placebo. SGA comparisons included aripiprazole,46,67,72,77 olanzapine,43,71,80,93,123 paliperidone,86 quetiapine,59,65,66,73,84 risperidone,44,47,49,50,52,53,55-58,60-62,68,69,101,104,105 and ziprasidone.70,85,98 The findings for each adverse event are provided below. The following adverse events were not reported: cerebrovascular events, exercise intolerance, and precocious puberty. Effect estimates and 95 percent confidence intervals for the significant findings are presented in Table 36.

Table 36 Significant findings for adverse events: SGAs versus placebo

Adverse Event | # Studies | N (Drug 1) | N (Drug 2) | Effect estimate | 95% CI | Favors^*^
Aripiprazole (Drug 1) Versus Placebo (Drug 2)
Total AE | 2 | 362 | 148 | RR = 1.24 | (1.1, 1.4) | Placebo
Weight (kg) | 4 | 527 | 271 | MD = 0.77 | (0.4, 1.2) | Placebo
Weight gain | 2 | 361 | 149 | RR = 3.81 | (1.2, 12.4) | Placebo
BMI | 3 | 508 | 214 | MD = 0.23 | (0.1, 0.4) | Placebo
Total cholesterol, elevated | 1 | 55 | 65 | RR = 2.50 | (1.4, 4.4) | Placebo
Prolactin (ng/ml) | 3 | 423 | 184 | MD = -4.1 | (-6.3, -1.8) | Aripiprazole
EPS | 4 | 582 | 273 | RR = 4.16 | (2.4, 7.2) | Placebo
Parkinsonism | 2 | 399 | 197 | RR = 3.89 | (2.1, 7.1) | Placebo
Myoclonus | 2 | 399 | 197 | RR = 3.98 | (2.2, 7.1) | Placebo
Sedation | 1 | 165 | 51 | RR = 4.02 | (1.3, 12.5) | Placebo
Somnolence | 4 | 582 | 273 | RR = 2.67 | (1.1, 6.5) | Placebo
Olanzapine (Drug 1) Versus Placebo (Drug 2)
Weight (kg) | 4 | 215 | 122 | MD = 4.60 | (3.1, 6.1) | Placebo
Weight gain | 3 | 109 | 69 | RR = 3.63 | (1.9, 6.8) | Placebo
Weight–gain ≥7% | 4 | 215 | 122 | RR = 6.57 | (2.1, 20.5) | Placebo
BMI | 2 | 179 | 88 | MD = 1.28 | (0.96, 1.6) | Placebo
Triglycerides (mg/dL) | 1 | 55 | 25 | MD = 37.2 | (8.9, 65.5) | Placebo
Triglycerides, abnormal/high (endpoint) | 2 | 179 | 89 | RR = 2.42 | (1.2, 4.9) | Placebo
Cholesterol, abnormal | 1 | 107 | 54 | RR = 10.1 | (1.4, 73.2) | Placebo
Cholesterol, increase | 1 | 75 | 34 | RR = 7.25 | (1.0, 52.5) | Placebo
Prolactin (ng/ml), change | 2 | 162 | 79 | MD = 11.5 | (8.8, 14.1) | Placebo
Prolactin, high | 2 | 179 | 89 | RR = 8.88 | (1.5, 52.5) | Placebo
SBP, supine | 1 | 107 | 54 | MD = 5.89 | (2.3, 9.5) | Placebo
Pulse, sitting | 1 | 29 | 29 | MD = 9.27 | (1.5, 17.1) | Placebo
Pulse, standing | 2 | 135 | 83 | MD = 9.52 | (5.1, 14.0) | Placebo
Pulse, supine | 1 | 107 | 54 | MD = 10.18 | (5.9, 14.5) | Placebo
Fatigue | 1 | 31 | 29 | RR = 8.42 | (1.1, 62.4) | Placebo
ALT (U/L) | 2 | 177 | 88 | MD = 22.5 | (14.3, 30.7) | Placebo
AST (U/L) | 2 | 177 | 88 | MD = 8.98 | (5.2, 12.8) | Placebo
GGT (U/L) | 1 | 70 | 34 | MD = 8.6 | (2.7, 14.5) | Placebo
ALT high | 1 | 107 | 54 | RR = 18.17 | (2.6, 129.0) | Placebo
AST high | 1 | 107 | 54 | RR = 12.11 | (1.7, 87.2) | Placebo
Quetiapine (Drug 1) Versus Placebo (Drug 2)
Total AE | 2 | 340 | 165 | RR = 1.26 | (1.1, 1.4) | Placebo
WAE | 5 | 381 | 205 | RR = 2.53 | (1.2, 5.4) | Placebo
Weight (kg) | 4 | 188 | 115 | MD = 1.78 | (1.1, 2.5) | Placebo
Weight gain | 2 | 202 | 100 | RR = 5.19 | (1.0, 27.6) | Placebo
BMI | 1 | 17 | 15 | MD = 0.6 | (0.4, 0.8) | Placebo
Triglyceride (mg/dL) | 2 | 164 | 90 | MD = 29.1 | (7.3, 50.9) | Placebo
Triglyceride, high | 3 | 357 | 180 | RR = 2.36 | (1.1, 5.4) | Placebo
SBP, standing | 1 | 17 | 15 | MD = 13 | (1.2, 24.8) | Placebo
SBP, supine | 1 | 17 | 15 | MD = 12 | (5.8, 18.3) | Placebo
DBP | 1 | 17 | 15 | MD = 11 | (3.0, 19.0) | Placebo
Pulse, change | 1 | 17 | 15 | MD = 14 | (5.7, 22.3) | Placebo
Tachycardia | 3 | 357 | 180 | RR = 9.54 | (1.9, 49.1) | Placebo
WBC (10^3^/μL) | 1 | 15 | 15 | MD = -1.5 | (-2.0, -1.0) | Placebo
Somnolence | 2 | 340 | 165 | RR = 3.41 | (2.0, 5.8) | Placebo
Risperidone (Drug 1) Versus Placebo (Drug 2)
Weight (kg) | 12 | 556 | 501 | MD = 1.79 | (1.5, 2.1) | Placebo
BMI | 5 | 397 | 343 | MD = 0.57 | (0.4, 0.8) | Placebo
EPS | 8 | 431 | 380 | RR = 2.65 | (1.4, 4.9) | Placebo
EPS-related AE | 1 | 106 | 54 | RR = 2.42 | (1.2, 4.8) | Placebo
Pulse | 4 | 114 | 117 | MD = 6.42 | (3.5, 9.4) | Placebo
Sedation | 5 | 206 | 163 | RR = 2.90 | (1.5, 5.5) | Placebo
Fatigue/Tiredness | 6 | 444 | 385 | RR = 4.58 | (1.5, 14.0) | Placebo
Constipation | 3 | 100 | 102 | RR = 2.72 | (1.3, 5.9) | Placebo
Ziprasidone (Drug 1) Versus Placebo (Drug 2)
Total AE | 3 | 358 | 190 | RR = 1.40 | (1.2, 1.6) | Placebo
EPS | 1 | 193 | 90 | RR = 10.26 | (1.4, 74.9) | Placebo
Somnolence | 3 | 358 | 190 | RR = 2.98 | (1.7, 5.2) | Placebo
Fatigue | 2 | 342 | 178 | RR = 1.97 | (1.0, 3.9) | Placebo

AE = adverse event; ALT = alanine transaminase; AST = aspartate aminotransferase; BMI = body mass index; CI = confidence interval; DBP = diastolic blood pressure; dl = deciliter; EPS = extrapyramidal symptom; GGT = gamma-glutamyl transpeptidase; kg = kilogram; MD = mean difference; mg = milligram; ml = milliliter; N = number; ng = nanogram; RR = relative risk; SBP = systolic blood pressure; SGA = second-generation antipsychotic; U/L = units per liter; WBC = white blood cell; WAE = withdrawal due to adverse event

* Denotes the drug with the better adverse event profile.

#### Total Adverse Events

Total adverse events were significantly higher for patients treated with aripiprazole than placebo in a meta-analysis of two studies.46,67 A significantly greater number of patients receiving quetiapine experienced any adverse event73,84 or withdrawal due to an adverse event than placebo.59,65,66,73,84 Eight of 10 studies52,55,57,58,60-62,68,69,104 showed that a significantly greater number of patients in the risperidone group experienced an adverse event than the placebo group; however, the studies could not be pooled due to heterogeneity. Treatment with ziprasidone resulted in significantly more patients with adverse events than placebo in a meta-analysis of three studies.70,85,98

#### Mortality

Studies found no difference in mortality for the following placebo comparisons: aripiprazole,46,67,77 olanzapine,71,80 paliperidone,86 quetiapine,73,84 risperidone,44,68,69 or ziprasidone.70,85

#### Weight Gain/Body Composition

A meta-analysis of two studies46,77 found that weight gain occurred in a significantly greater proportion of patients treated with aripiprazole than placebo. Similarly, meta-analyses favored placebo over aripiprazole for mean weight gain46,67,72,77 (Figure 52) and change in BMI.46,67,77 Mean weight gain (Figure 52) and weight gain of greater than 7 percent occurred significantly more frequently in olanzapine-treated patients than placebo in a meta-analysis of four studies.43,71,80,93 Similarly, change in BMI favored placebo over olanzapine.

Figure 52 SGAs versus placebo for mean weight gain (kg)

CI = confidence interval; df = degrees of freedom; IV = inverse variance; kg = kilogram; SD = standard deviation; SGA = second-generation antipsychotic

Figure 52 is a metagraph depicting the effect of SGAs on mean weight gain. Pooled results are displayed for placebo comparisons with five SGAs: aripiprazole, olanzapine, quetiapine, risperidone, and ziprasidone. Meta-analysis favored placebo over aripiprazole in four studies with 798 patients (MD = 0.77; 95 percent CI: 0.40 to 1.15). Mean weight gain favored placebo over olanzapine in four studies with 337 patients (MD = 4.60; 95 percent CI: 3.07 to 6.13). Placebo was favored over quetiapine in four studies with 303 patients (MD = 1.78; 95 percent CI, 1.10 to 2.47). Risperidone-treated patients showed a significantly greater increase in mean weight in a meta-analysis of 12 studies with 1057 patients (MD = 1.79; 95 percent CI: 1.48 to 2.10). No significant differences were observed between ziprasidone and placebo in two studies of 265 patients (MD = -0.10; 95 percent CI: -0.61 to 0.41). The studies were not pooled across all SGAs due to heterogeneity. Overall, olanzapine showed greater weight gain over placebo than the other SGAs.

Placebo was favored over quetiapine for the proportion of patients experiencing weight gain, mean weight, and mean BMI.59,73

Risperidone-treated patients showed a significantly greater increase in mean weight in a meta-analysis of 12 studies44,47,49,52,55,57,58,61,62,68,104,105 (MD = 1.79; 95% CI, 1.48 to 2.10) (Figure 52) and BMI in a meta-analysis of five studies.47,55,61,62,68

The studies were not pooled across all SGAs due to heterogeneity. Overall, olanzapine showed a greater magnitude of the effect for weight gain over placebo than the other SGAs. This finding is consistent with direct comparisons of SGAs above, in which olanzapine showed a significantly greater increase on weight and body composition measures than other SGAs.

#### Dyslipidemia

Total cholesterol levels were elevated in a significantly greater proportion of patients treated with aripiprazole than those receiving placebo.67 Two meta-analyses found elevated triglycerides71,80 and abnormal cholesterol71 to be significantly more frequent with olanzapine than placebo. Mean triglycerides levels were higher for olanzapine in one study80 and for quetiapine in two studies.65,84

#### Insulin Resistance and Diabetes

No difference was found between paliperidone and placebo for insulin resistance86 or between quetiapine and placebo for development of diabetes.65 In addition, there was no significant difference in glucose levels between placebo and the following SGAs: aripiprazole,46,67,77 olanzapine,71,80,93 paliperidone,86 quetiapine,65 or risperidone.68 All studies ranged between 3 and 8 weeks in duration; therefore, the studies were likely too short to detect changes in insulin resistance or risk of diabetes.

#### Prolactin-Related and Sexual Adverse Events

Figure 53 provides a meta-graph of the changes in prolactin levels comparing SGAs and placebo. Mean prolactin levels showed greater decrease with aripiprazole than with placebo in a meta-analysis of three studies.46,67,77 The proportion of patients with high prolactin as well as mean prolactin levels were significantly greater for olanzapine versus placebo in a meta-analysis of two studies.71,80 No significant difference was seen for prolactin levels between quetiapine and placebo. Placebo was significantly favored over risperidone for change in prolactin levels in seven of eight studies;44,47,57,58,61,62,68,69 however, studies could not be pooled due to heterogeneity.

Figure 53 SGAs versus placebo for change in prolactin levels (ng/L)

CI = confidence interval; df = degrees of freedom; IV = inverse variance; ng/L = nanogram per liter; SD = standard deviation; SGA = second-generation antipsychotic

Figure 53 is a metagraph depicting the effect of SGAs on mean prolactin levels. Pooled results are displayed for placebo comparisons with four SGAs: aripiprazole, olanzapine, quetiapine, and risperidone. In meta-analysis of three studies with 607 patients, aripiprazole showed a greater decrease in mean prolactin levels than with placebo (MD = -4.07; 95 percent CI: -6.30 to -1.83). Mean prolactin levels were significantly greater for olanzapine versus placebo in a meta-analysis of two studies with 241 patients (MD = 11.48; 95 percent CI: 8.82 to 14.14). No significant differences were observed between quetiapine and placebo in three studies with 82 patients (MD = 1.30; 95 percent CI: -1.35 to 3.95). Placebo was significantly favored over risperidone for change in prolactin levels in seven of eight studies; however, the studies could not be pooled due to heterogeneity.

#### Neuromotor Adverse Events

Tardive dyskinesia was rare and not significantly different between risperidone and placebo in six studies.52,61,62,68,78,105, Extrapyramidal side effects, including Parkinsonism and myoclonus, occurred significantly more frequently with aripiprazole than with placebo in a meta-analysis of four studies.46,67,72,77 Extrapyramidal symptoms were significantly more common among risperidone-treated patients than patients receiving placebo in a meta-analysis of eight studies.47,52,57,60-62,68,101 One study85 showed a significantly higher rate of extrapyramidal symptoms with ziprasidone versus placebo.

#### Cardiac Adverse Events

A significantly greater rate of tachycardia occurred with quetiapine treatment65,73,84 than placebo. Supine systolic blood pressure71 and pulse71,93 were significantly lower for placebo than for olanzapine. Blood pressure and pulse were significantly higher with quetiapine than with placebo in one study.65 A meta-analysis of four studies52,56,62,104 showed a greater increase in pulse with risperidone than placebo.

#### Sedation

Sedation46 and somnolence46,67,72,77 occurred significantly more frequently in the aripiprazole group than in the placebo group. Rate of fatigue93 was significantly higher with olanzapine than with placebo. Somnolence was significantly more common among patients treated with quetiapine than placebo in two studies.73,84 Two meta-analyses showed rates of sedation44,49,57,60,68 and fatigue47,52,58,61,62,68 occurred significantly more frequently for risperidone than for placebo. Ziprasidone resulted in significantly greater rates of somnolence70,85,98 and fatigue70,85 than placebo.

#### Liver Toxicity

Patients treated with olanzapine experienced elevated alanine transaminase and aspartate amino transferase significantly more frequently than patients who received placebo in one study.71 Mean alanine transaminase, aspartate amino transferase, and gamma-glutamyl transpeptidase levels were significantly higher with olanzapine than with placebo.71,80

#### Neutropenia and Agranulocytosis

White blood cell count was significantly lower in patients treated with quetiapine than in those receiving placebo.66

#### Thyroid Dysfunction

There was no significant difference between quetiapine and placebo for incidence of hypothyroidism or measures of thyroid dysfunction.66,84

#### Seizures

No difference was found in seizure rates between placebo and aripiprazole,46,72 paliperidone,86 or risperidone47

#### Neuroleptic Malignant Syndrome

Two studies reported no incidence of neuroleptic malignant syndrome in either the paliperidone and placebo86 or risperidone and placebo.105

#### Constipation

A meta-analysis of three studies44,47,52 showed that constipation occurred significantly more frequently among patients treated with risperidone than those receiving placebo.

#### Behavioral Adverse Events

The studies assessed a variety of adverse events, including agitation, aggression, and anxiety. No significant differences between the SGA drugs and placebo were observed.

#### Dermatological Events

No significant differences in dermatological adverse events, such as rashes, itching, or dry skin, were reported between placebo and aripiprazole,46,72 risperidone,47,60,68 or ziprasidone.70,85

Strength of evidence grades for key adverse events that were reported by at least one study are provided in Table 37. The strength of evidence was moderate for numerous outcomes: weight gain (aripiprazole, olanzapine, quetiapine, and risperidone), dyslipidemia (quetiapine), extrapyramidal symptoms (aripiprazole and risperidone), prolactin-related events (aripiprazole and olanzapine), and sedation (risperidone and ziprasidone). All of these outcomes favored placebo, except prolactin levels, which were lower with aripiprazole than placebo.

Table 37 Strength of evidence for adverse events: SGAs versus placebo (Key Question 2)

Comparison | Outcome (N studies; N patients) | Strength of Evidence Domains | | | | Strength of Evidence
Comparison | Outcome (N studies; N patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
Aripiprazole vs. placebo | Dyslipidemia (2; 514) | Moderate | Inconsistent | Direct | Precise | Low
Aripiprazole vs. placebo | EPS (4; 859) | Moderate | Consistent | Direct | Precise | Moderate
Aripiprazole vs. placebo | Insulin resistance (3; 816) | Moderate | Consistent | Direct | Imprecise | Low
Aripiprazole vs. placebo | Prolactin-related / sexual AE (3;816) | Moderate | Consistent | Direct | Precise | Moderate
Aripiprazole vs. placebo | Sedation (4; 859) | Moderate | Consistent | Direct | Precise | Low
Aripiprazole vs. placebo | Weight (4; 859) | Moderate | Consistent | Direct | Precise | Moderate
Olanzapine vs. placebo | Dyslipidemia (2; 268) | Moderate | Inconsistent | Direct | Precise | Low
Olanzapine vs. placebo | EPS (3; 232) | Moderate | Inconsistent | Direct | Imprecise | Low
Olanzapine vs. placebo | Insulin resistance (3; 328) | Moderate | Consistent | Direct | Imprecise | Low
Olanzapine vs. placebo | Prolactin-related / sexual AE (2; 268) | Moderate | Consistent | Direct | Precise | Moderate
Olanzapine vs. placebo | Sedation (3; 178) | Moderate | Consistent | Direct | Imprecise | Low
Olanzapine vs. placebo | Weight (4; 339) | Moderate | Consistent | Direct | Precise | Moderate
Paliperidone vs. placebo | Insulin resistance (1; 201) | Moderate | Unknown | Direct | Imprecise | Insufficient
Paliperidone vs. placebo | Weight (1; 201) | Moderate | Unknown | Direct | Imprecise | Insufficient
Quetiapine vs. placebo | Dyslipidemia (3; 538) | Moderate | Consistent | Direct | Imprecise | Low
Quetiapine vs. placebo | EPS (3; 271) | Moderate | Inconsistent | Direct | Imprecise | Low
Quetiapine vs. placebo | Insulin resistance (2; 316) | Moderate | Inconsistent | Direct | Imprecise | Insufficient
Quetiapine vs. placebo | Prolactin-related / sexual AE (5; 587) | Moderate | Consistent | Direct | Imprecise | Low
Quetiapine vs. placebo | Sedation (5; 587) | Moderate | Inconsistent | Direct | Imprecise | Low
Quetiapine vs. placebo | Weight (5; 587) | Moderate | Consistent | Direct | Precise | Moderate
Risperidone vs. placebo | Dyslipidemia (1; 170) | Moderate | Unknown | Direct | Imprecise | Insufficient
Risperidone vs. placebo | EPS (15; 1289) | Moderate | Consistent | Direct | Precise | Moderate
Risperidone vs. placebo | Insulin resistance (2; 330) | Moderate | Consistent | Direct | Imprecise | Insufficient
Risperidone vs. placebo | Prolactin-related / sexual AE (9; 1180) | Moderate | Inconsistent | Direct | Precise | Low
Risperidone vs. placebo | Sedation (13; 1235) | Moderate | Consistent | Direct | Precise | Moderate
Risperidone vs. placebo | Weight (12; 1081) | Moderate | Consistent | Direct | Precise | Moderate
Ziprasidone vs. placebo | EPS (3; 550) | Moderate | Consistent | Direct | Precise | Low
Ziprasidone vs. placebo | Prolactin-related / sexual AE (1; 28) | Moderate | Unknown | Direct | Imprecise | Insufficient
Ziprasidone vs. placebo | Sedation (3; 488) | Moderate | Consistent | Direct | Precise | Moderate
Ziprasidone vs. placebo | Weight (3; 488) | Moderate | Consistent | Direct | Imprecise | Low

AE = adverse event; EPS = extrapyramidal symptom; N = number; ROB = risk of bias; SGA = second-generation antipsychotic

## Key Question 4 Subpopulations

Overall, 36 of the 81 studies analyzed outcomes by various patient and disease characteristics. Nine relevant subgroups were identified a priori: sex, age, race, comorbidities, cotreatment, history of psychosis, duration of illness, duration of treatment, and treatment history. Data on subpopulations are presented separately for each condition and are organized by outcome (i.e., efficacy or harm). Most of the significant correlations were based on single studies. Table 38 through Table 44 outline the type of analysis used, patient and disease variables examined, outcomes, and author conclusions for each study.

Table 38 Differences between pervasive development disorder subpopulations on outcomes

Author, Year Comparison | Type of Analysis | Outcome | Authors' Conclusions
McCracken, 2002^47^ Risperidone vs. placebo | Regression analysis for age, IQ, baseline ABC irritability | Relapse | There was no significant difference in age, IQ and baseline ABC irritability scores between relapsing and non-relapsing patients.
McCracken, 2002^47^ Risperidone vs. placebo | Regression analysis for age, dose, sex, IQ, site, Tanner stage, and the following at baseline: ABC, Child Symptom Inventory, YBOCS, heart rate, BP, weight, initial leptin change | Weight | None of the variables or combinations of the variables listed were predictors of weight gain.
McCracken, 2002^47^ Risperidone vs. placebo | Regression analysis for age, baseline BMI, caloric intake | BMI | There was no significant effect of age, baseline BMI or caloric intake on BMI z-score.
Novaes, 2008^54^ FGA vs. risperidone vs. other SGA vs. FGA+SGA | Subgroup analysis by age, comorbidity (MR), cotreatment (nonpharmacological), duration of treatment, health care setting | Response (CGI–I≤2) | Patients with no MR had a significant greater response than patients with MR. Patients treated with at least one nonpharmacological intervention in addition to the principle treatment had greater clinical improvement than patients with no additional treatment. No significant improvements were observed as a function of age, health care clinic, or duration of treatment.
Perry, 1989^51^ Continuous haloperidol vs. discontinuous haloperidol | Subgroup analysis by age, developmental quotient, baseline rating scores | Severe deterioration (CGI–I difference) | Patients with high baseline CPRS Conduct Problem Factor scores and patients with significant improvement before the antipsychotic withdrawal regimen showed significant deterioration than patients without these variables. All other variables did not predict deterioration.

ABC = Aberrant Behavior Checklist; BMI = body mass index; BP = blood pressure; CGI–I = Clinical Global Impressions–Improvement; CPRS = Children's Psychiatric Rating Scale; FGA = first-generation antipsychotic; IQ = intelligence quotient; MR = mental retardation; SGA = second-generation antipsychotic; YBOCS = Yale-Brown Obsessive Compulsive Scale

Table 39 Differences between ADHD and disruptive behavior disorder subpopulations on outcomes

Author, Year Comparison | Type of Analysis | Outcome | Authors' Conclusions
Aman, 2002^57^ Risperidone vs. placebo | Subgroup analysis by sex | Prolactin | Males had a significantly greater increase in prolactin levels on risperidone than placebo, whereas increase in mean prolactin levels was not significant for females.
Buitelaar, 2001^58^ Risperidone vs. placebo | Subgroup analysis by IQ and use of prior medication | CGI–S, ABC (school) | No significant difference in rating scale change scores between IQ strata (60–69, 70–79, 80–90) or previous use of medication.
Findling, 2000^60^ Risperidone vs. placebo | Regression analysis by age, race, and baseline RAAPP and CGI–S scores | Completion of study | Age, race, baseline RAAPP score, and baseline CGI–S score was not significantly different between completers and noncompleters.
Findling, 2000^60^ Risperidone vs. placebo | Regression analysis by age, race, and baseline RAAPP and CGI–S scores | RAAPP, CPRS | When an adjustment for age was made, no alteration in rating scales scores were observed
Reyes, 2006^61^ Risperidone vs. placebo | Subgroup analysis by sex, age, diagnosis, disease severity | Risk for symptom recurrence | Sex, age, diagnosis and baseline disruptive behavior severity did not affect risk for symptom recurrence.
Reyes, 2006^61^ Risperidone vs. placebo | Subgroup analysis by age | Weight, AE | Weight gain was reported more frequently in children <12 years of age than those ≥12 years; however this trend was not significant. Other AEs were comparable between age groups.
Reyes, 2006^61^ Risperidone vs. placebo | Subgroup analysis by sex | Prolactin | Females experienced greater increase in prolactin levels than males.
Snyder, 2002^62^ Risperidone vs. placebo | Regression analysis by comorbidity, cotreatment, treatment history, condition | NCBRF conduct problem | The efficacy of risperidone was not affected by level of MR, presence of somnolence, ADHD, use of psychostimulants or type of disorder (CD, ODD, DBD–NOS). Conduct problems scores were lower in patients previously treated with risperidone than patients who were risperidone naïve.
Snyder, 2002^62^ Risperidone vs. placebo | Regression analysis by comorbidity, cotreatment, treatment history, condition | Weight | Cotreatment with psychostimulant had no impact on weight. Mean weight increase was similar between patients who were risperidone-naïve and those previously treated.
Snyder, 2002^62^ Risperidone vs. placebo | Regression analysis by comorbidity, cotreatment, treatment history, condition | Prolactin | Risperidone-naïve patients had significantly lower prolactin levels than those previously treated with risperidone at extension study entry.
Snyder, 2002^62^ Risperidone vs. placebo | Regression analysis by comorbidity, cotreatment, treatment history, condition | Sedation | Sedation increased among risperidone-naïve patients, but not among previously treated patients.

ABC = Aberrant Behavior Checklist; ADHD = attention deficit hyperactivity disorder; AE = Adverse Event; CD = conduct disorder; CGI–S = Clinical Global Impressions–Severity; CPRS = Children's Psychiatric Rating Scale; DBD = disruptive behavior disorder; IQ = intelligence quotient; MR = mental retardation; NCBRF = Nisonger Child Behavior Rating Form; NOS = not otherwise specified; ODD = oppositional defiant disorder; RAAPP = Rating of Aggression Against People and/or Property

Table 40 Differences between bipolar disorder subpopulations on outcomes

Author, Year Comparison | Type of Analysis | Outcome | Authors' Conclusions
DelBello, 2009^65^ Quetiapine vs. placebo | Subgroup analysis by inpatient status, site | Symptom rating scales | There was no difference in the change scores on rating scales between inpatient and outpatient participants, and study center.
Findling, 2009^67^ Low- vs. high-dose aripiprazole vs. placebo | Subgroup analysis by sex | Prolactin | Decreases in prolactin levels were more pronounced for males than for females.
Haas, 2009^68^ Low- vs. high-dose risperidone vs. placebo | Subgroup analysis by age | YMRS | Patients ≤12 and >12 years had significantly more improvement with risperidone than placebo.
Haas, 2009^68^ Low- vs. high-dose risperidone vs. placebo | Subgroup analysis by age | AE | The type and rate of AEs were generally similar between risperidone-treated patients ≤12 or >12 years. For the low dose risperidone, patients >12 years experienced slightly higher rates of somnolence and headache.
Haas, 2009^68^ Low- vs. high-dose risperidone vs. placebo | Subgroup analysis by sex, race, diagnosis, or hospitalization | YMRS | Risperidone was consistently more effective than placebo regardless or sex, race, diagnosis, or hospitalization at screening.
NCT00090311, 2008^73^ Low- vs. high dose quetiapine vs. placebo | Subgroup analysis by age, cotreatment | AEs | The most common AEs (increased appetite and tachycardia) occurred more frequently in quetiapine-treated patients in the 10–12 year age group. The incidence of individual common AEs was higher in concomitant psychostimulant users in the high-dose quetiapine group.
Tohen, 2007^71^ Olanzapine vs. placebo | Regression analysis controlling for comorbidities, cotreatment, bipolar subtypes, age of onset, sex | CGI–BP | Current diagnosis of ADHD, number of previous depressive episodes and rapid cycling did not significantly alter the outcome.
Tohen, 2007^71^ Olanzapine vs. placebo | Regression analysis controlling for comorbidities, cotreatment, bipolar subtypes, age of onset, sex | YMRS | There was no significant therapy-by-subgroup interaction on the YMRS for the following subgroups: mania type, rapid cycling, psychosis, ADHD, ODD, or age. Concomitant use of psychostimulants did not differentially affect YMRS scores.
Tohen, 2007^71^ Olanzapine vs. placebo | Regression analysis controlling for comorbidities, cotreatment, bipolar subtypes, age of onset, sex | Prolactin | A greater proportion of males had changes in prolactin levels than females.
Tramontina, 2009^72^ Aripiprazole vs. placebo | Regression analysis controlling for age | YMRS SNAP–IV Weight / BMI | There was no significant difference between patients ≤10 and >10 years of age for any primary outcome measure.

ADHD = attention deficit hyperactivity disorder; AE = Adverse Event; BMI = body mass index; CGI–BP = Clinical Global Impression–bipolar; ODD = oppositional defiant disorder; SNAP–IV = Swanson, Nolan and Pelham Scale–Version IV; YMRS = Young Mania Rating Scale

Table 41 Differences between schizoprenia and related psychoses subpopulations on outcomes

Author, Year Comparison | Type of Analysis | Outcome | Authors' Conclusions
Crocq, 2007^117^ Olanzapine ODT vs. SOT vs. risperidone | Subgroup analysis by sex | Weight | Weight and BMI increase was consistently but not statistically greater in girls than boys in all treatment groups.
Haas, 2009^78^ Low- vs. high-dose risperidone | Subgroup analysis by sex | Prolactin | Mean increases in prolactin levels were greater in females than males.
Haas, 2009^69^ Low- vs. high-dose risperidone | Subgroup analysis by sex | Prolactin | Mean change in prolactin levels were higher in females than males.
Kryzhanovskaya, 2009^80^ Olanzapine vs. placebo | Subgroup analysis by country | Response | The response rate did not differ significantly by country.
NCT00090324, 2008^84^ Low- vs. high-dose quetiapine vs. placebo | Subgroup analysis by geographical region | AE | Incidence of AEs was higher in treatment group over placebo, regardless of region.
Ratzoni, 2002^96^ Haloperidol vs. olanzapine vs. risperidone | Regression analysis by sex, treatment history, illness duration, dose, baseline weight, parental BMI, concern about weight gain, history of diet | Weight | Patients with lower baseline weight showed a significantly greater increase in weight. Paternal, but not maternal, BMI was significantly correlated with patient weight gain. Weight gain ≥7% occurred more frequently among males than females (nonsignificant). History of dieting, previous antipsychotic use, medication dose and duration of illness were not associated with weight gain.
Ratzoni, 2002^96^ Haloperidol vs. olanzapine vs. risperidone | Regression analysis by sex, treatment history, illness duration, dose, baseline weight, parental BMI, concern about weight gain, history of diet | BMI | Among patients who showed concerned about weight gain, males showing an increase in BMI, but females did not.
Sikich, 2003^89^ Haloperidol vs. olanzapine vs. risperidone | Subgroup analysis by age, cotreatment, treatment history, diagnosis, baseline symptom severity | Response | No significant relationship between response status and age, diagnosis, prior antipsychotic exposure or baseline severity of symptoms. Also, there was no significant difference in response rate between patients treated exclusively with antipsychotic, treated with either concomitant antidepressant or mood stabilizer, or both concomitant antidepressant and mood stabilizer.
Spencer, 1994^90^ Haloperidol vs. placebo | Subgroup analysis by age, age of onset, IQ | Global clinical judgments rating | Patients with only mild or moderate improvement tended to be younger, have earlier onset of psychosis, be diagnosed with schizophrenia at a younger age and have a lower IQ.
Woods, 2003^93^ Olanzapine vs. placebo | Subgroup analysis by age, race, IQ, baseline neuropsychological status | Conversion to psychosis | There was no difference between patients who converted to psychosis and those who did not in age, IQ or global neuropsychological status. Race, poor CPT performance and good WAIS–R digit symbol performance predicted conversion to psychosis.
Woods, 2003^93^ Olanzapine vs. placebo | Subgroup analysis by age, race, IQ, baseline neuropsychological status | Time to progression to psychosis | Baseline neurocognitive status was not a significant predictor of time to progression to psychosis.
Woods, 2003^93^ Olanzapine vs. placebo | Regression analysis by history of psychosis and duration of prodromal symptoms | Neurocogni-tive performance | Patients with first-episode psychosis were significantly more impaired than patients at-risk for psychosis on CPT, CVLT, WAIS–R digit symbol, working memory and verbal fluency measures. Cognitive performance was not significantly correlated with length of manifestation of prodromal symptoms.
Wudarsky, 1999^109^ Clozapine vs. haloperidol vs. olanzapine | Subgroup analysis by sex | Prolactin | In patients receiving clozapine, females had significantly elevated prolactin levels than males. There was no significant sex difference in patients receiving haloperidol or olanzapine.

AE = Adverse Event; BMI = body mass index; CPT = Continuous performance task; CVLT = California Verbal Learning Test; IQ = intelligence quotient; ODT = orally disintegrating tablet; SOT = standard oral tablet; WAIS–R = Wechsler Adult Intelligence Scale revised

Table 42 Differences between Tourette syndrome subpopulations on outcomes

Author, Year Comparison | Type of Analysis | Outcome | Authors' Conclusions
Bruggeman, 2001^111^ Pimozide vs. risperidone | Subgroup analysis by age | CGI, GAF, HAM–A, PGI,TSSS, YBOCS | Patients younger than 18 had consistently better scores at endpoint for efficacy measures than patients 18 and older; however, this trend was not significant. Change scores were comparable between groups.
Bruggeman, 2001^111^ Pimozide vs. risperidone | Subgroup analysis by age | Weight | Patients <18 years had more weight gain than patients ≥18 years in the risperidone group, however this was not significant. Weight gain was comparable across age groups in the pimozide-treated patients.
Sallee, 1997^99^ Haloperidol vs. pimozide vs. placebo | Subgroup analysis by sex, Tanner stage | Prolactin | No significant differences were found in prolactin levels by sex or Tanner scores.
Sallee, 1994^100^ Haloperidol vs. pimozide | Regression analysis by comorbidity | CPT task commission and omission errors | Patients with ADHD had significantly higher commission and omission errors than patients without ADHD.

ADHD = attention deficit hyperactivity disorder; CGI = Clinical Global Impressions Scale; CPT = Continuous performance task; GAF = Global Assessment of Functioning; HAM–A = Hamilton Anxiety Rating Scale; PGI = Patient Global Impressions; TSSS = Tourette Symptom Severity Scale; (C)YBOCS = (Children's) Yale-Brown Obsessive Compulsive Scale

Table 43 Differences between behavioral issues subpopulations on outcomes^*^

Author, Year Comparison | Type of Analysis | Outcome | Authors' Conclusions
Bastiaens, 2009^103^ Aripiprazole vs. ziprasidone | Subgroup analysis by sex, age | OAS | Males improved more than females, and patients ≤11 years improved more than patients 12 years or older; however neither trend was significant.
Hellings, 2006^105^ Low- vs. high-dose risperidone | Subgroup analysis by age | ABC irritability | Irritability scores were significantly higher in children than adolescents and adults. There was no significant difference between adolescents and adults.
Hellings, 2006^105^ Low- vs. high-dose risperidone | Subgroup analysis for sex, age, comorbidity, cotreatment, mood disorder | Response | Age and level of MR were significant predictors of response, with poor response in children and patients with severe MR. Sex, concomitant antiseizure medication, and mood disorder were not significant predictors of response.
Hellings, 2006^105^ Low- vs. high-dose risperidone | Subgroup analysis for age | Weight | Children and adolescents had greater weight gain than adults, but the differences between age groups were not significant.
Hellings, 2006^105^ Low- vs. high-dose risperidone | Subgroup analysis for age | Prolactin | Adults had a greater acute increased in prolactin levels than children/ adolescents. Prolactin levels were significantly higher for adults than children/adolescents in the acute phase but not during maintenance.
Khan, 2006^106^ Olanzapine vs. ziprasidone | Subgroup analysis for age | Dose required for symptom reduction | Adolescents (13–17 years) required a significantly higher dose of olanzapine than children (≤12 years). There was no difference between age groups for ziprasidone.
Khan, 2006^106^ Olanzapine vs. ziprasidone | Regression analysis controlling for sex and age | Number of restraints Time in restraint | Age and sex had no impact on differences between the groups for number of restraints or time in restraint after receiving the study medications.

ABC = Aberrant Behavior Checklist; MR = mental retardation; OAS = Overt Aggression Scale

* Behavioral issues included aggression,103,105,106 agitation,106 self-injury,105 or property destruction.105

Table 44 Differences between multiple conditions subpopulations on outcomes

Author, Year Comparison | Type of Analysis | Outcome | Authors' Conclusions
Correll, 2009^112^ Aripiprazole vs. olanzapine vs. quetiapine vs. risperidone | Subgroup analysis by pubertal status | Metabolic changes | Pubertal status was not related to metabolic changes in any of the treatment groups.
Fleischhaker, 2006^114^ Clozapine vs. olanzapine vs. risperidone | Regression analysis by sex, age, cotreatment, treatment history, history of dieting, baseline weight | Weight change | Significant correlation between baseline weight and subsequent weight gain was noted. No strong association between sex and extreme weight gain was found. No significant correlation was found between age, drug history status (naïve vs. previous use), comedications or dieting history and weight measures.
Fraguas, 2008^115^ Olanzapine vs. quetiapine vs. risperidone | Subgroup analysis by sex, age, race, comorbidities, cotreatment, duration of inpatient treatment, treatment history | Weight | Males gained more weight than females, but this trend was not significant. BMI increases were not related to race, age, presence of psychosis, alcohol abuse, cannabis abuse or length of inpatient treatment.
Fraguas, 2008^115^ (continued) | See above | Substantial weight gain (≥0.5 increased in BMI z-score) | Patients receiving cotreatment with antidepressants had significantly less weight gain. Substantial weight gain was not associated with sex, psychosis, antipsychotic-naïve status, lifetime antipsychotic use, length of inpatient treatment, cotreatment with benzodiazepines, alcohol or cannabis abuse, or tobacco use.
Fraguas, 2008^115^ (continued) | See above | At risk for adverse health outcome | A nonsignificant trend showed a higher proportion of males to be at risk for adverse health outcomes than females. Risk for an adverse health outcome was significantly not related to antipsychotic naïve status, total lifetime antipsychotic use, treatment with benzodiazepines, anticholinergics or antidepressants, length of inpatient treatment, psychosis, tobacco use, or alcohol or cannabis abuse.
Friedlander, 2001^118^ Olanzapine vs. risperidone | Subgroup analysis by psychosis | Drug dosage | Patients with psychosis were prescribed significantly higher dosages of risperidone, and nonsignificantly higher dosages of olanzapine, than patients without psychosis.
Friedlander, 2001^118^ Olanzapine vs. risperidone | Subgroup analysis by sex | Neuroleptic-induced movement disorders | All patients who developed neuroleptic-induced movement disorders were female.
Migliardi, 2009^120^ Olanzapine vs. risperidone | Regression analysis controlling for pubertal status, sex, treatment duration | Prolactin | Plasma olanzapine concentrations had a significant effect on prolactin levels in female, but not males. The effect of plasma risperidone concentrations at the end of 3 months was significant only in males but not in females. After adjusting for antipsychotic drug and gender, mean increases in prolactin levels at the end of 3 and 6 months were higher than those at the end of 1 and 12 months. Pubertal status did not have any significant effect on prolactin levels, adjusting for gender and treatment duration.
Saito, 2004^116^ Olanzapine vs. quetiapine vs. risperidone | Subgroup analysis by sex, puberty | Prolactin | There was no significant difference in prolactin levels by gender. Postpubertal females were not significantly different in endpoint prolactin levels compared to all others.

BMI = body mass index

### Pervasive Developmental Disorders

Three studies of pervasive developmental disorders conducted an analysis of outcomes in different subpopulations (Table 38).47,51,54

Three studies found no significant effect of age on response54 or relapse47,51 after treatment with a variety of FGAs and SGAs, including risperidone and haloperidol. One retrospective cohort study54 examined the impact of mental retardation and nonpharmacological cotreatment on response rate. A significantly higher response rate was found in patients with no mental retardation and in patients who received at least one nonpharmacological intervention in addition to the antipsychotic therapies given (various FGAs, various SGAs, risperidone, or a combination of FGAs and SGA).

One RCT47 found no impact of sex or age on weight gain in patients given risperidone.

### ADHD and Disruptive Behavior Disorders

Five studies of ADHD and disruptive behavior disorders conducted an analysis of outcomes in different subpopulations (Table 39).57,58,60-62 All studies compared risperidone and placebo.

Two studies found no effect of age on the Rating of Aggression Against People and/or Property scale,60 CPRS,60 rate of study completion,60 and risk of symptom recurrence.61 In one study, race was not significantly different in patients who completed the study than those who did not.60 Snyder et al.62 found no impact of comorbidities (including mental retardation, ADHD, and secondary diagnosis of disruptive behavior disorders) or cotreatment with psychostimulants on NCBRF conduct problem subscale. Two studies examined the effect of previous treatment on ABC,58 CGI–S,58 and NCBRF conduct problem subscale.62 Risperidone-naïve patients had lower NCBRF conduct problem scores in one study,62 whereas prior treatment had no impact on symptom severity (ABC, CGI–S) in another study.58

Two studies assessed the impact of sex on prolactin levels while on risperidone. Females experienced a greater increase in prolactin levels than males in one study.61 A second study found that males but not females experienced a significant increase in prolactin levels.57 Reyes et al. found no effect of age on total adverse events.61 However, weight gain was more frequent in children younger than 12 years than children older than 12 years (nonsignificant).61 Snyder et al.62 found no impact of cotreatment with psychostimulants or history of previous treatment on weight gain. Risperidone-naïve patients had lower prolactin levels and reported sedation more frequently than patients who were previously treated with risperidone.62

### Bipolar Disorder

Six studies examining bipolar disorder conducted an analysis of patient outcomes in different subpopulations (Table 40).65,67,68,71-73 All studies were placebo-controlled and evaluated SGAs.

Sex, age, and race had no significant impact on YMRS scores in one placebo-controlled RCT comparing risperidone dosing regimens.68 There was no impact of age on YMRS or Swanson, Nolan and Pelham Scale scores in patients treated with aripiprazole.72 Another study71 examined the impact of comorbidities and bipolar subtypes on CGI–BP and YMRS in patients treated with olanzapine. Diagnosis of comorbid ADHD and bipolar diagnostic subtypes did not alter treatment outcomes.71 In addition, concomitant use of psychostimulants had no effect on YMRS scores.71

Two studies assessed the impact of sex on prolactin levels.67,71 Prolactin levels were lower in males than females in one study.67 Greater changes in prolactin levels were reported in males than females in a second study.71 Age had no significant impact on total adverse events68,73 and weight gain measures.72 Adverse events were not affected by cotreatment in one placebo-controlled RCT of quetiapine.73

### Schizophrenia and Related Psychosis

Ten studies examining the efficacy of antipsychotics in patients with schizophrenia and related psychoses conducted an analysis of patient outcomes in different subpopulations (Table 41).69,78,80,84,89,90,93,96,109,117

Three studies examined the impact of age on global clinical judgments rating,90 treatment response,89 and conversion to psychosis.93 Younger patients experienced only mild or moderate improvement on the global clinical judgments rating scale on haloperidol than older patients.90 Age had no impact on response rate or conversion to psychosis. One study93 found that race (African American) predicted conversion to psychosis.

One study89 investigated the effect of antipsychotic monotherapy compared with treatment with an antipsychotic plus concomitant antidepressant and/or mood stabilizers on response rate. The study found no significant difference in response rate between subgroups in patients given haloperidol, olanzapine, or risperidone. Woods et al.93 analyzed the effect of history of psychosis and duration of prodromal symptoms on neurocognitive performance in olanzapine-treated patients. Patients with first-episode psychosis were significantly more impaired on neurocognitive function test than patients at risk for psychosis. Two studies found no impact of illness duration on global clinical judgments rating90 or neurocognitive performance.93

Five studies assessed the effect of sex on outcomes including weight gain,96,117 BMI,96 or prolactin levels.69,78,109 Girls experienced greater weight and BMI increases than boys in one study.96 In another study, weight gain greater than 7 percent from baseline occurred more frequently in males than in females.117 Findings in both studies were not significant. Prolactin levels were significantly higher in females than males in patients given clozapine109 or risperidone.69,78 One study found no impact of illness duration or previous antipsychotic use on weight gain.96

### Tourette Syndrome

Three studies on Tourette syndrome conducted an analysis of patient outcomes in different subpopulations (Table 42).99,100,111

One study111 investigated the effect of age on various disease-specific and nonspecific outcomes (i.e., CGI, Global Assessment of Functioning, Hamilton Anxiety Rating Scale, Patient Global Impressions, Tourette Symptom Severity Scale, and YBOCS) in pimozide- and risperidone-treated patients. Patients younger than 18 years of age had better efficacy scores at endpoint than patients older than 18 years, but the differences were not significant. In another study evaluating haloperidol and pimozide, Sallee et al.100 assessed the effect of ADHD comorbidity on cognitive functioning. Patients with comorbid ADHD had a significantly higher error rate on continuous performance tasks than patients without ADHD.100

One placebo-controlled crossover RCT99 comparing haloperidol with pimozide found no significant difference in prolactin levels by sex or Tanner stage. Bruggeman et al.111 examined the effect of age on weight gain in pimozide- and risperidone-treated patients. Patients younger than 18 years of age experienced more weight gain than patients older than 18 years (nonsignificant).

### Behavioral Issues

Three studies that examined patients with behavioral issues conducted an analysis of outcomes in different subpopulations (Table 43).103,105 106 Patients exhibited aggression,103,105,106 agitation,106 self-injury,105 or property destruction.105 Studies only evaluated SGAs.

Three studies investigated the effect of sex on outcomes including OAS,103 response,105 number of restraints, and time in restraints.106 Aggression decreased more in males than females as measured using OAS, but the difference was not significant. Sex was not a significant predictor of response, number of restraints, or time in restraints.

Three studies investigated the effect of age on ABC–I,105 OAS,103 response,105 dose required for symptom reduction,106 and number of restraints and time in restraints.106 Children experienced more irritability (measured on ABC–I) than adolescents and adults.105 In addition, children ≤11 years of age showed decreased aggression than patients ≥12 years of age.103 In another study, adolescents required a significantly higher dosage of olanzapine for reduction or agitation or aggression; however, age had no impact on number of restraints or time in restraints in this study.106 One study105 also investigated the impact of comorbid mental retardation, mood disorder, and cotreatment with antiseizure medications on response. Patients with severe mental retardation showed poorer response than patients with mild mental retardation, whereas mood disorders and concomitant antiseizure medications were not significant predictors of response.

One crossover RCT comparing two doses of risperidone found that children experienced greater weight gain and lower prolactin levels than adolescents and adults.105

### Multiple Conditions

Six cohort studies examining patients with a variety of psychiatric or behavioral diagnoses conducted an analysis of outcomes in different subpopulations (Table 44).112,114-116,118,120 All six studies evaluated SGAs.

The effect of sex was assessed on weight gain,114,115 BMI,114,115 neuroleptic-induced movement disorders,118 risk for adverse health outcomes,115 and prolactin.116,120 Males gained more weight than females in one study, but the difference was not significant.115 Two studies found no effect of age on weight gain measures including BMI.114,115

Sex had no impact on substantial weight gain in two studies114,115 or BMI in one study.115 All patients who developed antipsychotic-induced movement disorders were female.118 Males tended to be at risk of adverse health outcomes more frequently than females.115 Females had significantly higher prolactin levels than males in one study.120 In contrast, sex had no impact on prolactin level in a second study.116

Race had no impact on BMI in one study.115 The study also examined the effect of comorbidities, including psychosis and substance abuse, on weight gain and risk for adverse health outcomes. These outcomes were not related to presence of psychosis, length of inpatient treatment, tobacco use, alcohol abuse, or cannabis abuse.115 One study found psychosis to be associated with high drug dose.118

Cotreatment with antidepressants resulted in significantly less weight gain than monotherapy in one study,115 whereas a second study found no effect of comedications on weight gain.114 Risk for adverse health outcomes was not affected by cotreatments.115 Two studies assessed the effect of previous antipsychotic treatment on weight gain114,115 and risk of adverse health outcomes;115 no significant effect was observed. Three studies found no impact of puberty or pubertal status on metabolic changes,112 or prolactin.116,120