# References

1 Zito J, Safer D, dosReis S, et al. Trends in the prescribing of psychotropic medications to preschoolers. JAMA. 2000;238(8):1025-30. [pmid: 10697062].
2 Zito JM, Safer DJ, dosReis S, et al. Psychotropic practice patterns for youth: a 10-year perspective. Arch Pediatr Adolesc Med. 2003;157(1):17-25. [pmid: 12517190].
3 Zito JM, Safer DJ, de Jong-van den Berg LT, et al. A three-country comparison of psychotropic medication prevalence in youth. Child Adolesc Psychiatry Ment Health. 2008;2(1):26-33. [pmid: 18817536].
4 Zito JM, Safer DJ, Sai D, et al. Psychotropic medication patterns among youth in foster care. Pediatrics. 2008;121(1):e157-e163. [pmid: 18166534].
5 Pathak S, Arszman SP, Danielyan A, et al. Psychotropic utilization and psychiatric presentation of hospitalized very young children. J Child Adolesc Psychopharmacol. 2004;14(3):433-42. [pmid: 15650500].
6 Jensen PS, Buitelaar J, Pandina GJ, et al. Management of psychiatric disorders in children and adolescents with atypical antipsychotics: a systematic review of published clinical trials. Eur Child Adolesc Psychiatry. 2007;16(2):104-20. [pmid: 17075688].
7 Zito JM, Derivan AT, Kratochvil CJ, et al. Off-label psychopharmacologic prescribing for children: history supports close clinical monitoring. Child Adolesc Psychiatry Ment Health. 2008;2(1):24-34. [pmid: 18793403].
8 Baird G, Simonoff E, Pickles A, et al. Prevalence of disorders of the autism spectrum in a population cohort of children in south Thames: the Special Needs and Autism Project (SNAP). Lancet. 2006;368:210-5. [pmid: 16844490].
9 Costello DJ, Foley DL, Angold A. 10-year research update review: the epidemiology of child and adolescent psychiatric disorders: developmental epidemiology. J Am Acad Child Adolesc Psychiatry. 2006;45:8-25. [pmid: 16327577].
10 Leibenluft E, Rich BA. Pediatric bipolar disorder. Annu Rev Clin Psychol. 2008;4:163-87. [pmid: 17716034].
11 Remschmidt H, Theisen RM. Schizophrenia and related disorders in children and adolescents. J Neural Transm Suppl. 2005;69:121-41. [pmid: 16355606].
12 Lombroso PJ, Scahill LD, Chappell PB, et al. Tourette's syndrome: a multigenerational neuropsychiatric disorder. Adv Neurol. 1995;65:305-18. [pmid: 7872149].
13 Piacentini J, Bergman RL. Obsessive-compulsive disorder in children. Psychiatr Clin North Am. 2000;23:519-33. [pmid: 10986725].
14 Varley C, Smith C. Anxiety disorders in the child and teen. Pediatr Clin North Am. 2003;50:1107-38. [pmid: 14558683].
15 American Psychiatric Association. Diagnostic and statistical manual of mental disorders. fourth edition. Text Revisions. Washington, DC. American Psychiatric Association. 2000.
16 Gillberg C, Harrington R, Steinhausen HC. A clinician's handbook of child and adolescent psychiatry. Cambridge. Cambridge University Press. 2006.
17 Aman MG, Singh NN, Stewart AW, et al. The aberrant behavior checklist: a behavior rating scale for the assessment of treatment effects. Am J Ment Defic. 1985;89(5):485-91. [pmid: 3993694].
18 Hughes CW, Rintelmann J, Emslie GJ, et al. A revised anchored version of the BPRS-C for childhood psychiatric disorders. J Child Adolesc Psychopharmacol. 2001;11(1):77-93. [pmid: 11322749].
19 Lachar D, Randle SL, Harper RA, et al. The brief psychiatric rating scale for children (BPRS-C): validity and reliability of an anchored version. J Am Acad Child Adolesc Psychiatry. 2001;40(3):333-40. [pmid: 11288775].
20 Poznanski EO, Grossman JA, Buchsbaum Y, et al. Preliminary studies of the reliability and validity of the children's depression rating scale. J Am Acad Child Psychiatry. 1984;23(2):191-7. [pmid: 6715741].
21 Hodges K. Children's global assessment scale (CGAS). Rush AJ, First M, Backer D, editors. Handbook of psychiatric measures. 1st ed. Washington, DC. American Psychiatric Association. 2000:363-7.
22 Guy W. Early Clinical Drug Evaluation Unit (ECDEU) Assessment manual for psychopharmacology. Rockville, MD. Department of Health, Education and Welfare. 1976.
23 Rush AJ, Pincus HA, First MB, et al. Handbook of psychiatric measures. Washington, DC. American Psychiatric Association. 2000.
24 Aman MG, Tasse MJ, Rojahn J, et al. The Nisonger CBRF: a child behavior rating form for children with developmental disabilities. Res Dev Disabil. 1996;17(1):41-57. [pmid: 8750075].
25 Yudofsky SC, Silver JM, Jackson W, et al. The Overt Aggression Scale for the objective rating of verbal and physical aggression. Am J Psychiatry. 1986;143(1):35-9. [pmid: 3942284].
26 Kay SR, Fiszbein A, Opler LA. The positive and negative syndrome scale (PANSS) for schizophrenia. Schizophr Bull. 1987;13(2):261-76. [pmid: 3616518].
27 Young RC, Biggs JT, Ziegler VE, et al. A rating scale for mania: reliability, validity and sensitivity. Br J Psychiatry. 1978;133:429-35. [pmid: 728692].
28 Lane RD, Glazer WM, Hansen TE, et al. Assessment of tardive dyskinesia using the abnormal involuntary movement scale. J Nerv Ment Dis. 1985;173(6):353-7. [pmid: 3998720].
29 Barnes TR. A rating scale for drug-induced akathisia. Br J Psychiatry. 1989;154:672-6. [pmid: 2574607].
30 Chouinard G, Ross-Chouinard A, Annable L, et al. Extrapyramidal Symptom Rating Scale. Can J Neurol Sci. 1980;7:233-4.
31 Chouinard G, Margolese HC. Manual for the extrapyramidal symptom rating scale (ESRS). Schizophr Res. 2005;76(2–3):247-65. [pmid: 15949657].
32 Simpson GM, Angus JW. A rating scale for extrapyramidal side effects. Acta Psychiatr Scand Suppl. 1970;212:11-9. [pmid: 4917967].
33 Higgins J, Green S. Cochrane handbook for systematic reviews of interventions version 5.0.1. [updated September 2008]. The Cochrane Collaboration. 2008.
34 Sismondo S. Pharmaceutical company funding and its consequences: a qualitative systematic review. Contemporary Clinical Trials. 2008;29:109-13. [pmid: 17919992].
35 Wells G, Shea B, O'Connell N, et al. The Newcastle-Ottawa Scale for assessing the quality of nonrandomized studies in meta-analyses. Ottawa. Department of Epidemiology and Community Medicine, University of Ottawa. 2009.
36 Cho M, Bero L. The quality of drug studies published in symposium proceedings. Ann Int Med. 1996;124:185-9.
37 Correll CU, Penzner JB, Parikh UH, et al. Recognizing and monitoring adverse events of second-generation antipsychotics in children and adolescents. Child Adolesc Psychiatr Clin N Am. Jan. 2006;15(1):177-206. [pmid: 16321730].
38 Gartlehner G, Hansen RA, Nissman D, et al. A simple and valid tool distinguished efficacy from effectiveness studies. J Clin Epi. 2006;59(10):1040-8.
39 Owens D, Lohr K, Atkins D, et al. Grading the strength of a body of evidence when comparing medical interventions: Agency for Healthcare Research and Quality and the Effective Health Care Program; AHRQ series paper 5. J Clin Epi. 2010;63(5):513-23.
40 Higgins J, Thompson S. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539-58. [pmid: 12111919].
41 Deeks J, Altman D, Bradburn M. Statistical methods for examining heterogeneity and combining results from several studies in meta-analysis. Egger M, Davey Smith G, Altman DG, editors. Systematic review in health care: meta-analysis in context. 2nd ed. London. BMJ Publishing Group. 2001:285-312.
42 Delbello MP, Versavel M, Ice K, et al. Tolerability of oral ziprasidone in children and adolescents with bipolar mania, schizophrenia, or schizoaffective disorder. J Child Adolesc Psychopharmacol. 2008;18(5):491-9. [pmid: 18928413].
43 Hollander E, Wasserman S, Swanson EN, et al. A double-blind placebo-controlled pilot study of olanzapine in childhood/adolescent pervasive developmental disorder. J Child Adolesc Psychopharmacol. 2006;16(5):541-8. [pmid: 17069543].
44 Luby J, Mrakotsky C, Stalets MM, et al. Risperidone in preschool children with autistic spectrum disorders: an investigation of safety and efficacy. J Child Adolesc Psychopharmacol. 2006;16(5):575-87. [pmid: 17069546].
45 Malone RP, Cater J, Sheikh RM, et al. Olanzapine versus haloperidol in children with autistic disorder: an open pilot study. J Am Acad Child Adolesc Psychiatry. 2001;40(8):887-94. [pmid: 11501687].
46 Marcus RN, Owen R, Kamen L, et al. A placebo-controlled, fixed-dose study of aripiprazole in children and adolescents with irritability associated with autistic disorder. J Am Acad Child Adolesc Psychiatry. Nov. 2009;48(11):1110-9. [pmid: 19797985].
47 McCracken JT, McGough J, Shah B, et al. Risperidone in children with autism and serious behavioral problems. N Engl J Med. 2002;347(5):314-21. [pmid: 12151468].
48 Miral S, Gencer O, Inal-Emiroglu FN, et al. Risperidone versus haloperidol in children and adolescents with AD : a randomized, controlled, double-blind trial. Eur Child Adolesc Psychiatry. 2008;17(1):1-8. [pmid: 18080171].
49 Nagaraj R, Singhi P, Malhi P. Risperidone in children with autism: randomized, placebo-controlled, double-blind study. J Child Neurol. 2006;21(6):450-5. [pmid: 16948927].
50 NCT00576732. Risperidone in the treatment of children and adolescents with autistic disorder: A double-blind, placebo-controlled study of efficacy and safety, followed by an open-label extension study of safety. Clinical study report synopsis. 2010. http://download.veritasmedicine.com/PDF/CR014740_CSR.pdf. March 15, 2011.
51 Perry R, Campbell M, Adams P, et al. Long-term efficacy of haloperidol in autistic children: continuous versus discontinuous drug administration. J Am Acad Child Adolesc Psychiatry. 1989;28(1):87-92. [pmid: 2914841].
52 Shea S, Turgay A, Carroll A, et al. Risperidone in the treatment of disruptive behavioral symptoms in children with autistic and other pervasive developmental disorders. Pediatrics. 2004;114(5):e634-e641. [pmid: 15492353].
53 Troost PW, Lahuis BE, Steenhuis MP, et al. Long-term effects of risperidone in children with autism spectrum disorders: a placebo discontinuation study. J Am Acad Child Adolesc Psychiatry. 2005;44(11):1137-44. [pmid: 16239862].
54 Novaes CM, Ponde MP, Freire AC. Control of psychomotor agitation and aggressive behavior in patients with autistic disorder: a retrospective chart review. Arq Neuro-Psiquiatr. 2008;66(3B):646-51.
55 Armenteros JL, L J, D. Risperidone augmentation for treatment-resistant aggression in attention-deficit/hyperactivity disorder: a placebo-controlled pilot study. J Am Acad Child Adolesc Psychiatry. 2007;(5):558-65. [pmid: 17450046].
56 Aman MG, Hollway JA, Leone S, et al. Effects of risperidone on cognitive-motor performance and motor movements in chronically medicated children. Res Dev Disabil. 2009;30(2):386-96. [pmid: 18768293].
57 Aman MG, De Smedt G, Derivan A, et al. Double-blind, placebo-controlled study of risperidone for the treatment of disruptive behaviors in children with subaverage intelligence. Am J Psychiatry. 2002;159(8):1337-46. [pmid: 12153826].
58 Buitelaar JK, van der Gaag RJ, Cohen-Kettenis P, et al. A randomized controlled trial of risperidone in the treatment of aggression in hospitalized adolescents with subaverage cognitive abilities. J Clin Psychiatry. 2001;62(4):239-48. [pmid: 11379837].
59 Connor DF, McLaughlin TJ, Jeffers-Terry M. Randomized controlled pilot study of quetiapine in the treatment of adolescent conduct disorder. J Child Adolesc Psychopharmacol. 2008;18(2):140-56. [pmid: 18439112].
60 Findling RL, McNamara NK, Branicky LA, et al. A double-blind pilot study of risperidone in the treatment of conduct disorder. J Am Acad Child Adolesc Psychiatry. 2000;39(4):509-16. [pmid: 10761354].
61 Reyes M, Buitelaar J, Toren P, et al. A randomized, double-blind, placebo-controlled study of risperidone maintenance treatment in children and adolescents with disruptive behavior disorders. Am J Psychiatry. 2006;163(3):402-10. [pmid: 16513860].
62 Snyder R, Turgay A, Aman M, et al. Effects of risperidone on conduct and disruptive behavior disorders in children with subaverage IQs. J Am Acad Child Adolesc Psychiatry. 2002;41(9):1026-36. [pmid: 12218423].
63 Biederman J, Mick E, Hammerness P, et al. Open-label, 8-week trial of olanzapine and risperidone for the treatment of bipolar disorder in preschool-age children. Biol Psychiatry. 2005;58(7):589-94. [pmid: 16239162].
64 Biederman J, Mick E. Comparative open-label trial of atypical neuroleptics in children and adolescents with bipolar disorder. Eur Neuropsychopharmacol. 2004;14:S211-2.
65 Delbello MP, Chang K, Welge JA, et al. A double-blind, placebo-controlled pilot study of quetiapine for depressed adolescents with bipolar disorder. Bipolar Disord. 2009;11(5):483-93. [pmid: 19624387].
66 Delbello MP, Schwiers ML, Rosenberg HL, et al. A double-blind, randomized, placebo-controlled study of quetiapine as adjunctive treatment for adolescent mania. J Am Acad Child Adolesc Psychiatry. 2002;41(10):1216-23. [pmid: 12364843].
67 Findling RL, Nyilas M, Forbes RA, et al. Acute treatment of pediatric bipolar I disorder, manic or mixed episode, with aripiprazole: a randomized, double-blind, placebo-controlled study. J Clin Psychiatry. 2009;70(10):1441-51. [pmid: 19906348].
68 Haas M, Delbello MP, Pandina G, et al. Risperidone for the treatment of acute mania in children and adolescents with bipolar disorder: a randomized, double-blind, placebo-controlled study. Bipolar Disord. 2009;11(7):687-700. [pmid: 19839994].
69 Haas M, Unis AS, Armenteros J, et al. A 6-week, randomized, double-blind, placebo-controlled study of the efficacy and safety of risperidone in adolescents with schizophrenia. J Child Adolesc Psychopharmacol. 2009;19(6):611-21. [pmid: 20035579].
70 NCT00257166. Four week, double-blind, placebo controlled phase III trial evaluating the efficacy, safety and pharmacokinetics of flexible doses of oral ziprasidone in children and adolescents with bipolar I disorder (manic or mixed). PhRMA Web Synopsis. 2008. www.clinicalstudyresults.org/documents/company-study_4386_0.pdf. March 15, 2011.
71 Tohen M, Kryzhanovskaya L, Carlson G, et al. Olanzapine versus placebo in the treatment of adolescents with bipolar mania. Am J Psychiatry. 2007;164(10):1547-56. [pmid: 17898346].
72 Tramontina S, Zeni CP, Ketzer CR, et al. Aripiprazole in children and adolescents with bipolar disorder comorbid with attention-deficit/hyperactivity disorder: a pilot randomized clinical trial. J Clin Psychiatry. 2009;70(5):756-64. [pmid: 19389329].
73 NCT00090311. A 3-week, multicenter, randomized, double-blind, parallel-group, placebo-controlled study of the efficacy and safety of quetiapine fumarate immediate release tablets in daily doses of 400 mg and 600 mg compared with placebo in the treatment of children and adolescents with bipolar I mania. Clinical study report synopsis. 2006. www.astrazenecaclinicaltrials.com/drug-products/drugproducts/?itemId=8543609. March 15, 2011.
74 Arango C, Robles O, Parellada M, et al. Olanzapine compared to quetiapine in adolescents with a first psychotic episode. Eur Child Adolesc Psychiatry. 2009;18(7):418-28. [pmid: 19198920].
75 Berger GE, Proffitt TM, McConchie M, et al. Dosing quetiapine in drug-naive first-episode psychosis: a controlled, double-blind, randomized, single-center study investigating efficacy, tolerability, and safety of 200 mg/day vs. 400 mg/day of quetiapine fumarate in 141 patients aged 15 to 25 years. J Clin Psychiatry. 2008;69(11):1702-14. [pmid: 19036233].
76 de Haan L, van Bruggen M, Lavalaye J, et al. Subjective experience and D2 receptor occupancy in patients with recent-onset schizophrenia treated with low-dose olanzapine or haloperidol: a randomized, double-blind study. Am J Psychiatry. 2003;160(2):303-9. [pmid: 12562577].
77 Findling RL, Robb A, Nyilas M, et al. A multiple-center, randomized, double-blind, placebo-controlled study of oral aripiprazole for treatment of adolescents with schizophrenia. Am J Psychiatry. 2008;165(11):1432-41. [pmid: 18765484].
78 Haas M, Eerdekens M, Kushner S, et al. Efficacy, safety and tolerability of two dosing regimens in adolescent schizophrenia: double-blind study. Br J Psychiatry. 2009;194(2):158-64. [pmid: 19182179].
79 Jensen JB, Kumra S, Leitten W, et al. A comparative pilot study of second-generation antipsychotics in children and adolescents with schizophrenia-spectrum disorders. J Child Adolesc Psychopharmacol. 2008;18(4):317-26. [pmid: 18759641].
80 Kryzhanovskaya L, Schulz SC, McDougle C, et al. Olanzapine versus placebo in adolescents with schizophrenia: a 6-week, randomized, double-blind, placebo-controlled trial. J Am Acad Child Adolesc Psychiatry. 2009;48(1):60-70. [pmid: 19057413].
81 Kumra S, Kranzler H, Gerbino-Rosen G, et al. Clozapine and “high-dose” olanzapine in refractory early-onset schizophrenia: a 12-week randomized and double-blind comparison. Biol Psychiatry. 2008;63(5):524-9. [pmid: 17651705].
82 Kumra S, Frazier JA, Jacobsen LK, et al. Childhood-onset schizophrenia: a double-blind clozapine-haloperidol comparison. Arch Gen Psychiatry. 1996;53(12):1090-7. [pmid: 8956674].
83 Mozes T, Ebert T, Michal SE, et al. An open-label randomized comparison of olanzapine versus risperidone in the treatment of childhood-onset schizophrenia. J Child Adolesc Psychopharmacol. 2006;16(4):393-403. [pmid: 16958565].
84 NCT00090324. A 6-week, international, multicenter, randomized, double-blind, parallel-group, placebo-controlled, phase IIIb study of the efficacy and safety of quetiapine fumarate immediate-release tablets in daily doses of 400 mg and 800 mg compared with placebo in the treatment of adolescents with schizophrenia. Clinical study report synopsis. 2008. www.astrazenecaclinicaltrials.com/search/?itemId=8543604. March 15, 2011.
85 NCT00257192. Six week, double-blind, placebo controlled phase III trial evaluating the efficacy, safety and pharmacokinetics of flexible doses of oral ziprasidone in adolescent subjects with schizophrenia. PhRMA Web Synopsis. 2010. www.clinicalstudyresults.org/documents/company-study_9021_0.pdf. March 15, 2011.
86 NCT00518323. A randomized, multicenter, double-blind, weight-based, fixed-dose, parallel-group, placebo-controlled study of the efficacy and safety of extended release paliperidone for the treatment of schizophrenia in adolescent subjects, 12 to 17 years of age. Johnson & Johnson Pharmaceutical Research & Development. 2009. http://download.veritasmedicine.com/PDF/CR002368_CSR.pdf. March 15, 2011.
87 Shaw P, Sporn A, Gogtay N, et al. Childhood-onset schizophrenia: a double-blind, randomized clozapine-olanzapine comparison. Arch Gen Psychiatry. 2006;63(7):721-30. [pmid: 16818861].
88 Sikich L, Frazier JA, McClellan J, et al. Double-blind comparison of first- and second-generation antipsychotics in early-onset schizophrenia and schizo-affective disorder: findings from the treatment of early-onset schizophrenia spectrum disorders (TEOSS) study. Am J Psychiatry. 2008;165(11):1420-31. [pmid: 18794207].
89 Sikich L, Hamer RM, Bashford RA, et al. A pilot study of risperidone, olanzapine, and haloperidol in psychotic youth: a double-blind, randomized, 8-week trial. Neuropsychopharmacology. 2004;29(1):133-45. [pmid: 14583740].
90 Spencer EK, Campbell M. Children with schizophrenia: diagnosis, phenomenology, and pharmacotherapy. [review]. Schizophr Bull. 1994;20(4):713-25. [pmid: 7701278].
91 Swadi HS, Craig BJ, Pirwani NZ, et al. A trial of quetiapine compared with risperidone in the treatment of first onset psychosis among 15-to 18-year-old adolescents. Int Clin Psychopharmacol. 2010;25(1):1-6. [pmid: 19809337].
92 van Bruggen J, Tijssen J, Dingemans P, et al. Symptom response and side-effects of olanzapine and risperidone in young adults with recent onset schizophrenia. Int Clin Psychopharmacol. 2003;18(6):341-6. [pmid: 14571154].
93 Woods SW, Breier A, Zipursky RB, et al. Randomized trial of olanzapine versus placebo in the symptomatic acute treatment of the schizophrenic prodrome. Biol Psychiatry. 2003;54(4):453-64. [pmid: 12915290].
94 Yen YC, Lung FW, Chong MY. Adverse effects of risperidone and haloperidol treatment in schizophrenia. Prog Neuropsychopharmacol Biol Psychiatry. 2004;28(2):285-90. [pmid: 14751424].
95 Kumra S, Jacobsen LK, Lenane M, et al. Childhood-onset schizophrenia: an open-label study of olanzapine in adolescents. J Am Acad Child Adolesc Psychiatry. 1998;37(4):377-85. [pmid: 9549958].
96 Ratzoni G, Gothelf D, Brand-Gothelf A, et al. Weight gain associated with olanzapine and risperidone in adolescent patients: a comparative prospective study. J Am Acad Child Adolesc Psychiatry. Mar. 2002;41(3):337-43. [pmid: 11886029].
97 Gilbert DL, Batterson JR, Sethuraman G, et al. Tic reduction with risperidone versus pimozide in a randomized, double-blind, crossover trial. J Am Acad Child Adolesc Psychiatry. 2004;43(2):206-14. [pmid: 14726728].
98 Sallee FR, Kurlan R, Goetz CG, et al. Ziprasidone treatment of children and adolescents with Tourette's syndrome: a pilot study. J Am Acad Child Adolesc Psychiatry. 2000;39(3):292-9. [pmid: 10714048].
99 Sallee FR, Nesbitt L, Jackson C, et al. Relative efficacy of haloperidol and pimozide in children and adolescents with Tourette's disorder. Am J Psychiatry. 1997;154(8):1057-62. [pmid: 9247389].
100 Sallee FR, Sethuraman G, Rock CM. Effects of pimozide on cognition in children with Tourette syndrome: interaction with comorbid attention deficit hyperactivity disorder. Acta Psychiatr Scand. 1994;90(1):4-9. [pmid: 7976448].
101 Scahill L, Leckman JF, Schultz RT, et al. A placebo-controlled trial of risperidone in Tourette syndrome. Neurology. 2003;60(7):1130-5. [pmid: 12682319].
102 Sehgal N, the Tourette Syndrome Study Group. Short-term versus longer term pimozide therapy in Tourette's syndrome: a preliminary study. Neurology. 1999;52(4):874-7. [pmid: 10078748].
103 Bastiaens L. A non-randomized, open study with aripiprazole and ziprasidone for the treatment of aggressive behavior in youth in a community clinic. Community Ment Health J. Feb. 2009;45(1):73-7. [pmid: 18597173].
104 van Bellinghen M, de Troch C. Risperidone in the treatment of behavioral disturbances in children and adolescents with borderline intellectual functioning: a double-blind, placebo-controlled pilot trial. J Child Adolesc Psychopharmacol. 2001;11(1):5-13. [pmid: 11322745].
105 Hellings JA, Zarcone JR, Reese RM, et al. A crossover study of risperidone in children, adolescents and adults with mental retardation. J Autism Dev Disord. 2006;36(3):401-11. [pmid: 16596465].
106 Khan SS, Mican LM. A naturalistic evaluation of intramuscular ziprasidone versus intramuscular olanzapine for the management of acute agitation and aggression in children and adolescents. J Child Adolesc Psychopharmacol. 2006;16(6):671-7. [pmid: 17201611].
107 Hrdlicka M, Zedkova I, Blatny M, et al. Weight gain associated with atypical and typical antipsychotics during treatment of adolescent schizophrenic psychoses: a retrospective study. Neuroendocrinol Lett. 2009;30(2):256-61. [pmid: 19675512].
108 Schulz E, Fleischhaker C, Remschmidt HE. Correlated changes in symptoms and neurotransmitter indices during maintenance treatment with clozapine or conventional neuroleptics in adolescents and young adults with schizophrenia. J Child Adolesc Psychopharmacol. 1996;6(2):119-31. [pmid: 9231304].
109 Wudarsky M, Nicolson R, Hamburger SD, et al. Elevated prolactin in pediatric patients on typical and atypical antipsychotics. J Child Adolesc Psychopharmacol. 1999;9(4):239-45. [pmid: 10630453].
110 Gothelf D, Falk B, Singer P, et al. Weight gain associated with increased food intake and low habitual activity levels in male adolescent schizophrenic inpatients treated with olanzapine. Am J Psychiatry. 2002;159(6):1055-7. [pmid: 12042200].
111 Bruggeman R, van der Linden C, Buitelaar JK, et al. Risperidone versus pimozide in Tourette's disorder: a comparative double-blind parallel-group study. J Clin Psychiatry. 2001;62(1):50-6. [pmid: 11235929].
112 Correll CU, Manu P, Olshanskiy V, et al. Cardiometabolic risk of second-generation antipsychotic medications during first-time use in children and adolescents. JAMA. 2009;302(16):1765-73. [pmid: 19861668].
113 Alacqua M, Trifiro G, Arcoraci V, et al. Use and tolerability of newer antipsychotics and antidepressants: a chart review in a paediatric setting. Pharm World Sci. 2008;30(1):44-50. [pmid: 17588130].
114 Fleischhaker C, Heiser P, Hennighausen K, et al. Clinical drug monitoring in child and adolescent psychiatry: side effects of atypical neuroleptics. J Child Adolesc Psychopharmacol. 2006;16(3):308-16. [pmid: 16768638].
115 Fraguas D, Merchan-Naranjo J, Laita P, et al. Metabolic and hormonal side effects in children and adolescents treated with second-generation antipsychotics. J Clin Psychiatry. 2008;69(7):1166-75. [pmid: 18588363].
116 Saito E, Correll CU, Gallelli K, et al. A prospective study of hyperprolactinemia in children and adolescents treated with atypical antipsychotic agents. J Child Adolesc Psychopharmacol. 2004;14(3):350-8. [pmid: 15650492].
117 Crocq MA, Guillon MS, Bailey PE, et al. Orally disintegrating olanzapine induces less weight gain in adolescents than standard oral tablets. Eur Psychiatry. 2007;22(7):453-4. [pmid: 17761403].
118 Friedlander R, Lazar S, Klancnik J. Atypical antipsychotic use in treating adolescents and young adults with developmental disabilities. Can J Psychiatr Rev Canad Psychiatr. 2001;46(8):741-5.
119 Jefferson AM, Markowitz JS, Brewerton TD. Atypical antipsychotics. J Am Acad Child Adolesc Psychiatry. 1998;37(12):1243-4. [pmid: 9847493].
120 Migliardi G, Spina E, D'Arrigo C, et al. Short- and long-term effects on prolactin of risperidone and olanzapine treatments in children and adolescents. Prog Neuropsychopharmacol Biol Psychiatry. 2009;33(8):1496-501. [pmid: 19706318].
121 Findling RL, Kauffman RE, Sallee FR, et al. Tolerability and pharmacokinetics of aripiprazole in children and adolescents with psychiatric disorders: an open-label, dose-escalation study. J Clin Psychopharmacol. 2008;28(4):441-6. [pmid: 18626272].
122 NCT00796081. Open-label study to evaluate the safety and pharmacokinetics of single- and multiple-dose extended-release paliperidone in pediatric subjects (10 to 17 years of age) with schizophrenia, schizoaffective disorder, or schizophreniform disorder. Johnson & Johnson Pharmaceutical Research & Development. 2007. http://download.veritasmedicine.com/PDF/CR002371_CSR.pdf. March 15, 2011.
123 McGlashan TH, Zipursky RB, Perkins D, et al. Randomized, double-blind trial of olanzapine versus placebo in patients prodromally symptomatic for psychosis. Am J Psychiatry. 2006;(5):790-9. [pmid: 16648318].
124 Bekelman JE, Li Y, Gross CP. Scope and impact of financial conflicts of interest in biomedical research: a systematic review. JAMA. 2003;289(4):454-69. [pmid: 12533125].
125 Greenhill LL, Vitiello B, Fisher P, et al. Comparison of increasingly detailed elicitation methods for the assessment of adverse events in pediatric psychopharmacology. J Am Acad Child Adolesc Psychiatry. 2004;43(12):1488-96. [pmid: 15564818].
126 Bostic JQ, Rho Y. Target-symptom psychoparhmacology: Between the forest and the trees. Child Adolesc Psychiatrc Clin N Am. 2006;15(1):289-302.
127 Moher D, Schulz KF, Altman DG, et al. The CONSORT statement: Revised recommendations for improving the quality of reports of parallel group randomized trials. Ann Intern Med. 2001;134(8):657-62. [pmid: 11304106].
128 von Elm E, Altman DG, Egger M, et al. The Strengthening of Reporting of Observational Studies in Epidemiology (STROBE) statement: guidelines for reporting observational studies. J Clin Epidemiol. 2008;61(4):344-9. [pmid: 18313558].

## References of Companion Publications

Main Publication | Companion Studies
Aman MG, De Smedt G, Derivan, A, et al. Double-blind, placebo-controlled study of risperidone for the treatment of disruptive behaviors in children with subaverage intelligence. Am J Psychiatry 2002;159(8):1337–46. | Aman M, Findling A, Derivan U. Risperidone versus placebo for severe conduct disorder in children with mental retardation. Int J Neuropsychopharmacol 2000:S144.
| Aman MG, Findling RL, Derivan AT, et al. Effects of risperidone on the behavior of children with subaverage IQ's and conduct disorder or oppositional defiant disorder. Annual Meeting of the American Psychiatric Association; 2001.
| Biederman J, Mick E, Faraone SV, et al. Risperidone for the treatment of affective symptoms in children with disruptive behavior disorder: a post hoc analysis of data from a 6-week, multicenter, randomized, double-blind, parallel-arm study. Clin Ther 2006;28(5):794–800.
| Findling RL, Aman MG, Eerdekens M, et al. Long-term, open-label study of risperidone in children with severe disruptive behaviors and below-average IQ. Am J Psychiatry 2004;161(4):677–84.
| Aman MG, Findling RL. Effects of risperidone on the behavior of children with subaverage IQ's and conduct disorder or oppositional defiant disorder. 155th Annual Meeting of the American Psychiatric Association; 2002.
| Turgay A. Risperidone in children with disruptive behavior disorder and ADHD. 154th Annual Meeting of the American Psychiatric Association; 2001.
Arango C, Robles O, Parellada M, et al. Olanzapine compared to quetiapine in adolescents with a first psychotic episode. Eur Child Adolesc Psychiatry 2009;18(7):418–28. | Robles O, Zabala A, Bombin I, et al. Cognitive Efficacy of Quetiapine and Olanzapine in Early-Onset First-Episode Psychosis. Schizophr Bull 2009:1–11.
Buitelaar JK, van der Gaag RJ, Cohen-Kettenis P, et al. A randomized controlled trial of risperidone in the treatment of aggression in hospitalized adolescents with subaverage cognitive abilities. J Clin Psychiatry 2001;62(4):239–48. | Buitelaar JK, van der Gaag RJ, Melman CT. Risperidone in the treatment of aggressive behaviour disorders in adolescents with mild mental retardation: a prospective, randomised, double-blind, placebo-controlled trial. Paris: 11th European College of Neuropsychopharmacology Congress; 1998.
Findling RL, Robb A, Nyilas M, et al. A multiple-center, randomized, double-blind, placebo-controlled study of oral aripiprazole for treatment of adolescents with schizophrenia. Am J Psychiatry 2008;165(11):1432–41. | Robb AS, Carson WH, Nyilas M, et al. Changes in positive and negative syndrome scale-derived hostility factor in adolescents with schizophrenia treated with aripiprazole: post hoc analysis of randomized clinical trial data. J Child Adolesc Psychopharmacol 2010;20(1):33–8.
Findling RL, McNamara NK, Branicky LA, et al. A double-blind pilot study of risperidone in the treatment of conduct disorder. J Am Acad Child Adolesc Psychiatry 2000;39(4):509–16. | Findling RL, Branicky LA, Branicky LA, et al. Conduct disorder in children treated with risperidone. 152nd Annual Meeting of the American Psychiatric Association; 1999.
Findling RL, McNamara NK, Branicky LA, et al. A double-blind pilot study of risperidone in the treatment of conduct disorder. J Am Acad Child Adolesc Psychiatry 2000;39(4):509–16. | Findling RL, McNamara NK, Branicky LA, et al. Risperidone in children with conduct disorder conference abstract. Schizophrenia Research. Abstracts of The VIIth International Congress on Schizophrenia Research; Santa Fe, NM; 1999:17–21.
Findling RL, McNamara NK, Branicky LA, et al. A double-blind pilot study of risperidone in the treatment of conduct disorder. J Am Acad Child Adolesc Psychiatry 2000;39(4):509–16. | Findling RL. Risperidone in children with conduct disorder. Eur Neuropsychopharmacol 1999:S358
Findling RL, McNamara NK, Branicky LA, et al. A double-blind pilot study of risperidone in the treatment of conduct disorder. J Am Acad Child Adolesc Psychiatry 2000;39(4):509–16. | Findling RL, McNamara NK, Branicky LA. Conduct disorder in children treated with risperidone. 37th Annual Meeting of the American College of Neuropsychopharmacology; 1998 Dec 14–18; Las Croabas; 1998.
Fleischhaker C, Heiser P, Hennighausen K, et al. Clinical drug monitoring in child and adolescent psychiatry: side effects of atypical neuroleptics. J Child Adolesc Psychopharmacol 2006;16(3):308–16. | Fleischhaker C, Heiser P, Hennighausen K, et al. Weight gain in children and adolescents during 45 weeks treatment with clozapine, olanzapine and risperidone. J Neural Transm 2008;115(11):1599–608.
Fleischhaker C, Heiser P, Hennighausen K, et al. Clinical drug monitoring in child and adolescent psychiatry: side effects of atypical neuroleptics. J Child Adolesc Psychopharmacol 2006;16(3):308–16. | Fleischhaker C, Heiser P, Hennighausen K, et al. Weight gain associated with clozapine, olanzapine and risperidone in children and adolescents. J Neural Transm 2007;114(2):273–80.
Haas M, Delbello MP, Pandina G, et al. Risperidone for the treatment of acute mania in children and adolescents with bipolar disorder: a randomized, double-blind, placebo-controlled study. Bipolar Disord 2009;11(7):687–700. | Delbello M. Research on the effectiveness of risperidone in bipolar disorder in adolescents and children (REACH): a double-blind, randomized, placebo-controlled study of the efficacy and safety of risperidone for the treatment of acute mania in bipolar I disorder. Johnson & Johnson Pharmaceutical Research; 2010.
Hellings JA, Zarcone JR, Reese RM, et al. A crossover study of risperidone in children, adolescents and adults with mental retardation. J Autism Dev Disord 2006;36(3):401–11. | Hellings JA, Zarcone JR, Valdovinos MG, et al. Risperidone-induced prolactin elevation in a prospective study of children, adolescents, and adults with mental retardation and pervasive developmental disorders. J Child Adolesc Psychopharmacol 2005;15(6):885–92.
Hellings JA, Zarcone JR, Reese RM, et al. A crossover study of risperidone in children, adolescents and adults with mental retardation. J Autism Dev Disord 2006;36(3):401–11. | Hellings JA, Zarcone JR, Crandall K, et al. Weight gain in a controlled study of risperidone in children, adolescents and adults with mental retardation and autism J Child Adolesc Psychopharmacol 2001;11(3):229–38.
Hellings JA, Zarcone JR, Reese RM, et al. A crossover study of risperidone in children, adolescents and adults with mental retardation. J Autism Dev Disord 2006;36(3):401–11. | Zarcone JR, Hellings JA, Crandall K, et al. Effects of risperidone on aberrant behavior of persons with developmental disabilities: a double-blind crossover study using multiple measures. Am J Ment Retard 2001;106(6):525–38.
Kumra S, Kranzler H, Gerbino-Rosen G, et al. Clozapine and “high-dose” olanzapine in refractory early-onset schizophrenia: a 12-week randomized and double-blind comparison. Biol Psychiatry 2008;63(5):524–9. | Kumra S, Kranzler H, Gerbino-Rosen G, et al. Clozapine versus “high-dose” olanzapine in refractory early-onset schizophrenia: an open-label extension study. J Child Adolesc Psychopharmacol 2008;18(4):307–16.
Marcus RN, Owen R, Kamen L, et al. A placebo-controlled, fixed-dose study of aripiprazole in children and adolescents with irritability associated with autistic disorder. J Am Acad Child Adolesc Psychiatry 2009;48(11):1110–9. | Owen R, Sikich L, Marcus RN, et al. Aripiprazole in the treatment of irritability in children and adolescents with autistic disorder. Pediatrics 2009;124(6):1533–40.
Miral S, Gencer O, Inal-Emiroglu FN, et al. Risperidone versus haloperidol in children and adolescents with AD : a randomized, controlled, double-blind trial. Eur Child Adolesc Psychiatry 2008;17(1):1–8. | Gencer O, Inal-Emiroglu FN, Miral S, et al. Comparison of long-term efficacy and safety of risperidone and haloperidol in children and adolescents with autistic disorder. An open label maintenance study. Eur Child Adolesc Psychiatry 2008;17(4):217–25.
Ratzoni G, Gothelf D, Brand-Gothelf A, et al. Weight gain associated with olanzapine and risperidone in adolescent patients: a comparative prospective study. Journal of the J Am Acad Child Adolesc Psychiatry 2002;41(3):337–43. | Gothelf D, Apter A, Reidman J, et al. Olanzapine, risperidone and haloperidol in the treatment of adolescent patients with schizophrenia. J Neural Transm 2003;110(5):545–60.
Reyes M, Buitelaar J, Toren P, et al. A randomized, double-blind, placebo-controlled study of risperidone maintenance treatment in children and adolescents with disruptive behavior disorders. Am J Psychiatry 2006;163(3):402–10. | Haas M, Karcher K, Pandina GJ. Treating disruptive behavior disorders with risperidone: a 1-year, open-label safety study in children and adolescents. J Child Adolesc Psychopharmacol 2008;18(4):337–46.
McCracken JT, McGough J, Shah B, et al. Risperidone in children with autism and serious behavioral problems. N Engl J Med 2002;347(5):314–21. | Aman MG, Hollway JA, McDougle CJ, et al. Cognitive effects of risperidone in children with autism and irritable behavior. J Child Adolesc Psychopharmacol 2008;18(3):227–36.
McCracken JT, McGough J, Shah B, et al. Risperidone in children with autism and serious behavioral problems. N Engl J Med 2002;347(5):314–21. | Aman MG, Arnold LE, McDougle CJ, et al. Acute and long-term safety and tolerability of risperidone in children with autism. J Child Adolesc Psychopharmacol 2005;15(6):869–84.
McCracken JT, McGough J, Shah B, et al. Risperidone in children with autism and serious behavioral problems. N Engl J Med 2002;347(5):314–21. | Anderson GM, Scahill L, McCracken JT, et al. Effects of short- and long-term risperidone treatment on prolactin levels in children with autism. Biol Psychiatry 2007;61(4):545–50.
McCracken JT, McGough J, Shah B, et al. Risperidone in children with autism and serious behavioral problems. N Engl J Med 2002;347(5):314–21. | Arnold LE, Vitiello B, McDougle C, et al. Parent-defined target symptoms respond to risperidone in RUPP autism study: customer approach to clinical trials. J Am Acad Child Adolesc Psychiatry 2003;42(12):1443–50.
McCracken JT, McGough J, Shah B, et al. Risperidone in children with autism and serious behavioral problems. N Engl J Med 2002;347(5):314–21. | Lindsay RL, Eugene AL, Aman MG, et al. Dietary status and impact of risperidone on nutritional balance in children with autism: a pilot study. J Intellect Dev Disabil 2006;31(4):204–9.
McCracken JT, McGough J, Shah B, et al. Risperidone in children with autism and serious behavioral problems. N Engl J Med 2002;347(5):314–21. | Martin A, Scahill L, Anderson GM, et al. Weight and leptin changes among risperidone-treated youths with autism: 6-month prospective data. Am J Psychiatry 2004;161(6):1125–7.
McCracken JT, McGough J, Shah B, et al. Risperidone in children with autism and serious behavioral problems. N Engl J Med 2002;347(5):314–21. | McDougle CJ, Scahill L, Aman MG, et al. Risperidone for the core symptom domains of autism: results from the study by the autism network of the research units on pediatric psychopharmacology. Am J Psychiatry 2005;162(6):1142–8.
McCracken JT, McGough J, Shah B, et al. Risperidone in children with autism and serious behavioral problems. N Engl J Med 2002;347(5):314–21. | Research Units on Pediatric Psychopharmacology Autism Network. Risperidone treatment of autistic disorder: longer-term benefits and blinded discontinuation after 6 months. Am J Psychiatry 2005;162(7):1361–9.
McCracken JT, McGough J, Shah B, et al. Risperidone in children with autism and serious behavioral problems. N Engl J Med 2002;347(5):314–21. | Scahill L, McCracken J, McDougle CJ, et al. Methodological issues in designing a multisite trial of risperidone in children and adolescents with autism. J Child Adolesc Psychopharmacol 2001;11(4):377–88.
Sallee FR, Kurlan R, Goetz CG, et al. Ziprasidone treatment of children and adolescents with Tourette syndrome: a pilot study. J Am Acad Child Adolesc Psychiatry 2000;39(3):292–9. | Chappell P, Sallee F. The tolerability and efficacy of ziprasidone in the treatment of children and adolescents with Tourette syndrome. 9th Congress of the Association of European Psychiatrists; Copenhagen; 1998.
Sallee FR, Nesbitt L, Jackson C, et al. Relative efficacy of haloperidol and pimozide in children and adolescents with Tourette disorder. Am J Psychiatry 1997;154(8):1057–62. | Sallee FR, Dougherty D, Sethuraman G, et al. Prolactin monitoring of haloperidol and pimozide treatment in children with Tourette syndrome. Biol Psychiatry 1996;40(10):1044–50.
Sallee FR, Sethuraman G, Rock CM. Effects of pimozide on cognition in children with Tourette syndrome: interaction with comorbid attention deficit hyperactivity disorder. Acta Psychiatr Scand 1994;90(1):4–9. | Sallee FR, Rock CM, Head LA. Cognitive effects of neuroleptic use in children with Tourette syndrome. In: Richardson, Mary Ann, editors: Use of neuroleptics in children. Washington, DC; 1996. p.171–184.
Sikich L, Frazier JA, McClellan J, et al. Double-blind comparison of first- and second-generation antipsychotics in early-onset schizophrenia and schizo-affective disorder: findings from the treatment of early-onset schizophrenia spectrum disorders (TEOSS) study. Am J Psychiatry 2008;165(11):1420–31. | Findling RL, Johnson JL, McClellan J, et al. Double-blind maintenance safety and effectiveness findings from the Treatment of Early-Onset Schizophrenia Spectrum (TEOSS) Study. J Am Acad Child Adolesc Psychiatry 2010;49(6):583–94.
| Frazier JA, McClellan J, Findling RL, et al. Treatment of early-onset schizophrenia spectrum disorders (TEOSS): demographic and clinical characteristics. J Am Acad Child Adolesc Psychiatry 2007;46(8):979–88.
| McClellan J, Sikich L, Findling RL, et al. Treatment of early-onset schizophrenia spectrum disorders (TEOSS): rationale, design, and methods. J Am Acad Child Adolesc Psychiatry 2007;46(8):969–78.
Shea S, Turgay A, Carroll A, et al. Risperidone in the treatment of disruptive behavioral symptoms in children with autistic and other pervasive developmental disorders. Pediatrics 2004;114(5):e634–41. | Pandina GJ, Bossie CA, Youssef E, et al. Risperidone improves behavioral symptoms in children with autism in a randomized, double-blind, placebo-controlled trial. J Autism Dev Disord 2007;37(2):367–73.
Snyder R, Turgay A, Aman M, et al. Effects of risperidone on conduct and disruptive behavior disorders in children with subaverage IQs. J Am Acad Child Adolesc Psychiatry 2002;41(9):1026–36. | Turgay A, Binder C, Snyder R, et al. Long-term safety and efficacy of risperidone for the treatment of disruptive behavior disorders in children with subaverage IQs. Pediatrics 2002;110(3):e34–46.
Snyder R, Turgay A, Aman M, et al. Effects of risperidone on conduct and disruptive behavior disorders in children with subaverage IQs. J Am Acad Child Adolesc Psychiatry 2002;41(9):1026–36. | Turgay A. Risperidone in children with disruptive behavior disorder and ADHD. 155th Annual Meeting of the American Psychiatric Association; 2002.
Spencer EK, Campbell M. Children with schizophrenia: diagnosis, phenomenology, and pharmacotherapy. Schizophr Bull 1994;20(4):713–25. | Spencer EK, Kafantaris V, Padron-Gayol MV, et al. Haloperidol in hospitalized schizophrenic children. In: Richardson, Mary Ann, editors: Use of neuroleptics in children. Washington, DC; 1996. p. 67–83.
Spencer EK, Campbell M. Children with schizophrenia: diagnosis, phenomenology, and pharmacotherapy. Schizophr Bull 1994;20(4):713–25. | Spencer EK, Alpert M, Pouget ER. Scales for the assessment of neuroleptic response in schizophrenic children: specific measures derived from the CPRS. Psychopharmacol Bull 1994;30(2):199–202.
Spencer EK, Campbell M. Children with schizophrenia: diagnosis, phenomenology, and pharmacotherapy. Schizophr Bull 1994;20(4):713–25. | Spencer EK, Kafantaris V, Padron-Gayol MV, et al. Haloperidol in schizophrenic children: early findings from a study in progress. Psychopharmacol Bull 1992;28(2):183–6.
Tohen M, Kryzhanovskaya L, Carlson G, et al. Olanzapine versus placebo in the treatment of adolescents with bipolar mania. Am J Psychiatry 2007;164(10):1547–56. | Robertson-Plouch C. Olanzapine useful in adolescent mania. Academy of Adolescent and Child Psychiatry 2006;31(12):727.
Tohen M, Kryzhanovskaya L, Carlson G, et al. Olanzapine versus placebo in the treatment of adolescents with bipolar mania. Am J Psychiatry 2007;164(10):1547–56. | Tohen M, Kryzhanovskaya L, Carlson G, et al. Olanzapine in the treatment of acute mania in adolescents with bipolar I disorder: a 3-week randomized double-blind placebo-controlled study. Neuropsychopharmacol 2005;7:S176.
Troost PW, Lahuis BE, Steenhuis MP, et al. Long-term effects of risperidone in children with autism spectrum disorders: a placebo discontinuation study. J Am Acad Child Adolesc Psychiatry 2005;44(11):1137–44. | Troost PW, Althaus M, Lahuis BE, et al. Neuropsychological effects of risperidone in children with pervasive developmental disorders: a blinded discontinuation study. J Child Adolesc Psychopharmacol 2006;16(5):561–73.
van Bruggen J, Tijssen J, Dingemans P, et al. Symptom response and side-effects of olanzapine and risperidone in young adults with recent onset schizophrenia. Int Clin Psychopharmacol 2003;18(6):341–6. | Lavalaye J, Linszen DH, Booij J, et al. Dopamine D2 receptor occupancy by olanzapine or risperidone in young patients with schizophrenia. Psychiatry Res 1999;92(1):33–44.
Woods SW, Breier A, Zipursky RB, et al. Randomized trial of olanzapine versus placebo in the symptomatic acute treatment of the schizophrenic prodrome. Biol Psychiatry 2003;54(4):453–64. | Hawkins KA, Keefe RS, Christensen BK, et al. Neuropsychological course in the prodrome and first episode of psychosis: findings from the PRIME North America Double Blind Treatment Study. Schizophr Res 2008;105(1–3):1–9.
Woods SW, Breier A, Zipursky RB, et al. Randomized trial of olanzapine versus placebo in the symptomatic acute treatment of the schizophrenic prodrome. Biol Psychiatry 2003;54(4):453–64. | Keefe RS, Perkins DO, Gu H, et al. A longitudinal study of neurocognitive function in individuals at-risk for psychosis. Schizophr Res 2006;88(1–3):26–35.
Woods SW, Breier A, Zipursky RB, et al. Randomized trial of olanzapine versus placebo in the symptomatic acute treatment of the schizophrenic prodrome. Biol Psychiatry 2003;54(4):453–64. | McGlashan TH, Zipursky RB, Perkins D, et al. The PRIME North America randomized double-blind clinical trial of olanzapine versus placebo in patients at risk of being prodromally symptomatic for psychosis: study rationale and design. Schizophr Res 2003;61(1):7–18.
Woods SW, Breier A, Zipursky RB, et al. Randomized trial of olanzapine versus placebo in the symptomatic acute treatment of the schizophrenic prodrome. Biol Psychiatry 2003;54(4):453–64. | McGlashan TH, Zipursky RB, Perkins D, et al. Randomized, double-blind trial of olanzapine versus placebo in patients prodromally symptomatic for psychosis. Am J Psychiatry 2006;(5):790–9.
Woods SW, Breier A, Zipursky RB, et al. Randomized trial of olanzapine versus placebo in the symptomatic acute treatment of the schizophrenic prodrome. Biol Psychiatry 2003;54(4):453–64. | Miller TJ, Zipursky RB, Perkins D, et al. The PRIME North America randomized double-blind clinical trial of olanzapine versus placebo in patients at risk of being prodromally symptomatic for psychosis: baseline characteristics of the “prodromal” sample. Schizophr Res 2003;61(1):19–30.