# Peer Reviewers

Dr. Roberto Sassi

Assistant Professor

Department of Psychiatry and Behavioral Neuroscience

McMaster University

Hamilton, ON, Canada

Dr. Fay Kagan

Pediatric/Adolescent Psychiatrist

Hathaway-Sycamore Child and Family Services

Pacoima, CA

Dr. Adelaide S. Robb

Associate Professor

Psychiatry and Behavioral Sciences and Pediatrics

School of Medicine and Health Sciences

George Washington University

Washington, DC