# List of Excluded Studies and Unobtained Studies

One thousand four studies were excluded. The reasons for exclusion are as follows: (1) the study population was >24 years of age (N = 748), (2) the study was not primary research (N = 89), (3) inappropriate study design (N = 70), (4) the study intervention did not meet our criteria (N = 41), (5) there were no outcome of interest reported (N = 19), (6) the study population did not have the condition/diagnosis of interest (N = 18), (7) the article was a duplicate publication (N = 9), (8) the study was not published in English (N = 7), and (9) the study was published before 1987 (N = 3). In addition, 38 studies could not be retrieved through the univeristy interlibrary loan service.

## Excluded – Age>24 (N = 748)

The following studies were excluded because the participants were older than 24 years of age.

1 How do different atypical antipsychotics impact cognitive function in schizophrenia?. Brown Univ Psychopharmacol Update. 2005;16(2):1.
2 Abraham G, Paing WW, Kaminski J, et al. Effects of elevated serum prolactin on bone mineral density and bone metabolism in female patients with schizophrenia: a prospective study. Am J Psychiatry. 2003;160(9):1618-20. [pmid: 12944336].
3 Addington DE, Labelle A, Kulkarni J, et al. A comparison of ziprasidone and risperidone in the long-term treatment of schizophrenia: a 44-week, double-blind, continuation study. Can J Psychiatr Rev Canad Psychiatr. 2009;54(1):46-54.
4 Addington DEN, Pantelis C, Dineen M, et al. Efficacy and Tolerability of Ziprasidone Versus Risperidone in Patients With Acute Exacerbation of Schizophrenia or Schizoaffective Disorder: an 8-Week, Double-Blind, Multicenter Trial. J Clin Psychiatry. 2004;65(12):1624-33. [pmid: 15641867].
5 Adler LE, Olincy A, Cawthra EM, et al. Varied effects of atypical neuroleptics on P50 auditory gating in schizophrenia patients. Am J Psychiatry. 2004;161(10):1822-8. [pmid: 15465979].
6 Agelink MW, Majewski T, Wurthmann C, et al. Effects of newer atypical antipsychotics on autonomic neurocardiac function: a comparison between amisulpride, olanzapine, sertindole, and clozapine. J Clin Psychopharmacol. 2001;21(1):8-13. [pmid: 11199953].
7 Ahlfors UG, Rimon R, Appelberg B, et al. Remoxipride and haloperidol in schizophrenia: a double-blind multicentre study. Acta Psychiatr Scand Suppl. 1990;358:99-103. [pmid: 1978501].
8 Akdede BBK, Yagcioglu AEA, Alptekin K, et al. A double-blind study of combination of clozapine with risperidone in patients with schizophrenia: Effects on cognition. J Clin Psychiatry. 2006;67(12):1912-9. [pmid: 17194269].
9 Akhondzadeh S, Milajerdi MR, Amini H, et al. Allopurinol as an adjunct to lithium and haloperidol for treatment of patients with acute mania: a double-blind, randomized, placebo-controlled trial. Bipolar Disord. 2006;8(5 pt 1):485-9. [pmid: 17042886].
10 Akkaya C, Sarandol A, Cangur S, et al. Retrospective database analysis on the effectiveness of typical and atypical antipsychotic drugs in an outpatient clinic setting. Hum Psychopharmacol. 2007;22(8):515-28. [pmid: 17868197].
11 Al-Chalabi BM, Thanoon IA, Ahmed FA. Potential effect of olanzapine on total antioxidant status and lipid peroxidation in schizophrenic patients. Neuropsychobiology. 2009;59(1):8-11. [pmid: 19221442].
12 Al-Haddad MK, Kamel C, Sequeria RP, et al. Zuclopenthixol versus haloperidol in the initial treatment of schizophrenic psychoses, affective psychoses and paranoid states: a controlled clinical trial. Arab J Psychiatr. 1996;7(1):44-54.
13 Alessi-Severini S, Biscontri RG, Collins DM, et al. Utilization and costs of antipsychotic agents: a Canadian population-based study, 1996-2006. Psychiatr Serv. 2008;59(5):547-53. [pmid: 18451015].
14 Alfredsson G, Wiesel FA. Relationships between clinical effects and monoamine metabolites and amino acids in sulpiride-treated schizophrenic patients. Psychopharmacology. 1990;101(3):324-31. [pmid: 2362952].
15 Alhamad AM. Schizophrenia relapse in relation to drug treatment. Neurosciences. 2005;10(1):68-72.
16 Alhamad AM. Clozapine: A mood stabilizer in chronic resistant bipolar affective disorder. Arab J Psychiatr. 2003;14(2):88-93.
17 Alptekin K, Hafez J, Brook S, et al. Efficacy and tolerability of switching to ziprasidone from olanzapine, risperidone or haloperidol: an international, multicenter study. Int Clin Psychopharmacol. 2009;24(5):229-38. [pmid: 19531959].
18 Altamura AC, Percudani M, Mauri MC. Negative symptoms, DST and variability of response to neuroleptics in schizophrenia. Eur Neuropsychopharmacol. 1993;3(3):205-7.
19 Alvarez E, Ciudad A, Olivares JM, et al. A randomized, 1-year followup study of olanzapine and risperidone in the treatment of negative symptoms in outpatients with schizophrenia. J Clin Psychopharmacol. 2006;26(3):238-49. [pmid: 16702888].
20 Amann BL, Pogarell O, Mergl R, et al. EEG abnormalities associated with antipsychotics: a comparison of quetiapine, olanzapine, haloperidol and healthy subjects. Hum Psychopharmacol. 2003;18(8):641-6. [pmid: 14696024].
21 Andersen J, Korner A, Ostergaard P, et al. A double blind comparative multicentre study of remoxipride and haloperidol in schizophrenia. Acta Psychiatr Scand Suppl. 1990;358:104-7. [pmid: 1978467].
22 Andrezina R, Josiassen RC, Marcus RN, et al. Intramuscular aripiprazole for the treatment of acute agitation in patients with schizophrenia or schizoaffective disorder: a double-blind, placebo-controlled comparison with intramuscular haloperidol. Psychopharmacology. 2006;188(3):281-92. [pmid: 16953381].
23 Angelopoulos E, Markianos M, Daskalopoulou E, et al. Neuroendocrine responsivity to clomipramine challenge test in neuroleptic naive psychotic patients before and after treatment with haloperidol. Eur Psychiatry. 1997;12(7):362-6. [pmid: 19698552].
24 Apiquian R, Fresan A, Herrera K, et al. Minimum effective doses of haloperidol for the treatment of first psychotic episode: a comparative study with risperidone and olanzapine. Int J Neuropsychopharmacol. 2003;6(4):403-8. [pmid: 14604455].
25 Apiquian R, Fresan A, Munoz-Delgado J, et al. Variations of rest, activity rhythm and sleep, wake in schizophrenic patients versus healthy subjects: an actigraphic comparative study. Biol Rhythm Res. 2008;39(1):69-78.
26 Arango C, Summerfelt A, Buchanan RW. Olanzapine effects on auditory sensory gating in schizophrenia. Am J Psychiatry. 2003;160(11):2066-8. [pmid: 14594761].
27 Arato M, O'Connor R, Meltzer HY, et al. A 1-year, double-blind, placebo-controlled trial of ziprasidone 40, 80 and 160 mg/day in chronic schizophrenia: the Ziprasidone Extended Use in Schizophrenia (ZEUS) study. Int Clin Psychopharmacol. 2002;17(5):207-15. [pmid: 12177583].
28 Arranz B, Rosel P, Ramirez N, et al. Insulin resistance and increased leptin concentrations in noncompliant schizophrenia patients but not in antipsychotic-naive first-episode schizophrenia patients. J Clin Psychiatry. 2004;65(10):1335-42. [pmid: 15491236].
29 Arranz B, San L, Duenas RM, et al. Lower weight gain with the orally disintegrating olanzapine than with standard tablets in first-episode never treated psychotic patients. Hum Psychopharmacol. 2007;22(1):11-5. [pmid: 17191265].
30 Artaloytia JF, Arango C, Lahti A, et al. Negative signs and symptoms secondary to antipsychotics: a double-blind, randomized trial of a single dose of placebo, haloperidol, and risperidone in healthy volunteers. Am J Psychiatry. 2006;163(3):488-93. [pmid: 16513871].
31 Arvanitis LA, Miller BG. Multiple fixed doses of “Seroquel” (quetiapine) in patients with acute exacerbation of schizophrenia: a comparison with haloperidol and placebo: The Seroquel Trial 13 Study Group. Biol Psychiatry. 1997;42(4):233-46. [pmid: 9270900].
32 Assion HJ, Reinbold H, Lemanski S, et al. Amisulpride augmentation in patients with schizophrenia partially responsive or unresponsive to clozapine: a randomized, double-blind, placebo-controlled trial. Pharmacopsychiatry. 2008;41(1):24-8. [pmid: 18203048].
33 Atasoy N, Erdogan A, Yalug I, et al. A review of liver function tests during treatment with atypical antipsychotic drugs: a chart review study. Prog Neuro-Psychopharmacol Biol Psychiatry. 2007;31(6):1255-60.
34 Atmaca M, Kuloglu M, Tezcan E, et al. Quetiapine augmentation in patients with treatment resistant obsessive-compulsive disorder: a single-blind, placebo-controlled study. Int Clin Psychopharmacol. 2002;17(3):115-9. [pmid: 11981352].
35 Atmaca M, Kuloglu M, Tezcan E, et al. Quetiapine is not associated with increase in prolactin secretion in contrast to haloperidol. Arch Med Res. 2002;33(6):562-5. [pmid: 12505103].
36 Atmaca M, Kuloglu M, Tezcan E, et al. Serum leptin and triglyceride levels in patients with atypical antipsychotics. J Clin Psychiatry. 2003;64(5):598-604. [pmid: 12755665].
37 Auerbach JG, Hans SL, Marcus J, et al. Maternal psychotropic medication and neonatal behavior. Neurotoxicol Teratol. 1992;14(6):399-406. [pmid: 1488034].
38 Awad AG, Lapierre YD, Angus C, et al. Quality of life and response of negative symptoms in schizophrenia to haloperidol and the atypical antipsychotic remoxipride: The Canadian Remoxipride Group. J Psychiatry Neurosci. 1997;22(4):244-8. [pmid: 9262046].
39 Aydemir C, Goka E, Kisa C, et al. Dyskinesia and soft neurological signs in schizophrenia: a comparative study. Int J Psychiatry Clin Pract. 2005;9(4):238-43.
40 Azorin JM, Spiegel R, Remington G, et al. A double-blind comparative study of clozapine and risperidone in the management of severe chronic schizophrenia. Am J Psychiatry. 2001;158(8):1305-13. [pmid: 11481167].
41 Azorin JM, Strub N, Loft H. A double-blind, controlled study of sertindole versus risperidone in the treatment of moderate-to-severe schizophrenia. Int Clin Psychopharmacol. 2006;21(1):49-56. [pmid: 16317317].
42 Bai YM, Chen TT, Wu B, et al. A comparative efficacy and safety study of long-acting risperidone injection and risperidone oral tablets among hospitalized patients: 12-week randomized, single-blind study. Pharmacopsychiatry. 2006;39(4):135-41. [pmid: 16900609].
43 Bai YM, Chen TT, Chen JY, et al. Equivalent switching dose from oral risperidone to risperidone long-acting injection: a 48-week randomized, prospective, single-blind pharmacokinetic study. J Clin Psychiatry. 2007;68(8):1218-25. [pmid: 17854246].
44 Baker RW, K B, M G, L. Effectiveness of rapid initial dose escalation of up to forty milligrams per day of oral olanzapine in acute agitation. J Clin Psychopharmacol. 2003;(4):342-8. [pmid: 12920409].
45 Baker RW, Tohen M, Fawcett J, et al. Acute dysphoric mania: Treatment response to olanzapine versus placebo. J Clin Psychopharmacol. 2003;23(2):132-7. [pmid: 12640214].
46 Baldessarini RJ, Hennen J, Wilson M, et al. Olanzapine versus placebo in acute mania: treatment responses in subgroups. J Clin Psychopharmacol. 2003;23(4):370-6. [pmid: 12920413].
47 Bartzokis G, Lu PH, Nuechterlein KH, et al. Differential effects of typical and atypical antipsychotics on brain myelination in schizophrenia. Schizophr Res. 2007;93(1-3):13-22. [pmid: 17407804].
48 Battaglia J, Moss S, Rush J, et al. Haloperidol, lorazepam, or both for psychotic agitation? A multicenter, prospective, double-blind, emergency department study. Am J Emerg Med. 1997;15(4):335-40. [pmid: 9217519].
49 Battaglia J, Wolff TK, Wagner-Johnson DS, et al. Structured diagnostic assessment and depot fluphenazine treatment of multiple suicide attempters in the emergency department. Int Clin Psychopharmacol. 1999;14(6):361-72. [pmid: 10565804].
50 Beasley CM Jr., Tollefson G, Tran P, et al. Olanzapine versus placebo and haloperidol: acute phase results of the North American double-blind olanzapine trial. Neuropsychopharmacology. 1996;14(2):111-23. [pmid: 8822534].
51 Beasley CM Jr., Sutton VK, Hamilton SH, et al. A double-blind, randomized, placebo-controlled trial of olanzapine in the prevention of psychotic relapse. J Clin Psychopharmacol. 2003;23(6):582-94. [pmid: 14624189].
52 Beasley CM Jr., Sutton VK, Taylor CC, et al. Is quality of life among minimally symptomatic patients with schizophrenia better following withdrawal or continuation of antipsychotic treatment?. J Clin Psychopharmacol. 2006;26(1):40-4. [pmid: 16415704].
53 Beasley CMJ, Hamilton SH, Crawford AM, et al. Olanzapine versus haloperidol: acute phase results of the international double-blind olanzapine trial. Eur Neuropsychopharmacol. 1997;7(2):125-37. [pmid: 9169300].
54 Bebbington PE, Angermeyer M, Azorin JM, et al. Side-effects of antipsychotic medication and health-related quality of life in schizophrenia. Acta Psychiatr Scand Suppl. 2009;(438):22-8. [pmid: 19132963].
55 Bech P, Gormsen L, Loldrup D, et al. The clinical effect of clomipramine in chronic idiopathic pain disorder revisited using the Spielberger State Anxiety Symptom Scale (SSASS) as outcome scale. J Affect Disord. 2009;119(1-3):43-51. [pmid: 19349078].
56 Becker J, Gomes I, Ghisolfi ES, et al. Clozapine, but not typical antipsychotics, correct P50 suppression deficit in patients with schizophrenia. Clin Neurophysiol. 2004;115(2):396-401. [pmid: 14744582].
57 Becker MA, Young MS, Ochshorn E, et al. The relationship of antipsychotic medication class and adherence with treatment outcomes and costs for Florida Medicaid beneficiaries with schizophrenia. Adm Policy Ment Health. 2007;34(3):307-14. [pmid: 17211716].
58 Bender S, ttmann-Balcar A, Schall U, et al. Influence of atypical neuroleptics on executive functioning in patients with schizophrenia: a randomized, double-blind comparison of olanzapine vs. clozapine. Int J Neuropsychopharmacol. 2006;9(2):135-45. [pmid: 16174427].
59 Bergemann N, Mundt C, Parzer P, et al. Plasma concentrations of estradiol in women suffering from schizophrenia treated with conventional versus atypical antipsychotics. Schizophr Res. 2005;73(2-3):357-66. [pmid: 15653282].
60 Berk M, Brook S, Trandafir AI. A comparison of olanzapine with haloperidol in cannabis-induced psychotic disorder: a double-blind randomized controlled trial. Int Clin Psychopharmacol. 1999;14(3):177-80. [pmid: 10435771].
61 Berk M, Brook S, Nur F. Risperidone compared to haloperidol in cannabis-induced psychotic disorder: a double blind randomized controlled trial. Int J Psychiatry Clin Pract. 2000;4(2):139-42.
62 Berman RM, F M. Aripiprazole augmentation in major depressive disorder: a double-blind, placebo-controlled study in patients with inadequate response to antidepressants. CNS Spectrums. 2009;(4):197-206. [pmid: 19407731].
63 Bernardo M, Parellada E, Lomena F, et al. Double-blind olanzapine vs. haloperidol D2 dopamine receptor blockade in schizophrenic patients: a baseline-endpoint IBZM SPECT study. Psychiatry Res. 2001;107(2):87-97. [pmid: 11530275].
64 Bilder RM, Goldman RS, Volavka J, et al. Neurocognitive effects of clozapine, olanzapine, risperidone, and haloperidol in patients with chronic schizophrenia or schizoaffective disorder. Am J Psychiatry. 2002;159(6):1018-28. [pmid: 12042192].
65 Birkenaes AB, Birkeland KI, Engh JA, et al. Dyslipidemia independent of body mass in antipsychotic-treated patients under real-life conditions. J Clin Psychopharmacol. 2008;28(2):132-7. [pmid: 18344722].
66 Bissada H, Tasca GA, Barber AM, et al. Olanzapine in the treatment of low body weight and obsessive thinking in women with anorexia nervosa: a randomized, double-blind, placebo-controlled trial. Am J Psychiatry. 2008;165(10):1281-8. [pmid: 18558642].
67 Bitter I, Dossenbach MR, Brook S, et al. Olanzapine versus clozapine in treatment-resistant or treatment-intolerant schizophrenia. Prog Neuropsychopharmacol Biol Psychiatry. 2004;28(1):173-80. [pmid: 14687871].
68 Blin O, Azorin JM, Bouhours P. Antipsychotic and anxiolytic properties of risperidone, haloperidol, and methotrimeprazine in schizophrenic patients. J Clin Psychopharmacol. 1996;16(1):38-44. [pmid: 8834417].
69 Bloom JR, Cheng JS, Hu TW, et al. Use of antipsychotic medications in treating schizophrenia among different financing and delivery systems. J Ment Health Policy Econ. 2003;6(4):163-71. [pmid: 14713723].
70 Bobes J, Gibert J, Ciudad A, et al. Safety and effectiveness of olanzapine versus conventional antipsychotics in the acute treatment of first-episode schizophrenic inpatients. Prog Neuropsychopharmacol Biol Psychiatry. 2003;27(3):473-81. [pmid: 12691783].
71 Bogenschutz MP, Nurnberg G. Olanzapine versus placebo in the treatment of borderline personality disorder. J Clin Psychiatry. 2004;(1):104-9. [pmid: 14744178].
72 Boggs DL, Kelly DL, Love R, et al. Comparison of clozapine response for inpatients in the research setting versus routine clinical practice. Psychiatr Q. 2008;79(2):111-9. [pmid: 18214677].
73 Boidi G, Ferro M. Rapid dose initiation of quetiapine for the treatment of acute schizophrenia and schizoaffective disorder: a randomised, multicentre, parallel-group, open study. Hum Psychopharmacol. 2007;22(5):299-306. [pmid: 17487936].
74 Bond M, Perry JC. Psychotropic medication use, personality disorder and improvement in long-term dynamic psychotherapy. J Nerv Ment Dis. 2006;194(1):21-6. [pmid: 16462551].
75 Bondolfi G, Dufour H, Patris M, et al. Risperidone versus clozapine in treatment-resistant chronic schizophrenia: a randomized double-blind study: The Risperidone Study Group. Am J Psychiatry. 1998;155(4):499-504. [pmid: 9545995].
76 Borison RL, Sinha D, Haverstock S, et al. Efficacy and safety of tiospirone vs. haloperidol and thioridazine in a double-blind, placebo-controlled trial. Psychopharmacol Bull. 1989;25(2):190-3. [pmid: 2574893].
77 Borison RL, Diamond B, Pathiraja A, et al. Pharmacokinetics of risperidone in chronic schizophrenic patients. Psychopharmacol Bull. 1994;30(2):193-7. [pmid: 7530379].
78 Borison RL, Arvanitis LA, Miller BG. ICI 204,636, an atypical antipsychotic: efficacy and safety in a multicenter, placebo-controlled trial in patients with schizophrenia: U.S. SEROQUEL Study Group. J Clin Psychopharmacol. 1996;16(2):158-69. [pmid: 8690831].
79 Boter H, Peuskens J, Libiger J, et al. Effectiveness of antipsychotics in first-episode schizophrenia and schizophreniform disorder on response and remission: an open randomized clinical trial (EUFEST). Schizophr Res. 2009;115(2-3):97-103. [pmid: 19819114].
80 Bowden CL, Grunze H, Mullen J, et al. A randomized, double-blind, placebo-controlled efficacy and safety study of quetiapine or lithium as monotherapy for mania in bipolar disorder. J Clin Psychiatry. 2005;66(1):111-21. [pmid: 15669897].
81 Bowden CL, Calabrese JR, McElroy SL, et al. A randomized, placebo-controlled 12-month trial of divalproex and lithium in treatment of outpatients with bipolar I disorder. Arch Gen Psychiatry. 2000;57(5):481-9. [pmid: 10807488].
82 Bowden CL, Myers JE, Grossman F, et al. Risperidone in combination with mood stabilizers: a 10-week continuation phase study in bipolar I disorder. J Clin Psychiatry. 2004;65(5):707-14. [pmid: 15163260].
83 Bowers MB Jr., Mazure CM, Nelson JC, et al. Psychotogenic drug use and neuroleptic response. Schizophr Bull. 1990;16(1):81-5. [pmid: 1970670].
84 Breier A, Meehan K, Birkett M, et al. A double-blind, placebo-controlled dose-response comparison of intramuscular olanzapine and haloperidol in the treatment of acute agitation in schizophrenia. Arch Gen Psychiatry. 2002;59(5):441-8. [pmid: 11982448].
85 Breier A, Berg PH, Thakore JH, et al. Olanzapine versus ziprasidone: results of a 28-week double-blind study in patients with schizophrenia. Am J Psychiatry. 2005;162(10):1879-87. [pmid: 16199834].
86 Breier AF, Malhotra AK, Su TP, et al. Clozapine and risperidone in chronic schizophrenia: Effects on symptoms, parkinsonian side effects, and neuroendocrine response. Am J Psychiatry. 1999;156(2):294-8. [pmid: 9989566].
87 Broerse A, Crawford TJ, den Boer JA. Differential effects of olanzapine and risperidone on cognition in schizophrenia?: a saccadic eye movement study. J Neuropsychiatry Clin Neurosci. 2002;14(4):454-60. [pmid: 12426415].
88 Brook S, Lucey JV, Gunn KP. Intramuscular ziprasidone compared with intramuscular haloperidol in the treatment of acute psychosis. J Clin Psychiatry. 2000;61(12):933-41. [pmid: 11206599].
89 Brook S, Walden J, Benattia I, et al. Ziprasidone and haloperidol in the treatment of acute exacerbation of schizophrenia and schizoaffective disorder: comparison of intramuscular and oral formulations in a 6-week, randomized, blinded-assessment study. Psychopharmacology. 2005;178(4):514-23. [pmid: 15650846].
90 Brown RR, Estoup MW. Comparison of the metabolic effects observed in patients treated with ziprasidone versus olanzapine. Int Clin Psychopharmacol. 2005;20(2):105-12. [pmid: 15729087].
91 Brown S, Chan K. A randomized controlled trial of a brief health promotion intervention in a population with serious mental illness. J Ment Health. 2006;15(5):543-9.
92 Buchanan A. A two-year prospective study of treatment compliance in patients with schizophrenia. Psychol Med. 1992;22(3):787-97. [pmid: 1357703].
93 Butterfield MI, Becker ME, Connor KM, et al. Olanzapine in the treatment of post-traumatic stress disorder: a pilot study. Int Clin Psychopharmacol. 2001;16(4):197-203. [pmid: 11459333].
94 Byerly MJ, Nakonezny PA, Bettcher BM, et al. Sexual dysfunction associated with second-generation antipsychotics in outpatients with schizophrenia or schizoaffective disorder: an empirical evaluation of olanzapine, risperidone, and quetiapine. Schizophr Res. 2006;86(1-3):244-50. [pmid: 16730951].
95 Byerly MJ, Marcus RN, Tran QV, et al. Effects of aripiprazole on prolactin levels in subjects with schizophrenia during cross-titration with risperidone or olanzapine: analysis of a randomized, open-label study. Schizophr Res. 2009;107(2-3):218-22. [pmid: 19038534].
96 Bystritsky A, Ackerman DL, Rosen RM, et al. Augmentation of serotonin reuptake inhibitors in refractory obsessive-compulsive disorder using adjunctive olanzapine: a placebo-controlled trial. J Clin Psychiatry. 2004;65(4):565-8. [pmid: 15119922].
97 Calabrese JR, Keck PE Jr., Macfadden W, et al. A randomized, double-blind, placebo-controlled trial of quetiapine in the treatment of bipolar I or II depression. Am J Psychiatry. 2005;162(7):1351-60. [pmid: 15994719].
98 Canal M. Lack of effect of amisulpride on the pharmacokinetics and safety of lithium. Int J Neuropsychopharmacol. 2003;(2):103-9. [pmid: 12890302].
99 Canuso CM, Dirks B, Carothers J, et al. Randomized, double-blind, placebo-controlled study of paliperidone extended-release and quetiapine in inpatients with recently exacerbated schizophrenia. Am J Psychiatry. 2009;166(6):691-701. [pmid: 19411369].
100 Canuso CM, Goldstein JM, Wojcik J, et al. Antipsychotic medication, prolactin elevation, and ovarian function in women with schizophrenia and schizoaffective disorder. Psychiatry Res. 2002;111(1):11-20. [pmid: 12140115].
101 Carey PD, Vythilingum B, Seedat S, et al. Quetiapine augmentation of SRIs in treatment refractory obsessive-compulsive disorder: a double-blind, randomised, placebo-controlled study [ISRCTN83050762]. BMC Psychiatry. 2005;5:5. [pmid: 15667657].
102 Carlson C, Hornbuckle K, DeLisle F, et al. Diabetes mellitus and antipsychotic treatment in the United Kingdom. Eur Neuropsychopharmacol. 2006;16(5):366-75. [pmid: 16356695].
103 Carlson CD, Cavazzoni PA, Berg PH, et al. An Integrated analysis of acute treatment-emergent extrapyramidal syndrome in patients with schizophrenia during olanzapine clinical trials: comparisons with placebo, haloperidol, risperidone, or clozapine. J Clin Psychiatry. 2003;64(8):898-906. [pmid: 12927004].
104 Carrasco JL, Gutierrez M, Gomez JC, et al. Treatment of severely psychotic inpatients with schizophrenia: olanzapine versus other antipsychotic drugs. Int Clin Psychopharmacol. 2002;17(6):287-95. [pmid: 12409682].
105 Carriere P, Bonhomme D, Lemperiere T. Amisulpride has a superior benefit/risk profile to haloperidol in schizophrenia: results of a multicentre, double-blind study: the Amisulpride Study Group. Eur Psychiatry. 2000;15(5):321-9. [pmid: 11032464].
106 Casey DE, Daniel DG, Wassef AA, et al. Effect of divalproex combined with olanzapine or risperidone in patients with an acute exacerbation of schizophrenia. Neuropsychopharmacology. 2003;28(1):182-92. [pmid: 12496955].
107 Casey DE, Daniel DG, Tamminga C, et al. Divalproex ER combined with olanzapine or risperidone for treatment of acute exacerbations of schizophrenia. Neuropsychopharmacology. 2009;34(5):1330-8. [pmid: 19052541].
108 Casey DE, Sands EE, Heisterberg J, et al. Efficacy and safety of bifeprunox in patients with an acute exacerbation of schizophrenia: results from a randomized, double-blind, placebo-controlled, multicenter, dose-finding study. Psychopharmacology. 2008;200(3):317-31. [pmid: 18597078].
109 Castilla-Puentes R. Effects of psychotropics on glycosylated hemoglobin (HbA1c) in a cohort of bipolar patients. Bipolar Disord. 2007;9(7):772-8. [pmid: 17988369].
110 Centorrino F, Baldessarini RJ, Flood JG, et al. Relation of leukocyte counts during clozapine treatment to serum concentrations of clozapine and metabolites. Am J Psychiatry. 1995;152(4):610-2. [pmid: 7694912].
111 Centorrino F, Price BH, Tuttle M, et al. EEG abnormalities during treatment with typical and atypical antipsychotics. Am J Psychiatry. 2002;159(1):109-15. [pmid: 11772698].
112 Chan HY, Chang CJ, Chiang SC, et al. A randomised controlled study of risperidone and olanzapine for schizophrenic patients with neuroleptic-induced acute dystonia or parkinsonism. J Psychopharmacol. 2010;24(1):91-8. [pmid: 18801830].
113 Chang JS, Ahn YM, Park HJ, et al. Aropoprazole augmentation in closapine-treated patients with refractory schizophrenia: an 8-week, randomized, double-blind, placebo-controlled trial. J Clin Psychiatry. 2008;69(5):720-31. [pmid: 18370574].
114 Chengappa KN, Parepally H, Brar JS, et al. A random-assignment, double-blind, clinical trial of once- vs twice-daily administration of quetiapine fumarate in patients with schizophrenia or schizoaffective disorder: a pilot study. Can J Psychiatr Rev Canad Psychiatr. 2003;48(3):187-94.
115 Chengappa KN, Goldstein JM, Greenwood M, et al. A post hoc analysis of the impact on hostility and agitation of quetiapine and haloperidol among patients with schizophrenia. Clin Ther. 2003;25(2):530-41. [pmid: 12749512].
116 Chengappa KNR, Tohen M, Levine J, et al. Response to placebo among bipolar I disorder patients experiencing their first manic episode. Bipolar Disord. 2000;2(4):332-5. [pmid: 11252646].
117 Chengappa KNR, Goldstein JM, Greenwood M, et al. A post-hoc analysis of the impact on hostility and agitation of quetiapine and haloperidol among patients with schizophrenia. Clin Ther. 2003;25(2):530-41. [pmid: 12749512].
118 Chiu CC, Chen KP, Liu HC, et al. The early effect of olanzapine and risperidone on insulin secretion in atypical-naive schizophrenic patients. J Clin Psychopharmacol. 2006;26(5):504-7. [pmid: 16974193].
119 Chopra MP, Prakash SS, Raguram R. The neuroleptic malignant syndrome: an Indian experience. Compr Psychiatry. 1999;40(1):19-23. [pmid: 9924872].
120 Chouinard G, Annable L, Campbell W. A randomized clinical trial of haloperidol decanoate and fluphenazine decanoate in the outpatient treatment of schizophrenia. J Clin Psychopharmacol. 1989;9(4):247-53. [pmid: 2570086].
121 Chouinard G. A placebo-controlled clinical trial of remoxipride and chlorpromazine in newly admitted schizophrenic patients with acute exacerbation. Acta Psychiatr Scand Suppl. 1990;358:111-9. [pmid: 1978469].
122 Chouinard G, Annable L, Turnier L, et al. A double-blind randomized clinical trial of rapid tranquilization with I.M. clonazepam and I.M. haloperidol in agitated psychotic patients with manic symptoms. Can J Psychiatr Rev Canad Psychiatr. 1993;38(Suppl):21.
123 Chouinard G, Safadi G, Beauclair L. A double-blind controlled study of intramuscular zuclopenthixol acetate and liquid oral haloperidol in the treatment of schizophrenic patients with acute exacerbation. J Clin Psychopharmacol. 1994;14(6):377-84. [pmid: 7884017].
124 Chouinard G, Albright PS. Economic and health state utility determinations for schizophrenic patients treated with risperidone or haloperidol. J Clin Psychopharmacol. 1997;17(4):298-307. [pmid: 9241010].
125 Chowdhury AN, Mukherjee A, Ghosh K, et al. Horizon of a new hope: recovery of schizophrenia in India. Int Med J. 1999;6(3):181-5.
126 Chrzanowski WK, Marcus RN, Torbeyns A, et al. Effectiveness of long-term aripiprazole therapy in patients with acutely relapsing or chronic, stable schizophrenia: a 52-week, open-label comparison with olanzapine. Psychopharmacology. 2006;189(2):259-66. [pmid: 17058105].
127 Chue P, Eerdekens M, Augustyns I, et al. Comparative efficacy and safety of long-acting risperidone and risperidone oral tablets. Eur Neuropsychopharmacol. 2005;15(1):111-7. [pmid: 15572280].
128 Chwastiak LA, Rosenheck RA, McEvoy JP, et al. The impact of obesity on health care costs among persons with schizophrenia. Gen Hosp Psychiatry. 2009;31(1):1-7. [pmid: 19134502].
129 Ciliberto N, Bossie CA, Urioste R, et al. Lack of impact of race on the efficacy and safety of long-acting risperidone versus placebo in patients with schizophrenia or schizoaffective disorder. Int Clin Psychopharmacol. 2005;20(4):207-12. [pmid: 15933481].
130 Citrome L, Volavka J, Czobor P, et al. Efficacy of ziprasidone against hostility in schizophrenia: post hoc analysis of randomized, open-label study data. J Clin Psychiatry. 2006;67(4):638-42. [pmid: 16669729].
131 Citrome L, Casey DE, Daniel DG, et al. Adjunctive divalproex and hostility among patients with schizophrenia receiving olanzapine or risperidone. Psychiatr Serv. 2004;55(3):290-4. [pmid: 15001730].
132 Citrome L, Shope CB, Nolan KA, et al. Risperidone alone versus risperidone plus valproate in the treatment of patients with schizophrenia and hostility. Int Clin Psychopharmacol. 2007;22(6):356-62. [pmid: 17917554].
133 Citrome L, Stauffer VL, Chen L, et al. Olanzapine plasma concentrations after treatment with 10, 20, and 40 mg/d in patients with schizophrenia: an analysis of correlations with efficacy, weight gain, and prolactin concentration. J Clin Psychopharmacol. 2009;29(3):278-83. [pmid: 19440083].
134 Ciudad A, Olivares JM, Bousono M, et al. Improvement in social functioning in outpatients with schizophrenia with prominent negative symptoms treated with olanzapine or risperidone in a 1 year randomized, open-label trial. Prog Neuropsychopharmacol Biol Psychiatry. 2006;30(8):1515-22. [pmid: 16820255].
135 Cohen BM, Lipinski JF, Waternaux C. A fixed dose study of the plasma concentration and clinical effects of thioridazine and its major metabolites. Psychopharmacology. 1989;97(4):481-8. [pmid: 2498945].
136 Cohen H, Loewenthal U, Matar M, et al. Association of autonomic dysfunction and clozapine: Heart rate variability and risk for sudden death in patients with schizophrenia on long-term psychotropic medication. Br J Psychiatry. 2001;179:167-71. [pmid: 11483480].
137 Coley KC, Carter CS, DaPos SV, et al. Effectiveness of antipsychotic therapy in a naturalistic setting: a comparison between risperidone, perphenazine, and haloperidol. J Clin Psychiatry. 1999;60(12):850-6. [pmid: 10665632].
138 Colom F, Vieta E, Martinez-Aran A, et al. Clinical factors associated with treatment noncompliance in euthymic bipolar patients. J Clin Psychiatry. 2000;61(8):549-55. [pmid: 10982196].
139 Colonna L, Saleem P, Dondey-Nouvel L, et al. Long-term safety and efficacy of amisulpride in subchronic or chronic schizophrenia: Amisulpride Study Group. Int Clin Psychopharmacol. 2000;15(1):13-22. [pmid: 10836281].
140 Comaty JE, Advokat C. “Real world” study of antipsychotic effectiveness for chronic inpatients with schizophrenia in a state psychiatric hospital: Preliminary results and commentary. J Ment Health. 2006;15(1):57-62.
141 Conley RR, Kelly DL, Nelson MW, et al. Risperidone, quetiapine, and fluphenazine in the treatment of patients with therapy-refractory schizophrenia. Clin Neuropharmacol. 2005;28(4):163-8. [pmid: 16062094].
142 Conley RR, Mahmoud R. A randomized double-blind study of risperidone and olanzapine in the treatment of schizophrenia or schizoaffective disorder. Am J Psychiatry. 2001;158(5):758-64. [pmid: 11329399].
143 Cookson J, Keck PE Jr., Ketter TA, et al. Number needed to treat and time to response/remission for quetiapine monotherapy efficacy in acute bipolar depression: evidence from a large, randomized, placebo-controlled study. Int Clin Psychopharmacol. 2007;22(2):93-100. [pmid: 17293709].
144 Cooper D, Moisan J, Gaudet M, et al. Ambulatory use of olanzapine and risperidone: A population-based study on persistence and the use of concomitant therapy in the treatment of schizophrenia. Can J Psychiatry. 2005;50(14):901-8. [pmid: 16494259].
145 Cooper D, Moisan J, Abdous B, et al. A population-based cost-effectiveness analysis of olanzapine and risperidone among ambulatory patients with schizophrenia. Can J Clin Pharmacol. 2008;15(3):e385-e397. [pmid: 18953083].
146 Cooper SJ, Butler A, Tweed J, et al. Zotepine in the prevention of recurrence: a randomised, double-blind, placebo-controlled study for chronic schizophrenia. Psychopharmacology. 2000;150(3):237-43. [pmid: 10923750].
147 Cooper SJ, Tweed J, Raniwalla J, et al. A placebo-controlled comparison of zotepine versus chlorpromazine in patients with acute exacerbation of schizophrenia. Acta Psychiatr Scand. 2000;101(3):218-25. [pmid: 10721870].
148 Cordes J, Falkai P, Guse B, et al. Repetitive transcranial magnetic stimulation for the treatment of negative symptoms in residual schizophrenia: rationale and design of a sham-controlled, randomized multicenter study. Eur Arch Psychiatry Clin Neurosci. 2009;259(SUPPL. 2).
149 Correll CU, Frederickson AM, Kane JM, et al. Equally increased risk for metabolic syndrome in patients with bipolar disorder and schizophrenia treated with second-generation antipsychotics. Bipolar Disord. 2008;10(7):788-97. [pmid: 19032710].
150 Corrigan MH, Gallen CC, Bonura ML, et al. Effectiveness of the selective D4 antagonist sonepiprazole in schizophrenia: a placebo-controlled trial. Biol Psychiatry. 2004;55(5):445-51. [pmid: 15023570].
151 Corripio I, Catafau AM, Perez V, et al. Striatal dopaminergic D2 receptor occupancy and clinical efficacy in psychosis exacerbation: a 123I-IBZM study with ziprasidone and haloperidol. Prog Neuropsychopharmacol Biol Psychiatry. 2005;29(1):91-6. [pmid: 15610950].
152 Covington L, Cola PA. Clozapine vs. Haloperidol: antipsychotic effects on sexual function in schizophrenia. Sex Disabil. 2000;18(1):41-8.
153 Cramer JA, Sernyak M. Results of a naturalistic study of treatment options: Switching atypical antipsychotic drugs or augmenting with valproate. Clin Ther. 2004;26(6):905-14. [pmid: 15262461].
154 Crespo-Facorro B, Perez-Iglesias R, Ramirez-Bonilla M, et al. A practical clinical trial comparing haloperidol, risperidone, and olanzapine for the acute treatment of first-episode nonaffective psychosis. J Clin Psychiatry. 2006;67(10):1511-21. [pmid: 17107241].
155 Crespo-Facorro B, Carrasco-Marin E, Perez-Iglesias R, et al. Interleukin-12 plasma levels in drug-naive patients with a first episode of psychosis: effects of antipsychotic drugs. Psychiatry Res. 2008;158(2):206-16. [pmid: 18243335].
156 Crespo-Facorro B, Roiz-Santianez R, Perez-Iglesias R, et al. Effect of antipsychotic drugs on brain morphometry: a randomized controlled one-year followup study of haloperidol, risperidone and olanzapine. Prog Neuropsychopharmacol Biol Psychiatry. 2008;32(8):1936-43. [pmid: 18930104].
157 Crespo-Facorro B, Rodriguez-Sanchez JM, Perez-Iglesias R, et al. Neurocognitive effectiveness of haloperidol, risperidone, and olanzapine in first-episode psychosis: a randomized, controlled 1-year followup comparison. J Clin Psychiatry. 2009;70(5):717-29. [pmid: 19389335].
158 Crocq MA, Leclercq P, Guillon MS, et al. Open-label olanzapine in obsessive-compulsive disorder refractory to antidepressant treatment. Eur Psychiatry. 2002;17(5):296-7. [pmid: 12381502].
159 Csernansky JG, Mahmoud R, Brenner R. A comparison of risperidone and haloperidol for the prevention of relapse in patients with schizophrenia. N Engl J Med. 2002;346(1):16-22. [pmid: 11777998].
160 Cuesta MJ, Jalon EG, Campos MS, et al. Cognitive effectiveness of olanzapine and risperidone in first-episode psychosis. Br J Psychiatry. 2009;194(5):439-45. [pmid: 19407274].
161 Cuesta MJ, Peralta V, de Leon J. Schizophrenia syndromes associated with treatment response. Prog Neuropsychopharmacol Biol Psychiatry. 1994;18(1):87-99. [pmid: 7906897].
162 Currier GW, Chou JC, Feifel D, et al. Acute treatment of psychotic agitation: a randomized comparison of oral treatment with risperidone and lorazepam versus intramuscular treatment with haloperidol and lorazepam. J Clin Psychiatry. 2004;65(3):386-94. [pmid: 15096079].
163 Currier GW, Trenton AJ, Walsh PG, et al. A pilot, open-label safety study of quetiapine for treatment of moderate psychotic agitation in the emergency setting. J Psychiatr Pract. 2006;12(4):223-8. [pmid: 16883147].
164 Currier GW, Simpson GM. Risperidone liquid concentrate and oral lorazepam versus intramuscular haloperidol and intramuscular lorazepam for treatment of psychotic agitation. J Clin Psychiatry. 2001;62(3):153-7. [pmid: 11305699].
165 Cutler AJ, Kalali AH, Weiden PJ, et al. Four-week, double-blind, placebo- and ziprasidone-controlled trial of iloperidone in patients with acute exacerbations of schizophrenia. J Clin Psychopharmacol. 2008;28(2:Suppl 1):S20-8. [pmid: 18334909].
166 Czekalla J, Dittmann RW, Holstein W, et al. Olanzapine (Zyprexa-«) treatment in patients pre-treated with other antipsychotics: pharmacovigilance data from a large drug utilization observation (DUO) study in Germany. Germ J Psychiatry. 2005;8(3):49-59.
167 Czobor P, Volavka J. Quantitative electroencephalogram examination of effects of risperidone in schizophrenic patients. J Clin Psychopharmacol. 1993;13(5):332-42. [pmid: 7693770].
168 Czobor P, Volavka J, Meibach RC. Effect of risperidone on hostility in schizophrenia. J Clin Psychopharmacol. 1995;15(4):243-9. [pmid: 7593706].
169 Daniel DG, Wozniak P, Mack RJ, et al. Long-term efficacy and safety comparison of sertindole and haloperidol in the treatment of schizophrenia: The Sertindole Study Group. Psychopharmacol Bull. 1998;34(1):61-9. [pmid: 9564200].
170 Daniel DG, Zimbroff DL, Potkin SG, et al. Ziprasidone 80 mg/day and 160 mg/day in the acute exacerbation of schizophrenia and schizoaffective disorder: a 6-week placebo-controlled trial: Ziprasidone Study Group. Neuropsychopharmacology. 1999;20(5):491-505. [pmid: 10192829].
171 Daniel DG, Currier GW, Zimbroff DL, et al. Efficacy and safety of oral aripiprazole compared with haloperidol in patients transitioning from acute treatment with intramuscular formulations. J Psychiatr Pract. 2007;13(3):170-7. [pmid: 17522560].
172 Danion JM, Rein W, Fleurot O. Improvement of schizophrenic patients with primary negative symptoms treated with amisulpride: Amisulpride Study Group. Am J Psychiatry. 1999;156(4):610-6. [pmid: 10200742].
173 David SR, Taylor CC, Kinon BJ, et al. The effects of olanzapine, risperidone and haloperidol on plasma prolactin levels in patients with schizophrenia. Clin Ther. 2000;22(9):1085-96. [pmid: 11048906].
174 Davidson M, Galderisi S, Weiser M, et al. Cognitive effects of antipsychotic drugs in first-episode schizophrenia and schizophreniform disorder: a randomized, open-label clinical trial (EUFEST). Am J Psychiatry. 2009;166(6):675-82. [pmid: 19369319].
175 Davies LM, Lewis S, Jones PB, et al. Cost-effectiveness of first- v. second-generation antipsychotic drugs: results from a randomised controlled trial in schizophrenia responding poorly to previous therapy. Br J Psychiatry. 2007;191:14-22. [pmid: 17602120].
176 Day JC, Bentall RP, Roberts C, et al. Attitudes toward antipsychotic medication: the impact of clinical variables and relationships with health professionals. Arch Gen Psychiatry. 2005;62(7):717-24. [pmid: 15997012].
177 de Geus F, Denys D, Westenberg HGM. Effects of quetiapine on cognitive functioning in obsessive-compulsive disorder. Int Clin Psychopharmacol. 2007;22(2):77-84. [pmid: 17293707].
178 de Jesus MJ, Lima MS, Costa AN, et al. The prevalence of tardive dyskinesia after a nine month naturalistic randomized trial comparing olanzapine with conventional treatment for schizophrenia and related disorders. Eur Arch Psychiatry Clin Neurosci. 2004;254(6):356-61. [pmid: 15538607].
179 de Lima MS, de Jesus Mari J, Breier A, et al. Quality of life in schizophrenia: a multicenter, randomized, naturalistic, controlled trial comparing olanzapine to first-generation antipsychotics. J Clin Psychiatry. 2005;66(7):831-8. [pmid: 16013897].
180 de Oliveira IR, Elkis H, Gattaz WF, et al. Aripiprazole for patients with schizophrenia and schizoaffective disorder: an open-label, randomized, study versus haloperidol. CNS Spectr. 2009;14(2):93-102. [pmid: 19238124].
181 de Ronchi D, Ruggeri M, Belelli G, et al. Levosulpiride versus pimozide in negative symptoms of schizophrenia. Curr Ther Res. 1996;57(10):797-809.
182 de Sena EP, Santos-Jesus R, Miranda-Scippa A, et al. Relapse in patients with schizophrenia: a comparison between risperidone and haloperidol. Rev Bras Psiquiatr. 2003;25(4):220-3. [pmid: 15328547].
183 De HM, Schreurs V, Sweers K, et al. Typical and atypical antipsychotics differentially affect long-term incidence rates of the metabolic syndrome in first-episode patients with schizophrenia: a retrospective chart review. Schizophr Res. 2008;101(1-3):295-303. [pmid: 18299188].
184 Delieu JM, Badawoud M, Williams MA, et al. Antipsychotic drugs result in the formation of immature neutrophil leucocytes in schizophrenic patients. J Psychopharmacol. 2001;15(3):191-4. [pmid: 11565627].
185 Delieu JM, Horobin RW, Duguid JK. Formation of immature neutrophil leucocytes in schizophrenic patients treated with various antipsychotic drugs: comparisons and predictions. J Psychopharmacol. 2006;20(6):824-8. [pmid: 16401649].
186 den Boer JA, Ravelli DP, Huisman J, et al. Double blind comparative study of remoxipride and haloperidol in acute schizophrenic patients. Psychopharmacology. 1990;102(1):76-84. [pmid: 1975448].
187 Deo R, Soni S, Rastogi SC, et al. Remoxipride and haloperidol in the acute phase of schizophrenia: a double-blind comparison. Acta Psychiatr Scand Suppl. 1990;358:120-4. [pmid: 1978470].
188 Diaz E, Levine HB, Sullivan MC, et al. Use of the Medication Event Monitoring System to estimate medication compliance in patients with schizophrenia. J Psychiatry Neurosci. 2001;26(4):325-9. [pmid: 11590972].
189 Dion Y, Annable L, Sandor P, et al. Risperidone in the treatment of tourette syndrome: a double-blind, placebo-controlled trial. J Clin Psychopharmacol. 2002;22(1):31-9. [pmid: 11799340].
190 Dollfus S, Olivier V, Chabot B, et al. Olanzapine versus risperidone in the treatment of post-psychotic depression in schizophrenic patients. Schizophr Res. 2005;78(2-3):157-9. [pmid: 16102942].
191 Dolzan V, Serretti A, Mandelli L, et al. Acute antipsychotic efficacy and side effects in schizophrenia: association with serotonin transporter promoter genotypes. Prog Neuropsychopharmacol Biol Psychiatry. 2008;32(6):1562-6. [pmid: 18573584].
192 Donaldson S, Goldstein LH, Landau S, et al. The Maudsley Bipolar Disorder Project: the effect of medication, family history and duration of illness on IQ and memory in bipolar I disorder. J Clin Psychiatry. 2003;64(1):86-93. [pmid: 12590629].
193 Dyck DG, Short RA, Hendryx MS, et al. Management of negative symptoms among patients with schizophrenia attending multiple-family groups. Psychiatr Serv. 2000;51(4):513-9. [pmid: 10737828].
194 Edwards R, Stephenson U, Flewett T. Clonazepam in acute mania: a double blind trial. Aust NZ J Psychiatry. 1991;25(2):238-42.
195 Eerdekens M, Van H I, Remmerie B, et al. Pharmacokinetics and tolerability of long-acting risperidone in schizophrenia. SCHIZOPHR RES. 2004;70(1):91-100. [pmid: 15246468].
196 Emsley R, Turner HJ, Schronen J, et al. Effects of quetiapine and haloperidol on body mass index and glycaemic control: a long-term, randomized, controlled trial. Int J Neuropsychopharmacol. 2005;8(2):175-82. [pmid: 15737251].
197 Emsley RA. Risperidone in the treatment of first-episode psychotic patients: a double-blind multicenter study: Risperidone Working Group. Schizophr Bull. 1999;25(4):721-9. [pmid: 10667742].
198 Emsley RA, Raniwalla J, Bailey PJ, et al. A comparison of the effects of quetiapine (‘seroquel’) and haloperidol in schizophrenic patients with a history of and a demonstrated, partial response to conventional antipsychotic treatment: PRIZE Study Group. Int Clin Psychopharmacol. 2000;15(3):121-31. [pmid: 10870870].
199 Emsley R, Turner HJ, Schronen J, et al. A single-blind, randomized trial comparing quetiapine and haloperidol in the treatment of tardive dyskinesia. J Clin Psychiatry. 2004;65(5):696-701. [pmid: 15163258].
200 Endicott J, Rajagopalan K, Minkwitz M, et al. A randomized, double-blind, placebo-controlled study of quetiapine in the treatment of bipolar I and II depression: improvements in quality of life. Int Clin Psychopharmacol. 2007;22(1):29-37. [pmid: 17159457].
201 Endicott J, Paulsson B, Gustafsson U, et al. Quetiapine monotherapy in the treatment of depressive episodes of bipolar I and II disorder: improvements in quality of life and quality of sleep. J Affect Disord. 2008;111(2-3):306-19. [pmid: 18774180].
202 Erzegovesi S, Guglielmo E, Siliprandi F, et al. Low-dose risperidone augmentation of fluvoxamine treatment in obsessive-compulsive disorder: a double-blind, placebo-controlled study. Eur Neuropsychopharmacol. 2005;15(1):69-74. [pmid: 15572275].
203 Esen-Danaci A, Sarandol A, Taneli F, et al. Effects of second generation antipsychotics on leptin and ghrelin. Prog Neuropsychopharmacol Biol Psychiatry. 2008;32(6):1434-8. [pmid: 18579280].
204 Essock SM, Covell NH, Davis SM, et al. Effectiveness of switching antipsychotic medications. Am J Psychiatry. 2006;163(12):2090-5. [pmid: 17151159].
205 Fabre LF Jr., Arvanitis L, Pultz J, et al. ICI 204,636, a novel, atypical antipsychotic: early indication of safety and efficacy in patients with chronic and subchronic schizophrenia. Clin Ther. 1995;17(3):366-78. [pmid: 7585841].
206 Fagerlund B, Mackeprang T, Gade A, et al. Effects of low-dose risperidone and low-dose zuclopenthixol on cognitive functions in first-episode drug-naive schizophrenic patients. CNS Spectr. 2004;9(5):364-74. [pmid: 15115949].
207 Fakra E, Khalfa S, Da FD, et al. Effect of risperidone versus haloperidol on emotional responding in schizophrenic patients. Psychopharmacology. 2008;200(2):261-72. [pmid: 18575849].
208 Faries DE, Scher-Svanum H, Nyhuis AW, et al. Switching from risperidone to olanzapine in a one-year, randomized, open-label effectiveness study of schizophrenia. Curr Med Res Opin. 2008;24(5):1399-405. [pmid: 18397549].
209 Fava M, Wisniewski SR, Thase ME, et al. Metabolic assessment of aripiprazole as adjunctive therapy in major depressive disorder: a pooled analysis of 2 studies. J Clin Psychopharmacol. 2009;29(4):362-7. [pmid: 19593176].
210 Feldman D, Goldberg JF. A preliminary study of the relationship between clozapine-induced weight gain and menstrual irregularities in schizophrenic, schizoaffective, and bipolar women. Ann Clin Psychiatry. 2002;14(1):17-21. [pmid: 12046636].
211 Feldman PD, Kaiser CJ, Kennedy JS, et al. Comparison of risperidone and olanzapine in the control of negative symptoms of chronic schizophrenia and related psychotic disorders in patients aged 50 to 65 years. J Clin Psychiatry. 2003;64(9):998-1004. [pmid: 14628974].
212 Fiedorowicz JG, Palagummi NM, Forman-Hoffman VL, et al. Elevated prevalence of obesity, metabolic syndrome, and cardiovascular risk factors in bipolar disorder. Ann Clin Psychiatry. 2008;20(3):131-7. [pmid: 18633739].
213 Fleischhacker WW, Eerdekens M, Karcher K, et al. Treatment of schizophrenia with long-acting injectable risperidone: a 12-month open-label trial of the first long-acting second-generation antipsychotic. J Clin Psychiatry. 2003;64(10):1250-7. [pmid: 14658976].
214 Fleischhacker WW, McQuade RD, Marcus RN, et al. A double-blind, randomized comparative study of aripiprazole and olanzapine in patients with schizophrenia. Biol Psychiatry. 2009;65(6):510-7. [pmid: 18986646].
215 Fortier P, Mottard JP, Trudel G, et al. Study of sexuality-related characteristics in young adults with schizophrenia treated with novel neuroleptics and in a comparison group of young adults. Schizophr Bull. 2003;29(3):559-72. [pmid: 14609249].
216 Freudenreich O, Henderson DC, Walsh JP, et al. Risperidone augmentation for schizophrenia partially responsive to clozapine: a double-blind, placebo-controlled trial. Schizophr Res. 2007;92(1-3):90-4. [pmid: 17321111].
217 Fujikawa M, Togo T, Yoshimi A, et al. Evaluation of subjective treatment satisfaction with antipsychotics in schizophrenia patients. Prog Neuropsychopharmacol Biol Psychiatry. 2008;32(3):755-60. [pmid: 18226436].
218 Gaebel W, Moller HJ, Buchkremer G, et al. Pharmacological long-term treatment strategies in first episode schizophrenia: study design and preliminary results of an ongoing RCT within the German Research Network on Schizophrenia. Eur Arch Psychiatry Clin Neurosci. 2004;254(2):129-40. [pmid: 15146342].
219 Gaebel W, Riesbeck M, Wolwer W, et al. Maintenance treatment with risperidone or low-dose haloperidol in first-episode schizophrenia: 1-year results of a randomized controlled trial within the German research network on schizophrenia. J Clin Psychiatry. 2007;68(11):1763-74. [pmid: 18052570].
220 Gagiano C, Read S, Thorpe L, et al. Short- and long-term efficacy and safety of risperidone in adults with disruptive behavior disorders. Psychopharmacology. 2005;179(3):629-36. [pmid: 15668818].
221 Gallhofer B, Jaanson P, Mittoux A, et al. Course of recovery of cognitive impairment in patients with schizophrenia: a randomised double-blind study comparing sertindole and haloperidol. Pharmacopsychiatry. 2007;40(6):275-86. [pmid: 18030652].
222 Ganguli R, Brar JS, Mahmoud R, et al. Assessment of strategies for switching patients from olanzapine to risperidone: a randomized, open-label, rater-blinded study. BMC Med. 2008;6:17. [pmid: 18590519].
223 Garakani A. A randomized, double-blind, and placebo-controlled trial of quetiapine augmentation of fluoxetine in major depressive disorder. Int Clin Psychopharmacol. 2008;(5):269-75. [pmid: 18703936].
224 Garcia E, Robert M, Peris F, et al. The efficacy and safety of blonanserin compared with haloperidol in acute-phase schizophrenia: a randomized, double-blind, placebo-controlled, multicentre study. CNS Drugs. 2009;23(7):615-25. [pmid: 19552488].
225 Garza-Trevino ES, Hollister LE, Overall JE, et al. Efficacy of combinations of intramuscular antipsychotics and sedative-hypnotics for control of psychotic agitation. Am J Psychiatry. 1989;146(12):1598-601. [pmid: 2686478].
226 Gaszner P, Makkos Z. Clozapine maintenance therapy in schizophrenia. Prog Neuropsychopharmacol Biol Psychiatry. 2004;28(3):465-9. [pmid: 15093952].
227 Gau SSF, Chung CH, Gau CS. A pharmacoeconomic analysis of atypical antipsychotics and haloperidol in first-episode schizophrenic patients in Taiwan. J Clin Psychopharmacol. 2008;28(3):271-8. [pmid: 18480683].
228 Gebhardt S, Haberhausen M, Heinzel-Gutenbrunner M, et al. Antipsychotic-induced body weight gain: predictors and a systematic categorization of the long-term weight course. J Psychiatr Res. 2009;43(6):620-6. [pmid: 19110264].
229 Germana B. Clinical therapeutic experience with bromperidol-a double-blind study. Rivista di Psichiatria. 1990;(4):233-5.
230 Ghaemi SN, Sachs GS. Long-term risperidone treatment in bipolar disorder: 6-month followup. Int Clin Psychopharmacol. 1997;12(6):333-8. [pmid: 9547135].
231 Ghaemi SN, Hsu DJ, Rosenquist KJ, et al. Extrapyramidal side effects with atypical neuroleptics in bipolar disorder. Prog Neuropsychopharmacol Biol Psychiatry. 2006;30(2):209-13. [pmid: 16412546].
232 Gharabawi GM, Greenspan A, Rupnow MF, et al. Reduction in psychotic symptoms as a predictor of patient satisfaction with antipsychotic medication in schizophrenia: data from a randomized double-blind trial. BMC Psychiatry. 2006;6:45. [pmid: 17054789].
233 Gharabawi G, Bossie C, Turkoz I, et al. The impact of insight on functioning in patients with schizophrenia or schizoaffective disorder receiving risperidone long-acting injectable. J Nerv Ment Dis. 2007;195(12):976-82. [pmid: 18091190].
234 Gharabawi GM, Gearhart NC, Lasser RA, et al. Maintenance therapy with once-monthly administration of long-acting injectable risperidone in patients with schizophrenia or schizoaffective disorder: a pilot study of an extended dosing interval. Ann Gen Psychiatry. 2007;6.
235 Gianfrancesco FD, Sajatovic M, Rajagopalan K, et al. The association between treatment adherence and antipsychotic dose among individuals with bipolar disorder. Int Clin Psychopharmacol. 2008;23(6):305-16. [pmid: 18854718].
236 Gibel A, Ritsner MS. Neurocognitive effects of ziprasidone and related factors in patients with chronic schizophrenia undergoing usual care: a 12-month, open-label, flexible-dose, naturalistic observational trial. Clin Neuropharmacol. 2008;31(4):204-20. [pmid: 18670244].
237 Gitlin M, Nuechterlein K, Subotnik KL, et al. Clinical outcome following neuroleptic discontinuation in patients with remitted recent-onset schizophrenia. Am J Psychiatry. 2001;158(11):1835-42. [pmid: 11691689].
238 Glick ID, Zaninelli R, Hsu C, et al. Patterns of concomitant psychotropic medication use during a 2-year study comparing clozapine and olanzapine for the prevention of suicidal behavior. J Clin Psychiatry. 2004;65(5):679-85. [pmid: 15163255].
239 Goder R, Fritzer G, Gottwald B, et al. Effects of olanzapine on slow wave sleep, sleep spindles and sleep-related memory consolidation in schizophrenia. Pharmacopsychiatry. 2008;41(3):92-9. [pmid: 18484550].
240 Godleski LS, Goldsmith LJ, Vieweg WV, et al. Switching from depot antipsychotic drugs to olanzapine in patients with chronic schizophrenia. J Clin Psychiatry. 2003;64(2):119-22. [pmid: 12633119].
241 Goff DC, Posever T, Herz L, et al. An exploratory haloperidol-controlled dose-finding study of ziprasidone in hospitalized patients with schizophrenia or schizoaffective disorder. J Clin Psychopharmacol. 1998;18(4):296-304. [pmid: 9690695].
242 Goldberg JF, Perlis RH, Ghaemi SN, et al. Adjunctive antidepressant use and symptomatic recovery among bipolar depressed patients with concomitant manic symptoms: Findings from the STEP-BD. Am J Psychiatry. 2007;164(9):1348-55. [pmid: 17728419].
243 Goldberg JF, Kelley ME, Rosenquist KJ, et al. Effectiveness of quetiapine in rapid cycling bipolar disorder: a preliminary study. J Affect Disord. 2008;105(1-3):305-10. [pmid: 17550787].
244 Golden G, Honigfeld G. Bioequivalence of clozapine orally disintegrating 100-mg tablets compared with clozapine solid oral 100-mg tablets after multiple doses in patients with schizophrenia. Clin Drug Invest. 2008;28(4):231-9.
245 Gomez JC, Sacristan JA, Hernandez J, et al. The safety of olanzapine compared with other antipsychotic drugs: results of an observational prospective study in patients with schizophrenia (EFESO Study): pharmacoepidemiologic study of olanzapine in schizophrenia. J Clin Psychiatry. 2000;61(5):335-43. [pmid: 10847307].
246 Gopal S, Steffens DC, Kramer ML, et al. Symptomatic remission in patients with bipolar mania: results from a double-blind, placebo-controlled trial of risperidone monotherapy. J Clin Psychiatry. 2005;66(8):1016-20. [pmid: 16086617].
247 Gorobets LN. Effect of therapy with atypical antipsychotic drugs on prolactin concentration in patients with schizophrenia and schizoaffective disorders. Bull Exp Biol Med. 2005;140(6):714-5. [pmid: 16848233].
248 Gram LF. Acute and continuation therapy in unipolar depression: observations from the run-in phase of a maintenance trial. Acta Psychiatr Scand. 2008;(2):123-9. [pmid: 18384466].
249 Green AI, Tohen MF, Hamer RM, et al. First episode schizophrenia-related psychosis and substance use disorders: acute response to olanzapine and haloperidol. Schizophr Res. 2004;66(2-3):125-35. [pmid: 15061244].
250 Green AI, Lieberman JA, Hamer RM, et al. Olanzapine and haloperidol in first episode psychosis: two-year data. Schizophr Res. 2006;86(1-3):234-43. [pmid: 16887334].
251 Green MF, Marder SR, Glynn SM, et al. The neurocognitive effects of low-dose haloperidol: a two-year comparison with risperidone. Biol Psychiatry. 2002;51(12):972-8. [pmid: 12062881].
252 Guardia J, Segura L, Gonzalvo B, et al. A double-blind, placebo-controlled study of olanzapine in the treatment of alcohol-dependence disorder. Alcohol Clin Exp Res. 2004;28(5):736-45. [pmid: 15166648].
253 Gunther W, Baghai T, Naber D, et al. EEG alterations and seizures during treatment with clozapine: a retrospective study of 283 patients. Pharmacopsychiatry. 1993;26(3):69-74. [pmid: 8415896].
254 Guo JJ, Keck PE Jr., Corey-Lisle PK, et al. Risk of diabetes mellitus associated with atypical antipsychotic use among patients with bipolar disorder: a retrospective, population-based, case-control study. J Clin Psychiatry. 2006;67(7):1055-61. [pmid: 16889448].
255 Gurpegui M, Alvarez E, Bousono M, et al. Effect of olanzapine or risperidone treatment on some cognitive functions in a one-year followup of schizophrenia outpatients with prominent negative symptoms. Eur Neuropsychopharmacol. 2007;17(11):725-34. [pmid: 17543505].
256 Haessler F, Glaser T, Beneke M, et al. Zuclopenthixol in adults with intellectual disabilities and aggressive behaviors: discontinuation study. Br J Psychiatry. 2007;190:447-8. [pmid: 17470962].
257 Hamilton SH, Revicki DA, Genduso LA, et al. Olanzapine versus placebo and haloperidol: quality of life and efficacy results of the North American double-blind trial. Neuropsychopharmacology. 1998;18(1):41-9. [pmid: 9408917].
258 Han C, Lee BH, Kim YK, et al. Satisfaction of patients and caregivers with long-acting injectable risperidone and oral atypical antipsychotics. Prim Care Community Psychiatr. 2005;10(3):119-24.
259 Hanssens L, L'Italien G, Loze JY, et al. The effect of antipsychotic medication on sexual function and serum prolactin levels in community-treated schizophrenic patients: results from the Schizophrenia Trial of Aripiprazole (STAR) study (NCT00237913). BMC Psychiatry. 2008;8.
260 Haro JM, Novick D, Suarez D, et al. Antipsychotic treatment discontinuation in previously untreated patients with schizophrenia: 36-month results from the SOHO study. J Psychiatr Res. 2009;43(3):265-73. [pmid: 18644606].
261 Harrigan EP, Miceli JJ, Anziano R, et al. A randomized evaluation of the effects of six antipsychotic agents on QTc, in the absence and presence of metabolic inhibition. J Clin Psychopharmacol. 2004;24(1):62-9. [pmid: 14709949].
262 Harvey PD, Green MF, McGurk SR, et al. Changes in cognitive functioning with risperidone and olanzapine treatment: a large-scale, double-blind, randomized study. Psychopharmacology. 2003;169(3-4):404-11. [pmid: 12590356].
263 Harvey PD, Meltzer H, Simpson GM, et al. Improvement in cognitive function following a switch to ziprasidone from conventional antipsychotics, olanzapine, or risperidone in outpatients with schizophrenia. Schizophr Res. 2004;66(2-3):101-13. [pmid: 15061242].
264 Harvey PD, Patterson TL, Potter LS, et al. Improvement in social competence with short-term atypical antipsychotic treatment: a randomized, double-blind comparison of quetiapine versus risperidone for social competence, social cognition, and neuropsychological functioning. Am J Psychiatry. 2006;163(11):1918-25. [pmid: 17074943].
265 Harvey PD, Siu CO, Romano S. Randomized, controlled, double-blind, multicenter comparison of the cognitive effects of ziprasidone versus olanzapine in acutely ill inpatients with schizophrenia or schizoaffective disorder. Psychopharmacology. 2004;172(3):324-32. [pmid: 14615877].
266 Harvey PD, Rabinowitz J, Eerdekens M, et al. Treatment of cognitive impairment in early psychosis: a comparison of risperidone and haloperidol in a large long-term trial. Am J Psychiatry. 2005;162(10):1888-95. [pmid: 16199835].
267 Harvey PD, Bowie CR, Loebel A. Neuropsychological normalization with long-term atypical antipsychotic treatment: results of a six-month randomized, double-blind comparison of ziprasidone vs. olanzapine. J Neuropsychiatry Clin Neurosci. 2006;18(1):54-63. [pmid: 16525071].
268 Hasan S, Buckley P. Novel antipsychotics and the neuroleptic malignant syndrome: a review and critique. [review]. Am J Psychiatry. 1998;155(8):1113-6. [pmid: 9699705].
269 Hassan M, Madhavan SS, Kalsekar ID, et al. Comparing adherence to and persistence with antipsychotic therapy among patients with bipolar disorder. Ann Pharmacother. 2007;41(11):1812-8. [pmid: 17925501].
270 Hassler F, Glaser T, Pap AF, et al. A double-blind placebo-controlled discontinuation study of zuclopenthixol for the treatment of aggressive disruptive behaviors in adults with mental retardation: secondary parameter analyses. Pharmacopsychiatry. 2008;41(6):232-9. [pmid: 19067260].
271 Hatim A, Habil H, Jesjeet SG, et al. Safety and efficacy of rapid dose administration of quetiapine in bipolar mania. Hum Psychopharmacol. 2006;21(5):313-8. [pmid: 16856220].
272 Hatta K, Sato K, Hamakawa H, et al. Effectiveness of second-generation antipsychotics with acute-phase schizophrenia. Schizophr Res. 2009;113(1):49-55. [pmid: 19553086].
273 Haupt DW, Fahnestock PA, Flavin KA, et al. Adiposity and insulin sensitivity derived from intravenous glucose tolerance tests in antipsychotic-treated patients. Neuropsychopharmacology. 2007;32(12):2561-9. [pmid: 17375138].
274 Haupt DW, Rosenblatt LC, Kim E, et al. Prevalence and predictors of lipid and glucose monitoring in commercially insured patients treated with second-generation antipsychotic agents. Am J Psychiatry. 2009;166(3):345-53. [pmid: 19147694].
275 Hebenstreit GF, Laux G, Schubert H, et al. A double-blind comparative multicentre study of controlled-release remoxipride, immediate-release remoxipride and haloperidol in schizophrenia. Pharmacopsychiatry. 1991;24(5):153-8. [pmid: 1685572].
276 Heck AH, Haffmans PMJ, de Groot IW, et al. Risperidone versus haloperidol in psychotic patients with disturbing neuroleptic-induced extrapyramidal symptoms: a double-blind, multi-center trial. Schizophr Res. 2000;46(2-3):97-105. [pmid: 11120421].
277 Heinrich K, Klieser E, Lehmann E, et al. Risperidone versus clozapine in the treatment of schizophrenic patients with acute symptoms: a double blind, randomized trial. Prog Neuropsychopharmacol Biol Psychiatry. 1994;18(1):129-37. [pmid: 7509495].
278 Hempel RJ, Tulen JH, van Beveren NJ, et al. Cardiovascular variability during treatment with haloperidol, olanzapine or risperidone in recent-onset schizophrenia. J Psychopharmacol. 2009;23(6):697-707. [pmid: 18562420].
279 Henderson DC, Cagliero E, Copeland PM, et al. Elevated hemoglobin ale as a possible indicator of diabetes mellitus and diabetic ketoacidosis in schizophrenia patients receiving atypical antipsychotics. J Clin Psychiatry. 2007;68(4):533-41. [pmid: 17474808].
280 Henderson DC, Fan X, Copeland PM, et al. Aripiprazole added to overweight and obese olanzapine-treated schizophrenia patients. J Clin Psychopharmacol. 2009;29(2):165-9. [pmid: 19512978].
281 Hennen J, Perlis RH, Sachs G, et al. Weight gain during treatment of bipolar I patients with olanzapine. J Clin Psychiatry. 2004;65(12):1679-87. [pmid: 15641874].
282 Heresco-Levy U, Greenberg D, Lerer B, et al. Trial of maintenance neuroleptic dose reduction in schizophrenic outpatients: two-year outcome. J Clin Psychiatry. 1993;54(2):59-62. [pmid: 8095259].
283 Hertling I, Philipp M, Dvorak A, et al. Flupenthixol versus risperidone: subjective quality of life as an important factor for compliance in chronic schizophrenic patients. Neuropsychobiology. 2003;47(1):37-46. [pmid: 12606844].
284 Heydebrand G, Weiser M, Rabinowitz J, et al. Correlates of cognitive deficits in first episode schizophrenia. Schizophr Res. 2004;68(1):1-9. [pmid: 15037334].
285 Hirsch SR, Barnes TR, Dickinson M, et al. A double-blind comparison of raclopride and haloperidol in the acute phase of schizophrenia: The British Isles Raclopride Study Group. Acta Psychiatr Scand. 1992;86(5):391-8. [pmid: 1485530].
286 Hirsch SR, Kissling W, Bauml J, et al. A 28-week comparison of ziprasidone and haloperidol in outpatients with stable schizophrenia. J Clin Psychiatry. 2002;63(6):516-23. [pmid: 12088164].
287 Hirschfeld RM, Baker JD, Wozniak P, et al. The safety and early efficacy of oral-loaded divalproex versus standard-titration divalproex, lithium, olanzapine, and placebo in the treatment of acute mania associated with bipolar disorder. J Clin Psychiatry. 2003;64(7):841-6. [pmid: 12934987].
288 Hirschfeld RMA, Weisler RH, Raines SR, et al. Quetiapine in the treatment of anxiety in patients with bipolar I or II depression: a secondary analysis from a randomized, double-blind, placebo-controlled study. J Clin Psychiatry. 2006;67(3):355-62. [pmid: 16649820].
289 Ahlfors UG, Rimön R, Appelberg B, et al. Remoxipride and haloperidol in schizophrenia: a double-blind multicentre study. Acta Psychiatr Scand Suppl. 1990;358:99-103. [pmid: 1978501].
290 Ho BC, Miller D, Nopoulos P, et al. A comparative effectiveness study of risperidone and olanzapine in the treatment of schizophrenia. J Clin Psychiatry. 1999;60(10):658-63. [pmid: 10549681].
291 Hoencamp E, Knegtering H, Kooy JJ, et al. Patient requests and attitude towards neuroleptics. Nord J Psychiatry. 1995;49(Suppl 35):47-55.
292 Hofer A, Rettenbacher MA, Edlinger M, et al. Outcomes in schizophrenia outpatients treated with amisulpride or olanzapine. Pharmacopsychiatry. 2007;40(1):1-8. [pmid: 17327953].
293 Hogan TP, Awad AG. Subjective response to neuroleptics and outcome in schizophrenia: a re-examination comparing two measures. Psychol Med. 1992;22(2):347-52. [pmid: 1615101].
294 Hogarty GE, McEvoy JP, Munetz M, et al. Dose of fluphenazine, familial expressed emotion, and outcome in schizophrenia: results of a two-year controlled study. Arch Gen Psychiatry. 1988;45(9):797-805. [pmid: 3415422].
295 Honer WG, Kopala LC, Rabinowitz J. Extrapyramidal symptoms and signs in first-episode, antipsychotic exposed and non-exposed patients with schizophrenia or related psychotic illness. J Psychopharmacol. 2005;19(3):277-85. [pmid: 15888513].
296 Hong X, Chan RC, Zhuang X, et al. Neuroleptic effects on P50 sensory gating in patients with first-episode never-medicated schizophrenia. Schizophr Res. 2009;108(1-3):151-7. [pmid: 19106034].
297 Hovens JE, Dries PJ, Melman CT, et al. Oral risperidone with lorazepam versus oral zuclopenthixol with lorazepam in the treatment of acute psychosis in emergency psychiatry: a prospective, comparative, open-label study. J Psychopharmacol. 2005;19(1):51-7. [pmid: 15671129].
298 Hugenholtz GW, Heerdink ER, Meijer WE, et al. Reasons for switching between antipsychotics in daily clinical practice. Pharmacopsychiatry. 2005;38(3):122-4. [pmid: 15902582].
299 Hugenholtz GWK, Heerdink ER, Nolen WA, et al. Less medication switching after initial start with atypical antipsychotics. Eur Neuropsychopharmacol. 2004;14(1):1-5. [pmid: 14659981].
300 Huq ZU, RIS GBR. A trial of low doses of risperidone in the treatment of patients with first-episode schizophrenia, schizophreniform disorder, or schizoaffective disorder. J Clin Psychopharmacol. 2004;24(2):220-4. [pmid: 15206670].
301 Huttunen MO, Piepponen T, Rantanen H, et al. Risperidone versus zuclopenthixol in the treatment of acute schizophrenic episodes: a double-blind parallel-group trial. Acta Psychiatr Scand. 1995;91(4):271-7. [pmid: 7542829].
302 Inada T, Yagi G, Miura S. Extrapyramidal symptom profiles in Japanese patients with schizophrenia treated with olanzapine or haloperidol. Schizophr Res. 2002;57(2-3):227-38. [pmid: 12223254].
303 Ingole S, Belorkar NR, Waradkar P, et al. Comparison of effects of olanzapine and risperidone on body mass index and blood sugar level in schizophrenic patients. Indian J Physiol Pharmacol. 2009;53(1):47-54. [pmid: 19810576].
304 Ishak KJ, Tan Y, Glass J, et al. Risk of discontinuation of risperidone after exposure to potentially interacting drugs: a nested case-control study in patients with schizophrenia. Clin Ther. 2008;30(7):1251-63. [pmid: 18691984].
305 Izmeth MG, Khan SY, Kumarajeewa DI, et al. Zuclopenthixol decanoate in the management of behavioral disorders in mentally handicapped patients. Pharmatherapeutica. 1988;5(4):217-27. [pmid: 2902642].
306 Janicak PG, Javaid JI, Sharma RP, et al. A two-phase, double-blind randomized study of three haloperidol plasma levels for acute psychosis with reassignment of initial non-responders. Acta Psychiatr Scand. 1997;95(4):343-50. [pmid: 9150830].
307 Janno S, Holi MM, Tuisku K, et al. Actometry and Barnes Akathisia Rating Scale in neuroleptic-induced akathisia. Eur Neuropsychopharmacol. 2005;15(1):39-41. [pmid: 15572272].
308 Janssen B, Gaebel W, Haerter M, et al. Evaluation of factors influencing medication compliance in inpatient treatment of psychotic disorders. Psychopharmacology. 2006;187(2):229-36. [pmid: 16710714].
309 Jerrell JM. Cost-effectiveness of risperidone, olanzapine, and conventional antipsychotic medications. Schizophr Bull. 2002;28(4):589-605. [pmid: 12795493].
310 Jerrell JM, Ramirez PM. Changes in neuropsychological functioning following treatment with risperidone, olanzapine, and conventional antipsychotic medications. Hum Psychopharmacol. 2008;23(7):595-604. [pmid: 18680213].
311 Jessani M, Montgomery J, Fedde JD, et al. Lack of association between antipsychotics and hyponatremia in chronic schizophrenia. Schizophr Res. 2006;83(2-3):307-9. [pmid: 16504483].
312 Jin H, Meyer JM, Jeste DV. Phenomenology of and risk factors for new-onset diabetes mellitus and diabetic ketoacidosis associated with atypical antipsychotics: an analysis of 45 published cases. Ann Clin Psychiatry. 2002;14(1):59-64. [pmid: 12046641].
313 Johnstone EC, Owens DG, Crow TJ, et al. Does a four-week delay in the introduction of medication alter the course of functional psychosis?. J Psychopharmacol. 1999;13(3):238-44. [pmid: 10512078].
314 Jones PB, Barnes TR, Davies L, et al. Randomized controlled trial of the effect on Quality of Life of second- vs first-generation antipsychotic drugs in schizophrenia: Cost Utility of the Latest Antipsychotic Drugs in Schizophrenia Study (CUtLASS 1). Arch Gen Psychiatry. 2006;63(10):1079-87. [pmid: 17015810].
315 Jones PB, Barnes TRE, Davies L, et al. Randomized controlled trial of the effect on quality of life of second- vs first-generation antipsychotic drugs in schizophrenia. Arch Gen Psychiatry. 2006;63(10):1079-87. [pmid: 17015810].
316 Josiassen RC, Joseph A, Kohegyi E, et al. Clozapine augmented with risperidone in the treatment of schizophrenia: a randomized, double-blind, placebo-controlled trial. Am J Psychiatry. 2005;162(1):130-6. [pmid: 15625211].
317 Kagerer S, Winter C, Moller HJ, et al. Effects of haloperidol and atypical neuroleptics on psychomotor performance and driving ability in schizophrenic patients: results from an experimental study. Neuropsychobiology. 2003;47(4):212-8. [pmid: 12824745].
318 Kahn RS, Fleischhacker WW, Boter H, et al. Effectiveness of antipsychotic drugs in first-episode schizophrenia and schizophreniform disorder: an open randomised clinical trial. Lancet. 2008;371(9618):1085-97. [pmid: 18374841].
319 Kahn RS, Schulz C, Palazov VD, et al. Efficacy and tolerability of once-daily extended release quetiapine fumarate in acute schizophrenia: A randomized, double-blind, placebo-controlled study. J Clin Psychiatry. 2007;68(6):832-42. [pmid: 17592906].
320 Kampman KM, Pettinati H, Lynch KG, et al. A pilot trial of olanzapine for the treatment of cocaine dependence. Drug Alcohol Dependence. 2003;70(3):265-73.
321 Kane JM, Eerdekens M, Lindenmayer JP, et al. Long-acting injectable risperidone: efficacy and safety of the first long-acting atypical antipsychotic. Am J Psychiatry. 2003;160(6):1125-32. [pmid: 12777271].
322 Kane JM, Detke HC, Naber D, et al. Olanzapine long-acting injection: a 24-week, randomized, double-blind trial of maintenance treatment in patients with schizophrenia. Am J Psychiatry. 2010;167(2):181-9. [pmid: 20008947].
323 Kane JM, Marder SR, Schooler NR, et al. Clozapine and haloperidol in moderately refractory schizophrenia: a 6-month randomized double-blind comparison. Arch Gen Psychiatry. 2001;58(10):965-72. [pmid: 11576036].
324 Kane JM, Osuntokun O, Kryzhanovskaya LA, et al. A 28-week, randomized, double-blind study of olanzapine versus aripiprazole in the treatment of schizophrenia. J Clin Psychiatry. 2009;70(4):572-81. [pmid: 19323965].
325 Kapur S, Arenovich T, Agid O, et al. Evidence for onset of antipsychotic effects within the first 24 hours of treatment. Am J Psychiatry. 2005;162(5):939-46. [pmid: 15863796].
326 Kapur S, Roy P, Daskalakis J, et al. Increased dopamine D2 receptor occupancy and elevated prolactin level associated with addition of haloperidol to clozapine. Am J Psychiatry. 2001;158(2):311-4. [pmid: 11156818].
327 Karagianis J, Grossman L, Landry J, et al. A randomized controlled trial of the effect of sublingual orally disintegrating olanzapine versus oral olanzapine on body mass index: the PLATYPUS Study. Schizophr Res. 2009;113(1):41-8. [pmid: 19535229].
328 Karagianis JL, Baksh A. High-Dose Olanzapine and Prolactin Levels. J Clin Psychiatry. 2003;64(10):1192-4. [pmid: 14658967].
329 Kasper S, Lerman MN, McQuade RD, et al. Efficacy and safety of aripiprazole vs. haloperidol for long-term maintenance treatment following acute relapse of schizophrenia. Int J Neuropsychopharmacol. 2003;6(4):325-37. [pmid: 14609439].
330 Kasper S, Moller HJ, Hale A. The European post-marketing observational sertindole study: an investigation of the safety of antipsychotic drug treatment. Eur Arch Psychiatry Clin Neurosci. 2010;260(1):59-68. [pmid: 19455275].
331 Keck P Jr., Buffenstein A, Ferguson J, et al. Ziprasidone 40 and 120 mg/day in the acute exacerbation of schizophrenia and schizoaffective disorder: a 4-week placebo-controlled trial. Psychopharmacology. 1998;140(2):173-84. [pmid: 9860108].
332 Keck PE, Orsulak PJ, Cutler AJ, et al. Aripiprazole monotherapy in the treatment of acute bipolar I mania: a randomized, double-blind, placebo- and lithium-controlled study. J Affect Disord. 2009;112(1-3):36-49. [pmid: 18835043].
333 Keck PE Jr., Reeves KR, Harrigan EP, et al. Ziprasidone in the short-term treatment of patients with schizoaffective disorder: results from two double- blind, placebo-controlled, multicenter studies. J Clin Psychopharmacol. 2001;21(1):27-35. [pmid: 11199944].
334 Keck PE Jr, McElroy SL, Strakowski SM, et al. Factors associated with maintenance antipsychotic treatment of patients with bipolar disorder. J Clin Psychiatry. 1996;57(4):147-51. [pmid: 8601549].
335 Keefe RS, Poe MP, McEvoy JP, et al. Source monitoring improvement in patients with schizophrenia receiving antipsychotic medications. Psychopharmacology. 2003;169(3-4):383-9. [pmid: 12759802].
336 Keefe RS, Seidman LJ, Christensen BK, et al. Comparative effect of atypical and conventional antipsychotic drugs on neurocognition in first-episode psychosis: a randomized, double-blind trial of olanzapine versus low doses of haloperidol. Am J Psychiatry. 2004;161(6):985-95. [pmid: 15169686].
337 Keefe RS, Young CA, Rock SL, et al. One-year double-blind study of the neurocognitive efficacy of olanzapine, risperidone, and haloperidol in schizophrenia. Schizophr Res. 2006;81(1):1-15. [pmid: 16202565].
338 Keefe RSE, Sweeney JA, Gu H, et al. Effects of olanzapine, quetiapine, and risperidone on neurocognitive function in early psychosis: a randomized, double-blind 52-week comparison. Am J Psychiatry. 2007;164(7):1061-71. [pmid: 17606658].
339 Keks N, McGrath J, Lambert T, et al. The Australian multicentre double-blind comparative study of remoxipride and thioridazine in schizophrenia. Acta Psychiatr Scand. 1994;90(5):358-65. [pmid: 7872041].
340 Kelly DL, Conley RR, Richardson CM, et al. Adverse effects and laboratory parameters of high-dose olanzapine vs. clozapine in treatment-resistant schizophrenia. Ann Clin Psychiatry. 2003;15(3-4):181-6. [pmid: 14971863].
341 Kelly DL, Conley RR. A randomized double-blind 12-week study of quetiapine, risperidone or fluphenazine on sexual functioning in people with schizophrenia. Psychoneuroendocrinology. 2006;31(3):340-6. [pmid: 16198059].
342 Kelly DL, Conley RR, Love RC, et al. Metabolic risk with second-generation antipsychotic treatment: a double-blind randomized 8-week trial of risperidone and olanzapine. Ann Clin Psychiatry. 2008;20(2):71-8. [pmid: 18568578].
343 Kelly DL, Buchanan RW, Boggs DL, et al. A randomized double-blind trial of atomoxetine for cognitive impairments in 32 people with schizophrenia. J Clin Psychiatry. 2009;70(4):518-25. [pmid: 19358788].
344 Kelly MW, Perry PJ, Coryell WH, et al. Reduced haloperidol plasma concentration and clinical response in acute exacerbations of schizophrenia. Psychopharmacology. 1990;102(4):514-20. [pmid: 2096408].
345 Kern RS, Green MF, Cornblatt BA, et al. The neurocognitive effects of aripiprazole: an open-label comparison with olanzapine. Psychopharmacology. 2006;187(3):312-20. [pmid: 16810506].
346 Kerwin R, Millet B, Herman E, et al. A multicentre, randomized, naturalistic, open-label study between aripiprazole and standard of care in the management of community-treated schizophrenic patients Schizophrenia Trial of Aripiprazole: (STAR) study. Eur Psychiatry. 2007;22(7):433-43. [pmid: 17555947].
347 Ketter TA, Jones M, Paulsson B. Rates of remission/euthymia with quetiapine monotherapy compared with placebo in patients with acute mania. J Affect Disord. 2007;100(Suppl 1):S45-53. [pmid: 17383011].
348 Kilian R, Dietrich S, Toumi M, et al. Quality of life in persons with schizophrenia in out-patient treatment with first- or second-generation antipsychotics. Acta Psychiatr Scand. 2004;110(2):108-18. [pmid: 15233711].
349 Kim B, Lee SH, Tae KC, et al. Effectiveness of a combined therapy of long-acting injectable risperidone and psychosocial intervention for relapse prevention in patients with schizophrenia. Clin Psychopharmacol Neurosci. 2008;6(1):31-7.
350 Kim B, Lee SH, Choi TK, et al. Effectiveness of risperidone long-acting injection in first-episode schizophrenia: in naturalistic setting. Prog Neuropsychopharmacol Biol Psychiatry. 2008;32(5):1231-5. [pmid: 18442879].
351 Kim JH, Kim D, Marder SR. Time to rehospitalization of clozapine versus risperidone in the naturalistic treatment of comorbid alcohol use disorder and schizophrenia. Prog Neuropsychopharmacol Biol Psychiatry. 2008;32(4):984-8. [pmid: 18262321].
352 King DJ, Link CG, Kowalcyk B. A comparison of bd and tid dose regimens of quetiapine (Seroquel) in the treatment of schizophrenia. Psychopharmacology. 1998;137(2):139-46. [pmid: 9630000].
353 Kinon BJ, Kane JM, Johns C, et al. Treatment of neuroleptic-resistant schizophrenic relapse. Psychopharmacol Bull. 1993;29(2):309-14. [pmid: 7904762].
354 Kinon BJ, Volavka J, Stauffer V, et al. Standard and higher dose of olanzapine in patients with schizophrenia or schizoaffective disorder: a randomized, double-blind, fixed-dose study. J Clin Psychopharmacol. 2008;28(4):392-400. [pmid: 18626265].
355 Kinon BJ, Stauffer VL, Kollack-Walker S, et al. Olanzapine versus aripiprazole for the treatment of agitation in acutely ill patients with schizophrenia. J Clin Psychopharmacol. 2008;28(6):601-7. [pmid: 19011427].
356 Kinon BJ, Jeste DV, Kollack-Walker S, et al. Olanzapine treatment for tardive dyskinesia in schizophrenia patients: a prospective clinical trial with patients randomized to blinded dose reduction periods. Prog Neuropsychopharmacol Biol Psychiatry. 2004;28(6):985-96. [pmid: 15380859].
357 Kinon BJ, Ahl J, Liu-Seifert H, et al. Improvement in hyperprolactinemia and reproductive comorbidities in patients with schizophrenia switched from conventional antipsychotics or risperidone to olanzapine. Psychoneuroendocrinology. 2006;31(5):577-88. [pmid: 16488084].
358 Kinon BJ, Lipkovich I, Edwards SB, et al. A 24-week randomized study of olanzapine versus ziprasidone in the treatment of schizophrenia or schizoaffective disorder in patients with prominent depressive symptoms. J Clin Psychopharmacol. 2006;26(2):157-62. [pmid: 16633144].
359 Kishi T, Moriwaki M, Kitajima T, et al. Effect of aripiprazole, risperidone, and olanzapine on the acoustic startle response in Japanese chronic schizophrenia. Psychopharmacology. 2010;209(2):185-90. [pmid: 20177883].
360 Kluge M, Schuld A, Himmerich H, et al. Clozapine and olanzapine are associated with food craving and binge eating: results from a randomized double-blind study. J Clin Psychopharmacol. 2007;27(6):662-6. [pmid: 18004133].
361 Knegtering H, Boks M, Blijd C, et al. A randomized open-label comparison of the impact of olanzapine versus risperidone on sexual functioning. J Sex Marital Ther. 2006;32(4):315-26. [pmid: 16709552].
362 Knegtering R, Castelein S, Bous H, et al. A randomized open-label study of the impact of quetiapine versus risperidone on sexual functioning. J Clin Psychopharmacol. 2004;24(1):56-61. [pmid: 14709948].
363 Knegtering R, Castelein S, Bous H, et al. A randomized open-label study of the impact of quetiapine versus risperidone on sexual functioning. J Clin Psychopharmacol. 2004;24(1):56-61. [pmid: 14709948].
364 Knott V, Labelle A, Jones B, et al. Quantitative EEG in schizophrenia and in response to acute and chronic clozapine treatment. Schizophr Res. 2001;50(1-2):41-53. [pmid: 11378313].
365 Ko GN, Korpi ER, Kirch DG. Haloperidol and reduced haloperidol concentrations in plasma and red blood cells from chronic schizophrenic patients. J Clin Psychopharmacol. 1989;9(3):186-90. [pmid: 2661607].
366 Koenigsberg HW, Reynolds D, Goodman M, et al. Risperidone in the treatment of schizotypal personality disorder. J Clin Psychiatry. 2003;64(6):628-34. [pmid: 12823075].
367 Kongsakon R, Trinidad-Onate P, Chaudhry HR, et al. Asian outpatients with schizophrenia: a double-blind randomized comparison of quality of life and clinical outcomes for patients treated with olanzapine or haloperidol. J Med Assoc Thailand. 2006;89(8):1157-70.
368 Kopala LC, Good KP, Honer WG. Extrapyramidal signs and clinical symptoms in first-episode schizophrenia: response to low-dose risperidone. J Clin Psychopharmacol. 1997;17(4):308-13. [pmid: 9241011].
369 Kordon A, Wahl K, Koch N, et al. Quetiapine addition to serotonin reuptake inhibitors in patients with severe obsessive-compulsive disorder: a double-blind, randomized, placebo-controlled study. J Clin Psychopharmacol. 2008;28(5):550-4. [pmid: 18794652].
370 Koro CE, Fedder DO, l'Italien GJ, et al. An assessment of the independent effects of olazapine and risperidone exposure ont he risk of hyperlipidemia in schizophrenic patients. Arch Gen Psychiatry. 2002;59(11):1021-6. [pmid: 12418935].
371 Koshino Y, Madokoro S, Ito T, et al. A survey of tardive dyskinesia in psychiatric inpatients in Japan. Clin Neuropharmacol. 1992;15(1):34-43. [pmid: 1349507].
372 Kotler M, Strous RD, Reznik I, et al. Sulpiride augmentation of olanzapine in the management of treatment-resistant chronic schizophrenia: evidence for improvement of mood symptomatology. Int Clin Psychopharmacol. 2004;19(1):23-6. [pmid: 15101566].
373 Krakowski M, Czobor P, Citrome L. Weight gain, metabolic parameters, and the impact of race in aggressive inpatients randomized to double-blind clozapine, olanzapine or haloperidol. Schizophr Res. 2009;110(1-3):95-102. [pmid: 19269139].
374 Krakowski MI, Czobor P, Citrome L, et al. Atypical antipsychotic agents in the treatment of violent patients with schizophrenia and schizoaffective disorder. Arch Gen Psychiatry. 2006;63(6):622-9. [pmid: 16754835].
375 Kraus JE, Sheitman BB, Cook A, et al. Olanzapine versus risperidone in newly admitted acutely ill psychotic patients. J Clin Psychiatry. 2005;66(12):1564-8. [pmid: 16401158].
376 Kraus JE, Sheitman BB, Cook A, et al. Olanzapine versus risperidone in newly admitted acutely ill psychotic patients. J Clin Psychiatry. 2005;66(12):1564-8. [pmid: 16401158].
377 Kreisman D, Blumenthal R, Borenstein M, et al. Family attitudes and patient social adjustment in a longitudinal study of outpatient schizophrenics receiving low-dose neuroleptics: the family's view. Psychiatry. 1988;51(1):3-13. [pmid: 3368545].
378 Kufferle B, Friedmann A, Topitz A, et al. Smooth pursuit eye movements in schizophrenia: influences of neuroleptic treatment and the question of specificity. Psychopathology. 1990;23(2):106-14. [pmid: 1979684].
379 Kumari V, Soni W, Sharma T. Prepulse inhibition of the startle response in risperidone-treated patients: comparison with typical antipsychotics. Schizophr Res. 2002;55(1-2):139-46. [pmid: 11955973].
380 Kuruvilla A, Peedicayil J, Srikrishna G, et al. A study of serum prolactin levels in schizophrenia: comparison of males and females. Clin Exp Pharmacol Physiol. 1992;19(9):603-6. [pmid: 1356671].
381 Lage MJ, Hassan MK. The relationship between antipsychotic medication adherence and patient outcomes among individuals diagnosed with bipolar disorder: a retrospective study. Ann Gen Psychiatry. 2009;8:9. [pmid: 19419541].
382 Lahdelma RL, Appelberg B, Kuoppasalmi K, et al. Plasma concentrations of remoxipride and haloperidol in relation to prolactin and short-term therapeutic outcome in schizophrenic patients. Eur Neuropsychopharmacol. 1991;1(4):535-40. [pmid: 1688013].
383 Lahdelma RL, Katila H, Hirata-Hibi M, et al. Atypical lymphocytes in schizophrenia. Eur Psychiatry. 1995;10(2):92-6. [pmid: 19698320].
384 Lal S, Thavundayil JX, Nair NPV, et al. Levomepromazine versus chlorpromazine in treatment-resistant schizophrenia: a double-blind randomized trial. J Psychiatry Neurosci. 2006;31(4):271-9. [pmid: 16862245].
385 Lam SP, Fong SYY, Yu MWM, et al. Sleepwalking in psychiatric patients: comparison of childhood and adult onset. Aust N Z J Psychiatry. 2009;43(5):426-30. [pmid: 19373703].
386 Lam YWF. Combining resperidone, fluvoxamine may enhance response rate. Brown Univ Geriatr Psychopharmacol Update. 2003;7(2):1-3.
387 Lambert BL, Chang KY, Tafesse E, et al. Association between antipsychotic treatment and hyperlipidemia among California Medicaid patients with schizophrenia. J Clin Psychopharmacol. 2005;25(1):12-8. [pmid: 15643095].
388 Lambert BL, Chou CH, Chang KY, et al. Antipsychotic exposure and type 2 diabetes among patients with schizophrenia: a matched case-control study of California Medicaid claims. Pharmacoepidemiol Drug Saf. 2005;14(6):417-25. [pmid: 15786516].
389 Lambert M, Conus P, Schimmelmann BG, et al. Comparison of olanzapine and risperidone in 367 first-episode patients with non-affective or affective psychosis: results of an open retrospective medical record study. Pharmacopsychiatry. 2005;38(5):206-13. [pmid: 16189747].
390 Lamberti JS, Olson D, Crilly JF, et al. Prevalence of the metabolic syndrome among patients receiving clozapine. Am J Psychiatry. 2006;163(7):1273-6. [pmid: 16816234].
391 Lamure M, Toumi M, Chabannes JP, et al. Zuclopenthixol versus haloperidol: An observational randomised pharmacoeconomic evaluation of patients with chronic schizophrenia exhibiting acute psychosis. Int J Psychiatry Clin Prct. 2003;7(3):177-85.
392 Landmark J, Merskey H, Cernovsky ZZ. Fluphenazine treatment of DSM-III-R male schizophrenic patients among the Xhosa. Can J Psychiatr Rev Canad Psychiatr. 1994;39(4):219-22.
393 Lane HY, Lin HN, Hu OYP, et al. Blood levels of reduced haloperidol versus clinical efficacy and extrapyramidal side effects of haloperidol. Prog Neuropsychopharmacol Biol Psychiatry. 1997;21(2):299-311. [pmid: 9061775].
394 Lane HY, Guo SC, Hwang TJ, et al. Effects of olanzapine plasma concentrations on depressive symptoms in schizophrenia: a pilot study. J Clin Psychopharmacol. 2002;22(5):530-2. [pmid: 12352282].
395 Lapierre YD, Nair NP, Chouinard G, et al. A controlled dose-ranging study of remoxipride and haloperidol in schizophrenia: a Canadian multicentre trial. Acta Psychiatr Scand Suppl. 1990;358:72-7. [pmid: 1978496].
396 Lapierre YD, Angus C, Awad AG, et al. The treatment of negative symptoms: a clinical and methodological study. Int Clin Psychopharmacol. 1999;14(2):101-12. [pmid: 10220125].
397 Larmo I, de NA, Windhager E, et al. Efficacy and tolerability of quetiapine in patients with schizophrenia who switched from haloperidol, olanzapine or risperidone. Hum Psychopharmacol. 2005;20(8):573-81. [pmid: 16175656].
398 Lauriello J, McEvoy JP, Rodriguez S, et al. Long-acting risperidone vs. placebo in the treatment of hospital inpatients with schizophrenia. Schizophr Res. 2005;72(2-3):249-58. [pmid: 15560969].
399 Lauriello J, Lambert T, Andersen S, et al. An 8-week, double-blind, randomized, placebo-controlled study of olanzapine long-acting injection in acutely ill patients with schizophrenia. J Clin Psychiatry. 2008;69(5):790-9. [pmid: 18452346].
400 Laux G, Klieser E, Schroder HG, et al. A double-blind multicentre study comparing remoxipride, two and three times daily, with haloperidol in schizophrenia. Acta Psychiatr Scand Suppl. 1990;358:125-9. [pmid: 1978471].
401 Lee CT, Conde BJ, Mazlan M, et al. Switching to olanzapine from previous antipsychotics: a regional collaborative multicenter trial assessing 2 switching techniques in Asia Pacific. J Clin Psychiatry. 2002;63(7):569-76. [pmid: 12143912].
402 Lejeune J, Larmo I, Chrzanowski W, et al. Oral risperidone plus oral lorazepam versus standard care with intramuscular conventional neuroleptics in the initial phase of treating individuals with acute psychosis. Int Clin Psychopharmacol. 2004;19(5):259-69. [pmid: 15289699].
403 Lencz T, Robinson DG, Xu K, et al. DRD2 promoter region variation as a predictor of sustained response to antipsychotic medication in first-episode schizophrenia patients. Am J Psychiatry. 2006;163(3):529-31. [pmid: 16513877].
404 Leong OK, Wong KE, Tay WK, et al. A comparative study of pipothiazine palmitate and fluphenazine decanoate in the maintenance of remission of schizophrenia. Singapore Medical Journal. 1989;30(5):436-40. [pmid: 2575796].
405 Lepola U, Koskinen T, Rimon R, et al. Sulpiride and perphenazine in schizophrenia. A double-blind clinical trial. Acta Psychiatr Scand. 1989;80(1):92-6. [pmid: 2669445].
406 Lesem MD, Zajecka JM, Swift RH, et al. Intramuscular ziprasidone, 2 mg versus 10 mg, in the short-term management of agitated psychotic patients. J Clin Psychiatry. 2001;62(1):12-8. [pmid: 11235922].
407 Leumann L, Feldman J, Vollenweider FX, et al. Effects of typical and atypical antipsychotics on prepulse inhibition and latent inhibition in chronic schizophrenia. Biol Psychiatry. 2002;52(7):729-39. [pmid: 12372664].
408 Levin ED, Wilson W, Rose JE, et al. Nicotine-haloperidol interactions and cognitive performance in schizophrenics. Neuropsychopharmacology. 1996;15(5):429-36. [pmid: 8914115].
409 Levine J, Caspi N, Laufer N. Immediate effects of chlorpromazine and perphenazine following neuroleptic washout on word association of schizophrenic patients. Schizophr Res. 1997;26(1):55-63. [pmid: 9376337].
410 Lewis SW, D L. Randomised controlled trials of conventional antipsychotic versus new atypical drugs, and new atypical drugs versus clozapine, in people with schizophrenia responding poorly to, or intolerant of, current drug treatment. Health Technol Assess. May. 2006;10(17):iii-iv. ix. xi. 1. 165.
411 Lewis DA, Cho RY, Carter CS, et al. Subunit-selective modulation of GABA type A receptor neurotransmission and cognition in schizophrenia. Am J Psychiatry. 2008;165(12):1585-93. [pmid: 18923067].
412 Lewis SW, Barnes TR, Davies L, et al. Randomized controlled trial of effect of prescription of clozapine versus other second-generation antipsychotic drugs in resistant schizophrenia. Schizophr Bull. 2006;32(4):715-23. [pmid: 16540702].
413 Lewis SW, Barnes TRE, Davies L, et al. Randomized controlled trial of effect of prescription of clozapine versus other second-generation antipsychotic drugs in resistant schizophrenia. Schizophr Bull. 2006;32(4):715-23. [pmid: 16540702].
414 Li H, Ma C, Wang G, et al. Response and remission rates in Chinese patients with bipolar mania treated for 4 weeks with either quetiapine or lithium: a randomized and double-blind study. Curr Med Res Opin. 2008;24(1):1-10. [pmid: 18028587].
415 Li X, May RS, Tolbert LC, et al. Risperidone and haloperidol augmentation of serotonin reuptake inhibitors in refractory obsessive-compulsive disorder: a crossover study. J Clin Psychiatry. 2005;66(6):736-43. [pmid: 15960567].
416 Lieberman JA, Phillips M, Gu H, et al. Atypical and conventional antipsychotic drugs in treatment-naive first-episode schizophrenia: a 52-week randomized trial of clozapine vs chlorpromazine. Neuropsychopharmacology. 2003;28(5):995-1003. [pmid: 12700715].
417 Lieberman JA, Tollefson G, Tohen M, et al. Comparative efficacy and safety of atypical and conventional antipsychotic drugs in first-episode psychosis: a randomized, double-blind trial of olanzapine versus haloperidol. Am J Psychiatry. 2003;160(8):1396-404. [pmid: 12900300].
418 Lieberman JA, Jody D, Geisler S, et al. Time course and biologic correlates of treatment response in first-episode schizophrenia. Arch Gen Psychiatry. 1993;50(5):369-76. [pmid: 8098203].
419 Lieberman JA, Stroup TS, McEvoy JP, et al. Effectiveness of Antipsychotic Drugs in Patients with Chronic Schizophrenia. N Engl J Med. 2005;353(12):1209-23. [pmid: 16172203].
420 Lieberman JA, Tollefson GD, Charles C, et al. Antipsychotic Drug Effects on Brain Morphology in First-Episode Psychosis. Arch Gen Psychiatry. 2005;62(4):361-70. [pmid: 15809403].
421 Lin CY, Wu PL, Pariante CM, et al. A crossover study of prolactin changes associated with risperidone and olanzapine. J Clin Psychiatry. 2006;67(9):1470-1. [pmid: 17017838].
422 Lin HC, Chen IJ, Chen YH, et al. Maternal schizophrenia and pregnancy outcome: does the use of antipsychotics make a difference?. Schizophr Res. 2010;116(1):55-60. [pmid: 19896335].
423 Lindenmayer JP, Khan A, Eerdekens M, et al. Long-term safety and tolerability of long-acting injectable risperidone in patients with schizophrenia or schizoaffective disorder. Eur Neuropsychopharmacol. 2007;17(2):138-44. [pmid: 17049818].
424 Lindenmayer JP, Czobor P, Volavka J, et al. Effects of atypical antipsychotics on the syndromal profile in treatment-resistant schizophrenia. J Clin Psychiatry. 2004;65(4):551-6. [pmid: 15119920].
425 Lindenmayer JP, Jarboe K, Bossie CA, et al. Minimal injection site pain and high patient satisfaction during treatment with long-acting risperidone. Int Clin Psychopharmacol. 2005;20(4):213-21. [pmid: 15933482].
426 Lindstrom E, Eriksson B, Hellgren A, et al. Efficacy and safety of risperidone in the long-term treatment of patients with schizophrenia. Clin Ther. 1995;17(3):402-12. [pmid: 7585844].
427 Lindstrom LH, Wieselgren IM, Struwe G, et al. A double-blind comparative multicentre study of remoxipride and haloperidol in schizophrenia. Acta Psychiatr Scand Suppl. 1990;358:130-5. [pmid: 1978472].
428 Linehan MM, McDavid JP, Brown MZ, et al. Olanzapine plus dialectical behavior therapy for women with high irritability who Meet criteria for borderline personality disorder: a double-blind, placebo-controlled pilot study. J Clin Psychiatry. 2008;69(6):999-1005. [pmid: 18466045].
429 Liu CY, Chiu NY, Wu CK, et al. Optimal dose of risperidone and olanzapine for patients with schizophrenia in Taiwan. Int Clin Psychopharmacol. 2003;18(1):49-51. [pmid: 12490775].
430 Ljubin T, Milas ZD, Folnegovic-Smalc V, et al. A preliminary study of the comparative effects of olanzapine and fluphenazine on cognition in schizophrenic patients. Hum Psychopharmacol. 2000;15(7):513-9. [pmid: 12404620].
431 Loo H, Poirier-Littre MF, Theron M, et al. Amisulpride versus placebo in the medium-term treatment of the negative symptoms of schizophrenia. Br J Psychiatry. 1997;170:18-22. [pmid: 9068769].
432 Macfadden W, Alphs L, Haskins JT, et al. A randomized, double-blind, placebo-controlled study of maintenance treatment with adjunctive risperidone long-acting therapy in patients with bipolar I disorder who relapse frequently. Bipolar Disord. 2009;11(8):827-39. [pmid: 19922552].
433 Maina G, Albert U, Ziero S, et al. Antipsychotic augmentation for treatment resistant obsessive-compulsive disorder: what if antipsychotic is discontinued?. Int Clin Psychopharmacol. 2003;18(1):23-8. [pmid: 12490771].
434 Maixner S, Tandon R, Eiser A, et al. Effects of antipsychotic treatment on polysomnographic measures in schizophrenia: a replication and extension. Am J Psychiatry. 1998;155(11):1600-2. [pmid: 9812125].
435 Makela EH, Cutlip WD, Stevenson JM, et al. Branded versus generic clozapine for treatment of schizophrenia. Ann Pharmacother. 2003;37(3):350-3. [pmid: 12639161].
436 Makikyro T, Leinonen E, Koponen H, et al. Early developmental differences between DSM-III-R schizophrenics treated with clozapine and typical neuroleptics. J Psychiatr Res. 1998;32(2):105-10. [pmid: 9694006].
437 Malla A, Norman R, Scholten D, et al. A comparison of two novel antipsychotics in first episode non-affective psychosis: one-year outcome on symptoms, motor side effects and cognition. Psychiatry Res. 2004;129(2):159-69. [pmid: 15590043].
438 Manchanda R, Norman RMG, Malla AK, et al. Antipsychotic use in a first episode psychosis program. Int J Psychiatry Clin Pract. 2007;11(2):151-6.
439 Marangell LB, Dennehy EB, Wisniewski SR, et al. Case-control analyses of the impact of pharmacotherapy on prospectively observed suicide attempts and completed suicides in bipolar disorder: findings from STEP-BD. J Clin Psychiatry. 2008;69(6):916-22. [pmid: 18399724].
440 Marder SR, Meibach RC. Risperidone in the treatment of schizophrenia. Am J Psychiatry. 1994;151(6):825-35. [pmid: 7514366].
441 Marder SR, Davis JM, Chouinard G. The effects of risperidone on the five dimensions of schizophrenia derived by factor analysis: combined results of the North American trials. J Clin Psychiatry. 1997;58(12):538-46. [pmid: 9448657].
442 Marder SR, Glynn SM, Wirshing WC, et al. Maintenance treatment of schizophrenia with risperidone or haloperidol: 2-year outcomes. Am J Psychiatry. 2003;160(8):1405-12. [pmid: 12900301].
443 Marder SR, McQuade RD, Stock E, et al. Aripiprazole in the treatment of schizophrenia: safety and tolerability in short-term, placebo-controlled trials. Schizophr Res. 2003;61(2-3):123-36. [pmid: 12729864].
444 Markianos M, Hatzimanolis J, Lykouras L, et al. Prolactin responses to acute clomipramine and haloperidol of male schizophrenic patients in a drug-free state and after treatment with clozapine or with olanzapine. Schizophr Res. 2002;56(1-2):11-7. [pmid: 12084414].
445 Marra D, Warot D, Berlin I, et al. Amisulpride does not prevent relapse in primary alcohol dependence: Results of a pilot randomized, placebo-controlled trial. Alcohol Clin Exp Res. 2002;26(10):1545-52. [pmid: 12394288].
446 Martenyi F, Metcalfe S, Schausberger B, et al. An efficacy analysis of olanzapine treatment data in schizophrenia patients with catatonic signs and symptoms. J Clin Psychiatry. 2001;62(Suppl 2):25-7. [pmid: 11232748].
447 Martin S, Ljo H, Peuskens J, et al. A double-blind, randomised comparative trial of amisulpride versus olanzapine in the treatment of schizophrenia: short-term results at two months. Curr Med Res Opin. 2002;18(6):355-62. [pmid: 12442883].
448 Mata I, Crespo-Facorro B, Perez-Iglesias R, et al. Association between the interleukin-1 receptor antagonist gene and negative symptom improvement during antipsychotic treatment. Am J Med Genet B Neuropsychiatr Genet. 2006;141(8):939-43. [pmid: 16921503].
449 Matsunaga H, Nagata T, Hayashida K, et al. A long-term trial of the effectiveness and safety of atypical antipsychotic agents in augmenting SSRI-refractory obsessive-compulsive disorder. J Clin Psychiatry. 2009;70(6):863-8. [pmid: 19422759].
450 Mauri MC, Laini V, Steinhilber CPC, et al. Depression, negative and positive symptoms in schizophrenia: response to different dosages of haloperidol. New Trends Exp Clin Psychiatr. 1998;14(1):59-63.
451 McCann TV, Deans C, Clark E, et al. A comparative study of antipsychotic medication taking in people with schizophrenia. Int J Ment Health Nurs. 2008;17(6):428-38. [pmid: 19128290].
452 McDougle CJ, Goodman WK, Leckman JF, et al. Haloperidol addition in fluvoxamine-refractory obsessive-compulsive disorder: a double-blind, placebo-controlled study in patients with and without tics. Arch Gen Psychiatry. 1994;51(4):302-8. [pmid: 8161290].
453 McDougle CJ, Naylor ST, Cohen DJ, et al. A double-blind, placebo-controlled study of fluvoxamine in adults with autistic disorder. Arch Gen Psychiatry. 1996;53(11):1001-8. [pmid: 8911223].
454 McEvoy JP, Hogarty GE, Steingard S. Optimal dose of neuroleptic in acute schizophrenia: a controlled study of the neuroleptic threshold and higher haloperidol dose. Arch Gen Psychiatry. 1991;48(8):739-45. [pmid: 1883257].
455 McEvoy JP, Johnson J, Perkins D, et al. Insight in first-episode psychosis. Psychol Med. 2006;36(10):1385-93. [pmid: 16740175].
456 McEvoy JP, Lieberman JA, Perkins DO, et al. Efficacy and tolerability of olanzapine, quetiapine, and risperidone in the treatment of early psychosis: a randomized, double-blind 52-week comparison. Am J Psychiatry. 2007;164(7):1050-60. [pmid: 17606657].
457 McGurk SR, Green MF, Wirshing WC, et al. Antipsychotic and anticholinergic effects on two types of spatial memory in schizophrenia. Schizophr Res. 2004;68(2-3):225-33. [pmid: 15099605].
458 McGurk SR, Carter C, Goldman R, et al. The effects of clozapine and risperidone on spatial working memory in schizophrenia. Am J Psychiatry. 2005;162(5):1013-6. [pmid: 15863811].
459 McIntyre RS, Mancini DA, Srinivasan J, et al. The antidepressant effects of risperidone and olanzapine in bipolar disorder. Can J Clin Pharmacol. 2004;11(2):e218-e226. [pmid: 15520475].
460 McIntyre RS, Cohen M, Zhao J, et al. Asenapine versus olanzapine in acute mania: a double-blind extension study. Bipolar Disord. 2009;11(8):815-26. [pmid: 19832806].
461 McIntyre RS, Cohen M, Zhao J, et al. A 3-week, randomized, placebo-controlled trial of asenapine in the treatment of acute mania in bipolar mania and mixed states. Bipolar Disord. 2009;11(7):673-86. [pmid: 19839993].
462 McIntyre RS, Trakas K, Lin D, et al. Risk of weight gain adsociated with antipsychotic treatment: results from the Canadian national outcomes measurement study in schizophrenia. Can J Psychiatr Rev Canad Psychiatr. 2003;48(10):689-94.
463 McIntyre RS, Brecher M, Paulsson B, et al. Quetiapine or haloperidol as monotherapy for bipolar mania-a 12-week, double-blind, randomised, parallel-group, placebo-controlled trial. Eur Neuropsychopharmacol. 2005;15(5):573-85. [pmid: 16139175].
464 Medved V, Kuzman MR, Jovanovic N, et al. Metabolic syndrome in female patients with schizophrenia treated with second generation antipsychotics: a 3-month followup. J Psychopharmacol. 2009;23(8):915-22. [pmid: 18635691].
465 Melkersson KI, Hulting AL. Insulin and leptin levels in patients with schizophrenia or related psychoses: a comparison between different antipsychotic agents. Psychopharmacology. 2001;154(2):205-12. [pmid: 11314683].
466 Melkersson K. Differences in prolactin elevation and related symptoms of atypical antipsychotics in schizophrenic patients. J Clin Psychiatry. 2005;66(6):761-7. [pmid: 15960571].
467 Melkersson K. Serum creatine kinase levels in chronic psychosis patients--a comparison between atypical and conventional antipsychotics. Prog Neuropsychopharmacol Biol Psychiatry. 2006;30(7):1277-82. [pmid: 16806625].
468 Meltzer HY, Alphs L, Green AI, et al. Clozapine treatment for suicidality in schizophrenia: International Suicide Prevention Trial (InterSePT). Arch Gen Psychiatry. 2003;60(1):82-91. [pmid: 12511175].
469 Meltzer HY, Jayathilake K. Low-dose loxapine in the treatment of schizophrenia: is it more effective and more “atypical” than standard-dose loxapine?. J Clin Psychiatry. 1999;60(Suppl 10):47-51.
470 Meltzer HY, Bobo WV, Roy A, et al. A randomized, double-blind comparison of clozapine and high-dose olanzapine in treatment-resistant patients with schizophrenia. J Clin Psychiatry. 2008;69(2):274-85. [pmid: 18232726].
471 Mesulam MM, Petersen RC. Treatment of Gilles de la Tourette's syndrome: eight-year, practice-based experience in a predominantly adult population. Neurology. 1987;37(12):1828-33. [pmid: 3479704].
472 Meyer-Lindenberg A, Bauer U, Lis S, et al. Improvement of cognitive function in schizophrenic patients receiving clozapine or zotepine: results from a double-blind study. Pharmacopsychiatry. 1997;30(2):35-42. [pmid: 9131723].
473 Meyer JM, Rosenblatt LC, Kim E, et al. The moderating impact of ethnicity on metabolic outcomes during treatment with olanzapine and aripiprazole in patients with schizophrenia. J Clin Psychiatry. 2009;70(3):318-25. [pmid: 19192469].
474 Miller dD, Caroff SN, Davis SM, et al. Extrapyramidal side-effects of antipsychotics in a randomised trial. Br J Psychiatry. 2008;193(4):279-88. [pmid: 18827289].
475 Min SK, Rhee CS, Kim CE, et al. Risperidone versus haloperidol in the treatment of chronic schizophrenic patients: a parallel group double-blind comparative trial. Yonsei Med J. 1993;34(2):179-90. [pmid: 7691017].
476 Miodownik C, Lerner V, Kibari A, et al. The effect of sudden clozapine discontinuation on management of schizophrenic patients: a retrospective controlled study. J Clin Psychiatry. 2006;67(8):1204-8. [pmid: 16965197].
477 Mitchell M, Riesenberg R, Bari MA, et al. A double-blind, randomized trial to evaluate the pharmacokinetics and tolerability of 30 or 40 mg/d oral olanzapine relative to 20 mg/d oral olanzapine in stable psychiatric subjects. Clin Ther. 2006;28(6):881-92. [pmid: 16860171].
478 Mizrahi R, Rusjan P, Agid O, et al. Adverse subjective experience with antipsychotics and its relationship to striatal and extrastriatal D2 receptors: a PET study in schizophrenia. Am J Psychiatry. 2007;164(4):630-7. [pmid: 17403977].
479 Mizrahi R, Korostil M, Starkstein SE, et al. The effect of antipsychotic treatment on Theory of Mind. Psychol Med. 2007;37(4):595-601. [pmid: 17094815].
480 Moeller KE, Shireman TI, Liskow BI. Relapse rates in patients with schizophrenia receiving aripiprazole in comparison with other atypical antipsychotics. J Clin Psychiatry. 2006;67(12):1942-7. [pmid: 17194273].
481 Mojtabai R, Lavelle J, Gibson PJ, et al. Atypical antipsychotics in first admission schizophrenia: medication continuation and outcomes. Schizophr Bull. 2003;29(3):519-30. [pmid: 14609245].
482 Moller HJ, Bauml J, Ferrero F, et al. Risperidone in the treatment of schizophrenia: results of a study of patients from Germany, Austria, and Switzerland. Eur Arch Psychiatry Clin Neurosci. 1997;247(6):291-6. [pmid: 9477007].
483 Moller HJ, Johnson S, Mateva T, et al. Evaluation of the feasibility of switching from immediate release quetiapine to extended release quetiapine fumarate in stable outpatients with schizophrenia. Int Clin Psychopharmacol. 2008;23(2):95-105. [pmid: 18301124].
484 Moller HJ, Riedel M, Jager M, et al. Short-term treatment with risperidone or haloperidol in first-episode schizophrenia: 8-week results of a randomized controlled trial within the German Research Network on Schizophrenia. Int J Neuropsychopharmacol. 2008;11(7):985-97. [pmid: 18466670].
485 Montes JM, Ciudad A, Gascon J, et al. Safety, effectiveness, and quality of life of olanzapine in first-epsiode schizophrenia: a naturalistic study. Prog Neuropsychopharmacol Biol Psychiatry. 2003;27(4):667-74. [pmid: 12787855].
486 Montgomery J, Winterbottom E, Jessani M, et al. Prevalence of hyperprolactinemia in schizophrenia: association with typical and atypical antipsychotic treatment. J Clin Psychiatry. 2004;65(11):1491-8. [pmid: 15554761].
487 Moreno RA, Hanna MM, Tavares SM, et al. A double-blind comparison of the effect of the antipsychotics haloperidol and olanzapine on sleep in mania. Braz J Med Biol Res. 2007;40(3):357-66. [pmid: 17334533].
488 Mori K, Nagao M, Yamashita H, et al. Effect of switching to atypical antipsychotics on memory in patients with chronic schizophrenia. Prog Neuropsychopharmacol Biol Psychiatry. 2004;28(4):659-65. [pmid: 15276691].
489 Mortimer A, Martin S, Loo H, et al. A double-blind, randomized comparative trial of amisulpride versus olanzapine for 6 months in the treatment of schizophrenia. Int Clin Psychopharmacol. 2004;19(2):63-9. [pmid: 15076013].
490 Mortimer AM, Joyce E, Balasubramaniam K, et al. Treatment with amisulpride and olanzapine improve neuropsychological function in schizophrenia. Hum Psychopharmacol. 2007;22(7):445-54. [pmid: 17691076].
491 Muirhead D, Harvey C, Ingram G. Effectiveness of community treatment orders for treatment of schizophrenia with oral or depot antipsychotic medication: clinical outcomes. Aust NZ J Psychiatry. 2006;40(6-7):596-605.
492 Mullen J, Jibson MD, Sweitzer D. A comparison of the relative safety, efficacy, and tolerability of quetiapine and risperidone in outpatients with schizophrenia and other psychotic disorders: the quetiapine experience with safety and tolerability (QUEST) study. Clin Ther. 2001;23(11):1839-54. [pmid: 11768836].
493 Muller-Siecheneder F, Muller MJ, Hillert A, et al. Risperidone versus haloperidol and amitriptyline in the treatment of patients with a combined psychotic and depressive syndrome. J Clin Psychopharmacol. 1998;18(2):111-20. [pmid: 9555596].
494 Muller MJ, Wetzel H, Eich FX, et al. Dose-related effects of amisulpride on five dimensions of psychopathology in patients with acute exacerbation of schizophrenia. J Clin Psychopharmacol. 2002;22(6):554-60. [pmid: 12454554].
495 Mullins CD, Obeidat NA, Cuffel BJ, et al. Risk of discontinuation of atypical antipsychotic agents in the treatment of schizophrenia. Schizophr Res. 2008;98(1-3):8-15. [pmid: 17596914].
496 Mullins CD, Shaya FT, Zito JM, et al. Effect of initial ziprasidone dose on treatment persistence in schizophrenia. Schizophr Res. 2006;83(2-3):277-84. [pmid: 16545945].
497 Muscettola G, Pampallona S, Barbato G, et al. Persistent tardive dyskinesia: demographic and pharmacological risk factors. Acta Psychiatr Scand. 1993;87(1):29-36. [pmid: 8093821].
498 Naber D, Riedel M, Klimke A, et al. Randomized double blind comparison of olanzapine vs. clozapine on subjective well-being and clinical outcome in patients with schizophrenia. Acta Psychiatr Scand. 2005;111(2):106-15. [pmid: 15667429].
499 Nair NP. Therapeutic equivalence of risperidone given once daily and twice daily in patients with schizophrenia: The Risperidone Study Group. J Clin Psychopharmacol. 1998;18(2):103-10. [pmid: 9555595].
500 Nakamura M, Ogasa M, Guarino J, et al. Lurasidone in the treatment of acute schizophrenia: a double-blind, placebo-controlled trial. J Clin Psychiatry. 2009;70(6):829-36. [pmid: 19497249].
501 Nakonezny PA, Byerly MJ. Electronically monitored adherence in outpatients with schizophrenia or schizoaffective disorder: a comparison of first- vs. second-generation antipsychotics. Schizophr Res. 2006;82(1):107-14. [pmid: 16376522].
502 Nasrallah HA, Duchesne I, Mehnert A, et al. Health-related quality of life in patients with schizophrenia during treatment with long-acting, injectable risperidone. J Clin Psychiatry. 2004;65(4):531-6. [pmid: 15119916].
503 Naz B, Craig TJ, Bromet EJ, et al. Remission and relapse after the first hospital admission in psychotic depression: a 4-year naturalistic followup. Psychol Med. 2007;37(8):1173-81. [pmid: 17335639].
504 Nechifor M, Vaideanu C, Palamaru I, et al. The influence of some antipsychotics on erythrocyte magnesium and plasma magnesium, calcium, copper and zinc in patients with paranoid schizophrenia. J Am Coll Nutr. 2004;23(5):549S-51S. [pmid: 15466963].
505 Nejtek VA, Avila M, Chen LA, et al. Do atypical antipsychotics effectively treat co-occurring bipolar disorder and stimulant dependence? a randomized, double-blind trial. J Clin Psychiatry. 2008;69(8):1257-66. [pmid: 18681757].
506 Nesvag R, Tanum L. Therapeutic drug monitoring of patients on risperidone depot. Nord J Psychiatry. 2005;59(1):51-5. [pmid: 16195099].
507 Nesvag R, Hendset M, Refsum H, et al. Serum concentrations of risperidone and 9-OH risperidone following intramuscular injection of long-acting risperidone compared with oral risperidone medication. Acta Psychiatr Scand. 2006;114(1):21-6. [pmid: 16774657].
508 Newcomer JW, Campos JA, Marcus RN, et al. A multicenter, randomized, double-blind study of the effects of aripiprazole in overweight subjects with schizophrenia or schizoaffective disorder switched from olanzapine. J Clin Psychiatry. 2008;69(7):1046-56. [pmid: 18605811].
509 Newcomer JW, Ratner RE, Eriksson JW, et al. A 24-week, multicenter, open-label, randomized study to compare changes in glucose metabolism in patients with schizophrenia receiving treatment with olanzapine, quetiapine, or risperidone. J Clin Psychiatry. 2009;70(4):487-99. [pmid: 19358783].
510 Newport DJ, Calamaras MR, DeVane CL, et al. Atypical antipsychotic administration during late pregnancy: placental passage and obstetrical outcomes. Am J Psychiatry. 2007;164(8):1214-20. [pmid: 17671284].
511 Neznanow NG, Ivanov MV, Maslovsky SY. Maintenance antipsychotic therapy: subjective quality of life in patients with schizophrenia. Int J Ment Health. 2005;34(4):11-8.
512 Nickel MK, Muehlbacher M, Nickel C, et al. Aripiprazole in the treatment of patients with borderline personality disorder: a double-blind, placebo-controlled study. Am J Psychiatry. 2006;163(5):833-8. [pmid: 16648324].
513 Nil R, Wehnert A. Sertindole: an atypical neuroleptic. Ashland, OH. Hogrefe & Huber. 2001:67-76.
514 Novick D, Haro JM, Suarez D, et al. Recovery in the outpatient setting: 36-month results from the Schizophrenia Outpatients Health Outcomes (SOHO) study. Schizophr Res. 2009;108(1-3):223-30. [pmid: 19070991].
515 Ohlmeier MD, Jahn K, Wilhelm-Gossling C, et al. Perazine and carbamazepine in comparison to olanzapine in schizophrenia. Neuropsychobiology. 2007;55(2):81-8. [pmid: 17570951].
516 Okasha TA, Kucukalic A, Nasr AA, et al. Longer-term treatment of patients with bipolar disorder: a 9-month observational study in Central and Eastern Europe, the Middle East and Africa. Curr Med Res Opin. 2009;25(8):1889-900. [pmid: 19538106].
517 Okugawa G. Randomized clinical comparison of perospirone and risperidone in patients with schizophrenia: Kansai Psychiatric Multicenter Study. Psychiatry Clin Neurosci. 2009;(3):322-8. [pmid: 19566763].
518 Okugawa G, Kato M, Wakeno M, et al. Randomized clinical comparison of perospirone and risperidone in patients with schizophrenia: Kansai Psychiatric Multicenter Study. Psychiatry Clin Neurosci. 2009;63(3):322-8. [pmid: 19566763].
519 Olfson M, Marcus SC, Corey-Lisle P, et al. Hyperlipidemia following treatment with antipsychotic medications. Am J Psychiatry. 2006;163(10):1821-5. [pmid: 17012695].
520 Olfson M, Uttaro T, Carson WH, et al. Male sexual dysfunction and quality of life in schizophrenia. J Clin Psychiatry. 2005;66(3):331-8. [pmid: 15766299].
521 Olie JP, Spina E, Murray S, et al. Ziprasidone and amisulpride effectively treat negative symptoms of schizophrenia: results of a 12-week, double-blind study. Int Clin Psychopharmacol. 2006;21(3):143-51. [pmid: 16528136].
522 Oosthuizen P, Emsley R, Jadri TH, et al. A randomized, controlled comparison of the efficacy and tolerability of low and high doses of haloperidol in the treatment of first-episode psychosis. Int J Neuropsychopharmacol. 2004;7(2):125-31. [pmid: 15003147].
523 Opjordsmoen S, Melle I, Friis S, et al. Stability of medication in early psychosis: a comparison between second-generation and low-dose first-generation antipsychotics. Early Intervention in Psychiatry. 2009;3(1):58-65. [pmid: 21352176].
524 Padala PR, Madison J, Monnahan M, et al. Risperidone monotherapy for post-traumatic stress disorder related to sexual assault and domestic abuse in women. Int Clin Psychopharmacol. 2006;21(5):275-80. [pmid: 16877898].
525 Pae CU, Nassir GS, Kim TS, et al. Rapid titration versus conventional titration of quetiapine in the treatment of bipolar mania: a preliminary trial. Int Clin Psychopharmacol. 2005;20(6):327-30. [pmid: 16192842].
526 Pae CU, Nassir GS, Patkar A, et al. Adjunctive risperidone, olanzapine and quetiapine for the treatment of hospitalized patients with bipolar I disorder: a retrospective study. Prog Neuropsychopharmacol Biol Psychiatry. 2006;30(7):1322-5. [pmid: 16631294].
527 Pae CU, Kim JJ, Lee CU, et al. Rapid versus conventional initiation of quetiapine in the treatment of schizophrenia: a randomized, parallel-group trial. J Clin Psychiatry. 2007;68(3):399-405. [pmid: 17388709].
528 Pae CU, Serretti A, Chiesa A, et al. Immediate versus gradual suspension of previous treatments during switch to aripiprazole: results of a randomized, open label study. Eur Neuropsychopharmacol. 2009;19(8):562-70. [pmid: 19442491].
529 Pascual JC, Perez V, Martin JLR, et al. Olanzapine orally-disintegrating tablet in severe psychotic agitation: a naturalistic study. Actas Esp Psiquiatr. 2007;35(1):47-51. [pmid: 17323225].
530 Patel JK, Buckley PF, Woolson S, et al. Metabolic profiles of second-generation antipsychotics in early psychosis: Findings from the CAFE study. Schizophr Res. 2009;111(1-3):9-16. [pmid: 19398192].
531 Patel MX, de ZN, Bernadt M, et al. Depot and oral antipsychotics: patient preferences and attitudes are not the same thing. J Psychopharmacol. 2009;23(7):789-96. [pmid: 18583438].
532 Patel NC, Dorson PG, Edwards N, et al. One-year rehospitalization rates of patients discharged on atypical versus conventional antipsychotics. Psychiatry Serv. 2002;53(7):891-3.
533 Patel NC, Crismon ML, Pondrom M. Rehospitalization rates of patients with bipolar disorder discharged on a mood stabilizer versus a mood stabilizer plus an atypical or typical antipsychotic. J Behav Health Serv Res. 2005;32(4):438-45. [pmid: 16215452].
534 Patkar AA, Peindl K, Mago R, et al. An open-label, rater-blinded, augmentation study of aripiprazole in treatment-resistant depression. Prim Care Companion J Clin Psychiatry. 2006;8(2):82-7. [pmid: 16862232].
535 Patris M, Agussol P, Alby JM, et al. A double-blind multicentre comparison of remoxipride, at two dose levels, and haloperidol. Acta Psychiatr Scand Suppl. 1990;358:78-82. [pmid: 1978497].
536 Penn DL, Keefe RS, Davis SM, et al. The effects of antipsychotic medications on emotion perception in patients with chronic schizophrenia in the CATIE trial. Schizophr Res. 2009;115(1):17-23. [pmid: 19766459].
537 Percudani M, Barbui C. Cost and outcome implications of using typical and atypical antipsychotics in ordinary practice in Italy. J Clin Psychiatry. 2003;64(11):1293-9. [pmid: 14658942].
538 Perez-Iglesias R, Crespo-Facorro B, Amado JA, et al. A 12-week randomized clinical trial to evaluate metabolic changes in drug-naive, first-episode psychosis patients treated with haloperidol, olanzapine, or risperidone. J Clin Psychiatry. 2007;68(11):1733-40. [pmid: 18052567].
539 Perez-Iglesias R, Vazquez-Barquero JL, Amado JA, et al. Effect of antipsychotics on peptides involved in energy balance in drug-naive psychotic patients after 1 year of treatment. J Clin Psychopharmacol. 2008;28(3):289-95. [pmid: 18480685].
540 Perez-Iglesias R, Crespo-Facorro B, Martinez-Garcia O, et al. Weight gain induced by haloperidol, risperidone and olanzapine after 1 year: Findings of a randomized clinical trial in a drug-naive population. Schizophr Res. 2008;99(1-3):13-22. [pmid: 18053689].
541 Perez-Iglesias R, Mata I, Pelayo-Teran JM, et al. Glucose and lipid disturbances after 1 year of antipsychotic treatment in a drug-naive population. Schizophr Res. 2009;107(2-3):115-21. [pmid: 18993033].
542 Perkins D, Lieberman J, Gu H, et al. Predictors of antipsychotic treatment response in patients with first-episode schizophrenia, schizoaffective and schizophreniform disorders. Br J Psychiatry. 2004;185:18-24. [pmid: 15231551].
543 Perkins D, Gu H, Weiden PJ, et al. Predictors of treatment discontinuation and medication nonadherence in patients recovering from a first episode of schizophrenia, schizophreniform disorder, or schizoaffective disorder: a randomized, double-blind, flexible-dose, multicenter study. J Clin Psychiatry. 2008;69(1):106-13. [pmid: 18312044].
544 Perkins DO, Johnson JL, Hamer RM, et al. Predictors of antipsychotic medication adherence in patients recovering from a first psychotic episode. Schizophr Res. 2006;83(1):53-63. [pmid: 16529910].
545 Perlis RH, Baker RW, Zarate CAJ, et al. Olanzapine versus risperidone in the treatment of manic or mixed states in bipolar I disorder: a randomized, double-blind trial. J Clin Psychiatry. 2006;67(11):1747-53. [pmid: 17196055].
546 Perry PJ, Lund BC, Sanger T, et al. Olanzapine plasma concentrations and clinical response: acute phase results of the North American Olanzapine Trial. J Clin Psychopharmacol. 2001;21(1):14-20. [pmid: 11199942].
547 Peuskens J, Link CGG. A comparison of quetiapine and chlorpromazine in the treatment of schizophrenia. Acta Psychiatr Scand. 1997;96(4):265-73. [pmid: 9350955].
548 Peuskens J, Van BB, De SC, et al. Effects of risperidone on affective symptoms in patients with schizophrenia. Int Clin Psychopharmacol. 2000;15(6):343-9. [pmid: 11110010].
549 Peuskens J, Bech P, Moller HJ, et al. Amisulpride vs. risperidone in the treatment of acute exacerbations of schizophrenia. Psychiatry Res. 1999;88(2):107-17. [pmid: 10622347].
550 Phillips LJ, McGorry PD, Yuen HP, et al. Medium term followup of a randomized controlled trial of interventions for young people at ultra high risk of psychosis. Schizophr Res. 2007;96(1-3):25-33. [pmid: 17611080].
551 Pigott TA, Carson WH, Saha AR, et al. Aripiprazole for the prevention of relapse in stabilized patients with chronic schizophrenia: a placebo-controlled 26-week study. J Clin Psychiatry. 2003;64(9):1048-56. [pmid: 14628980].
552 Potkin SG, Thyrum PT, Alva G, et al. The safety and pharmacokinetics of quetiapine when coadministered with haloperidol, risperidone, or thioridazine. J Clin Psychopharmacol. 2002;22(2):121-30. [pmid: 11910256].
553 Potkin SG, Gharabawi GM, Greenspan AJ, et al. A double-blind comparison of risperidone, quetiapine and placebo in patients with schizophrenia experiencing an acute exacerbation requiring hospitalization. Schizophr Res. 2006;85(1-3):254-65. [pmid: 16797162].
554 Potkin SG, Weiden PJ, Loebel AD, et al. Remission in schizophrenia: 196-week, double-blind treatment with ziprasidone vs. haloperidol. Int J Neuropsychopharmacol. 2009;12(9):1233-48. [pmid: 19419595].
555 Potkin SG, Keck PE Jr, Segal S, et al. Ziprasidone in Acute Bipolar Mania: a 21-day randomized, double-blind, placebo-controlled replication trial. J Clin Psychopharmacol. 2005;25(4):301-10. [pmid: 16012271].
556 Poyurovsky M, Faragian S, Fuchs C, et al. Effect of the selective norepinephrine reuptake inhibitor reboxetine on cognitive dysfunction in schizophrenia patients: an add-on, double-blind placebo-controlled study. Isr J Psychiatry Relat Sci. 2009;46(3):213-20. [pmid: 20039523].
557 Preval H, Klotz SG, Southard R, et al. Rapid-acting IM ziprasidone in a psychiatric emergency service: a naturalistic study. Gen Hosp Psychiatry. 2005;27(2):140-4. [pmid: 15763126].
558 Purdon SE, Jones BD, Stip E, et al. Neuropsychological change in early phase schizophrenia during 12 months of treatment with olanzapine, risperidone, or haloperidol: The Canadian Collaborative Group for research in schizophrenia. Arch Gen Psychiatry. 2000;57(3):249-58. [pmid: 10711911].
559 Purdon SE, Woodward N, Lindborg SR, et al. Procedural learning in schizophrenia after 6 months of double-blind treatment with olanzapine, risperidone, and haloperidol. Psychopharmacology. 2003;169(3-4):390-7. [pmid: 12827347].
560 Putzhammer A, Perfahl M, Pfeiff L, et al. Correlation of subjective well-being in schizophrenic patients with gait parameters, expert-rated motor disturbances, and psychopathological status. Pharmacopsychiatry. 2005;38(3):132-8. [pmid: 15902585].
561 Rabinowitz J, Harvey PD, Eerdekens M, et al. Premorbid functioning and treatment response in recent-onset schizophrenia. Br J Psychiatry. 2006;189:31-5. [pmid: 16816303].
562 Rabinowitz J, Bromet EJ, Davidson M. Short report: comparison of patient satisfaction and burden of adverse effects with novel and conventional neuroleptics: a naturalistic study. Schizophr Bull. 2001;27(4):597-600. [pmid: 11824486].
563 Raedler TJ, Schreiner A, Naber D, et al. Gender-specific effects in the treatment of acute schizophrenia with risperidone. Pharmacopsychiatry. 2006;39(5):171-4. [pmid: 16944407].
564 Ravindran A, Silverstone P, Lacroix D, et al. Risperidone does not affect steady-state pharmacokinetics of divalproex sodium in patients with bipolar disorder. Clin Pharmacokinet. 2004;43(11):733-40. [pmid: 15301577].
565 Razali MS, Yahya H. Compliance with treatment in schizophrenia: a drug intervention program in a developing country. Acta Psychiatr Scand. 1995;91(5):331-5. [pmid: 7639089].
566 Reich DB, Winternitz S, Hennen J, et al. A preliminary study of risperidone in the treatment of posttraumatic stress disorder related to childhood abuse in women. J Clin Psychiatry. 2004;65(12):1601-6. [pmid: 15641864].
567 Reich DB, Winternitz S, Hennen J, et al. A preliminary study of risperidone in the treatment of posttraumatic stress disorder related to childhood abuse in women. J Clin Psychiatry. 2004;65(12):1601-6. [pmid: 15641864].
568 Reilly JG, Ayis SA, Ferrier IN, et al. Thioridazine and sudden unexplained death in psychiatric in-patients. Br J Psychiatry. June. 2002;180:515-22. [pmid: 12042230].
569 Remington G, Pollock B, Voineskos G, et al. Acutely psychotic patients receiving high-dose haloperidol therapy. J Clin Psychopharmacol. 1993;13(1):41-5. [pmid: 8486816].
570 Remington G, Khramov I. Health care utilization in patients with schizophrenia maintained on atypical versus conventional antipsychotics. Prog Neuropsychopharmacol Biol Psychiatry. 2001;25(2):363-9. [pmid: 11294482].
571 Ren XS, Lee AF, Huang YH, et al. Initiation of atypical antipsychotic agents and health outcomes in patients with schizophrenia. J Clin Pharm Ther. 2004;29(5):471-81. [pmid: 15482392].
572 Ren XS, Qian S, Lee AF, et al. Treatment persistence: a comparison among patients with schizophrenia who were initiated on atypical antipsychotic agents. J Clin Pharm Ther. 2006;31(1):57-65. [pmid: 16476121].
573 Rettenbacher MA, Hummer M, Hofer A, et al. Alterations of glucose metabolism during treatment with clozapine or amisulpride: results from a prospective 16-week study. J Psychopharmacol. 2007;21(4):400-4. [pmid: 17050656].
574 Riedel M, Spellmann I, Strassnig M, et al. Effects of risperidone and quetiapine on cognition in patients with schizophrenia and predominantly negative symptoms. Eur Arch Psychiatry Clin Neurosci. 2007;257(6):360-70. [pmid: 17629731].
575 Riedel M, Muller N, Spellmann I, et al. Efficacy of olanzapine versus quetiapine on cognitive dysfunctions in patients with an acute episode of schizophrenia. Eur Arch Psychiatry Clin Neurosci. 2007;257(7):402-12. [pmid: 17629725].
576 Riedel M, Muller N, Strassnig M, et al. Quetiapine has equivalent efficacy and superior tolerability to risperidone in the treatment of schizophrenia with predominantly negative symptoms. Eur Arch Psychiatry Clin Neurosci. 2005;255(6):432-7. [pmid: 16267634].
577 Rifkin A, Doddi S, Karajgi B, et al. Dosage of haloperidol for schizophrenia. Arch Gen Psychiatry. 1991;48(2):166-70. [pmid: 1989572].
578 Ritsner MS, Gibel A. The effectiveness and predictors of response to antipsychotic agents to treat impaired quality of life in schizophrenia: a 12-month naturalistic followup study with implications for confounding factors, antidepressants, anxiolytics, and mood stabilizers. Prog Neuropsychopharmacol Biol Psychiatry. 2006;30(8):1442-52. [pmid: 16842897].
579 Ritsner M, Ponizovsky A, Endicott J, et al. The impact of side-effects of antipsychotic agents on life satisfaction of schizophrenia patients: a naturalistic study. Eur Neuropsychopharmacol. 2002;12(1):31-8. [pmid: 11788238].
580 Ritsner M, Gibel A, Perelroyzen G, et al. Quality of life outcomes of risperidone, olanzapine, and typical antipsychotics among schizophrenia patients treated in routine clinical practice: a naturalistic comparative study. J Clin Psychopharmacol. 2004;24(6):582-91. [pmid: 15538118].
581 Ritsner M, Perelroyzen G, Ilan H, et al. Subjective response to antipsychotics of schizophrenia patients treated in routine clinical practice: a naturalistic comparative study. J Clin Psychopharmacol. 2004;24(3):245-54. [pmid: 15118477].
582 Robinson DG, Woerner MG, Napolitano B, et al. Randomized comparison of olanzapine versus risperidone for the treatment of first-episode schizophrenia: 4-month outcomes. Am J Psychiatry. 2006;163(12):2096-102. [pmid: 17151160].
583 Rocca P, Montemagni C, Castagna F, et al. Relative contribution of antipsychotics, negative symptoms and executive functions to social functioning in stable schizophrenia. Prog Neuropsychopharmacol Biol Psychiatry. 2009;33(2):373-9. [pmid: 19211031].
584 Romeo R, Knapp M, Tyrer P, et al. The treatment of challenging behavior in intellectual disabilities: cost-effectiveness analysis. J Intellect Disabil Res. 2009;53(7):633-43. [pmid: 19460067].
585 Rosenheck RA, Leslie DL, Sindelar J, et al. Cost-effectiveness of second-generation antipsychotics and perphenazine in a randomized trial of treatment for chronic schizophrenia. Am J Psychiatry. 2006;163(12):2080-9. [pmid: 17151158].
586 Roth T, rogowski T, Hull S, et al. Efficacy and safety of Doxepin 1 mg, 3 mg, and 6 mg in adults with primary insomnia. Sleep. 2007;30(11):1555-61. [pmid: 18041488].
587 Rothbaum BO, Killeen TK, Davidson JR, et al. Placebo-controlled trial of risperidone augmentation for selective serotonin reuptake inhibitor-resistant civilian posttraumatic stress disorder. J Clin Psychiatry. 2008;69(4):520-5. [pmid: 18278987].
588 Rothermundt M, Arolt V, Leadbeater J, et al. Cytokine production in unmedicated and treated schizophrenic patients. Neuroreport Rapid Comm Neurosci Res. 2000;11(15):3385-8.
589 Rubio G, Martinez I, Ponce G, et al. Long-acting injectable risperidone compared with zuclopenthixol in the treatment of schizophrenia with substance abuse comorbidity. Can J Psychiatr Rev Canad Psychiatr. 2006;51(8):531-9.
590 Rubio G, Lopez-Munoz F, Alamo C. Effects of lamotrigine in patients with bipolar disorder and alcohol dependence. Bipolar Disord. 2006;8(3):289-93. [pmid: 16696832].
591 Rubio G, Martinez I, Recio A, et al. Risperidone versus zuclopenthixol in the treatment of schizophrenia with substance abuse comorbidity: a long-term randomized, controlled, crossover Study. Eur J Psychiatr. 2006;20(3):133-46.
592 Ruhrmann S, Kissling W, Lesch OM, et al. Efficacy of flupentixol and risperidone in chronic schizophrenia with predominantly negative symptoms. Prog Neuropsychopharmacol Biol Psychiatry. 2007;31(5):1012-22. [pmid: 17412473].
593 Rupnow MFT, Greenspan A, Gharabawi GM, et al. Incidence and costs of polypharmacy: Data from a randomized, double-blind, placebo-controlled study of risperidone and quetiapine in patients with schizophrenia or schizoaffective disorder. Curr Med Res Opin. 2007;23(11):2815-22. [pmid: 17910802].
594 Ryckmans V, Kahn JP, Modell S, et al. Switching to aripiprazole in outpatients with schizophrenia experiencing insufficient efficacy and/or safety/tolerability issues with risperidone: a randomized, multicentre, open-label study. Pharmacopsychiatry. 2009;42(3):114-21. [pmid: 19452380].
595 Sa AR, Hounie AG, Sampaio AS, et al. Obsessive-compulsive symptoms and disorder in patients with schizophrenia treated with clozapine or haloperidol. Compr Psychiatry. 2009;50(5):437-42. [pmid: 19683614].
596 Sacchetti E, Galluzzo A, Valsecchi P, et al. Ziprasidone vs clozapine in schizophrenia patients refractory to multiple antipsychotic treatments: the MOZART study. Schizophr Res. 2009;110(1-3):80-9. [pmid: 19269791].
597 Sacchetti E, Valsecchi P, Parrinello G. A randomized, flexible-dose, quasi-naturalistic comparison of quetiapine, risperidone, and olanzapine in the short-term treatment of schizophrenia: The QUERISOLA trial. Schizophr Res. 2008;98(1-3):55-65. [pmid: 17933497].
598 Sachs GS, Grossman F, Ghaemi SN, et al. Combination of a mood stabilizer with risperidone or haloperidol for treatment of acute mania: a double-blind, placebo-controlled comparison of efficacy and safety. Am J Psychiatry. 2002;159(7):1146-54. [pmid: 12091192].
599 Saeedi H, Remington G, Christensen BK. Impact of haloperidol, a dopamine D2 antagonist, on cognition and mood. Schizophr Res. 2006;85(1-3):222-31. [pmid: 16679001].
600 Safa M, Sadr S, Delfan B, et al. Metabolic effects of olanzapine and risperidone in patients with psychotic disorders. Int J Psychiatry Clin Pract. 2008;12(4):299-302.
601 Sandor P, Musisi S, Moldofsky H, et al. Tourette syndrome: a followup study. J Clin Psychopharmacol. 1990;10(3):197-9. [pmid: 2115892].
602 Sayers SL, Campbell EC, Kondrich J, et al. Cocaine abuse in schizophrenic patients treated with olanzapine versus haloperidol. J Nerv Ment Dis. 2005;193(6):379-86. [pmid: 15920378].
603 Scher-Svanum H, Stensland MD, Kinon BJ, et al. Weight gain as a prognostic indicator of therapeutic improvement during acute treatment of schizophrenia with placebo or active antipsychotic. J Psychopharmacol. 2005;19(Suppl 6):117.
604 Schimmelmann BG, Moritz S, Karow A, et al. Correlates of subjective well-being in schizophrenic patients treated with atypical antipsychotics. Int J Psychiatry Clin Pract. 2005;9(2):94-8.
605 Schooler N, Rabinowitz J, Davidson M, et al. Risperidone and haloperidol in first-episode psychosis: a long-term randomized trial. Am J Psychiatry. 2005;162(5):947-53. [pmid: 15863797].
606 Schooler NR, Keith SJ, Severe JB, et al. Relapse and rehospitalization during maintenance treatment of schizophrenia: the effects of dose reduction and family treatment. Arch Gen Psychiatry. 1997;54(5):453-63. [pmid: 9152099].
607 Schuld A, Kuhn M, Haack M, et al. A comparison of the effects of clozapine and olanzapine on the EEG of patients with schizophrenia. Pharmacopsychiatry. 2000;33(3):109-11. [pmid: 10855462].
608 Sechter D, Peuskens J, Fleurot O, et al. Amisulpride vs. risperidone in chronic schizophrenia: results of a 6-month double-blind study. Neuropsychopharmacology. 2002;27(6):1071-81. [pmid: 12464464].
609 Sechter D, Peuskens J, Fleurot O, et al. Amisulpride vs risperidone in chronic schizophrenia: results of a 6-month, double-blind study: correction. Neuropsychopharmacology. 2003;28(3):611.
610 Segal J, Berk M, Brook S. Risperidone compared with both lithium and haloperidol in mania: a double-blind randomized controlled trial. Clin Neuropharmacol. 1998;21(3):176-80. [pmid: 9617509].
611 Sellwood W, Tarrier N. Demographic factors associated with extreme non-compliance in schizophrenia. Soc Psychiatry Psychiatr Epidemiol. 1994;29(4):172-7. [pmid: 7939966].
612 Sergi MJ, Green MF, Widmark C, et al. Cognition and neurocognition: effects of risperidone, olanzapine, and haloperidol. Am J Psychiatry. 2007;164(10):1585-92. [pmid: 17898351].
613 Sernyak MJ, Desai R, Stolar M, et al. Impact of clozapine on completed suicide. Am J Psychiatry. 2001;158(6):931-7. [pmid: 11384902].
614 Shapira NA, Ward HE, Mandoki M, et al. A double-blind, placebo-controlled trial of olanzapine addition in fluoxetine-refractory obsessive-compulsive disorder. Biol Psychiatry. 2004;55(5):553-5. [pmid: 15023585].
615 Shapiro E, Shapiro AK, Fulop G, et al. Controlled study of haloperidol, pimozide and placebo for the treatment of Gilles de la Tourette's syndrome. Arch Gen Psychiatry. 1989;46(8):722-30. [pmid: 2665687].
616 Sheehan DV, McElroy SL, Harnett-Sheehan K, et al. Randomized, placebo-controlled trial of risperidone for acute treatment of bipolar anxiety. J Affect Disord. 2009;115(3):376-85. [pmid: 19042026].
617 Sheitman B. The pharmacologic treatment of first episode schizophrenia. 2001:45-48.
618 Shen J, Kobak KA, Zhao Y, et al. Use of remote centralized raters via live 2-way video in a multicenter clinical trial for schizophrenia. J Clin Psychopharmacol. 2008;28(6):691-3. [pmid: 19011439].
619 Silvestrini C, Arcangeli T, Biondi M, et al. A second trial of clozapine in a case of granulocytopenia. Hum Psychopharmacol. 2000;15(4):275-9. [pmid: 12404322].
620 Simpson GM, Glick ID, Weiden PJ, et al. Randomized, controlled, double-blind multicenter comparison of the efficacy and tolerability of ziprasidone and olanzapine in acutely ill inpatients with schizophrenia or schizoaffective disorder. Am J Psychiatry. 2004;161(10):1837-47. [pmid: 15465981].
621 Simpson GM, O'Gorman CJ, Loebel A, et al. Long-term improvement in efficacy and safety after switching to ziprasidone in stable outpatients with schizophrenia. CNS Spectr. 2008;13(10):898-905. [pmid: 18955945].
622 Simpson GM, Lindenmayer JP. Extrapyramidal symptoms in patients treated with risperidone. J Clin Psychopharmacol. 1997;17(3):194-201. [pmid: 9169965].
623 Simpson GM, Loebel A, Warrington L, Yang R. Efficacy and tolerability of ziprasidone and olanzapine in acutely ill inpatients with schizophrenia or schizoaffective disorder: results of a double-blind, six-week study, with a six-month, double-blind, continuation phase. 2006:149-163.
624 Simpson GM, Mahmoud RA, Lasser RA, et al. A 1-year double-blind study of 2 doses of long-acting risperidone in stable patients with schizophrenia or schizoaffective disorder. J Clin Psychiatry. 2006;67(8):1194-203. [pmid: 16965196].
625 Singh I, Owino WJE. A double-blind comparison of zuclopenithixol tablets with placebo in the treatment of mentally handicapped in-patients with associated behavioral disorders. J Intellect Disabil Res. 1992;36(6):541-9. [pmid: 1477491].
626 Sirota P, Pannet I, Koren A, et al. Quetiapine versus olanzapine for the treatment of negative symptoms in patients with schizophrenia. Hum Psychopharmacol. 2006;21(4):227-34. [pmid: 16783811].
627 Smeraldi E, Haefele E, Crespi G, et al. Amisulpride versus fluoxetine in dysthymia: preliminary results of a double-blind comparative study. Eur Psychiatry. 1996;11(Suppl 3):141s-3s.
628 Smith MA, McCoy R, Hamer-Maansson J, et al. Rapid dose escalation with quetiapine: a pilot study. J Clin Psychopharmacol. 2005;25(4):331-5. [pmid: 16012275].
629 Smith MA, McCoy R, Hamer-Maansson J, et al. Rapid dose escalation with quetiapine: a pilot study. J Clin Psychopharmacol. 2005;25(4):331-5. [pmid: 16012275].
630 Smulevich AB, Khanna S, Eerdekens M, et al. Acute and continuation risperidone monotherapy in bipolar mania: a 3-week placebo-controlled trial followed by a 9-week double-blind trial of risperidone and haloperidol. Eur Neuropsychopharmacol. 2005;15(1):75-84. [pmid: 15572276].
631 Souza VB, Moura Filho FJ, Souza FG, et al. Cataract occurrence in patients treated with antipsychotic drugs. Rev Bras Psiquiatr. 2008;30(3):222-6. [pmid: 18833422].
632 Spivak B, Shabash E, Sheitman B, et al. The effects of clozapine versus haloperidol on measures of impulsive aggression and suicidality in chronic schizophrenia patients: an open, nonrandomized, 6-month study. J Clin Psychiatry. 2003;64(7):755-60. [pmid: 12934974].
633 Spivak B, Shabash E, Sheitman B, et al. The effects of clozapine versus haloperidol on measures of impulsive aggression and suicidality in chronic schizophrenia patients: an open, nonrandomized, 6-month study. J Clin Psychiatry. 2003;64(7):755-60. [pmid: 12934974].
634 Spoelstra JA, Stolk RP, Cohen D, et al. Antipsychotic drugs may worsen metabolic control in type 2 diabetes mellitus. J Clin Psychiatry. 2004;65(5):674-8. [pmid: 15163254].
635 Sramek JJ, Eldon MA, Posvar E, et al. Initial safety, tolerability pharmacodynamics, and pharmacokinetics of CI-1007 in patients with schizophrenia. Psychopharmacol Bull. 1998;34(1):93-9. [pmid: 9564205].
636 Sramek JJ, Mack RJ, Awni W, et al. Two rapid-dose titrations of sertindole in patients with schizophrenia. J Clin Psychopharmacol. 1997;17(5):419-22. [pmid: 9315993].
637 Stallard J, Joyce E. The impact of olanzapine on attitude to medication and quality of life in schizophrenia. Psychiatr Bull. 2001;25(10):378-81.
638 Stevens A, Schwarz J, Schwarz B, et al. Implicit and explicit learning in schizophrenics treated with olanzapine and with classic neuroleptics. Psychopharmacology. 2002;160(3):299-306. [pmid: 11889499].
639 Stip E, Lussier I, Ngan E, et al. Discriminant cognitive factors in responder and non-responder patients with schizophrenia. Eur Psychiatry. 1999;14(8):442-50. [pmid: 10683630].
640 Strakowski SM, Johnson JL, DelBello MP, et al. Quality of life during treatment with haloperidol or olanzapine in the year following a first psychotic episode. Schizophr Res. 2005;78(2-3):161-9. [pmid: 15950436].
641 Strassnig M, Miewald J, Keshavan M, et al. Weight gain in newly diagnosed first-episode psychosis patients and healthy comparisons: one-year analysis. Schizophr Res. 2007;93(1-3):90-8. [pmid: 17478082].
642 Strejilevich SA, Palatnik A, Avila R, et al. Lack of extrapyramidal side effects predicts quality of life in outpatients treated with clozapine or with typical antipsychotics. Psychiatry Res. 2005;133(2-3):277-80. [pmid: 15741003].
643 Strous RD, Kupchik M, Roitman S, et al. Comparison between risperidone, olanzapine, and clozapine in the management of chronic schizophrenia: a naturalistic prospective 12-week observational study. Hum Psychopharmacol. 2006;21(4):235-43. [pmid: 16783815].
644 Stuve TA, Friedman L, Jesberger JA, et al. The relationship between smooth pursuit performance, motion perception and sustained visual attention in patients with schizophrenia and normal controls. Psychol Med. 1997;27(1):143-52. [pmid: 9122294].
645 Stuyt EB, Sajbel TA, Allen MH. Differing effects of antipsychotic medications on substance abuse treatment patients with co-occurring psychotic and substance abuse disorders. Am J Addict. 2006;15(2):166-73. [pmid: 16595355].
646 Su KP, Shen WW, Chuang CL, et al. A pilot cross-over design study on QTc interval prolongation associated with sulpiride and haloperidol. Schizophr Res. 2003;59(1):93-4. [pmid: 12413648].
647 Sumiyoshi T, Park S, Jayathilake K, et al. Effect of buspirone, a serotonin1A partial agonist, on cognitive function in schizophrenia: a randomized, double-blind, placebo-controlled study. Schizophr Res. 2007;95(1-3):158-68. [pmid: 17628435].
648 Suppes T, Vieta E, Liu S, et al. Maintenance treatment for patients with bipolar I disorder: results from a north american study of quetiapine in combination with lithium or divalproex (trial 127). Am J Psychiatry. 2009;166(4):476-88. [pmid: 19289454].
649 Suppes T, Datto C, Minkwitz M, et al. Effectiveness of the extended release formulation of quetiapine as monotherapy for the treatment of acute bipolar depression. J Affect Disord. 2010;121(1-2):106-15. [pmid: 19903574].
650 Suzuki T, Uchida H, Takeuchi H, et al. Simplifying psychotropic medication regimen into a single night dosage and reducing the dose for patients with chronic schizophrenia. Psychopharmacology. 2005;181(3):566-75. [pmid: 15991004].
651 Svestka J, Nahunek K, Ceskova E, et al. Controlled cross-over comparison of isofloxythepin and perphenazine in the treatment of schizophrenic psychoses. Act Nerv Super (Praha). 1989;31(1):32-4. [pmid: 2571218].
652 Svestka J, Synek O, Tomanova J, et al. Differences in the effect of second-generation antipsychotics on prolactinaemia: six weeks open-label trial in female in-patients. Neuroendocrinol Lett. 2007;28(6):881-8. [pmid: 18063941].
653 Swanson JW, Swartz MS, Elbogen EB. Effectiveness of atypical antipsychotic medications in reducing violent behavior among persons with schizophrenia in community-based treatment. Schizophr Bull. 2004;30(1):3-20. [pmid: 15176758].
654 Swanson JW, Swartz MS, Van Dorn RA, et al. Comparison of antipsychotic medication effects on reducing violence in people with schizophrenia. Br J Psychiatry. 2008;193(1):37-43. [pmid: 18700216].
655 Swanson JW, Swartz MS, Elbogen EB, et al. Reducing violence risk in persons with schizophrenia: olanzapine versus risperidone. J Clin Psychiatry. 2004;65(12):1666-73. [pmid: 15641872].
656 Swartz MS, Perkins DO, Stroup TS, et al. Effects of antipsychotic medications on psychosocial functioning in patients with chronic schizophrenia: findings from the NIMH CATIE Study. Am J Psychiatry. 2007;164(3):428-36. [pmid: 17329467].
657 Sweeney JA, Bauer KS, Keshavan MS, et al. Adverse effects of risperidone on eye movement activity: a comparison of risperidone and haloperidol in antipsychotic-naive schizophrenic patients. Neuropsychopharmacology. 1997;16(3):217-28. [pmid: 9138438].
658 Swinton M, Haddock A. Clozapine in special hospital: a retrospective case-control study. J Forens Psychiatry. 2000;11(3):587-96.
659 Taylor D, Hanssens L, Loze JY, et al. Preference of medicine and patient-reported quality of life in community-treated schizophrenic patients receiving aripiprazole vs standard of care: results from the STAR study. Eur Psychiatry. 2008;23(5):336-43. [pmid: 18423987].
660 Taylor DM, Douglas-Hall P, Olofinjana B, et al. Reasons for discontinuing clozapine: matched, case-control comparison with risperidone long-acting injection. Br J Psychiatry. 2009;194(2):165-7. [pmid: 19182180].
661 Taylor M, Turner M, Watt L, et al. Atypical anti-psychotics in the real world: a naturalistic comparative outcome study. Scott Med J. 2005;50(3):102-6. [pmid: 16163994].
662 Taylor M, Shajahan P, Lawrie SM. Comparing the use and discontinuation of antipsychotics in clinical practice: an observational study. J Clin Psychiatry. 2008;69(2):240-5. [pmid: 18363452].
663 Tench D, Soni SD, Ashwood T, et al. Steady-state pharmacokinetics of controlled release and immediate release formulations of remoxipride in patients with chronic schizophrenia. Psychopharmacology. 1990;101(1):132-6. [pmid: 1971445].
664 Thase ME, Macfadden W, Weisler RH, et al. Efficacy of quetiapine monotherapy in bipolar I and II depression: a double-blind, placebo-controlled study (the BOLDER II study). J Clin Psychopharmacol. 2006;26(6):600-9. [pmid: 17110817].
665 Thomas P, Vieta E. Amisulpride plus valproate vs haloperidol plus valproate in the treatment of acute mania of bipolar I patients: a multicenter, open-label, randomized, comparative trial. Neuropsychiatr Dis Treat. 2008;4(3):675-86. [pmid: 18830442].
666 Thompson PM, Bartzokis G, Hayashi KM, et al. Time-lapse mapping of cortical changes in schizophrenia with different treatments. Cerebral Cortex. 2009;19(5):1107-23. [pmid: 18842668].
667 Tiihonen J, Wahlbeck K, Lonnqvist J, et al. Effectiveness of antipsychotic treatments in a nationwide cohort of patients in community care after first hospitalisation due to schizophrenia and schizoaffective disorder: observational followup study. Br Med J. 2006;333(7561):224-7. [pmid: 16825203].
668 Tohen M, Sanger TM, McElroy SL, et al. Olanzapine versus placebo in the treatment of acute mania: Olanzapine HGEH Study Group. Am J Psychiatry. 1999;156(5):702-9. [pmid: 10327902].
669 Tohen M, Jacobs TG, Grundy SL, et al. Efficacy of olanzapine in acute bipolar mania: a double-blind, placebo-controlled study: The Olanzipine HGGW Study Group. Arch Gen Psychiatry. 2000;57(9):841-9. [pmid: 10986547].
670 Tohen M, Chengappa KNR, Suppes T, et al. Relapse prevention in bipolar 1 disorder: 18-month comparison of olanzapine plus mood stabiliser v. mood stabiliser alone. Br J Psychiatry. 2004;184(4):337-45. [pmid: 15056579].
671 Tohen M, Vieta E, Goodwin GM, et al. Olanzapine versus divalproex versus placebo in the treatment of mild to moderate mania: a randomized, 12-week, double-blind study. J Clin Psychiatry. 2008;69(11):1776-89. [pmid: 19014751].
672 Tohen M, Bowden CL, Smulevich AB, et al. Olanzapine plus carbamazepine v. carbamazepine alone in treating manic episodes. Br J Psychiatry. 2008;192(2):135-43. [pmid: 18245032].
673 Tohen MF. Olanzapine vs. placebo in adolescents with bipolar mania. 46th Annual NCDEU (New Clinical Drug Evaluation Unit) Meeting. 2006. 2006-15.
674 Tohen M, Baker RW, Altshuler LL, et al. Olanzapine versus divalproex in the treatment of acute mania. Am J Psychiatry. 2002;159(6):1011-7. [pmid: 12042191].
675 Tollefson GD, S T. Negative symptoms: a path analytic approach to a double-blind, placebo- and haloperidol-controlled clinical trial with olanzapine. Am J Psychiatry. 1997;(4):466-74. [pmid: 9090332].
676 Tollefson GD, Beasley CM Jr., Tran PV, et al. Olanzapine versus haloperidol in the treatment of schizophrenia and schizoaffective and schizophreniform disorders: results of an international collaborative trial. Am J Psychiatry. 1997;154(4):457-65. [pmid: 9090331].
677 Tollefson GD, Birkett MA, Kiesler GM, et al. Double-blind comparison of olanzapine versus clozapine in schizophrenic patients clinically eligible for treatment with clozapine. Biol Psychiatry. 2001;49(1):52-63. [pmid: 11163780].
678 Tran-Johnson TK, Sack DA, Marcus RN, et al. Efficacy and safety of intramuscular aripiprazole in patients with acute agitation: a randomized, double-blind, placebo-controlled trial. J Clin Psychiatry. 2007;68(1):111-9. [pmid: 17284138].
679 Tran PV, Hamilton SH, Kuntz AJ, et al. Double-blind comparison of olanzapine versus risperidone in the treatment of schizophrenia and other psychotic disorders. J Clin Psychopharmacol. 1997;17(5):407-18. [pmid: 9315992].
680 Tschoner A, Engl J, Rettenbacher M, et al. Effects of six second generation antipsychotics on body weight and metabolism: risk assessment and results from a prospective study. Pharmacopsychiatry. 2009;42(1):29-34. [pmid: 19153944].
681 Tschoner A, Engl J, Rettenbacher MA, et al. Is second-generation antipsychotic-induced hyperprolactinemia due to biologically active prolactin or to biologically inactive macroprolactin?: results from a prospective study. J Clin Psychiatry. 2009;70(2):293-4. [pmid: 19265646].
682 Tsirigotis K, Gruszczynski W. Personality functioning of outpatients with schizophrenia treated with classic neuroleptics and risperidone. Arch Psychiatr Psychother. 2004;6(3):23-36.
683 Tsirigotis K, Gruszczynski W. Needs and values of outpatients with schizophrenia, treated with classic neuroleptics and risperidone. Arch Psychiatr Psychother. 2004;6(3):37-51.
684 Tuninger E, Axelsson R, Levander S. A 3-year study of maintenance therapy with depot neuroleptics: clinical characteristics and medication at study entry. Nord J Psychiatry. 1994;48(6):409-17.
685 Tyrer P, Oliver-Africano P, Romeo R, et al. Neuroleptics in the treatment of aggressive challenging behavior for people with intellectual disabilities: a randomised controlled trial (NACHBID). Health Technol Assess. Apr. 2009;13(21):iii-iv. [pmid: 19397849].
686 Tyrer P, Oliver-Africano PC, Ahmed Z, et al. Risperidone, haloperidol, and placebo in the treatment of aggressive challenging behavior in patients with intellectual disability: a randomised controlled trial. The Lancet. 2008;371(9606):57-63.
687 Ulrich S, Neuhof S, Braun V, et al. Reduced haloperidol does not interfere with the anitpsychotic activity of haloperidol in the treatment of acute schizophrenia. Int Clin Psychopharmacol. 1999;14(4):219-28. [pmid: 10468314].
688 Van Kammen DP, Hommer DW, Malas KL. Effect of pimozide on positive and negative symptoms in schizophrenic patients: are negative symptoms state dependent?. Neuropsychobiology. 1987;18(3):113-7. [pmid: 3453426].
689 Van Nimwegen LJ, de HL, van Beveren NJ, et al. Effect of olanzapine and risperidone on subjective well-being and craving for cannabis in patients with schizophrenia or related disorders: a double-blind randomized controlled trial. Can J Psychiatr Rev Canad Psychiatr. 2008;53(6):400-5.
690 Van NL, de HL, van BN, et al. Obsessive-compulsive symptoms in a randomized, double-blind study with olanzapine or risperidone in young patients with early psychosis. J Clin Psychopharmacol. 2008;28(2):214-8. [pmid: 18344733].
691 Vanden BR, Vermote R, Buttiens M, et al. Risperidone as add-on therapy in behavioral disturbances in mental retardation: a double-blind placebo-controlled cross-over study. Acta Psychiatr Scand. 1993;87(3):167-71. [pmid: 7682029].
692 Vanelle JM, Douki S. A double-blind randomised comparative trial of amisulpride versus olanzapine for 2 months in the treatment of subjects with schizophrenia and comorbid depression. Eur Psychiatry. 2006;21(8):523-30. [pmid: 17113759].
693 varez-Jimenez M, Gonzalez-Blanch C, Vazquez-Barquero JL, et al. Attenuation of antipsychotic-induced weight gain with early behavioral intervention in drug-naive first-episode psychosis patients: a randomized controlled trial. J Clin Psychiatry. 2006;67(8):1253-60. [pmid: 16965204].
694 Vazquez-Bourgon J, Arranz MJ, Mata I, et al. Serotonin transporter polymorphisms and early response to antipsychotic treatment in first episode of psychosis. Psychiatry Res. 2010;175(3):189-94. [pmid: 20031235].
695 Velligan DI, Prihoda TJ, Sui D, et al. The effectiveness of quetiapine versus conventional antipsychotics in improving cognitive and functional outcomes in standard treatment settings. J Clin Psychiatry. 2003;64(5):524-31. [pmid: 12755654].
696 Verdoux H, Lengronne J, Liraud F, et al. Medication adherence in psychosis: predictors and impact on outcome: a 2-year followup of first-admitted subjects. Acta Psychiatr Scand. 2000;102(3):203-10. [pmid: 11008856].
697 Verdoux H, Liraud F, Bergey C, et al. Is the association between duration of untreated psychosis and outcome confounded?: a two year followup study of first-admitted patients. Schizophr Res. 2001;49(3):231-41. [pmid: 11356584].
698 Veser FH, Veser BD, McMullan JT, et al. Risperidone versus haloperidol, in combination with lorazepam, in the treatment of acute agitation and psychosis: a pilot, randomized, double-blind, placebo-controlled trial. J Psychiatr Pract. 2006;12(2):103-8. [pmid: 16728906].
699 Vieta E, Bourin M, Sanchez R, et al. Effectiveness of aripiprazole v. haloperidol in acute bipolar mania: double-blind, randomised, comparative 12-week trial. Br J Psychiatry. 2005;187:235-42. [pmid: 16135860].
700 Vieta E, Calabrese JR, Goikolea JM, et al. Quetiapine monotherapy in the treatment of patients with bipolar I or II depression and a rapid-cycling disease course: a randomized, double-blind, placebo-controlled study. Bipolar Disord. 2007;9(4):413-25. [pmid: 17547587].
701 Vieta E, Suppes T, Eggens I, et al. Efficacy and safety of quetiapine in combination with lithium or divalproex for maintenance of patients with bipolar I disorder (international trial 126). J Affect Disord. 2008;109(3):251-63. [pmid: 18579216].
702 Vik-Mo AO, Birkenaes AB, Ferno J, et al. Increased expression of lipid biosynthesis genes in peripheral blood cells of olanzapine-treated patients. Int J Neuropsychopharmacol. 2008;11(5):679-84. [pmid: 18241359].
703 Villari V, Rocca P, Fonzo V, et al. Oral risperidone, olanzapine and quetiapine versus haloperidol in psychotic agitation. Prog Neuropsychopharmacol Biol Psychiatry. 2008;32(2):405-13. [pmid: 17900775].
704 Vinson DR, Migala AF, Quesenberry CP Jr. Slow infusion for the prevention of akathisia induced by prochlorperazine: a randomized controlled trial. J Emerg Med. 2001;20(2):113-9. [pmid: 11207403].
705 Vitiello B, Aman MG, Scahill L, et al. Research knowledge among parents of children participating in a randomized clinical trial. J Am Acad Child Adolesc Psychiatry. 2005;44(2):145-9. [pmid: 15689727].
706 Volavka J, Czobor P, Sheitman B, et al. Clozapine, olanzapine, risperidone, and haloperidol in the treatment of patients with chronic schizophrenia and schizoaffective disorder. Am J Psychiatry. 2002;159(2):255-62. [pmid: 11823268].
707 Voruganti L, Cortese L, Oyewumi L, et al. Comparative evaluation of conventional and novel antipsychotic drugs with reference to their subjective tolerability, side-effect profile and impact on quality of life. Schizophr Res. 2000;43(2-3):135-45. [pmid: 10858632].
708 Voruganti L, Cortese L, Owyeumi L, et al. Switching from conventional to novel antipsychotic drugs: results of a prospective naturalistic study. Schizophr Res. 2002;57(2-3):201-8. [pmid: 12223251].
709 Voruganti LP, Awad AG, Parker G, et al. Cognition, functioning and quality of life in schizophrenia treatment: results of a one-year randomized controlled trial of olanzapine and quetiapine. Schizophr Res. 2007;96(1-3):146-55. [pmid: 17728106].
710 Vulink NC, Denys D, Fluitman SB, et al. Quetiapine augments the effect of citalopram in non-refractory obsessive-compulsive disorder: a randomized, double-blind, placebo-controlled study of 76 patients. J Clin Psychiatry. 2009;70(7):1001-8. [pmid: 19497245].
711 Wagner M, Quednow BB, Westheide J, et al. Cognitive improvement in schizophrenic patients does not require a serotonergic mechanism: randomized controlled trial of olanzapine vs amisulpride. Neuropsychopharmacology. 2005;30(2):381-90. [pmid: 15578006].
712 Walinder J, Holm AC. Experiences of long-term treatment with remoxipride: efficacy and tolerability. Acta Psychiatr Scand Suppl. 1990;358:158-63. [pmid: 1978477].
713 Weiden PJ, Simpson GM, Potkin SG, et al. Effectiveness of switching to ziprasidone for stable but symptomatic outpatients with schizophrenia. J Clin Psychiatry. 2003;64(5):580-8. [pmid: 12755663].
714 Weiden PJ, Daniel DG, Simpson G, et al. Improvement in indices of health status in outpatients with schizophrenia switched to ziprasidone. J Clin Psychopharmacol. 2003;23(6):595-600. [pmid: 14624190].
715 Weiden PJ, Schooler NR, Weedon JC, et al. A randomized controlled trial of long-acting injectable risperidone vs continuation on oral atypical antipsychotics for first-episode schizophrenia patients: initial adherence outcome. J Clin Psychiatry. 2009;70(10):1397-406. [pmid: 19906343].
716 Weiden PJ, Newcomer JW, Loebel AD, et al. Long-term changes in weight and plasma lipids during maintenance treatment with ziprasidone. Neuropsychopharmacology. 2008;33(5):985-94. [pmid: 17637612].
717 Weiser M, Shneider-Beeri M, Nakash N, et al. Improvement in cognition associated with novel antipsychotic drugs: a direct drug effect or reduction of EPS?. Schizophr Res. 2000;46(2-3):81-9. [pmid: 11120419].
718 Wetterling T, Mussigbrodt HE. Weight gain: side effect of atypical neuroleptics?. J Clin Psychopharmacol. 1999;19(4):316-21. [pmid: 10440458].
719 Wetzel H, Grunder G, Hillert A, et al. Amisulpride versus flupentixol in schizophrenia with predominantly positive symptomatology: a double-blind controlled study comparing a selective D2-like antagonist to a mixed D1-/D2-like antagonist. Psychopharmacology. 1998;137(3):223-32. [pmid: 9682999].
720 Wichman CL. Atypical antipsychotic use in pregnancy: A retrospective review. ARCH WOMENS MENT HEALTH. 2009;12(1):53-7. [pmid: 19137446].
721 Wiedemann G, Hahlweg K, Hank G, et al. Deliverability of psychoeducational family management. Schizophr Bull. 1994;20(3):547-56. [pmid: 7973470].
722 Wiedemann G, Hahlweg K, Muller U, et al. Effectiveness of targeted intervention and maintenance pharmacotherapy in conjunction with family intervention in schizophrenia. Eur Arch Psychiatry Clin Neurosci. 2001;251(2):72-84. [pmid: 11407442].
723 Wilhelm S, Schacht A, Wagner T. Use of antipsychotics and benzodiazepines in patients with psychiatric emergencies: results of an observational trial. BMC Psychiatry. 2008;8:61. [pmid: 18647402].
724 Windgassen K. Treatment with neuroleptics: the patient's perspective. Acta Psychiatr Scand. 1992;86(5):405-10. [pmid: 1362474].
725 Wirshing DA, Marshall BD, Green MF, et al. Risperidone in treatment-refractory schizophrenia. Am J Psychiatry. 1999;156(9):1374-9. [pmid: 10484947].
726 Wittorf A, Sickinger S, Wiedemann G, et al. Neurocognitive effects of atypical and conventional antipsychotic drugs in schizophrenia: a naturalistic 6-month followup study. Arch Clin Neuropsychol. 2008;23(3):271-82. [pmid: 18272323].
727 Wolf J, Janssen F, Lublin H, et al. A prospective, multicentre, open-label study of aripiprazole in the management of patients with schizophrenia in psychiatric practice in Europe: Broad Effectiveness Trial with Aripiprazole in Europe (EU-BETA). Curr Med Res Opin. 2007;23(10):2313-23. [pmid: 17706003].
728 Wong CM, Hollander E. Headache response to m-chlorophenylpiperazine in obsessive-compulsive disorder and normal controls. Biol Psychiatry. 1996;40(6):544-6. [pmid: 8879476].
729 Wright P, Birkett M, David SR, et al. Double-blind, placebo-controlled comparison of intramuscular olanzapine and intramuscular haloperidol in the treatment of acute agitation in schizophrenia. Am J Psychiatry. 2001;158(7):1149-51. [pmid: 11431240].
730 Wunderink L, Nienhuis FJ, Sytema S, et al. Guided discontinuation versus maintenance treatment in remitted first-episode psychosis: relapse rates and functional outcome. J Clin Psychiatry. 2007;68(5):654-61. [pmid: 17503973].
731 Yagcioglu AEA, Akdede BBK, Turgut TI, et al. A double-blind controlled study of adjunctive treatment with risperidone in schizophrenic patients partially responsive to clozapine: efficacy and safety. J Clin Psychiatry. 2005;66(1):63-72. [pmid: 15669890].
732 Yamashita H, Morinobu S, Yamawaki S, et al. Effect of risperidone on sleep in schizophrenia: a comparison with haloperidol. Psychiatry Res. 2002;109(2):137-42. [pmid: 11927138].
733 Yatham LN, Paulsson B, Mullen J, et al. Quetiapine versus placebo in combination with lithium or divalproex for the treatment of bipolar mania. J Clin Psychopharmacol. 2004;24(6):599-606. [pmid: 15538120].
734 Yatham LN, Fallu A, Binder CE. A 6-month randomized open-label comparison of continuation of oral atypical antipsychotic therapy or switch to long acting injectable risperidone in patients with bipolar disorder. Acta Psychiatr Scand. 2007;116(Suppl 434):50-6.
735 Yatham LN, Grossman F, Augustyns I, et al. Mood stabilisers plus risperidone or placebo in the treatment of acute mania: international, double-blind, randomised controlled trial. Br J Psychiatry. 2003;182(2):141-7. [pmid: 12562742].
736 Young AH, Oren DA, Lowy A, et al. Aripiprazole monotherapy in acute mania: 12-week randomised placebo- and haloperidol-controlled study. Br J Psychiatry. 2009;194(1):40-8. [pmid: 19118324].
737 Yu AP, Atanasov P, Ben-Hamadi R, et al. Resource utilization and costs of schizophrenia patients treated with olanzapine versus quetiapine in a Medicaid population. Value Health. 2009;12(5):708-15. [pmid: 19508658].
738 Yuan GZ, Zhou ZH, Yao JJ. Effect of quetiapine on cognitive function in schizophrenia: a mismatch negativity potentials study. Acta Neuropsychiatrica. 2009;21(1):26-33.
739 Yumru M, Savas HA, Kurt E, et al. Atypical antipsychotics related metabolic syndrome in bipolar patients. J Affect Disord. 2007;98(3):247-52. [pmid: 16970993].
740 Zanarini MC, F F. Olanzapine treatment of female borderline personality disorder patients: a double-blind, placebo-controlled pilot study. J Clin Psychiatry. 2001;(11):849-54. [pmid: 11775043].
741 Zarcone JR, Lindauer SE, Morse PS, et al. Effects of risperidone on destructive behavior of persons with developmental disabilities: functional analysis. Am J Ment Retard. 2004;109(4):310-21. [pmid: 15176916].
742 Zbytovsky J, Zapletalek M. Longitudinal study of the effect, tolerance and undesired side effects of injection haloperidol decanoate applied in different psychiatric indications. Act Nerv Super (Praha). 1989;31(4):266-7. [pmid: 2638106].
743 Zhang XY, Zhou DF, Cao LY, et al. Risperidone versus haloperidol in the treatment of acute exacerbations of chronic inpatients with schizophrenia: a randomized double-blind study. Int Clin Psychopharmacol. 2001;16(6):325-30. [pmid: 11712620].
744 Zhong KX, Sweitzer DE, Hamer RM, et al. Comparison of quetiapine and risperidone in the treatment of schizophrenia: a randomized, double-blind, flexible-dose, 8-week study. J Clin Psychiatry. 2006;67(7):1093-103. [pmid: 16889453].
745 Zimbroff DL, Kane JM, Tamminga CA, et al. Controlled, dose-response study of sertindole and haloperidol in the treatment of schizophrenia: Sertindole Study Group. Am J Psychiatry. 1997;154(6):782-91. [pmid: 9167505].
746 Zink M, Kuwilsky A, Krumm B, et al. Efficacy and tolerability of ziprasidone versus risperidone as augmentation in patients partially responsive to clozapine: a randomised controlled clinical trial. J Psychopharmacol. 2009;23(3):305-14. [pmid: 18562423].
747 Zipursky RB, Christensen BK, Daskalakis Z, et al. Treatment response to olanzapine and haloperidol and its association with dopamine D receptor occupancy in first-episode psychosis. Can J Psychiatr Rev Canad Psychiatr. 2005;50(8):462-9.
748 Zipursky RB, Gu H, Green AI, et al. Course and predictors of weight gain in people with first-episode psychosis treated with olanzapine or haloperidol. Br J Psychiatry. 2005;187(6):537-43. [pmid: 16319406].

## Excluded – Not primary research (N = 89)

The following studies were excluded because they were not primary research.

1 Anon. AstraZeneca. Formulary. 1999;34(Suppl 10):13-8.
2 Anon. Atypical antipsychotic agents in the treatment of schizophrenia and other psychiatric disorders. Part I: unique patient populations. J Clin Psychiatry. 1998;59(5):259-65. [pmid: 9632042].
3 Anon. Effects of quetiapine on adolescent conduct disorder. Brown Univ Child Adolesc Psychopharmacol Update. 2008;10(7):3-4.
4 Anon. Effects of risperidone on cognitive function in children with disruptive behaviors. Brown Univ Child Adolesc Psychopharmacol Update. 2007;9(9):4-5.
5 Anon. First drug to treat irritability associated with autism. FDA Consumer. 2007;41(1):4.
6 Anon. Pharmacotherapy facilitates management of psychiatric disorders in children and adolescents. Drugs and Therapy Perspectives. 1996;8(7):9-12. Date of Publication: 30 Sep 1996 1996;(7):9-12.
7 Anon. Risperidone in children, adolescents and adults with MR. Brown Univ Child Adolesc Psychopharmacol Update. 2006;17(7):4.
8 Anon. Risperidone and piracetam may be effective for behavior problems in autism. Brown Univ Child Adolesc Psychopharmacol Update. 2007;9(12):4.
9 Anon. Study of risperidone with autistic children finds no detrimental cognitive effects. Brown Univ Child Adolesc Psychopharmacol Update. 2008;10(9):3-4.
10 Anon. Ziprasidone may help treat behavior problems associated with autism. Brown Univ Child Adolesc Psychopharmacol Update. 2003;5(1):1.
11 Adams CE, Fenton MKP, Quraishi S, et al. Systematic meta-review of depot antipsychotic drugs for people with schizophrenia. Br J Psychiatry. Oct. 2001;179:290-9. [pmid: 11581108].
12 Adler LA, Barkley RA, Newcorn JH, et al. Managing ADHD in children, adolescents, and adults with comorbid anxiety. Journal of Clinical Psychiatry. Mar. 2007;68(3):451-62. [pmid: 17388718].
13 Boucher N, Bairam A, Beaulac-Baillargeon L. A new look at the neonate's clinical presentation after in utero exposure to antidepressants in late pregnancy. J Clin Psychopharmacol. 2008;28(3):334-9. [pmid: 18480693].
14 Caicedo C, Williams SH. Risperidone improves behavior in children with autism. J Fam Pract. 2002;51(11):915. [pmid: 12485538].
15 Clark A. Proposed treatment for adolescent psychosis: bipolar illness. Adv Psychiatr Treat. 2001;7(2):143-9.
16 Clark AF. Proposed treatment for adolescent psychosis: schizophrenia and schizophrenia-like psychoses. Adv Psychiatr Treat. 2001;7(1):16-23.
17 Cooper WO, Arbogast PG, Ding H, et al. Trends in prescribing of antipsychotic medications for US children. Ambul Pediatr. 2006;6(2):79-83. [pmid: 16530143].
18 Correll CU. Metabolic side effects of second-generation antipsychotics in children and adolescents: a different story?. J Clin Psychiatry. Oct. 2005;66(10):1331-2. [pmid: 16259549].
19 Correll CU. Antipsychotic use in children and adolescents: minimizing adverse effects to maximize outcomes. J Am Acad Child Adolesc Psychiatry. Jan. 2008;47(1):9-20. [pmid: 18174821].
20 Costello EJ, Shugart MA. Child mental health and primary pediatric care. Curr Opin. 1991;3(4):636-41.
21 Czekalla J, Beasley CM Jr., Dellva MA, et al. Analysis of the QTc interval during olanzapine treatment of patients with schizophrenia and related psychosis. J Clin Psychiatry. 2001;62(3):191-8. [pmid: 11305706].
22 Danielyan A, Pathak S, Kowatch RA, et al. Clinical characteristics of bipolar disorder in very young children. J Affect Disord. 2007;97(1-3):51-9. [pmid: 16822549].
23 de HL, Booij J, Lavalaye J, et al. Occupancy of dopamine D2 receptors by antipsychotic drugs is related to nicotine addiction in young patients with schizophrenia. Psychopharmacology. 2006;183(4):500-5. [pmid: 16292589].
24 Dossenbach M, Treuer T, Kryzhanovskaya L, et al. Olanzapine versus chlorpromazine in the treatment of schizophrenia: a pooled analysis of four 6-week, randomized, open-label studies in the Middle East and North Africa. J Clin Psychopharmacol. 2007;27(4):329-37. [pmid: 17632215].
25 Ebell M. Is risperidone safe and effective for pediatric autism?. Evid Based Pract. 2002;5(11):7-8.
26 Eggers C, Rothenberger A, Berghaus U. Clinical and neurobiological findings in children suffering from tic disease following treatment with tiapride. Eur Arch Psychiatry Neurol Sci. 1988;237(4):223-9. [pmid: 2974416].
27 Einfeld SL. Systematic management approach to pharmacotherapy for people with learning disabilities. Adv Psychiatr Treat. 2001;7(1):43-8.
28 Findling RL, Frazier JA, Gerbino-Rosen G, et al. Is there a role for clozapine in the treatment of children and adolescents?. J Am Acad Child Adolesc Psychiatry. 2007;46(3):423-8. [pmid: 17314729].
29 Fisher M. Treatment of eating disorders in children, adolescents, and young adults. Pediatr Rev. Jan. 2006;27(1):5-16. [pmid: 16387924].
30 Galynker I, Khan A, Grebchenko Y, et al. Low-dose risperidone and quetiapine as monotherapy for comorbid anxiety and depression. J Clin Psychiatry. 2005;66(4):544. [pmid: 15816805].
31 Gillberg C. The psychopharmacology of autism and related disorders. J Psychopharmacol. 1996;10(1):54-63. [pmid: 22302728].
32 Glick ID, Lemmens P, Vester-Blokland E. Treatment of the symptoms of schizophrenia: a combined analysis of double-blind studies comparing risperidone with haloperidol and other antipsychotic agents. Int Clin Psychopharmacol. 2001;16(5):265-74. [pmid: 11552769].
33 Golden W, Domon S, Miller L, et al. Use of atypical antipsychotic medications in children. J Ark Med Soc. 2009;106(1):12-3. [pmid: 19606632].
34 Hamilton JD. The practical search. J Am Acad Child Adolesc Psychiatry. 2007;46(3):418-22. [pmid: 17314728].
35 Hilt RJ, Woodward TA. Agitation treatment for pediatric emergency patients. J Am Acad Child Adolesc Psychiatry. Feb. 2008;47(2):132-8. [pmid: 18216715].
36 Howland RH. Psychopharmacology grand rounds. Use of atypical antipsychotics in children & adolescents. J Psychosoc Nurs Ment Health Serv. 2005;43(8):15-8. [pmid: 16149723].
37 Howland RH. Use of atypical antipsychotics in children and adolescents. J Psychosoc Nurs Ment Health Serv. 2005;43(8):15-8. [pmid: 16149723].
38 Jensen J, Kumra SM, Thomarios N, et al. Atypical antipsychotics for children and adolescents with schizophrenia-spectrum disorders. Psychiatr Times. 2009;26(8):45.
39 Kaidar M, Zalsman G. Olanzapine for Childhood Disintegrative Disorder. Isr J Psychiatry Relat Sci. 2004;41(1):71-2. [pmid: 15160660].
40 Kane JM, Barrett EJ, Casey DE, et al. Metabolic effects of treatment with atypical antipsychotics. J Clin Psychiatry. 2004;65(11):1447-55. [pmid: 15554755].
41 Kane JM, Lauriello J, Laska E, et al. Long-term efficacy and safety of iloperidone: results from 3 clinical trials for the treatment of schizophrenia. J Clin Psychopharmacol. 2008;28(2:Suppl 1):S29-35. [pmid: 18334910].
42 Kaplan BJ, Shannon S. Nutritional aspects of child and adolescent psychopharmacology. Pediatric Annals. Sep. 2007;36(9):600-9. [pmid: 17910207].
43 Kennedy E, Kumar A, Datta SS. Antipsychotic medication for childhood-onset schizophrenia. Schizophr Bull. 2007;33(5):1082-3. [pmid: 17670793].
44 Kluger J, Song S. Young and bipolar. Time. 2002;160(8):38-46. [pmid: 12195775].
45 Kowatch RA. Placebo controlled trial of valproate and risperidone in young children with bipolar disorders. Controlled Trials. 2006.
46 Kryzhanovskaya LA, Robertson-Plouch CK, Xu W, et al. The safety of olanzapine in adolescents with schizophrenia or bipolar I disorder: a pooled analysis of 4 clinical trials. J Clin Psychiatry. 2009;70(2):247-58. [pmid: 19210948].
47 Kuehn BM. Scientists probe child bipolar disorder. J Am Med Assoc. Mar. 2007;297(11):1181.
48 Lane HY, Chang WH, Chiu CC, et al. A pilot double-blind, dose-comparison study of risperidone in drug-naive, first-episode schizophrenia. J Clin Psychiatry. 2001;62(12):994-5. [pmid: 11780884].
49 LeBlanc JC, Binder CE, Armenteros JL, et al. Risperidone reduces aggression in boys with a disruptive behavior disorder and below average intelligence quotient: analysis of two placebo-controlled randomized trials. Int Clin Psychopharmacol. 2005;20(5):275-83. [pmid: 16096518].
50 Locascio JJ, Malone RP, Small AM, et al. Factors related to haloperidol response and dyskinesias in autistic children. Psychopharmacol Bull. 1991;27(2):119-26. [pmid: 1924657].
51 Lemke JL. Clinical trials and the drugging of our children. J Orthomol Med. Sep. 2006;21(3):152-6.
52 Lydiard RB, Culpepper L, Schiler H, et al. Quetiapine monotherapy as treatment for anxiety symptoms in patients with bipolar depression: a pooled analysis of results from 2 double-blind, randomized, placebo-controlled studies. Prim Care Companion J Clin Psychiatry. 2009;11(5):215-25. [pmid: 19956459].
53 Malone RP, Sheikh R, Zito JM. Novel antipsychotic medications in the treatment of children and adolescents. Psychiatr Serv. 1999;50(2):171-4. [pmid: 10030474].
54 McClellan JM. Olanzapine and pediatric bipolar disorder: evidence for efficacy and safety concerns. AM J Psychiatry. 2007;164(10):1462-4. [pmid: 17898331].
55 McCracken JT, McGough J, Shah B, et al. Risperidone was safe and effective for short term treatment of children with autism and serious behavioral disturbances. Evid Based Med. Jan. 2003;8(1):22.
56 Miller dD, Eudicone JM, Pikalov A, et al. Comparative assessment of the incidence and severity of tardive dyskinesia in patients receiving aripiprazole or haloperidol for the treatment of schizophrenia: a post hoc analysis. J Clin Psychiatry. 2007;68(12):1901-6. [pmid: 18162021].
57 O'Connell N. Research and development round-up. Nurse Prescribing. June. 2008;6(7):318-23.
58 O'Connell N. Research and development round-up. Nurse Prescribing. Aug. 2008;6(9):412-9.
59 Oldham J. Indications. J Psychiatr Pract. 2008;14(3):133. [pmid: 18520781].
60 Pandina GJ, Bossie CA, Zhu Y, et al. Evaluating movement disorders in pediatric patients receiving risperidone: a comparison of spontaneous reports and research criteria for TD. Child Adolesc Psychiatry Ment Health. 2007. Jun. Article Number: 3.
61 Pandina GJ, Bilder R, Harvey PD, et al. Risperidone and cognitive function in children with disruptive behavior disorders. Biol Psychiatry. 2007;62(3):226-34. [pmid: 17210137].
62 Patel NC, Delbello MP, Kowatch RA, et al. Preliminary study of relationships among measures of depressive symptoms in adolescents with bipolar disorder. J Child Adolesc Psychopharmacol. 2006;16(3):327-35. [pmid: 16768640].
63 Pomerantz JM. Off-label uses for atypical antipsychotic drugs in children. Drug Benefit Trends. Jan. 2003;15(1):36-7.
64 Potkin SG, Litman RE, Torres R, et al. Efficacy of iloperidone in the treatment of schizophrenia: initial phase 3 studies. J Clin Psychopharmacol. 2008;28(2:Suppl 1):S4-11. [pmid: 18334911].
65 Remschmidt H. Childhood and adolescent schizophrenia. Curr Opin Psychiatry. 1993;6(4):470-9.
66 Roke Y, van Harten PN, Boot AM, et al. Antipsychotic medication in children and adolescents: a descriptive review of the effects on prolactin level and associated side effects. J Child Adolesc Psychopharmacol. 2009;19(4):403-414. Date of Publication: 01 Aug 2009 2009;(4):403-14. [pmid: 19702492].
67 Sanford M, Keating GM. Aripiprazole: in adolescents with schizophrenia. Paediatr Drugs. 2007;9(6):419-23. [pmid: 18052412].
68 Scahill L, Koenig K, Carroll DH, et al. Risperidone approved for the treatment of serious behavioral problems in children with autism. J Child Adolesc Psychiatr Nurs. 2007;20(3):188-90. [pmid: 17688557].
69 Shapiro AK, Shapiro E. Treatment of tic disorders with neuroleptic drugs. 1996:137-170.
70 Singh MK, Pfeifer JC, Barzman DH, et al. Medical management of pediatric mood disorders. Pediatr Ann. Sep. 2007;36(9):552-63. [pmid: 17910203].
71 Small JG, Kolar MC, Kellams JJ. Quetiapine in schizophrenia: onset of action within the first week of treatment. Curr Med Res Opin. 2004;20(7):1017-23. [pmid: 15265246].
72 Sporn AL, Vermani A, Greenstein DK, et al. Clozapine treatment of childhood-onset schizophrenia: evaluation of effectiveness, adverse effects, and long-term outcome. J Am Acad Child Adolesc Psychiatry. 2007;46(10):1349-56. [pmid: 17885577].
73 Srivastava LK, Rochford J, Young SN. The 21st annual meeting of the Canadian College of Neuropsychopharmacology. Journal of Psychiatry and Neuroscience. 1998;23(5):277-287. Date of Publication: 1998 1998;(5):277-87.
74 Stigler KA, Potenza MN, McDougle CJ. Tolerability profile of atypical antipsychotics in children and adolescents. Pediatr Drugs. 2001;3(12):927-42.
75 Suppes T, Eudicone J, McQuade R, et al. Efficacy and safety of aripiprazole in subpopulations with acute manic or mixed episodes of bipolar I disorder. J Affect Disord. 2008;107(1-3):145-54. [pmid: 17904226].
76 Swartz MS, Stroup TS, McEvoy JP, et al. What CATIE found: results from the schizophrenia trial. Psychiatr Serv. 2008;59(5):500-6. [pmid: 18451005].
77 Thase ME, Jonas A, Khan A, et al. Aripiprazole monotherapy in nonpsychotic bipolar I depression: results of 2 randomized, placebo-controlled studies. [Erratum appears in J Clin Psychopharmacol. 2009 Feb;29(1):38]. J Clin Psychopharmacol. 2008;28(1):13-20. [pmid: 18204335].
78 Thyssen A, Remmerie B, D'Hoore P, et al. Rapidly disintegrating risperidone in subjects with schizophrenia or schizoaffective disorder: a summary of ten phase I clinical trials assessing taste, tablet disintegration time, bioequivalence, and tolerability. Clin Ther. 2007;29(2):290-304. [pmid: 17472821].
79 Troost PW. Risperidone shows long-term effects in children with autism. Indian J Pediatr. 2006;73(4):286.
80 Varley CK, McClellan J. Implications of marked weight gain associated with atypical antipsychotic medications in children and adolescents. JAMA. 2009;302(16):1811-2. [pmid: 19861677].
81 Vieta E, Mullen J, Brecher M, et al. Quetiapine monotherapy for mania associated with bipolar disorder: combined analysis of two international, double-blind, randomised, placebo-controlled studies. Curr Med Res Opin. 2005;21(6):923-34. [pmid: 15969892].
82 Volavka J, Czobor P, Citrome L, et al. Efficacy of aripiprazole against hostility in schizophrenia and schizoaffective disorder: data from 5 double-blind studies. J Clin Psychiatry. 2005;66(11):1362-6. [pmid: 16420071].
83 Wagner K. New Findings in Early-Onset Schizophrenia. Psychiatr Times. 2008;25(4):67.
84 Waugaman RM. Potential lower efficacy of molindone among first-generation antipsychotics. AM J Psychiatry. 2009;166(4):491-3. [pmid: 19339370].
85 Weiden PJ, Cutler AJ, Polymeropoulos MH, et al. Safety profile of iloperidone: a pooled analysis of 6-week acute-phase pivotal trials. J Clin Psychopharmacol. 2008;28(2:Suppl 1):S12-9. [pmid: 18334908].
86 Weller EB, Danielyan AK, Weller RA. Somatic treatment of bipolar disorder in children and adolescents. Child Adolesc Psychiatr Clin N Am. 2002;11(3):595-617. [pmid: 12222085].
87 West CL, Findling RL. Newer pharmacologic treatments for childhood ADHD. Int Drug Ther Newsl. 2004;39(3):21-2.
88 Williams S. Recent treatment options for ADHD. US Pharm. Mar. 2008;33(3):66-71.
89 Young JG. Risperidone was effective for aggression in adolescents with disruptive behavior disorders and below average intelligence. Evid Based Ment Health. 2002;5(1):11. [pmid: 11915814].

## Excluded – Ineligible study design (N = 70)

The following studies were excluded because the study design did not meet the eligibility criteria.

1 Ad-Dab'bagh Y, Greenfield B, Milne-Smith J, et al. Inpatient treatment of severe disruptive behavior disorders with risperidone and milieu therapy. Can J Psychiatry. 2000;45(4):376-82. [pmid: 10813072].
2 Agid O, Remington G, Kapur S, et al. Early use of clozapine for poorly responding first-episode psychosis. J Clin Psychopharmacol. 2007;27(4):369-73. [pmid: 17632221].
3 Aman MG, Vinks AA, Remmerie B, et al. Plasma pharmacokinetic characteristics of risperidone and their relationship to saliva concentrations in children with psychiatric or neurodevelopmental disorders. Clin Ther. 2007;29(7):1476-86. [pmid: 17825699].
4 Barzman DH. Intramuscular ziprasidone controls acute agitation. P and T. Dec. 2006;31(12):727.
5 Biederman J, Mick E, Prince J, et al. Systematic chart review of the pharmacologic treatment of comorbid attention deficit hyperactivity disorder in youth with bipolar disorder. J Child Adolesc Psychopharmacol. 1999;9(4):247-56. [pmid: 10630454].
6 Biederman J, McDonnell MA, Wozniak J, et al. Aripiprazole in the treatment of pediatric bipolar disorder: a systematic chart review. CNS Spectr. 2005;10(2):141-8. [pmid: 15685125].
7 Biederman J. Open-label comparative study of risperidone versus olanzapine versus quetiapine for mania in children and adolescents with Bipolar I and Bipolar II Disorder. Control Trials. 2006.
8 Biederman J, Mick E, Spencer T, et al. A prospective open-label treatment trial of ziprasidone monotherapy in children and adolescents with bipolar disorder. Bipolar Disord. 2007;9(8):888-94. [pmid: 18076539].
9 Blader JC. Pharmacotherapy and postdischarge outcomes of child inpatients admitted for aggressive behavior. J Clin Psychopharmacol. 2006;26(4):419-25. [pmid: 16855463].
10 Bruun RD. Subtle and underrecognized side effects of neuroleptic treatment in children with Tourette's disorder. Am J Psychiatry. 1988;145(5):621-4. [pmid: 2895987].
11 Camacho A, Ng B, Galangue B, et al. Use of risperidone long-acting injectable in a rural border community clinic in southern California. Psychiatry. 2008;5(6):43-9. [pmid: 19727284].
12 Campbell M, Adams P, Perry R, et al. Tardive and withdrawal dyskinesia in autistic children: a prospective study. Psychopharmacol Bull. 1988;24(2):251-5. [pmid: 3212157].
13 Cannon TD, Huttunen MO, Dahlstrom M, et al. Antipsychotic drug treatment in the prodromal phase of schizophrenia. Am J Psychiatry. 2002;159(7):1230-2. [pmid: 12091205].
14 Centorrino F, Meyers AL, Ahl J, et al. An observational study of the effectiveness and safety of intramuscular olanzapine in the treatment of acute agitation in patients with bipolar mania or schizophrenia/schizoaffective disorder. Hum Psychopharmacol. 2007;22(7):455-62. [pmid: 17708578].
15 Connor DF, Ozbayrak KR, Kusiak KA, et al. Combined pharmacotherapy in children and adolescents in a residential treatment center. J Am Acad Child Adolesc Psychiatry. 1997;36(2):248-54. [pmid: 9031578].
16 Connor DF, Fletcher KE, Wood JS. Neuroleptic-related dyskinesias in children and adolescents. J Clin Psychiatry. 2001;62(12):967-74. [pmid: 11780878].
17 Cosgrove PVF. Risperidone added to methylphenidate in attention deficit hyperactivity disorder. XXth Collegium Internationale Neuro-psychopharmacologicum. 1996.
18 Crosland KA, Zarcone JR, Lindauer SE, et al. Use of functional analysis methodology in the evaluation of medication effects. J Autism Dev Disord. 2003;(3):271-9. [pmid: 12908830].
19 Delbello MP. Quetiapine promising for patients with mood disorders and a family history of bipolar disorder. P and T. Dec. 2006;31(12):726.
20 El-DeFrawi MH, Hirsch G, Jurkowicz A, et al. Tardive dyskinesia and pregnancy and delivery complications. Child Psychiatry Hum Dev. Mar. 1996;26(3):151-7. [pmid: 8819877].
21 Ernst M, Magee HJ, Gonzalez NM, et al. Pimozide in autistic children. Psychopharmacol Bull. 1992;28(2):187-91. [pmid: 1513923].
22 Esel E, Basturk M, Gonul AS, et al. Effects of olanzapine and haloperidol on serum prolactin levels in male schizophrenic patients. Psychoneuroendocrinology. 2001;26(6):641-7. [pmid: 11403983].
23 Farren CK, Dinan TG. Dyskinesia in mentally handicapped women: Relationship to level of handicap, age, and neuroleptic exposure. Acta Psychiatr Scand. 1994;90(3):210-3. [pmid: 7810345].
24 Feroz-Nainar C, Roy M. Risperidone and late onset tics. Autism. 2006;10(3):302-7. [pmid: 16682400].
25 Findling RL, S E, L. Aripiprazole in children with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2008;(4):347-54. [pmid: 18759644].
26 Gebhardt S, Hartling F, Hanke M, et al. Prevalence of movement disorders in adolescent patients with schizophrenia and in relationship to predominantly atypical antipsychotic treatment. Eur Child Adolesc Psychiatry. 2006;15(7):371-82. [pmid: 16648965].
27 Gebhardt S, Hartling F, Hanke M, et al. Relations between movement disorders and psychopathology under predominantly atypical antipsychotic treatment in adolescent patients with schizophrenia. Eur Child Adolesc Psychiatry. 2008;17(1):44-53. [pmid: 17876506].
28 Gianfrancesco F, Durkin MB, Mahmoud R, et al. Use of healthcare services by patients treated with risperidone versus conventional antipsychotic agents. Pharmacoeconomics. 2002;20(6):413-27. [pmid: 12052100].
29 Goin-Kochel RP, Mackintosh VH, Myers BJ. Parental reports on the efficacy of treatments and therapies for their children with autism spectrum disorders. Res Autism Spectr Disord. 2009;3(2):528-37.
30 Goldberg TE, Burdick KE, McCormack J, et al. Lack of an inverse relationship between duration of untreated psychosis and cognitive function in first episode schizophrenia. Schizophr Res. 2009;107(2-3):262-6. [pmid: 19042105].
31 Green WH, Padron-Gayol M, Hardesty AS, et al. Schizophrenia with childhood onset: a phenomenological study of 38 cases. J Am Acad Child Adolesc Psychiatry. 1992;31(5):968-76. [pmid: 1400132].
32 Gunther T, Herpertz-Dahlmann B, Jolles J, et al. The influence of risperidone on attentional functions in children and adolescents with attention-deficit/hyperactivity disorder and co-morbid disruptive behavior disorder. J Child Adolesc Psychopharmacol. 2006;16(6):725-35. [pmid: 17201616].
33 Hong WW, Rak IW, Ciuryla VT, et al. Medical-claims databases in the design of a health-outcomes comparison of quetiapine ('Seroquel') and usual-care antipsychotic medication. Schizophr Res. 1998;32(1):51-8. [pmid: 9690334].
34 Jerrell JM, Hwang TL, Livingston TS. Neurological adverse events associated with antipsychotic treatment in children and adolescents. J Child Neurol. 2008;23(12):1392-9. [pmid: 18772491].
35 Joshi PT, Capozzoli JA, Coyle JT. Low-dose neuroleptic therapy for children with childhood-onset pervasive developmental disorder. Am J Psychiatry. 1988;145(3):335-8. [pmid: 3344846].
36 Kopala LC, Fredrikson D, Good KP, et al. Symptoms in neuroleptic-naive, first-episode schizophrenia: response to risperidone. Biol Psychiatry. 1996;39(4):296-8. [pmid: 8645777].
37 Kronenberger WG, Giauque AL, Lafata DE, et al. Quetiapine addition in methylphenidate treatment-resistant adolescents with comorbid ADHD, conduct/oppositional-defiant disorder, and aggression: a prospective, open-label study. J Child Adolesc Psychopharmacol. 2007;17(3):334-47. [pmid: 17630867].
38 Kumra S, Briguglio C, Lenane M, et al. Including children and adolescents with schizophrenia in medication-free research. Am J Psychiatry. 1999;156(7):1065-8. [pmid: 10401453].
39 Kutcher S, Papatheodorou G, Reiter S, et al. The successful pharmacological treatment of adolescents and young adults with borderline personality disorder: a preliminary open trial of flupenthixol. J Psychiatry Neurosci. 1995;20(2):113-8. [pmid: 7703220].
40 Lencer R, Sprenger A, Harris MS, et al. Effects of second-generation antipsychotic medication on smooth pursuit performance in antipsychotic-naive schizophrenia. Arch Gen Psychiatry. 2008;65(10):1146-54. [pmid: 18838631].
41 Linszen DH, Dingemans PM, Lenior ME, et al. Early family and individual interventions and relapse in recent-onset schizophrenia and related disorders. Ital J Psychiatr Behav Sci. 1998;8(2):77-84.
42 Mace FC, Blum NJ, Sierp BJ, et al. Differential response of operant self-injury to pharmacologic versus behavioral treatment. J Dev Behav Pediatr. 2001;22(2):85-91. [pmid: 11332784].
43 Marchand WR, Wirth L, Simon C. Quetiapine adjunctive and monotherapy for pediatric bipolar disorder: a retrospective chart review. J Child Adolesc Psychopharmacol. 2004;14(3):405-11. [pmid: 15650496].
44 Margolese HC, Annable L, Dion Y. Depression and dysphoria in adult and adolescent patients with Tourette's disorder treated with risperidone. J Clin Psychiatry. 2002;63(11):1040-4. [pmid: 12444819].
45 Martin A, L'Ecuyer S. Triglyceride, cholesterol and weight changes among risperidone-treated youths: a retrospective study. Eur Child Adolesc Psychiatry. 2002;11(3):129-33. [pmid: 12369772].
46 McAdam DB, Zarcone JR, Hellings J, et al. Effects of risperidone on aberrant behavior in persons with developmental disabilities: social validity measures. Am J Ment Retard. 2002;107(4):261-9. [pmid: 12069645].
47 McConville B, Carrero L, Sweitzer D, et al. Long-term safety, tolerability, and clinical efficacy of quetiapine in adolescents: an open-label extension trial. J Child Adolesc Psychopharmacol. 2003;13(1):75-82. [pmid: 12804128].
48 McDermid SA, Hood J, Bockus S, et al. Adolescents on neuroleptic medication: Is this population at risk for tardive dyskinesia?. Can Psychiatr Assoc J. 1998;43(6):629-31.
49 McDougle CJ, Kem DL, Posey DJ. Case series: use of ziprasidone for maladaptive symptoms in youths with autism. J Am Acad Child Adolesc Psychiatry. 2002;41(8):921-7. [pmid: 12164181].
50 Mick EB. Risperidone for the treatment of ADHD in children with bipolar disorder. 158th Annual Meeting of the American Psychiatric Association. 2005. 2005-26.
51 Niaz OS, Haddad PM. Thirty-five months experience of risperidone long-acting injection in a UK psychiatric service including a mirror-image analysis of in-patient care. Acta Psychiatr Scand. 2007;116(1):36-46. [pmid: 17559599].
52 Parraga HC, Parraga MI. Quetiapine treatment in patients with Tourette syndrome. Can J Psychiatry. 2001;46(2):184-5. [pmid: 11280092].
53 Prescott LM. The 56th annual meeting of the American Academy of Neurology. P and T. 2004 Jul. 29(7):450-3+460.
54 Rossi G, Balottin U, Rossi M, et al. Pharmacological treatment of anorexia nervosa: a retrospective study in preadolescents and adolescents. Clin Pediatr. 2007;46(9):806-11.
55 Schimmelmann BG, Paulus S, Schacht M, et al. Subjective distress related to side effects and subjective well-being in first admitted adolescents with early-onset psychosis treated with atypical antipsychotics. J Child Adolesc Psychopharmacol. 2005;15e(2):249-58. [pmid: 15910209].
56 Shuster J. Enoxapirin-induced thrombocytopenia in a child. Hosp Pharm. Mar. 2004;39(3):204-9.
57 Singh NN, Landrum TJ, Ellis CR, et al. Effects of thioridazine and visual screening on stereotypy and social behavior in individuals with mental retardation. Res Dev Dis Abil. 1993;(3):163-77.
58 Stephens RJ, Bassel C, Sandor P. Olanzapine in the treatment of aggression and tics in children with Tourette's syndrome--a pilot study. J Child Adolesc Psychopharmacol. 2004;14(2):255-66. [pmid: 15319022].
59 Stigler KA, Diener JT, Kohn AE, et al. Aripiprazole in pervasive developmental disorder not otherwise specified and Asperger's disorder: a 14-week, prospective, open-label study. J Child Adolesc Psychopharmacol. 2009;19(3):265-74. [pmid: 19519261].
60 Storch EA, Merlo LJ, Larson MJ, et al. Clinical features associated with treatment-resistant pediatric obsessive-compulsive disorder. Compr Psychiatry. Jan. 2008;49(1):35-42. [pmid: 18063039].
61 Szymanski S, Lieberman J, Pollack S, et al. Gender differences in neuroleptic nonresponsive clozapine-treated schizophrenics. Biol Psychiatry. 1996;39(4):249-54. [pmid: 8645771].
62 Taniguchi T, Sumitani S, Aono M, et al. Effect of antipsychotic replacement with quetiapine on the symptoms and quality of life of schizophrenic patients with extrapyramidal symptoms. Hum Psychopharmacol. 2006;21(7):439-45. [pmid: 17029303].
63 Tarricone I, Serretti A, Gozzi BF, et al. Metabolic side effects of second generation antipsychotic agents in antipsychotic-naive patients: one-month prospective evaluation. Psychiatry Res. 2008;157(1-3):269-71. [pmid: 17961714].
64 Theisen FM, Linden A, Geller F, et al. Prevalence of obesity in adolescent and young adult patients with and without schizophrenia and in relationship to antipsychotic medication. J Psychiatr Res. 2001;35(6):339-45. [pmid: 11684141].
65 Tramontina S, Zeni CP, Pheula GF, et al. Aripiprazole in juvenile bipolar disorder comorbid with attention-deficit/hyperactivity disorder: an open clinical trial. CNS Spectrums. 2007;12(10):758-62. [pmid: 17934380].
66 van BM, van AT, Wouters L, et al. Sexual dysfunction and hormonal changes in first episode psychosis patients on olanzapine or risperidone. Psychoneuroendocrinology. Aug. 2009;34(7):989-95. [pmid: 19264412].
67 Verma S, Liew A, Subramaniam M, et al. Effect of treatment on weight gain and metabolic abnormalities in patients with first-episode psychosis. Aust NZ J Psychiatry. 2009;43(9):812-7.
68 Victor CS, smond James FA, Gifford S, et al. Real-world use of quetiapine in early psychosis: an acute inpatient and community followup effectiveness study. Int J Psychiatry Clin Pract. 2008;12(1):65-73.
69 Vitiello B, Davies M, Arnold LE, et al. Assessment of the integrity of study blindness in a pediatric clinical trial of risperidone. J Clin Psychopharmacol. 2005;25(6):565-9. [pmid: 16282839].
70 Yoshimura R, Ueda N, Nakamura J. Possible relationship between combined plasma concentrations of risperidone plus 9-hydroxyrisperidone and extrapyramidal symptoms. Neuropsychobiology. 2001;44(3):129-33. [pmid: 11586052].

## Excluded – Not intervention of interest (N = 41)

The following studies were excluded because they did not examine an intervention of interest for this review.

1 Akhondzadeh S, Tajdar H, Mohammadi MR, et al. A double-blind placebo controlled trial of piracetam added to risperidone in patients with autistic disorder. Child Psychiatry Hum Dev. 2008;39(3):237-45. [pmid: 17929164].
2 Bello MP, K R. Comparison of divalproex and quetiapine monotherapy for adolescent mania. 158th Annual Meeting of the American Psychiatric Association. 2005. 2005-26.
3 Bello MP, K R. Quetiapine compared with divalproex monotherapy in adolescent mania. Bipolar Disord. 2005;6.
4 Berger GE, Proffitt TM, McConchie M, et al. Ethyl-eicosapentaenoic acid in first-episode psychosis: a randomized, placebo-controlled trial. J Clin Psychiatry. 2007;68(12):1867-75. [pmid: 18162017].
5 Blouin M, Binet M, Bouchard RH, et al. Improvement of metabolic risk profile under second-generation antipsychotics: a pilot intervention study. Can J Psychiatry. 2009;54(4):275-9. [pmid: 19321034].
6 Bowers MBJ, Mazure CM, Nelson JC, et al. Psychotogenic drug use and neuroleptic response. Schizophr Bull. 1990;16(1):81-5. [pmid: 1970670].
7 Caldwell MF, Malterer M, Umstead D, et al. A retrospective evaluation of adjunctive risperidone treatment in severely behaviorally disordered boys receiving psychosocial treatment. Child Adolesc Psychopharmacol. Feb. 2008;18(1):34-43.
8 Carlson GA, Lavelle J, Bromet EJ. Medication treatment in adolescents vs. adults with psychotic mania. J Child Adolesc Psychopharmacol. 1999;9(3):221-31. [pmid: 10521014].
9 Degrauw RS, Li JZ, Gilbert DL. Body mass index changes and chronic neuroleptic drug treatment for Tourette syndrome. Pediatr Neurol. 2009;41(3):183-6. [pmid: 19664533].
10 DelBello MP, DelBello MP, Kowatch RA, Adler CM, et al. A double-blind comparison of divalproex versus quetiapine for adolescent mania. Neuropsychopharmacology. 2004;9.
11 den Boer JA, Westenberg HG. Atypical neuroleptics in acute schizophrenia: a double-blind comparative study of remoxipride and haloperidol. Psychopharmacol Bull. 1990;26(1):99-107. [pmid: 1973547].
12 Fleck DE, Hendricks WL, Delbello MP, et al. Differential prescription of maintenance antipsychotics to African American and White patients with new-onset bipolar disorder. J Clin Psychiatry. 2002;63(8):658-64. [pmid: 12197445].
13 Gaffney GR, Perry PJ, Lund BC, et al. Risperidone versus clonidine in the treatment of children and adolescents with Tourette's syndrome. J Am Acad Child Adolesc Psychiatry. 2002;41(3):330-6. [pmid: 11886028].
14 Hamilton JD. Lithium reduced aggression and was safe in aggressive children and adolescents with conduct disorder admitted to hospital. Evid Based Ment Health. 2001;4(1):17.
15 Harrow M, Jobe TH. Factors involved in outcome and recovery in schizophrenia patients not on antipsychotic medications: a 15-year multifollowup study. J Nerv Ment Dis. 2007;195(5):406-14. [pmid: 17502806].
16 Jangro WC, Preval H, Southard R, et al. Conventional intramuscular sedatives versus ziprasidone for severe agitation in adolescents: case-control study. Child Adolesc Psychiatry Ment Health. 2009. Article Number: 9.
17 Jerrell JM. Pharmacotherapy in the community-based treatment of children with bipolar I disorder. Hum Psychopharmacol. 2008;23(1):53-9. [pmid: 17957821].
18 Jerrell JM, McIntyre RS. Health-care costs of pediatric clients developing adverse events during treatment with antipsychotics. Value Health. 2009;12(5):716-22. [pmid: 19508657].
19 Kutcher S, Williamson P, MacKenzie S, et al. Successful clonazepam treatment of neuroleptic-induced akathisia in older adolescents and young adults: a double-blind, placebo-controlled study. J Clin Psychopharmacol. 1989;9(6):403-6. [pmid: 2574191].
20 Li AY, Cong S, Lu H, et al. Clinical observation on treatment of Tourette syndrome by integrative medicine. Chinese J Integr Med. 2009;15(4):261-5.
21 Linszen D, Dingemans P, Lenior M. Early intervention and a five year followup in young adults with a short duration of untreated psychosis: ethical implications. Schizophr Res. 2001;51(1):55-61. [pmid: 11479066].
22 Lloyd A, Koran W, Borgaro SR, et al. Predictors of medication compliance after hospital discharge in adolescent psychiatric patients. J Child Adolesc Psychopharmacol. 1998;8(2):133-41. [pmid: 9730079].
23 McConville BJ, Sanberg PR, Fogelson MH, et al. The effects of nicotine plus haloperidol compared to nicotine only and placebo nicotine only in reducing tic severity and frequency in Tourette's disorder. Biol Psychiatry. 1992;31(8):832-40. [pmid: 1643197].
24 McGorry PD, Yung AR, Phillips LJ, et al. Randomized controlled trial of interventions designed to reduce the risk of progression to first-episode psychosis in a clinical sample with subthreshold symptoms. Arch Gen Psychiatry. 2002;59(10):921-8. [pmid: 12365879].
25 Miklowitz DJ, Axelson DA, Birmaher B, et al. Family-focused treatment for adolescents with bipolar disorder: results of a 2-year randomized trial. Arch Gen Psychiatry. 2008;65(9):1053-61. [pmid: 18762591].
26 Paillere-Martinot ML, Lecrubier Y, Martinot JL, et al. Improvement of some schizophrenic deficit symptoms with low doses of amisulpride. Am J Psychiatry. Jan. 1995;152(1):130-3. [pmid: 7802104].
27 Penzner JB, Dudas M, Saito E, et al. Lack of effect of stimulant combination with second-generation antipsychotics on weight gain, metabolic changes, prolactin levels, and sedation in youth with clinically relevant aggression or oppositionality. J Child Adolesc Psychopharmacol. 2009;19(5):563-73. [pmid: 19877981].
28 Pogge DL, Young K, Insalaco B, et al. Use of atypical antipsychotic medications in adolescent psychiatric inpatients: a comparison with inpatients who did not receive antipsychotic medications during their stay. Int J Clin Pract. Jun. 2007;61(6):896-902. [pmid: 17504351].
29 Pushkov VV. Treatment of Tourette's syndrome. Sov Neurol Psychiatr. 1988;21(3):72-9.
30 Remington G, Sloman L, Konstantareas M, et al. Clomipramine versus haloperidol in the treatment of autistic disorder: a double-blind, placebo-controlled, crossover study. J Clin Psychopharmacol. 2001;21(4):440-4. [pmid: 11476129].
31 Richardson MA, Haugland G. Typicality and atypicality in the development of neuroleptic side effects in child and adolescent psychiatric patients. 1996:43-66.
32 Sanchez LE, Adams PB, Uysal S, et al. A comparison of live and videotape ratings: clomipramine and haloperidol in autism. Psychopharmacol Bull. 1995;31(2):371-8. [pmid: 7491394].
33 Shiloh R, Hermesh H, Weizer N, et al. Acute antipsychotic drug administration lowers body temperature in drug-free male schizophrenic patients. Eur Neuropsychopharmacol. 2000;10(6):443-5. [pmid: 11115733].
34 Sloman L. Haloperidol versus clomipramine in autistic disorder. 151st Annual Meeting of the American Psychiatric Association. 1998 Jun.
35 Starkova L, Mrna B. Treatment of some cases in child psychiatry with incisive neuroleptic drugs. Acta Univ Palacki Olomuc Fac Med. 1989;123:287-91. [pmid: 2576177].
36 Wade D, Harrigan S, Harris MG, et al. Treatment for the initial acute phase of first-episode psychosis in a real-world setting. Psychiatr Bull. Apr. 2006;30(4):127-31.
37 Walker EF, Cornblatt BA, Addington J, et al. The relation of antipsychotic and antidepressant medication with baseline symptoms and symptom progression: a naturalistic study of the North American Prodrome Longitudinal Sample. Schizophr Res. Nov. 2009;115(1):50-7. [pmid: 19709859].
38 Weiss M, Panagiotopoulos C, Giles L, et al. A naturalistic study of predictors and risks of atypical antipsychotic use in an attention-deficit/hyperactivity disorder clinic. J Child Adolesc Psychopharmacol. Oct. 2009;19(5):575-82. [pmid: 19877982].
39 Weng S, Tang J, Wang G, et al. Comparison of the addition of Siberian Ginseng (Acanthopanax senticosus) versus fluoxetine to lithium for the treatment of bipolar disorder in adolescents: a randomized, double-blind trial. Curr Ther Res Clin Exp. Jul. 2007;68(4):280-90.
40 Xie XL, Wu DH, Peng X, et al. Effects of metoclopramide on the symptoms as well as intelligence and memory in Tourette syndrome. Chin J Clin Rehab. Oct. 2005;9(40):155-7.
41 Zhang LD, Xu SH, Tang YH, et al. A comparative study of the treatment of schizophrenia with electric acupuncture, herbal decoction and Chlorpromazine. Am J Acupunct. 1990;18(1):11-4.

## Excluded – No outcome of interest (N = 19)

The following studies were excluded because they did not report any outcome of interest for this review.

1 Aichhorn W, Marksteiner J, Walch T, et al. Age and gender effects on olanzapine and risperidone plasma concentrations in children and adolescents. J Child Adolesc Psychopharmacol. 2007;17(5):665-74. [pmid: 17979586].
2 Alfaro CL, Wudarsky M, Nicolson R, et al. Correlation of antipsychotic and prolactin concentrations in children and adolescents acutely treated with haloperidol, clozapine, or olanzapine. J Child Adolesc Psychopharmacol. 2002;12(2):83-91. [pmid: 12188977].
3 Delbello M. CHQ and CGAS in an open-label study of ziprasidone in pediatric patients with bipolar disorder, schizophrenia, or schizoaffective disorder. 46th Annual NCDEU (New Clinical Drug Evaluation Unit) Meeting. 2006. 2006-15.
4 Deutsch SI, Milstoc M, Platovsky G, et al. Cholinesterase activities in blood in infantile autism. Biol Psychiatry. 1987;22(2):234-6. [pmid: 3814674].
5 Ernst M, Devi L, Silva RR, et al. Plasma beta-endorphin levels, naltrexone, and haloperidol in autistic children. Psychopharmacol Bull. 1993;29(2):221-7. [pmid: 8290669].
6 Fombonne E. Risperidone improves restricted, repetitive, and stereotyped behavior in autistic children and adolescents. Evid Based Ment Health. 2006;9(1):6. [pmid: 16436546].
7 Gearing RE, Charach A. Medication adherence for children and adolescents with first-episode psychosis following hospitalization. Eur Child Adolesc Psychiatry. 2009;18(10):587-95. [pmid: 19381709].
8 Levy F. Does haloperidol block methylphenidate? Motivation or attention?. Psychopharmacology. 1996;(1):70-4. [pmid: 8853219].
9 Litman RE, Hommer DW, Clem T, et al. Smooth pursuit eye movements in schizophrenia: effects of neuroleptic treatment and caffeine. Psychopharmacol Bull. 1989;25(3):473-8. [pmid: 2576322].
10 Mattai A, Chavez A, Greenstein D, et al. Effects of clozapine and olanzapine on cortical thickness in childhood-onset schizophrenia. Schizophr Res. Jan. 2010;116(1):44-8. [pmid: 19913390].
11 Meyerowitz W, Jaramillo JD, Denson D, et al. Optimum therapeutic dosing with haloperidol decanoate. Curr Ther Res. 1989;46(6):1174-8.
12 Minderaa RB, Anderson GM, Volkmar FR, et al. Neurochemical study of dopamine functioning in autistic and normal subjects. J Am Acad Child Adolesc Psychiatry. 1989;28(2):190-4. [pmid: 2925571].
13 Nieman DH, Bour LJ, Linszen DH, et al. Neuropsychological and clinical correlates of antisaccade task performance in schizophrenia. Neurology. 2000;54(4):866-71. [pmid: 10690978].
14 Phillips LJ, Nelson B, Yuen HP, et al. Randomized controlled trial of interventions for young people at ultra-high risk of psychosis: study design and baseline characteristics. Aust NZ J Psychiatry. 2009;43(9):818-29.
15 Piscitelli SC, Frazier JA, McKenna K, et al. Plasma clozapine and haloperidol concentrations in adolescents with childhood-onset schizophrenia: association with response. J Clin Psychiatry. 1994;55(Suppl B):94-7. [pmid: 7961584].
16 Scahill L, Aman MG, McDougle CJ, et al. Trial design challenges when combining medication and parent training in children with pervasive developmental disorders. J Autism Dev Disord. 2009;39(5):720-9. [pmid: 19096921].
17 Spettigue W, Buchholz A, Henderson K, et al. Evaluation of the efficacy and safety of olanzapine as an adjunctive treatment for anorexia nervosa in adolescent females: a randomized, double-blind, placebo-controlled trial. BMC Pediatr. 2008;8:4. [pmid: 18234120].
18 Staller J. The effect of long-term antipsychotic treatment on prolactin. J Child Adolesc Psychopharmacol. Jun. 2006;16(3):317-26. [pmid: 16768639].
19 Stevens JR, Kymissis PI, Baker AJL. Elevated prolactin levels in male youths treated with risperidone and quetiapine. J Child Adolesc Psychopharmacol. Dec. 2005;15(6):893-900. [pmid: 16379509].

## Excluded – Not diagnosis of interest (N = 18)

The following studies were excluded because the participants did not have the condition (diagnosis) of interest for this review.

1 Backman ML, Aberg LE, Aronen ET, et al. New antidepressive and antipsychotic drugs in juvenile neuronal ceroid lipofuscinoses: a pilot study. Eur J Paediatr Neurol. 2001;5(Suppl. A):163-6. [pmid: 11588990].
2 Bloch M, Stager S, Braun A, et al. Pimozide-induced depression in men who stutter. J Clin Psychiatry. 1997;58(10):433-6. [pmid: 9375593].
3 Flanders SC, Findling RL, Youngstrom EA, et al. Observed clinical and health services outcomes in pediatric inpatients treated with atypical antipsychotics: 1999-2003. J Child Adolesc Psychopharmacol. Jun. 2007;17(3):312-27. [pmid: 17630865].
4 Hammerman A, Dreiher J, Klang SH, et al. Antipsychotics and diabetes: an age-related association. Ann Pharmacother. Sep. 2008;42(9):1316-22. [pmid: 18664607].
5 Harrison-Woolrych M, Garcia-Quiroga J, Ashton J, et al. Safety and usage of atypical antipsychotic medicines in children: a nationwide prospective cohort study. Drug Saf. 2007;30(7):569-79. [pmid: 17604408].
6 Hellings JA, A L. Weight gain in a controlled study of risperidone in children, adolescents and adults with mental retardation. J Child Adolesc Psychopharmacol. 2000;(4):255-6.
7 Huang Y, Yang L, Wang S, et al. Alterative application of five anticonvulsants according to the half life for the treatment of status epilepticus in children with severe viral encephalitis. Neural Regeneration Research. Sep. 2007;2(9):561-4.
8 Jerrell JM, McIntyre RS. Adverse events in children and adolescents treated with antipsychotic medications. Hum Psychopharmacol. June. 2008;23(4):283-90. [pmid: 18302312].
9 Kalkan US, Ozbaran B, Demiral N, et al. Clinical overview of children with mucopolysaccharidosis type III A and effect of Risperidone treatment on children and their mothers psychological status. Brain Dev. Feb. 2010;32(2):156-61. [pmid: 19217229].
10 Kapetanovic S, Aaron L, Montepiedra G, et al. The use of second-generation antipsychotics and the changes in physical growth in children and adolescents with perinatally acquired HIV. AIDS Patient Care STDS. 2009;23(11):939-47. [pmid: 19827949].
11 Kelly DL, Conley RR, Love RC, et al. Weight gain in adolescents treated with risperidone and conventional antipsychotics over six months. J Child Adolesc Psychopharmacol. 1998;8(3):151-9. [pmid: 9853689].
12 Khan RA, Mican LM, Suehs BT. Effects of olanzapine and risperidone on metabolic factors in children and adolescents: a retrospective evaluation. J Psychiatr Pract. 2009;15(4):320-8. [pmid: 19625888].
13 Newell BD, Moinfar M, Mancini AJ, et al. Retrospective analysis of 32 pediatric patients with anticonvulsant hypersensitivity syndrome (ACHSS). Pediatr Dermatol. 2009;26(5):536-46. [pmid: 19840307].
14 Panagiotopoulos C, Ronsley R, Davidson J. Increased prevalence of obesity and glucose intolerance in youth treated with second-generation antipsychotic medications. Can J Psychiatry. Nov. 2009;54(11):743-9. [pmid: 19961662].
15 Pelletier G, Lacroix Y, Moghrabi A, et al. Double-blind crossover study of chlorpromazine and lorazepam in the treatment of behavioral problems during treatment of children with acute lymphoblastic leukaemia receiving glucocorticoids. Med Pediatr Oncol. Apr. 2000;34(4):276-7. [pmid: 10742070].
16 Singer MB. Variables related to compliance with neuroleptic medication in adolescent psychiatric patients after discharge from a psychiatric hospitalization. 2003.
17 Soloff PH, Cornelius J, George A, et al. Efficacy of phenelzine and haloperidol in borderline personality disorder. Arch Gen Psychiatry. 1993;50(5):377-85. [pmid: 8489326].
18 Zesiewicz MF, Natta MB, Kupst MJ. Effects of psychiatric hospitalization and psychotropic medications on weight in children. J Am Acad Child Adolesc Psychiatry. 1987;26(6):854-7. [pmid: 3429404].

## Excluded – Duplicates (N = 9)

The following articles were excluded because they were duplicates.

1 Chiu CC, Chen KP, Liu HC, et al. The early effect of olanzapine and risperidone on insulin secretion in atypical-naive schizophrenic patients. J Clin Psychopharmacol. 2006;26(5):504-7. [pmid: 16974193].
2 Quetiapine equal to placebo for teen bipolar depression. Brown Univ Child Adolesc Psychopharmacol Update. 2009;11(9):4-5.
3 DelBello MP, Schwiers ML, Rosenberg HL, et al. A double, randomized, placebo-controlled study of quetiapine adjunctive treatment for adolescent mania. J Am Acad Child Adolesc Psychiatry. 2002;41(10):1216-23. [pmid: 12364843].
4 Dougle CJ, S L. Risperidone for the core symptom domains of autism: results from the study by the autism network of the research units on pediatric psychopharmacology. Am J Psychiatry. 2005;(6):1142-8. [pmid: 15930063].
5 Gilbert DL, Batterson JR, Sethuraman G, et al. Tic reduction with risperidone Versus pimozide in a randomized, double-blind, crossover trial. J Am Acad Child Adolesc Psychiatry. 2004;43(2):206-14. [pmid: 14726728].
6 Lavalaye J, Linszen DH, Booij J, et al. Dopamine D2 receptor occupancy by olanzapine or risperidone in young patients with schizophrenia. Psychiatry Res. 1999;92(1):33-44. [pmid: 10688158].
7 Malone RP. Discontinuing risperidone results in relapse in children with autism spectrum disorders. Evid Based Ment Health. 2006;9(2):56. [pmid: 16638905].
8 Mauri MC, Laini V, Steinhilber CPC, et al. Depressive, negative and positive symptoms in schizophrenia: response to different dosages of haloperidol. New Trends Exp Clin Psychiatr. 1998;14(1):59-63.
9 Pflug B, Bartels M, Bauer H, et al. A double-blind multicentre study comparing remoxipride, controlled release formulation, with haloperidol in schizophrenia. Acta Psychiatr Scand Suppl. 1990;358:142-6. [pmid: 1978475].

## Excluded – Non-English (N = 7)

The following studies were excluded because they were published in a language other than English.

1 A study of risperidone in the treatment of child schizophrenia. J Clin Psychol Med. 2003;(2):80-1.
2 Comparison study of childhood schizophrenia treated with risperidone and chlorpromazine. Guizhou Med J. 2004;(8):697-8.
3 Gao C. A comparative study of risperidone and perphenazine in the treatment of child schizophrenia. Chin J Health Psychol. 2007;(10):950-1.
4 Huo WH. A controlled study of risperidone in child schizophrenia. Medical Journal of Chinese People's Health. 2007;(11):472-3.
5 Ji WD. [Olanzapine for treatment of Tourette syndrome: a double-blind randomized controlled trial]. Zhongguo Linchuang Kangfu. 2005;(4):66-8.
6 Muller-Vahl KR. The benzamides tiapride, sulpiride, and amisulpride in treatment for Tourette's syndrome. Der Nervenarzt. 2007;78(3):264-71. (Ger). [pmid: 16924461].
7 Zhang Y. A control study of aripiprazole in the treatment of childhood schizophrenia. J Clin Psychosom Dis. 2007;(2):122-4.

## Excluded – Published before 1987 (N = 3)

The following studies were excluded because they were published before 1987.

1 Anderson LT, Campbell M, Adams P, et al. The effects of haloperidol on discrimination learning and behavioral symptoms in autistic children. J Autism Dev Disord. 1989;19(2):227-39. [pmid: 2663834].
2 Greenhill LL, Halperin JM, Barmack J. Cognitive effects of neuroleptic treatment in children with conduct disorder. 1996:85-119.
3 Klein RG. Thioridazine effects on the cognitive performance of children with attention-deficit hyperactivity disorder. J Child Adolesc Psychopharmacol. 1990;1(4):263-70.

1 The primary study was published in 1984.

2 Data of this study was collected in 1976.

3 The primary study was published in 1985.

## Unobtained Studies (N = 38)

The following articles could not be obtained through the university interlibrary loan system.

1 Assessment of therapeutic efficacy versus sedation with antipsychotic agents. J Clin Psychiatry. 1996;57(6):1-12.
2 Allan ER, Sison CE, Alpert M, et al. The relationship between negative symptoms of schizophrenia and extrapyramidal side effects with haloperidol and olanzapine. Psychopharmacol Bull. 1998;34(1):71-4. [pmid: 9564201].
3 Barzega G, Bogetto F, Maina G, et al. Quetiapine in schizophrenic patients: a high- and low-dose double-blind comparison. Eur J Psychiatr. 2000;14(4):221-32.
4 Bello MP, V M, I. Ziprasidone dosing study in pediatric patients with bipolar disorder, schizophrenia or schizoaffective disorder. Proceedings of the 13th Biennial Winter Workshop on Schizophrenia Research. 2006. 2006-10.
5 Bianco G, Claps M, Marinucci S, et al. Use of risperidone in adolescent anorexia nervosa. Ital J Psychiatr Behav Sci. 2000;10(2):50-2.
6 Biederman J. The treatment of psychotic symptoms in children and adolescents with bipolar disorder. 158th Annual Meeting of the American Psychiatric Association. 2005. 2005-26.
7 Ceskova E, Svestka J, Buresova A, et al. Zuclopenthixol acetate in the treatment of acute psychoses. Homeost Health Dis. 1994;35(6):297-8.
8 Chappell PB, F S. Ziprasidone in Tourette's syndrome. [abstract]. 151st Annual Meeting of the American Psychiatric Association. 1998. Jun.
9 Delbello M. Ziprasidone in the treatment of children and adolescents with bipolar mania or schizophrenia: an open label, dose ranging safety and tolerability study. 45th Annual NCDEU (New Clinical Drug Evaluation Unit) Meeting. 2005. 2005-9.
10 Delbello M. A double-blind, randomized, placebo-controlled study of quetiapine for the treatment of depression in adolescents with bipolar disorder. Control Trials. 2006.
11 Delbello M. An open-label study of ziprasidone in pediatric patients with bipolar disorder: safety, tolerability, efficacy, and functional outcomes. Bipolar Disord. 2008.
12 Eli L. Olanzapine versus placebo in the treatment of mania in adolescents with Bipolar I Disorder. Control Trials. 2006.
13 Hamer AM. Update on children and adolescents with bipolar disorder. Psychiatr Times. 2004;21(5):1-5.
14 Jakovljevic M, Dossenbach MR, Friedel P, et al. Olanzapine versus fluphenazine in the acute (6-week) treatment of schizophrenia. Psychiatr Danub. 1999;11(1-2):3-11.
15 Jing Y. Health outcomes assessment for children and adolescents with bipolar disorder treated with and without atypical antipsychotics. [dissertation]. United States, Ohio. University of Cincinnati. 2009.
16 Kaleda VG, Oleichik IV, Artioukh VV, et al. Risperidone vs haloperidol in the therapy of adolescent schizophrenia and schizoaffective disorders: an open comparative medium-term efficacy and tolerability study. Int J Neuropsychopharmacol. Abstracts of the XXIInd CINP Congress. Brussels, Belgium. July 9-13, 2000. (Suppl 1):S99.
17 Klebovich A. Utilization of olanzapine and risperidone in Hungary with special concern to the treatment of schizophrenia in the psychiatric rehabilitation. 2009.
18 Kumra S, Frazier JA, Jacobsen LK, et al. Childhood-onset schizophrenia: a double-blind clozapine-haloperidol comparison. 1998:365-378.
19 Aman MG, Findling R. Risperidone versus placebo for conduct disorder in mentally retarded children. Pharmacotherapy: Annual Meeting of the American College of Clinical Pharmacy. Kansas, Missouri, USA. 24-27, 1999. (10):1214.
20 Marder SR. Risperidone: clinical development: North American results. Clin Neuropharmacol. 1992;15(Suppl 93A).
21 Martinez R. A double-blind study of risperidone versus placebo in conduct disorder in mentally retarded children conference abstract. Schizophrenia Research: abstracts of The VIIth International Congress on Schizophrenia Research. Santa Fe New Mexico USA. 1999;17-21. (288):1999.
22 Pavuluri M. Controlled trial of risperidone and divalproex sodium with MRI assessment of affected circuitry in pre and post treatment in pediatric bipolar. Control Trials. 2006.
23 Peuskens J, Trivedi J, Malyarov S, et al. Prevention of schizophrenia relapse with extended release quetiapine fumarate dosed once daily: a randomized, placebo-controlled trial in clinically stable patients. Psychiatry. 2007;4(11):34-50. [pmid: 20428302].
24 Qureshi NA, Al-Beyari TH, Al-Amri AH, et al. Neuroleptic malignant syndrome: a report of nine suspected cases. Saudi Pharmaceutical Journal. 1996;4(3-4):179-89.
25 Rapoport J. The spectrum of extrapyramidal symptoms in children and young adults conference abstract. 150th Annual Meeting of the American Psychiatric Association 1111. San:Diego-22.
26 Reich DB, W S, H. Risperidone treatment of PTSD related to childhood abuse. 157th Annual Meeting of the American Psychiatric Association. 2004. 2004-6.
27 Sallee FR, N L. Double-blind, controlled comparison of haloperidol and pimozide in children with gilles de la Tourette's Syndrome. 149th Annual Meeting of the American Psychiatric Association. 1996. 1996-9.
28 Sherritze S. Society for Neuroscience. 35th Annual Meeting. P and T. 2006. Jan. 31(1):52-6.
29 Sikich L. A double blind comparison of typical versus atypical antipsychotic agents on selected neurocognitive functions in children and adolescents with psychotic disorders [abstract]. Schizophr Res. 2001;(1-2 Suppl):245.
30 Song DH. Aripiprazole valuable in pediatric tic disorder or Tourette syndrome. P and T. Dec. 2006;31(12):727-8.
31 Tohen M. Olanzapine in the treatment of acute mania in adolescents with bipolar I disorder: a 3-week randomized double-blind placebo-controlled study. Bipolar Disord.
32 Tohen M. Efficacy of olanzapine for the treatment of acute mania in subtypes of adolescent patients: a 3-week randomized double-blind placebocontrolled study. Bipolar Disord.
33 Trabert W. 100 years of delusional parasitosis: meta-analysis of 1,223 case reports. Psychopathology. 1995;28(5):238-46. [pmid: 8559947].
34 Turgay A. A new generation antipsychotic risperidone versus placebo for severe conduct disorder in children with mental retardation. [abstract]. Schizophr Res. 2001;(1-2 Suppl):248-9.
35 Versavel M. Ziprasidone Dosing Study in Pediatric Patients with Bipolar Disorder, Schizophrenia, or Schizoaffective Disorder. Neuropsychopharmacology. 2005;3.
36 Wick JY. Use of psychoactive medications in children and adolescents. Am Pharm. 1993;33(1):51-8. [pmid: 8430620].
37 Yang W. A ramdomized controlled clinical study of aripiprazole in the treatment of childhood schizophrenia. Human Medical Journal. 2007;(6):942-4.
38 Zhang JQ, Q S. Risperidone or chlopiomazine combined with lithium in treatment of adolescence mania with psychotic symptoms. Schuan Mental Health. 2003;(2):79.