# Methodological Quality of Studies Included in the Review

Table C1 Methodological quality of randomized controlled trials (RCTs) and nonrandomized controlled (NRCTs)

Author, Year Study Design | Sequence Generation | Allocation Concealment | Blinding (Subjective) | Blinding (Objective) | Incomplete Outcome (Subjective) | Incomplete Outcome (Objective) | Selective Outcome Reporting | Other Sources of Bias | Overall (Subjective) | Overall (Objective)
Aman et al., 2009 RCT | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | No | High | High
Aman et al., 2002 RCT | Yes | Unclear | Yes | Yes | No | No | Yes | No | High | High
Arango et al., 2009 RCT | Unclear | Unclear | Unclear | Yes | No | No | Yes | No | High | High
Armenteros et al., 2007 RCT | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | No | High | High
Berger et al., 2008 RCT | Yes | Yes | Yes | Yes | No | Unclear | Yes | No | High | High
Biederman et al., 2005 RCT | Unclear | Unclear | No | No | No | No | Unclear | No | High | High
Bierderman et al., 2004 RCT | Unclear | Unclear | No | No | Unclear | Unclear | Unclear | Unclear | High | High
Bruggeman et al., 2001 RCT | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | No | High | High
Buitelaar et al., 2001 RCT | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | No | High | High
Connor et al., 2008 RCT | Unclear | Yes | Yes | Yes | Unclear | Unclear | Yes | No | High | High
Crocq et al., 2007 NRCT | No | No | NA | Yes | NA | Unclear | Yes | Unclear | NA | High
de Haan et al., 2003 RCT | Yes | Unclear | Unclear | NA | No | NA | Yes | Yes | High | NA
DelBello et al., 2009 RCT | Yes | Yes | Unclear | Yes | Unclear | Unclear | Yes | No | High | High
DelBello et al., 2008 RCT | Unclear | Unclear | No | Unclear | No | No | Yes | No | High | High
DelBello et al., 2002 RCT | Yes | Yes | Unclear | Unclear | Yes | Yes | Yes | No | High | High
Findling et al., 2009 RCT | Unclear | Unclear | Yes | Yes | No | No | Yes | No | High | High
Findling et al., 2008 RCT | Yes | Unclear | Unclear | Unclear | Yes | Yes | Unclear | Yes | High | High
Findling et al., 2000 RCT | Yes | Yes | Yes | Yes | No | No | Yes | No | High | High
Gilbert et al., 2004 RCT | Yes | Yes | Yes | Yes | No | No | No | No | High | High
Haas et al., 2009 RCT | Unclear | Unclear | Unclear | Yes | No | No | Yes | No | High | High
Haas et al., 2009 RCT | Yes | Unclear | Unclear | Yes | Unclear | Unclear | Yes | No | High | High
Haas et al., 2009 RCT | Yes | Unclear | Yes | Yes | Unclear | Unclear | Yes | No | High | High
Hellings et al., 2006 RCT | Unclear | Yes | Unclear | Yes | No | No | Yes | No | High | High
Hollander et al., 2006 RCT | Unclear | Unclear | Yes | Yes | Yes | Yes | Yes | No | High | High
Jensen et al., 2008 RCT | Yes | Unclear | No | Unclear | Unclear | Unclear | Yes | No | High | High
Kryzhanovskaya et al., 2009 RCT | Unclear | Unclear | Unclear | Unclear | No | No | Yes | No | High | High
Kumra et al., 2008 RCT | Yes | Yes | Unclear | Yes | No | No | Yes | Yes | High | High
Kumra et al., 1996 RCT | Yes | Yes | Yes | Yes | No | No | Yes | Unclear | High | High
Luby et al., 2006 RCT | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | High | High
Malone et al., 2001 RCT | Yes | Unclear | No | Yes | Yes | Yes | Yes | No | High | High
Marcus et al., 2009 RCT | Yes | Yes | Unclear | Unclear | No | No | Yes | No | High | High
McCracken et al., 2002 RCT | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear | Unclear
Miral et al., 2008 RCT | Unclear | Unclear | Unclear | Yes | Yes | Yes | Yes | No | High | High
Mozes et al., 2006 RCT | Unclear | Unclear | No | No | No | No | Yes | Unclear | High | High
Nagaraj et al., 2006 RCT | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear | Unclear
NCT00796081, 2007 RCT | Unclear | Unclear | No | No | Yes | Yes | No | No | High | High
NCT00090311, 2008 RCT | Yes | Unclear | Yes | Yes | Unclear | Unclear | Yes | No | High | High
NCT00576732, 2010 RCT | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | No | High | High
NCT00090324, 2008 RCT | Unclear | Unclear | Unclear | Unclear | Yes | Yes | Yes | No | High | High
NCT00257166, 2008 RCT | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | No | High | High
NCT00257192, 2010 RCT | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | No | High | High
Perry et al., 1989 RCT | Unclear | Unclear | Yes | Yes | No | No | No | Unclear | High | High
Reyes et al., 2006 RCT | Unclear | Unclear | Yes | Yes | No | No | Yes | No | High | High
Robb et al., 2009 RCT | Unclear | Unclear | Yes | Yes | Yes | Yes | Yes | No | High | High
Sallee et al., 2000 RCT | Unclear | Unclear | Unclear | Unclear | Yes | Yes | Yes | No | High | High
Sallee et al., 1997 RCT | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear | Unclear | Unclear
Sallee et al., 1994 RCT | Unclear | Unclear | Unclear | Unclear | No | No | No | Yes | High | High
Scahill et al., 2003 RCT | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | No | High | High
Schulz et al., 1996 NRCT | No | No | NA | No | NA | Yes | Yes | Unclear | NA | High
Sehgal et al., 1999 RCT | Unclear | Yes | Yes | NA | Yes | NA | Yes | Yes | High | NA
Shaw et al., 2006 RCT | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear | Unclear
Shea et al., 2004 RCT | Unclear | Unclear | Unclear | Unclear | Yes | Yes | Unclear | No | High | High
Sikich et al., 2008 RCT | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Yes | Unclear | Unclear
Sikich et al., 2004 RCT | Yes | Unclear | Unclear | Unclear | No | No | Yes | No | High | High
Spencer et al., 1994 RCT | Unclear | Unclear | Yes | Yes | Yes | Yes | Unclear | Unclear | Unclear | Unclear
Swadi et al., 2010 RCT | Yes | Unclear | Unclear | Yes | No | No | Yes | No | High | High
Synder et al., 2002 RCT | Yes | Yes | Unclear | Yes | No | No | Yes | No | High | High
Tohen et al., 2007 RCT | Unclear | Unclear | Unclear | Unclear | Yes | Yes | Yes | No | High | High
Tramontina et al., 2009 RCT | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | High | High
Troost et al., 2005 RCT | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | High | High
Van Bellinghen et al., 2001 RCT | Unclear | Unclear | Unclear | Yes | Yes | Yes | Yes | No | High | High
Van Bruggen et al., 2003 RCT | Unclear | Unclear | No | Yes | Yes | Yes | No | No | High | High
Woods et al., 2003 RCT | Yes | Yes | Unclear | Unclear | No | No | Unclear | No | High | High
Yen et al., 2004 RCT | Unclear | Unclear | Unclear | Unclear | No | No | Yes | Yes | High | High

NRCT = nonrandomized controlled trial; RCT = randomized controlled trial

Table C2 Methodological quality of cohort studies

Author, Year Study Design | Selection 1 | Selection 2 | Selection 3 | Comparability | Outcome 1 | Outcome 2 | Outcome 3 | Total Stars
Alacqua et al., 2008 RCS | B | A | A | C | B | A | A | 6
Bastiaens et al., 2009 RCS | B | A | A | A and B | E | A | C | 6
Correll et al., 2009 PCS | A | A | A | A and B | B | A | A | 8
Findling et al., 2008 PCS | B | A | A | C | C | B | B | 4
Fleischhaker et al., 2006 PCS | D | C | B | C | E | A | A | 2
Fraguas et al., 2008 PCS | A | A | A | A and B | D | A | C | 6
Friedlander et al., 2001 RCS | C | A | A | C | E | A | A | 4
Gothelf et al., 2002 PCS | C | C | A | C | B | A | D | 3
Hrdlicka et al., 2009 RCS | A | A | A | C | B | A | C | 5
Jefferson et al., 1998 RCS | C | A | A | C | B | A | D | 4
Khan et al., 2006 RCS | D | C | A | C | B | A | A | 4
Kumra et al., 1998 PCS | B | A | B | C | E | A | A | 5
Migliardi et al., 2009 RCS | B | A | A | B | B | A | A | 7
Novaes et al., 2008 RCS | A | A | A | C | B | A | A | 6
Ratzoni et al., 2002 PCS | D | C | B | C | E | A | A | 3
Saito et al., 2004 PCS | B | A | A | B | D | A | A | 6
Wudarsky et al., 1999 PCS | A | A | A | A | A | A | A | 7

PCS = prospective cohort study; RCS = retrospective cohort study