# Review Forms

B1 Eligibility Criteria

B2 Methodological Quality Assessment

B3 Data Extraction