# Literature Search Strings

Table A1 MEDLINE–Ovid Version

OvidSP_MEDLINE 1950 to February Week 1 2011 | Searched: 22Apr10 and 01Feb11 Results: 3957
1. exp Child Development Disorders, Pervasive/; 2. Child behavior disorders/; 3. (child adj1 development adj1 disorder*).tw.; 4. Asperger Syndrome/; 5. (asperger* adj1 (syndrome or disorder)).tw.; 6. Autistic Disorder/; 7. (autism* or (autistic adj1 disorder*) or kanner* syndrome).tw.; 8. Rett Syndrome/; 9. (((rett or retts) adj1 (sydrome or disorder)) or cerebroatrophic hyperammonemia*).tw.; 10. Schizophrenia, Childhood/; 11. (child* adj2 schizophrenia*).tw.; 12. aggression/; 13. aggression.tw.; 14. psychomotor agitation/; 15. ((psychomotor adj1 (agitation or restlessness or hyperactivity or excitement)) or akathisia).tw.; 16. “sleep initiation and maintenance disorders”/; 17. ((sleep adj2 disorder*) or insomnia*).tw.; 18. mood disorders/; 19. ((mood or affective) adj1 disorder*).tw.; 20. impulsive behavior/; 21. (impulsive adj1 behavio?r).tw.; 22. borderline personality disorder/; 23. (borderline adj1 personality adj1 disorder*).tw.; 24. personality disorders/; 25. (affective adj2 dysregulation).tw.; 26. (($behavioral adj2 dyscontrol) or (impulsive-behavioral adj2 deregulation)).tw.; 27. (mood adj2 lability).tw.; 28. (irritable or irritability).tw.; 29. Self-Injurious Behavior/; 30. (self-injurious behavio?r or self-mutilating behavio?r or self mutilation or self-desctructive behavio?r or deliberate self-harm or parasuicide).tw.; 31. antisocial personality disorder/; 32. “Attention Deficit and Disruptive Behavior Disorders”/; 33. Attention Deficit Disorder with Hyperactivity/; 34. ((attention adj deficit adj disorder) or hyperkinetic syndrome or adhd).tw.; 35. Conduct Disorder/; 36. (conduct adj disorder*).tw.; 37. Childhood Disintegrative Disorder.tw.; 38. “Pervasive Developmental Disorder Not Otherwise Specified”.tw.; 39. (atypical adj1 autism).tw.; 40. Oppositional Defiant Disorder.tw.; 41. “Disruptive Behavior Disorder Not Otherwise Specified”.tw.; 42. Schizophrenia/; 43. Schizophrenia, Catatonic/; 44. Schizophrenia, Disorganized/; 45. Schizophrenia, Paranoid/; 46. ((catatonic or disorganized or paranoid) adj schizophrenia).tw.; 47. Psychotic Disorders/; 48. ((Psychotic or schizoaffective or schizophreniform) adj disorder).tw.; 49. (brief reactive psychos?s or psychoses).tw.; 50. first episode schizophrenia.tw.; 51. (prodrom$ and schizophren$).tw.; 52. Schizotypal Personality Disorder/; 53. (schizotypal personality disorder or ((borderline or pseudoneurotic or pseudopsychopathic or incipient or latent) adj2 schizophrenia)).tw.; 54. Bipolar Disorder/; 55. (((bipolar or manic) adj (disorder or psychos?s or depression)) or mania*).tw.; 56. “Depressive Disorder, Major”/ and (refractory or chronic or resistant).ti,ab.; 57. Depression/ and (refractory or chronic or resistant).ti,ab.; 58. Depressive Disorder/; 59. ((depressive adj (disorder or neuroses or syndrome*)) or ((endogenous or neurotic or unipolar) adj depression*)).tw.; 60. Obsessive-Compulsive Disorder/; 61. (OCD or anankastic personalit* or (obsessive compulsive adj (disorder* or neuros*)) or (obsessive-compulsive adj (disorder* or neuros*))).tw.; 62. exp anorexia nervosa/; 63. ((anorexia adj nervosa*) or anorexia*).tw.; 64. exp stress disorders, post-traumatic/; 65. ((chronic or acute or delayed onset) and (post-traumatic adj stress adj disorder*)).tw.; 66. ((posttraumatic or post-traumatic or post traumatic) adj (neuroses or disorder)).tw.; 67. ptsd.tw.; 68. exp tourette syndrome/; 69. ($tourette* adj (syndrome or disorder or disease)).tw.; 70. (tic adj disorder).tw.; 71. (multiple adj motor adj vocal adj tic adj disorder).tw.; 72. or/1-71; 73. exp Antipsychotic Agents/; 74. exp Tranquilizing Agents/; 75. ((first or 1st) adj generation adj antipsychotic*).tw.; 76. azaperone/; 77. 1649-18-9.rn.; 78. (Atsaperoni or Azaperon or Azaperona or Azaperone or Azaperonum or Eucalmyl or Fluoperidol or NSC 170976 or R 1929 or R-1929 or Sedaperone or Stresnil or Suicalm).mp.; 79. Butyrophenones/ad, to, tu, ct, po, ae; 80. Clopenthixol/; 81. 982-24-1.rn.; 82. (Chlorpenthixol or Clopenthixol or Clopenthixolum or Sordinol or Zuclopenthixol).mp.; 83. chlorpromazine/; 84. 50-53-3.rn.; 85. (Aminazin or Aminazine or Ampliactil or BC 135 or Chlorpromazine or Chlorpromazinum or Clorpromazina or Chlor-Promanyl or Chlorpromados or Chlorderazin or Chlorpromazin or Contomin or Elmarin or Esmind or Fenactil or Fenaktyl or HL 5746 or Largactil or Largactilothiazine or Megaphen or Largactyl or Klooripromatsiini or Klorpromazin or 6 Copin or Trinicalm Forte or Diminex Balsamico Juven Tos or Largatrex or Phenactyl or Proma or Promactil or Promazil or Prozil or Psychozine or Sanpron or Thorazine or Torazina or Wintermin).mp.; 86. Chlorprothixene/; 87. 113-59-7.rn.; 88. (Chlorprothixene or Chlorprothixen or Chlorprothixenum or Chlorprotixen or Chlorprotixene or Clorprotisene or Clorprotixeno or Laractan or Paxyl or Rentovet or Taractan or Tarasan or Traquilan or Trictal or Truxal or Truxaletten or Truxil or Vetacalm).mp.; 89. Dibenzoxazepines/ad, to, tu, ct, po, ae; 90. Droperidol/; 91. 548-73-2.rn.; 92. (Dehydrobenzoperidol or Dehydrobenzperidol or Deidrobenzperidolo or Dridol or Droleptan or Droperidol or Droperidoli or Droperidolis or Droperidolum or Disifelit or Halkan or Inapsin or Inapsine or Inopsin or Thalamonal or Nilperidol or Properidol or Sintodril or Vetkalm).mp.; 93. Flupenthixol/; 94. 2709-56-0.rn.; 95. (Depixol or Emergil or Fluanxol or Flupenthixol or Flupentixol or Flupentixolum or Fluxanxol or Siplaril or Siplarol).mp.; 96. fluphenazine/; 97. 69-23-8.rn.; 98. (Dapotum or Elinol or Flufenazina or Fluofenazine or Fluphenazine or Fluorphenazine or Fluphenazinum or Ftorphenazine or Moditen or Pacinol or Sevinol or Siqualon or Triflumethazine or Valamina or Vespazine).mp.; 99. haloperidol/; 100. 52-86-8.rn.; 101. (Aldo or Aloperidin or Aloperidol or Aloperidolo or Brootopon or Dozic or Einalon S or Eukystol or Fortunan or Galoperidol or Haldol or Halojust or Halopal or Haloperidol or Haloperidoli or Haloperidolis or Haloperidolu or Halopoidol or Serenace or Halopidol or Haloper or Halperon or Keselan or Lealgin or Linton or Mixidol or Peluces or Pernox or Serenace or Serenefl or Sernas or Sernel or Serenase or Ulcolind or Uliolind or Vesalium).mp.; 102. Indoles/ad, to, tu, ct, po, ae; 103. Lithium carbonate/; 104. 554-13-2.rn.; 105. (Camcolit or Candamide or Carbolith or Carbonic acid lithium salt or dilithium salt or Eskalith or Eutimin or Hypnorex or Limas or Lithium or Liskonum or Litard or Lithane or Lithea or Lithicarb or Lithinate or Lithionate or Lithotabs or Liticar or Manialith or Maniprex or Micalith or Neurolepsin or Pfi-lithium or Phasal or Plenur or Priadel or Quilonorm or Teralithe).mp.; 106. loxapine/; 107. 1977-10-2.rn.; 108. (Cloxazepine or CL 62362 or Dibenzacepin or Dibenzoazepine or Hydrofluoride 3170 or LW 3170 or Lossapina or Loksapiini or Loxapin or Loxapina or Loxapine or Loxapinum or Oxilapine or Loxapac or SUM 3170 or Loxitane or Desconex).mp.; 109. Methiothepin/; 110. 20229-30-5.rn.; 111. (Methiothepin or metitepine or Methiothepine or Methiothepin maleate or Metitepina or Metitepinum).mp.; 112. Methotrimeprazine/; 113. 60-99-1.rn.; 114. (Dedoran or Hirnamin or Hirnamine or Levomepromazine or Levomepromazin or Levomepromazina or Levopromazioni or Levomepromazinum or Levoprome or Levotomin or Mepromazine or Methotrimeprazine or Neurocil or Neozine or Nirvan or Nocinan or Momizan or Nozinane or Sinogan or Levolam or Nozinan or Sinogan or Tisercin or Veractil).mp.; 115. molindone/; 116. 7416-34-4.rn.; 117. (Molindona or Molindone or Molindonum).mp.; 118. Penfluridol/; 119. 26864-56-2.rn.; 120. (Penfluridol or Penfluridolum or Semap).mp.; 121. Perazine/; 122. 84-97-9.rn.; 123. (Pemazine Dimalonate or Peragal or Perazin or Perazine or Perazinum or Taxilan).mp.; 124. perphenazine/; 125. 58-39-9.rn.; 126. (Chlorperphenazine or Chlorpiprazine or Decentan or Emesinal or Etaperazin or Etaperazine or Ethaperazine or Etrafon or F-mon or Fentazin or Mutabon or Perfenazin or Perfenazina or Perfenazinas or Perfenazine or Perphenazin or Perphenazine or Perfenazyna or Perphenazinum or Pertriptyl or Sch 3940 or Thilatazin or Tranquisan or Trifaron or Trilafon or Trilifan or Triptafen or Triphenot or Triavil).mp.; 127. Phenothiazines/ad, to, tu, ct, po, ae [Administration & Dosage, Toxicity, Therapeutic Use, Contraindications, Poisoning, Adverse Effects]; 128. Pimozide/; 129. 2062-78-4.rn.; 130. (Antalon or Opiran or Orap or Pimotsidi or Pimozid or Pimozida or Pimozidas or Pimozide or Pimozidum or Pimozyd).mp.; 131. Prochlorperazine/; 132. 58-38-8.rn.; 133. (Apo-Prochlorazine or Capazine or Chlormeprazine or Compazine or Compro or Dhaperazine or Emelent or Kronocin or Nipodal or Novamin or Nu-Prochlor or Meterazin or Meterazine or Mitil or Prochlorpemazine or Prochlorperazinum or Proclorperazina or Prochlorperazine or Proklooriperatsiini or Proklorperazin or Prorazin or Phenothiazine or Seratil or Stemetil or Tementil or Temetid).mp.; 134. Promazine/; 135. 58-40-2.rn.; 136. (Ampazine or Berophen or Esparin or Liranol or Neo-Hibernex or Prazin or Sparine or Sinophenin or Promazine hydrochloride or Protactyl or Promatsiini or Promazin or Promazine or Promazinum or Propazinum or Prazine or Promwill or Protactyl or Romtiazin or Sinophenin or Talofen or Talofen or Tomil or Verophen).mp.; 137. Raclopride/; 138. 84225-95-6.rn.; 139. (raclopride or racloprida or raclopridum or rakloprid or raklopridl).mp.; 140. Spiperone/; 141. 749-02-0.rn.; 142. (E 525 or Espiperona or Spiperone or Spiperonum or Spiroperidol or Spiropitan).mp.; 143. thioridazine/; 144. 50-52-2.rn.; 145. (Aldazine or Dazithin or Detril or Elperil or Mallorol or Malloryl or Melleril or Meleril or Mellaril or Mellerets or Mellerette or Melleretten or Melleril or Sonapax or Thioridazin or Thioridazine or Thioridazinum or Tioridatsiini or Tioridazin or Tioridazina or Tioridazinas).mp.; 146. Thiothixene/; 147. 5591-45-7.rn.; 148. (Navane or Navaron or Orbinamon or Thiothixene or Tiotikseeni or Tiotixen or Tiotixeno or Tiotixenum or Thixit or Tiotixene).mp.; 149. Thioxanthenes/ad, to, tu, ct, po, ae; 150. Tiapride/; 151. 51012-32-9.rn.; 152. (Betaprid or Delpral or Doparid or Etiles or Equilium or Italiprid or Luxoben or Normagit or Porfanil or Sereprid or Tiacob or Tiapridal or Tiapride).mp.; 153. Trifluperidol/; 154. 749-13-3.rn.; 155. (Flumoperone or Psicoperidol or Psychoperidol or Trifluperidol or Trifluperidoli or Trifluperidolum or Triperidol or Trisedil or Trisedyl).mp.; 156. Trifluoperazine/; 157. 117-89-5.rn.; 158. (Cuait D or Cuait N or eskazine or flupazine or Jatrosom or Jalonac or Parstelin or Parmodalin or stelazine or Stelabid or Stelapar or Sycot or Terfluzine or Trifluoperazine or Trifluoperazini Hydrochloridum or triftazin or Trinicalm Forte or Trinicalm Plus).mp.; 159. Triflupromazine/; 160. 146-54-3.rn.; 161. (Adazine or Fluopromazine or Phenothiazine or Psyquil or Siquil or Triflupromazina or Triflupromazine or Trifluopromazine or Vesprin or Vetame).mp.; 162. Zuclopenthixol/; 163. 53772-83-1.rn.; 164. (Cisordinol or Clopixol or Ciatyl-Z or Clopenthixol or Clopentixol or Sedanxol or Zuclopenthixolum or Zuclopentixol or Zuclopenthixol or Zuklopentixol).mp.; 165. or/73-164; 166. (atypical adj antipsychotic*).tw.; 167. ((second or 2nd) adj generation adj antipsychotic*).tw.; 168. ((third or 3rd) adj generation adj antipsychotic*).tw.; 169. Amisulpride.tw.; 170. 71675-85-9.rn.; 171. (Aminosultopride or Amisulprida or Amisulpridum or Solian or Sulpitac).mp.; 172. aripiprazole.tw.; 173. 129722-12-9.rn.; 174. (Abilitat or Abilify or Aripiprazole or Discmelt or OPC 31 or OPC 14597).mp.; 175. Asenapine.tw.; 176. 65576-45-6.rn.; 177. EINECS 265-829-4.mp.; 178. Blonanserin.tw.; 179. 132810-10-7.rn.; 180. AD 5423.mp.; 181. Clotiapine.tw.; 182. 2058-52-8.rn.; 183. (Clothiapine or Clotiapina or Clotiapinum or Dibenzothiazepine or Etumina or Etumine or Entumin or Etomine or Entumine or HF 2159 or LW 2159 or “BRN 0568276”).mp.; 184. clozapine/; 185. 5786-21-0.rn.; 186. (Clozapin or Clozapina or Clozapine or Clozapinum or Clorazil or Clozaril or FazaClo or Leponex or LX 100-129 or Zaponex).mp.; 187. Diazepine.tw.; 188. 12688-68-5.rn.; 189. Dibenzazepines/ad, to, tu, ct, po, ae; 190. Dibenzothiazepines/ct, ad, to, tu, ae, po; 191. Fluvoxamine/; 192. (54739-18-3 or 61718-82-9).rn.; 193. (dumirox or DU23000 or Fluvoxamina or fluvoxamine or Fluvoaminum or Fluvoxamine Maleate or Fevarin or Luvox or SME 3110).mp.; 194. Iloperidone.tw.; 195. 133454-47-4.rn.; 196. (Fanapt or HP 873 or Zomaril).mp.; 197. Isoxazoles/ad, to, tu, ct, po, ae; 198. Mesoridazine/; 199. 5588-33-0.rn.; 200. (Calodal or Lidanar or Lidanil or Mesoridazina or Mesoridazine or Mesoridazinum or Serentil or THD-2-SO).mp.; 201. mosapramine.tw.; 202. 89419-40-9.rn.; 203. (Clospipramine or Cremin or Mosapramina).mp.; 204. olanzapine.tw.; 205. 132539-06-1.rn.; 206. (Zyprexa or Olantsapiini or Olanzapin or Olanzapina or Olanzapinum or Olansek or Zalasta or Zypadhera).mp.; 207. paliperidone.tw.; 208. 144598-75-4.rn.; 209. (9-Hydroxyrisperidone or Invega or R 76477 or RO76477).mp.; 210. Perospirone.tw.; 211. 150915-41-6.rn.; 212. (lullan or perospirone hydrochloride).mp.; 213. Piperidines/ad, to, tu, ct, po, ae; 214. Piperazines/ad, tu, to, ct, po, ae; 215. Pirenzepine/tu, ad, to, ct, po, ae; 216. Pyrimidinones/ad, to, tu, ct, po, ae; 217. quetiapine.tw.; 218. 111974-69-7.rn.; 219. (Co-Quetiapine or HSDB 7557 or Seroquel).mp.; 220. Quinolones/to, po, ct, ad, tu, ae; 221. Remoxipride/; 222. 80125-14-0.rn.; 223. (FLA 731 or Remoxiprida or Remoxipride or Remoxipridum).mp.; 224. Risperidone/; 225. 106266-06-2.rn.; 226. (Apexidone or Psychodal or Risperdal or Risperidona or Risperidone or Risperidonum or Risperin or Risperilept or Rispolin or Spiron).mp.; 227. Sertindole.tw.; 228. 106516-24-9.rn.; 229. (Lu 23-174 or Sertindol or Serdolect or Sertindolum).mp.; 230. Sulpiride/; 231. 15676-16-1.rn.; 232. (Abilit or Aiglonyl or Alimoral or Calmoflorine or Championyl or Darleton or Desmenat or Dobren or Dogmatil or Dogmatyl or Dolmatil or Eclorion or Eglonil or Eglonyl or Enimon or Equilid or Eusulpid or Fardalan or Fidelan or Guastil or Isnamide or Kylistro or Lisopiride or Mariastel or Meresa or Miradol or Mirbanil or Neogama or Normum or Nufarol or Omiryl or Omperan or Ozoderpin or Psicocen or Pyrkappl or Sernevin or Splotin or Stamonevrol or Sulparex or Sulpirid or Sulpirida or Sulpiride or Sulpiridum or Sulpor or Suprium or Sulpyrid or Trilan or Valirem or Zemorcon).mp.; 233. Thiazoles/ad, th, ct, po, to, ae; 234. Zotepine.tw.; 235. 26615-21-4.rn.; 236. (Lodepin or Nipolept or Zotepina or Zotepinum or Zoleptil).mp.; 237. ziprasidone.tw.; 238. 146939-27-7.rn.; 239. Zeldox.mp.; 240. or/73-74,166-239; 241. or/165,240; 242. and/72,241; 243. randomized controlled trial.pt.; 244. controlled clinical trial.pt.; 245. randomi?ed.ab.; 246. placebo.ab.; 247. drug therapy.fs.; 248. randomly.ab.; 249. trial.ab.; 250. groups.ab.; 251. or/243-250; 252. (humans not (animals and humans)).sh,hw.; 253. 251 and 252; 254. cohort studies/; 255. followup studies/; 256. longitudinal studies/; 257. prospective studies/; 258. Retrospective Studies/; 259. Case-Control Studies/; 260. (cohort$ or longitudinal or retrospective or prospective or followup or case-control).tw.; 261. or/254-260; 262. 261 and 252; 263. exp infant/; 264. exp child/; 265. exp adolescent/; 266. exp pediatrics/; 267. ($child$ or adolescen$ or p*ediatric$).tw.; 268. or/263-267; 269. and/242,253,268; 270. and/242,262,268; 271. and/242,253; 272. and/242,262; 273. or/271-272; 274. limit 273 to “all child (0 to 18 years)”; 275. or/269-270; 276. or/274-275; 277. limit 276 to (english language and yr=“1987 -Current”); 278. limit 273 to “young adult (19 to 24 years)”; 279. exp Young Adult/; 280. (young adj adult*).tw.; 281. ((college or university) adj2 (age or student*)).tw.; 282. students/; 283. or/279-282; 284. and/242,253,283; 285. and/242,262,283; 286. or/284-285; 287. or/278,286; 288. limit 287 to (english language and yr=“1987 -Current”); 289. 277 or 288; 290. (editorial or letter or comment).pt. or case reports/; 291. 289 not 290

Table A2 Embase–Ovid Version

OvidSP_-EMBASE 1980 to February Week 1 2011 | Searched: 12Feb10 and 01Feb11 Results: 3925
1. autism/; 2. infantile autism/; 3. (autism* or (autistic adj1 disorder*) or kanner* syndrome).tw.; 4. asperger syndrome/; 5. (asperger* adj1 (syndrome or disorder)).tw.; 6. childhood disintegrative disorder/; 7. (child adj1 development adj1 disorder*).tw.; 8. “pervasive developmental disorder not otherwise specified”/; 9. rett syndrome/; 10. (((rett or retts) adj1 (sydrome or disorder)) or cerebroatrophic hyperammonemia*).tw.; 11. atypical autism.mp.; 12. behavior disorder/; 13. disruptive behavior/; 14. disruptive behavio$ disorder?.mp.; 15. conduct disorder/; 16. (conduct adj disorder*).tw.; 17. oppositional defiant disorder/; 18. “disruptive behavior disorder not otherwise specified”.mp.; 19. “pervasive developmental disorder?”.mp.; 20. schizophrenia/; 21. catatonic schizophrenia/; 22. hebephrenia/; 23. latent schizophrenia/; 24. negative syndrome/; 25. paranoid schizophrenia/; 26. positive syndrome/; 27. residual schizophrenia/; 28. schizoaffective psychosis/; 29. schizophrenic reaction/; 30. schizophreniform disorder/; 31. simple schizophrenia/; 32. first episode schizophrenia.mp.; 33. prodromal schizophrenia/; 34. ((catatonic or disorganized or paranoid) adj schizophrenia).tw.; 35. psychosis/; 36. schizotypal personality disorder/; 37. ((Psychotic or schizoaffective or schizophreniform) adj disorder).tw.; 38. (schizotypal personality disorder or ((borderline or pseudoneurotic or pseudopsychopathic or incipient or latent) adj2 schizophrenia)).tw.; 39. bipolar disorder/; 40. bipolar depression/; 41. bipolar i disorder/; 42. bipolar ii disorder/; 43. bipolar mania/; 44. cyclothymia/; 45. manic depressive psychosis/; 46. “mixed mania and depression”/; 47. rapid cycling bipolar disorder/; 48. (((bipolar or manic) adj (disorder or psychos?s or depression)) or mania*).tw.; 49. depression/ and (refractory or chronic or resistant).ti,ab.; 50. major depression/ and (refractory or chronic or resistant).ti,ab.; 51. ((refractory or chronic or resistant) adj3 depression).mp.; 52. ((depressive adj (disorder or neuroses or syndrome*)) or ((endogenous or neurotic or unipolar) adj depression*)).tw.; 53. obsessive compulsive disorder/; 54. (OCD or anankastic personalit* or (obsessive compulsive adj (disorder* or neuros*)) or (obsessive-compulsive adj (disorder* or neuros*))).tw.; 55. exp anorexia nervosa/; 56. (anorexia nervosa* or anorexia*).tw.; 57. exp post traumatic stress disorder/; 58. (post-traumatic adj stress adj disorder*).tw.; 59. (posttraumatic adj stress adj disorder*).tw.; 60. ((post-traumatic or posttraumatic) adj neuroses).tw.; 61. (ptsd or (post adj traumatic adj neuroses)).tw.; 62. exp gilles de la Tourette syndrome/; 63. (de adj la adj tourette adj disease).tw.; 64. (gilles adj de adj la adj tourette adj disease).tw.; 65. (tourette adj disease).tw.; 66. (tourette adj syndrome).tw.; 67. exp tic/; 68. (tic adj disorder*).tw.; 69. (($behavioral adj2 dyscontrol) or (impulsive-behavioral adj2 deregulation)).tw.; 70. borderline personality disorder/; 71. (borderline adj1 personality adj1 disorder*).tw.; 72. (affective adj2 dysregulation).tw.; 73. (mood adj2 lability).tw.; 74. (irritable or irritability).tw.; 75. antisocial personality disorder/; 76. aggression/; 77. aggression.tw.; 78. psychomotor agitation/; 79. ((psychomotor adj1 (agitation or restlessness or hyperactivity or excitement)) or akathisia).tw.; 80. “sleep initiation and maintenance disorders”/; 81. ((sleep adj2 disorder*) or insomnia*).tw.; 82. mood disorders/; 83. ((mood or affective) adj1 disorder*).tw.; 84. impulsive behavior/; 85. (impulsive adj1 behavio?r).tw.; 86. Self-Injurious Behavior/; 87. (self-injurious behavio?r or self-mutilating behavio?r or self mutilation or self-destructive behavio?r or deliberate self-harm or parasuicide).tw.; 88. or/1-87; 89. neuroleptic agent/; 90. ((first or 1st) adj generation adj antipsychotic*).tw.; 91. Azaperone/; 92. 1649-18-9.rn.; 93. (Atsaperoni or Azaperon or Azaperona or Azaperone or Azaperonum or Eucalmyl or Fluoperidol or NSC 170976 or R 1929 or R-1929 or Sedaperone or Stresnil or Suicalm).mp.; 94. Clopenthixol/; 95. 982-24-1.rn.; 96. (Chlorpenthixol or Clopenthixol or Clopenthixolum or Sordinol or Zuclopenthixol).mp.; 97. chlorpromazine/; 98. 50-53-3.rn.; 99. (Aminazin or Aminazine or Ampliactil or BC 135 or Chlorpromazine or Chlorpromazinum or Clorpromazina or Chlor-Promanyl or Chlorpromados or Chlorderazin or Chlorpromazin or Contomin or Elmarin or Esmind or Fenactil or Fenaktyl or HL 5746 or Largactil or Largactilothiazine or Megaphen or Largactyl or Klooripromatsiini or Klorpromazin or 6 Copin or Trinicalm Forte or Diminex Balsamico Juven Tos or Largatrex or Phenactyl or Proma or Promactil or Promazil or Prozil or Psychozine or Sanpron or Thorazine or Torazina or Wintermin).mp.; 100. Chlorprothixene/; 101. 113-59-7.rn.; 102. (Chlorprothixene or Chlorprothixen or Chlorprothixenum or Chlorprotixen or Chlorprotixene or Clorprotisene or Clorprotixeno or Laractan or Paxyl or Rentovet or Taractan or Tarasan or Traquilan or Trictal or Truxal or Truxaletten or Truxil or Vetacalm).mp.; 103. dibenzoxazepine derivative/; 104. Droperidol/; 105. 548-73-2.rn.; 106. (Dehydrobenzoperidol or Dehydrobenzperidol or Deidrobenzperidolo or Dridol or Droleptan or Droperidol or Droperidoli or Droperidolis or Droperidolum or Disifelit or Halkan or Inapsin or Inapsine or Inopsin or Thalamonal or Nilperidol or Properidol or Sintodril or Vetkalm).mp.; 107. flupentixol/; 108. 2709-56-0.rn.; 109. (Depixol or Emergil or Fluanxol or Flupenthixol or Flupentixol or Flupentixolum or Fluxanxol or Siplaril or Siplarol).mp.; 110. fluphenazine/; 111. 69-23-8.rn.; 112. (Dapotum or Elinol or Flufenazina or Fluofenazine or Fluphenazine or Fluorphenazine or Fluphenazinum or Ftorphenazine or Moditen or Pacinol or Sevinol or Siqualon or Triflumethazine or Valamina or Vespazine).mp.; 113. haloperidol/; 114. 52-86-8.rn.; 115. (Aldo or Aloperidin or Aloperidol or Aloperidolo or Brootopon or Dozic or Einalon S or Eukystol or Fortunan or Galoperidol or Haldol or Halojust or Halopal or Haloperidol or Haloperidoli or Haloperidolis or Haloperidolu or Halopoidol or Serenace or Halopidol or Haloper or Halperon or Keselan or Lealgin or Linton or Mixidol or Peluces or Pernox or Serenace or Serenefl or Sernas or Sernel or Serenase or Ulcolind or Uliolind or Vesalium).mp.; 116. indole derivative/; 117. levomepromazine/; 118. 60-99-1.rn.; 119. (Dedoran or Hirnamin or Hirnamine or Levomepromazine or Levomepromazin or Levomepromazina or Levopromazioni or Levomepromazinum or Levoprome or Levotomin or Mepromazine or Methotrimeprazine or Neurocil or Neozine or Nirvan or Nocinan or Momizan or Nozinane or Sinogan or Levolam or Nozinan or Sinogan or Tisercin or Veractil).mp.; 120. Lithium/; 121. 554-13-2.rn.; 122. (Camcolit or Candamide or Carbolith or Carbonic acid lithium salt or dilithium salt or Eskalith or Eutimin or Hypnorex or Limas or Lithium or Liskonum or Litard or Lithane or Lithea or Lithicarb or Lithinate or Lithionate or Lithotabs or Liticar or Manialith or Maniprex or Micalith or Neurolepsin or Pfi-lithium or Phasal or Plenur or Priadel or Quilonorm or Teralithe).mp.; 123. loxapine/; 124. 1977-10-2.rn.; 125. (Cloxazepine or CL 62362 or Dibenzacepin or Dibenzoazepine or Hydrofluoride 3170 or LW 3170 or Lossapina or Loksapiini or Loxapin or Loxapina or Loxapine or Loxapinum or Oxilapine or Loxapac or SUM 3170 or Loxitane or Desconex).mp.; 126. Metitepine/; 127. 20229-30-5.rn.; 128. (Methiothepin or metitepine or Methiothepine or Methiothepin maleate or Metitepina or Metitepinum).mp.; 129. molindone/; 130. 7416-34-4.rn.; 131. (Molindona or Molindone or Molindonum).mp.; 132. Penfluridol/; 133. 26864-56-2.rn.; 134. (Penfluridol or Penfluridolum or Semap).mp.; 135. Perazine/; 136. 84-97-9.rn.; 137. (Pemazine Dimalonate or Peragal or Perazin or Perazine or Perazinum or Taxilan).mp.; 138. perphenazine/; 139. 58-39-9.rn.; 140. (Chlorperphenazine or Chlorpiprazine or Decentan or Emesinal or Etaperazin or Etaperazine or Ethaperazine or Etrafon or F-mon or Fentazin or Mutabon or Perfenazin or Perfenazina or Perfenazinas or Perfenazine or Perphenazin or Perphenazine or Perfenazyna or Perphenazinum or Pertriptyl or Sch 3940 or Thilatazin or Tranquisan or Trifaron or Trilafon or Trilifan or Triptafen or Triphenot or Triavil).mp.; 141. phenothiazine derivative/; 142. Pimozide/; 143. 2062-78-4.rn.; 144. (Antalon or Opiran or Orap or Pimotsidi or Pimozid or Pimozida or Pimozidas or Pimozide or Pimozidum or Pimozyd).mp.; 145. Prochlorperazine/; 146. 58-38-8.rn.; 147. (Apo-Prochlorazine or Capazine or Chlormeprazine or Compazine or Compro or Dhaperazine or Emelent or Kronocin or Nipodal or Novamin or Nu-Prochlor or Meterazin or Meterazine or Mitil or Prochlorpemazine or Prochlorperazinum or Proclorperazina or Prochlorperazine or Proklooriperatsiini or Proklorperazin or Prorazin or Phenothiazine or Seratil or Stemetil or Tementil or Temetid).mp.; 148. Promazine/; 149. 58-40-2.rn.; 150. (Ampazine or Berophen or Esparin or Liranol or Neo-Hibernex or Prazin or Sparine or Sinophenin or Promazine hydrochloride or Protactyl or Promatsiini or Promazin or Promazine or Promazinum or Propazinum or Prazine or Promwill or Protactyl or Romtiazin or Sinophenin or Talofen or Talofen or Tomil or Verophen).mp.; 151. Raclopride/; 152. 84225-95-6.rn.; 153. (raclopride or racloprida or raclopridum or rakloprid or raklopridl).mp.; 154. Spiperone/; 155. 749-02-0.rn.; 156. (E 525 or Espiperona or Spiperonum or Spiroperidol or Spiropitan).mp.; 157. thioridazine/; 158. 50-52-2.rn.; 159. (Aldazine or Dazithin or Detril or Elperil or Mallorol or Malloryl or Melleril or Meleril or Mellaril or Mellerets or Mellerette or Melleretten or Melleril or Sonapax or Thioridazin or Thioridazinum or Tioridatsiini or Tioridazin or Tioridazina or Tioridazinas).mp.; 160. Tiapride/; 161. 51012-32-9.rn.; 162. tiotixene/; 163. 5591-45-7.rn.; 164. (Navane or Navaron or Orbinamon or Tiotixene or Tiotikseeni or Tiotixen or Tiotixeno or Tiotixenum or Thixit or Tiotixene).mp.; 165. trifluoperazine/; 166. 117-89-5.rn.; 167. (Cuait D or Cuait N or eskazine or flupazine or Jatrosom or Jalonac or Parstelin or Parmodalin or stelazine or Stelabid or Stelapar or Sycot or Terfluzine or Trifluoperazine or Trifluoperazini Hydrochloridum or triftazin or Trinicalm Forte or Trinicalm Plus).mp.; 168. Trifluperidol/; 169. 749-13-3.rn.; 170. (Flumoperone or Psicoperidol or Psychoperidol or Trifluperidol or Trifluperidoli or Trifluperidolum or Triperidol or Trisedil or Trisedyl).mp.; 171. Triflupromazine/; 172. 146-54-3.rn.; 173. (Adazine or Fluopromazine or Phenothiazine or Psyquil or Siquil or Triflupromazina or Trifluopromazine or Vesprin or Vetame).mp.; 174. Zuclopenthixol/; 175. 53772-83-1.rn.; 176. (Cisordinol or Clopixol or Ciatyl-Z or Clopenthixol or Clopentixol or Sedanxol or Zuclopenthixolum or Zuclopentixol or Zuclopenthixol or Zuklopentixol).mp.; 177. or/89-176; 178. atypical antipsychotic agent/; 179. (atypical adj antipsychotic*).tw.; 180. ((second or 2nd) adj generation adj antipsychotic*).tw.; 181. ((third or 3rd) adj generation adj antipsychotic*).tw.; 182. Amisulpride/; 183. 71675-85-9.rn.; 184. (Aminosultopride or Amisulprida or Amisulpride or Amisulpridum or Solian or Sulpitac).tw.; 185. Aripiprazole/; 186. 129722-12-9.rn.; 187. (Abilitat or Abilify or Aripiprazole or Discmelt or OPC 31 or OPC 14597).mp.; 188. Asenapine/; 189. 65576-45-6.rn.; 190. (Asenapine or EINECS 265-829-4).mp.; 191. Blonanserin/; 192. 132810-10-7.rn.; 193. (Blonserin or AD 5423).mp.; 194. Clospipramine/; 195. 89419-40-9.rn.; 196. (Clospipramine or Cremin or Mosapramina or Mosapramine).mp.; 197. Clotiapine/; 198. 2058-52-8.rn.; 199. (Clothiapine or Clotiapina or Clotiapine or Clotiapinum or Dibenzothiazepine or Etumina or Etumine or Entumin or Etomine or Entumine or HF 2159 or LW 2159 or “BRN 0568276”).mp.; 200. clozapine/; 201. 5786-21-0.rn.; 202. (Clozapin or Clozapina or Clozapine or Clozapinum or Clorazil or Clozaril or FazaClo or Leponex or LX 100-129 or Zaponex).mp.; 203. diazepine derivative/; 204. 12688-68-5.rn.; 205. dibenzazepine derivative/; 206. Dibenzothiazepines.tw.; 207. Fluvoxamine/; 208. (54739-18-3 or 61718-82-9).rn.; 209. (dumirox or DU23000 or Fluvoxamina or fluvoxamine or Fluvoaminum or Fluvoxamine Maleate or Fevarin or Luvox or SME 3110).mp.; 210. Iloperidone/; 211. 133454-47-4.rn.; 212. (Fanapt or HP 873 or Illoperidone or Zomaril).mp.; 213. Isoxazole derivative/; 214. mesoridazine besylate/ or mesoridazine/; 215. 5588-33-0.rn.; 216. (Calodal or Lidanar or Lidanil or Mesoridazina or Mesoridazine or Mesoridazinum or Serentil or THD-2-SO).mp.; 217. olanzapine/; 218. 132539-06-1.rn.; 219. (Zyprexa or Olantsapiini or Olanzapin or Olanzapina or Olanzapine or Olanzapinum or Olansek or Zalasta or Zypadhera).mp.; 220. paliperidone/; 221. 144598-75-4.rn.; 222. (9-Hydroxyrisperidone or Invega or Paliperidone or R 76477 or RO76477).mp.; 223. Perospirone/; 224. 150915-41-6.rn.; 225. (lullan or perospirone hydrochloride).mp.; 226. piperidine derivative/; 227. Piperazine derivative/; 228. Pirenzepine/; 229. pyrimidinone derivative/; 230. Quetiapine/; 231. 111974-69-7.rn.; 232. (Co-Quetiapine or HSDB 7557 or Quetiapine or Seroquel).mp.; 233. Quinolone derivative/; 234. Remoxipride/; 235. 80125-14-0.rn.; 236. (FLA 731 or Remoxiprida or Remoxipride or Remoxipridum).mp.; 237. risperidone/; 238. 106266-06-2.rn.; 239. (Apexidone or Psychodal or Risperdal or Risperidona or Risperidone or Risperidonum or Risperin or Risperilept or Rispolin or Spiron).mp.; 240. Sertindole/; 241. 106516-24-9.rn.; 242. (Lu 23-174 or Sertindol or Sertindole or Serdolect or Sertindolum).mp.; 243. Sulpiride/; 244. 15676-16-1.rn.; 245. (Abilit or Aiglonyl or Alimoral or Calmoflorine or Championyl or Darleton or Desmenat or Dobren or Dogmatil or Dogmatyl or Dolmatil or Eclorion or Eglonil or Eglonyl or Enimon or Equilid or Eusulpid or Fardalan or Fidelan or Guastil or Isnamide or Kylistro or Lisopiride or Mariastel or Meresa or Miradol or Mirbanil or Neogama or Normum or Nufarol or Omiryl or Omperan or Ozoderpin or Psicocen or Pyrkappl or Sernevin or Splotin or Stamonevrol or Sulparex or Sulpirid or Sulpirida or Sulpiride or Sulpiridum or Sulpor or Suprium or Sulpyrid or Trilan or Valirem or Zemorcon).mp.; 246. Thiazole derivative/; 247. Zotepine/; 248. 26615-21-4.rn.; 249. (Lodepin or Nipolept or Zotepina or Zotepine or Zotepinum or Zoleptil).mp.; 250. ziprasidone/; 251. 146939-27-7.rn.; 252. (ziprasidone or zeldox).tw.; 253. or/178-252; 254. or/177,253; 255. and/88,254; 256. exp clinical trial/; 257. randomi?ed.ti,ab.; 258. placebo.ti,ab.; 259. dt.fs.; 260. randomly.ti,ab.; 261. trial.ti,ab.; 262. groups.ti,ab.; 263. or/256-262; 264. (animal not (animal and human)).sh.; 265. 263 not 264; 266. (book or book series or editorial or letter or note).pt. or case report/; 267. 265 not 266; 268. cohort analysis/; 269. longitudinal study/; 270. follow up/; 271. retrospective study/; 272. prospective study/; 273. case control study/; 274. comparative study/; 275. observational study/; 276. (cohort$ or longitudinal or retrospective or prospective or followup or case-control).tw.; 277. or/268-276; 278. 277 not 264; 279. 278 not 266; 280. exp infant/; 281. exp child/; 282. exp adolescent/; 283. exp pediatrics/; 284. (child$ or adolescen$ or p*ediatrics$).tw.; 285. or/280-284; 286. and/255,267,285; 287. and/255,279,285; 288. or/286-287; 289. limit 288 to yr=“1987 -Current”; 290. limit 289 to english language; 291. (and/255,267) or (and/255,279); 292. limit 291 to (infant or child or preschool child <1 to 6 years> or school child <7 to 12 years> or adolescent <13 to 17 years>); 293. limit 292 to yr=“1987 -Current”; 294. limit 293 to english language; 295. 290 or 294; 296. (young adj adult*).mp.; 297. ((college or university) adj2 (age or student*)).tw.; 298. exp student/; 299. or/296-298; 300. and/255,267,299; 301. and/255,279,299; 302. or/300-301; 303. limit 302 to yr=“1987 -Current”; 304. limit 303 to english language; 305. 295 or 304

Table A3 PsycINFO–Ovid Version

OvidSP_-PsycINFO 1980 to February Week 1 2011 | Searched: 16Apr10 and 01Feb11 Results: 4176
1. exp Pervasive Developmental Disorders/; 2. (child adj1 development adj1 disorder*).tw.; 3. exp Aspergers Syndrome/; 4. (asperger* adj1 (syndrome or disorder)).tw.; 5. exp Autism/; 6. (autism* or (autistic adj1 disorder*) or kanner* syndrome).tw.; 7. exp Rett Syndrome/; 8. (((rett or retts) adj1 (sydrome or disorder)) or cerebroatrophic hyperammonemia*).tw.; 9. exp Childhood Schizophrenia/; 10. (childhood* adj2 schizophrenia*).tw.; 11. aggressive behavior/; 12. aggression.tw.; 13. agitation/; 14. ((psychomotor adj1 (agitation or restlessness or hyperactivity or excitement)) or akathisia).tw.; 15. Sleep Disorders/; 16. ((sleep adj2 disorder*) or insomnia*).tw.; 17. affective disorders/; 18. ((mood or affective) adj1 disorder*).tw.; 19. impulsiveness/; 20. (impulsive* or (impulsive adj1 behavio?r)).tw.; 21. exp Movement Disorders/; 22. borderline personality disorder/; 23. (borderline adj1 personality adj1 disorder*).tw.; 24. (affective adj2 dysregulation).tw.; 25. (($behavioral adj2 dyscontrol) or (impulsive-behavioral adj2 deregulation)).tw.; 26. (mood adj2 lability).tw.; 27. (irritable or irritability).tw.; 28. Self-Injurious Behavior/; 29. (self-injurious behavio?r or self-mutilating behavio?r or self mutilation or self-destructive behavio?r or deliberate self-harm or parasuicide).tw.; 30. antisocial personality disorder/; 31. exp Attention Deficit Disorder/; 32. ((attention adj deficit adj disorder) or hyperkinetic syndrome or adhd).tw.; 33. exp Behavior Disorders/; 34. exp Conduct Disorder/; 35. (conduct adj disorder*).tw.; 36. (Childhood adj Disintegrative adj Disorder).tw.; 37. “Pervasive Developmental Disorder Not Otherwise Specified”.tw.; 38. exp Oppositional Defiant Disorder/; 39. (Oppositional adj Defiant adj Disorder).tw.; 40. (atypical adj1 autism).tw.; 41. “Disruptive Behavior Disorder Not Otherwise Specified”.mp.; 42. exp Schizophrenia/; 43. exp Catatonic Schizophrenia/; 44. exp “Schizophrenia (Disorganized Type)”/; 45. exp Paranoid Schizophrenia/; 46. ((catatonic or disorganized or paranoid) adj schizophrenia).tw.; 47. exp Psychosis/; 48. exp Schizoaffective Disorder/; 49. ((Psychotic or schizoaffective or schizophreniform) adj disorder).tw.; 50. (brief reactive adj (psychos?s or psychoses)).tw.; 51. first episode schizophrenia.tw.; 52. (prodrom$ and schizophren$).tw.; 53. exp Schizotypal Personality Disorder/; 54. exp Schizoid Personality Disorder/; 55. (schizotypal personality disorder or ((borderline or pseudoneurotic or pseudopsychopathic or incipient or latent) adj2 schizophrenia)).tw.; 56. exp Bipolar Disorder/; 57. (((bipolar or manic) adj (disorder or psychos?s or depression)) or mania*).tw.; 58. exp Major Depression/; 59. (depress* and (refractory or chronic or resistant)).mp.; 60. exp Treatment Resistant Depression/; 61. ((refractive or chronic or resistant) adj3 depression).tw.; 62. (depressive adj2 disorder*).tw.; 63. exp Obsessive Compulsive Disorder/; 64. (OCD or anankastic personalit* or (obsessive compulsive adj (disorder* or neuros*)) or (obsessive-compulsive adj (disorder* or neuros*))).tw.; 65. exp Anorexia Nervosa/; 66. ((anorexia adj nervosa*) or anorexia*).tw.; 67. exp Posttraumatic Stress Disorder/; 68. ((chronic or acute or delayed onset) and (post-traumatic adj stress adj disorder*)).tw.; 69. ((posttraumatic or post-traumatic or post traumatic) adj (neuroses or disorder)).tw.; 70. ptsd.tw.; 71. exp Tourette Syndrome/; 72. exp Tics/; 73. ($tourette* adj (syndrome or disorder or disease)).tw.; 74. (tic adj disorder).tw.; 75. (multiple adj motor adj vocal adj tic adj disorder).tw.; 76. or/1-75; 77. exp Neuroleptic Drugs/; 78. exp Tranquilizing Drugs/; 79. (antipsychotic adj (drug* or agent*)).tw.; 80. ((first or 1st) adj generation adj antipsychotic*).tw.; 81. azaperone.mp.; 82. (Atsaperoni or Azaperon or Azaperona or Azaperone or Azaperonum or Eucalmyl or Fluoperidol or NSC 170976 or R 1929 or R-1929 or Sedaperone or Stresnil or Suicalm).mp.; 83. Butyrophenones.tw.; 84. Clopenthixol.mp.; 85. (Chlorpenthixol or Clopenthixol or Clopenthixolum or Sordinol or Zuclopenthixol).mp.; 86. exp Chlorpromazine/; 87. (Aminazin or Aminazine or Ampliactil or BC 135 or Chlorpromazine or Chlorpromazinum or Clorpromazina or Chlor-Promanyl or Chlorpromados or Chlorderazin or Chlorpromazin or Contomin or Elmarin or Esmind or Fenactil or Fenaktyl or HL 5746 or Largactil or Largactilothiazine or Megaphen or Largactyl or Klooripromatsiini or Klorpromazin or 6 Copin or Trinicalm Forte or Diminex Balsamico Juven Tos or Largatrex or Phenactyl or Proma or Promactil or Promazil or Prozil or Psychozine or Sanpron or Thorazine or Torazina or Wintermin).mp.; 88. Chlorprothixene/; 89. (Chlorprothixene or Chlorprothixen or Chlorprothixenum or Chlorprotixen or Chlorprotixene or Clorprotisene or Clorprotixeno or Laractan or Paxyl or Rentovet or Taractan or Tarasan or Traquilan or Trictal or Truxal or Truxaletten or Truxil or Vetacalm).mp.; 90. dibenzoxazepines.tw.; 91. Droperidol.mp.; 92. (Dehydrobenzoperidol or Dehydrobenzperidol or Deidrobenzperidolo or Dridol or Droleptan or Droperidol or Droperidoli or Droperidolis or Droperidolum or Disifelit or Halkan or Inapsin or Inapsine or Inopsin or Thalamonal or Nilperidol or Properidol or Sintodril or Vetkalm).mp.; 93. flupentixol.mp.; 94. (Depixol or Emergil or Fluanxol or Flupenthixol or Flupentixol or Flupentixolum or Fluxanxol or Siplaril or Siplarol).mp.; 95. exp Fluphenazine/; 96. (Dapotum or Elinol or Flufenazina or Fluofenazine or Fluphenazine or Fluorphenazine or Fluphenazinum or Ftorphenazine or Moditen or Pacinol or Sevinol or Siqualon or Triflumethazine or Valamina or Vespazine).mp.; 97. exp Haloperidol/; 98. (Aldo or Aloperidin or Aloperidol or Aloperidolo or Brootopon or Dozic or Einalon S or Eukystol or Fortunan or Galoperidol or Haldol or Halojust or Halopal or Haloperidol or Haloperidoli or Haloperidolis or Haloperidolu or Halopoidol or Serenace or Halopidol or Haloper or Halperon or Keselan or Lealgin or Linton or Mixidol or Peluces or Pernox or Serenace or Serenefl or Sernas or Sernel or Serenase or Ulcolind or Uliolind or Vesalium).mp.; 99. indoles.tw.; 100. Lithium/ or Lithium carbonate/; 101. (Camcolit or Candamide or Carbolith or Carbonic acid lithium salt or dilithium salt or Eskalith or Eutimin or Hypnorex or Limas or Lithium or Liskonum or Litard or Lithane or Lithea or Lithicarb or Lithinate or Lithionate or Lithotabs or Liticar or Manialith or Maniprex or Micalith or Neurolepsin or Pfi-lithium or Phasal or Plenur or Priadel or Quilonorm or Teralithe).mp.; 102. exp Loxapine/; 103. (Cloxazepine or CL 62362 or Dibenzacepin or Dibenzoazepine or Hydrofluoride 3170 or LW 3170 or Lossapina or Loksapiini or Loxapin or Loxapina or Loxapine or Loxapinum or Oxilapine or Loxapac or SUM 3170 or Loxitane or Desconex).mp.; 104. Methiothepin.mp.; 105. (Methiothepin or metitepine or Methiothepine or Methiothepin maleate or Metitepina or Metitepinum).mp.; 106. Methotrimeprazine.mp.; 107. (Dedoran or Hirnamin or Hirnamine or Levomepromazine or Levomepromazin or Levomepromazina or Levopromazioni or Levomepromazinum or Levoprome or Levotomin or Mepromazine or Methotrimeprazine or Neurocil or Neozine or Nirvan or Nocinan or Momizan or Nozinane or Sinogan or Levolam or Nozinan or Sinogan or Tisercin or Veractil).mp.; 108. exp Molindone/; 109. (Molindona or Molindone or Molindonum).mp.; 110. Penfluridol.mp.; 111. (Penfluridol or Penfluridolum or Semap).mp.; 112. perazine.mp.; 113. (Pemazine Dimalonate or Peragal or Perazin or Perazine or Perazinum or Taxilan).mp.; 114. exp Perphenazine/; 115. (Chlorperphenazine or Chlorpiprazine or Decentan or Emesinal or Etaperazin or Etaperazine or Ethaperazine or Etrafon or F-mon or Fentazin or Mutabon or Perfenazin or Perfenazina or Perfenazinas or Perfenazine or Perphenazin or Perphenazine or Perfenazyna or Perphenazinum or Pertriptyl or Sch 3940 or Thilatazin or Tranquisan or Trifaron or Trilafon or Trilifan or Triptafen or Triphenot or Triavil).mp.; 116. exp Phenothiazine Derivatives/; 117. Pimozide/; 118. (Antalon or Opiran or Orap or Pimotsidi or Pimozid or Pimozida or Pimozidas or Pimozide or Pimozidum or Pimozyd).mp.; 119. Prochlorperazine/; 120. (Apo-Prochlorazine or Capazine or Chlormeprazine or Compazine or Compro or Dhaperazine or Emelent or Kronocin or Nipodal or Novamin or Nu-Prochlor or Meterazin or Meterazine or Mitil or Prochlorpemazine or Prochlorperazinum or Proclorperazina or Prochlorperazine or Proklooriperatsiini or Proklorperazin or Prorazin or Phenothiazine or Seratil or Stemetil or Tementil or Temetid).mp.; 121. promazine/; 122. (Ampazine or Berophen or Esparin or Liranol or Neo-Hibernex or Prazin or Sparine or Sinophenin or Promazine hydrochloride or Protactyl or Promatsiini or Promazin or Promazine or Promazinum or Propazinum or Prazine or Promwill or Protactyl or Romtiazin or Sinophenin or Talofen or Talofen or Tomil or Verophen).mp.; 123. raclopride.mp.; 124. (raclopride or racloprida or raclopridum or rakloprid or raklopridl).mp.; 125. Spiroperidol/; 126. (E 525 or Espiperona or Spiperone or Spiperonum or Spiroperidol or Spiropitan).mp.; 127. exp Thiothixene/; 128. (Navane or Navaron or Orbinamon or Tiotixene or Tiotikseeni or Tiotixen or Tiotixeno or Tiotixenum or Thixit or Tiotixene).mp.; 129. exp Trifluoperazine/; 130. (Cuait D or Cuait N or eskazine or flupazine or Jatrosom or Jalonac or Parstelin or Parmodalin or stelazine or Stelabid or Stelapar or Sycot or Terfluzine or Trifluoperazine or Trifluoperazini Hydrochloridum or triftazin or Trinicalm Forte or Trinicalm Plus).mp.; 131. exp Thioridazine/; 132. (Aldazine or Dazithin or Detril or Elperil or Mallorol or Malloryl or Melleril or Meleril or Mellaril or Mellerets or Mellerette or Melleretten or Melleril or Sonapax or Thioridazin or Thioridazinum or Tioridatsiini or Tioridazin or Tioridazina or Tioridazinas).mp.; 133. exp Phenothiazine Derivatives/; 134. (Adazine or Fluopromazine or Phenothiazine or Psyquil or Siquil or Triflupromazina or Trifluopromazine or Vesprin or Vetame).mp.; 135. Zuclopenthixol.mp.; 136. (Cisordinol or Clopixol or Ciatyl-Z or Clopenthixol or Clopentixol or Sedanxol or Zuclopenthixolum or Zuclopentixol or Zuclopenthixol or Zuklopentixol).mp.; 137. or/77-136; 138. atypical antipsychotic$.tw.; 139. ((second or 2nd) adj generation adj antipsychotic*).tw.; 140. ((third or 3rd) adj generation adj antipsychotic*).tw.; 141. Amisulpride.mp.; 142. (Aminosultopride or Amisulprida or Amisulpridum or Solian or Sulpitac).mp.; 143. exp Aripiprazole/; 144. (Abilitat or Abilify or Aripiprazole or Discmelt or OPC 31 or OPC 14597).mp.; 145. Asenapine.mp.; 146. EINECS 265-829-4.mp.; 147. (Blonanserin or AD 5423).mp.; 148. Clotiapine.mp.; 149. (Clothiapine or Clotiapina or Clotiapinum or Dibenzothiazepine or Etumina or Etumine or Entumin or Etomine or Entumine or HF 2159 or LW 2159 or “BRN 0568276”).mp.; 150. exp Clozapine/; 151. (Clozapin or Clozapina or Clozapine or Clozapinum or Clorazil or Clozaril or FazaClo or Leponex or LX 100-129 or Zaponex).mp.; 152. Diazepine.mp.; 153. Dibenzazepines.mp.; 154. Fluvoxamine/; 155. (dumirox or DU23000 or Fluvoxamina or fluvoxamine or Fluvoaminum or Fluvoxamine Maleate or Fevarin or Luvox or SME 3110).mp.; 156. Iloperidone.mp.; 157. (Fanapt or HP 873 or Zomaril).mp.; 158. Isoxazole*.mp.; 159. Mesoridazine/; 160. (Calodal or Lidanar or Lidanil or Mesoridazina or Mesoridazine or Mesoridazinum or Serentil or THD-2-SO).mp.; 161. mosapramine.mp.; 162. (Clospipramine or Cremin or Mosapramina).mp.; 163. exp Olanzapine/; 164. (Zyprexa or Olantsapiini or Olanzapin or Olanzapine or Olanzapina or Olanzapinum or Olansek or Zalasta or Zypadhera).mp.; 165. paliperidone.tw.; 166. (9-Hydroxyrisperidone or Invega or R 76477 or RO76477).mp.; 167. Perospirone.tw.; 168. (lullan or perospirone hydrochloride).mp.; 169. Piperidines.mp.; 170. Piperazines/ or piperazine*.mp.; 171. Pirenzepine.mp.; 172. Pyrimidinones.mp.; 173. exp Quetiapine/; 174. (Co-Quetiapine or HSDB 7557 or Quetiapine or Seroquel).mp.; 175. Quinolones.mp.; 176. Remoxipride.mp.; 177. (FLA 731 or Remoxiprida or Remoxipride or Remoxipridum).mp.; 178. exp Risperidone/; 179. (Apexidone or Psychodal or Risperdal or Risperidona or Risperidone or Risperidonum or Risperin or Risperilept or Rispolin or Spiron).mp.; 180. Sertindole.mp.; 181. (Lu 23-174 or Sertindol or Sertindole or Serdolect or Sertindolum).mp.; 182. Sulpiride/; 183. (Abilit or Aiglonyl or Alimoral or Calmoflorine or Championyl or Darleton or Desmenat or Dobren or Dogmatil or Dogmatyl or Dolmatil or Eclorion or Eglonil or Eglonyl or Enimon or Equilid or Eusulpid or Fardalan or Fidelan or Guastil or Isnamide or Kylistro or Lisopiride or Mariastel or Meresa or Miradol or Mirbanil or Neogama or Normum or Nufarol or Omiryl or Omperan or Ozoderpin or Psicocen or Pyrkappl or Sernevin or Splotin or Stamonevrol or Sulparex or Sulpirid or Sulpirida or Sulpiride or Sulpiridum or Sulpor or Suprium or Sulpyrid or Trilan or Valirem or Zemorcon).mp.; 184. thiazole.mp.; 185. Zotepine.tw.; 186. (Lodepin or Nipolept or Zotepina or Zotepinum or Zoleptil).mp.; 187. ziprasidone.tw.; 188. Zeldox.mp.; 189. or/77-79,138-188; 190. or/137,189; 191. and/76,190; 192. randomi?ed controlled trial.tw,pt.; 193. exp Clinical Trials/; 194. controlled clinical trial.tw,pt.; 195. randomi?ed.ab.; 196. placebo.ab.; 197. exp drug therapy/; 198. randomly.ab.; 199. trial.ab.; 200. groups.ab.; 201. or/192-200; 202. (cohort studies or cohort study).tw.; 203. exp Followup Studies/; 204. exp Longitudinal Studies/; 205. exp Prospective Studies/; 206. exp Retrospective Studies/; 207. (cohort$ or longitudinal or retrospective or prospective or followup or case-control).tw.; 208. or/202-207; 209. (animals not (humans and animals)).sh,hw.; 210. 201 not 209; 211. 208 not 209; 212. (infant or $child$ or adolescen$ or p*ediatric$).tw.; 213. and/191,210,212; 214. and/191,211-212; 215. or/213-214; 216. and/191,210; 217. and/191,211; 218. or/216-217; 219. limit 218 to ((childhood or adolescence <13 to 17 years>) and (100 childhood or 140 infancy or 160 preschool age or 180 school age or 200 adolescence )); 220. limit 215 to ((childhood or adolescence <13 to 17 years>) and (100 childhood or 140 infancy or 160 preschool age or 180 school age or 200 adolescence )); 221. or/219-220; 222. limit 221 to human; 223. limit 222 to english language; 224. limit 223 to yr=“1987 -Current”; 225. ((college or university) adj2 (age or student*)).tw.; 226. exp College Students/; 227. (young adj adult*).tw.; 228. or/225-227; 229. and/191,210,228; 230. and/191,211,228; 231. limit 218 to 320 young adulthood; 232. limit 215 to 320 young adulthood; 233. 231 or 232; 234. limit 233 to (human and english language and yr=“1987 -Current”); 235. 224 or 234

Table A4 CENTRAL–Ovid Version

OvidSP_-CENTRAL 1980 to February Week 1 2011 | Searched: 16Apr10 and 01Feb11 Results: 1181
1. (child adj1 development adj1 disorder*).mp.; 2. (asperger* adj1 (syndrome or disorder)).mp.; 3. (autism* or (autistic adj1 disorder*) or kanner* syndrome).mp.; 4. (atypical adj1 autism).mp.; 5. (((rett or retts) adj1 (sydrome or disorder)) or cerebroatrophic hyperammonemia*).mp.; 6. (child* adj2 schizophrenia*).mp.; 7. aggression.mp.; 8. ((psychomotor adj1 (agitation or restlessness or hyperactivity or excitement)) or akathisia).mp.; 9. ((sleep adj2 disorder*) or insomnia*).mp.; 10. ((mood or affective) adj1 disorder*).mp.; 11. (impulsive adj1 behavio?r).mp.; 12. (borderline adj1 personality adj1 disorder*).mp.; 13. (affective adj2 dysregulation).mp.; 14. (($behavioral adj2 dyscontrol) or (impulsive-behavioral adj2 deregulation)).mp.; 15. (mood adj2 lability).mp.; 16. (irritable or irritability).mp.; 17. (self-injurious behavio?r or self-mutilating behavio?r or self mutilation or self-destructive behavio?r or deliberate self-harm or parasuicide).mp.; 18. movement disorders.mp.; 19. ((attention adj deficit adj disorder) or hyperkinetic syndrome or adhd).mp.; 20. (conduct adj disorder*).mp.; 21. oppositional defiant disorder.mp.; 22. “Disruptive Behavior Disorder Not Otherwise Specified”.mp.; 23. (schizophrenia* or ((catatonic or disorganized or paranoid) adj schizophrenia)).mp.; 24. ((Psychotic or schizoaffective or schizophreniform) adj disorder).mp.; 25. (schizotypal personality disorder or ((borderline or pseudoneurotic or pseudopsychopathic or incipient or latent) adj2 schizophrenia)).mp.; 26. (brief reactive psychos?s or psychoses).mp.; 27. (prodrom$ and schizophren$).mp.; 28. first episode schizophrenia.mp.; 29. (major depression or depressive disorder).mp.; 30. (depression and (refractory or chronic or resistant)).mp.; 31. (schizotypal personality disorder or ((borderline or pseudoneurotic or pseudopsychopathic or incipient or latent) adj2 schizophrenia)).mp.; 32. (((bipolar or manic) adj (disorder or psychos?s or depression)) or mania*).mp.; 33. (OCD or anankastic personalit* or (obsessive compulsive adj (disorder* or neuros*)) or (obsessive-compulsive adj (disorder* or neuros*))).tw.; 34. ((chronic or acute or delayed onset) and (post-traumatic adj stress adj disorder*)).mp.; 35. ((posttraumatic or post-traumatic or post traumatic) adj (neuroses or disorder)).mp.; 36. ptsd.mp.; 37. ((anorexia adj nervosa*) or anorexia*).mp.; 38. ($tourette* adj (syndrome or disorder or disease)).mp.; 39. (tic adj disorder).mp.; 40. (multiple adj motor adj vocal adj tic adj disorder).mp.; 41. or/1-40; 42. (antipsychotics or antipsychotic agent* or antipsychotic drug*).mp.; 43. (tranquilizing agent* or tranquilizing drug*).mp.; 44. ((first or 1st) adj generation adj antipsychotic*).mp.; 45. 1649-18-9.rn.; 46. (Atsaperoni or Azaperon or Azaperona or Azaperone or Azaperonum or Eucalmyl or Fluoperidol or NSC 170976 or R 1929 or R-1929 or Sedaperone or Stresnil or Suicalm).mp.; 47. Butyrophenones.mp.; 48. 982-24-1.rn.; 49. (Chlorpenthixol or Clopenthixol or Clopenthixolum or Sordinol or Zuclopenthixol).mp.; 50. 50-53-3.rn.; 51. (Aminazin or Aminazine or Ampliactil or BC 135 or Chlorpromazine or Chlorpromazinum or Clorpromazina or Chlor-Promanyl or Chlorpromados or Chlorderazin or Chlorpromazin or Contomin or Elmarin or Esmind or Fenactil or Fenaktyl or HL 5746 or Largactil or Largactilothiazine or Megaphen or Largactyl or Klooripromatsiini or Klorpromazin or 6 Copin or Trinicalm Forte or Diminex Balsamico Juven Tos or Largatrex or Phenactyl or Proma or Promactil or Promazil or Prozil or Psychozine or Sanpron or Thorazine or Torazina or Wintermin).mp.; 52. 113-59-7.rn.; 53. (Chlorprothixene or Chlorprothixen or Chlorprothixenum or Chlorprotixen or Chlorprotixene or Clorprotisene or Clorprotixeno or Laractan or Paxyl or Rentovet or Taractan or Tarasan or Traquilan or Trictal or Truxal or Truxaletten or Truxil or Vetacalm).mp.; 54. Dibenzoxazepines.mp.; 55. 548-73-2.rn.; 56. (Dehydrobenzoperidol or Dehydrobenzperidol or Deidrobenzperidolo or Dridol or Droleptan or Droperidol or Droperidoli or Droperidolis or Droperidolum or Disifelit or Halkan or Inapsin or Inapsine or Inopsin or Thalamonal or Nilperidol or Properidol or Sintodril or Vetkalm).mp.; 57. 2709-56-0.rn.; 58. (Depixol or Emergil or Fluanxol or Flupenthixol or Flupentixol or Flupentixolum or Fluxanxol or Siplaril or Siplarol).mp.; 59. 69-23-8.rn.; 60. (Dapotum or Elinol or Flufenazina or Fluofenazine or Fluphenazine or Fluorphenazine or Fluphenazinum or Ftorphenazine or Moditen or Pacinol or Sevinol or Siqualon or Triflumethazine or Valamina or Vespazine).mp.; 61. 52-86-8.rn.; 62. (Aldo or Aloperidin or Aloperidol or Aloperidolo or Brootopon or Dozic or Einalon S or Eukystol or Fortunan or Galoperidol or Haldol or Halojust or Halopal or Haloperidol or Haloperidoli or Haloperidolis or Haloperidolu or Halopoidol or Serenace or Halopidol or Haloper or Halperon or Keselan or Lealgin or Linton or Mixidol or Peluces or Pernox or Serenace or Serenefl or Sernas or Sernel or Serenase or Ulcolind or Uliolind or Vesalium).mp.; 63. indoles.mp.; 64. 554-13-2.rn.; 65. (Camcolit or Candamide or Carbolith or Carbonic acid lithium salt or dilithium salt or Eskalith or Eutimin or Hypnorex or Limas or Lithium or Liskonum or Litard or Lithane or Lithea or Lithicarb or Lithinate or Lithionate or Lithotabs or Liticar or Manialith or Maniprex or Micalith or Neurolepsin or Pfi-lithium or Phasal or Plenur or Priadel or Quilonorm or Teralithe).mp.; 66. 1977-10-2.rn.; 67. (Cloxazepine or CL 62362 or Dibenzacepin or Dibenzoazepine or Hydrofluoride 3170 or LW 3170 or Lossapina or Loksapiini or Loxapin or Loxapina or Loxapine or Loxapinum or Oxilapine or Loxapac or SUM 3170 or Loxitane or Desconex).mp.; 68. 20229-30-5.rn.; 69. (Methiothepin or metitepine or Methiothepine or Methiothepin maleate or Metitepina or Metitepinum).mp.; 70. 60-99-1.rn.; 71. (Dedoran or Hirnamin or Hirnamine or Levomepromazine or Levomepromazin or Levomepromazina or Levopromazioni or Levomepromazinum or Levoprome or Levotomin or Mepromazine or Methotrimeprazine or Neurocil or Neozine or Nirvan or Nocinan or Momizan or Nozinane or Sinogan or Levolam or Nozinan or Sinogan or Tisercin or Veractil).mp.; 72. 7416-34-4.rn.; 73. (Molindona or Molindone or Molindonum).mp.; 74. 26864-56-2.rn.; 75. (Penfluridol or Penfluridolum or Semap).mp.; 76. 84-97-9.rn.; 77. (Pemazine Dimalonate or Peragal or Perazin or Perazine or Perazinum or Taxilan).mp.; 78. 58-39-9.rn.; 79. (Chlorperphenazine or Chlorpiprazine or Decentan or Emesinal or Etaperazin or Etaperazine or Ethaperazine or Etrafon or F-mon or Fentazin or Mutabon or Perfenazin or Perfenazina or Perfenazinas or Perfenazine or Perphenazin or Perphenazine or Perfenazyna or Perphenazinum or Pertriptyl or Sch 3940 or Thilatazin or Tranquisan or Trifaron or Trilafon or Trilifan or Triptafen or Triphenot or Triavil).mp.; 80. Phenothiazines.mp.; 81. 2062-78-4.rn.; 82. (Antalon or Opiran or Orap or Pimotsidi or Pimozid or Pimozida or Pimozidas or Pimozide or Pimozidum or Pimozyd).mp.; 83. 58-38-8.rn.; 84. (Apo-Prochlorazine or Capazine or Chlormeprazine or Compazine or Compro or Dhaperazine or Emelent or Kronocin or Nipodal or Novamin or Nu-Prochlor or Meterazin or Meterazine or Mitil or Prochlorpemazine or Prochlorperazinum or Proclorperazina or Prochlorperazine or Proklooriperatsiini or Proklorperazin or Prorazin or Phenothiazine or Seratil or Stemetil or Tementil or Temetid).mp.; 85. 58-40-2.rn.; 86. (Ampazine or Berophen or Esparin or Liranol or Neo-Hibernex or Prazin or Sparine or Sinophenin or Promazine hydrochloride or Protactyl or Promatsiini or Promazin or Promazine or Promazinum or Propazinum or Prazine or Promwill or Protactyl or Romtiazin or Sinophenin or Talofen or Talofen or Tomil or Verophen).mp.; 87. 84225-95-6.rn.; 88. (raclopride or racloprida or raclopridum or rakloprid or raklopridl).mp.; 89. 749-02-0.rn.; 90. (E 525 or Espiperona or Spiperone or Spiperonum or Spiroperidol or Spiropitan).mp.; 91. 50-52-2.rn.; 92. (Aldazine or Dazithin or Detril or Elperil or Mallorol or Malloryl or Melleril or Meleril or Mellaril or Mellerets or Mellerette or Melleretten or Melleril or Sonapax or Thioridazin or Thioridazine or Thioridazinum or Tioridatsiini or Tioridazin or Tioridazina or Tioridazinas).mp.; 93. 5591-45-7.rn.; 94. (Navane or Navaron or Orbinamon or Thiothixene or Tiotikseeni or Tiotixen or Tiotixeno or Tiotixenum or Thixit or Tiotixene).mp.; 95. Thioxanthenes.mp.; 96. 51012-32-9.rn.; 97. (Betaprid or Delpral or Doparid or Etiles or Equilium or Italiprid or Luxoben or Normagit or Porfanil or Sereprid or Tiacob or Tiapridal or Tiapride).mp.; 98. 749-13-3.rn.; 99. (Flumoperone or Psicoperidol or Psychoperidol or Trifluperidol or Trifluperidoli or Trifluperidolum or Triperidol or Trisedil or Trisedyl).mp.; 100. 117-89-5.rn.; 101. (Cuait D or Cuait N or eskazine or flupazine or Jatrosom or Jalonac or Parstelin or Parmodalin or stelazine or Stelabid or Stelapar or Sycot or Terfluzine or Trifluoperazine or Trifluoperazini Hydrochloridum or triftazin or Trinicalm Forte or Trinicalm Plus).mp.; 102. 146-54-3.rn.; 103. (Adazine or Fluopromazine or Phenothiazine or Psyquil or Siquil or Triflupromazina or Triflupromazine or Trifluopromazine or Vesprin or Vetame).mp.; 104. 53772-83-1.rn.; 105. (Cisordinol or Clopixol or Ciatyl-Z or Clopenthixol or Clopentixol or Sedanxol or Zuclopenthixolum or Zuclopentixol or Zuclopenthixol or Zuklopentixol).mp.; 106. or/42-105; 107. atypical antipsychotic*.mp.; 108. ((second or 2nd) adj generation adj antipsychotic*).tw.; 109. ((third or 3rd) adj generation adj antipsychotic*).tw.; 110. 71675-85-9.rn.; 111. (Aminosultopride or Amisulprida or Amisulpride or Amisulpridum or Solian or Sulpitac).mp.; 112. 129722-12-9.rn.; 113. (Abilitat or Abilify or Aripiprazole or Discmelt or OPC 31 or OPC 14597).mp.; 114. 65576-45-6.rn.; 115. (Asenapine or EINECS 265-829-4).mp.; 116. 132810-10-7.rn.; 117. (Blonserin or AD 5423).mp.; 118. 2058-52-8.rn.; 119. (Clothiapine or Clotiapina or Clotiapine or Clotiapinum or Dibenzothiazepine or Etumina or Etumine or Entumin or Etomine or Entumine or HF 2159 or LW 2159 or “BRN 0568276”).mp.; 120. 5786-21-0.rn.; 121. (Clozapin or Clozapina or Clozapine or Clozapinum or Clorazil or Clozaril or FazaClo or Leponex or LX 100-129 or Zaponex).mp.; 122. 12688-68-5.rn.; 123. Diazepine.mp.; 124. Dibenzazepines.mp.; 125. Dibenzothiazepines.mp.; 126. (54739-18-3 or 61718-82-9).rn.; 127. (dumirox or DU23000 or Fluvoxamina or fluvoxamine or Fluvoaminum or Fluvoxamine Maleate or Fevarin or Luvox or SME 3110).mp.; 128. 133454-47-4.rn.; 129. (Fanapt or Iloperidone or HP 873 or Zomaril).mp.; 130. Isoxazoles.mp.; 131. 5588-33-0.rn.; 132. (Calodal or Lidanar or Lidanil or Mesoridazina or Mesoridazine or Mesoridazinum or Serentil or THD-2-SO).mp.; 133. 89419-40-9.rn.; 134. (Clospipramine or Cremin or Mosapramina or Mosapramine).mp.; 135. 132539-06-1.rn.; 136. (Zyprexa or Olantsapiini or Olanzapin or Olanzapina or Olanzapine or Olanzapinum or Olansek or Zalasta or Zypadhera).mp.; 137. 144598-75-4.rn.; 138. (9-Hydroxyrisperidone or Invega or Paliperidone or R 76477 or RO76477).mp.; 139. 150915-41-6.rn.; 140. (lullan or perospirone*).mp.; 141. Piperidines.mp.; 142. Pirenzepine.mp.; 143. Pyrimidinones.mp.; 144. 111974-69-7.rn.; 145. (Co-Quetiapine or HSDB 7557 or Quetiapine or Seroquel).mp.; 146. Quinolones.mp.; 147. 80125-14-0.rn.; 148. (FLA 731 or Remoxiprida or Remoxipride or Remoxipridum).mp.; 149. 106266-06-2.rn.; 150. (Apexidone or Psychodal or Risperdal or Risperidona or Risperidone or Risperidonum or Risperin or Risperilept or Rispolin or Spiron).mp.; 151. 106516-24-9.rn.; 152. (Lu 23-174 or Sertindol or Sertindole or Serdolect or Sertindolum).mp.; 153. 15676-16-1.rn.; 154. (Abilit or Aiglonyl or Alimoral or Calmoflorine or Championyl or Darleton or Desmenat or Dobren or Dogmatil or Dogmatyl or Dolmatil or Eclorion or Eglonil or Eglonyl or Enimon or Equilid or Eusulpid or Fardalan or Fidelan or Guastil or Isnamide or Kylistro or Lisopiride or Mariastel or Meresa or Miradol or Mirbanil or Neogama or Normum or Nufarol or Omiryl or Omperan or Ozoderpin or Psicocen or Pyrkappl or Sernevin or Splotin or Stamonevrol or Sulparex or Sulpirid or Sulpirida or Sulpiride or Sulpiridum or Sulpor or Suprium or Sulpyrid or Trilan or Valirem or Zemorcon).mp.; 155. thiazoles.mp.; 156. 26615-21-4.rn.; 157. (Lodepin or Nipolept or Zotepina or Zotepine or Zotepinum or Zoleptil).mp.; 158. 146939-27-7.rn.; 159. (ziprasidone or zeldox).tw.; 160. or/107; 161. or/106,160; 162. infant.mp.; 163. ($child$ or adolescen$ or p*ediatric$).mp.; 164. or/162-163; 165. and/41,161,164; 166. limit 165 to yr=“1987 -Current”; 167. (young adj adult*).mp.; 168. ((college or university) adj2 (age or student*)).tw.; 169. or/167-168; 170. and/41,161,169; 171. limit 170 to yr=“1987 -Current”; 172. 166 or 171

Table A5 IPA–Ovid Version

OvidSP_-IPA 1980 to April Week 3 2010 | Searched: 16Apr10 Results: 322
1. (child adj1 development adj1 disorder*).mp.; 2. (asperger* adj1 (syndrome or disorder)).mp.; 3. (autism* or (autistic adj1 disorder*) or kanner* syndrome).mp.; 4. (atypical adj1 autism).mp.; 5. (((rett or retts) adj1 (sydrome or disorder)) or cerebroatrophic hyperammonemia*).mp.; 6. (child* adj2 schizophrenia*).mp.; 7. aggression.mp.; 8. ((psychomotor adj1 (agitation or restlessness or hyperactivity or excitement)) or akathisia).mp.; 9. ((sleep adj2 disorder*) or insomnia*).mp.; 10. ((mood or affective) adj1 disorder*).mp.; 11. (impulsive adj1 behavio?r).mp.; 12. (borderline adj1 personality adj1 disorder*).mp.; 13. (affective adj2 dysregulation).mp.; 14. (($behavioral adj2 dyscontrol) or (impulsive-behavioral adj2 deregulation)).mp.; 15. (mood adj2 lability).mp.; 16. (irritable or irritability).mp.; 17. (self-injurious behavio?r or self-mutilating behavio?r or self mutilation or self-destructive behavio?r or deliberate self-harm or parasuicide).mp.; 18. movement disorders.mp.; 19. ((attention adj deficit adj disorder) or hyperkinetic syndrome or adhd).mp.; 20. (conduct adj disorder*).mp.; 21. oppositional defiant disorder.mp.; 22. “Disruptive Behavior Disorder Not Otherwise Specified”.mp.; 23. (schizophrenia* or ((catatonic or disorganized or paranoid) adj schizophrenia)).mp.; 24. ((Psychotic or schizoaffective or schizophreniform) adj disorder).mp.; 25. (schizotypal personality disorder or ((borderline or pseudoneurotic or pseudopsychopathic or incipient or latent) adj2 schizophrenia)).mp.; 26. (brief reactive psychos?s or psychoses).mp.; 27. (prodrom$ and schizophren$).mp.; 28. first episode schizophrenia.mp.; 29. (major depression or depressive disorder).mp.; 30. (depression and (refractory or chronic or resistant)).mp.; 31. (schizotypal personality disorder or ((borderline or pseudoneurotic or pseudopsychopathic or incipient or latent) adj2 schizophrenia)).mp.; 32. (((bipolar or manic) adj (disorder or psychos?s or depression)) or mania*).mp.; 33. (OCD or anankastic personalit* or (obsessive compulsive adj (disorder* or neuros*)) or (obsessive-compulsive adj (disorder* or neuros*))).tw.; 34. ((chronic or acute or delayed onset) and (post-traumatic adj stress adj disorder*)).mp.; 35. ((posttraumatic or post-traumatic or post traumatic) adj (neuroses or disorder)).mp.; 36. ptsd.mp.; 37. ((anorexia adj nervosa*) or anorexia*).mp.; 38. ($tourette* adj (syndrome or disorder or disease)).mp.; 39. (tic adj disorder).mp.; 40. (multiple adj motor adj vocal adj tic adj disorder).mp.; 41. or/1-40; 42. (antipsychotics or antipsychotic agent* or antipsychotic drug*).mp.; 43. (tranquilizing agent* or tranquilizing drug*).mp.; 44. ((first or 1st) adj generation adj antipsychotic*).mp.; 45. 1649-18-9.rn.; 46. (Atsaperoni or Azaperon or Azaperona or Azaperone or Azaperonum or Eucalmyl or Fluoperidol or NSC 170976 or R 1929 or R-1929 or Sedaperone or Stresnil or Suicalm).mp.; 47. Butyrophenones.mp.; 48. 982-24-1.rn.; 49. (Chlorpenthixol or Clopenthixol or Clopenthixolum or Sordinol or Zuclopenthixol).mp.; 50. 50-53-3.rn.; 51. (Aminazin or Aminazine or Ampliactil or BC 135 or Chlorpromazine or Chlorpromazinum or Clorpromazina or Chlor-Promanyl or Chlorpromados or Chlorderazin or Chlorpromazin or Contomin or Elmarin or Esmind or Fenactil or Fenaktyl or HL 5746 or Largactil or Largactilothiazine or Megaphen or Largactyl or Klooripromatsiini or Klorpromazin or 6 Copin or Trinicalm Forte or Diminex Balsamico Juven Tos or Largatrex or Phenactyl or Proma or Promactil or Promazil or Prozil or Psychozine or Sanpron or Thorazine or Torazina or Wintermin).mp.; 52. 113-59-7.rn.; 53. (Chlorprothixene or Chlorprothixen or Chlorprothixenum or Chlorprotixen or Chlorprotixene or Clorprotisene or Clorprotixeno or Laractan or Paxyl or Rentovet or Taractan or Tarasan or Traquilan or Trictal or Truxal or Truxaletten or Truxil or Vetacalm).mp.; 54. Dibenzoxazepines.mp.; 55. 548-73-2.rn.; 56. (Dehydrobenzoperidol or Dehydrobenzperidol or Deidrobenzperidolo or Dridol or Droleptan or Droperidol or Droperidoli or Droperidolis or Droperidolum or Disifelit or Halkan or Inapsin or Inapsine or Inopsin or Thalamonal or Nilperidol or Properidol or Sintodril or Vetkalm).mp.; 57. 2709-56-0.rn.; 58. (Depixol or Emergil or Fluanxol or Flupenthixol or Flupentixol or Flupentixolum or Fluxanxol or Siplaril or Siplarol).mp.; 59. 69-23-8.rn.; 60. (Dapotum or Elinol or Flufenazina or Fluofenazine or Fluphenazine or Fluorphenazine or Fluphenazinum or Ftorphenazine or Moditen or Pacinol or Sevinol or Siqualon or Triflumethazine or Valamina or Vespazine).mp.; 61. 52-86-8.rn.; 62. (Aldo or Aloperidin or Aloperidol or Aloperidolo or Brootopon or Dozic or Einalon S or Eukystol or Fortunan or Galoperidol or Haldol or Halojust or Halopal or Haloperidol or Haloperidoli or Haloperidolis or Haloperidolu or Halopoidol or Serenace or Halopidol or Haloper or Halperon or Keselan or Lealgin or Linton or Mixidol or Peluces or Pernox or Serenace or Serenefl or Sernas or Sernel or Serenase or Ulcolind or Uliolind or Vesalium).mp.; 63. indoles.mp.; 64. 554-13-2.rn.; 65. (Camcolit or Candamide or Carbolith or Carbonic acid lithium salt or dilithium salt or Eskalith or Eutimin or Hypnorex or Limas or Lithium or Liskonum or Litard or Lithane or Lithea or Lithicarb or Lithinate or Lithionate or Lithotabs or Liticar or Manialith or Maniprex or Micalith or Neurolepsin or Pfi-lithium or Phasal or Plenur or Priadel or Quilonorm or Teralithe).mp.; 66. 1977-10-2.rn.; 67. (Cloxazepine or CL 62362 or Dibenzacepin or Dibenzoazepine or Hydrofluoride 3170 or LW 3170 or Lossapina or Loksapiini or Loxapin or Loxapina or Loxapine or Loxapinum or Oxilapine or Loxapac or SUM 3170 or Loxitane or Desconex).mp.; 68. 20229-30-5.rn.; 69. (Methiothepin or metitepine or Methiothepine or Methiothepin maleate or Metitepina or Metitepinum).mp.; 70. 60-99-1.rn.; 71. (Dedoran or Hirnamin or Hirnamine or Levomepromazine or Levomepromazin or Levomepromazina or Levopromazioni or Levomepromazinum or Levoprome or Levotomin or Mepromazine or Methotrimeprazine or Neurocil or Neozine or Nirvan or Nocinan or Momizan or Nozinane or Sinogan or Levolam or Nozinan or Sinogan or Tisercin or Veractil).mp.; 72. 7416-34-4.rn.; 73. (Molindona or Molindone or Molindonum).mp.; 74. 26864-56-2.rn.; 75. (Penfluridol or Penfluridolum or Semap).mp.; 76. 84-97-9.rn.; 77. (Pemazine Dimalonate or Peragal or Perazin or Perazine or Perazinum or Taxilan).mp.; 78. 58-39-9.rn.; 79. (Chlorperphenazine or Chlorpiprazine or Decentan or Emesinal or Etaperazin or Etaperazine or Ethaperazine or Etrafon or F-mon or Fentazin or Mutabon or Perfenazin or Perfenazina or Perfenazinas or Perfenazine or Perphenazin or Perphenazine or Perfenazyna or Perphenazinum or Pertriptyl or Sch 3940 or Thilatazin or Tranquisan or Trifaron or Trilafon or Trilifan or Triptafen or Triphenot or Triavil).mp.; 80. Phenothiazines.mp.; 81. 2062-78-4.rn.; 82. (Antalon or Opiran or Orap or Pimotsidi or Pimozid or Pimozida or Pimozidas or Pimozide or Pimozidum or Pimozyd).mp.; 83. 58-38-8.rn.; 84. (Apo-Prochlorazine or Capazine or Chlormeprazine or Compazine or Compro or Dhaperazine or Emelent or Kronocin or Nipodal or Novamin or Nu-Prochlor or Meterazin or Meterazine or Mitil or Prochlorpemazine or Prochlorperazinum or Proclorperazina or Prochlorperazine or Proklooriperatsiini or Proklorperazin or Prorazin or Phenothiazine or Seratil or Stemetil or Tementil or Temetid).mp.; 85. 58-40-2.rn.; 86. (Ampazine or Berophen or Esparin or Liranol or Neo-Hibernex or Prazin or Sparine or Sinophenin or Promazine hydrochloride or Protactyl or Promatsiini or Promazin or Promazine or Promazinum or Propazinum or Prazine or Promwill or Protactyl or Romtiazin or Sinophenin or Talofen or Talofen or Tomil or Verophen).mp.; 87. 84225-95-6.rn.; 88. (raclopride or racloprida or raclopridum or rakloprid or raklopridl).mp.; 89. 749-02-0.rn.; 90. (E 525 or Espiperona or Spiperone or Spiperonum or Spiroperidol or Spiropitan).mp.; 91. 50-52-2.rn.; 92. (Aldazine or Dazithin or Detril or Elperil or Mallorol or Malloryl or Melleril or Meleril or Mellaril or Mellerets or Mellerette or Melleretten or Melleril or Sonapax or Thioridazin or Thioridazine or Thioridazinum or Tioridatsiini or Tioridazin or Tioridazina or Tioridazinas).mp.; 93. 5591-45-7.rn.; 94. (Navane or Navaron or Orbinamon or Thiothixene or Tiotikseeni or Tiotixen or Tiotixeno or Tiotixenum or Thixit or Tiotixene).mp.; 95. Thioxanthenes.mp.; 96. 51012-32-9.rn.; 97. (Betaprid or Delpral or Doparid or Etiles or Equilium or Italiprid or Luxoben or Normagit or Porfanil or Sereprid or Tiacob or Tiapridal or Tiapride).mp.; 98. 749-13-3.rn.; 99. (Flumoperone or Psicoperidol or Psychoperidol or Trifluperidol or Trifluperidoli or Trifluperidolum or Triperidol or Trisedil or Trisedyl).mp.; 100. 117-89-5.rn.; 101. (Cuait D or Cuait N or eskazine or flupazine or Jatrosom or Jalonac or Parstelin or Parmodalin or stelazine or Stelabid or Stelapar or Sycot or Terfluzine or Trifluoperazine or Trifluoperazini Hydrochloridum or triftazin or Trinicalm Forte or Trinicalm Plus).mp.; 102. 146-54-3.rn.; 103. (Adazine or Fluopromazine or Phenothiazine or Psyquil or Siquil or Triflupromazina or Triflupromazine or Trifluopromazine or Vesprin or Vetame).mp.; 104. 53772-83-1.rn.; 105. (Cisordinol or Clopixol or Ciatyl-Z or Clopenthixol or Clopentixol or Sedanxol or Zuclopenthixolum or Zuclopentixol or Zuclopenthixol or Zuklopentixol).mp.; 106. or/42-105; 107. atypical antipsychotic*.mp.; 108. ((second or 2nd) adj generation adj antipsychotic*).tw.; 109. ((third or 3rd) adj generation adj antipsychotic*).tw.; 110. 71675-85-9.rn.; 111. (Aminosultopride or Amisulprida or Amisulpride or Amisulpridum or Solian or Sulpitac).mp.; 112. 129722-12-9.rn.; 113. (Abilitat or Abilify or Aripiprazole or Discmelt or OPC 31 or OPC 14597).mp.; 114. 65576-45-6.rn.; 115. (Asenapine or EINECS 265-829-4).mp.; 116. 132810-10-7.rn.; 117. (Blonserin or AD 5423).mp.; 118. 2058-52-8.rn.; 119. (Clothiapine or Clotiapina or Clotiapine or Clotiapinum or Dibenzothiazepine or Etumina or Etumine or Entumin or Etomine or Entumine or HF 2159 or LW 2159 or “BRN 0568276”).mp.; 120. 5786-21-0.rn.; 121. (Clozapin or Clozapina or Clozapine or Clozapinum or Clorazil or Clozaril or FazaClo or Leponex or LX 100-129 or Zaponex).mp.; 122. 12688-68-5.rn.; 123. Diazepine.mp.; 124. Dibenzazepines.mp.; 125. Dibenzothiazepines.mp.; 126. (54739-18-3 or 61718-82-9).rn.; 127. (dumirox or DU23000 or Fluvoxamina or fluvoxamine or Fluvoaminum or Fluvoxamine Maleate or Fevarin or Luvox or SME 3110).mp.; 128. 133454-47-4.rn.; 129. (Fanapt or Iloperidone or HP 873 or Zomaril).mp.; 130. Isoxazoles.mp.; 131. 5588-33-0.rn.; 132. (Calodal or Lidanar or Lidanil or Mesoridazina or Mesoridazine or Mesoridazinum or Serentil or THD-2-SO).mp.; 133. 89419-40-9.rn.; 134. (Clospipramine or Cremin or Mosapramina or Mosapramine).mp.; 135. 132539-06-1.rn.; 136. (Zyprexa or Olantsapiini or Olanzapin or Olanzapina or Olanzapine or Olanzapinum or Olansek or Zalasta or Zypadhera).mp.; 137. 144598-75-4.rn.; 138. (9-Hydroxyrisperidone or Invega or Paliperidone or R 76477 or RO76477).mp.; 139. 150915-41-6.rn.; 140. (lullan or perospirone*).mp.; 141. Piperidines.mp.; 142. Pirenzepine.mp.; 143. Pyrimidinones.mp.; 144. 111974-69-7.rn.; 145. (Co-Quetiapine or HSDB 7557 or Quetiapine or Seroquel).mp.; 146. Quinolones.mp.; 147. 80125-14-0.rn.; 148. (FLA 731 or Remoxiprida or Remoxipride or Remoxipridum).mp.; 149. 106266-06-2.rn.; 150. (Apexidone or Psychodal or Risperdal or Risperidona or Risperidone or Risperidonum or Risperin or Risperilept or Rispolin or Spiron).mp.; 151. 106516-24-9.rn.; 152. (Lu 23-174 or Sertindol or Sertindole or Serdolect or Sertindolum).mp.; 153. 15676-16-1.rn.; 154. (Abilit or Aiglonyl or Alimoral or Calmoflorine or Championyl or Darleton or Desmenat or Dobren or Dogmatil or Dogmatyl or Dolmatil or Eclorion or Eglonil or Eglonyl or Enimon or Equilid or Eusulpid or Fardalan or Fidelan or Guastil or Isnamide or Kylistro or Lisopiride or Mariastel or Meresa or Miradol or Mirbanil or Neogama or Normum or Nufarol or Omiryl or Omperan or Ozoderpin or Psicocen or Pyrkappl or Sernevin or Splotin or Stamonevrol or Sulparex or Sulpirid or Sulpirida or Sulpiride or Sulpiridum or Sulpor or Suprium or Sulpyrid or Trilan or Valirem or Zemorcon).mp.; 155. thiazoles.mp.; 156. 26615-21-4.rn.; 157. (Lodepin or Nipolept or Zotepina or Zotepine or Zotepinum or Zoleptil).mp.; 158. 146939-27-7.rn.; 159. (ziprasidone or zeldox).tw.; 160. or/107; 161. or/106,160; 162. infant.mp.; 163. ($child$ or adolescen$ or p*ediatric$).mp.; 164. or/162-163; 165. and/41,161,164; 166. limit 165 to yr=“1987 -Current”; 167. (young adj adult*).mp.; 168. ((college or university) adj2 (age or student*)).tw.; 169. or/167-168; 170. and/41,161,169; 171. limit 170 to yr=“1987 -Current”; 172. randomi$ed.ab. or randomly.tw. or random$.tw.; 173. (placebo or groups or trials).ab.; 174. $controlled clinical trial$.tw.; 175. or/172-174; 176. (cohort$ or longitudinal or retrospective or prospective or followup or case-control).tw.; 177. 175 or 176; 178. 165 and 177; 179. limit 178 to (english language and yr=“1987 -Current”); 180. 169 and 177; 181. limit 180 to (english language and yr=“1987 -Current”); 182. 179 or 181

Table A6 CINAHL–EBSCO Version

EBSCOHost_-CINAHL Plus with FullText 1987 to April Week 3 2010 | Searched: 23Feb10 Results: 233
S83=S69 or S82 S82=S64 AND S78 AND S66 Limiters - Age Groups: Infant, Newborn 0-1 month, Infant, 1-23 months, Child, Preschool 2-5 years, Child, 6-12 years, Adolescence, 13-18 years S81=S64 AND S78 AND S66 Limiters - English Language; Language: English S80=S64 AND S78 AND S66 Limiters - Publication Year from: 1987-2010 S79=S64 AND S78 AND S66 S78=S77 AND (S35 OR S48) S77=S70 or S71 or S72 or S73 or S74 or S75 or S76 S76=TX Tourette syndrome S75=(MH “Tourette Syndrome”) S74=TX anorexia S73=(MH “Anorexia Nervosa”) or (MH “Anorexia”) S72=TX ptsd S71=Post-traumatic stress and ( disorder OR disease OR syndrome ) S70=(MH “Stress Disorders, Post-Traumatic+”) S69= S64 and S65 and S66 Limiters - Language: English; Age Groups: Infant, Newborn 0-1 month, Infant, 1-23 months, Child, Preschool 2-5 years, Child, 6-12 years, Adolescence, 13-18 years S68=S64 and S65 and S66 Limiters - Publication Year from: 1987-2010; English Language S67=S64 and S65 and S66 S66=S53 OR S58 S65=S19 ANd (S35 or S48) S64=S59 or S60 or S61 or S62 or S63 S63=TX ($child$ OR adolescen$ OR p*ediatric$) S62=(MH “Pediatrics+”) S61=(MH “Adolescence+”) S60=(MH “Child+”) S59=(MH “Infant+”) S58=S54 or S55 or S56 or S57 S57=TX (cohort$ OR longitudinal OR retrospective OR prospective OR followup OR case-control) S56=(MH “Case Control Studies+”) S55=TX retrospective stud* S54=(MH “Prospective Studies+”) S53=S49 or S50 or S51 or S52 S52=(“Placebo”) or (MH “Placebos”) S51=TX randomi$ed S50=(MH “Cochrane Library”) S49=(MH “Clinical Trials+”) S48=S36 or S37 or S38 or S39 or S40 or S41 or S42 or S43 or S44 or S45 or S46 or S47 S47=(MH “Antiinfective Agents, Quinolone”) S46=(MH “Thiazoles+”) S45=Pirenzepine S44=(MH “Piperidines+”) S43=paliperidone S42=(MH “Aripiprazole”) S41=ziprasidone S40=(MH “Quetiapine”) S39=(MH “Olanzapine”) S38=(MH “Risperidone”) S37=(MH “Clozapine”) S36=atypical antipsychotics S35=S20 or S21 or S22 or S23 or S24 or S25 or S26 or S27 or S28 or S29 or S30 or S31 or S32 or S33 or S34 S34=(MH “Indoles”) S33=(MH “Antipsychotic Agents, Butyrophenone+”) S32=(MH “Antipsychotic Agents, Phenothiazine+”) S31=methotrimeprazine S30=(MH “Thioridazine”) S29=(MH “Trifluoperazine Hydrochloride”) S28=Thiothixene S27=perphenazine S26=molindone S25=loxapine S24=(MH “Haloperidol”) S23=(MH “Fluphenazine”) S22=(MH “Chlorpromazine”) S21=(MH “Tranquilizing Agents+”) S20=(MH “Antipsychotic Agents+”) S19=S1 or S2 or S3 or S4 or S5 or S6 or S7 or S8 or S9 or S10 or S11 or S12 or S13 or S14 or S15 or S16 or S17 or S18 S18=“depressive disorder” S17=(MH “Obsessive-Compulsive Disorder+”) S16=TX (refractory OR chronic OR resistant) and depression S15=(MH “Depression”) S14=(MH “Bipolar Disorder+”) S13=TX schizotypal personality disorder S12=“Oppositional defiant disorder” S11=TX atypical autism S10=(MH “Mental Disorders Diagnosed in Childhood+”) S9=(MH “Child Behavior Disorders+”) S8=(MH “Attention Deficit Hyperactivity Disorder”) S7=(MH “Movement Disorders+”) S6=(MH “Mental Retardation+”) S5=(MH “Schizophrenia, Childhood”) S4=(MH “Rett Syndrome”) S3=(MH “Autistic Disorder”) S2=(MH “Asperger Syndrome”) S1=(MH “Child Development Disorders, Pervasive+”

Table A7 SCOPUS–Elsevier

SCOPUS - Elsevier 1987 to April Week 3 2010 | Searched: 19Apr10 Results: 858
(((TITLE-ABS-KEY((infant) OR (*child*) OR (adolescen*) OR (p?ediatric) OR (young W/1 adult*) OR (college) OR (university))) AND ((TITLE-ABS-KEY((asperger sydrome) OR (autism OR autistic) OR (rett syndrome) OR (schizophrenia) OR (aggression) OR (sleep W/3 disorder) OR (insomnia) OR (agitation) OR (borderline personality disorder) OR (mood disorder) OR (mood lability) OR (self-injurious OR self-mutilating OR self-harm) OR (conduct disorder) OR (adhd) OR (attention deficit) OR (bipolar) OR (ocd) OR (obsessive-compulsive) OR (depression) OR (depressive disorder) OR (ptsd) OR (post-traumatic) OR (anorexia nervosa) OR (anorexia) OR (tic disorder) OR (tourette syndrome))) AND ((TITLE-ABS-KEY((typical W/2 antipsychotic*) OR (tranquiliz*) OR (neuroleptic) OR (first W/2 antipsychotic*) OR (azaperone) OR (butyrophenones) OR (clopenthixol) OR (chlorpromazine) OR (chlorprothixene) OR (dibenzoxazepines) OR (droperidol) OR (flupenthixol) OR (fluphenazine) OR (haloperidol) OR (indoles) OR (lithium) OR (loxapine) OR (methiothepin) OR (methotrimeprazine) OR (molindone) OR (penfluridol) OR (perazine) OR (perphenazine) OR (pimozide) OR (prochlorperazine) OR (promazine) OR (raclopride) OR (spiperone) OR (thioridazine) OR (thiothixene) OR (thioxanthenes) OR (tiapride) OR (trifluperidol) OR (trifluoperazine) OR (triflupromazine) OR (zuclopenthixol))) OR (TITLE-ABS-KEY((atypical W/2 antipsychotic*) OR (second W/2 antipsychotic*) OR (third W/2 antipsychotic*) OR (amisulpride) OR (aripiprazole) OR (asenapine) OR (blonanserin) OR (clotiapine) OR (clozapine) OR (diazepine) OR (dibenzazepines) OR (dibenzothiazepines) OR (fluvoxamine) OR (iloperidone) OR (isoxazoles) OR (mesoridazine) OR (mosapramine) OR (olanzapine) OR (paliperidone) OR (perospirone) OR (piperidines) OR (piperazines) OR (pirenzepine) OR (pyrimidinones) OR (quetiapine) OR (quinolones) OR (remoxipride) OR (risperidone) OR (sertindole) OR (sulpiride) OR (thiazoles) OR (zotepine) OR (ziprasidone))))) AND ((((SRCTYPE((randomized controlled trial) OR (randomised controlled trial) OR (controlled clinical trial)) OR TITLE((randomi?ed) OR (placebo) OR (drug therapy) OR (randomly) OR (trial) OR (groups)))) OR ((SRCTYPE((cohort stud*) OR (followup stud*) OR (longitudinal stud*) OR (prospective stud*) OR (retrospective stud*) OR (case-control stud*)) OR TITLE((cohort*) OR (longitudinal) OR (retrospective) OR (prospective) OR (followup) OR (case-control)) OR ABS((cohort*) OR (longitudinal) OR (retrospective) OR (prospective) OR (followup) OR (case-control))))))) AND (PUBYEAR AFT 1986 AND LANGUAGE(english))) AND NOT (((((TITLE-ABS-KEY((asperger sydrome) OR (autism) OR (rett syndrome) OR (schizophrenia) OR (mental retardation) OR (conduct disorder) OR (adhd) OR (attention deficit disorder) OR (bipolar) OR (ocd) OR (obsessive-compulsive) OR (depression) OR (ptsd) OR (post-traumatic) OR (anorexia nervosa) OR (anorexia) OR (tourette syndrome))) AND ((TITLE-ABS-KEY((antipsychotic*) OR (tranquiliz*) OR (chloropromazine) OR (fluphenazine) OR (haloperidol) OR (loxapine) OR (molindone) OR (perphenazine) OR (thiothixene) OR (trifluoperazine) OR (thioridazine) OR (methotrimeprazine) OR (phenothiazine) OR (butyrophenones) OR (thioxanthenes) OR (dibenzoxazepines) OR (indoles))) OR (TITLE-ABS-KEY((atypical antipsychotic*) OR (clozapine) OR (risperidone) OR (olanzapine) OR (quetiapine) OR (ziprasidone) OR (aripiprazole) OR (paliperidone) OR (isoxazoles) OR (dibenzothiazepines) OR (piperazines) OR (thiazoles) OR (quinolones))))) AND (SRCTYPE((randomized controlled trial) OR (randomised controlled trial) OR (controlled clinical trial)) OR TITLE((randomi?ed) OR (placebo) OR (drug therapy) OR (randomly) OR (trial) OR (groups)))) OR (((TITLE-ABS-KEY((asperger sydrome) OR (autism) OR (rett syndrome) OR (schizophrenia) OR (mental retardation) OR (conduct disorder) OR (adhd) OR (attention deficit disorder) OR (bipolar) OR (ocd) OR (obsessive-compulsive) OR (depression) OR (ptsd) OR (post-traumatic) OR (anorexia nervosa) OR (anorexia) OR (tourette syndrome))) AND ((TITLE-ABS-KEY((antipsychotic*) OR (tranquiliz*) OR (chloropromazine) OR (fluphenazine) OR (haloperidol) OR (loxapine) OR (molindone) OR (perphenazine) OR (thiothixene) OR (trifluoperazine) OR (thioridazine) OR (methotrimeprazine) OR (phenothiazine) OR (butyrophenones) OR (thioxanthenes) OR (dibenzoxazepines) OR (indoles))) OR (TITLE-ABS-KEY((atypical antipsychotic*) OR (clozapine) OR (risperidone) OR (olanzapine) OR (quetiapine) OR (ziprasidone) OR (aripiprazole) OR (paliperidone) OR (isoxazoles) OR (dibenzothiazepines) OR (piperazines) OR (thiazoles) OR (quinolones))))) AND (SRCTYPE((cohort stud*) OR (followup stud*) OR (longitudinal stud*) OR (prospective stud*) OR (retrospective stud*) OR (case-control stud*)) OR TITLE((cohort*) OR (longitudinal) OR (retrospective) OR (prospective) OR (followup) OR (case-control)) OR ABS((cohort*) OR (longitudinal) OR (retrospective) OR (prospective) OR (followup) OR (case-control))))) AND (TITLE-ABS-KEY((infant) OR (*child*) OR (adolescen*) OR (p?ediatric)))) AND (LIMIT-TO(DOCTYPE, “ar”) OR LIMIT-TO(DOCTYPE, “cp”) OR LIMIT-TO(DOCTYPE, “ip”) OR LIMIT-TO(DOCTYPE, “ar”)) AND (LIMIT-TO(EXACTKEYWORD, “Human”) AND LIMIT-TO(DOCTYPE, “ar”) OR LIMIT-TO(DOCTYPE, “cp”) OR LIMIT-TO(DOCTYPE, “ip”)) AND (LIMIT-TO(LANGUAGE, “English”) AND LIMIT-TO(DOCTYPE, “ar”) OR LIMIT-TO(DOCTYPE, “cp”) OR LIMIT-TO(DOCTYPE, “ip”)) AND (LIMIT-TO(PUBYEAR, 2010) OR LIMIT-TO(PUBYEAR, 2009) OR LIMIT-TO(PUBYEAR, 2008) OR LIMIT-TO(PUBYEAR, 2007) OR LIMIT-TO(PUBYEAR, 2006) OR LIMIT-TO(PUBYEAR, 2005) OR LIMIT-TO(PUBYEAR, 2004) OR LIMIT-TO(PUBYEAR, 2003) OR LIMIT-TO(PUBYEAR, 2002) OR LIMIT-TO(PUBYEAR, 2001) OR LIMIT-TO(PUBYEAR, 2000) OR LIMIT-TO(PUBYEAR, 1999) OR LIMIT-TO(PUBYEAR, 1998) OR LIMIT-TO(PUBYEAR, 1997) OR LIMIT-TO(PUBYEAR, 1996) OR LIMIT-TO(PUBYEAR, 1995) OR LIMIT-TO(PUBYEAR, 1994) OR LIMIT-TO(PUBYEAR, 1993) OR LIMIT-TO(PUBYEAR, 1992) OR LIMIT-TO(PUBYEAR, 1991) OR LIMIT-TO(PUBYEAR, 1990) OR LIMIT-TO(PUBYEAR, 1989) OR LIMIT-TO(PUBYEAR, 1988) OR LIMIT-TO(PUBYEAR, 1987) AND LIMIT-TO(DOCTYPE, “ar”) OR LIMIT-TO(DOCTYPE, “cp”) OR LIMIT-TO(DOCTYPE, “ip”)) AND (LIMIT-TO(EXACTKEYWORD, “Human”) OR LIMIT-TO(EXACTKEYWORD, “Adolescent”) OR LIMIT-TO(EXACTKEYWORD, “Child”) OR LIMIT-TO(EXACTKEYWORD, “School child”) OR LIMIT-TO(EXACTKEYWORD, “Child, Preschool”) AND LIMIT-TO(DOCTYPE, “ar”) OR LIMIT-TO(DOCTYPE, “cp”) OR LIMIT-TO(DOCTYPE, “ip”)) AND (LIMIT-TO(LANGUAGE, “English”) AND LIMIT-TO(DOCTYPE, “ar”) OR LIMIT-TO(DOCTYPE, “cp”) OR LIMIT-TO(DOCTYPE, “ip”)) AND (LIMIT-TO(SUBJAREA, “MEDI”) OR LIMIT-TO(SUBJAREA, “NEUR”) OR LIMIT-TO(SUBJAREA, “PSYC”) OR LIMIT-TO(SUBJAREA, “PHAR”) OR LIMIT-TO(SUBJAREA, “MULT”) AND LIMIT-TO(DOCTYPE, “ar”) OR LIMIT-TO(DOCTYPE, “cp”) OR LIMIT-TO(DOCTYPE, “ip”)) AND (EXCLUDE(SUBJAREA, “AGRI”) OR EXCLUDE(SUBJAREA, “ENVI”) OR EXCLUDE(SUBJAREA, “CHEM”) OR EXCLUDE(SUBJAREA, “DENT”) OR EXCLUDE(SUBJAREA, “VETE”) OR EXCLUDE(SUBJAREA, “MATH”) OR EXCLUDE(SUBJAREA, “ENGI”) OR EXCLUDE(SUBJAREA, “ECON”) AND LIMIT-TO(DOCTYPE, “ar”) OR LIMIT-TO(DOCTYPE, “cp”) OR LIMIT-TO(DOCTYPE, “ip”)) AND (LIMIT-TO(EXACTKEYWORD, “Human”) AND LIMIT-TO(DOCTYPE, “ar”)) AND (LIMIT-TO(EXACTKEYWORD, “Human”) OR LIMIT-TO(EXACTKEYWORD, “Human”)) AND (LIMIT-TO(LANGUAGE, “English”) AND LIMIT-TO(EXACTKEYWORD, “Human”)) AND (LIMIT-TO(EXACTKEYWORD, “Human”) AND LIMIT-TO(PUBYEAR, 2010) OR LIMIT-TO(PUBYEAR, 2009) OR LIMIT-TO(PUBYEAR, 2008) OR LIMIT-TO(PUBYEAR, 2007) OR LIMIT-TO(PUBYEAR, 2006) OR LIMIT-TO(PUBYEAR, 2005) OR LIMIT-TO(PUBYEAR, 2004) OR LIMIT-TO(PUBYEAR, 2003) OR LIMIT-TO(PUBYEAR, 2002) OR LIMIT-TO(PUBYEAR, 2001) OR LIMIT-TO(PUBYEAR, 2000) OR LIMIT-TO(PUBYEAR, 1999) OR LIMIT-TO(PUBYEAR, 1998) OR LIMIT-TO(PUBYEAR, 1997) OR LIMIT-TO(PUBYEAR, 1996) OR LIMIT-TO(PUBYEAR, 1995) OR LIMIT-TO(PUBYEAR, 1994) OR LIMIT-TO(PUBYEAR, 1993) OR LIMIT-TO(PUBYEAR, 1992) OR LIMIT-TO(PUBYEAR, 1991) OR LIMIT-TO(PUBYEAR, 1990) OR LIMIT-TO(PUBYEAR, 1989) OR LIMIT-TO(PUBYEAR, 1988) OR LIMIT-TO(PUBYEAR, 1987)) AND (LIMIT-TO(EXACTKEYWORD, “Human”) OR LIMIT-TO(EXACTKEYWORD, “Human”) OR LIMIT-TO(EXACTKEYWORD, “Adolescent”) OR LIMIT-TO(EXACTKEYWORD, “Child”) OR LIMIT-TO(EXACTKEYWORD, “School child”) OR LIMIT-TO(EXACTKEYWORD, “Child, Preschool”)) AND (LIMIT-TO(LANGUAGE, “English”) AND LIMIT-TO(EXACTKEYWORD, “Human”)) AND (LIMIT-TO(SUBJAREA, “MEDI”) OR LIMIT-TO(SUBJAREA, “NEUR”) OR LIMIT-TO(SUBJAREA, “PSYC”) OR LIMIT-TO(SUBJAREA, “PHAR”) OR LIMIT-TO(SUBJAREA, “MULT”) AND LIMIT-TO(EXACTKEYWORD, “Human”)) AND (EXCLUDE(SUBJAREA, “AGRI”) OR EXCLUDE(SUBJAREA, “ENVI”) OR EXCLUDE(SUBJAREA, “CHEM”) OR EXCLUDE(SUBJAREA, “DENT”) OR EXCLUDE(SUBJAREA, “VETE”) OR EXCLUDE(SUBJAREA, “MATH”) OR EXCLUDE(SUBJAREA, “ENGI”) OR EXCLUDE(SUBJAREA, “ECON”) AND LIMIT-TO(EXACTKEYWORD, “Human”)) AND (LIMIT-TO(LANGUAGE, “English”) AND LIMIT-TO(DOCTYPE, “ar”)) AND (LIMIT-TO(LANGUAGE, “English”) AND LIMIT-TO(EXACTKEYWORD, “Human”)) AND (LIMIT-TO(LANGUAGE, “English”) OR LIMIT-TO(LANGUAGE, “English”)) AND (LIMIT-TO(LANGUAGE, “English”) AND LIMIT-TO(PUBYEAR, 2010) OR LIMIT-TO(PUBYEAR, 2009) OR LIMIT-TO(PUBYEAR, 2008) OR LIMIT-TO(PUBYEAR, 2007) OR LIMIT-TO(PUBYEAR, 2006) OR LIMIT-TO(PUBYEAR, 2005) OR LIMIT-TO(PUBYEAR, 2004) OR LIMIT-TO(PUBYEAR, 2003) OR LIMIT-TO(PUBYEAR, 2002) OR LIMIT-TO(PUBYEAR, 2001) OR LIMIT-TO(PUBYEAR, 2000) OR LIMIT-TO(PUBYEAR, 1999) OR LIMIT-TO(PUBYEAR, 1998) OR LIMIT-TO(PUBYEAR, 1997) OR LIMIT-TO(PUBYEAR, 1996) OR LIMIT-TO(PUBYEAR, 1995) OR LIMIT-TO(PUBYEAR, 1994) OR LIMIT-TO(PUBYEAR, 1993) OR LIMIT-TO(PUBYEAR, 1992) OR LIMIT-TO(PUBYEAR, 1991) OR LIMIT-TO(PUBYEAR, 1990) OR LIMIT-TO(PUBYEAR, 1989) OR LIMIT-TO(PUBYEAR, 1988) OR LIMIT-TO(PUBYEAR, 1987)) AND (LIMIT-TO(LANGUAGE, “English”) AND LIMIT-TO(EXACTKEYWORD, “Human”) OR LIMIT-TO(EXACTKEYWORD, “Adolescent”) OR LIMIT-TO(EXACTKEYWORD, “Child”) OR LIMIT-TO(EXACTKEYWORD, “School child”) OR LIMIT-TO(EXACTKEYWORD, “Child, Preschool”)) AND (LIMIT-TO(LANGUAGE, “English”) OR LIMIT-TO(LANGUAGE, “English”)) AND (LIMIT-TO(LANGUAGE, “English”) AND LIMIT-TO(SUBJAREA, “MEDI”) OR LIMIT-TO(SUBJAREA, “NEUR”) OR LIMIT-TO(SUBJAREA, “PSYC”) OR LIMIT-TO(SUBJAREA, “PHAR”) OR LIMIT-TO(SUBJAREA, “MULT”)) AND (LIMIT-TO(LANGUAGE, “English”) AND EXCLUDE(SUBJAREA, “AGRI”) OR EXCLUDE(SUBJAREA, “ENVI”) OR EXCLUDE(SUBJAREA, “CHEM”) OR EXCLUDE(SUBJAREA, “DENT”) OR EXCLUDE(SUBJAREA, “VETE”) OR EXCLUDE(SUBJAREA, “MATH”) OR EXCLUDE(SUBJAREA, “ENGI”) OR EXCLUDE(SUBJAREA, “ECON”)) AND (EXCLUDE(SUBJAREA, “ENGI”) OR EXCLUDE(SUBJAREA, “VETE”) AND LIMIT-TO(DOCTYPE, “ar”)) AND (EXCLUDE(SUBJAREA, “ENGI”) OR EXCLUDE(SUBJAREA, “VETE”) AND LIMIT-TO(EXACTKEYWORD, “Human”)) AND (LIMIT-TO(LANGUAGE, “English”) AND EXCLUDE(SUBJAREA, “ENGI”) OR EXCLUDE(SUBJAREA, “VETE”)) AND (EXCLUDE(SUBJAREA, “ENGI”) OR EXCLUDE(SUBJAREA, “VETE”) AND LIMIT-TO(PUBYEAR, 2010) OR LIMIT-TO(PUBYEAR, 2009) OR LIMIT-TO(PUBYEAR, 2008) OR LIMIT-TO(PUBYEAR, 2007) OR LIMIT-TO(PUBYEAR, 2006) OR LIMIT-TO(PUBYEAR, 2005) OR LIMIT-TO(PUBYEAR, 2004) OR LIMIT-TO(PUBYEAR, 2003) OR LIMIT-TO(PUBYEAR, 2002) OR LIMIT-TO(PUBYEAR, 2001) OR LIMIT-TO(PUBYEAR, 2000) OR LIMIT-TO(PUBYEAR, 1999) OR LIMIT-TO(PUBYEAR, 1998) OR LIMIT-TO(PUBYEAR, 1997) OR LIMIT-TO(PUBYEAR, 1996) OR LIMIT-TO(PUBYEAR, 1995) OR LIMIT-TO(PUBYEAR, 1994) OR LIMIT-TO(PUBYEAR, 1993) OR LIMIT-TO(PUBYEAR, 1992) OR LIMIT-TO(PUBYEAR, 1991) OR LIMIT-TO(PUBYEAR, 1990) OR LIMIT-TO(PUBYEAR, 1989) OR LIMIT-TO(PUBYEAR, 1988) OR LIMIT-TO(PUBYEAR, 1987)) AND (EXCLUDE(SUBJAREA, “ENGI”) OR EXCLUDE(SUBJAREA, “VETE”) AND LIMIT-TO(EXACTKEYWORD, “Human”) OR LIMIT-TO(EXACTKEYWORD, “Adolescent”) OR LIMIT-TO(EXACTKEYWORD, “Child”) OR LIMIT-TO(EXACTKEYWORD, “School child”) OR LIMIT-TO(EXACTKEYWORD, “Child, Preschool”)) AND (LIMIT-TO(LANGUAGE, “English”) AND EXCLUDE(SUBJAREA, “ENGI”) OR EXCLUDE(SUBJAREA, “VETE”)) AND (EXCLUDE(SUBJAREA, “ENGI”) OR EXCLUDE(SUBJAREA, “VETE”) OR LIMIT-TO(SUBJAREA, “MEDI”) OR LIMIT-TO(SUBJAREA, “NEUR”) OR LIMIT-TO(SUBJAREA, “PSYC”) OR LIMIT-TO(SUBJAREA, “PHAR”) OR LIMIT-TO(SUBJAREA, “MULT”)) AND (EXCLUDE(SUBJAREA, “ENGI”) OR EXCLUDE(SUBJAREA, “VETE”) OR EXCLUDE(SUBJAREA, “AGRI”) OR EXCLUDE(SUBJAREA, “ENVI”) OR EXCLUDE(SUBJAREA, “CHEM”) OR EXCLUDE(SUBJAREA, “DENT”) OR EXCLUDE(SUBJAREA, “VETE”) OR EXCLUDE(SUBJAREA, “MATH”) OR EXCLUDE(SUBJAREA, “ENGI”) OR EXCLUDE(SUBJAREA, “ECON”))

Table A8 ProQuest Dissertations International

ProQuest Dissertations International 1987 to February Week 3 2010 | Searched: 26Feb10 Results: 13
((asperger) OR (autistic disorder) OR autism OR schizophrenia OR (bipolar disorder) OR (depression) OR (bipolar disorder) OR (obsessive-compulsive) OR (post-traumatic) OR (anorexia nervosa) OR anorexia) AND (antipsychotics ) AND (child OR adolescent OR pediatric OR infant) AND PDN(>1/1/1987) AND PDN(<12/31/2010)

Table A9 TOXLINE (TOXNET)

TOXLINE (TOXNET) 1987 to February Week 3 2010 | Searched: 26Feb10 Results: 12
( [na] ( antipsychotics OR antipsychotic agents ) AND ( ( asperger OR asperger syndrome ) OR ( autism OR autistic disorder ) OR bipolar OR obsessive-compulsive OR ( adhd OR attention deficit disorder with hyperactivity ) OR ( anorexia ) OR post-traumatic OR ( schizophrenia ) ) AND ( ( children OR child ) OR ( infant ) OR ( adolescent ) OR ( child ) ) ) AND 1987:2010 [yr] AND ( eng [la] )

Table A10 ClinicalTrials.gov and WHO

ClinicalTrials.gov 1987 to February Week 3 2010 | Searched: 23Feb10 Results: 200
((asperger) OR (autistic disorder) OR autism OR schizophrenia OR (bipolar disorder) OR (depression) OR (bipolar disorder) OR (obsessive-compulsive) OR (post-traumatic) OR (anorexia nervosa) OR anorexia) AND (antipsychotics ) AND (child OR adolescent OR pediatric OR infant) AND PDN(>1/1/1987) AND PDN(<12/31/2010)