# Appendixes

Appendix A Literature Search Strings

Appendix B Review Forms

Appendix C Methodological Quality of Studies Included in the Review

Appendix D Evidence Table

Appendix E List of Excluded Studies and Unobtained Studies