# Acronyms and Abbreviations

ABC: Aberrant Behavior Checklist
ADHD: Attention deficit hyperactivity disorder
AHRQ: Agency for Healthcare Research and Quality
BMI: Body mass index
BPRS: Brief Psychiatric Rating Scale
CARS: Childhood Autism Rating Scale
CDRS: Children's Depression Rating Scale
CGAS: Children's Global Assessment Scale
CGI: Clinical Global Impressions Scale
CGI–BP: Clinical Global Impressions–Bipolar
CGI–I: Clinical Global Impressions–Improvement
CGI–S: Clinical Global Impressions–Severity
CI: Confidence interval
CPRS: Children's Psychiatric Rating Scale
CSQ: Caregiver Strain Questionnaire
(C)YBOCS: (Children's) Yale-Brown Obsessive Compulsive Scale
DSM: Diagnostic and Statistical Manual of Mental Disorders
EPC: Evidence-based Practice Center
FDA: U.S. Food and Drug Administration
FGA: First-generation antipsychotic
IQR: Interquartile range
MD: Mean difference
N: Number
NCBRF: Nisonger Child Behavior Rating Form
NRCT: Nonrandomized controlled trial
OAS: Overt Aggression Scale
PANSS: Positive and Negative Syndrome Scale
RCT: Randomized controlled trial
RR: Relative risk
SANS: Scale for the Assessment of Negative Symptoms
SGA: Second-generation antipsychotic
VAS: Visual analog scale
YGTSS: Yale Global Tic Severity Scale
YMRS: Young Mania Rating Scale