# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Kenneth Bond (data extraction, quality assessment, and copy editing), Tamara Durec (peer review of literature search strategies), and Andrea Milne (data extraction, quality assessment, and table of outcome measures). We thank Christine Ha, Elizabeth Sumamo, and Kai Wong for help in screening the grey literature.