# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design and/or methodologic approaches do not necessarily represent the views of individual technical and content experts.

Michel Boucher, B.Pharm., M.Sc., RPh

Canadian Agency for Drugs and Technologies in Health

Ottawa, Ontario, Canada

Penney Cowan

American Chronic Pain Association

Rocklin, CA

David Graham, M.D.

US Food and Drug Administration

Silver Spring, MD

Loren Laine, M.D.

Keck School of Medicine

University of Southern California

Los Angeles, CA

Alan Rosenberg, M.D.

WellPoint Inc.

Chicago, IL

James Scheiman, M.D.

University of Michigan

Ann Arbor, MI

Maria Suarez-Almazor, M.D.

M.D. Anderson Cancer Center

Houston, TX