# Peer Reviewers

Penney Cowan

Executive Director and Founder

American Chronic Pain Association

Marc C. Hochberg, M.D., M.P.H.

Professor of Medicine and Epidemiology and Preventive Medicine

Head, Division of Rheumatology & Clinical Immunology

University of Maryland School of Medicine

Loren A. Laine, M.D.

Professor of Medicine

University of Southern California

Lara Maxwell

Coordinator, Cochrane Musculoskeletal Group

University of Ottawa

James M. Scheiman, M.D.

Professor, Department of Internal Medicine

University of Michigan

Daniel Solomon, M.D., M.P.H.

Assistant Professor of Medicine

Harvard Medical School

Brigham and Women’s Hospital