# Evidence Tables: Oral NSAIDs

Oral NSAID Trials

Author Year | Subjects | Demographics (age, Gender, Race) | Comparison (mg) | | Number of Subjects | Duration (Weeks) | Aspirin Permitted? | Efficacy Measures | Withdrawals due to Adverse Events | | Other Outcomes | Run-in/Washout | Class Naïve Patients Only
Chan, 2007^235^ | Arthritis (OA, RA and others) | Mean age: 71 years 52% female | Celecoxib 200 | Esomeprazole 20 | 273 | 52 | No | PGA, pain | NR | NR | Combination therapy with PPI was more effective in preventing ulcers | NR/NR | No
Cheung, 2010^82^ | OA or RA | Age range:18–88 years Mean age= 51 years 83% Female Race: 100% Asian | Celecoxib 100 | Diclofenac 50 | 759 | 12 | Yes | Incidence of GI ulcers | 3% | 6% | Incidence of GI ulcer celecoxib vs. diclofenac 2.8% vs. 5.1%; p =0.083 | NR/NR | No
Dahlberg, 2009^52^ | Knee or hip osteoarthritis | Mean age: 71 years Female: 69% Race: NR | Celecoxib 200 | Diclofenac 50 | 925 | 52 | Unclear | Pain, Physician and patient PGA and adverse events | 27% | 31% | No difference | Unclear/NR | No
Emery, 2008^53^ | OA hip | Mean age: 64 years 46% Female Race: 99% White | Celecoxib 200 | Diclofenac 50 mg | 249 | 12 | Unclear | Patient and Physician GA | 10% | 15% | Improvement in GA with Celecoxib vs. Diclofenac | NR/10 days-2 weeks | No
Goei The, 1997^62^ | OA knee | Mean age: 71 years Female: 81.9% Race: NR | Meloxicam 7.5 | Diclofenac 100 | 258 | 6 | Yes | Pain during active movement, PGA, acetaminophen use | 3.9% | 2.3% | No difference, trend favored meloxicam | NR/7 day minimum | No
Goldstein, 2000^88^ | OA and RA with no ulcer on EGD | Mean age: 57 years Female: 57% White: 84% Black: 13% Hispanic: 4% | Celecoxib 200 | Naproxen 500 | 537 | 12 | Yes (included in study) | PGA, withdrawals | 7.0% | 9.0% | No difference in adverse event severity. | NR/NR | No
Goldstein, 2007^254^ | OA without history of ulcer taking low-dose ASA | Mean age: 56.7 years Female: 66% White: 72% Black: 13% Hispanic: 11% Asian: 2% Other: 2% | Celecoxib 200 | Naproxen 500 + Lansoprazole 30 | 1045 | 12 | Yes (included in study) | Joint pain, GI complications and GDU incidence at final visit | 6.3% | 6.6% | No difference | Unclear/NR | No
Goldstein 2010^253^, included two Phase III studies | H pylori negative patients with OA, RA, ankylosing spondylitis or other condition requiring daily NSAID therapy | Mean age: 60 years Female: 67% White: 86% Black: 12% Other: 2% | enteric-coated naproxen 500 mg and immediate-release esomeprazole 20 mg | Enteric-coated naproxen 500 | 438; 423 | 26 | Yes | Ulcer incidence, other harm related outcomes | 9.3%; 9.4% | 15.7% 14.2% | Enterica coded with PPI protective | Unclear/14 days | No
Hawkey, 1998^281^ (MELISSA) | OA hip, knee, hand, or spine | Mean age: 61 years Female: 67% Race: NR | Meloxicam 7.5 | Diclofenac 100 | 9323 | 4 | Unclear | Pain, PGA, withdrawals | 1.7% | 1.0% | No difference, trend slightly favored meloxicam | NR/washout 3 days | No
Hosie, 1996^64^ | OA hip or knee | Mean age: 64 years Female: 68% Race: NR | Meloxicam 7.5 | Diclofenac 100 | 336 | 24 | Unclear | Pain, quality of life | 4.0% | 4.2% | No difference | NR/washout 3 days | No
Hosie, 1997^65^ | OA hip or knee | Mean age: 65 years Female: 55% Race: NR | Meloxicam 15 | Piroxicam 20 | 455 | 24 | Unclear | Overall pain, pain on movement, joint stiffness, global efficacy and quality of life | 57.0% | 15.0% | No difference | NR/7 day minimum | No
Linden, 1996^66^ | OA hip | Mean age: 67 years Female: 63% Race: NR | Meloxicam 15 | Piroxicam 20 | 255 | 6 | Unclear | Pain, pain on active movement, global efficacy, withdrawals | 9.3% | 7.9% | No difference | NR/washout 3–7 days | No
Scheiman, 2006;^262^ Includes two similar RCT | At risk of ulcer (age 60 or greater or history of ulcer within past 5 yr) and taking NSAID for OA or RA | Mean age: 64 years Female: 72% Race: NR | COX-2 + esomeprazole 20 or 40 | COX-2 + placebo | 844; 585 | 26 | Yes | Related to ulcer development including pain and other symptoms | 4.2% 20 mg 8.3% 40 mg | 11% 20 mg 18% 40 mg | PPI reduced risk compared to placebo. COX-2 users: 16.5% placebo vs. 0.9% 20 mg esomeprazole (P < 0.001) non-selective NSAID: 17.1% placebo vs. 6.8% 20 mg esomeprazole (P <0.001). | NR/NR | No
Silverstein, 2000^52^ (CLASS) | OA and RA | Mean age: 60 years Female: 69% White: 88.2%; Black: 7.7%; Hispanic: 2.8%; Asian: 0.8% | Celecoxib 400 | Ibuprofen 800 or diclofenac 75 | 7968 | 24 | Yes | No efficacy measures reported except withdrawals | 18.4% | 20.6% | No difference | NR/NR | No
Valat, 2001^65^ | OA lumbar spine | Mean age: 58 years Female: 82% Race: NR | Meloxicam 7.5 | Diclofenac 100 | 229 | 2 | Unclear | Pain on motion | 0.0% | 0.0% | No difference | NR/washout 3–7 days | No
Wojtulewski, 1996^66^ | RA | Aged 18–75 years Gender and race: NR | Meloxicam 7.5 | Naproxen 750 | 379 | 24 | No | PGA, several others | 23.6% | 14.4% | No difference, trend favored naproxen | NR/washout 3–11 days | No

ASA = aspirin; CLASS = Celecoxib Long-term Arthritis Safety Study; COX = cyclo-oxygenase; EGD = esophagogastroduodenoscopy; GDU = gastroduodenal ulcer; GI = gastrointestinal; NA = not applicable; NSAID = nonsteroidal anti-inflammatory drug; OA = osteoarthritis; PPI = proton pump inhibitor; RA = rheumatoid arthritis RCT = randomized controlled trial; WOMAC = Western Ontario and McMaster Universities Osteoarthritis Index

Oral NSAID Systematic Reviews

Author Year | Aims | Time Period Covered | Eligibility Criteria | Number of Patients | Characteristics of Identified Articles: Study Designs | Characteristics of Identified Articles: Populations | Characteristis of Identified Articles: Interventions | Main Results | Subgroups | Adverse Events | Comments
Caldwell, 2006^111^ | To examine whether the increased risk of cardiovascular events with rofecoxib represents a class effect of COX-2 specific inhibitors (celecoxib). | Searches through April 2005 MEDLINE, Cochrane Database of Systematic Reviews, Cochrane Central Register of Controlled Trials, ACP Journal Club, Database of Abstracts of Review of Effects, EMBASE, FDA website, requested additional data from Pfizer (none provided) | RCTs of celecoxib of at least 6 weeks duration and reported serious cardiovascular thromboembolic events | 12,780 (6,859 randomized to celecoxib) | 6 RCTs: 3 celecoxib vs. placebo, 1 celecoxib vs. another NSAID, 1 celecoxib vs. another NSAID vs. placebo, 1 celecoxib vs. paracetamol | Osteoarthritis (2 trials) Mixed osteoarthritis or rheumatoid arthritis (1 trial) Prevention of colorectal carcinoma recurrence (2 trials) Prevention of Alzheimer’s disease (1 trial) | 2 trials 6 weeks in duration, 2 trials 52 weeks in duration, 1 trial 156 weeks in duration, 1 trial 145–161 weeks in duration | -- | -- | Celecoxib vs. placebo: Myocardial infarction (n=2574 vs. n=1247): RR 2.3 (1.0, 5.1); Cerebrovascular event (n=2775 vs. n=1447): RR 1.0 (0.51, 1.8); Cardiovascular death (n=2574 vs. n=1247): RR 1.06 (0.38, 3.0); Composite cardiovascular events (n=2775 vs. n=1447): RR 1.4 (0.91, 2.1); Celecoxib vs. placebo, diclofenac, ibuprofen, or paracetamol Myocardial infarction (n=6658 vs. n=5522): RR 1.9 (1.2, 3.1); Cerebrovascular event (n=6859 vs. n=5921): RR 0.73 (0.42, 1.3); Cardiovascular death (n=6561 vs. n=5428): RR 1.0 (0.52, 2.0); Composite cardiovascular events (n=6859 vs. n=5921): RR 1.2 (0.92, 1.6)
Chen, et al 2008^58^ | To review the clinical and cost effectiveness of COX-2s for OA and rheumatoid arthritis RA | Cochrane Library through Issue 4, 2003; Ovid MEDLINE 1966–October 2003; Ovid MEDLINE In-Process and Other Non-Indexed Citations November 4 and 11, 2003; EMBASE 1980–October 2003; EMEA and FDA websites | RCTs with duration of treatment ≥ 2 weeks; OA or RA population; COX-2 vs. placebo, nonselective NSAID or other COX-2 | Etodolac n=5,775 Meloxicam n=22,886 Celecoxib n=NR | Etodolac: 29 RCTs; etodolac vs. naproxen, piroxicam, diclofenac, indomethacin, tenoxicam, ibuprofen, nabumetone, nimesulide, placebo Meloxicam: 16 RCTs; meloxicam vs. diclofenac, piroxicam, nabumetone, naproxen nabumetone, placebo; 11 abstracts reporting adverse event outcomes also included in meta-analysis but not quality-rated Celecoxib: 40 RCT; celecoxib vs. naproxen, diclofenac, dexibuprofen, acetaminophen, ibuprofen, rofecoxib, lumiracoxib, placebo | OA (63 trials), RA (15 trials) or both (7 trials) | Etodolac 300–1000 mg/day vs. naproxen 750–1000 mg/day (10 studies), piroxicam 20 mg/day (7 studies), diclofenac 100–150 mg/day (4 studies), indomethacin 100–150 mg/day (2 studies); tenoxicam 20 mg/day (2 studies), nimesulide 200 mg/day (1 study), nabumetone 1500 mg/day (1 study), ibuprofen 2400 mg/day (1 study) Meloxicam 3.75–15 mg/day vs. diclofenac 100–150 mg/day (6 studies), piroxicam 20 mg/day (5 studies), nabumetone 1000 mg/day (2 studies), naproxen 750 mg/day (1 study) Celecoxib 80–800 mg/day vs. naproxen 1000 mg/day, diclofenac 100–150 mg/day, acetaminophen 4000 mg/day, ibuprofen 1000 mg/day (not all interventions and doses could be listed and number of studies for each intervention could not be accurately determined; information from some studies not reported) | [underlined: Etodolac vs. NSAIDs] Mean difference, pain score: 2.06 (CI −2.09 to 6.22) Mean difference, global efficacy: −0.08 (CI −0.25 to 0.09) Withdrawals due to lack of efficacy RR 1.00 (CI 0.85 to 1.19) [underlined: Meloxicam vs. NSAIDs] Mean difference, pain score: 1.7 (CI 0.8 to 2.7) Mean difference, global efficacy: −0.05 (CI −0.25 to 0.15) Withdrawals due to lack of efficacy RR 1.47 (CI 1.24 to 1.73) [underlined: Celecoxib vs. NSAIDs] Mean difference, pain score: −0.42 (CI −2.4 to 1.6) Mean difference, global efficacy: 0 (−0.05 to 0.03) ACR-20 RR 1.00 (CI 0.89 to 1.14) Withdrawals due to lack of efficacy RR 0.94 (CI 0.77 to 1.14) | [underlined: Etodolac vs. NSAIDs] No analysis; 1 trial reported higher AE incidence in patients >65 yrs in etodolac and placebo groups [underlined: Meloxicam vs. NSAIDs] No analysis; two studies reported lower AE rates in patients >65 yrs in meloxicam arms relative to piroxicam and diclofenac [underlined: Celecoxib vs. NSAIDs] Risk of POBs, concomitant low-dose aspirin use: comparative RR 2.82; p=0.138 Risk of PUBs, concomitant low-dose aspirin use: comparative RR 0.67; p=0.04 Risk of MI, concomitant low-dose aspirin use: comparative RR 2.24; p=0.121 | [underlined: Etodolac vs. NSAIDs] All-cause withdrawals RR 0.97 (CI 0.90 to 1.05) Withdrawals due to AEs RR 0.93 (CI 0.77 to 1.12) Withdrawals due to GI AEs RR 0.95 (CI 0.54 to 1.65) Any AE incidence RR 0.83 (CI 0.70 to 0.99) GI AE incidence RR 0.77 (CI 0.55 to 1.08) PUBs RR 0.32 (CI 0.15 to 0.71) POBs RR 0.39 (CI 0.12 to 1.24) [underlined: Meloxicam vs. NSAIDs] All-cause withdrawals RR 0.86 (CI 0.77 to 0.96) Withdrawals due to AEs RR 0.92 (CI 0.66 to 1.28) Withdrawals due to GI AEs RR 0.61 (CI 0.54 to 0.69) Any AE incidence RR 0.91 (CI 0.84 to 0.99) GI AE incidence RR 0.31 (CI 0.24 to 0.39) PUBs RR 0.53 (CI 0.29 to 0.97) POBs RR 0.56 (CI 0.27 to 1.15) MI RR 0.33 (CI 0.01 to 8.03) Serious CV events 0.99 (CI 0.06 to 15.9) [underlined: Celecoxib vs. NSAIDs] All-cause withdrawals RR 0.93 (CI 0.84 to 1.05) Withdrawals due to AEs RR 0.86 (CI 0.73 to 1.00) Withdrawals due to GI AEs RR 0.45 (CI 0.35 to 0.56) Any AE incidence RR 0.96 (CI 0.91 to 1.01) GI AE incidence RR 0.90 (CI 0.78 to 1.04) PUBs RR 0.55 (CI 0.40 to 0.76) POBs RR 0.57 (CI 0.35 to 0.95) MI RR 1.77 (CI 1.00 to 3.11) Serious CV events RR 0.99 (CI 0.54 to 1.79)
Kearney, 2006^121^ | To assess the effects of selective COX-2 inhibitors and traditional NSAIDs on the risk of vascular events | January 1966–April 2005 (MEDLINE and Embase) | RCTs at least 4 wks “scheduled treatment” of COX-2 vs. placebo or NSAID that reported serious CV events | 145,373 | only described as RCTs (n=138); either placebo (n=121) or active | Numerous indications, including: RA, OA, low back pain, ankylosing spondylitis, polyps and Alzheimer’s Disease. | Randomized trials that included a comparison of a selective COX-2 inhibitor versus placebo or a selective COX-2 inhibitor versus a traditional NSAID, of at least four weeks’ duration, with information on serious vascular events. 41 Celecoxib trials, 17 Etoricoxib trials, 12 Lumiracoxib trials, 14 Valdecoxib trials. | NA | No subgroup analysis | COX-2 vs. placebo short- and long-term studies: COX-2s associated with increase in rate of MI - 0.6%/yr vs. 0.3%/yr (RR 1.86 CI 95% 1.33 to 2.59, p=0.0003) RR or all vascular events increases to 1.45 (95% CI 1.12 to 1.80, p=0.0003) when only long-term (>1 yr) were analyzed. COX-2 vs. NSAID: Overall RR of any vascular event among heterogeneous studies 1.0%/yr vs. 0.9%/yr was 1.16 (CI 95% 0.97 to 1.38, p=0.1) | Quality of included studies not considered Of 121 placebo trials, nine were long-term. 2/3 of CV events occurred in long-term trials.
Lee, 2004^179^ | To compare efficacy and safety of recommended doses of NSAIDs, including Cox 2 inhibitors, vs. acetaminophen in the treatment of symptomatic hip and knee osteoarthritis | 1966 through February 2003 MEDLINE 1991 to 1st quarter 2003 EMBASE Drugs and Pharmacy database | Original clinical trials with direct comparisons of an NSAID with acetaminophen or paracetamol without combination with a nonnarcotic analgesic or narcotic agent. Duration of NSAID exposure ≥ 7 days. Sufficient analyzable data | 1252 | 7 clinical trials: 2 randomized active comparator trials without placebo arms, 2 randomized parallel-group double-blinded trials, 2 randomized crossover trials, and 1 randomized placebo-controlled double-blinded trial. | All trials included patients with knee OA, and 2 also included patients with hip OA. 71% were women. | 1 study compared acetaminophen to placebo, and 5 compared acetaminophen to NSAIDs. Acetaminophen dose ranged from 2600 mg/d (1 study) to 4000 mg/d (5 studies). Mean duration of trials was 22 weeks, with a range from 6 days to 2 years. If outlier study (104 weeks) removed, mean duration was 5.8 weeks. | Acetaminophen vs. placebo Based on 1 cross-over, double-blind RCT Improvement in rest pain: 16/22 (73%) vs. 2/22 (9%) Improvement in pain on motion:15/22 (68%) vs. 4/22 (18%) Physician global assessment: 20/21 (95%) vs. 1/21 (5%) Patient global assessment:10/10 (100%) vs. 1/10 (10%) Acetaminophen vs. NSAIDS : absolute values not available except for global assessment Rest pain and HAQ pain: NSAIDs superior to acetaminophen. Rest pain effect sizes measured by SMD: 0.32(95% CI, 0.08 to 0.56) and 0.34 (95% CI, 0.10 to 0.58). HAQ pain: 0.27 (95% CI, 0.05 to 0.48) and 0.24 (95% CI, 0.03 to 0.45). Pain on motion: SMDs not significant. Physical function: Neither 50 foot walk time nor HAQ showed significant differences between NSAIDs and acetaminophen. Group 1 (ibuprofen 2400 mg, Arthrotec, celecoxib, naproxen) Physician global assessment: 23/61 (38%) vs. 23/61 (38%) Patient global assessment: 37/94(39%) vs. 45/97(46%) Group 2 (ibuprofen 1200 mg, Arthrotec, rofecoxib 25 mg, naproxen) Physician global assessment: 23/61(38%) vs. 27/62 (44%) Patient global assessment: 37/94 (39%) vs. 57/95 (60%) Group 3 (ibuprofen 1200 mg, Arthrotec, rofecoxib 12.5 mg, naproxen) Physician global assessment: not reported Patient global assessment: 37/94 (39%) vs. 54/96 (56%) | Not reported | Acetaminophen vs. Placebo No participant removed from study due to side effects. Withdrawals/total number of AEs: 10/25 (40%) acetaminophen vs. 8/25 (32%) placebo. Acetaminophen vs. NSAIDS Group 1: Total number of AEs: 164/360 (46%) vs. 179/353 (51%). Withdrawals due to toxicity: 35/448 (8%) vs. 38/443 (8%). Group 2: Total number of AEs: 164/360 (46%) vs. 170/352 (48%). Withdrawals due to toxicity: 35/448 (8%) vs. 38/442 (9%). Group 3: Total number of AEs: 164/360 (46%) vs. 180/353 (51%). Withdrawals due to toxicity: 35/448 (8%) vs. 39/443 (9%). GI events, acetaminophen vs. traditional NSAIDs 10/148 (7%) vs. 38/212 (18%) GI events, acetaminophen vs. Coxib NSAIDs 16/94 (17%) vs. 47/288 (16%) GI withdrawals, acetaminophen vs. traditional NSAIDS 9/151 (6%) vs. 24/213 (11%) | Results do not account for differences in baseline pain Most trials had short follow-up periods. 1 included trial was an abstract only (Altman 1999)
Moore, 2005^51^ | The objective was to improve understanding of adverse events occurring with celecoxib in the treatment of osteoarthritis and rheumatoid arthritis. | Trials completed by December 2003 Pfizer supplied company clinical trial reports | RCTs, 2 weeks or longer in duration, any dose of celecoxib and any comparator, in osteoarthritis or rheumatoid arthritis | 38,746 (22,192 randomized to celecoxib) | 31 RCTs: 12 celecoxib vs. another NSAID, 5 celecoxib vs. placebo, 14 celecoxib vs. another NSAID vs. placebo | Osteoarthritis (21 trials) Rheumatoid arthritis (4 trials) Mixed osteoarthritis or rheumatoid arthritis (6 trials) | All trials 2–12 weeks in duration, with the exception of 1 trial 24 weeks (n=655), 1 trial 52 weeks (n=7968) | -- | -- | Myocardial infarction Celecoxib vs. placebo: 0.12% vs. 0.07%, RR not reported (10 events, n=9315) Celecoxib vs. paracetamol: RR not reported (0 events, n=1056) Celecoxib 200–400 mg vs. NSAID to maximum daily dose: 0.15% vs. 0.04%, RR 1.9 (95% CI 0.87 to 4.1) (23 events, n=21,818) Celecoxib any dose vs. NSAID to maximum daily dose: 0.22% vs. 0.14%, RR 1.6 (95% CI 0.93 to 2.6) (56 events, n=30,220) Celecoxib any dose vs. any active comparator: 0.19% vs. 0.13%, RR 1.4 (95% CI 0.88 to 2.2) (57 events, n=34,174) Celecoxib any dose vs. any comparator: 0.18% vs. 0.12%, RR 1.4 (95% CI 0.88 to 2.2) (59 events, n=38,499) Celecoxib any dose vs. any noncoxib: 0.19% vs. 0.12%, RR 1.4 (95% CI 0.88 to 2.2) (57 events, n=36,316)
Niculescu 2009^170^ | To compare the (GI) tolerability of celecoxib and NSAIDs at approved doses in patients with common musculoskeletal conditions. | Pfizer Corporate Clinical Trials Registry available to October 31 2004. | RCTs parallel-group studies; with at least one treatment group receiving celecoxib at a total daily dose of ≥ 200mg or higher; at least one placebo or active comparator (e.g., NSAID s) group; planned duration ≥ 2 weeks. | 21 studies involving 26,574 patients | 21 RCTs. Duration ranged from 6 wks to 1 year. 6 had duration of 6 wks, 13 lasted for 12 wks, 1 lasted for 24 wks and 1 for 52 wks. | Patients had a mean age of 60.7 years, 72.6% were female, (72.7%) were white. 85.9% of patients in these RCTs had OA. | OA/RA: 6993/667 patients received celecoxib total daily dose 200 mg; 5542/950 patients received celecoxib total daily dose 400 mg; 2280/516 patients received naproxen; 408/91 patients who received ibuprofen, and 5010/633 patients who received diclofenac. | Safety of Celecoxib vs. drug; RR (95% CI); 1. Naproxen; Abdominal pain: 1.42 (1.23–1.63); Dyspepsia: 1.72 (1.51–1.95); Flatulence: 2.06 (1.64–2.60); Nausea: 2.00 (1.68–2.39); 2. Ibuprofen; Abdominal pain: 1.19 (1.04–1.36); Dyspepsia: 1.71 (1.30–2.24); Flatulence: 1.48 (0.83–2.62); Nausea: 2.23 (1.58–3.16); 3. Diclofenac; Abdominal pain: 1.38 (1.00–1.89); Dyspepsia: 1.07 (0.95–1.21); Flatulence: 1.36 (1.10–1.69); Nausea: 1.17 (0.98–1.38); 4. Pooled NSAIDs; Abdominal pain: 1.72 (1.51–1.95); Dyspepsia: 1.07 (0.95–1.21); Flatulence: 1.17 (0.98–1.38) | -- | Significant greater proportion of patients treated with naproxen (24.3%), ibuprofen (24.2%), or diclofenac (19.9%) experienced a tolerability-related GI AE (combined incidence of abdominal pain, dyspepsia, nausea and flatulence)
Rostom, 2002^263^ | To determine the frequency of lab and clinical hepatic side effects associated with NSAID use. | MEDLINE, EMBASE and Cochrane through January 2004. | RCTs (>4 wks, >40 pts) in duration of adults with OA or RA including one of the following drugs: celecoxib, rofecoxib, valdecoxib, meloxicam, diclofenac, naproxen or ibuprofen. | Total NR | 64 RCTs: designs not specified | Patients age >18 with a diagnosis of OA or RA | 18 NSAID vs. placebo; 33 diclofenac studies; 12 ibuprofen studies; 14 naproxen studies; 5 meloxicam studies; 8 rofecoxib studies; 5 celecoxib studies; 1 valdecoxib study. | See Adverse Events | Use of high dose of diclofenac (>100mg/day) was associated with a higher proportion of patients having aminotransferase elevation >3x ULN. No SS differences for other subgroups (high dose rofecoxib; longer duration for all comparators including placebo) | Among all comparisons, no NSAID had higher rates of renal serious adverse events, hospitalizations or death. Diclofenac and rofecoxib both showed higher rates of aminotransferase elevations (>3x ULN) when compared to all other NSAIDs (3.55% [95% CI 3.12 to 4.03] and 1.80% [95% CI 1.52 to 2.13] respectively, vs. <0.43%)
Rostom, 2007^81^ | To assess upper GI harms of long-term COX-2 use | CCRCT through 2005; Cochrane Collaboration library through 2005; MEDLINE 1966–2006; EMBASE 1980–2005 | RCTs of COX-2s reporting upper GI toxicity relative to nonselective NSAID or placebo; study participants age ≥ 18 yrs with osteoarthritis, rheumatoid arthritis or other arthritic condition; NSAID exposure ≥ 4 wks | 31,106 celecoxib vs. nonselective NSAID; other interventions not abstracted (outside scope of report) | 4 RCTs celecoxib vs. nonselective NSAID (clinical outcomes) | Not described; all had OA, RA or other arthritic condition per inclusion criteria | Celecoxib doses not specified | Clinical GI events - celecoxib vs. NSAIDS: PODs (perforation, obstruction or bleeding) RR 0.23 (CI 0.07 to 0.76) PUDs (perforation, obstruction, bleeding or symptomatic ulcer) RR 0.39 (CI 0.21 to 0.73) Sensitivity analysis removing combined analysis study eliminated heterogeneity and results still favored celecoxib | Not reported | Not stratified according to intervention; for all COX-2s vs. NSAIDs: Withdrawals due to GI tolerability RR 0.65 (CI 0.57 to 0.73) Withdrawals due to dyspepsia RR 0.37 (CI 0.18 to 0.74) Withdrawals due to abdominal pain RR 0.25 (CI 0.13 to 0.49) GI symptoms (low-dose COX-2s) RR 0.78 (CI 0.74 to 0.82) Dyspepsia RR 0.83 (CI 0.75 to 0.90) Nausea RR 0.72 (CI 0.64 to 0.82) Abdominal pain RR 0.25 (CI 0.58 to 0.70)
Rubenstein, 2004^166^ | To systematically review the published literature of population-based epidemiological studies reporting the incidence or comparative risk of NSAIDs for liver injury resulting in clinically significant events (defined as hospitalization or death) | MEDLINE, Pre-MEDLINE and EMBASE through 2004. | Case-control, controlled cohort, single cohort population-based studies. | Total NR; 396,392 patient years included in analysis | 1 case-control; 1 nested case-control; 2 retrospective single-cohort w/nested case-control studies; 3 retrospective single-cohort w/out nested case-control. | Patients taking NSAIDs for any indication | 6 studies: unspecified NSAIDs (including any of the following: diclofenac, diflunisal, fenbufen, fenoprofen, ibuprofen, indomethacin, ketoprofen, mefenamic acid, naproxen, nimesulide, sulindac, tenoxicam); 2 of these 6 included aspirin. 1 study: diclofenac, naproxen and piroxicam only. | -- | Not reported | No SS difference between current NSAID user and past NSAID users in hospitalization rates for liver injury (range 1.2–1.7) Incidence of liver injury resulting in hospitalization ranged from 3.1–23.4/100,000 patient years for current NSAID users, compared to 4.8–8.6/100,000 patient years for past NSAID users. | Assessed adverse events only
Solomon, 2008^114^ | inhibitor celecoxib affects CV risk, | Time period covered not specified (publication date 2008) Electronic databases not specified, “asked” NIH and Pfizer for unpublished trials | RCTs that were double-blind and placebo-controlled, planned follow-up at least 3 years | 7950 (3664 randomized to celecoxib) | 6 RCTs of celecoxib vs. placebo | Prevention of colorectal adenoma recurrence (3 trials) Prevention of recurrent breast cancer in postmenopausal women receiving aromatase inhibitors (1 trial) Prevention of Alzheimer’s disease and age-related cognitive decline (1 trial) Treatment of diabetic retinopathy with photocoagulation (1 trial) | Planned followup >=3 years in all trials | -- | -- | Cardiovascular death, MI, stroke, heart failure, or thromboembolism Celecoxib any dose (101/4286) vs. placebo (52/3664): HR 1.6 (1.1, 2.3) Celecoxib 400 mg QD (30/1347) vs. placebo (20/1038): HR 1.1 (0.6, 2.0) Celecoxib 200 mg bid (38/1450) vs. placebo (29/1809): HR 1.8 (1.1, 3.1) Celecoxib 400 mg bid (33/1489) vs. placebo (11/1496): HR 3.1 (1.5, 6.1) | Risk increased from low to moderate CV risk groups (HR 2.0 [1.5, 2.6]) and from low-risk to high-risk groups (HR 3.9 [2.3, 6.7]). Celecoxib associated with increased risk regardless of baseline aspirin use
Towheed, 2006^180^ | To determine which NSAID is most effective and which is most toxic in the treatment of hip OA | 1966 – August, 1994 MEDLINE Cochrane Musculoskeletal Group trials register and CCTR through August 1994 | RCTs published in English; placebo-controlled comparative treatment w/analgesics or NSAIDs; single and double-blinded trials | Total number of patients not specified, however mean number of randomized patients per trial was 95, with a range from 9 to 455. Mean number of patients completing trial was 81, range of 9 to 397. | 43 RCTs: 21 crossover study design and 22 parallel group design. | Eligible participants were any adult (>18) with a diagnosis of primary or secondary OA. 53% of trial participants were women, mean age 63. | Placebo: etodolac, tenoxicam, ketoprofen, diacerhein Head to head: flurbiprofen vs. sulindac diclofenac vs. naproxen proquazone vs. naproxen piroxicam vs. naproxen diclofenac vs. ibuprofen sulindac vs. ibuprofen carprofen vs. diclofenac piroxicam vs. indomethacin naproxen vs. indomethacin tenoxicam vs. diacerhein | Efficacy When compared to placebo, all NSAIDs except diacerhein resulted in pain decrease and improvement of global assessment (no RR provided) In head to head trials, no SS difference amongst any of the compared interventions (no RR provided) Low-dose ibuprofen (<1600 mg/day) and low-dose naproxen (<750 mg/day) less efficacious than other NSAIDs An alternative, more sensitive technique of results analysis (Heller, et al) found that indomethacin was more effective than its comparators in 5 of 7 cases. | Not reported | Out of 29 NSAID combinations, 9 revealed clinically relevant differences in toxicity. Indomethacin was found to be more toxic in 7 of these 9 combinations. However, only 6 of the 29 comparisons were tested for SS differences. | SR limited by lack of standardization of OA diagnosis and OA outcomes Results suggest that best NSAID varies widely depending on a particular patient
Towheed, 2006^68^ | 1. To assess the efficacy and safety of acetaminophen vs. placebo for treating participants with OA.; 2. To assess the efficacy and safety of acetaminophen vs. other NSAIDs (e.g., ibuprofen, diclofena) for treating participants with OA. | MEDLINE (up to July 2005), EMBASE (2002–July 2005), Cochrane Central Register of Controlled Trials, ACP Journal Club, DARE, CDSR (all from 1994 to July 2005) | Published RCTs evaluating the efficacy and safety of acetaminophen alone in patients with OA. | 5986 | 15 RCTs, 7 of acetaminophen vs. placebo and 10 of acetaminophen vs. NSAIDs. Mean duration of the RCTs=13.1 weeks (duration ranged from 1–104 weeks, median of 6 weeks). | Mean age= 62.2 years (69% female and 31% male). In 3 RCTs included participants with primary OA, 1 RCT enrolled both primary and secondary OA participants and in other 11 RCTs did not specify. In 15 RCTs patients had OA of the knee and in 5, had OA of hip. | Dosage of acetaminophen for 12 of the RCTs was 1000 mg four times daily. One trial used 650 mg four times daily | Pooled RR (95% CI):; A. SMD: −0.13 (−0.22 to −0.04); B. GI Safety: 1.47 (1.08 to 2.00), patients taking NSAIDs at higher risk | NR | A. Any AE: 1.02 (0.89 to 1.17) in acetaminophen vs. placebo trials; B. Withdrawals due to AE: 1.24 (0.87 to 1.77) in acetaminophen vs. placebo. | Update to 2006 review
Trelle, 2011^115^ | To analyze the current evidence availble on CV safety of NSAIDs. | Bibliographica databases, conference proceedings, study registers, FDA website and used the Science Citation Index through July 2009. | RCTs comparing any NSAIDs with other non-NSAIDs, paracetamol (acetaminophen), or placebo for any medical condition. Trials required at least two arms h arms with at least 100 patient years of follow-up. | 116429 patients indeified from 31 trials and included 115000 patient years of follow-up. | 31 RCTs included:; 1. 29 reporting MI with 554 events; 2. 26 reporting stroke with 337 events; 3. 26 trials with 312 events related to CV death; 4. 28 trials with all cause mortality with 676 events | Not specified | All NSAIDs vs. placebo | Compared with placebo (rate ratios); A. Risk of MI:; Lumiracoxib: 2.00, 95% CI 0.71 to 6.21; B. Risk of stroke:; Ibuprofen 3.36, 1.00 to 11.6; Diclofenac 2.86, 1.09 to 8.36; C. Risk of CV Death; Etoricoxib: 4.07, 1.23 to 15.7; Diclofenac 3.98, 1.48 to 12.7 | -- | -- | --
Watson, 2005^57^ | To determine difference in efficacy of NSAIDs in treatment of knee OA. | 1966 – November, 1996 MEDLINE 1980– December, 1995 EMBASE | Double-blind RCTs published in English evaluating two NSAIDs | not stated | 16 RCTs: All double-blind although most failed to report method used to achieve double-blind conditions | Patients age >16 with a confirmed diagnosis of OA of the knee. | Etodolac (600 mg and 800 mg) vs. diclofenac (100–150 mg), naproxen (1000 mg), piroxicam (20 mg), indomethacin (150 mg), nabumetone (1500 mg) Nabumetone (1000 mg) vs. diclofenac (100 mg) Tenoxicam (20 mg) vs. piroxicam (20 mg) Tenoxicam (20 mg) vs. diclofenac (150 mg) Flurbiprofen (150 mg) vs. diclofenac (150 mg) Naproxen (750 mg) vs. diclofenac (150 mg) | Efficacy Withdrawal due to lack of efficacy: Meta-analysis of nine trials showed no SS differences between etodolac, diclofenac or naproxen. Patient Global Assessment: Favored etodolac in two trials however results are questionable due to nonequivalent dose comparisons. Pain: Only 2 of 14 trials assessed pain measurement with adequate power (70%) to detect minimum clinical difference between treatments. Both trials favored etodolac over the comparator drug. Again, nonequivalent dose comparisons resulted in questionable validity of results. Physical function: Only one trial showed a SS difference in favor of tenoxicam vs. diclofenac (OR 3.93 95% CI 1.07 to 14.44) | Not reported | -- | Poor methodology resulted in little SS evidence favoring one NSAID over another Only 5 of 16 trials compared equivalent dosing of trial and comparators
Wegman, 2004^181^ | To systematically evaluate RCT evidence on short and long term efficacy of NSAID compared to acetaminophen for OA of the hip or knee. To critically appraise the quality of guidelines for management of OA, and compare content of recommendations in these guidelines on treatment of OA with NSAID or acetaminophen. | To December 2001 | For evidence review: RCTs published as full reports comparing NSAIDs with acetaminophen for patients with pain and/or disability related to OA of the hip or knee. At least one of the following outcomes included: overall change, pain or disability. Random allocation of interventions. For guidelines: Guidelines developed by a professional working group of experts. Recommendations on pharmacological management of hip or knee OA. | 655 | 7 publications describing 5 RCTs, two of which were of cross-over design 9 guidelines | All trials included patients with knee OA, and two included those with hip or knee OA. | 7 different types of NSAIDs, including 3 coxibs within recommended dose ranges were compared to acetaminophen with daily doses ranging from 2600 mg to 4000 mg. Mean duration of trail period from which data were drawn was 49 ± 25 days, with a range of 24 – 84 days. | Rest pain (Based on 5 trials with 1208 subjects) Overall improvement using pooled data: inverse-variance-weighted mean difference (WMD) = −6.33 (95% CI −9.24 to −3.41) and an average ES of 0.23 favoring NSAID-treated groups. In 3/6 studies, there was a reduction in rest pain favoring NSAIDs (p<0.05) Walking pain (Based on 6 trials with 1051 subjects) Pooled data demonstrated a WMD of −5.76 (95% CI −8.99 to −2.52) and an average ES of 0.23 favoring NSAID-treated groups. | Not reported | Dropouts due to adverse events All NSAID groups: 63/752 (8.4%) High dose NSAID groups only: 48/497 (9.7%) Acetaminophen: 32/500 (6.4%) The overall safety measure derived from pooled data for dropouts due to AEs showed no statistically significant difference between NSAID vs. acetaminophen (OR 1.45; 95% CI 0.93 to 2.27). Specific types of AEs resulting in withdrawal were not discernable due to lack of data in primary studies. | No data on specific AEs
White, 2003^112^ | To determine whether the celecoxib affects cardiovascular thrombotic risk. | Time period covered not specified (publication date 2003) Databases not described, possibly Pfizer database of trials. | Completed RCTs of celecoxib for arthritis with planned duration of >=4 weeks | 31,879 (18,942 randomized to celecoxib) | 15 RCTs: 9 celecoxib vs. another NSAID, 4 celecoxib vs. placebo, 2 celecoxib vs. another NSAID vs. placebo | Osteoarthritis (8 trials) Rheumatoid arthritis (4 trials) Mixed osteoarthritis or rheumatoid arthritis (3 trials) | All trials 4–12 weeks in duration with the exception of 1 trial 24 weeks (n=655), 1 trial 26 weeks (n=7968) | -- | -- | Antiplatelet Trialists’ Collaboration composite CV events All patients Celecoxib (n=4849) vs. placebo (n=1794): 9/700 vs. 3/200 patient-years, RR 0.85 (95% CI 0.23 to 3.15) Celecoxib (n=17,473) vs. NSAIDs (n=11,143): 54/4969 vs. 38/3613 patient-years, RR 1.06 (95% CI 0.70 to 1.61) Celecoxib (n=12,449) vs. naproxen (2,271): 4/606 vs. 2/171 patient-years, RR 0.85 (95% CI 0.29 to 2.46) Aspirin nonusers Celecoxib (n=4192) vs. placebo (n=1,553): 4/606 vs. 2/171 person-years, RR 0.60 (95% CI 0.11 to 3.29) Celecoxib (n=15,353) vs. NSAIDs (n=9649): 24/4224 vs. 20/3012 person-years, RR 0.86 (95% CI 0.48 to 1.56) Celecoxib (n=11,289) vs. naproxen (n=1975): 11/2204 vs. 3/343 person-years, RR 0.82 (95% CI 0.18 to 2.46) | Pooled CV across all trials (instead of pooling RR’s from individual trials)
White, 2007^113^ | To determine whether the celecoxib affects CV risk. | Trials completed through October 31, 2004 Pfizer’s celecoxib drug safety database | RCTs with a parallel group design; 1 treatment arm given celecoxib at doses of >=200 mg/day; 1 treatment arm given a placebo comparator or a NSAID comparator; planned double-blind treatment period >=2 weeks; final study report completed by October 31, 2004 | 41,077 (23,030 randomized to celecoxib) | 41 RCTs: 12 celecoxib vs. another NSAID, 16 celecoxib vs. placebo, 13 celecoxib vs. another NSAID vs. placebo | Osteoarthritis (21 trials) Rheumatoid arthritis (4 trials) Mixed osteoarthritis or rheumatoid arthritis (6 trials) Ankylosing spondylitis (2 trials) Low back pain (4 trials) Alzheimer’s disease (2 trials) | All trials 4–12 weeks in duration, with the exception of 1 trial 24 weeks (n=655), 2 trials 52 weeks (n=1341), 1 trial 52–65 weeks (n=7968), 1 trial 104 weeks (n=36) | -- | -- | Celecoxib 200–800 mg (n=7462) vs. placebo (n=4057) (adjudicated events, nonadjudicated events) Antiplatelet Trialists’ Collaboration composite CV events (18 vs. 7, 23 vs. 8): RR 1.1 (95% CI 0.47 to 2.7), RR 1.3 (95% CI 0.57 to 2.8) CV deaths (8 vs. 3, 11 vs. 3): RR 1.3 (95% CI 0.33 to 4.8), RR 1.7 (95% CI 0.49 to 6.2) Nonfatal MI (5 vs. 1, 7 vs. 2): RR 1.6 (95% CI 0.21 to 12), RR 1.2 (95% CI 0.27 to 5.8) Nonfatal stroke (5 vs. 3, 5 vs. 3): RR 0.80 (95% CI 0.19 to 3.3), RR 0.80 (95% CI 0.19 to 3.3) Celecoxib 200–800 mg (n=19,773) vs. nonselective NSAIDs (n=13,990): (adjudicated events, nonadjudicated events) Antiplatelet Trialists’ Collaboration composite CV events (54 vs. 49, 57 vs. 54): RR 0.90 (95% CI 0.60 to 1.3), RR 0.86 (95% CI 0.59 to 1.3) CV deaths (12 vs. 19, 15 vs. 19): RR 0.57 (95% CI 0.28 to 1.1), RR 0.72 (95% CI 0.37 to 1.4) Nonfatal MI (32 vs. 15, 35 vs. 19): RR 1.8 (95% CI 0.93 to 3.4), RR 1.5 (95% CI 0.82 to 2.7) Nonfatal stroke (10 vs. 15, 7 vs. 16): RR 0.51 (95% CI 0.23 to 1.1), RR 0.33 (95% CI 0.14 to 0.78) | Appeared to simply pool CV events across all trials (instead of pooling RR’s from individual trials), did not include Pre SAP, ADAPT, or APC trials
Zhang, 2004^182^ | To assess the best available evidence for efficacy of paracetamol (acetaminophen) in the treatment of OA. | 1966 through July, 2003 | RCTs comparing paracetamol with placebo or NSAIDs for treatment of OA (radiographic evidence or ACR clinical criteria) or OA pain. | 1712 | 10 RCTs: 5 double blind parallel, 3 double blind crossover, one “n of 1” and one undefined RCT (abstract only) design | Patients with either symptomatic OA of the knee (6 trials) or hip/knee (3 trials) or multiple joints (1 trial). | 5 types of NSAIDs were compared to acetaminophen with daily doses ranging from 2600 mg/d to 6000 mg/d. Trial periods ranged from 7 days to 2 years. | General pain/rest pain (Based on 3 trials, OA of hip or knee, 4 – 6 weeks follow-up) Pooled standardized mean difference of 0.33 (95% CI 0.15 to 0.51), indicating a small effect in favor of NSAIDs. Pain on motion, comparison with high dose ibuprofen: 0.24 (95% CI 0.00 to 0.48); with low dose: 0.18 (95% CI −0.06 to 0.42) Functional disability, comparison with high dose ibuprofen: 0.19 (95% CI 0.01 to 0.37); with low dose: 0.18 (95% CI 0.00 to 0.35) Overall change (physician assessment): 0.22 (95% CI 0.02 to 0.43) 3/9 guidelines satisfied more AGREE criteria than others, especially rigor of development. Most guidelines had poor descriptions of stakeholder involvement, applicability and editorial independence were poorly described in most guidelines. The recommendations on use of NSAIDs or acetaminophen were fairly consistent. | Not reported | Not reported | Main results based on 3 trials with a total n of 589 Baseline pain levels not accounted for in analysis

ACP = American College of Physicians; ACR = American College of Rheumatology; ADAPT = Alzheimer’s Disease Anti-Inflammatory Prevention Trial; AE = adverse event; APC = the Adenoma Prevention with Celecoxib trial; AGREE = Appraisal of Guidelines for Research & Evaluation trial; COX = Cyclo-oxygenase; CI = confidence interval; bid = twice daily; CLASS = Celecoxib Long-term Arthritis Safety Study; CV = cardiovascular; ES = effect size; EULAR = the European League Against Rheumatism; FDA = U.S. Food and Drug Administration; GI = gastrointestinal; HAQ = Health Assessment Questionnaire; HR = hazard ratio; MI = myocardial infarction; NNT = number needed to treat; NR = not reported; NSAID = nonsteroidal anti-inflammatory drug; OA = osteoarthritis; OMERACT = Outcomes Measures in Arthritis Clinical Trials; OR = odds ratio; PreSAP = Prevention of Colorectal Sporadic Adenomatous Polyps; POB = Gastric or duodenal perforation, gastric outlet obstruction, or upper gastrointestinal bleeding; PUB = Perforations, symptomatic gastroduodenal ulcers, and upper GI bleeding; qd = once daily; RA = rheumatoid arthritis; RCT = randomized controlled trial; RR = relative risk; SMD = standardized mean difference; SR = systematic review; SS = statistically significant; WOMAC = Western Ontario and McMaster Universities Osteoarthritis Index; WMD = weighted mean difference; ULN = upper limit of normal; VIGOR = Vioxx Gastrointestinal Outcomes Research; wk = week, yr = year

Cardiovascular Safety in Observational Studies

Author, Year Data Source Sample Size | Population | Categorization of Exposure | Demographics (Age, Gender, Race) | Study Design/Type | Adjusted Variables, Selection of Controls (for Case-Control Studies) | NSAIDs Evaluated | Aspirin use (%) | Outcome: Incidence | Results | Effects of Confounders, Dose, Duration
Andersohn, 2006^132^ UK General Practice Research Database (GPRD) (6/1/00–10/31/04) Cases=3,643 | Age ≥ 40 years; ≥ 1 NSAID prescription between June 1, 2000 and October 31, 2004; from a practice with ensured quality standards of data recording for ≥ 1 year | Recent use: within 15 to 183 days before index date Past use: 184 days to 1 year Nonuse: no use during 1 year before index date | Age: Mean 69 years Female: 41% Race: Not reported | Nested case-control study | CHD, hypertension, diabetes mellitus, cerebrovascular disease, hyperlipidemia, rheumatoid arthritis, body mass index, smoking status. Controls matched on age, sex, practice, year of cohort entry. | A. Celecoxib; B. Diclofenac; C. Ibuprofen; D. Naproxen; E. Other nonselective NSAIDs | NR | AMI, death from AMI, or sudden death from CHD: 3.7 per 1000 person-years | Current use vs. nonuse: adjusted RR (95% CI); A. 1.56 (1.23 to 1.98); B. 1.36 (1.17 to 1.58); C. 1.00 (0.83 to 1.21); D. 1.16 (0.86 to 1.58); E. 1.19 (1.02 to 1.39) | Risk increased with dose for celecoxib. No significant interaction with age, gender, or presence of risk factors
Cunnington, 2008^148^ Medical and pharmacy claims from Life-link database (1/1/94–12/31/98) N=71, 026 | Patients diagnosed with osteoarthritis before 1999 | Chronic user: At least 90 days continuous use with at least two prescriptions Non-user: No recorded exposure to NSAIDs | Chronic user vs. non-user Age: 52% vs. 46% >=65 years Female: 64% vs. 54% Race: Not reported | Retrospective cohort study | Diabetes, smoking-related illness, anticoagulant use, use of lipid lowering drugs, antihypertensive medication, estrogen hormone replacement therapy, intermittent COX-2 inhibitor use or chronic non-selective NSAID use, prior acute myocardial infarction, ischemic stroke, revascularizations, time since osteoarthritis diagnosis | A. Celecoxib; B. Naproxen | NR | Hospitalization for acute myocardial infarction or ischemic stroke: 8.6/1000 person-years for acute myocardial infarction and 4.2 per 1000 person-year for ischemic stroke | Chronic use vs. non-use: adjusted HR (95% CI); A. 1.05 (0.91 to 1.22); B. 0.99 (0.64 to 1.54) | No effect on estimates in stratified analysis by age or history of ischemic stroke
Cunnington, 2008^148^ Life-link US claims database (1/1/1994–12/31/1998) N=80,826 | A cohort of subjects with osteoarthritis diagnosed before 1999 introduced to COX-2s. | User: chronic medication exposure defined as at least 90 days continuous use with at least two prescriptions. A non chronic/non-user category was no recorded exposure to NSAIDs or COX-2s or short-term use of NSAIDs and COX-2s. | Age: 52% <65 years, 48% ≥65 years Female: 58% Race: NR | Cohort | Age and sex | A. Celecoxib; B. Naproxen | NR | CV events per 1000 patient yrs of chronic users A); a. 65 years of age + history of ischemic stroke: 55.4; b. 65 years of age: 29.2; c. Hx of ischemic stroke: 49.4; B); a. 65 years of age + history of ischemic stroke: 65.0; b. 65 years of age: 32.2; c. Hx of ischemic stroke: 49.6 | Adjusted HR (95% CI) of chonic vs. non-users; A. 1.05 (0.99 to 1.22); B. 0.99 (0.64 to 1.54) | The strongest predictors of AMI/ischemic stroke risk were history of ischemic stroke and age 65 years or greater. Dose, duration of use and time since OA diagnosis did not meet statistical signficance.
Fischer, 2005^133^ UK GPRD database January 1995 – April 2001 Cases= 8688 | Residents of the England and Wales who see a GP registered with the General Practice Research Database (GPRD) | Current users: supply of the last prescription for an NSAID before the index date ended or after the index date Non-users: without exposure before index date | Age: ≤89 years Female: 37.1% Race: NR | Case-control | Age, sex, smoking status, aspirin use, body mass index, and diagnosed CV or metabolic diseases (hypertension, hyperlipidemia, diabetes mellitus, ischemic heart disease, arrhythmias of heart failure, arterial thrombosis, kidney disease, rheumatoid arthritis, lupus), acute chest infections and NSAID drug use | A. Current use; B. Diclofenac; C. Ibuprofen; D. Naproxen; E. Indomethacin; F. Piroxicam; G. Ketoprofen; H. Fenbufen; I. Nabumetone; J. Etodolac; K. Flurbiprofen | 4.4% of cases (and never NSAIDs use) | First-time acute myocardial infarction | Current use vs. no use: adjusted OR (95% CI); 1. 1.07 (0.96–1.19); A. 1.23 (1.00–1.51); B. 1.16 (0.92–1.46); C. 0.96 (0.66–1.38); D. 1.36 (0.82 to 2.25); E. 0.95 (0.53–1.69); F. 0.86 (1.44–1.70); G. 3.08 (1.18–8.06); H. 0.62 (0.25–1.53); I. 1.13 (0.40–3.22); J. 0.68 (0.22–2.12) | Concomitant use of aspirin with NSAIDs was associated with a decreased risk of MI 0.74 (0.57–0.97)
Fosbol 2009^149^ Danish Cohort (as of 1/1/1997) Population A: N=1,028,437 Population B: N=153,456 | A cohort of Danish citizens with no hospital admissions 10 years before their first claimed NSAID prescription and no claimed prescription for concomitant medication (e.g., ACE inhibitors) | Any use (one or more claimed prescription) and by dose. | Median age: 43 (IQR: 26–56) Age: 33% 31–50 years; 27% 51–70 years, 8% >70 years 28% Female Race NR | Cohort: Population B | Age, sex, and calendar year | A. Ibuprofen; B. Diclofenac; C. Naproxen; D. Celecoxib | NR | Death rate per 1,000 person years (95% CI); NNH (95% CI); A. 16 (13–19); 432 (184–1251); B. 18 (17–19); 77 (51–158); C. 12 (5–19); −165 (−76 to −941); D. 68 (41–95); 20 (13–43) | Adjusted HR (95% CI) of death; MI for no use vs. any use or by dose of NSAID; A. Any use: 0.78 (0.64–0.94); 0.88 (0.74–1.06); ≤ 1,200: 0.68 (0.54–0.85); 0.76 (0.62–0.94); >1,200: 1.49 (0.99–2.24); 1.75 (1.21–2.53); B. Any use: 1.40 (1.13–1.75); 1.58 (1.29–1.93); <100 mg: 0.51 (0.28–0.92); 0.71 (0.44–1.16); ≥ 100 mg1.93 (1.53–2.44); 2.09 (1.68–2.61); C. Any use: 0.76 (0.42–1.36); 0.85 (0.49–1.46); ≤ 500 mg : 0.73 (0.38–1.41); 0.85 (0.47–1.53); >500 mg: 0.87 (0.22–3.47); 0.83 (0.21–3.30); D. Any use: 1.56 (1.04–1.75); 1.49 (0.99–2.25); ≤200 mg: 1.02 (0.58–1.79); 1.05 (0.61–1.81); >200 mg: 3.60 (1.99–6.51); 3.12 (1.68–5.81) | A dose-dependent increase in risk of death and MI was seen for selective COX-2 inhibitors and diclofenac. Particularly high doses should be avoided of both these should be avoided. Risk also increased with age.
Garcia-Rodriguez, 2000^237^ (1/1/1991–12/31/1995) N=164,769 Cases= 1,013 | Residents of the England and Wales who see a GP registered with the GPRD | Current user: prescribed aspirin/NSAIDs during the month before the index date Past user: No prescribed NSAID before index date | Age: 50–74 years (60% < 65 years) Female only Race: NR | Case-control (authors state within a cohort) | Age, HRT use, smoking, hypertension, diabetes, obesity, surgical menopause, family history of CHD, and aspirin use (if applies) | A. Aspirin; B. NSAIDs | NA Aspirin evaluated as drug | First recorded date of MI | Current user vs. non user: adjusted OR (95% CI); A. 0.80 (0.41–1.53); B. 1.45 (1.18–1.79); Past user vs. non user: adjusted OR (95% CI); A. 0.86 (0.46 to 1.58); B. 0.89 (0.76–1.05) | Beneficial effects of aspirin use seen in women using ≤150 mg
Garcia-Rodriguez, 2004^134^ UK GPRD (1/1997–12/2000) Controls= 20,000 Cases= 4975 | Residents of the U.K. who see a GP registered with the GPRD | Current user: supply of the most recent prescription lasted until index date or ended in the 30 days before the index date Recent user: ended between 31 and 180 days before the index date Past user: ended between 6 months and 2 years before the index date Nonusers: no recorded use in the 2 years before the index date | Age: 50–84 years Men and women Race: NR | Case-control (authors state within a cohort) | Age, sex, calendar year, cancer diagnosis, smoking, diabetes, hypertension, hyperlipidemia, BMI, RA, osteoarthritis, anemia, CHD, cerebrovascular disease, alcohol intake, use of steroids, aspirin, anticoagulants, paracetamol, and NSAIDS | A. Naproxen; B. Ibuprofen; C. Diclofenac; D. Ketoprofen; E. Meloxicam; F. Piroxicam; G. Indomethacin | 27% of cases 14% of controls | MI association with current use of individual NSAIDS | NSAID use vs. non-use of NSAIDs OR (95% CI); A. 0.89 (0.64–1.2); B. 1.1 (0.87–1.3); C. 1.2 (0.99–1.4); D. 1.1 (0.59–2.0); E. 0.97 (0.60–1.6); F. 1.2 (0.69–2.2); G. 0.86 (0.56–1.3) | Duration or daily dose did not change the results
Gislason 2009^160^ Danish National Patient Registry (1/1/1995 to 12/31/2004) N=107,092 | Patients aged 30 years or older who survived their first hospitalization from heart failure. | Claims for prescription of NSAIDs categorized by low and high doses. | Mean age: 74.8 years Female: 48% Race: Not reported | Cohort | Age, sex, year of first hospitalization due to heart failure, comorbidity, severity, and concomitant medical treatment. | A. Celecoxib; B. Ibuprofen; C. Diclofenac; D. Naproxen; E. Other NSAIDs | NR | Death, hospitalization due to HF and hospitalization due to AMI. | Adjusted HR (95% CI) of death, HF hospitalization, and AMI hospitaltion for any use of drug vs. no NSAID; A. 1.75 (1.63–1.88), p<.001; 1.40 (1.26–1.55) .001; 1.30 (1.07–1.59) .01; B. 1.31 (1.25–1.37), p<.001; 1.24 (1.12–1.39) .001; 1.38 (1.13–1.69) .001; C. 2.08 (1.95–2.21), p<.001; 1.16 (1.10–1.23) .001; 1.33 (1.19–1.50) .001; D. 1.22 (1.07–1.39), p=.004; 1.35 (1.24–1.48); 1.36 (1.12–1.64) .002; E. 1.22 (1.07–1.39) p=.004; 1.18 (1.00–1.40) .05; 1.52 (1.11–2.06) .01 | Dose dependent increase of mortailty and cardiovascular morbidity with NSAIDs.
Graham 2005^135^ State of California Kaiser Permanente health care database (1/1/99–12/31/09) Cases=8,143 | Age 18–84 years, filled ≥ 1 prescription for celecoxib, rofecoxib or any other non-selective NSAID; ≥ 12 months of health plan coverage before index prescription date | Current use: overlap with index date Remote use: ended >60 days before index date Recent use: ended 1–60 days before index date | Age: Mean 67 years Female: 38% Race: Not reported | Nested case-control study | Age, sex, health plan region, cardiovascular risk score, admission for non-cardiac-related disorders and same-day procedures, emergency room visits for non-cardiac reasons, hormone replacement therapy, and high-dose prednisone. Controls matched on index date, age, sex, health plan region. | A. Celecoxib; B. Ibuprofen; C. Naproxen; D. Other NSAIDs | Random sample of n=817 cases participated in phone interview and 23% reported using aspirin | Acute MI requiring admission or sudden cardiac death: 3.5/1000 person-years | Current use vs. remote use: adjusted OR (95% CI); A. 0.84 (0.67, 1.04); B. 1.06 (0.96, 1.17); C. 1.14 (1.00, 1.30); D. 1.13 (1.01, 1.27); Current use vs. celecoxib use; A. 1 (reference); B. 1.26 (1.00, 1.60); C. 1.36 (1.06, 1.75); D. 1.35 (1.06, 1.72) | 3.8% taking anticoagulants
Hippisley-Cox 2005^136^ Case-control QRESEARCH database (8/1/00–7/31/04) Cases=9218 | Age 25 to 100 years, registered for at least 1 year prior to index date | No use in past 3 years Use >3 months before index date Use within 3 months of index date | Age: 20% 55–64 years, 28% 65–74 Male: 63% Race: Not reported | Nested case-control study | Other NSAIDs, use of aspirin, statin, tricyclic antidepressant, SSRI, ischemic heart disease, diabetes, hypertension, osteoarthritis, rheumatoid arthritis, smoking obesity, deprivation. Controls matched on age, calendar time, sex, and practice. | A. Celecoxib; B. Ibuprofen; C. Diclofenac; D. Naproxen; E. Other non-selective NSAIDs | Yes, but proportion NR | First ever MI: 1.7/1000 person-years | Use within 3 months vs. no use in past three years: adjusted OR (95% CI); A. 1.21 (0.96, 1.54); B. 1.24 (1.11, 1.39); C. 1.55 (1.39, 1.72); D. 1.27 (1.01, 1.60); E. 1.21 (1.02, 1.44) | No interactions between any NSAID and aspirin use or coronary heart disease; smoking and BMI interacted only with naproxen; age 65 and over only interacted with other non-selective NSAIDs
Hudson 2005^161^ Database of hospital discharge summaries (4/1/00–3/31/02) N=997 | Aged > 66 with admission for CHF from 4/00–3/02 | Prescription following hospitalization for CHF | Celecoxib vs. NSAIDs Age: Median 79 vs. 76 years Female: 60% vs. 44% Race: Not reported | Retrospective cohort study | Age, sex, comorbidities, other drugs prescribed, characteristics of the treating doctor or hospital, length of stay, year of exposure, acute myocardial infarction in the previous 3 years, time to first prescription, episodes of CHF after the index admission but before the first prescription | A. Celecoxib; B. Any nonselective NSAID | Yes, in 1006 (53.9%) | Celecoxib vs. nonselective NSAIDs Recurrent CHF: 28 vs. 34/100 person-years Death: 19 vs. 29/100 person-years Death OR recurrent HF: 42 vs. 53/100 person-years (Primary outcome) | Nonselective NSAID use vs. celecoxib use: adjusted hazard ratio, (95% CI) Recurrent CHF: 1.21 (0.92, 1.60) Death: 1.54 (1.17, 2.04) Death or recurrent CHF: 1.26 (1.00, 1.57) | NR
Johnsen 2005^137^ Denmark National Health Service registries (1/100-12/31-03) Cases=10,280 | Persons living in 3 counties in Denmark, using a hospital registry | Nonuser: No recorded prescription Current user: Filled prescription within 0–30 days New users: Current users who filled first prescription within 0–30 days Recent users: Filled prescription within 31–90 days Former users: Filled prescription >90 days before index date | Age: Mean 70 years Female: 40% Race: Not reported | Case-control study | Discharge diagnosis of cardiovascular disease, various comorbid conditions, various prescription drugs. Controls matched on age and sex. | A. Celecoxib; B. Naproxen; C. Other nonselective NSAID | 6.9% high dose | Acute MI: Incidence not reported | Current user vs. non-user: adjusted HR (95% CI); A. 1.25 (0.97, 1.62);; B. 1.50 (0.99, 2.29); C. 1.68 (1.52, 1.85); New user vs. nonuser:; A. 2.13 (1.45, 3.13); B. 1.65 (0.57, 4.83); C. 2.65 (2.00, 3.50) | 13.7% CV disease; 2.2% cc anticoagulant use; rofecoxib was associated with increased risk regardless of baseline risk status
Kimmel 2005^138^ Hospitals in 5-county region (5/98–12/02) Cases: 1718 | Persons aged 40 to 75 years in a 5-country region | Use within 1 week before the index date | Cases vs. controls Age: Mean 58 vs. 53 years Female: 37% vs. 59% Non-white: 28% vs. 19% | Case-control study | Age, sex, race, smoking, insurance, number of physician visits in the previous year, family history of coronary disease, body mass index, activity score, year, previous angina or coronary disease, history of diabetes, hypertension, heart failure, and hypercholesterolemia, use of statins, beta-blockers, calcium-channel blockers, angiotensin-converting enzyme inhibitors, and diuretics. Controls randomly selected from study population. | A. Celecoxib; B. Any nonselective NSAID; C. Ibuprofen or diclofenac; D. Naproxen | 33.60% | Nonfatal MI: Incidence not reported | NSAID use within 1 week vs. no use within 1 week: adjusted OR (95% CI) overall, among aspirin nonusers, and among aspirin users; A. 0.43 (0.23, 0.79), 0.35 (0.16, 0.76), 0.67 (0.25, 1.80); B. 0.61 (0.52, 0.71), 0.55 (0.46, 0.66), 0.77 (0.59, 1.00); C. 0.53 (0.43, 0.66) overall; D. 0.48 (0.32, 0.73); Celecoxib vs. ibuprofen or diclofenac use within 1 week: 0.77 (0.40, 1.48) overall Celecoxib vs. naproxen use within 1 week: 0.81 (0.37, 1.77) | Some results stratified by aspirin use
Levesque 2005^139^ Computerized health insurance and vital statistics databases of Quebec, Canada (1/1/99–6/30/02) Cases=2844 | ≥ 66 years of age prescribed an NSAID or COX-2 who’ve never had an MI | Current user: Duration of the last prescription dispensed overlapped with the index date Past user: Filled at least 1 NSAID prescription in the year prior to the index date but not currently exposed Ever user: Current or past user Nonuser: No NSAIDs in the last year | Age: Mean 78 years Female: 54% (cases) vs. 68% (controls) Race: Not reported | Nested case-control study | Age, sex, hypertension, coronary artery disease, cerebrovascular disease, peripheral vascular disease, congestive heart failure, diabetes, use of lipid-lowering drugs, anticoagulant, and aspirin; co-morbid conditions or use of oral corticosteroids; measures of health utilization, measures of comorbidity. Controls matched on month and year of cohort entry and age. | A. Celecoxib; B. Naproxen; C. Meloxicam; D. Non-naproxen nonselective NSAIDs | 22.50% | Acute MI, fatal or nonfatal: 10.4/1000 person-years | Current use vs. no use: adjusted RR (95% CI); A. 0.99 (0.85, 1.16) overall, 0.98 (0.83, 1.17) low-dose, 1.00 (0.78, 1.29) high dose, 1.07 (0.89, 1.30) no aspirin, 0.88 (0.70, 1.10) taking aspirin; B. 1.17 (0.75, 1.84) overall, 1.59 (0.95, 2.65 no aspirin), 0.60 (0.24–1.50) taking aspirin; C. 1.06 (0.49, 2.30) overall, 0.59 (0.14, 2.41) no aspirin, 1.59 (0.61, 4.14) on aspirin; D. 1.00 (0.73, 1.37) overall, 1.04 (0.71, 1.54) no aspirin, 0.94 (0.57, 1.54) taking aspirin | --
Mamdani 2003^140^ Ontario healthcare administrative database (4/1/98–3/31/01) N=154,808 | NSAID-naïve patients aged ≥ 66 years of age prescribed an NSAID or COX-2 | New user: Received prescription for a drug of interest, no prior prescription within the last year Control: Not prescribed a drug of interest in the 1 year prior to the index date, or during the observation period | Age: Mean 75 years Female: 64% Race: Not reported | Retrospective cohort study | Age, sex, long-term care, low-income status, hospitalizations, cancer, cardiovascular hospitalizations, cardiovascular procedures, concomitant drugs | A. Celecoxib; B. Naproxen; C. Non-naproxen nonselective NSAIDs | 14.70% | Hospitalization for acute MI: 9/1000 person-years | New user vs. nonuser: adjusted RR (95% CI); A. 0.9 (0.7–1.2); B. 1.0 (0.6–1.7); C. 1.2 (0.9, 1.4) | --
Mamdani 2004^162^ Ontario healthcare administrative database (4/17/00–3/31/01) N=130,514 | NSAID-naïve patients aged ≥ 66 years of age prescribed an NSAID or COX-2 | New user: Prescribed drug of interest (at least two successive prescriptions), no drug of interest in the year prior to the index prescription | Age: Mean 76 years Female: 58% Race: Not reported | Retrospective cohort study | Age, sex, long-term care, low-income status, hospitalizations, cancer, cardiovascular hospitalizations, cardiovascular procedures, concomitant drugs | A. Celecoxib; B. Nonselective NSAIDs | NR | Admission for CHF: 10/1000 person-years | New user vs. nonuser: adjusted RR (95% CI); A. 1.0 (0.8, 1.3); B. 1.4 (1.0, 1.9); Non-selective NSAIDs vs. celecoxib: 1.4 (1.0, 1.9) | History of heart failure admission within past 3 years increased risk
Patel, 2004^259^ Durham VA 1/1/1990–12/31/2000 Cases=3850 aspirin + ibuprofen; 10239 aspirin only (Controls matched by patient month, not patient) | Patients in clinical database of the Durham VA Medical Center | Outpatient prescription of aspirin or ibuprofen; aspirin alone, aspirin + ibuprofen and combined | Average birth year, 1933 97% Male Race: 29% black | Case control | Controls matched to cases by sex, race, age and LDL cholesterol level
Rahme 2002^141^ Quebec, Canada RAMQ and Med-Echo databases (1/1/1988–12/31/1994) Controls= 14,160 Cases= 4163 | Residents of Quebec (all persons ≥65 years are eligible) registered for health coverage, maintained by RAMQ and Med-Echo databases | Current user: prescriptions with a duration that covered or overlapped with the index date Chronic user: filled at least twice and with 60+ consecutive days of prescription duration Current-chronic user: subject of primary analysis Interrupted-chronic user: chronic user without use at the index date | Age: ≥ 65 years Men: 52.8% cases; 52.8% controls | Case-control (population-based) | Age, sex, use of anticoagulants, nitrates, lipid-lowering agents, antidiabetic agents, or antihypertensive agents, prior AMI, cardiovascular diseases, presence of comorbidity factors
Rahme, 2007 Arthritis and Rheumatism130 Health care records and hospital records of patients in Quebec Canada including those with OA (1997 to 12/2002) | Patients of 65 years of age or older who filled a prescription for acetaminophen or a NSAIDs. | The number of days of supply for each NSAID or acetaminophen prescription with a grace period of 25%. | Age ≥ 65 years Male: 45% | Retrospective cohort | Age, gender, alcohol/drug use, co-morbidities (e.g., COPD) and other drugs
Rahme 2007^108^ Quebec government health insurance database and hospital discharge summary database (RAMQ and Med-Echo) (1/1998 to 12/2004) N=644,183 | Patients of 65–80 years of age or older who filled a prescription for NSAIDs | The number of days of supply for each NSAID or acetaminophen prescription. Exposure was designated to be 1.25 × number of days supplied). | Age 65–80 years of age Male: 40% | Retrospective cohort | Concomitant drugs and baseline characteristics
Ray 2002^142^ Tennessee Medicaid program database (1/1/99–6/30/01) N=354,644 | Aged 50–84 (mean=61.5); eligible for TennCare benefits for past 365 days; not in a nursing home; no history of non-CV life-threatening illness; new users | User: Taking an NSAID at enrollment, or during the time they were eligible for the study New user: Began an NSAID during follow-up Non-users: No NSAID within 1 year | Age: Mean 61 years Female: 66% Non-white: 27% | Retrospective cohort study | Age, sex, summary cardiovascular disease risk score, ethnic origin, calendar year, basis for inclusion in TennCare, use of estrogen, hospital admission for non-cardiovascular illness, visits to emergency department, rheumatoid arthritis, visits to family doctor, current aspirin use | A. Celecoxib; B. Ibuprofen; C. Naproxen | NR | Serious CHD (hospital admission for AMI or death from CHD): 12/1000 person-years | Current user vs. nonuser; A. 0.96 (0.76, 1.21); B. 0.91 (0.78, 1.06); C. 0.93 (0.82, 1.06); New user vs. nonuser; A. 0.88 (0.67, 1.16); B. 1.01 (0.77, 1.33); C. 0.92 (0.73, 1.16) | NR
Schlienger 2002^143^ UK GPRD (1/1/92–10/31/97) Cases=3,315 | ≤ 75 years of age; free of metabolic or cardiovascular diseases predisposing to AMI; registered on the database for at least 3 years before the index date | Current user: Last prescription for an NSAID ended on or after the index date Recent user: Supply ended between 1 and 29 days prior to index date Past user: Supply ended 30 or more days prior to index date Nonuser: No NSAID prescription prior to index date | Age: 25% 50–59 years, 37% 60–69 Female: 26% Race: Not reported | Case-control study | Smoking status, body mass index, hormone replacement therapy, aspirin use. Controls matched on age, sex, index date, practice attended. | A Ibuprofen; B Diclofenac; C Piroxicam; D Ketoprofen; E Indomethacin; G Naproxen | Yes | First-time acute MI: Proportion not reported | Current use vs. nonuse: adjusted OR (95% CI); A. 1.17 (0.87, 1.58); B. 1.38 (1.08, 1.77); C. 1.65 (0.78, 3.49); D. 2.06 (0.80, 5.30); E. 1.39 (0.77, 2.51); F. 1.03 (0.58, 1.85); G. 2.26 (0.93, 5.46); H. 0.68 (0.42, 1.13) | Current use of aspirin at the index date and longer term use of HRT in women interacted with AMI risk; exposure duration, age, and gender did not.
Solomon 2002^144^ New Jersey Medicaid or Medicare and Pharmaceutical Assistance for the Aged and Disabled programs (1/1/91–12/31/95) Cases=4425 | Participants in a state Medicaid program or a program for older adults with moderate incomes, who were continuous participants in the program | Cumulative duration in the prior 6 months 1 to 30 days, 31 to 90 days, or 91 to 180 days | Age: 15% <=64 years, 30% 65–74 years Female: 69% (cases) vs. 79% (controls) Non-white: 28% (cases) vs. 31% (controls) | Case-control study | Age, sex, ethnicity, Medicaid enrollment, nursing home use, diabetes mellitus, hypertension, congestive heart failure, Charlson Comorbidity Index, number of different drug prescriptions, number of hospitalizations. Controls matched on age. | A. Any nonselective NSAID; B. Naproxen; C. Ibuprofen; D. Etodolac; E. Fenoprofen | Excluded | Acute MI: Incidence not reported | NSAID user vs. non-user: adjusted OR (95% CI); A. 1.00 (0.92, 1.08); B. 0.84 (0.72–0.98); C. 1.02 (0.88, 1.18); D. 1.28 (1.00, 1.64); E. 1.95 (1.16, 3.30); Naproxen user vs. ibuprofen user: 0.82 (0.67–1.01) | No dose- or duration-response relationship
Solomon 2004a145 Chart review of prescription drug benefit program participants (1998–2000) Cases=10,895 | Low-income, elderly, Medicare beneficiaries who had at least 1 healthcare visit in each 6-month period | Cumulative duration of exposure during the 1–30 days 31–90 days > 90 days | Mean age: 82 years Female: 78% Non-white: 9% | Case-control study | Race, number of physician visits, hospitalized in previous year, comorbid conditions, diabetes, hypertension, number of prescription drugs, history of cardiovascular conditions, use of statin, hormone replacement therapy, an anticoagulant, rheumatoid arthritis, osteoarthritis, prior nonselective NSAID use. Controls matched on age, sex, and month of index date. | A. Celecoxib; B. Naproxen; C. Ibuprofen; D. Other nonselective NSAID | NR | Acute MI: Incidence not reported | Adjusted OR (95% CI) Celecoxib use vs. no current NSAID use: 0.93 (0.84, 1.02) Celecoxib use vs. naproxen use: 0.95 (0.74, 1.21) Celecoxib use vs. ibuprofen use: 0.98 (0.76, 1.26) Celecoxib use vs. other nonselective NSAID use: 0.95 (0.82, 1.10) | Dose had an effect for rofecoxib but not celecoxib; couldn’t adjust for aspirin use
Solomon 2004b131 Medicare Prescription Drug Benefit Program databases through Pennsylvania PACE or the New Jersey PAAD (1998–2000) Cases=3,915 | Active users of prescription drug benefit program for 2 consecutive years out of the 3-year period with no prior diagnosis of hypertension and no use of antihypertensive medications | NSAID use: Active prescription on the day before the index date Short duration of use: 1–30 days Long duration of use: 31–90 days | Mean age: 79 years Female: 81% Non-white: 5% | Case-control study | Age >=75 years, sex, race, hospitalization in prior year, nursing home resident in prior year, diabetes, coronary artery disease, osteoarthritis, physician visits in prior year, number of different medications, and comorbid illnesses. Controls randomly selected from eligible pool of patients | A. Celecoxib; B. Nonspecific NSAID | NR | New onset hypertension and the filling of at least 1 antihypertensive medication prescription: Incidence not reported | Adjusted OR (95% CI) Celecoxib use vs. no NSAID use: 1.0 (0.9, 1.2) Celecoxib use vs. nonspecific NSAID use: 0.9 (0.7, 1.1) Celecoxib use <=200 mg vs. no NSAID use: 1.0 (0.8, 1.2) Celecoxib use >200 mg vs. no NSAID use: 1.2 (0.8, 1.7) Celecoxib use <=200 mg vs. nonspecific NSAID use: 0.9 (0.6, 1.1) Celecoxib use >200 mg vs. nonspecific NSAID use: 1.1 (0.6, 1.7) Celecoxib use 1–30 days vs. no NSAID use: 1.4 (1.0, 1.9) Celecoxib use >30 days vs. no NSAID use: 0.9 (0.7, 1.1) Celecoxib use 1–30 days vs. nonspecific NSAID use: 0.8 (0.5, 1.3) Celecoxib use >30 days vs. nonspecific NSAID use: 0.9 (0.7, 1.2) | Dose, duration had no effect; but presence of renal disease, liver disease, or congestive heart failure appeared in increase risk for rofecoxib users
Solomon, 2008^114^ Medicare database (1999–2004) N=140, 437 | Medicare beneficiaries also eligible for a drug benefits program for older adults and enrolled for at least 12 continuous months during 1999 to 2003 | New user: No use in 180 days prior to the study, initiated drug during study Continuous user: No gap longer than 15 days between successive prescription periods | Age: Mean 80 years Female: 86% Non-white race: 7% | Retrospective cohort study | Age, sex, race, hospitalized, nursing home resident, physician visits, number of different medications, myocardial infarction, CHF, coronary revascularization, angina, diabetes, hypertension, hyperlipidemia, statin use, clopidogrel use, peripheral vascular disease, stroke, carotid revascularization, chronic renal disease, rheumatoid arthritis, osteoarthritis, malignancy, number of comorbid conditions | A. Celecoxib; B. Diclofenac; C. Ibuprofen; D. Naproxen; E. Other nonspecific NSAID | NR | Hospitalization for myocardial infarction, stroke, or congestive heart failure; or out-of-hospital death attributable to cardiovascular disease: 8.5 to 15/1000 person-years | New user vs. nonuser: adjusted HR (95% CI); A. 0.89 (0.83, 0.94); B. 0.91 (0.74, 1.13); C. 0.96 (0.83, 1.10); D. 0.79 (0.67, 0.93); E. 0.87 (0.79, 0.96) | Ibuprofen associated with additional 3.4 CVD events/1000 person-years in patients >80 years old, and additional 11.4 CVD events/1000 person-years in persons with prior myocardial infarction
Velentgas 2005^146^ Insurance claims/administrative records of United Healthcare (1/1/99 to 6/30/01) N=424,584 | Patients aged 40–64 who received at least one dispensing of rofecoxib, celecoxib, naproxen, ibuprofen, or diclofenac in oral tablet or capsule from 1/1/99 to 6/30/01 | Current use: Use began on day of new medication dispensing and continued through the number of days supplied Recent use: Began the day following the last day of current use and continued for 60 days | Age: range 21% to 24% for 50–54 years, 14% to 21% for 55–59 years Female: 57% Race: Not reported | Retrospective cohort study | Age, sex, and prior history of vascular event | A. Celecoxib; B. Naproxen; C. Ibuprofen or diclofenac | NR | Acute coronary syndrome or myocardial infarction: 8.0 to 10/1000 person-years | Current NSAID use vs. current ibuprofen or diclofenac use: adjusted RR (95% CI); A. 1.03 (0.83, 1.27); B. 1.14 (0.93, 1.39); Recent NSAID use vs. current ibuprofen or diclofenac use: adjusted RR (95% CI); A. 0.91 (0.70, 1.17); B. 0.86 (0.70, 1.04); C. 1.00 (0.83, 1.20) | No dose-relationship; increased risk for males and for individuals with a cardiac history, peripheral arterial disease, diabetes, beta blocker use, nitrate use

AMI = acute myocardial infarction; ASA = aspirin; BMI = body mass index; CHD = coronary heart disease; CHF = congestive heart failure; CI = confidence interval; COPD = chronic obstructive pulmonary disease; COX = cyclo-oxygenase; CV = cardiovascular; CVD = cardiovascular disease; GP = general practitioner; GPRD = General Practice Research Database; HF = heart failure; HRT = hormone replacement therapy; LDL = low-density lipoprotein (cholesterol); MI = myocardial infarction; NSAID = nonsteroidal anti-inflammatory drug; NA = not applicable; NR = not reported; OR = odds ratio; PACE = Pharmaceutical Assistance Contract for the Elderly; PAAD = Pharmaceutical Assistance Program for the Aged and Disabled, RR = relative risk; SSRI = selective serotonin reuptake inhibitor; TARGET = Therapeutic Arthritis Research and Gastrointestinal Event Trial; UK = United Kingdom

Gastrointestinal Safety in Observational Studies

Author, Year Data Dource Sample Size | Population | Categorization of Exposure | Demographics (age, Gender, Race) | Study Design/Type | Adjusted Variables, Selection of Controls (for Case-Control Studies) | NSAIDs Evaluated | Outcome: Incidence | Results | Effects of Confounders, Dose, Duration | Notes
Garcia-Rodriguez, 2001^98^ UK General Practice Research Database (4/2003–10/2008); Cases=2,105 Controls=11,500 | Age 40–79 years; enrolled with the General Practitioner free of cancer, esophageal varices, Mallory-Weiss disease, liver disease, coagulopathies, and alcohol-related disorders at start date | Current use: prescription lasted until the index date or ended in the 30 days before the index date Recent use: prescription ended 31–90 days before index date Past use: 91–180 days before the index date Non-use: no recorded use in the 6 months before index date Duration evaluated by adding periods of an interval of < 2 months between 2 prescriptions (“consecutive” prescriptions) Dose-response for Acetaminophen:; 1. ≤1,000g; 2. 1,001–1,999; 3. 2,000; 4. 2,001–3,999; 5. ≥ 4,000g | Age= 40–79 years Male and Female Race not reported | Nested, case-control | Age, sex, calendar year, smoking, antecedents to of upper GI disorders and use of possible meds with interactions Controls frequency matched by age and sex (randomly selected index-date) | A. Etodolac; B. Ibuprofen; C. Ketoprofen; D. Nabumetone; E. Tenoxicam; F. Meloxicam; G. Naproxen; H. Diclofenac; I. Flurbiprofen; J. Indomethacin; K. Piroxicam | Codes for UGIC:; 1. Bleed/perforation in stomach or duodenum; 2. Clinical diagnosis of peptic ulcer with referral to consultant or admitted to a hospital; a. Uncomplicated ulcer NSAID use: 16.0/1,000 person-years; b. Complicated ulcer NSAID use: 24.6/1000 person-years; ^*^Case status validated by a random sample of 100 patients; 99% had confirmed UGIC) | Adjusted RR (95% CI) Acetaminophen vs. nonuse: 1.3 (1.1–1.5) NSAIDs vs. nonuse; A. Etodolac: 2.2 (0.4–11.3); B. Ibuprofen: 2.5 (1.9, 3.4); C. Ketoprofen: 3.3 (1.9, 5.9); D. Nabumetone: 3.4 (1.1, 10.6); E. Tenoxicam: 3.4 (0.9, 13.1); F. Meloxicam: 3.8 (0.8, 17.2); G. Naproxen: 4.0 (2.8, 5.8); H. Diclofenac: 4.6 (3.6, 5.8); I. Flurbiprofen: 4.6 (2.0, 10.9); J. Indomethacin: 5.2 (3.2, 8.3); K. Piroxicam: 6.2 (3.7, 10.1) | Dose: Acetaminophen ≥2g had greater risk of UGIC compared to lower doses and risk of dose-response increase was independent of duration Dose NSAIDs: Medium or lower daily dose, 2.5 (CI 1.9–3.1) High daily dose, 4.9 (CI 4.1–5.8) Substantial interaction when taking NSAIDs and ≥2 g or more of acetaminophen | Etodolac, nabumetone, meloxicam: risk estimates compatible with average NSAID; small sample size per NSAID resulted in wide CI’s
Garcia-Rodriguez, 2007^102^ UK Health Improvement Network database (1/2000–2005) Cases=1,561 Controls=10,000 | Age 40–85 years enrolled at least 2 years with GP and 1 year since first recorded prescription without cancer, esophageal varices, Mallory-Weiss syndrome, coagulopathies, alcohol-related disorders and liver disease | Prescription records; duration determined by consecutive prescriptions (less than 2 months between prescriptions) | Mean age, gender, race not reported | Nested, case-control | Age, sex, calendar year, GP visits, smoking, alcohol consumption, history of peptic ulcer disease, use of aspirin, anticoagulants and steroids Controls random date matched (based on case length follow-up) | A. Aceclofenac; B. Acemetacin; C. Apazone; D. Azapropazone, Celecoxib; E. Diclofenac; F. Diflunisal; G. Etodolac, Etoricoxib; H. Fenbufen; I. Fenoprofen; J. Flurbiprofen; K. Ibuprofen; L. Indomethacin; M. Ketoprofen; N. Ketorolac; O. Mefenamic acid; P. Meloxicam; Q. Nabumetone; R. Naproxen; S. Piroxicam Rofecoxib; T. Sulindac; U. Tenoxicam; V. Tiaprofenic acid; W. Valdecoxib | Upper GI complications, bleeding or perforations | Adjusted RR of upper GI complications – Celecoxib 2.7 (CI 1.5 to 4.1^*^) Ibuprofen 2.0 (CI 1.4 to 2.9) Meloxicam 2.7 (CI 1.4 to 4.3^*^) Diclofenac 3.7 (CI 2.4 to 4.2^*^) Ketoprofen 5.4 (CI 1.5 to 16.1^*^) Indomethacin 7.2 (CI 3.8 to 13.8^*^) Naproxen 8.1 (CI 4.9 to 12.2^*^) ^*^CIs estimated based on graph | Non-use vs. current steroid use RR 1.4 (CI 1.0 to 1.9) Non-use vs. past steroid use RR 1.1 (CI 0.8 to 1.5) Non-use vs. current aspirin use RR 1.1 (CI 1.5 to 2.0) Non-use vs. recent aspirin use RR 1.7 (CI 1.3 to 2.2) Non-use vs. current warfarin use RR 2.0 (CI 1.5 to 2.6) Non-use vs. past warfarin use RR 1.6 (CI 0.9 to 2.8)
Hippisley-Cox, 2005 136 367 general practices in the UK contributing to the QRESEARCH database (8/1/00–7/31/04) Cases: 9407 Controls: 88,867 | Age ≥ 25 with first ever upper GI event and ≥ 3 yrs of recorded medical data | Grouped by usage and type (COX-2 inhibitor), other NSAIDS, and aspirin Non-use: no prescription in past 3 years Past use: prescribed > 90 days of index date Current use: prescribed ≤ 90 days of index date | Age at index date, Median (IQR): Cases: 68 years, (53–79) Controls: 67 years, (52–78) Gender (% Female): Cases: 47.2 Controls: 52.8 Race not reported | Nested, case-control | Smoking, obesity, Townsend score (comparable to SES), ulcer healing drugs, antidepressants, statins, and comorbidities (i.e., diabetes) Controls matched up to 10 per case by age, calendar time, sex and general practice | A. Celecoxib; B. Other selective NSAIDs; C. Ibuprofen; D. Diclofenac; E. Naproxen; F. Other non-selective NSAIDs | Complicated GI event (those involving hemorrhage, perforation, or surgery) Overall incidence: 1.36 per 1000 p-years (95% CI 1.34 to 1.39) | Adjusted Odds Ratio (95% CI): Past use vs. non-use; A. 1.00 (0.77 to 1.29); B. 0.87 (0.69 to 1.10); C. 1.05 (0.96 to 1.15); D. 1.09 (0.99 to 1.19); E. 1.06 (0.89 to 1.26); F. 1.08 (0.94 to 1.24); Current Use vs. non-use; A. 1.25 (0.91 to 1.72); B. 1.72 (1.29–2.29); C. 1.58 (1.37–1.83); D. 2.07 (1.82–2.35); E. 1.97 (1.48–2.61); F. 1.59 (1.29 to 1.96); Aspirin: Past use vs. non-use 1.64 (1.49, 1.81) Current Use vs. non-use 1.60 (1.49, 1.72) | Increase incidence of peptic ulcer or gastrointestinal hemorrhage Reduction in GI adverse events in NSAIDs with concurrent use of ulcer healing drugs
Lanas 2006^104^ Hospitals in the Spanish Association of Gastroenterology (2001–2005) Cases=2,777 Controls=5,532 | Age 20–85 years free of liver disease, coagulation disorders or malignancies, excluding GI varices, vascular lesions, tumors, Mallory-Weiss syndrome, coagulopathy and esophagitis | Current use: drug taken up to 7 days prior to index date Past use: drug taken more than 7 days prior to index date | Mean age 61 years Gender, race not reported | Case-control | Age, sex, calendar semester, ulcer history, nitrate use, oral anticoagulants, antiplatelets, acid-suppressing drugs, NSAIDs, coxibs and aspirin Controls age-matched based on hospital admission of outpatient visit for reasons considered to be unrelated to NSAIDs | A. Aceclofenac; B. Diclofenac; C. Ibuprofen; D. Indomethacin; E. Ketoprofen; F. Ketorolac; G. Lornoxicam; H. Meloxicam; I. Naproxen; J. Piroxicam | Clinically confirmed hospitalization due to GI bleeding | Adjusted RR, upper GI bleeding - Non-use vs. current use RR 5.3 (CI 4.5 to 6.2) Non-use vs. past use RR 0.9 (CI 0.7 to 1.2) Non-use vs. low/medium dose RR 4.0 (CI 3.2 to 5.0) Non-use vs. high dose RR 6.8 (CI 5.3 to 8.8) Non-use vs. use 1–30 days RR 7.6 (CI 6.0 to 9.5) Non-use vs. use 90 days RR 7.3 (CI 4.0 to 13.2) Non-use vs. use 91–365 days RR 2.6 (CI 1.6 to 4.1) Non-use vs. use >365 days RR 2.5 (CI 1.8 to 3.4) | -- | --
Laporte 2004^105^ 18 hospitals in Spain and Italy (9/1998–12/2001) Cases=2,813 Controls=7193 | Patients aged > 18 years admitted with primary diagnosis of acute upper GI bleeding, acute lesions of gastric mucosa, erosive duodenitis, or mixed lesions | Any use in the 7 days before the index day | > 18 years of age Male and female Race not reported | Case-control | History of peptic ulcer, diabetes, heart failure, smoking, alcohol consumption, SSRIs and other medications with possible interactions Controls: randomly selected and matched according to center, date of admission (within 2 months), sex and age (+/− 5 years) | A. Diclofenac; B. Ibuprofen; C. Indomethacin; D. Ketoprofen; E. Ketorolac; F. Meloxicam; G. Naproxen; H. Nimesulide; I. Piroxicam; J. Other NSAIDs | Upper GI bleeding | Adjusted Odds Ratio (95%): Exposed vs. non-exposed Acetaminophen: 1.2 (1.0, 1.5) NSAIDs; A. 3.7 (2.6, 5.4); B. 3.1 (2.0, 4.9); C. 10.0 (4.4, 22.6); D. 10.0 (3.9, 25.8); E. 24.7 (8.0, 77.0); F. 5.7 (2.2, 15.0); G. 10.0 (5.7, 17.6); H. 3.2 (1.9, 5.6); I. 15.5 (10.0, 24.2); J. 3.6 (2.0, 6.8) | Risk increased with dose, history of peptic ulcer and/or upper GI bleeding, and use of antiplatelet drugs | Excluded patients on anticoagulants
Mellemkjaer 2002^107^ Pharmaco-Epidemiologic Database of North Jutland (1991–1995) n=156,138 | Age range not reported, but <16 year or >105 years excluded; other exclusions due to alcoholism, esophageal varices, Mallory-Weiss syndrome, liver cirrhosis; cancer | Dispensed prescriptions based on database information | Mean age not reported; 70% (110,062/156,138) <60 years; 12% (19,307/156,138) 60–69 years; 17% (26,768/156,138) >70 years 55% female Race not reported | Retrospective cohort | Sex, five-year age group, 1 -year calendar period | | Hospitalization for upper GI bleeding | Relative risk, hospitalization due to UGIC, non-use vs.: Diclofenac RR 4.9 (3.5–6.6) Ibuprofen RR 2.4 (2.0–2.9) Indomethacin RR 4.3 (2.9–6.0) Ketoprofen RR 6.3 (4.5–8.5) Naproxen RR 3.0 (2.1–4.2) Piroxicam RR 5.0 (3.3–7.2) | Women 4.2 (CI 3.7 to 4.8) Men 2.9 (CI 2.4 to 3.4)
Rahme, 2007 Arthritis and Rheumatism130 Health care records and hospital records of patients in Quebec Canada including those with OA (1997 to 12/2002) | Patients of 65 years of age or older who filled a prescription for acetaminophen or a NSAIDs. | The number of days of supply for each NSAID or acetaminophen prescription with a grace period of 25%. | Age ≥ 65 years Male: 45% | Retrospective cohort | Age, gender, alcohol/drug use, co-morbidities (e.g., COPD) and other drugs | | First hospitalization for AMI or GI bleed | Adjusted HR (95% CI) for GI bleed with acetaminophen as a reference; A. 0.82 (0.66–1.01); B. 1.11 (0.56–2.16); C. 1.18 (0.86–1.62); D. 2.75 (2.05–3.69); Adjusted HR (95% CI) in patients with OA of AMI or GI bleed; A. 1.13 (0.92–1.40); B. 0.61 (0.19–1.91); C. 1.54 (1.12–2.11); D. 1.86 (1.23–2.80) | Aspirin use with a NSAID increased risk of GI bleed
Rahme 2007^130^ Quebec government health insurance database and hospital discharge summary database (RAMQ and Med-Echo) (1/1998 to 12/2004) N=644,183 | Patients 65 years old or older who filled a prescription for acetaminophen or a NSAIDs with or w/o PPI versus those taking acetaminophen alone. | The number of days of supply for each NSAID or acetaminophen prescription. Exposure was designated to be 1.25 times number of days supplied). Doses of ≤3 g/day of acetaminophen and/or NSAIDs. | Age ≥65 years Male: 39% | Retrospective cohort | Aspirin, anticoagulants, clopidogrel and other baseline characteristics | A. Acetaminophen ≤3 g/day; B. Acetaminophen > 3 g/day; C. Acetaminophen and NSAIDs; D. NSAIDs | Number of GI hospitalizations (crude rate/1,000 patient-years); A. 640 (4.3); B. 234 (4.9); C. 68 (8.6) | Adjusted HR (95% CI): with acetaminophen ≤ 3g/day (Upper and Lower GI hospitalizations); A. Reference; B. 1.20 (1.03–1.40); C. 2.55 (1.98–3.28); D. 1.63 (1.44–1.85); Users of PPI:; A. 0.95 (0.81–1.11); B. 1.16 (0.94–1.43); C. 2.15 (1.35–3.40); D. 1.07 (0.82–1.39) | NSAIDs and acetaminophen increase GI risk, PPIs were not protective
Rahme 2007^130^ Quebec government health insurance database and hospital discharge summary database (RAMQ and Med-Echo) (1/1998 to 12/2004) N=644,183 | Patients of 65 years of age or older who filled a prescription for acetaminophen or a NSAIDs with or w/o PPI versus those taking acetaminophen alone. | The number of days of supply for each NSAID or acetaminophen prescription. Exposure was designated to be 1.25 times number of days supplied). Doses of ≤ 3 g/day of acetaminophen and/or NSAIDs. | Age ≥65 years Male: 39% | Retrospective cohort | Aspirin, anticoagulants, clopidogrel and other baseline characteristics | A. Celecoxib; B. Ibuprofen; C. Diclofenac; D. Naproxen | Hospitalization for GI bleeding or acute MI | Celecoxib: HR 0.82 (CI 0.66 to1.0) Ibuprofen: HR 1.1 (CI 0.56 to 2.2) Diclofenac: HR 1.2 (CI 0.86 to 1.6) Naproxen: HR 2.8 (CI 2.0 to 3.7) | Celecoxib + aspirin: HR 1.85 (CI 1.48 to 2.31) Ibuprofen + aspirin: HR 1.81 (CI 0.75 to 4.40) Diclofenac + aspirin: HR 3.06 (CI 2.16 to 4.35) Naproxen + aspirin: HR 2.37 (CI 1.40 to 3.99)

AMI = acute myocardial infarction; CI = confidence interval; COPD = chronic obstructive pulmonary disease; COX = cyclo-oxygenase; GI = gastrointestinal; GP = general practitioner; HR = hazard ratio; MI = myocardial infarction; NSAID = nonsteroidal anti-inflammatory drug; OA = osteoarthritis; PPI = proton pump inhibitor; RR = relative risk; SES = socioeconomic status; SSRI = selective serotonin reuptake inhibitor; UGIC = upper gastrointestinal complecations; U.K. = United Kingdom; VA = Veterans Affairs