# Quality Assessment of Trials, Systematic Reviews, and Observational Studies^*^

Trials

Author, Year | Randomization Adequate? | Allocation Concealment Adequate? | Groups Similar at Baseline? | Eligibility Criteria Specified? | Outcome Assessors Masked? | Care Provider Masked? | Patient Masked? | Reporting of Attrition, Crossovers, Adherence, and Contamination? | Loss to Followup and Attrition: Differential/High? | Intention-to-Treat Analysis? | Quality Rating | Funding
Chan, 2007^235^ | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear | Yes; Unclear; Yes; Yes | Yes; No | Yes | Fair | Research grant
Chan, 2010^295^ | Yes | Yes | Yes | Yes | No | Yes | Yes | Yes; No; Yes; No | Yes; Yes | Yes | Fair | Pfizer
Cheung, 2010^82^ | Yes | Unclear | Yes | Yes | Unclear | Yes | Yes | Yes; No; No; No | No; No | Yes, >95% included in ITT | Fair | Pfizer
Dahlberg, 2009^52^ | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | No; No; Yes; No | No; Yes | Yes | Fair | Pfizer
Dequeker, 1998^60^ | Unclear | Unclear | Yes | No | Unclear | Unclear | Yes | No; No; No; No | No; No | No | Fair | Boehringer Ingelheim
Dickson, 1991^298^ | Unclear | Unclear | Yes | Yes | Unclear | Yes | Yes | Yes; No; No; No | No; Yes | No | Fair | Pfizer Ltd.
Emery, 2008^53^ | Yes | No | No | Yes | Unclear | Yes | Yes | Yes; No; Yes; No | Yes; Yes | No | Fair | Pfizer
Feng, 2008^116^ | Unclear | Unclear | Yes | Yes | Yes | Yes | Yes | No; No; Yes; No | Unclear; Unclear | No | Fair | Chinese Government
Furst, 2001^61^ | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | No; No; No; No | No; No | No | Fair | Boehringer Ingelheim
Goldstein, 2000^88^ | Yes | Unclear | Yes | Yes | Unclear | Unclear | Unclear | No; No; No; No | No; No | Yes | Fair | GD Searle; Pfizer
Goldstein, 2007^254^ | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes, No, No, No | Yes, No | No | Fair | TAP pharmaceuticals
Goldstein, 2010^253^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes; No; Yes; No | No, Yes | Yes | Fair | AstraZeneca
Hawkey, 1996^63^ | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | No; No; No; No | No; No | Unclear | Fair | NR
Herrero-Beaumont, 2007^206^ | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | Yes; No; Yes; No | No; Yes | Yes | Fair | Rottapharm
Hosie, 1996^64^ | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | No; No; No; No | No; No | Yes | Fair | NR
Kahan, 2009^209^ | Yes | Unclear | Yes | Yes | Yes for radiographs, Unclear for other outcome assessment | Yes | Yes | Yes; No; Yes; No | No; Yes (32% at 2 years) | Yes | Fair | IBSA and Genevrier Laboratories
Kosuwon 2010^312^ | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes; NA; Yes; No | No; No | Yes, >95% included in ITT | Fair | Faculty of Medicine, Khon Kaen University and Bangkok Drug Company
Linden, 1996^66^ | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | No; No; No; No | No; No | No | Fair | NR
Mazieres, 2007^210^ | Yes | Unclear | Yes | Yes | Unclear | Yes | Yes | Yes; No; Yes; No | No; No | Yes | Fair | Pierre Fabre Company
McKenna, 1998^284^ | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | No; No; No; No | No; No | Yes | Fair | NR (Pharmacia)
Messier, 2007^213^ | Unclear | Unclear | No | Yes | Unclear | Yes | Yes | Yes; No; Yes; No | No; No | Yes | Fair | Rexall Sundown
Michel, 2005^211^ | Yes | Unclear | Yes | Yes | Yes for reading radiographs, Unclear for other outcome assessment | Yes | Yes | Yes; No; Yes; No | No; Yes | Yes | Fair | NR
Moller, 2010^212^ | Yes | Unclear | Yes | Yes | Unclear | Yes | Yes | Chondroitin: 9.4% Placebo: 20% | Yes; No | No | Fair | Bioiberica
Rother, 2007^299^ | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | Yes; Yes; Yes; No | No; No | Yes | Good | IDEA AG and McNeall Consumer and Specialty Pharmaceuticals
Rozendaal, 2008^207^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes; No; Yes; No | No; No | Yes | Good | Erasmus Medical Center
Sandelin, 1997^300^ | Unclear | Unclear | Yes | Yes | Unclear | Yes | Yes | Unclear; No; No; No | Unclear; Unclear | Yes | Fair | NR
Sawitzke, 2008^214^ Sawitzke, 2010^215^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes; No; Yes; No | No; No | Yes | Good | NIH
Scheiman, 2006^261^ | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes, No, No, No | Yes, No | Yes | Fair | AstraZeneca
Silverstein, 2000^54^ | Yes | Yes | Yes | Yes | Yes | Unclear | Yes | No; No; No; No | No; No | No | Good | Pharmacia
Simon, 2009^301^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes; No; No; No | No; No | Yes | Good | Nuvo Research Inc
Temple, 2006^183^ | Yes | No | Yes | Yes | No | Yes | Yes | Yes; No; Yes; No | Yes; Yes | Yes | Fair | McNeil Consumer & Specialty Pharmaceuticals
Tiso, 2010^302^ | Yes | Yes | Yes | Yes | No | No | No | Yes; No; No; No | No; No | Yes | Fair | Helm Pharmaceuticals
Tugwell, 2004^303^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes; No; Yes; No | No; No | Yes | Good | Dimethaid Healthcare Ltd.
Underwood, 2007^49^ | Yes | Yes | Yes | Yes | No | No | No | Yes; Yes; Yes; Yes | No; Yes | No | Fair | NHS Health Technology Programme
Valat, 2001^67^ | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | No; No; No; No | No; No | Yes | Fair | NR
Wilkens, 2010^208^ | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | Yes; No; Yes; No | No; No | Yes | Good | Norwegian Foundation for Health and Rehabilitation
Wojtulewski, 1996^68^ | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | No; No; No; No | No; No | Yes | Fair | NR

* Quality ratings for the original 2006 CER available at: Chou R, Helfand M, Peterson K, Dana T, Roberts C. Comparative effectiveness and safety of analgesics for osteoarthritis. Comparative Effectiveness Review No.6 (Prepared by the Oregon Evidence-based Practice Center under Contract No. 290-02-0024.). Rockville, MD: Agency for Healthcare Research and Quality, 2006. AHRQ Publication No. 06-EHC009.

NA = not applicable; NR = not reported; NSAID = nonsteroidal antiinflammatory drug; QR = quality result; RA = rheumatoid arthritis

Systematic Reviews

Author, Year | A Priori Design Provided? | Duplicate Study Selection and Data Extraction? a. Study Selection b. Data Extraction | Comprehensive Literature Search Performed? | Status of Publication Used as an Inclusion Criteria? | List of Studies (Included and Excluded) Provided? | Characteristics of the Included Studies Provided? | Scientific Quality of Included Studies Assessed and Documented? | Scientific Quality of the Included Studies Used Appropriately in Formulating Conclusions? | Methods Used to Combine the Findings of Studies Appropriate? | Likelihood of Publication Bias Assessed? | Conflict of Interest Stated? a. Systematic Review b. Individual Studies | Quality Rating
Bjordal, 2007^197^ | Yes | Unclear; Unclear | Yes | Yes | Yes; No | Yes | | Yes | Yes | No | Yes; No | Fair
Caldwell, 2006^111^ | Yes | Yes; Yes | Yes | Yes | Yes; No | Yes | No | No | Yes | Yes | Yes; No | Fair
Chen et al., 2008^58^ | Yes | Yes; Yes | Yes | Yes | Yes;Yes | Yes | Yes | Yes | Yes | No | Yes; No | Good
Hochberg, 2010^199^ | Yes | Unclear; Yes | No | Unclear | No | Yes | Yes | Yes | Yes | No | Yes; No | Fair
Juni, 2004^127^ | Yes | Unclear; Yes | Yes | Yes | Yes; No | Yes | Yes | Yes | Yes | Yes | Yes; Yes | Good
Kearney et al., 2006^121^ | Yes | Unclear; Unclear | Yes | Yes | Yes; No | Yes | No | No | Yes | Yes | Yes; No | Fair
Lee, 2004^179^ | Yes | Unclear; Unclear | Yes | Yes | Yes; Yes | Yes | Yes | Yes | Yes | Yes | Yes; Yes | Good
Lee, 2010^200^ | Unclear | Unclear; Unclear | Yes | No | No | Yes | Yes | Unclear | Yes | Yes | No; No | Fair
Masso Gonzalez, 2010^97^ | Yes | Unclear; Yes | No | No | Yes; No | Yes | No | No | Yes | No | Yes; No | Fair
Moore, 2005^51^ | Yes | Unclear; Unclear | Yes | Yes | Yes; No | No | Yes | No | No | Yes | Yes; Yes | Fair
Niculescu, 2009^170^ | Yes | No; No | No | Yes | No | Yes | Yes | No | Unclear | No | Yes; No | Poor
Rostom, 2007^81^ | Yes | Yes; Yes | Yes | Yes | Yes; No | Yes | Yes | Yes | Yes | No | No; No | Fair
Rostom, 2002^264^ | Yes | Yes; Yes | Yes | Yes | Yes; No | No | Yes | Yes | No | Yes | Yes; No | Fair
Rubenstein, 2004^166^ | Yes | Yes; Yes | Yes | Yes | Yes; Yes | Yes | Yes | Yes | NA | No | Yes; No | Good
Solomon, 2008^114^ | Yes | Unclear; Yes | Unclear | Yes | Yes; No | Yes | No | No | No | Yes | Yes; Yes | Fair
Soni, 2009^165^ | Unclear | No; Unclear | No | No | Yes; No | Yes | No | No | Yes | No | Yes; No | Fair
Towheed, 2006^180^ | Yes | Yes; Yes | Yes | Yes | Yes; Yes | Yes | Yes | Yes | Yes | Yes | Yes; Yes | Good
Towheed, 2006^70^ | Yes | Yes; Yes | Yes | Yes | Yes; No | Yes | Yes | Yes | Yes | No | Yes; No | Fair
Trelle 2011^115^ | Yes | Yes; Yes | Yes | Yes | Yes; No | Yes | Yes | Yes | Yes | Yes | Yes; No | Good
Vlad, 2007^201^ | Yes | Unclear; Unclear | Yes | Yes | No | No | Yes | Yes | Yes | Yes | Yes; Yes | Good
Watson, 2006^57^ | Yes | Unclear; Unclear | No | Yes | Yes; No | Yes | No | No | No | No | Yes; No | Poor
Wegman, 2004^181^ | Yes | Unclear; Unclear | Yes | Yes | Yes; Yes | Yes | Yes | Yes | Yes | No | Yes; No | Fair
White, 2003^112^ | Yes | Unclear; Unclear | No | Yes | Yes; No | No | No | No | No | No | Yes; Yes | Poor
White, 2007^113^ | Yes | Unclear; Yes | No | Yes | Yes; No | No | No | No | No | No | No; No | Poor
Zhang, 2004^182^ | Yes | Unclear; Yes | Yes | Yes | Yes; Yes | No | Yes | Yes | Yes | Yes | Yes; No | Good
Zhang, 2006^157^ | Unclear | Unclear; Yes | Yes | Unclear | Yes; No | Yes | No | Unclear | Yes | Yes | Yes; No | Fair

RA = rheumatoid arthritis

Cohort Studies

Author, Year | Did the Study Attempt to Enroll all (or a Random Sample of) Patients Meeting Inclusion Criteria, or a Random Sample (Inception Cohort)? | Were the Groups Comparable at Baseline on key Prognostic Factors (e.g., by Restriction or Matching)? | Did the Study use Accurate Methods for Ascertaining Exposures, Potential Confounders, and Outcomes? | Were Outcome Assessors and/or Data Analysts Blinded to Treatment? | Did the Article Report Attrition? | Did the Study Perform Appropriate Statistical Analyses on Potential Confounders? | Is There Important Differential Loss to Followup or Overall High Loss to Followup? | Were Outcomes Prespecified and Defined, and Ascertained Using Accurate Methods? | Quality Rating
Cunnington, 2008^148^ | Yes | No | Yes | Unclear | Unclear | Yes | Unclear | Yes | Fair
Fosbol, 2009^149^ | Yes | No | Unclear | Unclear | Unclear | Yes | Unclear | Yes | Fair
Gislason, 2009^160^ | Yes | No | Yes | Unclear | Yes | Yes | No | Yes | Fair
Hudson, 2005^161^ | Yes | Yes | Yes | Unclear | No | Yes | Unclear | Yes | Fair
Ko, 2002^257^ | Yes | No | Yes | Yes | No | Yes | Unclear | Yes | Fair
Kurth, 2003^260^ | No | Yes | Yes | Yes | Yes | Yes | Unclear | Yes | Fair
Mamdani, 2002^106^ | Yes | No | Yes | Unclear | No | Yes | Unclear | Yes | Fair
Mamdani, 2003^140^ | Yes | Yes | Yes | Unclear | No | Yes | Unclear | Yes | Fair
Mamdani, 2004^162^ | Yes | Yes | Yes | Unclear | No | Yes | Unclear | Yes | Fair
Mann, 2004^109^ | No | N/A | Yes | Unclear | No | No | Unclear | Yes | Fair
Mellemkjar, 2002^107^ | Yes | Unclear | Yes | Unclear | Yes | Unclear | Unclear | Yes | Fair
Patel, 2004^259^ | No | No | Yes | Yes | No | Yes | Unclear | Yes | Fair
Rahme & Nedjar, 2007^108^ Rheumatology | Yes | No | Yes | Unclear | No | Unclear | Unclear | Yes | Fair
Rahme, 2007 Arthritis and Rheumatism130 | Yes | No | Yes | Yes | No | Yes | Unclear | Yes | Fair
Rahme, 2007^130^ Pharmacoepidemiology and Drug Safety | Yes | No | Yes | Unclear | No | Unclear | Unclear | Yes | Fair
Ray, 2007^297^ | Yes | No | Yes | Unclear | No | Yes | Unclear | Yes | Fair
Ray, 2002^142^ | Yes | Yes | Yes | Unclear | No | Yes | Unclear | Yes | Fair
Solomon, 2008^114^ | Yes | Yes | Yes | Unclear | No | Yes | Unclear | Yes | Fair
Solomon 2010^114^ | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Fair
Velentgas, 2006^146^ | Yes | Yes | Yes | Yes | No | No | Unclear | Yes | Fair

Case-Control Studies

Author, Year | Did the Study Attempt to Enroll all or Random Sample of Cases Using Predefined Criteria? | Were the Controls Derived From the Same Population as the Cases? Would They Have Been Selected as Cases if the Outcome was Present? | Were the Groups Comparable at Baseline on key Prognostic Factors (e.g., by Restriction or Matching)? | Did the Study Report the Proportion of Cases and Controls who met Inclusion Criteria That Were Analyzed? | Did the Study use Accurate Methods for Identifying Outcomes? | Did the Study use Accurate Methods for Ascertaining Exposures and Potential Confounders? | Did the Study Perform Appropriate Statistical Analyses on Potential Confounders? | Were Outcomes Prespecified and Defined, and Ascertained Using Accurate Methods? | Quality Rating
Andersohn, 2006^132^ | Yes | Yes; Yes | Yes | No | Yes | Yes | Yes | Yes | Fair
Fischer, 2005^133^ | Yes | Yes; Yes | No | No | Yes | Yes | Yes | Yes | Fair
Garcia-Rodriguez, 2004^134^ | Yes | Yes; Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Fair
Garcia-Rodriguez, 2000^237^ | Yes | Yes; Yes | No | No | Yes | Yes | Yes | Yes | Fair
Garcia-Rodriguez, 2001^98^ | Yes | Yes; Yes | Yes | No | Yes | No | Unclear | Yes | Fair
Garcia-Rodriguez, 2007^102^ | Yes | Yes; Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Graham, 2005^135^ | Yes | Yes; Yes | Yes | No | Yes | Yes | Yes | Yes | Fair
Helin-Salmivaara, 2006^129^ | Yes | Yes; Yes | No | No | Yes | Yes | Yes | Yes | Fair
Hippisley-Cox, 2005^136^ | Yes | Yes; Yes | Yes | No | Yes | Yes | Yes | Yes | Fair
Johnsen, 2005^137^ | Yes | Yes; Yes | Yes | No | Yes | Yes | Yes | Yes | Fair
Kimmel, 2005^138^ | Yes | Yes; Yes | No | No | Yes | Yes | Yes | Yes | Fair
Lanas, 2006^104^ | Yes | Yes; Yes | No | Yes | Yes | Yes | Yes | Yes | Good
Laporte, 2004^105^ | Yes | Yes; Yes | Yes | Unclear | Unclear | Yes | Yes | Yes | Fair
Levesque, 2005^139^ | Yes | Yes; Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Mamdani, 2002^140^ | Yes | No; No | Yes | Unclear | No | Yes | Unclear | Yes | Fair
Mann, 2004^109^ | No | N/A | Yes | Unclear | No | No | Unclear | Yes | Fair
Mellemkjar, 2002^107^ | Yes | Unclear | Yes | Unclear | Yes | Unclear | Unclear | Yes | Fair
Patel, 2004^259^ | Yes | Yes; Yes | Yes | No | Yes | Yes | Yes | Yes | Fair
Rahme&Nedjar, 2007^108^ | Yes | No; No | Yes | Unclear | No | Unclear | Unclear | Yes | Fair
Rahme, 2002^141^ | Yes | Yes; Yes | Yes | Yes | Yes | Yes | Yes | Yes | Fair
Ray, 2007^297^ | Yes | No; No | Yes | Unclear | No | Yes | Unclear | Yes | Fair
Schlienger, 2002^143^ | Yes | Yes; Yes | Yes | No | Yes | Yes | No | Yes | Fair
Solomon, 2002^144^ | Yes | Yes; Yes | Yes | No | Yes | Yes | Yes | Yes | Fair
Solomon, 2004a145 | Yes | Yes; Yes | Unclear | No | Yes | Yes | Yes | Yes | Fair