# Inclusion and Exclusion Criteria

Abstract-Level Eligibility Criteria

Study Characteristic | Inclusion/Exclusion
Population | Include: all ages >18; patients with osteoarthritis (for studies reporting benefits or harms); patients with rheumatoid arthritis, Alzheimer’s or enrolled in cancer prevention trials (for studies reporting harms) Exclude: Juvenile populations; Post-surgical pain patients
Interventions | Include: acetaminophen, aspirin, celecoxib, chondroitin, diclofenac, diflunisal, etodolac, fenoprofen, flurbiprofen, glucosamine, ibuprofen, indomethacin, ketoprofen, ketorolac, meclofenamate sodium, mefenamic acid, meloxicam, nabumetone, naproxen, oxaprozin, piroxicam, salsalate, sulindac, tolmetin Exclude: all other medications, including COX-2 and other drugs included in previous report but no longer FDA approved for use in the United States
Comparators | Include: any above medication, placebo Exclude: drugs not included in this review
Outcomes | Include: Improvements in osteoarthritis symptoms; Adverse events: any cardiovascular, gastrointestinal, renal toxicity, hepatic toxicity; quality of life; sudden death
Timing/Duration | Include any study duration (no minimum exposure)
Setting | Include primary care or specialty setting
Study Design | Include: RCT, cohort, case control, systematic review, meta-analysis

Full-Text Eligibility Criteria

Study Characteristic | Inclusion/Exclusion
Population | Include: all ages >18; patients with osteoarthritis (for studies reporting benefits or harms); patients with rheumatoid arthritis, Alzheimer’s or enrolled in cancer prevention trials (for studies reporting harms) Exclude: Juvenile populations; post-surgical pain patients
Interventions | Include: acetaminophen, aspirin, celecoxib, chondroitin, diclofenac, diflunisal, etodolac, fenoprofen, flurbiprofen, glucosamine, ibuprofen, indomethacin, ketoprofen, ketorolac, meclofenamate sodium, mefenamic acid, meloxicam, nabumetone, naproxen, oxaprozin, piroxicam, salsalate, sulindac, tolmetin Exclude: all other medications, including COX-2 and other drugs included in previous report but no longer FDA approved for use in the United States; combination therapies of multiple NSAIDs
Comparators | Include: any above medication, placebo Exclude: drugs not included in this review
Outcomes | Include: Improvements in osteoarthritis symptoms; Adverse events: any cardiovascular, gastrointestinal, renal toxicity, hepatic toxicity; quality of life; sudden death
Timing/Duration | Include any study duration (no minimum exposure)
Setting | Include primary care or specialty setting
Study Design | Include: RCT, cohort, case control, systematic review, meta-analysis Exclude: cohort or case control study with <1000 patients, dose-ranging study, pharmacokinetics, single-dose study, drug interaction, case report, nonsystematic review