# Exact Search Strings

Original Report

## Ovid MEDLINE Searches (1966 to July Week 3 2005)

### I Search Strategy: NSAIDs, focus on efficacy (OA)

1. exp OSTEOARTHRITIS/ (26153)
2. limit 1 to (humans and english language) (18162)
3. celecoxib.mp. (1545)
4. choline magnesium trisalicylate.mp. (38)
5. DICLOFENAC/ (3399)
6. DIFLUNISAL/ (380)
7. ETODOLAC/ (284)
8. FENOPROFEN/ (257)
9. FLURBIPROFEN/ (1184)
10. IBUPROFEN/ (4177)
11. INDOMETHACIN/ (23527)
12. KETOPROFEN/ (1443)
13. KETOROLAC/ (723)
14. meclofenamate sodium.mp. (51)
15. Mefenamic Acid/ (764)
16. meloxicam.mp. (522)
17. nabumetone.mp. (350)
18. NAPROXEN/ (2378)
19. oxaprozin.mp. (121)
20. PIROXICAM/ (1920)
21. salsalate.mp. (74)
22. SULINDAC/ (923)
23. TOLMETIN/ (1255)
24. valdecoxib.mp. (183)
25. 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 (40472)
26. limit 25 to (humans and english language) (17770)
27. 2 and 26 (1094)
28. Comparative Study/ (1202473)
29. Cohort Studies/ (57012)
30. Randomized Controlled Trials/ (38090)
31. 27 and (28 or 29 or 30) (532)
32. from 31 keep 1–532 (532)

### II Search Strategy: NSAIDs, focus on adverse events (OA & RA)

1. Arthritis, Rheumatoid/ (53548)
2. limit 1 to (humans and english language) (37493)
3. celecoxib.mp. (1545)
4. choline magnesium trisalicylate.mp. (38)
5. *DICLOFENAC/ae [Adverse Effects] (374)
6. *DIFLUNISAL/ae [Adverse Effects] (27)
7. *ETODOLAC/ae [Adverse Effects] (19)
8. *FENOPROFEN/ae [Adverse Effects] (41)
9. *FLURBIPROFEN/ae [Adverse Effects] (41)
10. *IBUPROFEN/ae [Adverse Effects] (356)
11. *INDOMETHACIN/ae [Adverse Effects] (678)
12. *KETOPROFEN/ae [Adverse Effects] (109)
13. *KETOROLAC/ae [Adverse Effects] (16)
14. meclofenamate sodium.mp. (51)
15. *Mefenamic Acid/ae [Adverse Effects] (67)
16. meloxicam.mp. (522)
17. nabumetone.mp. (350)
18. *NAPROXEN/ae [Adverse Effects] (269)
19. oxaprozin.mp. (121)
20. *PIROXICAM/ae [Adverse Effects] (130)
21. salsalate.mp. (74)
22. *SULINDAC/ae [Adverse Effects] (116)
23. *TOLMETIN/ae [Adverse Effects] (74)
24. valdecoxib.mp. (183)
25. 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 (4875)
26. limit 25 to (humans and english language) (3433)
27. 2 and 26 (357)
28. Cohort Studies/ (57012)
29. Comparative Study/ (1202473)
30. Randomized Controlled Trials/ (38090)
31. 27 and (28 or 29 or 30) (128)
32. from 31 keep 1–128 (128)

### III Search Strategy: Aspirin/acetaminophen

1. exp OSTEOARTHRITIS/ (26153)
2. limit 1 to (humans and english language) (18162)
3. ASPIRIN/ (26642)
4. ACETAMINOPHEN/ (8992)
5. 2 and (3 or 4) (323)
6. exp Arthritis, Rheumatoid/ (71858)
7. limit 6 to (humans and english language) (50057)
8. *ASPIRIN/ae [Adverse Effects] (2386)
9. *ACETAMINOPHEN/ae [Adverse Effects] (719)
10. 7 and (8 or 9) (81)
11. 5 or 10 (400)
12. Cohort Studies/ (57012)
13. Comparative Study/ (1202473)
14. Randomized Controlled Trials/ (38090)
15. 11 and (12 or 13 or 14) (158)
16. from 15 keep 1–158 (158)

### IV Search Strategy: Topical analgesics

1. exp OSTEOARTHRITIS/ (26153)
2. limit 1 to (humans and english language) (18162)
3. (topical and capsaicin).mp. [mp=title, original title, abstract, name of substance word, subject heading word] (614)
4. (topical and diclofenac).mp. [mp=title, original title, abstract, name of substance word, subject heading word] (356)
5. (topical and ibuprofen).mp. [mp=title, original title, abstract, name of substance word, subject heading word] (137)
6. (topical and ketoprofen).mp. [mp=title, original title, abstract, name of substance word, subject heading word] (114)
7. (topical and salicylate).mp. [mp=title, original title, abstract, name of substance word, subject heading word] (160)
8. 2 and (3 or 4 or 5 or 6 or 7) (40)
9. exp Arthritis, Rheumatoid/ (71858)
10. 9 and (3 or 4 or 5 or 6 or 7) (11)
11. 8 or 10 (49)
12. from 11 keep 1–49 (49)

## CDSR/CRCT Searches (Through Third Quarter 2005)

### I Search Strategy: NSAIDs, focus on efficacy (OA)

1. exp OSTEOARTHRITIS/ (1546)
2. limit 1 to (humans and english language) (1546)
3. celecoxib.mp. (219)
4. choline magnesium trisalicylate.mp. (29)
5. DICLOFENAC/ (878)
6. DIFLUNISAL/ (90)
7. ETODOLAC/ (70)
8. FENOPROFEN/ (35)
9. FLURBIPROFEN/ (272)
10. IBUPROFEN/ (776)
11. INDOMETHACIN/ (1224)
12. KETOPROFEN/ (299)
13. KETOROLAC/ (279)
14. meclofenamate sodium.mp. (37)
15. Mefenamic Acid/ (92)
16. meloxicam.mp. (133)
17. nabumetone.mp. (141)
18. NAPROXEN/ (645)
19. oxaprozin.mp. (47)
20. PIROXICAM/ (447)
21. salsalate.mp. (31)
22. SULINDAC/ (119)
23. TOLMETIN/ (360)
24. valdecoxib.mp. (56)
25. 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 (5040)
26. limit 25 to (humans and english language)(5040)
27. 2 and 26 (555)
28. Comparative Study/ (96540)
29. Cohort Studies/ (2139)
30. Randomized Controlled Trials/ (4538)
31. 27 and (28 or 29 or 30) (402)

### II Search Strategy: NSAIDs, focus on adverse events (OA & RA)

1. Arthritis, Rheumatoid/ (2385)
2. limit 1 to (humans and english language) (2385)
3. celecoxib.mp. (219)
4. choline magnesium trisalicylate.mp. (29)
5. *DICLOFENAC/ae [Adverse Effects] (39)
6. *DIFLUNISAL/ae [Adverse Effects] (6)
7. *ETODOLAC/ae [Adverse Effects] (3)
8. *FENOPROFEN/ae [Adverse Effects] (2)
9. *FLURBIPROFEN/ae [Adverse Effects] (5)
10. *IBUPROFEN/ae [Adverse Effects] (40)
11. *INDOMETHACIN/ae [Adverse Effects] (61)
12. *KETOPROFEN/ae [Adverse Effects] (9)
13. *KETOROLAC/ae [Adverse Effects] (6)
14. meclofenamate sodium.mp. (37)
15. *Mefenamic Acid/ae [Adverse Effects] (0)
16. meloxicam.mp. (133)
17. nabumetone.mp. (141)
18. *NAPROXEN/ae [Adverse Effects] (62)
19. oxaprozin.mp. (47)
20. *PIROXICAM/ae [Adverse Effects] (19)
21. salsalate.mp. (31)
22. *SULINDAC/ae [Adverse Effects] (11)
23. *TOLMETIN/ae [Adverse Effects] (0)
24. valdecoxib.mp. (56)
25. 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 (846)
26. limit 25 to (humans and english language) [Limit not valid in: CDSR,ACP Journal Club,DARE,CCTR; records were retained] (846)
27. 2 and 26 (98)
28. Cohort Studies/ (2139)
29. Comparative Study/ (96540)
30. Randomized Controlled Trials/ (4538)
31. 27 and (28 or 29 or 30) (73)

### III Search Strategy: Aspirin/acetaminophen

1. exp OSTEOARTHRITIS/ (1546)
2. limit 1 to (humans and english language) (1546)
3. ASPIRIN/ (3028)
4. ACETAMINOPHEN/ (1128)
5. 2 and (3 or 4) (115)
6. exp Arthritis, Rheumatoid/ (2730)
7. limit 6 to (humans and english language) (2730)
8. *ASPIRIN/ae [Adverse Effects] (271)
9. *ACETAMINOPHEN/ae [Adverse Effects] (32)
10. 7 and (8 or 9) (10)
11. 5 or 10 (124)
12. Cohort Studies/ (2139)
13. Comparative Study/ (96540)
14. Randomized Controlled Trials/ (4538)
15. 11 and (12 or 13 or 14) (90)

### IV Search Strategy: Topicals

1. exp OSTEOARTHRITIS/ (1546)
2. limit 1 to (humans and english language) (1546)
3. (topical and capsaicin).mp. [mp=ti, ab, tx, kw, ct, ot, sh, hw] (123)
4. (topical and diclofenac).mp. [mp=ti, ab, tx, kw, ct, ot, sh, hw] (199)
5. (topical and ibuprofen).mp. [mp=ti, ab, tx, kw, ct, ot, sh, hw] (69)
6. (topical and ketoprofen).mp. [mp=ti, ab, tx, kw, ct, ot, sh, hw] (46)
7. (topical and salicylate).mp. [mp=ti, ab, tx, kw, ct, ot, sh, hw] (44)
8. 2 and (3 or 4 or 5 or 6 or 7) (18)
9. exp Arthritis, Rheumatoid/ (2730)
10. 9 and (3 or 4 or 5 or 6 or 7) (6)
11. 8 or 10 (22)

## Current CER Update Search Strings

### Database: Ovid MEDLINE 1996 to January week 2 2011

#### RCTs

1. exp OSTEOARTHRITIS/ (18286)
2. osteoarthriti$.mp. (23317)
3. 1 or 2 (23317)
4. Aspirin/ or aspirin.mp. (20844)
5. acetaminophen.mp. or Acetaminophen/ (7386)
6. Cyclooxygenase 2 Inhibitors/ or celecoxib.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] (7518)
7. capsaicin.mp. or Capsaicin/ (6135)
8. Chondroitin/or chondroitin.mp. (5835)
9. diclofenac.mp. or Diclofenac/ (4611)
10. diflunisal.mp. or Diflunisal/ (162)
11. etodolac.mp. or Etodolac/ (295)
12. fenoprofen.mp. or Fenoprofen/ (106)
13. flurbiprofen.mp. or Flurbiprofen/ (813)
14. Glucosamine/ or glucosamine.mp. (4146)
15. ibuprofen.mp. or Ibuprofen/ (4484)
16. indomethacin.mp. or Indomethacin/ (11590)
17. ketoprofen.mp. or Ketoprofen/ (1574)
18. Ketorolac/ or ketorolac.mp. (1209)
19. meclofenamate.mp. (157)
20. mefenamic acid.mp. or Mefenamic Acid/ (362)
21. meloxicam.mp. (881)
22. nabumetone.mp. (218)
23. naproxen.mp. or Naproxen/ (2158)
24. oxaprozin.mp. (59)
25. piroxicam.mp. or Piroxicam/ (1288)
26. salsalate.mp. (27)
27. sulindac.mp. or Sulindac/ (878)
28. tolmetin.mp. or Tolmetin/ (410)
29. or/4–28 (71421)
30. randomized controlled trial.mp. or exp Randomized Controlled Trial/ (189494)
31. randomized controlled trial.pt. (186325)
32. controlled clinical trial.mp. or exp Controlled Clinical Trial/ (38495)
33. controlled clinical trial.pt. (34791)
34. clinical trial.mp. or exp Clinical Trial/ (404159)
35. clinical trial.pt. (252913)
36. or/30–35 (406908)
37. limit 36 to humans (397588)
38. 3 and 29 and 37 (542)
39. 38 and (200507$ or 200508$ or 200509$ or 20051$ or 2006$ or 2007$ or 2008$ or 2009$ or 2010$).ed. (211)
40. limit 39 to english language (189)
41. limit 39 to abstracts (202)
42. 40 or 41 (210)

#### Systematic Reviews

1. exp OSTEOARTHRITIS/ (18286)
2. osteoarthriti$.mp. (23317)
3. 1 or 2 (23317)
4. Aspirin/ or aspirin.mp. (20844)
5. acetaminophen.mp. or Acetaminophen/ (7386)
6. Cyclooxygenase 2 Inhibitors/ or celecoxib.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] (7518)
7. capsaicin.mp. or Capsaicin/ (6135)
8. Chondroitin/ or chondroitin.mp. (5835)
9. diclofenac.mp. or Diclofenac/ (4611)
10. diflunisal.mp. or Diflunisal/ (162)
11. etodolac.mp. or Etodolac/ (295)
12. fenoprofen.mp. or Fenoprofen/ (106)
13. flurbiprofen.mp. or Flurbiprofen/ (813)
14. Glucosamine/ or glucosamine.mp. (4146)
15. ibuprofen.mp. or Ibuprofen/ (4484)
16. indomethacin.mp. or Indomethacin/ (11590)
17. ketoprofen.mp. or Ketoprofen/ (1574)
18. Ketorolac/ or ketorolac.mp. (1209)
19. meclofenamate.mp. (157)
20. mefenamic acid.mp. or Mefenamic Acid/ (362)
21. meloxicam.mp. (881)
22. nabumetone.mp. (218)
23. naproxen.mp. or Naproxen/ (2158)
24. oxaprozin.mp. (59)
25. piroxicam.mp. or Piroxicam/ (1288)
26. salsalate.mp. (27)
27. sulindac.mp. or Sulindac/ (878)
28. tolmetin.mp. or Tolmetin/ (410)
29. or/4–28 (71421)
30. meta-analysis.mp. or exp Meta-Analysis/ (33804)
31. (cochrane or medline).tw. (33065)
32. search$.tw. (112106)
33. 30 or 31 or 32 (139975)
34. “Review Literature as Topic”/ or systematic review.mp. (19084)
35. 33 or 34 (146484)
36. 3 and 29 and 35 (163)
37. 36 and (200507$ or 200508$ or 200509$ or 20051$ or 2006$ or 2007$ or 2008$ or 2009$ or 2010$).ed. (77)
38. limit 37 to humans (75)
39. limit 38 to english language (72)
40. limit 38 to abstracts (66)

#### Harms

1. Aspirin/ or aspirin.mp. (20844)
2. acetaminophen.mp. or Acetaminophen/ (7386)
3. Cyclooxygenase 2 Inhibitors/ or celecoxib.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] (7518)
4. capsaicin.mp. or Capsaicin/ (6135)
5. Chondroitin/ or chondroitin.mp. (5835)
6. diclofenac.mp. or Diclofenac/ (4611)
7. diflunisal.mp. or Diflunisal/ (162)
8. etodolac.mp. or Etodolac/ (295)
9. fenoprofen.mp. or Fenoprofen/ (106)
10. flurbiprofen.mp. or Flurbiprofen/ (813)
11. Glucosamine/ or glucosamine.mp. (4146)
12. ibuprofen.mp. or Ibuprofen/ (4484)
13. indomethacin.mp. or Indomethacin/ (11590)
14. ketoprofen.mp. or Ketoprofen/ (1574)
15. Ketorolac/ or ketorolac.mp. (1209)
16. meclofenamate.mp. (157)
17. mefenamic acid.mp. or Mefenamic Acid/ (362)
18. meloxicam.mp. (881)
19. nabumetone.mp. (218)
20. naproxen.mp. or Naproxen/ (2158)
21. oxaprozin.mp. (59)
22. piroxicam.mp. or Piroxicam/ (1288)
23. salsalate.mp. (27)
24. sulindac.mp. or Sulindac/ (878)
25. tolmetin.mp. or Tolmetin/ (410)
26. or/1–25 (71421)
27. (ae or co or de).fs. (1917797)
28. (adverse effect$ or adverse event$ or harm$).mp. (125151)
29. 27 or 28 (1980478)
30. rheumatoid arthritis.mp. or Arthritis, Rheumatoid/ (34754)
31. Alzheimer Disease/pc [Prevention & Control] (1442)
32. (alzheimer$ adj2 prevent$).mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] (267)
33. 31 or 32 (1566)
34. Neoplasms/pc [Prevention & Control] (6517)
35. (cancer adj1 prevent$).mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] (6643)
36. 34 or 35 (11729)
37. 30 or 33 or 36 (47989)
38. 26 and 29 and 37 (1011)
39. 38 and (200507$ or 200508$ or 200509$ or 20051$ or 2006$ or 2007$ or 2008$ or 2009$ or 2010$).ed. (332)
40. limit 39 to humans (290)
41. limit 40 to english language (264)
42. limit 40 to abstracts (252)
43. 41 or 42 (278)

### Database: EBM Reviews - Cochrane Central Register of Controlled Trials (fourth quarter 2010)

1. exp OSTEOARTHRITIS/ (2149)
2. osteoarthriti$.mp. (3327)
3. 1 or 2 (3327)
4. Aspirin/ or aspirin.mp. (6044)
5. acetaminophen.mp. or Acetaminophen/ (2083)
6. Cyclooxygenase 2 Inhibitors/ or celecoxib.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (639)
7. capsaicin.mp. or Capsaicin/ (427)
8. Chondroitin/ or chondroitin.mp. (212)
9. diclofenac.mp. or Diclofenac/ (2245)
10. diflunisal.mp. or Diflunisal/ (207)
11. etodolac.mp. or Etodolac/ (154)
12. fenoprofen.mp. or Fenoprofen/ (83)
13. flurbiprofen.mp. or Flurbiprofen/ (499)
14. Glucosamine/ or glucosamine.mp. (171)
15. ibuprofen.mp. or Ibuprofen/ (1769)
16. indomethacin.mp. or Indomethacin/ (2174)
17. ketoprofen.mp. or Ketoprofen/ (687)
18. Ketorolac/ or ketorolac.mp. (909)
19. meclofenamate.mp. (69)
20. mefenamic acid.mp. or Mefenamic Acid/ (196)
21. meloxicam.mp. (160)
22. nabumetone.mp. (137)
23. naproxen.mp. or Naproxen/ (1268)
24. oxaprozin.mp. (48)
25. piroxicam.mp. or Piroxicam/ (900)
26. salsalate.mp. (31)
27. sulindac.mp. or Sulindac/ (249)
28. tolmetin.mp. or Tolmetin/ (421)
29. or/4–28 (17609)
30. 3 and 29 (1357)
31. limit 30 to yr=“2005 -Current” (192)

### Database: EBM Reviews - Cochrane Database of Systematic Reviews (2005 to January 2011)

1. osteoarthriti$.mp. (203)
2. Aspirin/ or aspirin.mp. (303)
3. acetaminophen.mp. or Acetaminophen/ (86)
4. Cyclooxygenase 2 Inhibitors/ or celecoxib.mp. [mp=title, abstract, full text, keywords, caption text] (58)
5. capsaicin.mp. or Capsaicin/ (37)
6. Chondroitin/ or chondroitin.mp. (10)
7. diclofenac.mp. or Diclofenac/ (99)
8. diflunisal.mp. or Diflunisal/ (17)
9. etodolac.mp. or Etodolac/ (17)
10. fenoprofen.mp. or Fenoprofen/ (14)
11. flurbiprofen.mp. or Flurbiprofen/ (24)
12. Glucosamine/ or glucosamine.mp. (17)
13. ibuprofen.mp. or Ibuprofen/ (126)
14. indomethacin.mp. or Indomethacin/ (92)
15. ketoprofen.mp. or Ketoprofen/ (40)
16. Ketorolac/ or ketorolac.mp. (43)
17. meclofenamate.mp. (8)
18. mefenamic acid.mp. or Mefenamic Acid/ (27)
19. meloxicam.mp. (14)
20. nabumetone.mp. (9)
21. naproxen.mp. or Naproxen/ (90)
22. oxaprozin.mp. (5)
23. piroxicam.mp. or Piroxicam/ (33)
24. salsalate.mp. (2)
25. sulindac.mp. or Sulindac/ (21)
26. tolmetin.mp. or Tolmetin/ (8)
27. or/2–26 (536)
28. 1 and 27 (60)
29. limit 28 to full systematic reviews (49)