# Appendixes

Appendix A Comparable NSAID Dose Levels

Appendix B Cyclooxygenase Selectivity of NSAIDs

Appendix C Exact Search Strings

Appendix D Inclusion and Exclusion Criteria

Appendix E Excluded Studies

Appendix F Quality Assessment Methods

Appendix G Quality Assessment of Trials, Systematic Reviews, and Observational Studies

Appendix H Evidence Tables: Oral NSAIDs

Appendix I Evidence Tables: Glucosamine and Chondroitin Studies

Appendix J Evidence Tables: Topical NSAIDs