# Acknowledgements

We would like to acknowledge with appreciation the members of the Technical Expert Panel for their advice and consultation. In addition, we would like to acknowledge Sasha Walia, Tracy Dana, Christina Bougatsos, and Leah Williams for their valuable contributions to this report.