# Acronyms and Abbreviations

ACR: American College of Rheumatology
ADAPT: Alzheimer’s Disease Anti-Inflammatory Prevention Trial
AE: Adverse event
AHRQ: Agency for Healthcare Research and Quality
ALT: Alanine aminotransferase
AMI: Acute myocardial infarction
AMSTAR: Assessment of Multiple Systematic Reviews
APC: Adenoma Prevention with Celecoxib trial
ARAMIS: Arthritis, Rheumatism, and Aging Medical Information System
ARR: Adjusted relative risk
AST: Aspartate aminotransferase
CCOHTA: Canadian Coordinating Office for Health Technology Assessment
CDME: Central Diabetic Macular Edema trial
CER: Comparative effectiveness review
CHD: Coronary heart disease
CHF: Congestive heart failure
CI: Confidence interval
CLASS: Celecoxib Long-term Arthritis Safety Study
CNS: Central nervous system
COX: Cyclooxygenase
CV: Cardiovascular
DMSO: Dimethyl sulphoxide
EPC: Evidence-based Practice Center
FDA: Food and Drug Administration
GI: Gastrointestinal
GAIT: Glucosamine/chondroitin Arthritis Intervention Trial
H2: Histamine 2
HR: Hazard ratio
HTN: Hypertension
INR: Immediate release
JAMA: Journal of the American Medical Association
JSM: Joint space measurement
JSN: Joint space narrowing
JSW: Joint space width
MeSH: Medical Subject Headings
MI: Myocardial infarction
MUCOSA: Misoprostol Ulcer Complications Outcomes Safety Assessment Trial
NIH: National Institutes of Health
NNT: Number needed to treat
NR: Not reported
NRS LBP: Numerical rating scale for low back pain
NS: Not significant
NSAID: Nonsteroidal anti-inflammatory drug
OA: Osteoarthritis
OR: Odds ratio
OMERACT-OARSI: Outcomes Measures in Arthritis Clinical Trials-Osteoarthritis Research Society International
PCT: Placebo-controlled trial
PICOTS: Populations, Interventions, Comparators, Outcomes, Timing and Setting
POBs: Gastric or duodenal perforation, gastric outlet obstruction, or upper gastrointestinal bleeding
PPI: Proton pump inhibitor
PreSAP: Prevention of colorectal sporadic adenomatous polyps
PUBs: Perforations, symptomatic gastroduodenal ulcers, and upper GI bleeding
PUD: Peptic ulcer disease
qd: Once a day (quaque die)
RA: Rheumatoid arthritis
RCT: Randomized controlled trial
RMDQ: Roland Morris Disability Questionnaire
RR: Relative risk
RRR: Relative risk reduction
SCHIP: State Children s Health Insurance
SF-36: Medical Outcomes Short Form-36
SMD: Standardized mean difference
SR: Sustained release
SR: Rystematic review
SUCCESS-1: Successive Celecoxib Efficacy and Safety Study-1
TARGET: Therapeutic Arthritis Research and Gastrointestinal Event Trial
TEP: Technical Expert Panel
tid: Three times a day (ter in die)
UGIB: Upper gastrointestinal bleeding
UK GPRD: United Kingdom General Practice Research Database
VAS: Visual analog scale
VIGOR: Vioxx Gastrointestinal Outcomes Research
WOMAC: Western Ontario and McMaster Universities Osteoarthritis Index