# Technical Expert Panel

Ned Calonge, M.D., M.P.H.

The Colorado Trust

Denver, CO

Robert Christenson, Ph.D.

University of Maryland Medical Center

Baltimore, MD

Chester Fox, M.D.

Jefferson Family Medicine

Buffalo, NY

Robert Hopkins, M.D., FAAP, FACP

University of Arkansas for Medical Sciences

Little Rock, AR

Andrew Levey, M.D.

Tufts University School of Medicine

Boston, MA

Wanda Nicholson, M.D., M.P.H., M.B.A.

University of North Carolina School of Medicine

Chapel Hill, NC

Neil Powe, M.D., M.P.H., M.B.A.

University of California San Francisco

San Francisco, CA

Donna Sweet, M.D., M.A.C.P.

University of Kansas School of Medicine

Wichita, KS

Katrin Uhlig, M.D., M.S.

Tufts University School of Medicine

Boston, MA