# References

1 CDC. National Chronic Kidney Disease Fact Sheet 2010. 2010. Available at: www.cdc.gov/diabetes/pubs/pdf/kidney_Factsheet.pdf. November 12 2010.
2 National Kidney Foundation. K/DOQI clinical practice guidelines for chronic kidney disease: evaluation, classification, and stratification. American Journal of Kidney Diseases. Feb. 2002;39(2 Suppl 1):S1-266. [pmid: 11904577].
3 Matsushita K, van der Velde M, Astor BC, et al. Association of estimated glomerular filtration rate and albuminuria with all-cause and cardiovascular mortality in general population cohorts: a collaborative meta-analysis. Lancet. Jun. 12. 2010;375(9731):2073-81. [pmid: 20483451].
4 Astor BC, Matsushita K, Gansevoort RT, et al. Lower estimated glomerular filtration rate and higher albuminuria are associated with mortality and end-stage renal disease. A collaborative meta-analysis of kidney disease population cohorts. Kidney Int. 2011. Feb. 2. [pmid: 21289598].
5 Gansevoort RT, Matsushita K, van der Velde M, et al. Lower estimated GFR and higher albuminuria are associated with adverse kidney outcomes in both general and high-risk populations. A collaborative meta-analysis of general and high-risk population cohorts. Kidney Int. 2011. Feb. 2. [pmid: 21289597].
6 van der Velde M, Matsushita K, Coresh J, et al. Lower estimated glomerular filtration rate and higher albuminuria are associated with all-cause and cardiovascular mortality. A collaborative meta-analysis of high-risk population cohorts. Kidney Int. 2011. Feb. 9. [pmid: 21307840].
7 Levey AS, de Jong PE, Coresh J, et al. The definition, classification and prognosis of chronic kidney disease: a KDIGO Controversies Conference report. Kidney Int. 2010. Dec. 8. [pmid: 21150873].
8 Levey AS, Stevens LA, Schmid CH, et al. A new equation to estimate glomerular filtration rate. Annals of Internal Medicine. May. 5. 2009;150(9):604-12. [pmid: 19414839].
9 USRDS. United States Renal Data System 2008 Annual Data Report: Atlas of Chronic Kidney Disease and End-Stage Renal Disease in the United States. Bethesda, MD. National Institutes of Health, National Institute of Diabetes and Digestive and Kidney Diseases. 2008. www.usrds.org/adr_2008.htm. Jan. 2010. 2010.
10 Coresh J, Selvin E, Stevens LA, et al. Prevalence of chronic kidney disease in the United States. JAMA. Nov. 7. 2007;298(17):2038-47. [pmid: 17986697].
11 Gilbertson DT, Liu J, Xue JL, et al. Projecting the number of patients with end-stage renal disease in the United States to the year 2015. Journal of the American Society of Nephrology. Dec. 2005;16(12):3736-41. [pmid: 16267160].
12 USRDS. United States Renal Data System 2010 Annual Data Report: Atlas of Chronic Kidney Disease and End-Stage Renal Disease in the United States. Bethesda, MD. National Institutes of Health, National Institute of Diabetes and Digestive and Kidney Diseases. 2010. www.usrds.org/adr_2010.htm. 2010.
13 Go AS, Chertow GM, Fan D, et al. Chronic kidney disease and the risks of death, cardiovascular events, and hospitalization. New England Journal of Medicine. Sep. 23. 2004;351(13):1296-305. [pmid: 15385656].
14 Weiner DE, Tabatabai S, Tighiouart H, et al. Cardiovascular outcomes and all-cause mortality: exploring the interaction between CKD and cardiovascular disease. American Journal of Kidney Diseases. Sep. 2006;48(3):392-401. [pmid: 16931212].
15 Ensrud KE, Lui LY, Taylor BC, et al. Renal function and risk of hip and vertebral fractures in older women. Archives of Internal Medicine. Jan. 22. 2007;167(2):133-9. [pmid: 17242313].
16 Ishani A, Paudel M, Taylor BC, et al. Renal function and rate of hip bone loss in older men: the Osteoporotic Fractures in Men Study. Osteoporosis International. Nov. 2008;19(11):1549-56. [pmid: 18392664].
17 James MT, Quan H, Tonelli M, et al. CKD and risk of hospitalization and death with pneumonia. American Journal of Kidney Diseases. Jul. 2009;54(1):24-32. [pmid: 19447535].
18 Khatri M, Nickolas T, Moon YP, et al. CKD associates with cognitive decline. Journal of the American Society of Nephrology. Nov. 2009;20(11):2427-32. [pmid: 19729443].
19 Wilhelm-Leen ER, Hall YN, M KT, et al. Frailty and chronic kidney disease: the Third National Health and Nutrition Evaluation Survey. Am J Med. Jul. 2009;122(7):664-71.e2. [pmid: 19559169].
20 Rifkin DE, Katz R, Chonchol M, et al. Albuminuria, impaired kidney function and cardiovascular outcomes or mortality in the elderly. Nephrology Dialysis Transplantation. May. 2010;25(5):1560-7. [pmid: 20008829].
21 Ishani A, Grandits GA, Grimm RH, et al. Association of single measurements of dipstick proteinuria, estimated glomerular filtration rate, and hematocrit with 25-year incidence of end-stage renal disease in the multiple risk factor intervention trial. Journal of the American Society of Nephrology. May. 2006;17(5):1444-52. [pmid: 16611715].
22 Ninomiya T, Perkovic V, de Galan BE, et al. Albuminuria and kidney function independently predict cardiovascular and renal outcomes in diabetes. Journal of the American Society of Nephrology. Aug. 2009;20(8):1813-21. [pmid: 19443635].
23 Snyder JJ, Collins AJ. KDOQI hypertension, dyslipidemia, and diabetes care guidelines and current care patterns in the United States CKD population: National Health and Nutrition Examination Survey 1999-2004. Am J Nephrol. 2009;30(1):44-54. [pmid: 19202328].
24 Levey AS, Atkins R, Coresh J, et al. Chronic kidney disease as a global public health problem: approaches and initiatives - a position statement from Kidney Disease Improving Global Outcomes. Kidney Int. Aug. 2007;72(3):247-59. [pmid: 17568785].
25 Executive summary: standards of medical care in diabetes--2011. Diabetes Care. Jan. Suppl 1. 2011;34:S4-10. [pmid: 21193627].
26 McCullough PA, Vassalotti JA, Collins AJ, et al. National Kidney Foundation's Kidney Early Evaluation Program (KEEP) annual data report 2009: executive summary. Am J Kidney Dis. Mar. 2010;55(3 Suppl 2):S1-3. [pmid: 20172443].
27 K/DOQI clinical practice guidelines for chronic kidney disease: evaluation, classification, and stratification. Am J Kidney Dis. Feb. 2002;39(2 Suppl 1):S1-266. [pmid: 11904577].
28 Renal Association T. Chronic Kidney Disease in Adults: UK Guidelines for Identification, Management and Referral of Adults. www.renal.org/CKDguide/full/SupportingEvidence1.htm.
29 American Diabetes Association. Standards of medical care in diabetes--2009. Diabetes Care. Jan. Suppl 1. 2009;32:S13-61. [pmid: 19118286].
30 Chobanian AV, Bakris GL, Black HR, et al. The Seventh Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure: the JNC 7 report. JAMA. May. 21. 2003;289(19):2560-72. [pmid: 12748199].
31 Levey AS, Cattran D, Friedman A, et al. Proteinuria as a surrogate outcome in CKD: report of a scientific workshop sponsored by the National Kidney Foundation and the US Food and Drug Administration. American Journal of Kidney Diseases. Aug. 2009;54(2):205-26. [pmid: 19577347].
32 Nelson RG, Tuttle KR. Prevention of diabetic kidney disease: negative clinical trials with renin-angiotensin system inhibitors. American Journal of Kidney Diseases. Mar. 2010;55(3):426-30. [pmid: 20005029].
33 Hogan M. KDIGO conference proposes changes to CKD classification, but not to the definition. Nephrology Times. 2009;2(12):9-10.
34 Moher D, Pham B, Lawson ML, et al. The inclusion of reports of randomised trials published in languages other than English in systematic reviews. Health Technol Assess. 2003;7(41):1-90. [pmid: 14670218].
35 Relevo R, Balshem H. Finding Evidence for Comparing Medical Interventions. Agency for Healthcare Research and Quality. 2011.
36 Cochrane Handbook for Systematic Reviews of Interventions. Higgins JPT, Green S, editors. Version 5.0.2 [updated September 2009]ed. The Cochrane Collaboration. 2008.
37 Schulz KF, Grimes DA. Allocation concealment in randomised trials: defending against deciphering. Lancet. Feb. 16. 2002;359(9306):614-8. [pmid: 11867132].
38 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
39 Review Manager. 5.0 ed. Copenhagen. The Nordic Cochrane Centre, The Cochrane Collaboration. 2008.
40 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. Bmj. Sep. 6. 2003;327(7414):557-60. [pmid: 12958120].
41 Halbesma N, Kuiken DS, Brantsma AH, et al. Macroalbuminuria is a better risk marker than low estimated GFR to identify individuals at risk for accelerated GFR loss in population screening. J Am Soc Nephrol. Sep. 2006;17(9):2582-90. [pmid: 16899519].
42 USRDS. United States Renal Data System 2009 Annual Data Report: Atlas of Chronic Kidney Disease and End-Stage Renal Disease in the United States. Bethesda, MD. National Institutes of Health, National Institute of Diabetes and Digestive and Kidney Diseases. 2009. www.usrds.org/adr_2009.htm. Jan. 2010. 2010.
43 Ryan TP, Sloand JA, Winters PC, et al. Chronic kidney disease prevalence and rate of diagnosis. Am J Med. Nov. 2007;120(11):981-6. [pmid: 17976426].
44 CDC. CDC Chronic Kidney Disease (CKD) Surveillance Report. 2009. www.cdc.gov/features/dsChronicKidneyDisease/2010.
45 USRDS. United States Renal Data System 2006 Annual Data Report: Atlas of Chronic Kidney Disease and End-Stage Renal Disease in the United States. Bethesda, MD. National Institutes of Health, National Institute of Diabetes and Digestive and Kidney Diseases. 2006. www.usrds.org/adr_2006.htm. Jan. 2010. 2010.
46 Levey AS, Coresh J, Greene T, et al. Using standardized serum creatinine values in the modification of diet in renal disease study equation for estimating glomerular filtration rate. Annals of Internal Medicine. Aug. 15. 2006;145(4):247-54. [pmid: 16908915].
47 Stevens LA, Schmid CH, Greene T, et al. Comparative performance of the CKD Epidemiology Collaboration (CKD-EPI) and the Modification of Diet in Renal Disease (MDRD) Study equations for estimating GFR levels above 60 mL/min/1.73 m2. Am J Kidney Dis. Sep. 2010;56(3):486-95. [pmid: 20557989].
48 Miller WG, Bruns DE, Hortin GL, et al. Current issues in measurement and reporting of urinary albumin excretion. Clin Chem. Jan. 2009;55(1):24-38. [pmid: 19028824].
49 Witte EC, Lambers Heerspink HJ, et al. First morning voids are more reliable than spot urine samples to assess microalbuminuria. J Am Soc Nephrol. Feb. 2009;20(2):436-43. [pmid: 19092125].
50 Gomes MB, Goncalves MF. Is there a physiological variability for albumin excretion rate? Study in patients with diabetes type 1 and non-diabetic individuals. Clin Chim Acta. Feb. 2001;304(1-2):117-23. [pmid: 11165206].
51 Coresh J, Astor BC, Greene T, et al. Prevalence of chronic kidney disease and decreased kidney function in the adult US population: Third National Health and Nutrition Examination Survey. American Journal of Kidney Diseases. Jan. 2003;41(1):1-12. [pmid: 12500213].
52 Perkins BA, Ficociello LH, Silva KH, et al. Regression of microalbuminuria in type 1 diabetes. New England Journal of Medicine. Jun. 5. 2003;348(23):2285-93. [pmid: 12788992].
53 Boulware LE, Jaar BG, Tarver-Carr ME, et al. Screening for proteinuria in US adults: a cost-effectiveness analysis. JAMA. Dec. 17. 2003;290(23):3101-14. [pmid: 14679273].
54 Strippoli GFM, Bonifati C, Craig M, et al. Angiotensin converting enzyme inhibitors and angiotensin II receptor antagonists for preventing the progression of diabetic kidney disease. Cochrane Database of Systematic Reviews. 2006;(4):CD006257. [pmid: 17054288].
55 Crepaldi G, Carta Q, Deferrari G, et al. Effects of lisinopril and nifedipine on the progression to overt albuminuria in IDDM patients with incipient nephropathy and normal blood pressure. The Italian Microalbuminuria Study Group in IDDM. Diabetes Care. Jan. 1998;21(1):104-10. [pmid: 9538979].
56 Effects of ramipril on cardiovascular and microvascular outcomes in people with diabetes mellitus: results of the HOPE study and MICRO-HOPE substudy. Heart Outcomes Prevention Evaluation Study Investigators. [Erratum appears in Lancet 2000 Sep 2; 356(9232):860]. Lancet. Jan. 22. 2000;355(9200):253-9. [pmid: 10675071].
57 Laffel LM, McGill JB, Gans DJ. The beneficial effect of angiotensin-converting enzyme inhibition with captopril on diabetic nephropathy in normotensive IDDM patients with microalbuminuria. North American Microalbuminuria Study Group. American Journal of Medicine. Nov. 1995;99(5):497-504. [pmid: 7485207].
58 O'Hare P, Bilbous R, Mitchell T, et al. Low-dose ramipril reduces microalbuminuria in type 1 diabetic patients without hypertension: results of a randomized controlled trial. Diabetes Care. Dec. 2000;23(12):1823-9. [pmid: 11128360].
59 Ravid M, Savin H, Jutrin I, et al. Long-term stabilizing effect of angiotensin-converting enzyme inhibition on plasma creatinine and on proteinuria in normotensive type II diabetic patients. Annals of Internal Medicine. Apr. 15. 1993;118(8):577-81. [pmid: 8452322].
60 Adler AI, Stevens RJ, Manley SE, et al. Development and progression of nephropathy in type 2 diabetes: the United Kingdom Prospective Diabetes Study (UKPDS 64). Kidney Int. Jan. 2003;63(1):225-32. [pmid: 12472787].
61 Perkovic V, Ninomiya T, Arima H, et al. Chronic kidney disease, cardiovascular events, and the effects of perindopril-based blood pressure lowering: data from the PROGRESS study. Journal of the American Society of Nephrology. Oct. 2007;18(10):2766-72. [pmid: 17804673].
62 Asselbergs FW, Diercks GFH, Hillege HL, et al. Effects of fosinopril and pravastatin on cardiovascular events in subjects with microalbuminuria. Circulation. Nov. 2. 2004;110(18):2809-16. [pmid: 15492322].
63 Marre M, Lievre M, Chatellier G, et al. Effects of low dose ramipril on cardiovascular and renal outcomes in patients with type 2 diabetes and raised excretion of urinary albumin: randomised, double blind, placebo controlled trial (the DIABHYCAR study). [Erratum appears in BMJ. 2004 Mar 20;328(7441):686]. BMJ. Feb. 28. 2004;328(7438):495. [pmid: 14960504].
64 Katayama S, Kikkawa R, Isogai S, et al. Effect of captopril or imidapril on the progression of diabetic nephropathy in Japanese with type 1 diabetes mellitus: a randomized controlled study (JAPAN-IDDM). [Erratum appears in Diabetes Res Clin Pract 2002 Jul 57(1):71]. Diabetes Research & Clinical Practice. Feb. 2002;55(2):113-21. [pmid: 11796177].
65 Bojestig M, Karlberg BE, Lindstrom T, et al. Reduction of ACE activity is insufficient to decrease microalbuminuria in normotensive patients with type 1 diabetes. Diabetes Care. May. 2001;24(5):919-24. [pmid: 11347755].
66 Gerstein HC, Mann JF, Yi Q, et al. Albuminuria and risk of cardiovascular events, death, and heart failure in diabetic and nondiabetic individuals. JAMA. Jul. 25. 2001;286(4):421-6. [pmid: 11466120].
67 Muirhead N, Feagan BF, Mahon J, et al. The effects of valsartan and captopril on reducing microalbuminuria in patients with type 2 diabetes mellitus: a placebo-controlled trial. Current Therapeutic Research - Clinical and Experimental 1999. Dec. 1999;60(12):650-60.
68 Ruggenenti P, Perna A, Gherardi G, et al. Renoprotective properties of ACE-inhibition in non-diabetic nephropathies with non-nephrotic proteinuria. Lancet. Jul. 31. 1999;354(9176):359-64. [pmid: 10437863].
69 Randomised placebo-controlled trial of effect of ramipril on decline in glomerular filtration rate and risk of terminal renal failure in proteinuric, non-diabetic nephropathy. The GISEN Group (Gruppo Italiano di Studi Epidemiologici in Nefrologia). Lancet. Jun. 28. 1997;349(9069):1857-63. [pmid: 9217756].
70 Maschio G, Alberti D, Janin G, et al. Effect of the angiotensin-converting-enzyme inhibitor benazepril on the progression of chronic renal insufficiency. The Angiotensin-Converting-Enzyme Inhibition in Progressive Renal Insufficiency Study Group. New England Journal of Medicine. Apr. 11. 1996;334(15):939-45. [pmid: 8596594].
71 Trevisan R, Tiengo A. Effect of low-dose ramipril on microalbuminuria in normotensive or mild hypertensive non-insulin-dependent diabetic patients. North-East Italy Microalbuminuria Study Group. American Journal of Hypertension. Sep. 1995;8(9):876-83. [pmid: 8541002].
72 Lewis EJ, Hunsicker LG, Bain RP, et al. The effect of angiotensin-converting-enzyme inhibition on diabetic nephropathy. The Collaborative Study Group. [Erratum appears in N Engl J Med 1993 Jan 13;330(2):152]. New England Journal of Medicine. Nov. 11. 1993;329(20):1456-62. [pmid: 8413456].
73 Sano T, Kawamura T, Matsumae H, et al. Effects of long-term enalapril treatment on persistent micro-albuminuria in well-controlled hypertensive and normotensive NIDDM patients. Diabetes Care. May. 1994;17(5):420-4. [pmid: 8062609].
74 Yusuf S, Sleight P, Pogue J, et al. Effects of an angiotensin-converting-enzyme inhibitor, ramipril, on cardiovascular events in high-risk patients. The Heart Outcomes Prevention Evaluation Study Investigators. New England Journal of Medicine. Jan. 20. 2000;342(3):145-53. [pmid: 10639539].
75 Mann JFE, Schmieder RE, McQueen M, et al. Renal outcomes with telmisartan, ramipril, or both, in people at high vascular risk (the ONTARGET study): a multicentre, randomised, double-blind, controlled trial. Lancet. Aug. 16. 2008;372(9638):547-53. [pmid: 18707986].
76 Menne J, Farsang C, Deak L, et al. Valsartan in combination with lisinopril versus the respective high dose monotherapies in hypertensive patients with microalbuminuria: the VALERIA trial. Journal of Hypertension. Sep. 2008;26(9):1860-7. [pmid: 18698222].
77 Sengul AM, Altuntas Y, Kurklu A, et al. Beneficial effect of lisinopril plus telmisartan in patients with type 2 diabetes, microalbuminuria and hypertension. Diabetes Research & Clinical Practice. Feb. 2006;71(2):210-9. [pmid: 16112244].
78 Barnett AH, Bain SC, Bouter P, et al. Angiotensin-receptor blockade versus converting-enzyme inhibition in type 2 diabetes and nephropathy. [Erratum appears in N Engl J Med 2005 Apr 21 352(16)1731]. New England Journal of Medicine. Nov. 4. 2004;351(19):1952-61. [pmid: 15516696].
79 Lacourciere Y, Belanger A, Godin C, et al. Long-term comparison of losartan and enalapril on kidney function in hypertensive type 2 diabetics with early nephropathy. Kidney International. Aug. 2000;58(2):762-9. [pmid: 10916100].
80 Teo K, Yusuf S, Sleight P, et al. Rationale, design, and baseline characteristics of 2 large, simple, randomized trials evaluating telmisartan, ramipril, and their combination in high-risk patients: the Ongoing Telmisartan Alone and in Combination with Ramipril Global Endpoint Trial/Telmisartan Randomized Assessment Study in ACE Intolerant Subjects with Cardiovascular Disease (ONTARGET/TRANSCEND) trials. Am Heart J. Jul. 2004;148(1):52-61. [pmid: 15215792].
81 Rahman M, Pressel S, Davis BR, et al. Renal outcomes in high-risk hypertensive patients treated with an angiotensin-converting enzyme inhibitor or a calcium channel blocker vs a diuretic: a report from the Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT). Archives of Internal Medicine. Apr. 25. 2005;165(8):936-46. [pmid: 15851647].
82 Rahman M, Pressel S, Davis BR, et al. Cardiovascular outcomes in high-risk hypertensive patients stratified by baseline glomerular filtration rate. [Summary for patients in Ann Intern Med 2006 Feb 7; 144(3):I33; PMID: 16461958]. Annals of Internal Medicine. Feb. 7. 2006;144(3):172-80. [pmid: 16461961].
83 Rahman M, Baimbridge C, Davis BR, et al. Progression of kidney disease in moderately hypercholesterolemic, hypertensive patients randomized to pravastatin versus usual care: a report from the Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT). American Journal of Kidney Diseases. Sep. 2008;52(3):412-24. [pmid: 18676075].
84 Fogari R, Preti P, Zoppi A, et al. Effects of amlodipine fosinopril combination on microalbuminuria in hypertensive type 2 diabetic patients. American Journal of Hypertension. Dec. 2002;15(12):1042-9. [pmid: 12460699].
85 Agodoa LY, Appel L, Bakris GL, et al. Effect of ramipril vs amlodipine on renal outcomes in hypertensive nephrosclerosis: a randomized controlled trial. JAMA. Jun. 6. 2001;285(21):2719-28. [pmid: 11386927].
86 Marin R, Ruilope LM, Aljama P, et al. A random comparison of fosinopril and nifedipine GITS in patients with primary renal disease. Journal of Hypertension. Oct. 2001;19(10):1871-6. [pmid: 11593109].
87 Zucchelli P, Zuccala A, Borghi M, et al. Long-term comparison between captopril and nifedipine in the progression of renal insufficiency. Kidney International. Aug. 1992;42(2):452-8. [pmid: 1405330].
88 Zucchelli P, Zuccala A, Gaggi R. Comparison of the effects of ACE inhibitors and calcium channel blockers on the progression of renal failure. Nephrology Dialysis Transplantation. Oct. Suppl 9. 1995;10:46-51. [pmid: 8643208].
89 Wright JT Jr., Kusek JW, Toto RD, et al. Design and baseline characteristics of participants in the African American Study of Kidney Disease and Hypertension (AASK) Pilot Study. Controlled Clinical Trials. Aug. 1996;17(4 Suppl):3S-16S. [pmid: 8889350].
90 Wright JT Jr., Bakris G, Greene T, et al. Effect of blood pressure lowering and antihypertensive drug class on progression of hypertensive kidney disease: results from the AASK trial. [Erratum appears in JAMA. 2006 Jun 21 295(23):2726]. JAMA. Nov. 20. 2002;288(19):2421-31. [pmid: 12435255].
91 Norris K, Bourgoigne J, Gassman J, et al. Cardiovascular outcomes in the African American Study of Kidney Disease and Hypertension (AASK) Trial. American Journal of Kidney Diseases. Nov. 2006;48(5):739-51. [pmid: 17059993].
92 van Essen GG, Apperloo AJ, Rensma PL, et al. Are angiotensin converting enzyme inhibitors superior to beta blockers in retarding progressive renal function decline?. Kidney International - Supplement. Dec. 1997;63:S58-62. [pmid: 9407423].
93 Hannedouche T, Landais P, Goldfarb B, et al. Randomised controlled trial of enalapril and beta blockers in non-diabetic chronic renal failure. BMJ. Oct. 1. 1994;309(6958):833-7. [pmid: 7950612].
94 Marre M, Puig JG, Kokot F, et al. Equivalence of indapamide SR and enalapril on microalbuminuria reduction in hypertensive patients with type 2 diabetes: the NESTOR Study. Journal of Hypertension. Aug. 2004;22(8):1613-22. [pmid: 15257186].
95 Makino H, Haneda M, Babazono T, et al. Prevention of transition from incipient to overt nephropathy with telmisartan in patients with type 2 diabetes. Diabetes Care. Jun. 2007;30(6):1577-8. [pmid: 17389334].
96 Parving HH, Lehnert H, Brochner-Mortensen J, et al. The effect of irbesartan on the development of diabetic nephropathy in patients with type 2 diabetes. New England Journal of Medicine. Sep. 20. 2001;345(12):870-8. [pmid: 11565519].
97 Lewis EJ, Hunsicker LG, Clarke WR, et al. Renoprotective effect of the angiotensin-receptor antagonist irbesartan in patients with nephropathy due to type 2 diabetes. New England Journal of Medicine. Sep. 20. 2001;345(12):851-60. [pmid: 11565517].
98 Brenner BM, Cooper ME, de Zeeuw D, et al. Effects of losartan on renal and cardiovascular outcomes in patients with type 2 diabetes and nephropathy. New England Journal of Medicine. Sep. 20. 2001;345(12):861-9. [pmid: 11565518].
99 Tobe SW, Clase CM, Gao P, et al. Cardiovascular and renal outcomes with telmisartan, ramipril, or both in people at high renal risk: results from the ONTARGET and TRANSCEND studies. Circulation. Mar. 15. 2011;123(10):1098-107. [pmid: 21357827].
100 Saruta T, Hayashi K, Ogihara T, et al. Effects of candesartan and amlodipine on cardiovascular events in hypertensive patients with chronic kidney disease: subanalysis of the CASE-J Study. Hypertension Research - Clinical & Experimental. Jun. 2009;32(6):505-12. [pmid: 19390535].
101 Ogawa S, Takeuchi K, Mori T, et al. Effects of monotherapy of temocapril or candesartan with dose increments or combination therapy with both drugs on the suppression of diabetic nephropathy. Hypertension Research - Clinical & Experimental. Apr. 2007;30(4):325-34. [pmid: 17541211].
102 Fukui T, Rahman M, Hayashi K, et al. Candesartan Antihypertensive Survival Evaluation in Japan (CASE-J) trial of cardiovascular events in high-risk hypertensive patients: rationale, design, and methods. Hypertens Res. Dec. 2003;26(12):979-90. [pmid: 14717341].
103 Mehdi UF, Adams-Huet B, Raskin P, et al. Addition of angiotensin receptor blockade or mineralocorticoid antagonism to maximal angiotensin-converting enzyme inhibition in diabetic nephropathy. Journal of the American Society of Nephrology. Dec. 2009;20(12):2641-50. [pmid: 19926893].
104 Kanno Y, Takenaka T, Nakamura T, et al. Add-on angiotensin receptor blocker in patients who have proteinuric chronic kidney diseases and are treated with angiotensin-converting enzyme inhibitors. Clinical Journal of The American Society of Nephrology: CJASN. Jul. 2006;1(4):730-7. [pmid: 17699280].
105 Anand IS, Bishu K, Rector TS, et al. Proteinuria, chronic kidney disease, and the effect of an angiotensin receptor blocker in addition to an angiotensin-converting enzyme inhibitor in patients with moderate to severe heart failure. Circulation. Oct. 20. 2009;120(16):1577-84. [pmid: 19805651].
106 Bakris GL, Toto RD, McCullough PA, et al. Effects of different ACE inhibitor combinations on albuminuria: results of the GUARD study. Kidney International. Jun. 2008;73(11):1303-9. [pmid: 18354383].
107 Bakris GL, Sarafidis PA, Weir MR, et al. Renal outcomes with different fixed-dose combination therapies in patients with hypertension at high risk for cardiovascular events (ACCOMPLISH): a prespecified secondary analysis of a randomised controlled trial. Lancet. Apr. 3. 2010;375(9721):1173-81. [pmid: 20170948].
108 Jamerson KA, Bakris GL, Wun CC, et al. Rationale and design of the avoiding cardiovascular events through combination therapy in patients living with systolic hypertension (ACCOMPLISH) trial: the first randomized controlled trial to compare the clinical outcome effects of first-line combination therapies in hypertension. Am J Hypertens. Sep. 2004;17(9):793-801. [pmid: 15363822].
109 Mogensen CE, Viberti G, Halimi S, et al. Effect of low-dose perindopril/indapamide on albuminuria in diabetes: preterax in albuminuria regression: PREMIER. Hypertension. May. 2003;41(5):1063-71. [pmid: 12654706].
110 Lambers Heerspink HJ, Gansevoort RT, Brenner BM, et al. Comparison of different measures of urinary protein excretion for prediction of renal events. J Am Soc Nephrol. Aug. 2010;21(8):1355-60. [pmid: 20634296].
111 Burgess E, Muirhead N, Rene de Cotret P, et al. Supramaximal dose of candesartan in proteinuric renal disease. Journal of the American Society of Nephrology. Apr. 2009;20(4):893-900. [pmid: 19211712].
112 Bakris G, Burgess E, Weir M, et al. Telmisartan is more effective than losartan in reducing proteinuria in patients with diabetic nephropathy. Kidney International. Aug. 2008;74(3):364-9. [pmid: 18496508].
113 Galle J, Schwedhelm E, Pinnetti S, et al. Antiproteinuric effects of angiotensin receptor blockers: telmisartan versus valsartan in hypertensive patients with type 2 diabetes mellitus and overt nephropathy. Nephrology Dialysis Transplantation. Oct. 2008;23(10):3174-83. [pmid: 18450829].
114 van den Meiracker AH, Baggen RG, Pauli S, et al. Spironolactone in type 2 diabetic nephropathy: Effects on proteinuria, blood pressure and renal function. Journal of Hypertension. Nov. 2006;24(11):2285-92. [pmid: 17053552].
115 Ghali JK, Wikstrand J, Van Veldhuisen DJ, et al. The influence of renal function on clinical outcome and response to beta-blockade in systolic heart failure: insights from Metoprolol CR/XL Randomized Intervention Trial in Chronic HF (MERIT-HF). Journal of Cardiac Failure. May. 2009;15(4):310-8. [pmid: 19398079].
116 Cohen-Solal A, Kotecha D, van Veldhuisen DJ, et al. Efficacy and safety of nebivolol in elderly heart failure patients with impaired renal function: insights from the SENIORS trial. Eur J Heart Fail. Sep. 2009;11(9):872-80. [pmid: 19648605].
117 Berl T, Hunsicker LG, Lewis JB, et al. Cardiovascular outcomes in the Irbesartan Diabetic Nephropathy Trial of patients with type 2 diabetes and overt nephropathy. [Summary for patients in Ann Intern Med 2003 Apr 1; 138(7):I43; PMID 12667050]. Annals of Internal Medicine. Apr. 1. 2003;138(7):542-9. [pmid: 12667024].
118 Pahor M, Shorr RI, Somes GW, et al. Diuretic-based treatment and cardiovascular events in patients with mild renal dysfunction enrolled in the systolic hypertension in the elderly program. Archives of Internal Medicine. Jun. 22. 1998;158(12):1340-5. [pmid: 9645829].
119 Cinotti GA, Zucchelli PC, Collaborative Study G. Effect of Lisinopril on the progression of renal insufficiency in mild proteinuric non-diabetic nephropathies. Nephrology Dialysis Transplantation. May. 2001;16(5):961-6. [pmid: 11328901].
120 Bakris GL, Copley JB, Vicknair N, et al. Calcium channel blockers versus other antihypertensive therapies on progression of NIDDM associated nephropathy. Kidney International. Nov. 1996;50(5):1641-50. [pmid: 8914031].
121 Dahlof B, Sever PS, Poulter NR, et al. Prevention of cardiovascular events with an antihypertensive regimen of amlodipine adding perindopril as required versus atenolol adding bendroflumethiazide as required, in the Anglo-Scandinavian Cardiac Outcomes Trial-Blood Pressure Lowering Arm (ASCOT-BPLA): a multicentre randomised controlled trial. Lancet. Sep. 10-16. 2005;366(9489):895-906. [pmid: 16154016].
122 Ruggenenti P, Perna A, Loriga G, et al. Blood-pressure control for renoprotection in patients with non-diabetic chronic renal disease (REIN-2): multicentre, randomised controlled trial. Lancet. Mar. 12-18. 2005;365(9463):939-46. [pmid: 15766995].
123 Lewis JB, Berl T, Bain RP, et al. Effect of intensive blood pressure control on the course of type 1 diabetic nephropathy. Collaborative Study Group. American Journal of Kidney Diseases. Nov. 1999;34(5):809-17. [pmid: 10561135].
124 Toto RD, Mitchell HC, Smith RD, et al. “Strict” blood pressure control and progression of renal disease in hypertensive nephrosclerosis. Kidney International. Sep. 1995;48(3):851-9. [pmid: 7474675].
125 Peterson JC, Adler S, Burkart JM, et al. Blood pressure control, proteinuria, and the progression of renal disease. The Modification of Diet in Renal Disease Study. Annals of Internal Medicine. Nov. 15. 1995;123(10):754-62. [pmid: 7574193].
126 Shulman NB, Ford CE, Hall WD, et al. Prognostic value of serum creatinine and effect of treatment of hypertension on renal function. Results from the hypertension detection and follow-up program. The Hypertension Detection and Follow-up Program Cooperative Group. Hypertension. May. 1989;13(5 Suppl):I80-93. [pmid: 2490833].
127 Greene T, Bourgoignie JJ, Habwe V, et al. Baseline characteristics in the Modification of Diet in Renal Disease Study. [Republished from J Am Soc Nephrol 1993 May; 3(11):1819-34]. Journal of the American Society of Nephrology. Nov. 1993;4(5):1221-36. [pmid: 8305650].
128 Koya D, Haneda M, Inomata S, et al. Long-term effect of modification of dietary protein intake on the progression of diabetic nephropathy: a randomised controlled trial. Diabetologia. Oct. 2009;52(10):2037-45. [pmid: 19652945].
129 Dussol B, Iovanna C, Raccah D, et al. A randomized trial of low-protein diet in type 1 and in type 2 diabetes mellitus patients with incipient and overt nephropathy. Journal of Renal Nutrition. Oct. 2005;15(4):398-406. [pmid: 16198932].
130 Klahr S, Levey AS, Beck GJ, et al. The effects of dietary protein restriction and blood-pressure control on the progression of chronic renal disease. Modification of Diet in Renal Disease Study Group. New England Journal of Medicine. Mar. 31. 1994;330(13):877-84. [pmid: 8114857].
131 Kopple JD, Levey AS, Greene T, et al. Effect of dietary protein restriction on nutritional status in the Modification of Diet in Renal Disease Study. Kidney International. Sep. 1997;52(3):778-91. [pmid: 9291200].
132 D'Amico G, Gentile MG, Fellin G, et al. Effect of dietary protein restriction on the progression of renal failure: a prospective randomized trial. Nephrology Dialysis Transplantation. 1994;9(11):1590-4. [pmid: 7870348].
133 Locatelli F, Alberti D, Graziani G, et al. Prospective, randomised, multicentre trial of effect of protein restriction on progression of chronic renal insufficiency. Northern Italian Cooperative Study Group Lancet. Jun. 1. 1991;337(8753):1299-304. [pmid: 1674294].
134 Rosman JB, ter Wee PM, Meijer S, et al. Prospective randomised trial of early dietary protein restriction in chronic renal failure. Lancet. Dec. 8. 1984;2(8415):1291-6. [pmid: 6150320].
135 Rosman JB, Langer K, Brandl M, et al. Protein-restricted diets in chronic renal failure: a four year follow-up shows limited indications. Kidney International - Supplement. Nov. 1989;27:S96-102. [pmid: 2636680].
136 Facchini FS, Saylor KL. A low-iron-available, polyphenol-enriched, carbohydrate-restricted diet to slow progression of diabetic nephropathy. Diabetes. May. 2003;52(5):1204-9. [pmid: 12716753].
137 Samuelsson O, Attman PO, Knight-Gibson C, et al. Effect of gemfibrozil on lipoprotein abnormalities in chronic renal insufficiency: a controlled study in human chronic renal disease. Nephron. 1997;75(3):286-94. [pmid: 9069450].
138 Williams PS, Stevens ME, Fass G, et al. Failure of dietary protein and phosphate restriction to retard the rate of progression of chronic renal failure: a prospective, randomized, controlled trial. Quarterly Journal of Medicine. Oct. 1991;81(294):837-55. [pmid: 1801057].
139 Duckworth W, Abraira C, Moritz T, et al. Glucose control and vascular complications in veterans with type 2 diabetes. New England Journal of Medicine. Jan. 8. 2009;360(2):129-39. [pmid: 19092145].
140 Intensive therapy and progression to clinical albuminuria in patients with insulin dependent diabetes mellitus and microalbuminuria. Microalbuminuria Collaborative Study Group, United Kingdom. BMJ. Oct. 14. 1995;311(7011):973-7. [pmid: 7580637].
141 Kendrick J, Shlipak MG, Targher G, et al. Effect of lovastatin on primary prevention of cardiovascular events in mild CKD and kidney function loss: a post hoc analysis of the Air Force/Texas Coronary Atherosclerosis Prevention Study. American Journal of Kidney Diseases. Jan. 2010;55(1):42-9. [pmid: 19932541].
142 Nakamura H, Mizuno K, Ohashi Y, et al. Pravastatin and cardiovascular risk in moderate chronic kidney disease. Atherosclerosis. Oct. 2009;206(2):512-7. [pmid: 19423108].
143 Colhoun HM, Betteridge DJ, Durrington PN, et al. Effects of atorvastatin on kidney outcomes and cardiovascular disease in patients with diabetes: an analysis from the Collaborative Atorvastatin Diabetes Study (CARDS). American Journal of Kidney Diseases. Nov. 2009;54(5):810-9. [pmid: 19540640].
144 Koren MJ, Davidson MH, Wilson DJ, et al. Focused atorvastatin therapy in managed-care patients with coronary heart disease and CKD. American Journal of Kidney Diseases. May. 2009;53(5):741-50. [pmid: 19216014].
145 Chonchol M, Cook T, Kjekshus J, et al. Simvastatin for secondary prevention of all-cause mortality and major coronary events in patients with mild chronic renal insufficiency. American Journal of Kidney Diseases. Mar. 2007;49(3):373-82. [pmid: 17336698].
146 Kjekshus J, Apetrei E, Barrios V, et al. Rosuvastatin in older patients with systolic heart failure. New England Journal of Medicine. Nov. 29. 2007;357(22):2248-61. [pmid: 17984166].
147 Lemos PA, Serruys PW, de Feyter P, et al. Long-term fluvastatin reduces the hazardous effect of renal impairment on four-year atherosclerotic outcomes (a LIPS substudy). American Journal of Cardiology. Feb. 15. 2005;95(4):445-51. [pmid: 15695126].
148 Tonelli M, Moye L, Sacks FM, et al. Pravastatin for secondary prevention of cardiovascular events in persons with mild chronic renal insufficiency. [Summary for patients in Ann Intern Med 2003 Jan 21 138(2):I28; PMID: 12529112]. Annals of Internal Medicine. Jan. 21. 2003;138(2):98-104. [pmid: 12529091].
149 Tonelli M, Isles C, Curhan GC, et al. Effect of pravastatin on cardiovascular events in people with chronic kidney disease. Circulation. Sep. 21. 2004;110(12):1557-63. [pmid: 15364796].
150 Ridker PM, MacFadyen J, Cressman M, et al. Efficacy of rosuvastatin among men and women with moderate chronic kidney disease and elevated high-sensitivity C-reactive protein: a secondary analysis from the JUPITER (Justification for the Use of Statins in Prevention-an Intervention Trial Evaluating Rosuvastatin) trial. J Am Coll Cardiol. Mar. 23. 2010;55(12):1266-73. [pmid: 20206456].
151 Shepherd J, Kastelein JJP, Bittner V, et al. Intensive lipid lowering with atorvastatin in patients with coronary heart disease and chronic kidney disease: the TNT (Treating to New Targets) study. Journal of the American College of Cardiology. Apr. 15. 2008;51(15):1448-54. [pmid: 18402899].
152 Armitage J, Bowman L, Wallendszus K, et al. Intensive lowering of LDL cholesterol with 80 mg versus 20 mg simvastatin daily in 12,064 survivors of myocardial infarction: a double-blind randomised trial. Lancet. Nov. 13. 2010;376(9753):1658-69. [pmid: 21067805].
153 Tonolo G, Velussi M, Brocco E, et al. Simvastatin maintains steady patterns of GFR and improves AER and expression of slit diaphragm proteins in type II diabetes. Kidney International. Jul. 2006;70(1):177-86. [pmid: 16710349].
154 Tonelli M, Collins D, Robins S, et al. Effect of gemfibrozil on change in renal function in men with moderate chronic renal insufficiency and coronary disease. Am J Kidney Dis. Nov. 2004;44(5):832-9. [pmid: 15492949].
155 Chan JC, So WY, Yeung CY, et al. Effects of structured versus usual care on renal endpoint in type 2 diabetes: the SURE study: a randomized multicenter translational study. Diabetes Care. Jun. 2009;32(6):977-82. [pmid: 19460913].
156 Gaede P, Vedel P, Larsen N, et al. Multifactorial intervention and cardiovascular disease in patients with type 2 diabetes. New England Journal of Medicine. Jan. 30. 2003;348(5):383-93. [pmid: 12556541].
157 Gaede P, Vedel P, Parving HH, et al. Intensified multifactorial intervention in patients with type 2 diabetes mellitus and microalbuminuria: the Steno type 2 randomised study. Lancet. Feb. 20. 1999;353(9153):617-22. [pmid: 10030326].
158 Joss N, Ferguson C, Brown C, et al. Intensified treatment of patients with type 2 diabetes mellitus and overt nephropathy. Qjm. Apr. 2004;97(4):219-27. [pmid: 15028852].
159 Harris LE, Luft FC, Rudy DW, et al. Effects of multidisciplinary case management in patients with chronic renal insufficiency. American Journal of Medicine. Dec. 1998;105(6):464-71. [pmid: 9870830].
160 Wilt TJ, Bloomfield HE, MacDonald R, et al. Effectiveness of statin therapy in adults with coronary heart disease. Arch Intern Med. Jul. 12. 2004;164(13):1427-36. [pmid: 15249352].
161 Ray KK, Seshasai SR, Erqou S, et al. Statins and all-cause mortality in high-risk primary prevention: a meta-analysis of 11 randomized controlled trials involving 65,229 participants. Arch Intern Med. Jun. 28. 2010;170(12):1024-31. [pmid: 20585067].
162 Haller H, Ito S, Izzo JL Jr., et al. Olmesartan for the delay or prevention of microalbuminuria in type 2 diabetes. N Engl J Med. Mar. 10. 2011;364(10):907-17. [pmid: 21388309].