# Peer Reviewers

L. Ebony Boulware, M.D., M.P.H.

Johns Hopkins Medical Institutions

Baltimore, MD

Ann Bullock, M.D.

Indian Health Service

Cherokee, NC

Julie Lin, M.D., M.P.H., FASN

Harvard Medical School

Boston, MA

Rajiv Saran, M.B.B.S., M.D., D.T.C.D., M.R.C.P., M.S.

University of Michigan

Ann Arbor, MI

Desmond Williams, M.D., Ph.D.

National Center for Chronic Disease Prevention and Health Promotion

Atlanta, GA