# Discussion

For CKD screening or monitoring to be of benefit, each would need to improve clinically important outcomes, presumably by leading to specific changes in treatment. However, we identified no RCTs that randomized individuals without known CKD to CKD screening, or those with CKD stages 1–3 to CKD monitoring, and collected and reported associated clinical outcomes.

With no direct link between screening or monitoring and clinical outcomes, concluding likely benefit of screening or monitoring requires, at minimum, the availability of accurate screening tests, and sufficient evidence that treatment for CKD stages 1–3 improves clinically important outcomes while limiting harms. For treatment benefits in CKD patients to be relevant to screening or monitoring, treatments also would need to improve these outcomes in individuals who would not otherwise receive them; i.e., patients without specific treatment indications in the absence of a CKD diagnosis. In patients with other treatment indications, diagnosis of CKD or of CKD progression might be beneficial if outcomes in these patients are significantly improved with a higher treatment dose or by treatment to a stricter target than indicated in individuals with no or less severe CKD. Finally, any treatment benefit would need to outstrip treatment harms and potential screening and monitoring harms, and applicability of treatment RCT results to screening or monitoring would be increased if subjects were identified for participation in these treatment trials through screening.

In this synthesis of RCT evidence, several treatments reduced risk of clinical events in patients with CKD stages 1–3. Compared with placebo, ACEI and ARB significantly reduced risk of ESRD in patients with proteinuria, nearly all of whom had concomitant diabetes and hypertension. While there was no significant reduction in risk of ESRD with ACEI or ARB in patients without proteinuria, because of the low rate of progression to ESRD in these patients, the present analysis had limited statistical power to detect such a difference. This is not direct evidence that testing patients with diabetes and hypertension for proteinuria will reduce ESRD risk, but it suggests, in patients not currently being treated with ACEI or ARB, that knowledge of these results might inform this treatment decision. Also compared with placebo, ACEI significantly reduced risk of mortality in patients with microalbuminuria who had cardiovascular disease or had diabetes and other cardiovascular risk factors. Though the relative reduction in mortality risk appeared slightly greater in patients with microalbuminuria compared with those without microalbuminuria, this difference was not statistically significant, suggesting that such patients may have an indication for ACEI regardless of CKD status.

In individuals with hyperlipidemia and impaired eGFR or creatinine clearance, we found that statins significantly reduced risk of mortality, MI, and stroke compared with placebo, including in patients without coronary artery disease. This is not direct evidence that testing patients with hyperlipidemia for eGFR will reduce risk of these outcomes, in part because some of these patients already have a clinical indication for statin treatment. Determining CKD status in these patients wouldn't alter their management. Specifically, as previously documented, patients with hyperlipidemia and coronary artery disease randomized to statins have a significantly reduced risk of mortality compared with placebo,160 They have an indication for statin treatment regardless of their CKD status. In contrast, also previously documented, hyperlipidemic patients without coronary artery disease taken as a whole did not have a significant mortality benefit from statins.161 The current results suggest that, in patients with hyperlipidemia and no coronary artery disease who are not currently being treated with a statin, knowledge of impaired eGFR might inform this treatment decision.

In individuals with CHF and impaired eGFR, beta blockers significantly reduced risk of mortality, MI, and CHF events compared with placebo. Patients in all eGFR strata had a significant reduction in risk of these clinical outcomes. Inconsistent results suggested possibly a greater relative risk reduction with beta blockers in patients with lower eGFR. However, as patients with systolic CHF already have an indication for beta blocker treatment, testing for eGFR is not likely to inform this treatment decision.

With regard to patients with CKD stages 1–3 already receiving treatments for conditions associated with CKD (e.g., ACEI for treatment of hypertension), no clear RCT evidence showed whether intensification of treatment improves clinical outcomes. We identified no eligible RCTs that compared clinical outcomes in CKD patients randomized to different fixed ACEI doses, though separate trials suggested that ramipril at 1.25 mg per day in patients with albuminuria lacks the mortality benefit of ramipril at 10 mg per day in patients with microalbuminuria. For other treatments in CKD patients, we did not find evidence of significant or consistent benefit in clinical outcomes in high versus low dose ARB, strict versus standard blood pressure control, high versus low dose statin, tight versus standard glycemic control, intensive multidisciplinary interventions versus standard care, and combination treatment versus monotherapy. While data limited to these latter trials suggests an absence of evidence for benefit from intensification of therapy as a justification for either CKD screening or monitoring, most had low statistical power to detect a significant difference in clinical outcomes.

In RCTs included in this evidence synthesis, many treatments reduced the risk of doubling of serum creatinine and progression from microalbuminuria to macroalbuminuria. However, these renal endpoints are not clinical outcomes. Although impaired GFR and albuminuria are unquestionably adverse prognostic markers, treatments that target and even improve these measures will not necessarily reduce risk of mortality, ESRD or important clinical vascular outcomes. Findings reported from the large ROADMAP study162—in which patients with diabetes and at least one additional CKD risk factor were randomized to ARB versus non-ARB blood pressure control—illustrated the potential danger of utilizing albuminuria as a surrogate marker for clinical outcomes in kidney disease. Though blood pressure control was significantly better and time to onset of microalbuminuria was significantly delayed in the ARB treatment group, these patients also experienced a significant increase in fatal cardiovascular events.

As we have noted, establishing the benefit of CKD screening and/or monitoring requires evidence of treatment benefit. Yet, treatment benefit does not by itself prove screening or monitoring benefit. First, the accuracy of available screening and monitoring measures for persistent CKD and progressive CKD, respectively, is uncertain. Second, only two of the dozens of RCTs included in this evidence synthesis reported that study participants were identified through screening.26,27 Consequently, patients with CKD stages 1–3 enrolled in all these trials may not be representative of those who would be identified through systematic screening. For example, patients identified through screening may be earlier in their course of CKD, less likely to progress during treatment followup, and thus less likely to benefit from treatment intervention. In addition, formal diagnosis of CKD requires that impairment in kidney function or kidney damage persists for at least 3 months. The vast majority of trials included in this evidence synthesis categorized patients as having CKD based on one-time abnormalities. Other trials that required repeated or sustained kidney abnormalities for entry did not mandate persistence for 3 months. Study participants thus may have had transient impairments, been more likely to improve regardless of treatment, and less likely to develop progressive CKD than patients with CKD confirmed over 3 months duration. Finally, we identified no evidence to quantify harms that may be associated with CKD screening and monitoring. Potential harms of systematic CKD screening could include adverse effects from screening and followup tests, including following false positive tests; psychological effects from labeling asymptomatic individuals as diseased; medication adverse effects; increased medical visits; and increased difficulty keeping health insurance coverage. Analogously, potential harms of systematic monitoring of patients with CKD stages 1–3 for worsening kidney function or damage could include adverse effects from monitoring and followup tests, including potentially unnecessary testing; medication adverse effects; and increased medical visits. Accurate information on screening and monitoring harms is needed to evaluate their overall impact in CKD.

Considering these issues, if there is a benefit from CKD screening, evidence suggests the likelihood of benefit is greatest in individuals with diabetes, cardiovascular disease, and possibly hyperlipidemia. For other populations with a high prevalence of CKD, such as patients with hypertension, obesity, and older age, evidence for benefit from screening appears weaker. Though also based only on indirect data, individuals under 50 years old and without diabetes, hypertension, cardiovascular disease, or obesity infrequently have CKD and seem least likely to benefit from CKD screening.

Finally, because of the imprecision and high intra-individual variability of eGFR and albuminuria, providers who monitor patients with CKD stages 1–3 for worsening kidney function and/or damage will identify both declines and improvements in these measures, including many that are transient and/or clinically insignificant. We identified no RCTs that assigned patients with CKD stages 1–3 to systematic monitoring versus control, or that modified treatment based on followup levels of eGFR or albuminuria and evaluated clinical outcomes. Rather, trials either assigned participants to a fixed dose to be maintained throughout the trial or titrated upward from an initial dose to achieve a specific target dose or clinical target (e.g., systolic blood pressure less than 140 mm Hg). Although treatment RCT results suggest that monitoring could inform decisions regarding whether to start ACEI or ARB treatment in patients with diabetes and hypertension who develop albuminuria, or statin treatment in patients with hyperlipidemia who develop impaired eGFR, considering uncertainty in the accuracy of monitoring tests for identifying CKD progression and uncertainty regarding possible monitoring harms, the relative benefits and harms of CKD monitoring are unclear.