# Evidence Tables and Other Supporting Tables and Figures

Appendix Evidence Table C1 Overview of ACEI monotherapy versus control treatment trials

Appendix Table C2 Summary of study baseline characteristics for ACEI monotherapy versus control treatment trials

Appendix Table C3 Clinical outcomes (outcomes part A), ACEI monotherapy versus control treatment trials

Appendix Figure C1 Forest plots for ACEI monotherapy versus control treatment trials

*First outcome identified for each study

*Second outcome identified for each study

Appendix Figure C1 displays forest plots for risk ratios associated with clinical outcomes in studies of patients receiving an angiotensin converting enzyme inhibitor (ACEI) compared to patients receiving a control treatment. The first section is for studies comparing ACEI monotherapy to placebo. The findings are described in the report section “ACE Inhibitor Monotherapy versus Placebo/No Treatment Trials.” Treatment with ACE inhibitors was found to significantly reduce the risk of end-stage renal disease, doubling of serum creatinine, and progression from microalbuminuria to macroalbuminuria compared to placebo. The second section is for studies comparing ACEI monotherapy to angiotensin receptor blocker (ARB) monotherapy. The findings are described in the report section “ACE Inhibitor Monotherapy versus ARB Monotherapy.” No significant reductions in risk were identified. The third section is for studies comparing ACEI monotherapy to calcium channel blockers (CCB). The findings are described in the report section “ACE Inhibitor Monotherapy versus CCB Monotherapy.” No significant reductions in risk were identified. The fourth section is for studies comparing ACEI to beta-blockers (BB). The findings are described in the report section “ACE Inhibitor Monotherapy versus Beta Blocker.” No significant reductions in risk were identified. The fifth section is for studies comparing ACEI to diuretics. The findings are described in the report section “ACE Inhibitor Monotherapy versus Diuretic.” Treatment with ACE inhibitors was found (based on data from one trial) to significantly increase the risk of congestive heart failure compared to treatment with diuretics.

Appendix Table C4 Clinical outcomes (outcomes part B), ACEI monotherapy versus control treatment trials

Appendix Table C5 Composite vascular outcome definitions for ACEI monotherapy versus control treatment trials

Appendix Table C6 Clinical renal outcomes (outcomes part C), ACEI monotherapy versus control treatment trials

Appendix Table C7 Composite renal outcome definitions for ACEI versus control treatment trials

Appendix Table C8 Study withdrawals and adverse events (outcomes Part D), ACEI monotherapy versus control treatment trials

Appendix Evidence Table C9 Overview of ARB monotherapy trials

Appendix Table C10 Summary of study baseline characteristics for ARB monotherapy trials

Appendix Table C11 Clinical outcomes (outcomes part A), ARB monotherapy trials

Appendix Figure C2 Forest plots for ARB monotherapy trials

Appendix Figure C2 displays forest plots for risk ratios associated with clinical outcomes in studies of patients receiving an angiotensin receptor blocker (ARB) compared to patients receiving a control treatment. The first section is for studies comparing ARB monotherapy to placebo. The findings are described in the report section “ARB Monotherapy versus Placebo Trials.” Treatment with ARBs was found to significantly reduce the risk of hospitalization for congestive heart failure, end-stage renal disease, doubling of serum creatinine, and progression from microalbuminuria to macroalbuminuria compared to placebo. The second section is for studies comparing ARB monotherapy to calcium channel blocker (CCB) monotherapy. The findings are described in the report section “ARB Monotherapy versus CCB Trials.” Treatment with ARBs was found to significantly reduce the risk of doubling of serum creatinine compared to treatment with CCBs.

Appendix Table C12 Clinical outcomes (outcomes part B), ARB monotherapy trials

Appendix Table C13 Composite vascular outcome definitions for ARB monotherapy trials

Appendix Table C14 Clinical renal outcomes (outcomes part C), ARB monotherapy trials

Appendix Table C15 Composite renal outcome definitions for ARB monotherapy trials

Appendix Table C16 Study withdrawals and adverse events (outcomes part D), ARB monotherapy trials

Appendix Table C17 Overview of ACEI plus ARB versus ACEI or ARB trials (n=6 trials)

Appendix Table C18 Summary of study baseline characteristics for ACEI plus ARB versus ACEI or ARB trials

Appendix Table C19 Clinical outcomes (outcomes part A), ACEI plus ARB versus ACEI or ARB trials

Appendix Table C20 Clinical outcomes (outcomespart B), ACEI plus ARB versus ACEI or ARB trials

No ACE+ARB versus ARB studies reported these outcomes

Appendix Figure C3 Forest plots for ACEI plus ARB versus ACEI trials

Appendix Figure C3 displays forest plots for risk ratios associated with clinical outcomes in studies of patients receiving ACE inhibitor plus ARB compared to patients receiving ACE inhibitor alone. The findings are described in the report section “ACE Inhibitor plus ARB Therapy versus ACE Inhibitor Alone Trials.” Treatment with ACEI plus ARB was found to significantly reduce the risk of a composite vascular outcome (defined as death, sudden death with resuscitation, hospitalization for heart failure, or administration of intravenous inotropic or vasolilator drugs for 4 hours or more without hospitalization) compared to treatment with ACEI alone.

Appendix Table C21 Composite vascular outcome definitions for ACEI plus ARB versus ACEI or ARB trials

Appendix Table C22 Clinical renal outcomes (outcomes part C), ACEI plus ARB versus ACEI or ARB trials

Appendix Table C23 Composite renal outcome definitions for ACEI plus ARB versus ACEI or ARB trials

Appendix Table C24 Study withdrawals and adverse events (outcomes part D), ACEI plus ARB versus ACEI or ARB trials

Appendix Table C25 Overview of ACEI plus ARB versus ARB trials (n=3 trials)

Appendix Figure C4 Forest plots ACEI plus ARB versus ARB trials

Appendix Figure C4 displays forest plots for risk ratios associated with clinical outcomes in studies of patients receiving ACE inhibitor plus ARB compared to patients receiving ARB alone. The findings are described in the report section “ACE Inhibitor plus ARB Therapy versus ARB Alone Trials.” There were no significant findings.

Appendix Figure C5 Forest plots ACEI plus ARB versus ACEI or ARB trial

Appendix Figure C5 displays forest plots for risk ratios associated with clinical outcomes in studies of patients receiving ACE inhibitor plus ARB compared to patients receiving ACEI or ARB alone. The findings are described in the report section “ACE Inhibitor plus ARB Therapy Versus ACE Inhibitor or ARB (Monotherapy) Trial.” There were no significant findings.

Appendix Evidence Table C26 Overview of ACEI plus ARB versus ACEI plus aldosterone antagonist trial

Appendix Table C27 Clinical outcomes (outcomes part A), ACEI plus ARB versus ACEI plus aldosterone antagonist trial

Appendix Figure C6 Forest plots for ACEI plus ARB versus ACEI plus aldosterone antagonist trial

Appendix Figure C6 displays forest plots for risk ratios associated with clinical outcomes in one study of patients receiving ACE inhibitor plus ARB compared to patients receiving ACE inhibitor plus an aldosterone antagonist. The findings are described in the report section “ACE Inhibitor Plus ARB Versus ACE Inhibitor Plus Aldosterone Antagonist Trial.” There were no significant findings.

Appendix Table C28 Clinical renal outcomes (outcomes part C), ACEI plus ARB versus ACEI plus aldosterone antagonist trial

Appendix Table C29 Study withdrawals and adverse events (outcomes part D), ACEI plus ARB versus ACEI plus aldosterone antagonist trial

Appendix Evidence Table C30 Overview of ACEI plus CCB versus ACEI monotherapy or CCB monotherapy trial

Appendix Table C31 Clinical outcomes (outcomes part A), ACEI plus CCB versus ACEI monotherapy or CCB monotherapy trial

Appendix Table C32 Clinical outcomes (outcomespart B), ACEI plus CCB versus ACEI monotherapy or CCB monotherapy trial

Appendix Figure C7 Forest plots for ACEI plus CCB versus ACE monotherapy trial

Appendix Figure C7 displays forest plots for risk ratios associated with clinical outcomes in one study of patients receiving ACE inhibitor plus CCB compared to patients receiving ACE inhibitor alone. The findings are described in the report section “ACE Inhibitor Plus CCB Versus ACE Inhibitor Monotherapy or CCB Monotherapy Trial.” There were no significant findings.

Appendix Figure C8 Forest plots for ACEI plus CCB versus CCB monotherapy trial

Appendix Figure C8 displays forest plots for risk ratios associated with clinical outcomes in one study of patients receiving ACE inhibitor plus CCB compared to patients receiving CCB alone. The findings are described in the report section “ACE Inhibitor Plus CCB Versus ACE Inhibitor Monotherapy or CCB Monotherapy Trial.” There were no significant findings.

Appendix Table C33 Study withdrawals and adverse events (outcomes part D), ACEI plus CCB versus ACEI monotherapy or CCB monotherapy trial

Appendix Table C34 Overview of ACEI plus diuretic versus ACEI plus CCB trials

Appendix Table C35 Clinical outcomes (outcomes part A), ACEI plus diuretic versus ACEI plus CCB trials

Appendix Table C36 Clinical outcomes (outcomes part B), ACEI plus diuretic versus ACEI plus CCB trials

Appendix Table C37 Clinical renal outcomes (outcomes part C), ACEI plus diuretic versus ACEI plus CCB trials

Appendix Table 38 Composite renal outcome definition, ACEI plus diuretic versus ACEI plus CCB trials

Appendix Figure C9 Forest plots forACEI plus diuretic versus ACEI plus CCB trials

Appendix Figure C9 displays forest plots for risk ratios associated with clinical outcomes in one study of patients receiving ACE inhibitor plus diuretic compared to patients receiving ACE inhibitor plus CCB. The findings are described in the report section “ACE Inhibitor Plus Diuretic Versus ACE Inhibitor Plus CCB Trials.” There were no significant findings.

Appendix Table C39 Study withdrawals and adverse events (outcomes part D), ACEI plus diuretic versus ACEI plus CCB trials

Appendix Table C40 Overview of ACEI plus diuretic versus ACEI monotherapy trial

Appendix Table C41 Clinical outcomes (outcomes part B), ACEI plus diuretic versus ACEI monotherapy trial

Appendix Table C42 Composite vascular outcome definitions, ACEI plus diuretic versus ACEI monotherapy trial

Appendix Figure C10 Forest plot for ACEI plus diuretic versus ACEI monotherapy trial

Appendix Figure C10 displays a forest plot for the risk ratio associated with a composite vascular outcome in one study of patients receiving ACE inhibitor plus diuretic compared to patients receiving ACE inhibitor plus placebo. The findings are described in the report section “ACE Inhibitor Plus Diuretic Versus ACE Inhibitor Monotherapy Trial.” Treatment with ACEI plus diuretic was found to significantly reduce the risk of a composite vascular outcome defined as “serious cardiovascular events” compared to treatment with ACEI plus placebo.

Appendix Table C43 Study withdrawals and adverse events (outcomes part D), ACEI plus diuretic versus ACEI monotherapy trial

Appendix Evidence Table C44 Overview of ACEI plus diuretic versus placebo trial

Appendix Table C45 Clinical outcomes (outcomes part A), ACEI plus diuretic versus placebo trial

Appendix Table C46 Clinical outcomes (outcomes part B), ACEI plus diuretic versus placebo trial

Appendix Table C47 Composite vascular outcome definition, ACEI plus diuretic versus placebo trial

Appendix Table C48 Clinical outcomes (outcomes part C), ACEI plus diuretic versus placebo trial

Appendix Table C49 Composite renal outcome definitions, ACEI plus diuretic versus placebo trial

Appendix Figure C11 Forest plots for ACEI plus diuretic versus placebo trial

Appendix Figure C11 displays forest plots for risk ratios associated with clinical outcomes in studies of patients receiving ACEI plus diuretic compared to patients receiving placebo. The findings are described in the report section “ACE Inhibitor Plus Diuretic Versus Placebo Trial.” Treatment with ACEI plus diuretic was found to significantly reduce the risk of cardiovascular mortality compared to placebo.

Appendix Table C50 Study withdrawals and adverse events (outcomes part D), ACEI plus diuretic versus placebo trial

Appendix Table C51 Overview of ARB versus ARB trials

Appendix Table C52 Summary of study baseline characteristics for ARB versus ARB studies

Appendix Table C53 Clinical outcomes (outcomes part A), ARB versus ARB trials

Appendix Table C54 Clinical outcomes (outcomes part B), ARB versus ARB trials

Appendix Table C55 Composite vascular outcome definitions, ARB versus ARB trials

Appendix Figure C12 Forest plots for ARB versus different ARB trials

Appendix Figure C12 displays forest plots for risk ratios associated with clinical outcomes in studies of patients receiving a high dose of an ARB compared to patients receiving a low or standard dose and in studies of patients receiving one ARB (telmisartan) compared to patients receiving a different ARB. The findings are described in the report sections “ARB (Higher Dose) Versus ARB (Lower Dose) Trial” and “ARB Versus Different ARB Trials.” Treatment with a high dose of an ARB was found to significantly reduce the risk of progression from microalbuminuria to macroalbuminuria compared to treatment with a low dose.

Appendix Table C56 Clinical renal outcomes (outcomes part C), ARB versus ARB trials

Appendix Table C57 Composite renal outcome definitions, ARB versus ARB trials

Appendix Table C58 Study withdrawals and adverse events (outcomes part D), ARB versus ARB trials

Appendix Evidence Table C59 Overview of ACEI plus aldosterone antagonist versus ACEI trial

Appendix Table C60 Clinical outcomes (outcomes part A), ACEI plus aldosterone antagonist versus ACEI plus placebo trial

Appendix Table C61 Clinical outcomes (outcome part B), ACEI plus aldosterone antagonist versus ACEI plus placebo trial

Appendix Figure C13 Forest plots for ACEI plus aldosterone antagonist versus ACEI plus placebo trial

Appendix Figure C13 displays forest plots for risk ratios associated with clinical outcomes in one study of patients receiving an ACE inhibitor plus aldosterone antagonist compared to patients receiving an ACE inhibitor plus placebo. The findings are described in the report section “ACE Inhibitor Plus Aldosterone Antagonist Versus ACE Inhibitor Plus Placebo Trial.” There were no significant findings.

Appendix Table C62 Study withdrawals and adverse events (outcomes part D), ACEI plus aldosterone antagonist versus. ACEI plus placebo trials

Appendix Evidence Table C63 Overview of ACE/ARB plus aldosterone antagonist versus ACE/ARB plus placebo trial

Appendix Table C64 Clinical outcomes (outcomes part A), ACEI/ARB plus aldosterone antagonist versus ACEI/ARB plus placebo trial

Appendix Figure C14 Forest plot for ACEI/ARB plus aldosterone antagonist versus ACEI/ARB plus placebo trial

Appendix Figure C14 displays a forest plot for the risk ratio associated with all-cause mortality in one study of patients receiving an ACE inhibitor or ARB plus aldosterone antagonist compared to patients receiving an ACE inhibitor or ARB plus placebo. This finding is described in the report section “ACE Inhibitor/ARB Plus Aldosterone Antagonist Versus ACE Inhibitor/ARB Plus Placebo Trial.” The finding was not significant.

Appendix Table C65 Study withdrawals and adverse events (outcomes part D), ACEI/ARB plus aldosterone antagonist versus ACEI/ARB plus placebo trial

Appendix Evidence Table C66 Overview of BB versus placebo trials

Appendix Table C67 Clinical outcomes (outcomes part A), BB versus placebo trials

Appendix Table C68 Clinical outcomes (outcomes part B), BB versus placebo trials

Appendix Table C69 Composite vascular outcome definitions, BB versus placebo trials

Appendix Figure C15 Forest plots for BB versus placebo trials

Appendix Figure C15 displays forest plots for risk ratios associated with clinical outcomes in studies of patients receiving beta blocker (BB) compared to patients receiving placebo. The findings are described further in the section “BB Versus Placebo Trials.” Treatment with BB was found to significantly reduce the risk of all-cause mortality compared to placebo.

Appendix Table C70 Study withdrawals and adverse events (outcomes part D), BB versus placebo trials

Appendix Evidence Table C71 Overview of CCB versus placebo trials

Appendix Table C72 Summary of study baseline characteristics, CCB versus placebo trials

Appendix Table C73 Clinical outcomes (outcomes part A), CCB versus placebo trials

Appendix Figure C16 Forest plots for CCB versus placebo trials

Appendix Figure C16 displays forest plots for risk ratios associated with clinical outcomes in studies of patients receiving calcium channel blocker (CCB) compared to patients receiving placebo. The findings are described in the report section “CCB Versus Placebo Trials.” Treatment with CCB was found to significantly reduce the risk of myocardial infarction compared to placebo.

Appendix Table C74 Clinical outcomes (outcomes part B), CCB versus placebo trials

Appendix Table C75 Composite vascular outcome definitions, CCB versus placebo trials

Appendix Table C76 Clinical renal outcomes (outcomes part C), CCB versus placebo trials

Appendix Table C77 Composite renal outcome definitions, CCB versus placebo trials

Appendix Table C78 Study withdrawals and adverse events (outcomes part D), CCB versus placebo trials

Appendix Evidence Table C79 Overview of diuretic versus placebo trial

Appendix Table C80 Clinical outcomes (outcomes part A), diuretic versus placebo trial

Appendix Table C81 Clinical outcomes (outcomes part B), diuretic versus placebo trial

Appendix Figure C17 Forest plots for diuretic versus placebo trial

Appendix Figure C17 displays forest plots for risk ratios associated with clinical outcomes in one study of patients receiving diuretic compared to patients receiving placebo. The findings are described in the report section “Diuretic Versus Placebo Trial.” Treatment with diuretic was found to significantly reduce the risk of stroke and the risk of a composite vascular outcome defined as “any cardiovascular event” (stroke, transient ischemic attack, myocardial infarction, heart failure, coronary artery bypass grafting, angioplasty, aneurysm, endarterectomy, sudden death, or rapid cardiac death).

Appendix Table C82 Composite vascular outcome definitions, diuretic versus placebo trial

Appendix Table C83 Study withdrawals and adverse events (outcomes part D), diuretic versus placebo trial

Appendix Evidence Table C84 Overview of ACEI versus conventional therapy without ACEI trial

Appendix Table C85 Clinical outcomes (outcomes part A), ACEI versus conventional therapy without ACEI trial

Appendix Table C86 Clinical renal outcomes (outcomes part C), ACEI versus conventional therapy without ACEI trial

Appendix Table C87 Composite renal outcome definitions, ACEI versus conventional therapy without ACEI trial

Appendix Figure C18 Forest plots for ACEI versus conventional therapy without ACEI trial

Appendix Figure C18 displays forest plots for risk ratios associated with clinical outcomes in one study of patients receiving ACE inhibitor compared to patients receiving therapy without ACE inhibitor. The findings are described in the report section “ACE Inhibitor Versus Non-ACE Inhibitor Antihypertensive Therapy Trial.” There were no significant findings.

Appendix Table C88 Study withdrawals and adverse events (outcomes part D), ACEI versus conventional therapy without ACEI trial

Appendix Table C89 Overview of CCB versus BB trials

Appendix Table C90 Summary of study baseline characteristics, CCB versus BB trials

Appendix Table C91 Clinical outcomes (outcomes part A), CCB versus BB trials

Appendix Table C92 Clinical outcomes (outcomes part B), CCB versus BB trials

Appendix Table C93 Composite vascular outcome definitions, CCB versus BB trials

Appendix Figure C19 Forest plots for CCB versus BB trials

Appendix Figure C19 displays forest plots for risk ratios associated with clinical outcomes in studies of patients receiving calcium channel blocker (CCB) compared to patients receiving beta blocker (BB). The findings are described in the report section “CCB Versus BB Trials.” Treatment with CCB was found to significantly reduce the risk of a composite vascular outcome (defined as cardiovascular mortality, nonfatal MI (symptomatic and silent), unstable angina, chronic stable angina, life threatening arrhythmias, silent nonfatal heart failure, nonfatal stroke, peripheral arterial disease, revascularization procedures, and retinal vascular thromboses) compared to treatment with BB.

Appendix Table C94 Clinical renal outcomes (outcomes part C), CCB versus BB trials

Appendix Table C95 Composite renal outcome definitions, CCB versus BB trials

Appendix Table C96 Study withdrawals and adverse events (outcomes part D), CCB versus BB trials

Appendix Table C97 Overview of CCB versus diuretic trial

Appendix Table C98 Summary of study baseline characteristics, CCB versus diuretic trial

Appendix Table C99 Clinical outcomes (outcomes part A), CCB versus diuretic trial

Appendix Table C100 Clinical outcomes (outcomes part B), CCB versus diuretic trial

Appendix Table C101 Composite vascular outcome definitions, CCB versus diuretic trial

Appendix Table C102 Clinical renal outcomes (outcomes part C), CCB versus diuretic trial

Appendix Table C103 Composite renal outcome definitions, CCB versus diuretic trial

Appendix Figure C20 Forest plots for CCB versus diuretic trial

Appendix Figure C20 displays forest plots for risk ratios associated with clinical outcomes in one study of patients receiving calcium channel blocker (CCB) compared to patients receiving diuretic. The findings are described in the report section “CCB Monotherapy Versus Diuretic Trial.” There were no significant findings.

Appendix Table C104 Overview of strict versus standard blood pressure control trials

Appendix Table C105 Summary of study baseline characteristics, strict versus standard blood pressure control trials

Appendix Table C106 Clinical outcomes (outcomes part A), strict versus standard blood pressure control trials

Appendix Figure C21 Forest plots for strict versus standard blood pressure control trials

Appendix Figure C21 displays forest plots for risk ratios associated with clinical outcomes in studies of patients assigned to strict blood pressure control compared to patients assigned to standard blood pressure control. The findings are described in the report section “Strict Versus Standard Blood Pressure Target Treatment Trials.” There were no significant findings.

Appendix Table C107 Clinical outcomes (outcomes part B), strict versus standard blood pressure control trials

Appendix Table C108 Composite vascular outcome definitions, strict versus standard blood pressure control trial

Appendix Table C109 Clinical renal outcomes (outcomes part C), strict versus standard blood pressure control trials

Appendix Table C110 Composite renal outcome definitions, strict versus standard blood pressure control trials

Appendix Table C111 Study withdrawals and adverse events (outcomes part D), strict versus standard blood pressure control trials

Appendix Table C112 Overview of low protein diet versus usual protein diet and other dietary intervention trials

Appendix Table C113 Summary of study baseline characteristics for low protein diet versus usual protein diet and other dietary intervention trials

Appendix Table C114 Clinical outcomes (outcomes part A), low protein diet versus usual protein diet and other dietary intervention trials

Appendix Figure C22 Forest plots for low protein diet versus usual protein diet and other dietary intervention trials

Appendix Figure C22 displays forest plots for risk ratios associated with clinical outcomes in studies of patients assigned to different dietary interventions. The findings are described in the report sections “Low Protein Diet Versus Usual Protein Diet Trials” and “Other Dietary Intervention Trials.” Treatment with a low protein diet was found to decrease the risk of a composite renal outcome defined as dialysis or doubling of plasma creatinine concentration compared to a usual protein diet. Treatment with a low protein diet was found to increase the risk of a doubling of serum creatinine and a composite renal outcome defined as renal replacement therapy or death compared to a carbohydrate restricted, low-iron-available, polyphenol-enriched diet.

Appendix Table C115 Clinical outcomes (outcomes part B), low protein diet versus usual protein diet and other dietary intervention trials

Appendix Table C116 Clinical renal outcomes (outcomes part C), low protein diet versus usual protein diet and other dietary intervention trials

Appendix Table C117 Composite renal outcome definitions, low protein diet versus usual protein diet and other dietary intervention trials

Appendix Table C118 Study withdrawals and adverse events (outcomes part D), low protein diet versus usual protein diet and other dietary intervention trials

Appendix Evidence Table C119 Overview of glycemic control trials

Appendix Table C120 Summary of study baseline characteristics for glycemic control trials

Appendix Table C121 Clinical outcomes (outcomes part A), glycemic control trials

Appendix Table C122 Clinical renal outcomes (outcomes part C), glycemic control trials

Appendix Figure C23 Forest plot for glycemic control trials

Appendix Figure C23 displays a forest plot for the risk ratio associated with progression from microalbuminuria to macroalbuminuria in two studies of patients assigned to intensive glycemic control compared to patients assigned to conventional glycemic control. The finding is described in the report section “Glycemic Control Trials.” The finding was not significant.

Appendix Table C123 Study withdrawals and adverse events (outcomes part D), glycemic control trials

Appendix Table C124 Overview of anti-lipid trials

Appendix Table C125 Summary of study baseline characteristics, anti-lipid (AL) monotherapy versus control treatment trials

Appendix Table C126 Clinical outcomes (outcomes part A), AL monotherapy versus control treatment trials

Appendix Figure C24 Forest plots for anti-lipid monotherapy versus control trials

Appendix Figure C24 displays forest plots for risk ratios associated with clinical outcomes in studies of patients receiving antilipid treatment compared to patients receiving a control treatment. The findings are described in the report sections “HMG-CoA Reductase Inhibitors (Statins) Versus Control Trials,” “High-Dose Versus Low-Dose HMG-CoA Reductase Inhibitors Trials,” “HMG-CoA Reductase Inhibitor Versus Bile Acid Sequestrant Trial” and “Gemfibrozil Versus Placebo or Control Trials.” Treatment with HMG-CoA Reductase Inhibitors was found to reduce the risk of all-cause mortality, myocardial infarction, non-fatal myocardial infarction, and stroke compared to placebo. A high dose of HMG-CoA Reductase Inhibitor was found to significantly reduce the risk of hospitalization for congestive heart failure compared to a lower dose. Treatment with gemfibrozil was found to significantly reduce the risk of a composite vascular outcome defined as fatal coronary heart disease, nonfatal myocardial infarction, and stroke.

Appendix Table C127 Clinical outcomes (outcomes part B), AL monotherapy versus control treatment trials

Appendix Table C128 Composite vascular outcome definitions, AL monotherapy versus control treatment trials

Appendix Table C129 Clinical renal outcomes (outcomes part C), AL monotherapy versus control treatment trials

Appendix Table C130 Composite renal outcome definitions for AL monotherapy versus control treatment trials

Appendix Table C131 Study withdrawals and adverse events (outcomes part D), AL monotherapy versus control treatment trials

Appendix Evidence Table C132 Overview of intensive multicomponent intervention (INT) versus control treatment trials

Appendix Table C133 Summary of study baseline characteristics for INT versus control treatment trials

Appendix Table C134 Clinical outcomes (outcomes part A), INT versus control treatment trials

Appendix Figure C25 Forest plots for INT versus control treatment trials

Appendix Figure C25 displays forest plots for risk ratios associated with clinical outcomes in studies of patients assigned to intensive, multi-component treatment (INT) compared to patients assigned to standard (control) treatment. The findings are described in the report section “Intensive Multi-Component Intervention Trials.” Treatment with an intensive multi-component approach was found to significantly reduce the risk of non-fatal stroke and the risk of progression from microalbuminuria to macroalbuminuria.

Appendix Table C135 Clinical outcomes (outcomes part B), INT versus control treatment trials

Appendix Table C136 Composite vascular outcome definitions for INT versus control treatment trials

Appendix Table C137 Clinical renal outcomes (outcomes part C), INT versus control treatment trials

Appendix Table C138 Composite renal outcome definitions for INT versus control treatment trials

Appendix Table C139 Study withdrawals and adverse events (outcomes part D), INT versus control treatment trials

Table C140 Assessment of individual study quality for KQ5 and KQ6

## References for Appendix C

1 Perkovic V, Ninomiya T, Arima H, et al. Chronic kidney disease, cardiovascular events, and the effects of perindopril-based blood pressure lowering: data from the PROGRESS study. Journal of the American Society of Nephrology. Oct. 2007;18(10):2766-72. [pmid: 17804673].
2 Asselbergs FW, Diercks GFH, Hillege HL, et al. Effects of fosinopril and pravastatin on cardiovascular events in subjects with microalbuminuria. Circulation. Nov. 2. 2004;110(18):2809-16. [pmid: 15492322].
3 Marre M, Lievre M, Chatellier G, et al. Effects of low dose ramipril on cardiovascular and renal outcomes in patients with type 2 diabetes and raised excretion of urinary albumin: randomised, double blind, placebo controlled trial (the DIABHYCAR study). [Erratum appears in BMJ. 2004 Mar 20; 328(7441):686]. BMJ. Feb. 28. 2004;328(7438):495. [pmid: 14960504].
4 Katayama S, Kikkawa R, Isogai S, et al. Effect of captopril or imidapril on the progression of diabetic nephropathy in Japanese with type 1 diabetes mellitus: a randomized controlled study (JAPAN-IDDM). [Erratum appears in Diabetes Res Clin Pract 2002 Jul;57(1):71]. Diabetes Research & Clinical Practice. Feb. 2002;55(2):113-21. [pmid: 11796177].
5 Bojestig M, Karlberg BE, Lindstrom T, et al. Reduction of ACE activity is insufficient to decrease microalbuminuria in normotensive patients with type 1 diabetes. Diabetes Care. May. 2001;24(5):919-24. [pmid: 11347755].
6 Gerstein HC, Mann JF, Yi Q, et al. Albuminuria and risk of cardiovascular events, death, and heart failure in diabetic and nondiabetic individuals. JAMA. Jul. 25. 2001;286(4):421-6. [pmid: 11466120].
7 O'Hare P, Bilbous R, Mitchell T, et al. Low-dose ramipril reduces microalbuminuria in type 1 diabetic patients without hypertension: results of a randomized controlled trial. Diabetes Care. Dec. 2000;23(12):1823-9. [pmid: 11128360].
8 Muirhead N, Feagan BF, Mahon J, et al. The effects of valsartan and captopril on reducing microalbuminuria in patients with type 2 diabetes mellitus: a placebo-controlled trial. Current Therapeutic Research - Clinical and Experimental. 1999. Dec. 1999;60(12):650-60.
9 Ruggenenti P, Perna A, Gherardi G, et al. Renoprotective properties of ACE-inhibition in non-diabetic nephropathies with non-nephrotic proteinuria. Lancet. Jul. 31. 1999;354(9176):359-64. [pmid: 10437863].
10 Crepaldi G, Carta Q, Deferrari G, et al. Effects of lisinopril and nifedipine on the progression to overt albuminuria in IDDM patients with incipient nephropathy and normal blood pressure. The Italian Microalbuminuria Study Group in IDDM. Diabetes Care. Jan. 1998;21(1):104-10. [pmid: 9538979].
11 Randomised placebo-controlled trial of effect of ramipril on decline in glomerular filtration rate and risk of terminal renal failure in proteinuric, non-diabetic nephropathy. The GISEN Group (Gruppo Italiano di Studi Epidemiologici in Nefrologia). Lancet. Jun. 28. 1997;349(9069):1857-63. [pmid: 9217756].
12 Maschio G, Alberti D, Janin G, et al. Effect of the angiotensin-converting-enzyme inhibitor benazepril on the progression of chronic renal insufficiency. The Angiotensin-Converting-Enzyme Inhibition in Progressive Renal Insufficiency Study Group. New England Journal of Medicine. Apr. 11. 1996;334(15):939-45. [pmid: 8596594].
13 Trevisan R, Tiengo A. Effect of low-dose ramipril on microalbuminuria in normotensive or mild hypertensive non-insulin-dependent diabetic patients. North-East Italy Microalbuminuria Study Group. American Journal of Hypertension. Sep. 1995;8(9):876-83. [pmid: 8541002].
14 Laffel LM, McGill JB, Gans DJ. The beneficial effect of angiotensin-converting enzyme inhibition with captopril on diabetic nephropathy in normotensive IDDM patients with microalbuminuria. North American Microalbuminuria Study Group. American Journal of Medicine. Nov. 1995;99(5):497-504. [pmid: 7485207].
15 Sano T, Kawamura T, Matsumae H, et al. Effects of long-term enalapril treatment on persistent micro-albuminuria in well-controlled hypertensive and normotensive NIDDM patients. Diabetes Care. May. 1994;17(5):420-4. [pmid: 8062609].
16 Lewis EJ, Hunsicker LG, Bain RP, et al. The effect of angiotensin-converting-enzyme inhibition on diabetic nephropathy. The Collaborative Study Group. [Erratum appears in N Engl J Med 1993 Jan 13;330(2):152]. New England Journal of Medicine. Nov. 11. 1993;329(20):1456-62. [pmid: 8413456].
17 Ravid M, Savin H, Jutrin I, et al. Long-term stabilizing effect of angiotensin-converting enzyme inhibition on plasma creatinine and on proteinuria in normotensive type II diabetic patients. Annals of Internal Medicine. Apr. 15. 1993;118(8):577-81. [pmid: 8452322].
18 Mann JFE, Schmieder RE, McQueen M, et al. Renal outcomes with telmisartan, ramipril, or both, in people at high vascular risk (the ONTARGET study): a multicentre, randomised, double-blind, controlled trial. Lancet. Aug. 16. 2008;372(9638):547-53. [pmid: 18707986].
19 Menne J, Farsang C, Deak L, et al. Valsartan in combination with lisinopril versus the respective high dose monotherapies in hypertensive patients with microalbuminuria: the VALERIA trial. Journal of Hypertension. Sep. 2008;26(9):1860-7. [pmid: 18698222].
20 Sengul AM, Altuntas Y, Kurklu A, et al. Beneficial effect of lisinopril plus telmisartan in patients with type 2 diabetes, microalbuminuria and hypertension. Diabetes Research & Clinical Practice. Feb. 2006;71(2):210-9. [pmid: 16112244].
21 Barnett AH, Bain SC, Bouter P, et al. Angiotensin-receptor blockade versus converting-enzyme inhibition in type 2 diabetes and nephropathy. [Erratum appears in N Engl J Med. 2005 Apr 21;352(16)1731]. New England Journal of Medicine. Nov. 4. 2004;351(19):1952-61. [pmid: 15516696].
22 Lacourciere Y, Belanger A, Godin C, et al. Long-term comparison of losartan and enalapril on kidney function in hypertensive type 2 diabetics with early nephropathy. Kidney International. Aug. 2000;58(2):762-9. [pmid: 10916100].
23 Rahman M, Pressel S, Davis BR, et al. Renal outcomes in high-risk hypertensive patients treated with an angiotensin-converting enzyme inhibitor or a calcium channel blocker vs a diuretic: a report from the Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT). Archives of Internal Medicine. Apr. 25. 2005;165(8):936-46. [pmid: 15851647].
24 Fogari R, Preti P, Zoppi A, et al. Effects of amlodipine fosinopril combination on microalbuminuria in hypertensive type 2 diabetic patients. American Journal of Hypertension. Dec. 2002;15(12):1042-9. [pmid: 12460699].
25 Agodoa LY, Appel L, Bakris GL, et al. Effect of ramipril vs amlodipine on renal outcomes in hypertensive nephrosclerosis: a randomized controlled trial. JAMA. Jun. 6. 2001;285(21):2719-28. [pmid: 11386927].
26 Wright JT Jr, Bakris G, Greene T, et al. Effect of blood pressure lowering and antihypertensive drug class on progression of hypertensive kidney disease: results from the AASK trial. [Erratum appears in JAMA. 2006 Jun 21;295(23):2726]. JAMA. Nov. 20. 2002;288(19):2421-31. [pmid: 12435255].
27 Norris K, Bourgoigne J, Gassman J, et al. Cardiovascular outcomes in the African American Study of Kidney Disease and Hypertension (AASK) Trial. American Journal of Kidney Diseases. Nov. 2006;48(5):739-51. [pmid: 17059993].
28 Marin R, Ruilope LM, Aljama P, et al. A random comparison of fosinopril and nifedipine GITS in patients with primary renal disease. Journal of Hypertension. Oct. 2001;19(10):1871-6. [pmid: 11593109].
29 Zucchelli P, Zuccala A, Gaggi R. Comparison of the effects of ACE inhibitors and calcium channel blockers on the progression of renal failure. Nephrology Dialysis Transplantation. Oct. Suppl 9. 1995;10:46-51. [pmid: 8643208].
30 Zucchelli P, Zuccala A, Borghi M, et al. Long-term comparison between captopril and nifedipine in the progression of renal insufficiency. Kidney International. Aug. 1992;42(2):452-8. [pmid: 1405330].
31 van Essen GG, Apperloo AJ, Rensma PL, et al. Are angiotensin converting enzyme inhibitors superior to beta blockers in retarding progressive renal function decline?. Kidney International - Supplement. Dec. 1997;63:S58-62. [pmid: 9407423].
32 Hannedouche T, Landais P, Goldfarb B, et al. Randomised controlled trial of enalapril and beta blockers in non-diabetic chronic renal failure. BMJ. Oct. 1. 1994;309(6958):833-7. [pmid: 7950612].
33 Marre M, Puig JG, Kokot F, et al. Equivalence of indapamide SR and enalapril on microalbuminuria reduction in hypertensive patients with type 2 diabetes: the NESTOR Study. Journal of Hypertension. Aug. 2004;22(8):1613-22. [pmid: 15257186].
34 Rahman M, Pressel S, Davis BR, et al. Cardiovascular outcomes in high-risk hypertensive patients stratified by baseline glomerular filtration rate. [Summary for patients in Ann Intern Med. 2006 Feb 7;144(3):I33; PMID: 16461958]. Annals of Internal Medicine. Feb. 7. 2006;144(3):172-80. [pmid: 16461961].
35 Tobe SW, Clase CM, Gao P, et al. Cardiovascular and renal outcomes with telmisartan, ramipril, or both in people at high renal risk: results from the ONTARGET and TRANSCEND studies. Circulation. Mar. 15. 2011;123(10):1098-107. [pmid: 21357827].
36 Yusuf S, Sleight P, Pogue J, et al. Effects of an angiotensin-converting-enzyme inhibitor, ramipril, on cardiovascular events in high-risk patients. The Heart Outcomes Prevention Evaluation Study Investigators. New England Journal of Medicine. Jan. 20. 2000;342(3):145-53. [pmid: 10639539].
37 Makino H, Haneda M, Babazono T, et al. Prevention of transition from incipient to overt nephropathy with telmisartan in patients with type 2 diabetes. Diabetes Care. Jun. 2007;30(6):1577-8. [pmid: 17389334].
38 Brenner BM, Cooper ME, de Zeeuw D, et al. Effects of losartan on renal and cardiovascular outcomes in patients with type 2 diabetes and nephropathy. New England Journal of Medicine. Sep. 20. 2001;345(12):861-9. [pmid: 11565518].
39 Parving HH, Lehnert H, Brochner-Mortensen J, et al. The effect of irbesartan on the development of diabetic nephropathy in patients with type 2 diabetes. New England Journal of Medicine. Sep. 20. 2001;345(12):870-8. [pmid: 11565519].
40 Lewis EJ, Hunsicker LG, Clarke WR, et al. Renoprotective effect of the angiotensin-receptor antagonist irbesartan in patients with nephropathy due to type 2 diabetes. New England Journal of Medicine. Sep. 20. 2001;345(12):851-60. [pmid: 11565517].
41 Saruta T, Hayashi K, Ogihara T, et al. Effects of candesartan and amlodipine on cardiovascular events in hypertensive patients with chronic kidney disease: subanalysis of the CASE-J Study. Hypertension Research - Clinical & Experimental. Jun. 2009;32(6):505-12. [pmid: 19390535].
42 Ogawa S, Takeuchi K, Mori T, et al. Effects of monotherapy of temocapril or candesartan with dose increments or combination therapy with both drugs on the suppression of diabetic nephropathy. Hypertension Research - Clinical & Experimental. Apr. 2007;30(4):325-34. [pmid: 17541211].
43 Viberti G, Wheeldon NM, MicroAlbuminuria Reduction With VSI. Microalbuminuria reduction with valsartan in patients with type 2 diabetes mellitus: a blood pressure-independent effect. Circulation. Aug. 6. 2002;106(6):672-8. [pmid: 12163426].
44 Kanno Y, Takenaka T, Nakamura T, et al. Add-on angiotensin receptor blocker in patients who have proteinuric chronic kidney diseases and are treated with angiotensin-converting enzyme inhibitors. Clinical Journal of The American Society of Nephrology: CJASN. Jul. 2006;1(4):730-7. [pmid: 17699280].
45 Mehdi UF, Adams-Huet B, Raskin P, et al. Addition of angiotensin receptor blockade or mineralocorticoid antagonism to maximal angiotensin-converting enzyme inhibition in diabetic nephropathy. Journal of the American Society of Nephrology. Dec. 2009;20(12):2641-50. [pmid: 19926893].
46 Anand IS, Bishu K, Rector TS, et al. Proteinuria, chronic kidney disease, and the effect of an angiotensin receptor blocker in addition to an angiotensin-converting enzyme inhibitor in patients with moderate to severe heart failure. Circulation. Oct. 20. 2009;120(16):1577-84. [pmid: 19805651].
47 Bakris GL, Toto RD, McCullough PA, et al. Effects of different ACE inhibitor combinations on albuminuria: results of the GUARD study. Kidney International. Jun. 2008;73(11):1303-9. [pmid: 18354383].
48 Bakris GL, Sarafidis PA, Weir MR, et al. Renal outcomes with different fixed-dose combination therapies in patients with hypertension at high risk for cardiovascular events (ACCOMPLISH): a prespecified secondary analysis of a randomised controlled trial. Lancet. Apr. 3. 2010;375(9721):1173-81. [pmid: 20170948].
49 Jamerson KA, Bakris GL, Wun CC, et al. Rationale and design of the avoiding cardiovascular events through combination therapy in patients living with systolic hypertension (ACCOMPLISH) trial: the first randomized controlled trial to compare the clinical outcome effects of first-line combination therapies in hypertension. Am J Hypertens. Sep. 2004;17(9):793-801. [pmid: 15363822].
50 Mogensen CE, Viberti G, Halimi S, et al. Effect of low-dose perindopril/indapamide on albuminuria in diabetes: preterax in albuminuria regression: PREMIER. Hypertension. May. 2003;41(5):1063-71. [pmid: 12654706].
51 Lambers Heerspink HJ, Gansevoort RT, Brenner BM, et al. Comparison of different measures of urinary protein excretion for prediction of renal events. J Am Soc Nephrol. Aug. 2010;21(8):1355-60. [pmid: 20634296].
52 Study rationale and design of ADVANCE: action in diabetes and vascular disease--preterax and diamicron MR controlled evaluation. Diabetologia. Sep. 2001;44(9):1118-20. [pmid: 11596665].
53 Bakris G, Burgess E, Weir M, et al. Telmisartan is more effective than losartan in reducing proteinuria in patients with diabetic nephropathy. Kidney International. Aug. 2008;74(3):364-9. [pmid: 18496508].
54 Galle J, Schwedhelm E, Pinnetti S, et al. Antiproteinuric effects of angiotensin receptor blockers: telmisartan versus valsartan in hypertensive patients with type 2 diabetes mellitus and overt nephropathy. Nephrology Dialysis Transplantation. Oct. 2008;23(10):3174-83. [pmid: 18450829].
55 Burgess E, Muirhead N, Rene de Cotret P, et al. Supramaximal dose of candesartan in proteinuric renal disease. Journal of the American Society of Nephrology. Apr. 2009;20(4):893-900. [pmid: 19211712].
56 van den Meiracker AH, Baggen RG, Pauli S, et al. Spironolactone in type 2 diabetic nephropathy: Effects on proteinuria, blood pressure and renal function. Journal of Hypertension. Nov. 2006;24(11):2285-92. [pmid: 17053552].
57 Cohen-Solal A, Kotecha D, van Veldhuisen DJ, et al. Efficacy and safety of nebivolol in elderly heart failure patients with impaired renal function: insights from the SENIORS trial. Eur J Heart Fail. Sep. 2009;11(9):872-80. [pmid: 19648605].
58 Flather MD, Shibata MC, Coats AJ, et al. Randomized trial to determine the effect of nebivolol on mortality and cardiovascular hospital admission in elderly patients with heart failure (SENIORS). Eur Heart J. Feb. 2005;26(3):215-25. [pmid: 15642700].
59 Ghali JK, Wikstrand J, Van Veldhuisen DJ, et al. The influence of renal function on clinical outcome and response to beta-blockade in systolic heart failure: insights from Metoprolol CR/XL Randomized Intervention Trial in Chronic HF (MERIT-HF). Journal of Cardiac Failure. May. 2009;15(4):310-8. [pmid: 19398079].
60 Berl T, Hunsicker LG, Lewis JB, et al. Cardiovascular outcomes in the Irbesartan Diabetic Nephropathy Trial of patients with type 2 diabetes and overt nephropathy. [Summary for patients in Ann Intern Med. 2003 Apr 1;138(7):I43; PMID: 12667050]. Annals of Internal Medicine. Apr. 1. 2003;138(7):542-9. [pmid: 12667024].
61 Pahor M, Shorr RI, Somes GW, et al. Diuretic-based treatment and cardiovascular events in patients with mild renal dysfunction enrolled in the systolic hypertension in the elderly program. Archives of Internal Medicine. Jun. 22. 1998;158(12):1340-5. [pmid: 9645829].
62 Cinotti GA, Zucchelli PC, Collaborative Study G. Effect of Lisinopril on the progression of renal insufficiency in mild proteinuric non-diabetic nephropathies. Nephrology Dialysis Transplantation. May. 2001;16(5):961-6. [pmid: 11328901].
63 Bakris GL, Copley JB, Vicknair N, et al. Calcium channel blockers versus other antihypertensive therapies on progression of NIDDM associated nephropathy. Kidney International. Nov. 1996;50(5):1641-50. [pmid: 8914031].
64 Wright JT Jr, Kusek JW, Toto RD, et al. Design and baseline characteristics of participants in the African American Study of Kidney Disease and Hypertension (AASK) Pilot Study. Controlled Clinical Trials. Aug. 1996;17(4 Suppl):3S-16S. [pmid: 8889350].
65 Dahlof B, Sever PS, Poulter NR, et al. Prevention of cardiovascular events with an antihypertensive regimen of amlodipine adding perindopril as required versus atenolol adding bendroflumethiazide as required, in the Anglo-Scandinavian Cardiac Outcomes Trial-Blood Pressure Lowering Arm (ASCOT-BPLA): a multicentre randomised controlled trial. Lancet. Sep. 10-16. 2005;366(9489):895-906. [pmid: 16154016].
66 Ruggenenti P, Perna A, Loriga G, et al. Blood-pressure control for renoprotection in patients with non-diabetic chronic renal disease (REIN-2): multicentre, randomised controlled trial. Lancet. Mar. 12-18. 2005;365(9463):939-46. [pmid: 15766995].
67 Estacio RO, Jeffers BW, Gifford N, et al. Effect of blood pressure control on diabetic microvascular complications in patients with hypertension and type 2 diabetes. Diabetes Care. Apr. Suppl 2. 2000;23:B54-64. [pmid: 10860192].
68 Schrier RW, Estacio RO, Esler A, et al. Effects of aggressive blood pressure control in normotensive type 2 diabetic patients on albuminuria, retinopathy and strokes. Kidney Int. Mar. 2002;61(3):1086-97. [pmid: 11849464].
69 Lewis JB, Berl T, Bain RP, et al. Effect of intensive blood pressure control on the course of type 1 diabetic nephropathy. Collaborative Study Group. American Journal of Kidney Diseases. Nov. 1999;34(5):809-17. [pmid: 10561135].
70 Toto RD, Mitchell HC, Smith RD, et al. “Strict” blood pressure control and progression of renal disease in hypertensive nephrosclerosis. Kidney International. Sep. 1995;48(3):851-9. [pmid: 7474675].
71 Peterson JC, Adler S, Burkart JM, et al. Blood pressure control, proteinuria, and the progression of renal disease. The Modification of Diet in Renal Disease Study. Annals of Internal Medicine. Nov. 15. 1995;123(10):754-62. [pmid: 7574193].
72 Klahr S, Levey AS, Beck GJ, et al. The effects of dietary protein restriction and blood-pressure control on the progression of chronic renal disease. Modification of Diet in Renal Disease Study Group. New England Journal of Medicine. Mar. 31. 1994;330(13):877-84. [pmid: 8114857].
73 Greene T, Bourgoignie JJ, Habwe V, et al. Baseline characteristics in the Modification of Diet in Renal Disease Study. [Republished from J Am Soc Nephrol 1993 May;3(11):1819-34]. Journal of the American Society of Nephrology. Nov. 1993;4(5):1221-36. [pmid: 8305650].
74 Shulman NB, Ford CE, Hall WD, et al. Prognostic value of serum creatinine and effect of treatment of hypertension on renal function. Results from the hypertension detection and follow-up program. The Hypertension Detection and Follow-up Program Cooperative Group. Hypertension. May. 1989;13(5 Suppl):I80-93. [pmid: 2490833].
75 Koya D, Haneda M, Inomata S, et al. Long-term effect of modification of dietary protein intake on the progression of diabetic nephropathy: a randomised controlled trial. Diabetologia. Oct. 2009;52(10):2037-45. [pmid: 19652945].
76 Dussol B, Iovanna C, Raccah D, et al. A randomized trial of low-protein diet in type 1 and in type 2 diabetes mellitus patients with incipient and overt nephropathy. Journal of Renal Nutrition. Oct. 2005;15(4):398-406. [pmid: 16198932].
77 Kopple JD, Levey AS, Greene T, et al. Effect of dietary protein restriction on nutritional status in the Modification of Diet in Renal Disease Study. Kidney International. Sep. 1997;52(3):778-91. [pmid: 9291200].
78 D'Amico G, Gentile MG, Fellin G, et al. Effect of dietary protein restriction on the progression of renal failure: a prospective randomized trial. Nephrology Dialysis Transplantation. 1994;9(11):1590-4. [pmid: 7870348].
79 Locatelli F, Alberti D, Graziani G, et al. Prospective, randomised, multicentre trial of effect of protein restriction on progression of chronic renal insufficiency. Northern Italian Cooperative Study Group. Lancet. Jun. 1. 1991;337(8753):1299-304. [pmid: 1674294].
80 Rosman JB, Langer K, Brandl M, et al. Protein-restricted diets in chronic renal failure: a four year follow-up shows limited indications. Kidney International - Supplement. Nov. 1989;27:S96-102. [pmid: 2636680].
81 Rosman JB, ter Wee PM, Meijer S, et al. Prospective randomised trial of early dietary protein restriction in chronic renal failure. Lancet. Dec. 8. 1984;2(8415):1291-6. [pmid: 6150320].
82 Facchini FS, Saylor KL. A low-iron-available, polyphenol-enriched, carbohydrate-restricted diet to slow progression of diabetic nephropathy. Diabetes. May. 2003;52(5):1204-9. [pmid: 12716753].
83 Williams PS, Stevens ME, Fass G, et al. Failure of dietary protein and phosphate restriction to retard the rate of progression of chronic renal failure: a prospective, randomized, controlled trial. Quarterly Journal of Medicine. Oct. 1991;81(294):837-55. [pmid: 1801057].
84 Samuelsson O, Attman PO, Knight-Gibson C, et al. Effect of gemfibrozil on lipoprotein abnormalities in chronic renal insufficiency: a controlled study in human chronic renal disease. Nephron. 1997;75(3):286-94. [pmid: 9069450].
85 Duckworth W, Abraira C, Moritz T, et al. Glucose control and vascular complications in veterans with type 2 diabetes. New England Journal of Medicine. Jan. 8. 2009;360(2):129-39. [pmid: 19092145].
86 Intensive therapy and progression to clinical albuminuria in patients with insulin dependent diabetes mellitus and microalbuminuria. Microalbuminuria Collaborative Study Group, United Kingdom. BMJ. Oct. 14. 1995;311(7011):973-7. [pmid: 7580637].
87 Kendrick J, Shlipak MG, Targher G, et al. Effect of lovastatin on primary prevention of cardiovascular events in mild CKD and kidney function loss: a post hoc analysis of the Air Force/Texas Coronary Atherosclerosis Prevention Study. American Journal of Kidney Diseases. Jan. 2010;55(1):42-9. [pmid: 19932541].
88 Ridker PM, MacFadyen J, Cressman M, et al. Efficacy of rosuvastatin among men and women with moderate chronic kidney disease and elevated high-sensitivity C-reactive protein: a secondary analysis from the JUPITER (Justification for the Use of Statins in Prevention-an Intervention Trial Evaluating Rosuvastatin) trial. J Am Coll Cardiol. Mar. 23. 2010;55(12):1266-73. [pmid: 20206456].
89 Nakamura H, Mizuno K, Ohashi Y, et al. Pravastatin and cardiovascular risk in moderate chronic kidney disease. Atherosclerosis. Oct. 2009;206(2):512-7. [pmid: 19423108].
90 Colhoun HM, Betteridge DJ, Durrington PN, et al. Effects of atorvastatin on kidney outcomes and cardiovascular disease in patients with diabetes: an analysis from the Collaborative Atorvastatin Diabetes Study (CARDS). American Journal of Kidney Diseases. Nov. 2009;54(5):810-9. [pmid: 19540640].
91 Koren MJ, Davidson MH, Wilson DJ, et al. Focused atorvastatin therapy in managed-care patients with coronary heart disease and CKD. American Journal of Kidney Diseases. May. 2009;53(5):741-50. [pmid: 19216014].
92 Isaacsohn JL, Davidson MH, Hunninghake D, et al. Aggressive Lipid-Lowering Initiation Abates New Cardiac Events (ALLIANCE)-rationale and design of atorvastatin versus usual care in hypercholesterolemic patients with coronary artery disease. Am J Cardiol. Jul. 15. 2000;86(2):250-2. [pmid: 10913499].
93 Rahman M, Baimbridge C, Davis BR, et al. Progression of kidney disease in moderately hypercholesterolemic, hypertensive patients randomized to pravastatin versus usual care: a report from the Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT). American Journal of Kidney Diseases. Sep. 2008;52(3):412-24. [pmid: 18676075].
94 Chonchol M, Cook T, Kjekshus J, et al. Simvastatin for secondary prevention of all-cause mortality and major coronary events in patients with mild chronic renal insufficiency. American Journal of Kidney Diseases. Mar. 2007;49(3):373-82. [pmid: 17336698].
95 Huskey J, Lindenfeld J, Cook T, et al. Effect of simvastatin on kidney function loss in patients with coronary heart disease: findings from the Scandinavian Simvastatin Survival Study (4S). Atherosclerosis. Jul. 2009;205(1):202-6. [pmid: 19124121].
96 Kjekshus J, Apetrei E, Barrios V, et al. Rosuvastatin in older patients with systolic heart failure. New England Journal of Medicine. Nov. 29. 2007;357(22):2248-61. [pmid: 17984166].
97 Lemos PA, Serruys PW, de Feyter P, et al. Long-term fluvastatin reduces the hazardous effect of renal impairment on four-year atherosclerotic outcomes (a LIPS substudy). American Journal of Cardiology. Feb. 15. 2005;95(4):445-51. [pmid: 15695126].
98 Tonelli M, Isles C, Curhan GC, et al. Effect of pravastatin on cardiovascular events in people with chronic kidney disease. Circulation. Sep. 21. 2004;110(12):1557-63. [pmid: 15364796].
99 Tonelli M, Moye L, Sacks FM, et al. Pravastatin for secondary prevention of cardiovascular events in persons with mild chronic renal insufficiency. [Summary for patients in Ann Intern Med. 2003 Jan 21;138(2):I28; PMID:12529112]. Annals of Internal Medicine. Jan. 21. 2003;138(2):98-104. [pmid: 12529091].
100 Armitage J, Bowman L, Wallendszus K, et al. Intensive lowering of LDL cholesterol with 80 mg versus 20 mg simvastatin daily in 12,064 survivors of myocardial infarction: a double-blind randomised trial. Lancet. Nov. 13. 2010;376(9753):1658-69. [pmid: 21067805].
101 Shepherd J, Kastelein JJP, Bittner V, et al. Intensive lipid lowering with atorvastatin in patients with coronary heart disease and chronic kidney disease: the TNT (Treating to New Targets) study. Journal of the American College of Cardiology. Apr. 15. 2008;51(15):1448-54. [pmid: 18402899].
102 LaRosa JC, Grundy SM, Waters DD, et al. Intensive lipid lowering with atorvastatin in patients with stable coronary disease. N Engl J Med. Apr. 7. 2005;352(14):1425-35. [pmid: 15755765].
103 Waters DD, Guyton JR, Herrington DM, et al. Treating to New Targets (TNT) Study: does lowering low-density lipoprotein cholesterol levels below currently recommended guidelines yield incremental clinical benefit?. Am J Cardiol. Jan. 15. 2004;93(2):154-8. [pmid: 14715339].
104 Tonolo G, Velussi M, Brocco E, et al. Simvastatin maintains steady patterns of GFR and improves AER and expression of slit diaphragm proteins in type II diabetes. Kidney International. Jul. 2006;70(1):177-86. [pmid: 16710349].
105 Chan JC, So WY, Yeung CY, et al. Effects of structured versus usual care on renal endpoint in type 2 diabetes: the SURE study: a randomized multicenter translational study. Diabetes Care. Jun. 2009;32(6):977-82. [pmid: 19460913].
106 Joss N, Ferguson C, Brown C, et al. Intensified treatment of patients with type 2 diabetes mellitus and overt nephropathy. Qjm. Apr. 2004;97(4):219-27. [pmid: 15028852].
107 Gaede P, Vedel P, Larsen N, et al. Multifactorial intervention and cardiovascular disease in patients with type 2 diabetes. New England Journal of Medicine. Jan. 30. 2003;348(5):383-93. [pmid: 12556541].
108 Gaede P, Vedel P, Parving HH, et al. Intensified multifactorial intervention in patients with type 2 diabetes mellitus and microalbuminuria: the Steno type 2 randomised study. Lancet. Feb. 20. 1999;353(9153):617-22. [pmid: 10030326].
109 Harris LE, Luft FC, Rudy DW, et al. Effects of multidisciplinary case management in patients with chronic renal insufficiency. American Journal of Medicine. Dec. 1998;105(6):464-71. [pmid: 9870830].
110 Major outcomes in high-risk hypertensive patients randomized to angiotensin-converting enzyme inhibitor or calcium channel blocker vs diuretic: The Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT). JAMA. Dec. 18. 2002;288(23):2981-97. [pmid: 12479763].