# Excluded Studies

(Note that this set of references is different from those in the text, and the numbers are different.)

## CKD Screening (KQ1, KQ2)

1 Microalbuminuria in type I diabetic patients. Prevalence and clinical characteristics. Microalbuminuria Collaborative Study Group. Diabetes Care. 1992;15(4):495-501. Not a randomized trial. [pmid: 1499464].
2 The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial Research Group. New England Journal of Medicine. 1993;329(14):977-86. Not an intervention for screening for CKD. [pmid: 8366922].
3 The relationship of glycemic exposure (HbA1c) to the risk of development and progression of retinopathy in the diabetes control and complications trial. Diabetes. 1995;44(8):968-83. Not a randomized trial. [pmid: 7622004].
4 Effects of ramipril on cardiovascular and microvascular outcomes in people with diabetes mellitus: results of the HOPE study and MICRO-HOPE substudy. Heart Outcomes Prevention Evaluation Study Investigators. Lancet. 2000;355(9200):253-9. Not an intervention for screening for CKD. [pmid: 10675071].
5 Abetimus: Abetimus sodium, LJP 394. Biodrugs. 2003;17(3):212-5. Less than 1000 patients in study. [pmid: 12749759].
6 Accetta NA, Gladstone EH, DiSogra C, et al. Prevalence of estimated GFR reporting among US clinical laboratories. American Journal of Kidney Diseases. 2008;52(4):778-87. Not a randomized trial. [pmid: 18676076].
7 Adler AI, Stevens RJ, Manley SE, et al. Development and progression of nephropathy in type 2 diabetes: the United Kingdom Prospective Diabetes Study (UKPDS 64). Kidney International. 2003;63(1):225-32. Not an intervention for screening for CKD. [pmid: 12472787].
8 Agarwal A, Silver MR, Walczyk M, et al. Once-monthly darbepoetin alfa for maintaining hemoglobin levels in older patients with chronic kidney disease. Journal of the American Medical Directors Association. 2007;8(2):83-90. Not a randomized trial. [pmid: 17289537].
9 Agodoa LY, Francis ME, Eggers PW. Association of analgesic use with prevalence of albuminuria and reduced GFR in US adults. American Journal of Kidney Diseases. 2008;51(4):573-83. Not a randomized trial. [pmid: 18371533].
10 Agrawal A, Sautter MC, Jones NP. Effects of rosiglitazone maleate when added to a sulfonylurea regimen in patients with type 2 diabetes mellitus and mild to moderate renal impairment: a post hoc analysis. Clinical Therapeutics. 2003;25(11):2754-64. Duration of follow-up less than 1 year. [pmid: 14693302].
11 Ahmedani MY, Hydrie MZI, Iqbal A, et al. Prevalence of microalbuminuria in type 2 diabetic patients in Karachi: Pakistan: a multi-center study. [Erratum appears in J Pak Med Assoc. 2005 Nov;55(11):523].[Erratum appears in J Pak Med Assoc. 2005 Dec;55(12):570]. JPMA - Journal of the Pakistan Medical Association. 2005;55(9):382-6. Not a randomized trial.
12 Ahn CW, Song YD, Kim JH, et al. The validity of random urine specimen albumin measurement as a screening test for diabetic nephropathy. Yonsei Medical Journal. 1999;40(1):40-5. Less than 1000 patients in study. [pmid: 10198605].
13 Akanji AO, Mainasara AS, Akinlade KS. Urinary iodine excretion in mothers and their breast-fed children in relation to other childhood nutritional parameters. European Journal of Clinical Nutrition. 1996;50(3):187-91. Not an intervention for screening for CKD. [pmid: 8654333].
14 Al-Maskari F, El-Sadig M, Obineche E. Prevalence and determinants of microalbuminuria among diabetic patients in the United Arab Emirates. BMC Nephrology. 2008;9:1. Not a randomized trial. [pmid: 18230135].
15 Alsuwaida A, Abdulkareem A, Alwakeel J. The Gulf Survey on Anemia Management (GSAM 2005). Saudi Journal of Kidney Diseases & Transplantation. 2007;18(2):206-14. Patients already diagnosed with CKD. [pmid: 17496396].
16 Amato D, Alvarez-Aguilar C, Castaneda-Limones R, et al. Prevalence of chronic kidney disease in an urban Mexican population. Kidney International - Supplement. 2005;(97):S11-7. Not a randomized trial. [pmid: 16014087].
17 Andrassy J, Zeier M, Andrassy K. Do we need screening for thrombophilia prior to kidney transplantation?. Nephrology Dialysis Transplantation. Suppl 4. 2004;19:iv64-8. Not a randomized trial.
18 Atkins RC, Briganti EM, Zimmet PZ, et al. Association between albuminuria and proteinuria in the general population: the AusDiab Study. Nephrology Dialysis Transplantation. 2003;18(10):2170-4. Not a randomized trial.
19 Atthobari J, Asselbergs FW, Boersma C, et al. Cost-effectiveness of screening for albuminuria with subsequent fosinopril treatment to prevent cardiovascular events: A pharmacoeconomic analysis linked to the prevention of renal and vascular endstage disease (PREVEND) study and the prevention of renal and vascular endstage disease intervention trial (PREVEND IT). Clinical Therapeutics. 2006;28(3):432-44. Not an intervention for screening for CKD. [pmid: 16750458].
20 Atthobari J, Brantsma AH, Gansevoort RT, et al. The effect of statins on urinary albumin excretion and glomerular filtration rate: results from both a randomized clinical trial and an observational cohort study. Nephrology Dialysis Transplantation. 2006;21(11):3106-14. Less than 1000 patients in study.
21 Atthobari J, Gansevoort RT, Visser ST, et al. The effect of screening for cardio-renal risk factors on drug use in the general population. British Journal of Clinical Pharmacology. 2007;64(6):810-8. Not an intervention for screening for CKD. [pmid: 18078475].
22 Awai K, Imuta M, Utsunomiya D, et al. Contrast enhancement for whole-body screening using multidetector row helical CT: comparison between uniphasic and biphasic injection protocols. Radiation Medicine. 2004;22(5):303-9. Less than 1000 patients in study. [pmid: 15553010].
23 Azizi M, Menard J, Peyrard S, et al. Assessment of patients' and physicians' compliance to an ACE inhibitor treatment based on urinary N-acetyl Ser-Asp-Lys-Pro determination in the Noninsulin-Dependent Diabetes, Hypertension, Microalbuminuria, Proteinuria, Cardiovascular Events, and Ramipril (DIABHYCAR) study. Diabetes Care. 2006;29(6):1331-6. Not a randomized trial. [pmid: 16732017].
24 Bakris G. Inclusion of albuminuria in hypertension and heart guidelines. Kidney International - Supplement. 2004;((92)):S124-5. Not a randomized trial. [pmid: 15485406].
25 Bakris G, Hester A, Weber M, et al. The diabetes subgroup baseline characteristics of the Avoiding Cardiovascular Events Through Combination Therapy in Patients Living With Systolic Hypertension (ACCOMPLISH) trial. J Cardiometab Syndr. 2008;3(4):229-33. Not an intervention for screening for CKD. [pmid: 19040592].
26 Bakris GL, Fonseca V, Katholi RE, et al. Differential effects of beta-blockers on albuminuria in patients with type 2 diabetes. Hypertension. 2005;46(6):1309-15. Not an intervention for screening for CKD. [pmid: 16286578].
27 Bang H, Mazumdar M, Newman G, et al. Screening for kidney disease in vascular patients: SCreening for Occult REnal Disease (SCORED) experience. Nephrology Dialysis Transplantation. 2009;24(8):2452-7. Not a randomized trial.
28 Barbanel CS, Winkelman JW, Fischer GA, et al. Confirmation of the Department of Transportation criteria for a substituted urine specimen. Journal of Occupational & Environmental Medicine. 2002;44(5):407-16. Not a randomized trial. [pmid: 12024686].
29 Barrett BJ, Katzberg RW, Thomsen HS, et al. Contrast-induced nephropathy in patients with chronic kidney disease undergoing computed tomography: a double-blind comparison of iodixanol and iopamidol. [Erratum appears in Invest Radiol. 2007 Feb;42(2):94 Note: Ni, Zhao-hui [added]]. Investigative Radiology. 2006;41(11):815-21. Patients already diagnosed with CKD. [pmid: 17035872].
30 Baskar V, Kamalakannan D, Holland MR, et al. Uncertain clinical utility of contemporary strategies for microalbuminuria testing. Diabetes, Obesity & Metabolism. 2003;5(4):262-6. Not a randomized trial.
31 Baxter GM, Aitchison F, Sheppard D, et al. Colour Doppler ultrasound in renal artery stenosis: intrarenal waveform analysis. British Journal of Radiology. 1996;69(825):810-5. Not a randomized trial. [pmid: 8983584].
32 Beatovic S, Jaksic ED, Han RS. Measurement of renal function by calculation of fractional uptake of technetium-99m dimercaptosuccinic acid. Nucl Med Rev Cent East Eur. 2004;7(1):49-52. Not an intervention for screening for CKD. [pmid: 15318311].
33 Beatty OL, Ritchie CM, Hadden DR, et al. Is a random urinary albumin concentration a useful screening test in insulin-treated diabetic patients?. Irish Journal of Medical Science. 1994;163(9):406-9. Not a randomized trial. [pmid: 7982765].
34 Beaulieu AJ, Gohh RY, Han H, et al. Enhanced reduction of fasting total homocysteine levels with supraphysiological versus standard multivitamin dose folic acid supplementation in renal transplant recipients. Arteriosclerosis, Thrombosis & Vascular Biology. 1999;19(12):2918-21. Patients already diagnosed with CKD.
35 Beevers DG, Lip GY. Does non-malignant essential hypertension cause renal damage? A clinician's view. Journal of Human Hypertension. 1996;10(10):695-9. Not a randomized trial. [pmid: 9004097].
36 Bellizzi V, Scalfi L, Terracciano V, et al. Early changes in bioelectrical estimates of body composition in chronic kidney disease. Journal of the American Society of Nephrology. 2006;17(5):1481-7. Not a randomized trial. [pmid: 16611719].
37 Beresford TP, Blow FC, Hill E, et al. Comparison of CAGE questionnaire and computer-assisted laboratory profiles in screening for covert alcoholism. Lancet. 1990;336(8713):482-5. Not an intervention for screening for CKD. [pmid: 1974998].
38 Berland LL, Koslin DB, Routh WD, et al. Renal artery stenosis: prospective evaluation of diagnosis with color duplex US compared with angiography. Work in progress. Radiology. 1990;174(2):421-3. Not a randomized trial. [pmid: 2404314].
39 Berthoux P, Dejean C, Cecillon S, et al. High prevalence of hepatitis G virus (HGV) infection in renal transplantation. Nephrology Dialysis Transplantation. 1998;13(11):2909-13. Not a randomized trial.
40 Beto JA, Bansal VK, Hart J, et al. Hemodialysis prognostic nutrition index as a predictor for morbidity and mortality in hemodialysis patients and its correlation to adequacy of dialysis. Council on Renal Nutrition National Research Question Collaborative Study Group. Journal of Renal Nutrition. 1999;9(1):2-8. Patients already diagnosed with CKD. [pmid: 9861095].
41 Bobrie G, Clerson P, Menard J, et al. Masked hypertension: a systematic review. Journal of Hypertension. 2008;26(9):1715-25. Not a randomized trial. [pmid: 18698202].
42 Boero R, Prodi E, Elia F, et al. How well are hypertension and albuminuria treated in type II diabetic patients?. Journal of Human Hypertension. 2003;17(6):413-8. Less than 1000 patients in study. [pmid: 12764404].
43 Bosmans JL, De Broe ME. Renovascular hypertension: diagnostic and therapeutic challenges. Jbr-Btr: Organe de la Societe Royale Belge de Radiologie. 2004;87(1):32-5. Not a randomized trial.
44 Bostom AG, Carpenter MA, Kusek JW, et al. Rationale and design of the Folic Acid for Vascular Outcome Reduction In Transplantation (FAVORIT) trial. American Heart Journal. 2006;152(3):448.e1-7. Patients already diagnosed with CKD. [pmid: 16923411].
45 Bostom AG, Shemin D, Gohh RY, et al. Treatment of hyperhomocysteinemia in hemodialysis patients and renal transplant recipients. Kidney International - Supplement. 2001;78:S246-52. Patients already diagnosed with CKD. [pmid: 11169020].
46 Boucher BA, Coffey BC, Kuhl DA, et al. Algorithm for assessing renal dysfunction risk in critically ill trauma patients receiving aminoglycosides. American Journal of Surgery. 1990;160(5):473-80. Not a randomized trial. [pmid: 2240380].
47 Bouhanick B, Berrut G, Chameau AM, et al. Predictive value of testing random urine sample to detect microalbuminuria in diabetic subjects during outpatient visit. Diabete et Metabolisme. 1992;18(1):54-8. Less than 1000 patients in study. [pmid: 1563538].
48 Budde K, L Schmouder R, Nashan B, et al. Pharmacodynamics of single doses of the novel immunosuppressant FTY720 in stable renal transplant patients. American Journal of Transplantation. 2003;3(7):846-54. Patients already diagnosed with CKD. [pmid: 12814476].
49 Budde RJ, Ke S, Levin VA. Activity of pp60c-src in 60 different cell lines derived from human tumors. Cancer Biochemistry Biophysics. 1994;14(3):171-5. Not an intervention for screening for CKD. [pmid: 7537173].
50 Budney AJ, Hughes JR, Moore BA, et al. Marijuana abstinence effects in marijuana smokers maintained in their home environment. Archives of General Psychiatry. 2001;58(10):917-24. Not a randomized trial. [pmid: 11576029].
51 Buhimschi CS, Norwitz ER, Funai E, et al. Urinary angiogenic factors cluster hypertensive disorders and identify women with severe preeclampsia. American Journal of Obstetrics & Gynecology. 2005;192(3):734-41. Not a randomized trial. [pmid: 15746665].
52 Burrowes JD, Larive B, Chertow GM, et al. Self-reported appetite, hospitalization and death in haemodialysis patients: findings from the Hemodialysis (HEMO) Study. Nephrology Dialysis Transplantation. 2005;20(12):2765-74. Patients already diagnosed with CKD.
53 Buturovic-Ponikvar J. Renal transplant artery stenosis. Nephrology Dialysis Transplantation. Suppl 5. 2003;18:v74-7. Not a randomized trial.
54 Buxbaum J, Tagoe C, Gallo G, et al. The pathogenesis of transthyretin tissue deposition: lessons from transgenic mice. Amyloid. Suppl 1. 2003;10:2-6. Not a randomized trial. [pmid: 14640034].
55 Canani LH, Costa LA, Crispim D, et al. The presence of allele D of angiotensin-converting enzyme polymorphism is associated with diabetic nephropathy in patients with less than 10 years duration of Type 2 diabetes. Diabetic Medicine. 2005;22(9):1167-72. Not a randomized trial. [pmid: 16108844].
56 Cao C, Wan X, Chen Y, et al. Metabolic factors and microinflammatory state promote kidney injury in type 2 diabetes mellitus patients. Renal Failure. 2009;31(6):470-4. Not a randomized trial. [pmid: 19839824].
57 Cardiel MH, Tumlin JA, Furie RA, et al. Abetimus sodium for renal flare in systemic lupus erythematosus: results of a randomized, controlled phase III trial. Arthritis & Rheumatism. 2008;58(8):2470-80. Not an intervention for screening for CKD. [pmid: 18668592].
58 Carter JL, O'Riordan SE, Eaglestone GL, et al. Chronic kidney disease prevalence in a UK residential care home population. Nephrology Dialysis Transplantation. 2008;23(4):1257-64. Not a randomized trial.
59 Cathelineau G, de Champvallins M, Bouallouche A, et al. Management of newly diagnosed non-insulin-dependent diabetes mellitus in the primary care setting: effects of 2 years of gliclazide treatment--the Diadem Study. Metabolism: Clinical & Experimental. 1997;46(12 Suppl 1):31-4. Not a randomized trial. [pmid: 9439556].
60 Chadban SJ, Briganti EM, Kerr PG, et al. Prevalence of kidney damage in Australian adults: The AusDiab kidney study. Journal of the American Society of Nephrology. 2003;14(7 Suppl 2):S131-8. Not a randomized trial. [pmid: 12819318].
61 Champion MC, Bending JJ, Rodger NW, et al. Conference on insulin pump therapy in diabetes. Multicenter study of effect on microvascular disease. Recruitment, Randomization, and baseline characteristics of the treatment groups. Diabetes. Suppl 3. 1985;34:13-6. Less than 1000 patients in study. [pmid: 3926567].
62 Chan JC, So WY, Yeung CY, et al. Effects of structured versus usual care on renal endpoint in type 2 diabetes: the SURE study: a randomized multicenter translational study. Diabetes Care. 2009;32(6):977-82. Not an intervention for screening for CKD. [pmid: 19460913].
63 Chan YL, Leung CB, Yu SC, et al. Comparison of non-breath-hold high resolution gadolinium-enhanced MRA with digital subtraction angiography in the evaluation on allograft renal artery stenosis. Clinical Radiology. 2001;56(2):127-32. Patients already diagnosed with CKD. [pmid: 11222071].
64 Charytan DM, Wallentin L, Lagerqvist B, et al. Early angiography in patients with chronic kidney disease: a collaborative systematic review. Clinical Journal of The American Society of Nephrology: CJASN. 2009;4(6):1032-43. Not an intervention for screening for CKD. [pmid: 19423566].
65 Chen N, Wang W, Huang Y, et al. Community-based study on CKD subjects and the associated risk factors. Nephrology Dialysis Transplantation. 2009;24(7):2117-23. Not a randomized trial.
66 Chen YC, Chiu WT, Wu MS. Therapeutic effect of topical gamma-linolenic acid on refractory uremic pruritus. American Journal of Kidney Diseases. 2006;48(1):69-76. Patients already diagnosed with CKD. [pmid: 16797388].
67 Chen Zh, Wang Gh, Wang Xp, et al. Effects of warm-supplementing kidney yang (WSKY) capsule added on risperidone on cognition in chronic schizophrenic patients: a randomized, double-blind, placebo-controlled, multi-center clinical trial. Human Psychopharmacology. 2008;23(6):465-70. Not an intervention for screening for CKD. [pmid: 18536066].
68 Cho ME, Kopp JB. HIV and the kidney: a status report after 20 years. Current HIV/AIDS Reports. 2004;1(3):109-15. Not a randomized trial. [pmid: 16091230].
69 Chow FY, Briganti EM, Kerr PG, et al. Health-related quality of life in Australian adults with renal insufficiency: a population-based study. American Journal of Kidney Diseases. 2003;41(3):596-604. Not a randomized trial. [pmid: 12612983].
70 Chow J, Bennett L. Pre-training assessment tool (JPAT)--a pilot study. Edtna-Erca Journal. 2001;27(1):37-41. Not a randomized trial.
71 Christianson TJ, Bryant SC, Weymiller AJ, et al. A pen-and-paper coronary risk estimator for office use with patients with type 2 diabetes. Mayo Clin Proc. 2006;81(5):632-6. Not a randomized trial. [pmid: 16706261].
72 Chumlea WC, Dwyer J, Bergen C, et al. Nutritional status assessed from anthropometric measures in the HEMO study. Journal of Renal Nutrition. 2003;13(1):31-8. Patients already diagnosed with CKD. [pmid: 12563621].
73 Cohen A, Basch C. Steady state pharmacokinetics of naproxen in young and elderly healthy volunteers. Seminars in Arthritis & Rheumatism. 1988;17(3 Suppl 2):7-11. Not an intervention for screening for CKD. [pmid: 3508329].
74 Cohen SD, Norris L, Acquaviva K, et al. Screening, diagnosis, and treatment of depression in patients with end-stage renal disease. Clinical Journal of The American Society of Nephrology: CJASN. 2007;2(6):1332-42. Patients already diagnosed with CKD. [pmid: 17942763].
75 Col M, Ocaktan E, Ozdemir O, et al. Microalbuminuria: prevalence in hypertensives and diabetics. Acta Medica Austriaca. 2004;31(1):23-9. Not a randomized trial. [pmid: 15259594].
76 Cole LA, Rinne KM, Mahajan SM, et al. Urinary screening tests for fetal Down syndrome: I. Fresh beta-core fragment. Prenatal Diagnosis. 1999;19(4):340-50. Not an intervention for screening for CKD. [pmid: 10327140].
77 Collins AC, Vincent J, Newall RG, et al. An aid to the early detection and management of diabetic nephropathy: assessment of a new point of care microalbuminuria system in the diabetic clinic. Diabetic Medicine. 2001;18(11):928-32. Less than 1000 patients in study. [pmid: 11703439].
78 Constantiner M, Sehgal AR, Humbert L, et al. A dipstick protein and specific gravity algorithm accurately predicts pathological proteinuria. American Journal of Kidney Diseases. 2005;45(5):833-41. Not a randomized trial. [pmid: 15861348].
79 Cook JD, Hannon MW Sr., Vo T, et al. Evaluation of freezing point depression osmolality for classifying random urine specimens defined as substituted under HHS/DOT criteria. Journal of Analytical Toxicology. 2002;26(7):424-9. Less than 1000 patients in study. [pmid: 12422996].
80 Cortes-Sanabria L, Cabrera-Pivaral CE, Cueto-Manzano AM, et al. Improving care of patients with diabetes and CKD: a pilot study for a cluster-randomized trial. American Journal of Kidney Diseases. 2008;51(5):777-88. Not an intervention for screening for CKD. [pmid: 18436088].
81 Craig JC, Barratt A, Cumming R, et al. Feasibility study of the early detection and treatment of renal disease by mass screening. Internal Medicine Journal. 2002;32(1-2):6-14. Not an intervention for screening for CKD. [pmid: 11783681].
82 Craig KJ, Donovan K, Munnery M, et al. Identification and management of diabetic nephropathy in the diabetes clinic. Diabetes Care. 2003;26(6):1806-11. Not a randomized trial. [pmid: 12766114].
83 Cueto-Manzano AM, Cortes-Sanabria L, Martinez-Ramirez HR, et al. Detection of early nephropathy in Mexican patients with type 2 diabetes mellitus. Kidney International - Supplement. 2005;(97):S40-5. Not a randomized trial. [pmid: 16014099].
84 Cukor D, Coplan J, Brown C, et al. Anxiety disorders in adults treated by hemodialysis: a single-center study. American Journal of Kidney Diseases. 2008;52(1):128-36. Patients already diagnosed with CKD. [pmid: 18440682].
85 Curtis JJ, Barbeito R, Pirsch J, et al. Differences in bioavailability between oral cyclosporine formulations in maintenance renal transplant patients. American Journal of Kidney Diseases. 1999;34(5):869-74. Patients already diagnosed with CKD. [pmid: 10561143].
86 Cusick M, Meleth AD, Agron E, et al. Associations of mortality and diabetes complications in patients with type 1 and type 2 diabetes: early treatment diabetic retinopathy study report no. 27. Diabetes Care. 2005;28(3):617-25. Not a randomized trial. [pmid: 15735198].
87 Davidson MB, Wong A, Hamrahian AH, et al. Effect of spironolactone therapy on albuminuria in patients with type 2 diabetes treated with angiotensin-converting enzyme inhibitors. Endocrine Practice. 2008;14(8):985-92. Less than 1000 patients in study. [pmid: 19095597].
88 Davis TM, Beilby J, Davis WA, et al. Prevalence, characteristics, and prognostic significance of HFE gene mutations in type 2 diabetes: the Fremantle Diabetes Study. Diabetes Care. 2008;31(9):1795-801. Not a randomized trial. [pmid: 18566337].
89 De Cosmo S, Motterlini N, Prudente S, et al. Impact of the PPAR-gamma2 Pro12Ala polymorphism and ACE inhibitor therapy on new-onset microalbuminuria in type 2 diabetes: evidence from BENEDICT. Diabetes. 2009;58(12):2920-9. Not a randomized trial. [pmid: 19720797].
90 de Silva R, Nikitin NP, Bhandari S, et al. Atherosclerotic renovascular disease in chronic heart failure: should we intervene?. European Heart Journal. 2005;26(16):1596-605. Not a randomized trial. [pmid: 15919719].
91 de Zeeuw D, Parving HH, Henning RH. Microalbuminuria as an early marker for cardiovascular disease. Journal of the American Society of Nephrology. 2006;17(8):2100-5. Not a randomized trial. [pmid: 16825327].
92 Debatin JF, Spritzer CE, Grist TM, et al. Imaging of the renal arteries: value of MR angiography. AJR. American Journal of Roentgenology. 1991;157(5):981-90. Less than 1000 patients in study. [pmid: 1927823].
93 Deepa M, Pradeepa R, Rema M, et al. The Chennai Urban Rural Epidemiology Study (CURES)--study design and methodology (urban component) (CURES-I). J Assoc Physicians India. 2003;51:863-70. Not a randomized trial. [pmid: 14710970].
94 D'Elia JA, Weinrauch LA, Gleason RE, et al. Preliminary screening of the relationship of serum lipids to survival of chronic dialysis patients. Renal Failure. 1993;15(2):203-9. Patients already diagnosed with CKD. [pmid: 8469788].
95 Dennen P, Douglas IS, Anderson R. Acute kidney injury in the intensive care unit: an update and primer for the intensivist. Critical Care Medicine. 38(1):261-75. Not a randomized trial. [pmid: 19829099].
96 Desberg AL, Paushter DM, Lammert GK, et al. Renal artery stenosis: evaluation with color Doppler flow imaging. Radiology. 1990;177(3):749-53. Less than 1000 patients in study. [pmid: 2243982].
97 Diaz VA, Mainous AG 3rd, Carek PJ, et al. The association of vitamin D deficiency and insufficiency with diabetic nephropathy: implications for health disparities. J Am Board Fam Med. 2009;22(5):521-7. Not a randomized trial. [pmid: 19734398].
98 Dieker JW, Sun YJ, Jacobs CW, et al. Mimotopes for lupus-derived anti-DNA and nucleosome-specific autoantibodies selected from random peptide phage display libraries: facts and follies. Journal of Immunological Methods. 2005;296(1-2):83-93. Not a randomized trial. [pmid: 15680153].
99 Doig JK, MacFadyen RJ, Sweet CS, et al. Haemodynamic and renal responses to oral losartan potassium during salt depletion or salt repletion in normal human volunteers. Journal of Cardiovascular Pharmacology. 1995;25(4):511-7. Not an intervention for screening for CKD. [pmid: 7596116].
100 Dunn PJ, Jury DR. Random urine albumin:creatinine ratio measurements as a screening test for diabetic microalbuminuria--a five year follow up. New Zealand Medical Journal. 1990;103(902):562-4. Not a randomized trial. [pmid: 2243654].
101 Ejerblad E, Fored CM, Lindblad P, et al. Obesity and risk for chronic renal failure. Journal of the American Society of Nephrology. 2006;17(6):1695-702. Not a randomized trial. [pmid: 16641153].
102 Eleftheriadis T, Tsiaga P, Antoniadi G, et al. The value of serum antilipoarabinomannan antibody detection in the diagnosis of latent tuberculosis in hemodialysis patients. American Journal of Kidney Diseases. 2005;46(4):706-12. Patients already diagnosed with CKD. [pmid: 16183426].
103 Elkohen M, Beregi JP, Deklunder G, et al. A prospective study of helical computed tomography angiography versus angiography for the detection of renal artery stenoses in hypertensive patients. Journal of Hypertension. 1996;14(4):525-8. Less than 1000 patients in study. [pmid: 8761904].
104 Emamian SA, Nielsen MB, Pedersen JF. Can dipstick screening for hematuria identify individuals with structural renal abnormalities? A sonographic evaluation. Scandinavian Journal of Urology & Nephrology. 1996;30(1):25-7. Not a randomized trial. [pmid: 8727861].
105 Ensom MHH, Chong G, Zhou D, et al. Estradiol in premenstrual asthma: a double-blind, randomized, placebo-controlled, crossover study. Pharmacotherapy. 2003;23(5):561-71. Not an intervention for screening for CKD. [pmid: 12741429].
106 Escobedo J, Rana JS, Lombardero MS, et al. Association between albuminuria and duration of diabetes and myocardial dysfunction and peripheral arterial disease among patients with stable coronary artery disease in the BARI 2D study. Mayo Clin Proc. 2010;85(1):41-6. Not a randomized trial. [pmid: 20042560].
107 Etard JF, Borel E. Epidemiological survey of urinary schistosomiasis in southeastern Mauritania. Tropical Medicine & Parasitology. 1987;38(1):27-30. Not an intervention for screening for CKD. [pmid: 3110930].
108 Ethier J, Mendelssohn DC, Elder SJ, et al. Vascular access use and outcomes: an international perspective from the Dialysis Outcomes and Practice Patterns Study. Nephrology Dialysis Transplantation. 2008;23(10):3219-26. Not a randomized trial.
109 Ewald B, Attia J. Which test to detect microalbuminuria in diabetic patients? A systematic review. Australian Family Physician. 2004;33(7):565-7. Not a randomized trial. [pmid: 15301181].
110 Fabian J, Katz I, Gerntholtz T, et al. Chronic kidney disease in human immunodeficiency virus infection. Panminerva Medica. 2007;49(2):51-66. Not a randomized trial. [pmid: 17625482].
111 Fagnani F, Souchet T, Labed D, et al. Management of hypertension and screening of renal complications by GPs in diabetic type 2 patients (France--2001). Diabetes & Metabolism. 2003;29(1):58-64. Not a randomized trial. [pmid: 12629449].
112 Fava S, Azzopardi J, Hattersley AT, et al. Increased prevalence of proteinuria in diabetic sibs of proteinuric type 2 diabetic subjects. American Journal of Kidney Diseases. 2000;35(4):708-12. Less than 1000 patients in study. [pmid: 10739793].
113 Fellstrom B, Holdaas H, Jardine AG, et al. Effect of rosuvastatin on outcomes in chronic haemodialysis patients: baseline data from the AURORA study. Kidney & Blood Pressure Research. 2007;30(5):314-22. Patients already diagnosed with CKD. [pmid: 17671394].
114 Ferris M, Shoham DA, Pierre-Louis M, et al. High prevalence of unlabeled chronic kidney disease among inpatients at a tertiary-care hospital. American Journal of the Medical Sciences. 2009;337(2):93-7. Not a randomized trial. [pmid: 19214023].
115 Fischbacher CM, Bhopal R, Rutter MK, et al. Microalbuminuria is more frequent in South Asian than in European origin populations: a comparative study in Newcastle, UK. Diabetic Medicine. 2003;20(1):31-6. Not a randomized trial. [pmid: 12519317].
116 Fishbane S, Shapiro WB, Corry DB, et al. Cinacalcet HCl and concurrent low-dose vitamin D improves treatment of secondary hyperparathyroidism in dialysis patients compared with vitamin D alone: the ACHIEVE study results. Clinical Journal of The American Society of Nephrology: CJASN. 2008;3(6):1718-25. Patients already diagnosed with CKD. [pmid: 18945995].
117 Flack JM, Grimm RH Jr., Staffileno BA, et al. New salt-sensitivity metrics: variability-adjusted blood pressure change and the urinary sodium-to-creatinine ratio. Ethnicity & Disease. 2002;12(1):10-9. Less than 1000 patients in study. [pmid: 11913598].
118 Fored CM, Nise G, Ejerblad E, et al. Absence of association between organic solvent exposure and risk of chronic renal failure: a nationwide population-based case-control study. Journal of the American Society of Nephrology. 2004;15(1):180-6. Not a randomized trial. [pmid: 14694171].
119 Frankenfield DL, Rocco MV, Roman SH, et al. Survival advantage for adult Hispanic hemodialysis patients? Findings from the end-stage renal disease clinical performance measures project. Journal of the American Society of Nephrology. 2003;14(1):180-6. Patients already diagnosed with CKD. [pmid: 12506150].
120 Freedman BI, Hicks PJ, Sale MM, et al. A leucine repeat in the carnosinase gene CNDP1 is associated with diabetic end-stage renal disease in European Americans. Nephrology Dialysis Transplantation. 2007;22(4):1131-5. Not a randomized trial.
121 Freeman RB, Paya C, Pescovitz MD, et al. Risk factors for cytomegalovirus viremia and disease developing after prophylaxis in high-risk solid-organ transplant recipients. Transplantation. 2004;78(12):1765-73. Not an intervention for screening for CKD. [pmid: 15614149].
122 Freemont AJ, Hoyland JA, Denton J, et al. The effects of lanthanum carbonate and calcium carbonate on bone abnormalities in patients with end-stage renal disease. Clinical Nephrology. 2005;64(6):428-37. Patients already diagnosed with CKD. [pmid: 16370155].
123 Fujii H, Nakamura S, Kuroda S, et al. Relationship between renal artery stenosis and intrarenal damage in autopsy subjects with stroke. Nephrology Dialysis Transplantation. 2006;21(1):113-9. Not a randomized trial.
124 Galassi A, Brancaccio D, Cozzolino M, et al. Awareness of hypertension and proteinuria in randomly selected patients in 11 Italian cities. A 2005 report of the National Kidney Foundation of Italy. Journal of Clinical Hypertension. 2009;11(3):138-43. Not a randomized trial. [pmid: 19302425].
125 Gallant JE, Winston JA, DeJesus E, et al. The 3-year renal safety of a tenofovir disoproxil fumarate vs. a thymidine analogue-containing regimen in antiretroviral-naive patients. AIDS. 2008;22(16):2155-63. Not an intervention for screening for CKD. [pmid: 18832879].
126 Gansevoort RT, Verhave JC, Hillege HL, et al. The validity of screening based on spot morning urine samples to detect subjects with microalbuminuria in the general population. Kidney International - Supplement. 2005;(94):S28-35. Not a randomized trial. [pmid: 15752236].
127 Garcia-Tsao G, Lim JK, Members of Veterans Affairs Hepatitis CRCP. Management and treatment of patients with cirrhosis and portal hypertension: recommendations from the Department of Veterans Affairs Hepatitis C Resource Center Program and the National Hepatitis C Program. American Journal of Gastroenterology. 2009;104(7):1802-29. Not a randomized trial. [pmid: 19455106].
128 Garg AX, Kiberd BA, Clark WF, et al. Albuminuria and renal insufficiency prevalence guides population screening: results from the NHANES III. Kidney International. 2002;61(6):2165-75. Not a randomized trial. [pmid: 12028457].
129 Gatling W, Knight C, Hill RD. Screening for early diabetic nephropathy: which sample to detect microalbuminuria?. Diabetic Medicine. 1985;2(6):451-5. Not a randomized trial. [pmid: 2951116].
130 Gatling W, Knight C, Mullee MA, et al. Microalbuminuria in diabetes: a population study of the prevalence and an assessment of three screening tests. Diabetic Medicine. 1988;5(4):343-7. Not a randomized trial. [pmid: 2968883].
131 Gazis A, Page SR. Microalbuminuria screening in the UK: are we meeting European standards?. Diabetic Medicine. 1996;13(8):764-7. Not a randomized trial. [pmid: 8862954].
132 George S, Braithwaite RA. An investigation into the extent of possible dilution of specimens received for urinary drugs of abuse screening. Addiction. 1995;90(7):967-70. Not a randomized trial. [pmid: 7663318].
133 Gerber LM, Johnston K, Alderman MH. Assessment of a new dipstick test in screening for microalbuminuria in patients with hypertension. American Journal of Hypertension. 1998;11(11 Pt 1):1321-7. Not a randomized trial. [pmid: 9832175].
134 Ghahramani N, Shadrou S, Hollenbeak C. A systematic review of continuous renal replacement therapy and intermittent haemodialysis in management of patients with acute renal failure. Nephrology. 2008;13(7):570-8. Patients already diagnosed with CKD. [pmid: 18518933].
135 Ghandour H, Bagley PJ, Shemin D, et al. Distribution of plasma folate forms in hemodialysis patients receiving high daily doses of L-folinic or folic acid. Kidney International. 2002;62(6):2246-9. Patients already diagnosed with CKD. [pmid: 12427152].
136 Giordano M, Tirelli P, Ciarambino T, et al. Screening of depressive symptoms in young-old hemodialysis patients: relationship between Beck Depression Inventory and 15-item Geriatric Depression Scale. Nephron. 2007;106(4):c187-92. Patients already diagnosed with CKD. [pmid: 17596728].
137 Giugliani R, Ferrari I, Greene LJ. An evaluation of four methods for the detection of heterozygous cystinuria. Clinica Chimica Acta. 1987;164(2):227-33. Not a randomized trial.
138 Go RC, Desmond R, Roseman JM, et al. Prevalence and risk factors of microalbuminuria in a cohort of African-American women with gestational diabetes. Diabetes Care. 2001;24(10):1764-9. Not a randomized trial. [pmid: 11574439].
139 Gok MA, Shenton BK, Buckley PE, et al. How to improve the quality of kidneys from non-heart-beating donors: a randomised controlled trial of thrombolysis in non-heart-beating donors. Transplantation. 2003;76(12):1714-9. Not an intervention for screening for CKD. [pmid: 14688521].
140 Golan L, Birkmeyer JD, Welch HG. The cost-effectiveness of treating all patients with type 2 diabetes with angiotensin-converting enzyme inhibitors. Annals of Internal Medicine. 1999;131(9):660-7. Not an intervention for screening for CKD. [pmid: 10577328].
141 Goldsmith DJ, Covic A. Coronary artery disease in uremia: Etiology, diagnosis, and therapy. Kidney International. 2001;60(6):2059-78. Not a randomized trial. [pmid: 11737581].
142 Goldsmith DJ, Reidy J, Scoble J. Renal arterial intervention and angiotensin blockade in atherosclerotic nephropathy. American Journal of Kidney Diseases. 2000;36(4):837-43. Not a randomized trial. [pmid: 11007688].
143 Groetzner J, Wittwer T, Kaczmarek I, et al. Conversion to sirolimus and mycophenolate can attenuate the progression of bronchiolitis obliterans syndrome and improves renal function after lung transplantation. Transplantation. 2006;81(3):355-60. Not a randomized trial. [pmid: 16477220].
144 Gross JL, Zelmanovitz T, Oliveira J, et al. Screening for diabetic nephropathy: is measurement of urinary albumin-to-creatinine ratio worthwhile?. Diabetes Care. 1999;22(9):1599-600. Less than 1000 patients in study. [pmid: 10480542].
145 Group B. The BErgamo NEphrologic DIabetes Complications Trial (BENEDICT): design and baseline characteristics. Controlled Clinical Trials. 2003;24(4):442-61. Not an intervention for screening for CKD. [pmid: 12865039].
146 Gupta R, Birnbaum Y, Uretsky BF. The renal patient with coronary artery disease: current concepts and dilemmas. Journal of the American College of Cardiology. 2004;44(7):1343-53. Not a randomized trial. [pmid: 15464310].
147 Hall AM, Edwards SG, Lapsley M, et al. Subclinical tubular injury in HIV-infected individuals on antiretroviral therapy: a cross-sectional analysis. American Journal of Kidney Diseases. 2009;54(6):1034-42. Not a randomized trial. [pmid: 19783343].
148 Hallan H, Romundstad S, Kvenild K, et al. Microalbuminuria in diabetic and hypertensive patients and the general population--consequences of various diagnostic criteria--the Nord-Trondelag Health Study (HUNT). Scandinavian Journal of Urology & Nephrology. 2003;37(2):151-8. Not a randomized trial. [pmid: 12745725].
149 Hallett M, Burden S, Stewart D, et al. Sleep apnea in end-stage renal disease patients on hemodialysis and continuous ambulatory peritoneal dialysis. ASAIO Journal. 1995;41(3):M435-41. Patients already diagnosed with CKD. [pmid: 8573841].
150 Hara N, Koike H, Ogino S, et al. Application of serum PSA to identify acute bacterial prostatitis in patients with fever of unknown origin or symptoms of acute pyelonephritis. Prostate. 2004;60(4):282-8. Not a randomized trial. [pmid: 15264238].
151 Harding GKM, Zhanel GG, Nicolle LE, et al. Antimicrobial treatment in diabetic women with asymptomatic bacteriuria. New England Journal of Medicine. 2002;347(20):1576-83. Not an intervention for screening for CKD. [pmid: 12432044].
152 Haug K, Bakke A, Daae LN, et al. Screening for hematuria, glucosuria and proteinuria in people aged 55-64. Technical, clinical and cost-benefit experience from a pilot study. Scandinavian Journal of Primary Health Care. 1985;3(1):31-4. Not a randomized trial. [pmid: 3933072].
153 Herget-Rosenthal S, Marggraf G, Husing J, et al. Early detection of acute renal failure by serum cystatin C. Kidney International. 2004;66(3):1115-22. Not an intervention for screening for CKD. [pmid: 15327406].
154 Hindmarsh JT. Microalbuminuria. Clinics in Laboratory Medicine. 1988;8(3):611-6. Not a randomized trial. [pmid: 3048860].
155 Hor T, Baldwin D. Urinary albumin excretion in patients with diabetes after renal transplantation. Transplantation Proceedings. 2006;38(9):2879-82. Not a randomized trial. [pmid: 17112854].
156 Howey JE, Browning MC, Fraser CG. Biologic variation of urinary albumin: consequences for analysis, specimen collection, interpretation of results, and screening programs. American Journal of Kidney Diseases. 1989;13(1):35-7. Not a randomized trial. [pmid: 2912063].
157 Hoy WE, Wang Z, Baker PRA, et al. Reduction in natural death and renal failure from a systematic screening and treatment program in an Australian Aboriginal community. Kidney International - Supplement. 2003;(83):S66-73. Not a randomized trial. [pmid: 12864878].
158 Huestis MA, Cone EJ. Differentiating new marijuana use from residual drug excretion in occasional marijuana users. Journal of Analytical Toxicology. 1998;22(6):445-54. Not an intervention for screening for CKD. [pmid: 9788519].
159 Hyndman ME, Manns BJ, Snyder FF, et al. Vitamin B12 decreases, but does not normalize, homocysteine and methylmalonic acid in end-stage renal disease: a link with glycine metabolism and possible explanation of hyperhomocysteinemia in end-stage renal disease. Metabolism: Clinical & Experimental. 2003;52(2):168-72. Patients already diagnosed with CKD. [pmid: 12601627].
160 Incerti J, Zelmanovitz T, Camargo JL, et al. Evaluation of tests for microalbuminuria screening in patients with diabetes. Nephrology Dialysis Transplantation. 2005;20(11):2402-7. Not a randomized trial.
161 Investigators RRTT, Bellomo R, Cass A, et al. Screening and study enrolment in the Randomized Evaluation of Normal vs. Augmented Level (RENAL) Replacement Therapy Trial. Blood Purification. 2009;27(2):199-205. Not an intervention for screening for CKD. [pmid: 19256108].
162 Iso H, Shimamoto T, Yokota K, et al. Community-based education classes for hypertension control. A 1.5-year randomized controlled trial. Hypertension. 1996;27(4):968-74. Not an intervention for screening for CKD. [pmid: 8613276].
163 Izzedine H, Hulot JS, Vittecoq D, et al. Long-term renal safety of tenofovir disoproxil fumarate in antiretroviral-naive HIV-1-infected patients. Data from a double-blind randomized active-controlled multicentre study. Nephrology Dialysis Transplantation. 2005;20(4):743-6. Not an intervention for screening for CKD.
164 Jafar TH, Qadri Z, Hashmi S. Prevalence of microalbuminuria and associated electrocardiographic abnormalities in an Indo-Asian population. Nephrology Dialysis Transplantation. 2009;24(7):2111-6. Not a randomized trial.
165 James MA, Fotherby MD, Potter JF. Screening tests for microalbuminuria in non-diabetic elderly subjects and their relation to blood pressure. Clinical Science. 1995;88(2):185-90. Not a randomized trial. [pmid: 7720343].
166 Jansen JJ, Maassen JA, van der Woude FJ, et al. Mutation in mitochondrial tRNA(Leu(UUR)) gene associated with progressive kidney disease. Journal of the American Society of Nephrology. 1997;8(7):1118-24. Not a randomized trial. [pmid: 9219161].
167 Johnson CA, McCarthy J, Bailie GR, et al. Analysis of renal bone disease treatment in dialysis patients. American Journal of Kidney Diseases. 2002;39(6):1270-7. Not a randomized trial. [pmid: 12046041].
168 Johnson RK, Mortimer AJ. Routine pre-operative blood testing: is it necessary?. Anaesthesia. 2002;57(9):914-7. Not an intervention for screening for CKD. [pmid: 12190758].
169 Juarez FJ, Barrios Y, Cano L, et al. A randomized trial comparing two corticosteroid regimens combined with mycophenolate mofetil and cyclosporine for prevention of acute renal allograft rejection. Transplantation Proceedings. 2006;38(9):2866-8. Patients already diagnosed with CKD. [pmid: 17112851].
170 Judge JS, Low V, Gajraj H, et al. The value of technetium-99M renography for the detection of renal artery stenosis in patients with aortic and lower limb vascular disease. Australian & New Zealand Journal of Surgery. 1992;62(4):261-5. Not a randomized trial. [pmid: 1550514].
171 Jurkovitz C, Franch H, Shoham D, et al. Family members of patients treated for ESRD have high rates of undetected kidney disease. American Journal of Kidney Diseases. 2002;40(6):1173-8. Not a randomized trial. [pmid: 12460035].
172 Justesen TI, Petersen JLA, Ekbom P, et al. Albumin-to-creatinine ratio in random urine samples might replace 24-h urine collections in screening for micro- and macroalbuminuria in pregnant woman with type 1 diabetes. Diabetes Care. 2006;29(4):924-5. Not a randomized trial. [pmid: 16567839].
173 Kale K, Sawant S. Clinical significance and evaluation of proteinuria in NIDDM patients. Indian Journal of Medical Sciences. 1999;53(3):103-7. Not a randomized trial. [pmid: 10798009].
174 Kapila K, Nampoory MRN, Johny KV, et al. Role of urinary cytology in detecting human polyoma bk virus in kidney transplant recipients. A preliminary report. Medical Principles & Practice. 2007;16(3):237-9. Not a randomized trial. [pmid: 17409762].
175 Karaminia R, Tavallaii SA, Lorgard-Dezfuli-Nejad M, et al. Anxiety and depression: a comparison between renal transplant recipients and hemodialysis patients. Transplantation Proceedings. 2007;39(4):1082-4. Patients already diagnosed with CKD. [pmid: 17524897].
176 Kelley DE, Bidot P, Freedman Z, et al. Efficacy and safety of acarbose in insulin-treated patients with type 2 diabetes. Diabetes Care. 1998;21(12):2056-61. Not an intervention for screening for CKD. [pmid: 9839094].
177 Kimmel PL, Cukor D, Cohen SD, et al. Depression in end-stage renal disease patients: a critical review. Advances in Chronic Kidney Disease. 2007;14(4):328-34. Not a randomized trial. [pmid: 17904499].
178 King CH, Wiper DW 3rd, De Stigter KV, et al. Dose-finding study for praziquantel therapy of Schistosoma haematobium in Coast Province, Kenya. American Journal of Tropical Medicine & Hygiene. 1989;40(5):507-13. Not an intervention for screening for CKD. [pmid: 2499203].
179 Kliewer MA, Tupler RH, Carroll BA, et al. Renal artery stenosis: analysis of Doppler waveform parameters and tardus-parvus pattern. Radiology. 1993;189(3):779-87. Not a randomized trial. [pmid: 8234704].
180 Kocvara R, Plasgura P, Petrik A, et al. A prospective study of nonmedical prophylaxis after a first kidney stone. BJU International. 1999;84(4):393-8. Not an intervention for screening for CKD. [pmid: 10468751].
181 Kouidi EJ, Grekas DM, Deligiannis AP. Effects of exercise training on noninvasive cardiac measures in patients undergoing long-term hemodialysis: a randomized controlled trial. American Journal of Kidney Diseases. 2009;54(3):511-21. Patients already diagnosed with CKD. [pmid: 19646801].
182 Kovarik JM, Hartmann S, Figueiredo J, et al. Effect of food on everolimus absorption: quantification in healthy subjects and a confirmatory screening in patients with renal transplants. Pharmacotherapy. 2002;22(2):154-9. Not an intervention for screening for CKD. [pmid: 11837553].
183 Kovarik JM, Moore R, Wolf P, et al. Screening for basiliximab exposure-response relationships in renal allotransplantation. Clinical Transplantation. 1999;13(1 Pt 1):32-8. Patients already diagnosed with CKD. [pmid: 10081632].
184 Kristal B, Shasha SM, Labin L, et al. Estimation of quantitative proteinuria by using the protein-creatinine ratio in random urine samples. American Journal of Nephrology. 1988;8(3):198-203. Not a randomized trial. [pmid: 3239593].
185 Krol E, Rutkowski B, Czarniak P, et al. Early detection of chronic kidney disease: results of the PolNef study. American Journal of Nephrology. 2009;29(3):264-73. Not a randomized trial. [pmid: 18812692].
186 Kyle PM, Campbell S, Buckley D, et al. A comparison of the inactive urinary kallikrein:creatinine ratio and the angiotensin sensitivity test for the prediction of pre-eclampsia. British Journal of Obstetrics & Gynaecology. 1996;103(10):981-7. Not an intervention for screening for CKD. [pmid: 8863695].
187 Lafolie P, Beck O, Blennow G, et al. Importance of creatinine analyses of urine when screening for abused drugs. Clinical Chemistry. 1991;37(11):1927-31. Not an intervention for screening for CKD. [pmid: 1934467].
188 Lauritzen T, Christiansen JS, Brock A, et al. Repeated screening for albumin-creatinine ratio in an unselected population. The Ebeltoft Health Promotion Study, a randomized, population-based intervention trial on health test and health conversations with general practitioners. Journal of Diabetes & its Complications. 1994;8(3):146-9. Not an intervention for screening for CKD. [pmid: 8086649].
189 Laville M, Anaemia CiDt. New strategies in anaemia management: ACORD (Anaemia CORrection in Diabetes) trial. Acta Diabetologica. Suppl 1. 2004;41:S18-22. Not an intervention for screening for CKD. [pmid: 15103544].
190 Lawrie AS, McDonald SJ, Purdy G, et al. Prothrombin time derived fibrinogen determination on Sysmex CA-6000. Journal of Clinical Pathology. 1998;51(6):462-6. Not an intervention for screening for CKD. [pmid: 9771446].
191 Leanos-Miranda A, Marquez-Acosta J, Romero-Arauz F, et al. Protein:creatinine ratio in random urine samples is a reliable marker of increased 24-hour protein excretion in hospitalized women with hypertensive disorders of pregnancy. Clinical Chemistry. 2007;53(9):1623-8. Not a randomized trial. [pmid: 17660273].
192 Leedman PJ, Nankervis A, Goodwin M, et al. Assessment of the Albuscreen microalbuminuria kit in diabetic outpatients. Medical Journal of Australia. 1987;147(6):285-6. Not a randomized trial. [pmid: 3626944].
193 Lehmann R, Borovicka J, Kunz P, et al. Evaluation of delayed gastric emptying in diabetic patients with autonomic neuropathy by a new magnetic resonance imaging technique and radio-opaque markers. Diabetes Care. 1996;19(10):1075-82. Not an intervention for screening for CKD. [pmid: 8886552].
194 Leong SO, Lui KF, Ng WY, et al. The use of semi-quantitative urine test-strip (Micral Test) for microalbuminuria screening in patients with diabetes mellitus. Singapore Medical Journal. 1998;39(3):101-3. Not a randomized trial. [pmid: 9632966].
195 Lewis EJ, Hunsicker LG, Rodby RA, et al. A clinical trial in type 2 diabetic nephropathy. American Journal of Kidney Diseases. 2001;38(4 Suppl 1):S191-4. Patients already diagnosed with CKD. [pmid: 11576953].
196 Lewis WH, Yeger H, Bonetta L, et al. Homozygous deletion of a DNA marker from chromosome 11p13 in sporadic Wilms tumor. Genomics. 1988;3(1):25-31. Not a randomized trial. [pmid: 2851538].
197 Lou HX, Vathsala A. Conversion from mycophenolate mofetil to azathioprine in high-risk renal allograft recipients on cyclosporine-based immunosuppression. Transplantation Proceedings. 2004;36(7):2090-1. Patients already diagnosed with CKD. [pmid: 15518756].
198 Lu B, Song X, Dong X, et al. High prevalence of chronic kidney disease in population-based patients diagnosed with type 2 diabetes in downtown Shanghai. Journal of Diabetes & its Complications. 2008;22(2):96-103. Not a randomized trial. [pmid: 18280439].
199 Lucas P, Blome S, Roche J. Intra-renal Doppler wave-form analysis as a screening test for renal artery stenosis. Australasian Radiology. 1996;40(3):276-82. Not an intervention for screening for CKD. [pmid: 8826735].
200 Lum G. How effective are screening tests for microalbuminuria in random urine specimens?. Annals of Clinical & Laboratory Science. 2000;30(4):406-11. Not a randomized trial. [pmid: 11045765].
201 Macdougall IC, Matcham J, Gray SJ, et al. Correction of anaemia with darbepoetin alfa in patients with chronic kidney disease receiving dialysis. Nephrology Dialysis Transplantation. 2003;18(3):576-81. Patients already diagnosed with CKD.
202 Malaguarnera M, Ferlito L, Gulizia G, et al. Use of interleukin-2 in advanced renal carcinoma: meta-analysis and review of the literature. European Journal of Clinical Pharmacology. 2001;57(4):267-73. Not an intervention for screening for CKD. [pmid: 11549203].
203 Malik J, Slavikova M, Svobodova J, et al. Regular ultrasonographic screening significantly prolongs patency of PTFE grafts. Kidney International. 2005;67(4):1554-8. Not an intervention for screening for CKD. [pmid: 15780111].
204 Malleson PN, Lockitch G, Mackinnon M, et al. Renal disease in chronic arthritis of childhood. A study of urinary N-acetyl-beta-glucosaminidase and beta 2-microglobulin excretion. Arthritis & Rheumatism. 1990;33(10):1560-6. Not adult population. [pmid: 2222536].
205 Marcus J, Sarnak MJ, Menon V. Homocysteine lowering and cardiovascular disease risk: lost in translation. Canadian Journal of Cardiology. 2007;23(9):707-10. Not a randomized trial. [pmid: 17622392].
206 Marshall SM. Screening for microalbuminuria: which measurement?. Diabetic Medicine. 1991;8(8):706-11. Not a randomized trial. [pmid: 1838060].
207 Matinlauri IH, Kyllonen LEJ, Eklund BH, et al. Weak humoral posttransplant alloresponse after a well-HLA-matched cadaveric kidney transplantation. Transplantation. 2004;78(2):198-204. Patients already diagnosed with CKD. [pmid: 15280678].
208 McClellan WM, Ramirez SPB, Jurkovitz C. Screening for chronic kidney disease: unresolved issues. Journal of the American Society of Nephrology. 2003;14(7 Suppl 2):S81-7. Not a randomized trial. [pmid: 12819308].
209 McCullough PA, Li S, Jurkovitz CT, et al. CKD and cardiovascular disease in screened high-risk volunteer and general populations: the Kidney Early Evaluation Program (KEEP) and National Health and Nutrition Examination Survey (NHANES) 1999-2004. American Journal of Kidney Diseases. 2008;51(4 Suppl 2):S38-45. Not a randomized trial. [pmid: 18359407].
210 McInnes GT, Semple PF. Hypertension: investigation, assessment and diagnosis. British Medical Bulletin. 1994;50(2):443-59. Not a randomized trial. [pmid: 8205468].
211 McParland P, Pearce JM, Chamberlain GV. Doppler ultrasound and aspirin in recognition and prevention of pregnancy-induced hypertension. Lancet. 1990;335(8705):1552-5. Not an intervention for screening for CKD. [pmid: 1972487].
212 Moore RR Jr., Hirata-Dulas CA, Kasiske BL. Use of urine specific gravity to improve screening for albuminuria. Kidney International. 1997;52(1):240-3. Not a randomized trial. [pmid: 9211369].
213 Morgenstern BZ, Butani L, Wollan P, et al. Validity of protein-osmolality versus protein-creatinine ratios in the estimation of quantitative proteinuria from random samples of urine in children. American Journal of Kidney Diseases. 2003;41(4):760-6. Not adult population. [pmid: 12666062].
214 Mori S, Satoh T, Koide H, et al. Inhibition of Ras/Raf interaction by anti-oncogenic mutants of neurofibromin, the neurofibromatosis type 1 (NF1) gene product, in cell-free systems. Journal of Biological Chemistry. 1995;270(48):28834-8. Not an intervention for screening for CKD. [pmid: 7499408].
215 Mori TA, Vandongen R, Masarei JR. Fish oil-induced changes in apolipoproteins in IDDM subjects. Diabetes Care. 1990;13(7):725-32. Not an intervention for screening for CKD. [pmid: 2201495].
216 Mudun A, Falay O, Eryilmaz A, et al. Can exercise renography be an alternative to ACE inhibitor renography in hypertensive patients who are suspicious for renal artery stenosis?. Clinical Nuclear Medicine. 2004;29(1):27-34. Not a randomized trial. [pmid: 14688594].
217 Nakao N, Yoshimura A, Morita H, et al. Combination treatment of angiotensin-II receptor blocker and angiotensin-converting-enzyme inhibitor in non-diabetic renal disease (COOPERATE): a randomised controlled trial. [Erratum appears in Lancet. 2003 Apr 5;361(9364):1230].[Retraction in Lancet. 2009 Oct 10;374(9697):1226; PMID: 19819378]. Lancet. 2003;361(9352):117-24. Less than 1000 patients in study. [pmid: 12531578].
218 Nankivell BJ, Chapman JR. The significance of subclinical rejection and the value of protocol biopsies. American Journal of Transplantation. 2006;6(9):2006-12. Patients already diagnosed with CKD. [pmid: 16796717].
219 Nathan DM, Zinman B, Cleary PA, et al. Modern-day clinical course of type 1 diabetes mellitus after 30 years' duration: the diabetes control and complications trial/epidemiology of diabetes interventions and complications and Pittsburgh epidemiology of diabetes complications experience (1983-2005). Arch Intern Med. 2009;169(14):1307-16. Not a randomized trial. [pmid: 19636033].
220 Newman DJ, Mattock MB, Dawnay ABS, et al. Systematic review on urine albumin testing for early detection of diabetic complications. Health Technology Assessment. 2005;9(30):iii-vi. xiii. 163. Not a randomized trial. [pmid: 16095545].
221 Ng LC, Teng LC, Ng ML, et al. Microalbuminuria measurements by two in-house ELISA methods. Malaysian Journal of Pathology. 2000;22(2):73-8. Not a randomized trial. [pmid: 16329538].
222 O'Connor PJ, Spann SJ, Woolf SH. Care of adults with type 2 diabetes mellitus. A review of the evidence. Journal of Family Practice. 1998;47(5 Suppl):S13-22. Not an intervention for screening for CKD. [pmid: 9834750].
223 Ogawa H, Xu FH, Uebaba K, et al. Antioxidative potentiality of a Kampo formulation measured by an ex vivo study. Journal of Alternative & Complementary Medicine. 2009;15(3):267-74. Not an intervention for screening for CKD.
224 Ohmit SE, Flack JM, Peters RM, et al. Longitudinal Study of the National Kidney Foundation's (NKF) Kidney Early Evaluation Program (KEEP). Journal of the American Society of Nephrology. 2003;14(7 Suppl 2):S117-21. Not a randomized trial. [pmid: 12819315].
225 Orakzai N, Hanbury DC, Farrington K. Screening for biochemical abnormalities in urolithiasis patients. Journal of Ayub Medical College, Abbottabad: JAMC. 2004;16(2):60-3. Not a randomized trial.
226 Palmer AJ, Valentine WJ, Chen R, et al. A health economic analysis of screening and optimal treatment of nephropathy in patients with type 2 diabetes and hypertension in the USA. Nephrology Dialysis Transplantation. 2008;23(4):1216-23. Not a randomized trial.
227 Paranjape SB, Thibonnier M. Development and therapeutic indications of orally-active non-peptide vasopressin receptor antagonists. Expert Opinion on Investigational Drugs. 2001;10(5):825-34. Not a randomized trial. [pmid: 11322860].
228 Parikh CR, Gyamlani GG, Carvounis CP. Screening for microalbuminuria simplified by urine specific gravity. American Journal of Nephrology. 2002;22(4):315-9. Less than 1000 patients in study. [pmid: 12169861].
229 Parving HH. Is antihypertensive treatment the same for NIDDM and IDDM patients?. Diabetes Research & Clinical Practice. 1998;39(Suppl):S43-7. Not a randomized trial. [pmid: 9649959].
230 Parving HH. Benefits and cost of antihypertensive treatment in incipient and overt diabetic nephropathy. Journal of Hypertension - Supplement. 1998;16(1):S99-101. Not a randomized trial.
231 Parving HH, Rossing P. The use of antihypertensive agents in prevention and treatment of diabetic nephropathy. Current Opinion in Nephrology & Hypertension. 1994;3(3):292-300. Not a randomized trial. [pmid: 7922255].
232 Pegoraro A, Singh A, Bakir AA, et al. Simplified screening for microalbuminuria. Annals of Internal Medicine. 1997;127(9):817-9. Not a randomized trial. [pmid: 9382403].
233 Perroud B, Lee J, Valkova N, et al. Pathway analysis of kidney cancer using proteomics and metabolic profiling. Molecular Cancer. 2006;5:64. Not an intervention for screening for CKD. [pmid: 17123452].
234 Persky AM, Ng C, Song MH, et al. Comparison of the acute pharmacodynamic responses after single doses of ephedrine or sibutramine in healthy, overweight volunteers. International Journal of Clinical Pharmacology & Therapeutics. 2004;42(8):442-8. Not an intervention for screening for CKD. [pmid: 15366324].
235 Petersson B, Kristenson H, Trell E, et al. Screening and intervention for alcohol-related disease in middle-aged men: the Malmo Preventive Programme. Ciba Foundation Symposium. 1985;110:143-63. Not an intervention for screening for CKD. [pmid: 2859153].
236 Pfab T, Franz U, Herfeld F, et al. Rapid immunochromatographic strip test for the detection of albuminuria and brief literature review on albuminuria screening. European Journal of Medical Research. 2006;11(1):3-6. Not a randomized trial. [pmid: 16504953].
237 Phillips RA, Faulkner M, Gassman J, et al. Recruitment of African Americans with chronic renal insufficiency into a multicenter clinical trial: the african american study of kidney disease and hypertension. Journal of Clinical Hypertension. 2004;6(8):430-6. Not an intervention for screening for CKD. [pmid: 15308881].
238 Plestina S, Stavljenic A, Ceovic S, et al. Haematological features of the population of the area of Croatia, Yugoslavia, endemic for Balkan nephropathy. IARC Scientific Publications. 1991;(115):43-6. Not a randomized trial. [pmid: 1820352].
239 Polkinghorne KR, Lau KKP, Saunder A, et al. Does monthly native arteriovenous fistula blood-flow surveillance detect significant stenosis--a randomized controlled trial. Nephrology Dialysis Transplantation. 2006;21(9):2498-506. Not an intervention for screening for CKD.
240 Postma CT, van Aalen J, de Boo T, et al. Doppler ultrasound scanning in the detection of renal artery stenosis in hypertensive patients. British Journal of Radiology. 1992;65(778):857-60. Not a randomized trial. [pmid: 1422658].
241 Prodjosudjadi W, Suhardjono, Suwitra K, et al. Detection and prevention of chronic kidney disease in Indonesia: initial community screening. Nephrology. 2009;14(7):669-74. Not a randomized trial. [pmid: 19796026].
242 Pugia MJ, Lott JA, Luke KE, et al. Comparison of instrument-read dipsticks for albumin and creatinine in urine with visual results and quantitative methods. Journal of Clinical Laboratory Analysis. 1998;12(5):280-4. Not a randomized trial. [pmid: 9773958].
243 Rabindranath KS, Butler JA, Macleod AM, et al. Physical measures for treating depression in dialysis patients. Cochrane Database of Systematic Reviews. 2005;(2):CD004541. Patients already diagnosed with CKD. [pmid: 15846720].
244 Ralston SH, Caine N, Richards I, et al. Screening for proteinuria in a rheumatology clinic: comparison of dipstick testing, 24 hour urine quantitative protein, and protein/creatinine ratio in random urine samples. Annals of the Rheumatic Diseases. 1988;47(9):759-63. Not an intervention for screening for CKD. [pmid: 3263087].
245 Ravikovich E, Messersmith T, Mick G, et al. Effect of oral fluid intake on urinary albumin excretion in diabetes mellitus. Journal of Diabetes & its Complications. 2002;16(4):310-2. Not a randomized trial. [pmid: 12126790].
246 Reach I, Luong N, Chastang C, et al. Dose effect relationship of reviparin in chronic hemodialysis: a crossover study versus nadroparin. Artificial Organs. 2001;25(7):591-5. Not an intervention for screening for CKD. [pmid: 11493282].
247 Reddy PP, Mandell J. Prenatal diagnosis. Therapeutic implications. Urologic Clinics of North America. 1998;25(2):171-80. Not adult population. [pmid: 9633572].
248 Reeves JH, Cumming AR, Gallagher L, et al. A controlled trial of low-molecular-weight heparin (dalteparin) versus unfractionated heparin as anticoagulant during continuous venovenous hemodialysis with filtration. Critical Care Medicine. 1999;27(10):2224-8. Not an intervention for screening for CKD. [pmid: 10548211].
249 Regeniter A, Haenni V, Risch L, et al. Urine analysis performed by flow cytometry: reference range determination and comparison to morphological findings, dipstick chemistry and bacterial culture results--a multicenter study. Clinical Nephrology. 2001;55(5):384-92. Not a randomized trial. [pmid: 11393384].
250 Reid A, Stohr W, Walker AS, et al. Severe renal dysfunction and risk factors associated with renal impairment in HIV-infected adults in Africa initiating antiretroviral therapy. Clinical Infectious Diseases. 2008;46(8):1271-81. Not a randomized trial. [pmid: 18444867].
251 Ricos C, Jimenez CV, Hernandez A, et al. Biological variation in urine samples used for analyte measurements. Clinical Chemistry. 1994;40(3):472-7. Not a randomized trial. [pmid: 7510594].
252 Roderick PJ, Atkins RJ, Smeeth L, et al. Detecting chronic kidney disease in older people; what are the implications?. [Erratum appears in Age Ageing. 2009 Sep;38(5):638 Note: Flectcher, Astrid E [corrected to Fletcher, Astrid E]]. Age & Ageing. 2008;37(2):179-86. Not a randomized trial. [pmid: 18083723].
253 Romundstad S, Holmen J, Kvenild K, et al. Clinical relevance of microalbuminuria screening in self-reported non-diabetic/non-hypertensive persons identified in a large health screening--the Nord-Trondelag Health Study (HUNT), Norway. Clinical Nephrology. 2003;59(4):241-51. Not a randomized trial. [pmid: 12708563].
254 Romundstad S, Holmen J, Kvenild K, et al. Microalbuminuria and all-cause mortality in 2,089 apparently healthy individuals: a 4.4-year follow-up study. The Nord-Trondelag Health Study (HUNT), Norway. American Journal of Kidney Diseases. 2003;42(3):466-73. Not a randomized trial. [pmid: 12955674].
255 Sandler DP, Burr FR, Weinberg CR. Nonsteroidal anti-inflammatory drugs and the risk for chronic renal disease. Annals of Internal Medicine. 1991;115(3):165-72. Not a randomized trial. [pmid: 2058870].
256 Saran AM, DuBose TD Jr. Cardiovascular disease in chronic kidney disease. Therapeutic Advances in Cardiovascular Disease. 2008;2(6):425-34. Not a randomized trial. [pmid: 19124439].
257 Saraux A, Fautrel B, Maillefert JF, et al. Laboratory and imaging studies used by French rheumatologists to evaluate patients with early arthritis. Journal of Rheumatology. 2006;33(5):897-902. Not an intervention for screening for CKD. [pmid: 16583465].
258 Saw J, Levin A, Gin K. Coronary artery disease in chronic kidney disease patients: assessing the evidence for diagnosis, screening and revascularization. Canadian Journal of Cardiology. 2004;20(8):807-13. Not a randomized trial. [pmid: 15229763].
259 Sawicki PT, Kaiser S, Heinemann L, et al. Prevalence of renal artery stenosis in diabetes mellitus--an autopsy study. Journal of Internal Medicine. 1991;229(6):489-92. Not a randomized trial. [pmid: 2045754].
260 Scheid DC, McCarthy LH, Lawler FH, et al. Screening for microalbuminuria to prevent nephropathy in patients with diabetes: a systematic review of the evidence. Journal of Family Practice. 2001;50(8):661-8. Not an intervention for screening for CKD. [pmid: 11509158].
261 Schreij G, van Es PN, Schiffers PM, et al. ‘Captopril test’, with blood pressure and peripheral renin as response variables in hypertensive patients with suspected renal artery stenosis. Journal of Human Hypertension. 1995;9(9):741-6. Not an intervention for screening for CKD. [pmid: 8551488].
262 Schumacher G, Hilscher W, Mollering H, et al. Engineering enzymes for clinical diagnosis. Annales de Biologie Clinique. 1993;51(9):815-9. Not an intervention for screening for CKD. [pmid: 8166396].
263 Schwab SJ, Dunn FL, Feinglos MN. Screening for microalbuminuria. A comparison of single sample methods of collection and techniques of albumin analysis. Diabetes Care. 1992;15(11):1581-4. Not a randomized trial. [pmid: 1468288].
264 Servois V, Laissy JP, Feger C, et al. Two-dimensional time-of-flight magnetic resonance angiography of renal arteries without maximum intensity projection: a prospective comparison with angiography in 21 patients screened for renovascular hypertension. Cardiovascular & Interventional Radiology. 1994;17(3):138-42. Not a randomized trial. [pmid: 8087829].
265 Shambesh MA, Craig PS, Macpherson CN, et al. An extensive ultrasound and serologic study to investigate the prevalence of human cystic echinococcosis in northern Libya. American Journal of Tropical Medicine & Hygiene. 1999;60(3):462-8. Not an intervention for screening for CKD. [pmid: 10466978].
266 Shionoiri H, Kosaka T, Kita E, et al. Comparison of long-term therapeutic effect of an ACE inhibitor, temocapril, with that of a diuretic on microalbuminuria in non-diabetic essential hypertension. Hypertension Research - Clinical & Experimental. 2000;23(6):593-600. Not an intervention for screening for CKD.
267 Siewert-Delle A. Long-term renal function in primary hypertension. An epidemiological and pathophysiological study. Scandinavian Journal of Urology & Nephrology Supplementum. 1999;199:1-36. Not a randomized trial. [pmid: 10349677].
268 Sikka R, Waters J, Moore W, et al. Renal assessment practices and the effect of nurse case management of health maintenance organization patients with diabetes. Diabetes Care. 1999;22(1):1-6. Less than 1000 patients in study. [pmid: 10333895].
269 Singh GR, White AV, Hoy WE. Renal ultrasound findings in an Australian Aboriginal population with high rates of renal disease. Nephrology. 2005;10(4):358-61. Not a randomized trial. [pmid: 16109082].
270 Singh NP, Ingle GK, Saini VK, et al. Prevalence of low glomerular filtration rate, proteinuria and associated risk factors in North India using Cockcroft-Gault and Modification of Diet in Renal Disease equation: an observational, cross-sectional study. BMC Nephrology. 2009;10:4. Not a randomized trial. [pmid: 19220921].
271 Skipper GE, Weinmann W, Thierauf A, et al. Ethyl glucuronide: a biomarker to identify alcohol use by health professionals recovering from substance use disorders. Alcohol & Alcoholism. 2004;39(5):445-9. Not an intervention for screening for CKD. [pmid: 15289206].
272 Smaill F. Antibiotics for asymptomatic bacteriuria in pregnancy. Cochrane Database of Systematic Reviews. 2001;(2):CD000490. Not an intervention for screening for CKD. [pmid: 11405965].
273 Smaill F, Vazquez JC. Antibiotics for asymptomatic bacteriuria in pregnancy. Cochrane Database of Systematic Reviews. 2007;(2):CD000490. Not an intervention for screening for CKD. [pmid: 17443502].
274 Smith ML, Barnes AJ, Huestis MA. Identifying new cannabis use with urine creatinine-normalized THCCOOH concentrations and time intervals between specimen collections. Journal of Analytical Toxicology. 2009;33(4):185-9. Not an intervention for screening for CKD. [pmid: 19470219].
275 Smith-Kielland A, Skuterud B, Olsen KM, et al. Urinary excretion of diazepam metabolites in healthy volunteers and drug users. Scandinavian Journal of Clinical & Laboratory Investigation. 2001;61(3):237-46. Not an intervention for screening for CKD. [pmid: 11386610].
276 Snyder S, Pendergraph B. Detection and evaluation of chronic kidney disease. American Family Physician. 2005;72(9):1723-32. Not a randomized trial. [pmid: 16300034].
277 Soonthornpun S, Leelawattana R, Thamprasit A, et al. Screening for microalbuminuria in type 2 diabetes: a reconsideration. Journal of the Medical Association of Thailand. 2002;85(5):604-11. Not a randomized trial. [pmid: 12188392].
278 Springhart WP, Marguet CG, Sur RL, et al. Forced versus minimal intravenous hydration in the management of acute renal colic: a randomized trial. Journal of Endourology. 2006;20(10):713-6. Not an intervention for screening for CKD. [pmid: 17094744].
279 Sumaili EK, Cohen EP, Zinga CV, et al. High prevalence of undiagnosed chronic kidney disease among at-risk population in Kinshasa, the Democratic Republic of Congo. BMC Nephrology. 2009;10:18. Not a randomized trial. [pmid: 19622160].
280 Suri RS, Clark WF, Barrowman N, et al. Diabetes during diarrhea-associated hemolytic uremic syndrome: a systematic review and meta-analysis. Diabetes Care. 2005;28(10):2556-62. Not an intervention for screening for CKD. [pmid: 16186301].
281 Takahashi H, Kinouchi M, Wuepper KD, et al. Cloning of human keratolinin cDNA: keratolinin is identical with a cysteine proteinase inhibitor, cystatin A, and is regulated by Ca2+, TPA, and cAMP. Journal of Investigative Dermatology. 1997;108(6):843-7. Not an intervention for screening for CKD. [pmid: 9182808].
282 Tapp RJ, Shaw JE, Harper CA, et al. The prevalence of and factors associated with diabetic retinopathy in the Australian population. Diabetes Care. 2003;26(6):1731-7. Not a randomized trial. [pmid: 12766102].
283 Thomsen HS, Morcos SK, Erley CM, et al. The ACTIVE Trial: comparison of the effects on renal function of iomeprol-400 and iodixanol-320 in patients with chronic kidney disease undergoing abdominal computed tomography. Investigative Radiology. 2008;43(3):170-8. Not an intervention for screening for CKD. [pmid: 18301313].
284 Thomsen HS, Sos TA, Nielsen SL. Renovascular hypertension. Diagnosis and intervention. Acta Radiologica. 1989;30(2):113-20. Not a randomized trial. [pmid: 2522309].
285 Torng S, Rigatto C, Rush DN, et al. The urine protein to creatinine ratio (P/C) as a predictor of 24-hour urine protein excretion in renal transplant patients. Transplantation. 2001;72(8):1453-6. Not a randomized trial. [pmid: 11685120].
286 Toussaint ND, Lau KK, Strauss BJ, et al. Determination and validation of aortic calcification measurement from lateral bone densitometry in dialysis patients. Clinical Journal of The American Society of Nephrology: CJASN. 2009;4(1):119-27. Patients already diagnosed with CKD. [pmid: 18945998].
287 Toyoda N, Nagai S, Terashima Y, et al. Analysis of mRNA with microsomal fractionation using a SAGE-based DNA microarray system facilitates identification of the genes encoding secretory proteins. Genome Research. 2003;13(7):1728-36. Not an intervention for screening for CKD. [pmid: 12805275].
288 Tsai SY, Tseng HF, Tan HF, et al. End-stage renal disease in Taiwan: a case-control study. Journal of Epidemiology. 2009;19(4):169-76. Not a randomized trial. [pmid: 19542686].
289 Tumlin JA, Finkel KW, Murray PT, et al. Fenoldopam mesylate in early acute tubular necrosis: a randomized, double-blind, placebo-controlled clinical trial. American Journal of Kidney Diseases. 2005;46(1):26-34. Not an intervention for screening for CKD. [pmid: 15983954].
290 Tutone VK, Mark PB, Revanur V, et al. Random blood glucose measurements and survival in nondiabetic renal transplant recipients. Transplantation Proceedings. 2004;36(10):3006-11. Patients already diagnosed with CKD. [pmid: 15686682].
291 van Kooten F, Ciabattoni G, Koudstaal PJ, et al. Increased thromboxane biosynthesis is associated with poststroke dementia. Stroke. 1999;30(8):1542-7. Not an intervention for screening for CKD. [pmid: 10436098].
292 Vegter S, Perna A, Hiddema W, et al. Cost-effectiveness of ACE inhibitor therapy to prevent dialysis in nondiabetic nephropathy: influence of the ACE insertion/deletion polymorphism. Pharmacogenetics & Genomics. 2009;19(9):695-703. Not a randomized trial. [pmid: 19696696].
293 Velazquez Lopez L, Sil Acosta MJ, Goycochea Robles MV, et al. Effect of protein restriction diet on renal function and metabolic control in patients with type 2 diabetes: a randomized clinical trial. Nutricion Hospitalaria. 2008;23(2):141-7. Not an intervention for screening for CKD. [pmid: 18449450].
294 Viberti G, Kahn SE, Greene DA, et al. A diabetes outcome progression trial (ADOPT): an international multicenter study of the comparative efficacy of rosiglitazone, glyburide, and metformin in recently diagnosed type 2 diabetes. Diabetes Care. 2002;25(10):1737-43. Not an intervention for screening for CKD. [pmid: 12351470].
295 Wachtell K, Olsen MH, Dahlof B, et al. Microalbuminuria in hypertensive patients with electrocardiographic left ventricular hypertrophy: the LIFE study. Journal of Hypertension. 2002;20(3):405-12. Not a randomized trial. [pmid: 11875307].
296 Wanner C, Horl WH, Luley CH, et al. Effects of HMG-CoA reductase inhibitors in hypercholesterolemic patients on hemodialysis. Kidney International. 1991;39(4):754-60. Patients already diagnosed with CKD. [pmid: 2051734].
297 Warrington SJ, Ravic M, Dawnay A. Renal and general tolerability of repeated doses of nimesulide in normal subjects. Drugs. Suppl 1. 1993;46:263-9. Not an intervention for screening for CKD. [pmid: 7506187].
298 Waterman AD, Browne T, Waterman BM, et al. Attitudes and behaviors of African Americans regarding early detection of kidney disease. American Journal of Kidney Diseases. 2008;51(4):554-62. Not a randomized trial. [pmid: 18371531].
299 Watson WJ. Screening for glycosuria during pregnancy. Southern Medical Journal. 1990;83(2):156-8. Not a randomized trial. [pmid: 2305295].
300 Watts GF, Hodgson B, Morris RW, et al. Side-room tests to screen for microalbuminuria in diabetes mellitus. Diabetic Medicine. 1988;5(3):298-303. Not a randomized trial. [pmid: 2967156].
301 Webb DJ, Newman DJ, Chaturvedi N, et al. The use of the Micral-Test strip to identify the presence of microalbuminuria in people with insulin dependent diabetes mellitus (IDDM) participating in the EUCLID study. Diabetes Research & Clinical Practice. 1996;31(1-3):93-102. Not a randomized trial. [pmid: 8792107].
302 Weger M, Deutschmann H, Weger W, et al. Incomplete renal tubular acidosis in ‘primary’ osteoporosis. Osteoporosis International. 1999;10(4):325-9. Not a randomized trial. [pmid: 10692983].
303 Whelton PK, Lee JY, Kusek JW, et al. Recruitment experience in the African American Study of Kidney Disease and Hypertension (AASK) Pilot Study. Controlled Clinical Trials. 1996;17(4 Suppl):17S-33S. Not an intervention for screening for CKD. [pmid: 8889351].
304 Wilde HM, Banks D, Larsen CL, et al. Evaluation of the Bayer microalbumin/creatinine urinalysis dipstick. Clinica Chimica Acta. 2008;393(2):110-3. Not a randomized trial.
305 Williams BT, Ketchum CH, Robinson CA, et al. Screening for slight albuminuria: a comparison of selected commercially available methods. Southern Medical Journal. 1990;83(12):1447-9. Not a randomized trial. [pmid: 2251534].
306 Wilson RA, Norman DJ, Barry JM, et al. Noninvasive cardiac testing in the end-stage renal disease patient. Blood Purification. 1994;12(1):78-83. Not an intervention for screening for CKD. [pmid: 7986481].
307 Wingo CS, Clapp WL. Proteinuria: potential causes and approach to evaluation. American Journal of the Medical Sciences. 2000;320(3):188-94. Not a randomized trial. [pmid: 11014373].
308 Witting M, Kuo D. Screening with blood urea nitrogen before intravenous contrast. American Journal of Emergency Medicine. 2003;21(6):494-6. Not a randomized trial. [pmid: 14574660].
309 Womer KL, Huang Y, Herren H, et al. Dendritic cell deficiency associated with development of BK viremia and nephropathy in renal transplant recipients. Transplantation. 2010;89(1):115-23. Not an intervention for screening for CKD. [pmid: 20061927].
310 Woo J, Lau E, Swaminathan R, et al. Biochemical predictors for osteoporotic fractures in elderly Chinese--a longitudinal study. Gerontology. 1990;36(1):55-8. Not an intervention for screening for CKD. [pmid: 2384226].
311 Woolhandler S, Pels RJ, Bor DH, et al. Dipstick urinalysis screening of asymptomatic adults for urinary tract disorders. I. Hematuria and proteinuria. JAMA. 1989;262(9):1214-9. Not a randomized trial. [pmid: 2668582].
312 Wroe S. Zonisamide and renal calculi in patients with epilepsy: how big an issue?. Current Medical Research & Opinion. 2007;23(8):1765-73. Not a randomized trial. [pmid: 17594758].
313 Wu SY, Fisher DA, Huang WS, et al. Urinary compound W in pregnant women is a potential marker for fetal thyroid function. American Journal of Obstetrics & Gynecology. 1998;178(5):886-91. Not an intervention for screening for CKD. [pmid: 9609555].
314 Xin G, Wang M, Jiao Ll, et al. Protein-to-creatinine ratio in spot urine samples as a predictor of quantitation of proteinuria. Clinica Chimica Acta. 2004;350(1-2):35-9. Not a randomized trial.
315 Yanik B, Bavbek N, Yanik T, et al. The effect of alendronate, risedronate, and raloxifene on renal functions, based on the Cockcroft and Gault method, in postmenopausal women. Renal Failure. 2007;29(4):471-6. Not an intervention for screening for CKD. [pmid: 17497471].
316 Ylinenjarvi K, Widersten M, Bjork I. Hydrophobic sequences can substitute for the wild-type N-terminal sequence of cystatin A (stefin A) in tight binding to cysteine proteinases selection of high-affinity N-terminal region variants by phage display. European Journal of Biochemistry. 1999;261(3):682-8. Not an intervention for screening for CKD. [pmid: 10215884].
317 Yocum DE, Furst DE, Bensen WG, et al. Safety of tacrolimus in patients with rheumatoid arthritis: long-term experience. Rheumatology. 2004;43(8):992-9. Not an intervention for screening for CKD. [pmid: 15014199].
318 Zarif L, Covic A, Iyengar S, et al. Inaccuracy of clinical phenotyping parameters for hypertensive nephrosclerosis. Nephrology Dialysis Transplantation. 2000;15(11):1801-7. Not a randomized trial.
319 Zeller A, Sigle JP, Battegay E, et al. Value of a standard urinary dipstick test for detecting microalbuminuria in patients with newly diagnosed hypertension. Swiss Medical Weekly. 2005;135(3-4):57-61. Not a randomized trial. [pmid: 15729608].
320 Zelmanovitz T, Gross JL, Oliveira J, et al. Proteinuria is still useful for the screening and diagnosis of overt diabetic nephropathy. Diabetes Care. 1998;21(7):1076-9. Not a randomized trial. [pmid: 9653598].
321 Zelmanovitz T, Gross JL, Oliveira JR, et al. The receiver operating characteristics curve in the evaluation of a random urine specimen as a screening test for diabetic nephropathy. Diabetes Care. 1997;20(4):516-9. Not a randomized trial. [pmid: 9096972].
322 Zhang Q, Zhang Z, Xin D, et al. Suppression subtractive hybridization for identifying differentially expressed genes in renal cell carcinoma. Chinese Medical Journal. 2001;114(8):807-12. Not an intervention for screening for CKD. [pmid: 11780355].
323 Zhao H, Li X, Johnson DE, et al. Identification of protease and rpoN-associated genes of uropathogenic Proteus mirabilis by negative selection in a mouse model of ascending urinary tract infection. Microbiology. 1999;145(Pt 1):185-95. Not a randomized trial. [pmid: 10206698].
324 Ziegler D, Siekierka-Kleiser E, Meyer B, et al. Validation of a novel screening device (NeuroQuick) for quantitative assessment of small nerve fiber dysfunction as an early feature of diabetic polyneuropathy. Diabetes Care. 2005;28(5):1169-74. Not an intervention for screening for CKD. [pmid: 15855584].

## CKD Monitoring (KQ3, KQ4)

1 The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial Research Group. New England Journal of Medicine. 1993;329(14):977-86. Intervention not related to monitoring of CKD. [pmid: 8366922].
2 Intensive therapy and progression to clinical albuminuria in patients with insulin dependent diabetes mellitus and microalbuminuria Microalbuminuria Collaborative Study Group, United Kingdom. BMJ. 1995;311(7011):973-7. Intervention not related to monitoring of CKD. [pmid: 7580637].
3 Effect of intensive therapy on the development and progression of diabetic nephropathy in the Diabetes Control and Complications Trial. The Diabetes Control and Complications (DCCT) Research Group. Kidney International. 1995;47(6):1703-20. Intervention not related to monitoring of CKD. [pmid: 7643540].
4 The absence of a glycemic threshold for the development of long-term complications: the perspective of the Diabetes Control and Complications Trial. Diabetes. 1996;45(10):1289-98. Intervention not related to monitoring of CKD. [pmid: 8826962].
5 Captopril reduces the risk of nephropathy in IDDM patients with microalbuminuria. The Microalbuminuria Captopril Study Group. Diabetologia. 1996;39(5):587-93. Intervention not related to monitoring of CKD. [pmid: 8739919].
6 Randomised placebo-controlled trial of effect of ramipril on decline in glomerular filtration rate and risk of terminal renal failure in proteinuric, non-diabetic nephropathy. The GISEN Group (Gruppo Italiano di Studi Epidemiologici in Nefrologia). Lancet. 1997;349(9069):1857-63. Intervention not related to monitoring of CKD. [pmid: 9217756].
7 Parenteral cidofovir for cytomegalovirus retinitis in patients with AIDS: the HPMPC peripheral cytomegalovirus retinitis trial. A randomized, controlled trial. Studies of Ocular complications of AIDS Research Group in Collaboration with the AIDS Clinical Trials Group. Annals of Internal Medicine. 1997;126(4):264-74. Intervention not related to monitoring of CKD. [pmid: 9036798].
8 Effects of ramipril on cardiovascular and microvascular outcomes in people with diabetes mellitus: results of the HOPE study and MICRO-HOPE substudy. Heart Outcomes Prevention Evaluation Study Investigators. [Erratum appears in Lancet 2000 Sep 2;356(9232):860]. Lancet. 2000;355(9200):253-9. Intervention not related to monitoring of CKD. [pmid: 10675071].
9 Retinopathy and nephropathy in patients with type 1 diabetes four years after a trial of intensive therapy. The Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications Research Group. [Erratum appears in N Engl J Med 2000 May 4;342(18):1376]. New England Journal of Medicine. 2000;342(6):381-9. Intervention not related to monitoring of CKD. [pmid: 10666428].
10 Angiotensin II receptor antagonists and heart failure: angiotensin-converting-enzyme inhibitors remain the first-line option. Prescrire International. 2005;14(79):180-6. Intervention not related to monitoring of CKD. [pmid: 16285075].
11 Telmisartan did not prevent renal disease in patients without proteinuria. [Original report in Ann Intern Med. 2009 Jul 7;151(1):1-10, W1-2; PMID: 19451556]. Annals of Internal Medicine. 2009;151(1):I28. Intervention not related to monitoring of CKD. [pmid: 19451555].
12 Abe M, Okada K, Kikuchi F, et al. Clinical investigation of the effects of pioglitazone on the improvement of insulin resistance and blood pressure in type 2-diabetic patients undergoing hemodialysis. Clinical Nephrology. 2008;70(3):220-8. Less than 50 patients in study. [pmid: 18793563].
13 Abe M, Okada K, Maruyama T, et al. Comparison of the antiproteinuric effects of the calcium channel blockers benidipine and amlodipine administered in combination with angiotensin receptor blockers to hypertensive patients with stage 3-5 chronic kidney disease. Hypertension Research - Clinical & Experimental. 2009;32(4):270-5. Intervention not related to monitoring of CKD.
14 Abe M, Okada K, Maruyama T, et al. Antiproteinuric and blood pressure-lowering effects of a fixed-dose combination of losartan and hydrochlorothiazide in hypertensive patients with stage 3 chronic kidney disease. Pharmacotherapy. 2009;29(9):1061-72. Duration of follow-up less than 1 year. [pmid: 19698011].
15 Abouna GM, al-Abdullah IH, Kelly-Sullivan D, et al. Randomized clinical trial of antithymocyte globulin induction in renal transplantation comparing a fixed daily dose with dose adjustment according to T cell monitoring. Transplantation. 1995;59(11):1564-8. Not patients with early CKD. [pmid: 7778170].
16 Acone D, Cante D, Cillo F, et al. Blood pressure and progression of renal failure in the elderly. Kidney International - Supplement. 1996;55:S75-7. Less than 50 patients in study. [pmid: 8743516].
17 Adler AI, Stevens RJ, Manley SE, et al. Development and progression of nephropathy in type 2 diabetes: the United Kingdom Prospective Diabetes Study (UKPDS 64). Kidney International. 2003;63(1):225-32. Not a randomized trial. [pmid: 12472787].
18 Agarwal R. Reproducibility of renal function measurements in adult men with diabetic nephropathy: research and clinical implications. American Journal of Nephrology. 2007;27(1):92-100. Not a randomized trial. [pmid: 17284896].
19 Agarwal R. Vitamin D, proteinuria, diabetic nephropathy, and progression of CKD. Clinical Journal of The American Society of Nephrology: CJASN. 2009;4(9):1523-8. Not a randomized trial. [pmid: 19478099].
20 Agarwal R. Blood pressure components and the risk for end-stage renal disease and death in chronic kidney disease. Clinical Journal of The American Society of Nephrology: CJASN. 2009;4(4):830-7. Not a randomized trial. [pmid: 19339424].
21 Agarwal R, Acharya M, Tian J, et al. Antiproteinuric effect of oral paricalcitol in chronic kidney disease. Kidney International. 2005;68(6):2823-8. Duration of follow-up less than 1 year. [pmid: 16316359].
22 Agha A, Amer W, Anwar E, et al. Reduction of microalbuminuria by using losartan in normotensive patients with type 2 diabetes mellitus: A randomized controlled trial. Saudi Journal of Kidney Diseases & Transplantation. 2009;20(3):429-35. Duration of follow-up less than 1 year. [pmid: 19414946].
23 Agrawal A, Sautter MC, Jones NP. Effects of rosiglitazone maleate when added to a sulfonylurea regimen in patients with type 2 diabetes mellitus and mild to moderate renal impairment: a post hoc analysis. Clinical Therapeutics. 2003;25(11):2754-64. Duration of follow-up less than 1 year. [pmid: 14693302].
24 Agrawal RP, Dogra R, Mohta N, et al. Beneficial effect of camel milk in diabetic nephropathy. Acta Bio-Medica de l Ateneo Parmense. 2009;80(2):131-4. Duration of follow-up less than 1 year.
25 Ahern MJ, Harrison W, Hollingsworth P, et al. A randomised double-blind trial of cyclosporin and azathioprine in refractory rheumatoid arthritis. Australian & New Zealand Journal of Medicine. 1991;21(6):844-9. Intervention not related to monitoring of CKD. [pmid: 1818543].
26 Ahmad J, Shafique S, Abidi SM, et al. Effect of 5-year enalapril therapy on progression of microalbuminuria and glomerular structural changes in type 1 diabetic subjects. Diabetes Research & Clinical Practice. 2003;60(2):131-8. Intervention not related to monitoring of CKD. [pmid: 12706322].
27 Ahmad J, Siddiqui MA, Ahmad H. Effective postponement of diabetic nephropathy with enalapril in normotensive type 2 diabetic patients with microalbuminuria. Diabetes Care. 1997;20(10):1576-81. Intervention not related to monitoring of CKD. [pmid: 9314638].
28 Aho PS, Niemi T, Lindgren L, et al. Endovascular vs open AAA repair: similar effects on renal proximal tubular function. Scandinavian Journal of Surgery: SJS. 2004;93(1):52-6. Not a randomized trial.
29 Ahsan N, Hricik D, Matas A, et al. Prednisone withdrawal in kidney transplant recipients on cyclosporine and mycophenolate mofetil--a prospective randomized study. Steroid Withdrawal Study Group. Transplantation. 1999;68(12):1865-74. Not patients with early CKD. [pmid: 10628766].
30 Akesson A, Wollheim FA, Thysell H, et al. Visceral improvement following combined plasmapheresis and immunosuppressive drug therapy in progressive systemic sclerosis. Scandinavian Journal of Rheumatology. 1988;17(5):313-23. Not a randomized trial. [pmid: 3212403].
31 Akizawa T, Asano Y, Morita S, et al. Effect of a carbonaceous oral adsorbent on the progression of CKD: a multicenter, randomized, controlled trial. American Journal of Kidney Diseases. 2009;54(3):459-67. Intervention not related to monitoring of CKD. [pmid: 19615804].
32 Akriviadis E, Botla R, Briggs W, et al. Pentoxifylline improves short-term survival in severe acute alcoholic hepatitis: a double-blind, placebo-controlled trial. Gastroenterology. 2000;119(6):1637-48. Not patients with early CKD. [pmid: 11113085].
33 Albanis S, Ather HM, Papatsoris AG, et al. Inversion, hydration and diuresis during extracorporeal shock wave lithotripsy: does it improve the stone-free rate for lower pole stone clearance?. Urologia Internationalis. 2009;83(2):211-6. Not a randomized trial. [pmid: 19752619].
34 Albert I, Jais JP. The use of frailty models in genetic studies: application to the relationship between end-stage renal failure and mutation type in Alport syndrome. European Community Alport Syndrome Concerted Action Group (ECASCA). Journal of Epidemiology & Biostatistics. 2000;5(3):169-75. Not a randomized trial. [pmid: 11051113].
35 Albert SG, Shapiro MJ, Brown WW, et al. Analysis of radiocontrast-induced nephropathy by dual-labeled radionuclide clearance. Investigative Radiology. 1994;29(6):618-23. Duration of follow-up less than 1 year. [pmid: 8088970].
36 Al-Kateb H, Boright AP, Mirea L, et al. Multiple superoxide dismutase 1/splicing factor serine alanine 15 variants are associated with the development and progression of diabetic nephropathy: the Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications Genetics study. Diabetes. 2008;57(1):218-28. Not a randomized trial. [pmid: 17914031].
37 Allon M, Robbin ML. Hemodialysis vascular access monitoring: current concepts. Hemodialysis International. 2009;13(2):153-62. Not a randomized trial. [pmid: 19432687].
38 Amato RJ, Jac J, Hernandez-McClain J. Interferon-alpha in combination with either imatinib (Gleevec) or gefitinib (Iressa) in metastatic renal cell carcinoma: a phase II trial. Anti-Cancer Drugs. 2008;19(5):527-33. Not a randomized trial. [pmid: 18418219].
39 Andersen S, Brochner-Mortensen J, Parving HH. Kidney function during and after withdrawal of long-term irbesartan treatment in patients with type 2 diabetes and microalbuminuria. Diabetes Care. 2003;26(12):3296-302. Duration of follow-up less than 1 year. [pmid: 14633817].
40 Ansquer JC, Foucher C, Rattier S, et al. Fenofibrate reduces progression to microalbuminuria over 3 years in a placebo-controlled study in type 2 diabetes: results from the Diabetes Atherosclerosis Intervention Study (DAIS). American Journal of Kidney Diseases. 2005;45(3):485-93. Intervention not related to monitoring of CKD. [pmid: 15754270].
41 Aoki TT, Grecu EO, Prendergast JJ, et al. Effect of chronic intermittent intravenous insulin therapy on antihypertensive medication requirements in IDDM subjects with hypertension and nephropathy. Diabetes Care. 1995;18(9):1260-5. Intervention not related to monitoring of CKD. [pmid: 8612440].
42 Appel LJ, Wright JT Jr., Greene T, et al. Long-term effects of renin-angiotensin system-blocking therapy and a low blood pressure goal on progression of hypertensive chronic kidney disease in African Americans. Archives of Internal Medicine. 2008;168(8):832-9. Intervention not related to monitoring of CKD. [pmid: 18443258].
43 Artz MA, Hilbrands LB, Borm G, et al. Blockade of the renin-angiotensin system increases graft survival in patients with chronic allograft nephropathy. Nephrology Dialysis Transplantation. 2004;19(11):2852-7. Not patients with early CKD.
44 Assan R, Blanchet F, Feutren G, et al. Normal renal function 8 to 13 years after cyclosporin A therapy in 285 diabetic patients. Diabetes/Metabolism Research Reviews. 2002;18(6):464-72. Not a randomized trial.
45 Astobieta A, Calvo R, Aguirre C, et al. Netilmicin kinetics in urology. International Journal of Clinical Pharmacology, Therapy, & Toxicology. 1993;31(11):557-60. Not a randomized trial.
46 Atzpodien J, Kirchner H, Rebmann U, et al. Interleukin-2/interferon-alpha2a/13-retinoic acid-based chemoimmunotherapy in advanced renal cell carcinoma: results of a prospectively randomised trial of the German Cooperative Renal Carcinoma Chemoimmunotherapy Group (DGCIN). British Journal of Cancer. 2006;95(4):463-9. Intervention not related to monitoring of CKD. [pmid: 16909131].
47 Aulitzky WE, Grosse-Wilde H, Westhoff U, et al. Enhanced serum levels of soluble HLA class I molecules are induced by treatment with recombinant interferon-gamma (IFN-gamma). Clinical & Experimental Immunology. 1991;86(2):236-9. Not a randomized trial. [pmid: 1934591].
48 Axelsson J, Witasp A, Carrero JJ, et al. Circulating levels of visfatin/pre-B-cell colony-enhancing factor 1 in relation to genotype, GFR, body composition, and survival in patients with CKD. American Journal of Kidney Diseases. 2007;49(2):237-44. Not a randomized trial. [pmid: 17261426].
49 Azizi M, Menard J, Peyrard S, et al. Assessment of patients' and physicians' compliance to an ACE inhibitor treatment based on urinary N-acetyl Ser-Asp-Lys-Pro determination in the Noninsulin-Dependent Diabetes, Hypertension, Microalbuminuria, Proteinuria, Cardiovascular Events, and Ramipril (DIABHYCAR) study. Diabetes Care. 2006;29(6):1331-6. Not a randomized trial. [pmid: 16732017].
50 Bacoyiannis C, Dimopoulos MA, Kalofonos HP, et al. Vinblastine and interferon-gamma combination with and without 13-cis retinoic acid for patients with advanced renal cell carcinoma. Results of two phase II clinical trials. Oncology. 2002;63(2):130-8. Not a randomized trial. [pmid: 12239447].
51 Baigent C, Landray M, Leaper C, et al. First United Kingdom Heart and Renal Protection (UK-HARP-I) study: biochemical efficacy and safety of simvastatin and safety of low-dose aspirin in chronic kidney disease. American Journal of Kidney Diseases. 2005;45(3):473-84. Intervention not related to monitoring of CKD. [pmid: 15754269].
52 Baigent C, Landray M, Warren M. Statin therapy in kidney disease populations: potential benefits beyond lipid lowering and the need for clinical trials. Current Opinion in Nephrology & Hypertension. 2004;13(6):601-5. Not a randomized trial. [pmid: 15483449].
53 Baker LR, Abrams L, Roe CJ, et al. 1,25(OH)2D3 administration in moderate renal failure: a prospective double-blind trial. Kidney International. 1989;35(2):661-9. Less than 50 patients in study. [pmid: 2651758].
54 Baker LR, Abrams SM, Roe CJ, et al. Early therapy of renal bone disease with calcitriol: a prospective double-blind study. Kidney International - Supplement. 1989;27:S140-2. Less than 50 patients in study. [pmid: 2699994].
55 Bakir AA, Share DS, Levy PS, et al. Focal segmental glomerulosclerosis in adult African Americans. Clinical Nephrology. 1996;46(5):306-11. Not a randomized trial. [pmid: 8953119].
56 Bakris G, Hester A, Weber M, et al. The diabetes subgroup baseline characteristics of the Avoiding Cardiovascular Events Through Combination Therapy in Patients Living With Systolic Hypertension (ACCOMPLISH) trial. J Cardiometab Syndr. 2008;3(4):229-33. Intervention not related to monitoring of CKD. [pmid: 19040592].
57 Bakris GL, Copley JB, Vicknair N, et al. Calcium channel blockers versus other antihypertensive therapies on progression of NIDDM associated nephropathy. Kidney International. 1996;50(5):1641-50. Intervention not related to monitoring of CKD. [pmid: 8914031].
58 Bakris GL, Weir MR. Angiotensin-converting enzyme inhibitor-associated elevations in serum creatinine: is this a cause for concern?. Archives of Internal Medicine. 2000;160(5):685-93. Intervention not related to monitoring of CKD. [pmid: 10724055].
59 Bakris GL, Weir MR, Shanifar S, et al. Effects of blood pressure level on progression of diabetic nephropathy: results from the RENAAL study. Archives of Internal Medicine. 2003;163(13):1555-65. Intervention not related to monitoring of CKD. [pmid: 12860578].
60 Ballardie FW, Roberts ISD. Controlled prospective trial of prednisolone and cytotoxics in progressive IgA nephropathy. Journal of the American Society of Nephrology. 2002;13(1):142-8. Intervention not related to monitoring of CKD. [pmid: 11752031].
61 Banikazemi M, Bultas J, Waldek S, et al. Agalsidase-beta therapy for advanced Fabry disease: a randomized trial. Annals of Internal Medicine. 2007;146(2):77-86. Intervention not related to monitoring of CKD. [pmid: 17179052].
62 Bannister KM, Weaver A, Clarkson AR, et al. Effect of angiotensin-converting enzyme and calcium channel inhibition on progression of IgA nephropathy. Contributions to Nephrology. 1995;111:184-92. discussion 92-3. Intervention not related to monitoring of CKD. [pmid: 7758341].
63 Bansal N, Tighiouart H, Weiner D, et al. Anemia as a risk factor for kidney function decline in individuals with heart failure. American Journal of Cardiology. 2007;99(8):1137-42. Intervention not related to monitoring of CKD. [pmid: 17437743].
64 Barichella M, Savardi C, Mauri A, et al. Diet with LPP for renal patients increases daily energy expenditure and improves motor function in parkinsonian patients with motor fluctuations. Nutritional Neuroscience. 2007;10(3-4):129-35. Duration of follow-up less than 1 year. [pmid: 18019394].
65 Barlage S, Hauser IA, Elbracht R, et al. Monitoring of peripheral blood cytotoxic T-cells under fluvastatin treatment in renal transplant recipients. Journal of Biological Regulators & Homeostatic Agents. 2005;19(3-4):159-68. Not a randomized trial. [pmid: 16602632].
66 Barratt J, Feehally J. Treatment of IgA nephropathy. Kidney International. 2006;69(11):1934-8. Not a randomized trial. [pmid: 16641928].
67 Barrett BJ. Managing progressive renal disease before dialysis. Canadian Family Physician. 1999;45:977-84. Not a randomized trial. [pmid: 10216796].
68 Barrett SV, Paul J, Hay A, et al. Does body mass index affect progression-free or overall survival in patients with ovarian cancer? Results from SCOTROC I trial. Annals of Oncology. 2008;19(5):898-902. Intervention not related to monitoring of CKD. [pmid: 18272913].
69 Basile C, Ruggieri G, Vernaglione L, et al. The natural history of autogenous radio-cephalic wrist arteriovenous fistulas of haemodialysis patients: a prospective observational study. Nephrology Dialysis Transplantation. 2004;19(5):1231-6. Not patients with early CKD.
70 Bax L, Mali WPTM, Buskens E, et al. The benefit of STent placement and blood pressure and lipid-lowering for the prevention of progression of renal dysfunction caused by Atherosclerotic ostial stenosis of the Renal artery. The STAR-study: rationale and study design. Journal of Nephrology. 2003;16(6):807-12. Not a randomized trial. [pmid: 14736007].
71 Bazzato G, Scanferla F. Assessment of the best compatible dialysis system: feasible application for bioelectrical impedance. International Journal of Artificial Organs. 1995;18(11):712-5. Not a randomized trial. [pmid: 8964633].
72 Beatovic S, Jaksic ED, Han RS. Measurement of renal function by calculation of fractional uptake of technetium-99m dimercaptosuccinic acid. Nucl Med Rev Cent East Eur. 2004;7(1):49-52. Not adult population. [pmid: 15318311].
73 Bellasi A, Kooienga L, Block GA, et al. How long is the warranty period for nil or low coronary artery calcium in patients new to hemodialysis?. Journal of Nephrology. 2009;22(2):255-62. Not a randomized trial. [pmid: 19384844].
74 Bellizzi V, Scalfi L, Terracciano V, et al. Early changes in bioelectrical estimates of body composition in chronic kidney disease. Journal of the American Society of Nephrology. 2006;17(5):1481-7. Not a randomized trial. [pmid: 16611719].
75 Bello E, Caramelo C, Martell N, et al. Impairment of renal vasodilation with l-arginine is related to more severe disease in untreated hypertensive patients. Hypertension. 2001;38(4):907-12. Not a randomized trial. [pmid: 11641307].
76 Bellomo R, Auriemma S, Fabbri A, et al. The pathophysiology of cardiac surgery-associated acute kidney injury (CSA-AKI). International Journal of Artificial Organs. 2008;31(2):166-78. Not a randomized trial. [pmid: 18311733].
77 Ben-Zvi I, Green Y, Nakhoul F, et al. Effects of diabetes mellitus, chronic renal failure and hemodialysis on serum and salivary antioxidant status. Nephron Clin Pract. 2007;105(3):c114-20. Not a randomized trial. [pmid: 17199094].
78 Berenson JR. Recommendations for zoledronic acid treatment of patients with bone metastases. Oncologist. 2005;10(1):52-62. Not a randomized trial. [pmid: 15632252].
79 Bergrem H, Goransson LG, Asmundsson P, et al. The Nephrocare project: referral, patient case-mix, follow-up and quality of renal care in Nordic renal centres. Scandinavian Journal of Urology & Nephrology. 2009;43(4):319-24. Not a randomized trial. [pmid: 19333821].
80 Bertolissi M, Antonucci F, De Monte A, et al. Effects on renal function of a continuous infusion of nifedipine during cardiopulmonary bypass. Journal of Cardiothoracic & Vascular Anesthesia. 1996;10(2):238-42. Less than 50 patients in study. [pmid: 8850405].
81 Besarab A, Frinak S, Yee J. What is so bad about a hemoglobin level of 12 to 13 g/dL for chronic kidney disease patients anyway?. Advances in Chronic Kidney Disease. 2009;16(2):131-42. Not a randomized trial. [pmid: 19233072].
82 Bhandari S, Brownjohn A, Turney J. Effective utilization of erythropoietin with intravenous iron therapy. Journal of Clinical Pharmacy & Therapeutics. 1998;23(1):73-8. Not a randomized trial. [pmid: 9756115].
83 Bianchi S, Bigazzi R, Caiazza A, et al. A controlled, prospective study of the effects of atorvastatin on proteinuria and progression of kidney disease. [Erratum appears in Am J Kidney Dis. 2004 Jan;43(1):193]. American Journal of Kidney Diseases. 2003;41(3):565-70. Intervention not related to monitoring of CKD. [pmid: 12612979].
84 Bianchi S, Bigazzi R, Campese VM. Antagonists of aldosterone and proteinuria in patients with CKD: an uncontrolled pilot study. American Journal of Kidney Diseases. 2005;46(1):45-51. Duration of follow-up less than 1 year. [pmid: 15983956].
85 Biancofiore G, Esposito M, Bindi L, et al. Regional filter heparinization for continuous veno-venous hemofiltration in liver transplant recipients. Minerva Anestesiologica. 2003;69(6):527-34. 34. 8. Not a randomized trial. [pmid: 14564251].
86 Bibi G, Green Y, Nagler RM. Compositional and oxidative analysis in the saliva and serum of predialysis chronic kidney disease patients and end-stage renal failure patients on peritoneal dialysis. Therapeutic Apheresis & Dialysis: Official Peer-Reviewed Journal of the International Society for Apheresis, the Japanese Society for Apheresis, the Japanese Society for Dialysis Therapy. 2008;12(2):164-70. Not a randomized trial.
87 Bilous R. Microvascular disease: what does the UKPDS tell us about diabetic nephropathy?. Diabetic Medicine. Suppl 2. 2008;25:25-9. Not a randomized trial. [pmid: 18717975].
88 Birnbaum BA, Jacobs JE, Langlotz CP, et al. Assessment of a bolus-tracking technique in helical renal CT to optimize nephrographic phase imaging. Radiology. 1999;211(1):87-94. Not a randomized trial. [pmid: 10189457].
89 Ble A, Fink JC, Woodman RC, et al. Renal function, erythropoietin, and anemia of older persons: the InCHIANTI study. Archives of Internal Medicine. 2005;165(19):2222-7. Not a randomized trial. [pmid: 16246987].
90 Blohme I, Idstrom JP, Andersson T. A study of the interaction between omeprazole and cyclosporine in renal transplant patients. British Journal of Clinical Pharmacology. 1993;35(2):156-60. Intervention not related to monitoring of CKD. [pmid: 8443034].
91 Boccardo F, Rubagotti A, Canobbio L, et al. Interleukin-2, interferon-alpha and interleukin-2 plus interferon-alpha in renal cell carcinoma. A randomized phase II trial. Tumori. 1998;84(5):534-9. Intervention not related to monitoring of CKD. [pmid: 9862512].
92 Body JJ, Diel I, Bell R. Profiling the safety and tolerability of bisphosphonates. Seminars in Oncology. 2004;31(5 Suppl 10):73-8. Not a randomized trial. [pmid: 15490380].
93 Boger RH, Schwedhelm E, Maas R, et al. ADMA and oxidative stress may relate to the progression of renal disease: rationale and design of the VIVALDI study. Vasc Med. Suppl 1. 2005;10:S97-102. Not a randomized trial. [pmid: 16444875].
94 Bohler T, Waiser J, Schutz M, et al. FTY 720A mediates reduction of lymphocyte counts in human renal allograft recipients by an apoptosis-independent mechanism. Transplant International. Suppl 1. 2000;13:S311-3. Not a randomized trial. [pmid: 11112021].
95 Boldt J, Brosch C, Piper SN, et al. Influence of prophylactic use of pentoxifylline on postoperative organ function in elderly cardiac surgery patients. Critical Care Medicine. 2001;29(5):952-8. Intervention not related to monitoring of CKD. [pmid: 11378603].
96 Bolondi L, Piscaglia F, Gatta A, et al. Effect of potassium canrenoate, an anti-aldosterone agent, on incidence of ascites and variceal progression in cirrhosis. Clinical Gastroenterology & Hepatology. 2006;4(11):1395-402. Intervention not related to monitoring of CKD. [pmid: 16931172].
97 Bolton WK, Cattran DC, Williams ME, et al. Randomized trial of an inhibitor of formation of advanced glycation end products in diabetic nephropathy. American Journal of Nephrology. 2004;24(1):32-40. Intervention not related to monitoring of CKD. [pmid: 14685005].
98 Bonello M, House AA, Cruz D, et al. Integration of blood volume, blood pressure, heart rate and bioimpedance monitoring for the achievement of optimal dry body weight during chronic hemodialysis. International Journal of Artificial Organs. 2007;30(12):1098-108. Not a randomized trial. [pmid: 18203072].
99 Boogaard PJ, Houtsma AT, Journee HL, et al. Effects of exposure to elemental mercury on the nervous system and the kidneys of workers producing natural gas. Archives of Environmental Health. 1996;51(2):108-15. Not a randomized trial. [pmid: 8638960].
100 Booth AD, Firth JD, Jayne DRW. Immunotherapy for autoimmune and inflammatory renal diseases. Expert Opinion on Biological Therapy. 2003;3(3):487-500. Not a randomized trial. [pmid: 12783617].
101 Braden GL, von Oeyen PT, Germain MJ, et al. Ritodrine- and terbutaline-induced hypokalemia in preterm labor: mechanisms and consequences. Kidney International. 1997;51(6):1867-75. Not a randomized trial. [pmid: 9186877].
102 Brennan DC, Barbeito R, Burke J, et al. Safety of Neoral conversion in maintenance renal transplant patients: A one-year, double-blind study. NOVARTIS OLN-353 Study Group. Kidney International. 1999;56(2):685-91. Not patients with early CKD. [pmid: 10432409].
103 Brenner BM, Cooper ME, de Zeeuw D, et al. Effects of losartan on renal and cardiovascular outcomes in patients with type 2 diabetes and nephropathy. New England Journal of Medicine. 2001;345(12):861-9. Intervention not related to monitoring of CKD. [pmid: 11565518].
104 Bretzel RG. Prevention and slowing down the progression of the diabetic nephropathy through antihypertensive therapy. Journal of Diabetes & its Complications. 1997;11(2):112-22. Not a randomized trial. [pmid: 9101397].
105 Breyer JA, Bain RP, Evans JK, et al. Predictors of the progression of renal insufficiency in patients with insulin-dependent diabetes and overt diabetic nephropathy. The Collaborative Study Group. Kidney International. 1996;50(5):1651-8. Not a randomized trial. [pmid: 8914032].
106 Brienza N, Giglio MT, Marucci M, et al. Does perioperative hemodynamic optimization protect renal function in surgical patients? A meta-analytic study. Critical Care Medicine. 2009;37(6):2079-90. Not a randomized trial. [pmid: 19384211].
107 Brophy DF, Martin EJ, Gehr TWB, et al. Enhanced anticoagulant activity of enoxaparin in patients with ESRD as measured by thrombin generation time. American Journal of Kidney Diseases. 2004;44(2):270-7. Not a randomized trial. [pmid: 15264185].
108 Buargub MA, Nabulsi MF, Shafeh TA. Prevalence and pattern of renal osteodystrophy in chronic hemodialysis patients: a cross sectional study of 103 patients. Saudi Journal of Kidney Diseases & Transplantation. 2006;17(3):401-7. Not a randomized trial. [pmid: 16970264].
109 Budoff MJ, Kessler P, Gao YL, et al. The interscan variation of CT coronary artery calcification score: analysis of the Calcium Acetate Renagel Comparison (CARE)-2 study. Academic Radiology. 2008;15(1):58-61. Intervention not related to monitoring of CKD. [pmid: 18078907].
110 Bukowski RM. Targeted therapy for cytokine-refractory metastatic renal cell carcinoma, and treatment in the community. Oncology. 2006;20(6 Suppl 5):25-8. Not a randomized trial. [pmid: 16773842].
111 Bunke M, Sloan R, Brier M, et al. An improved glomerular filtration rate in cardiac transplant recipients with once-a-day cyclosporine dosing. Transplantation. 1995;59(4):537-40. Intervention not related to monitoring of CKD. [pmid: 7878758].
112 Buraczynska M, Grzebalska A, Spasiewicz D, et al. Genetic polymorphisms of renin-angiotensin system and progression of interstitial nephritis. Annales Universitatis Mariae Curie-Sklodowska - Sectio d - Medicina. 2002;57(2):330-6. Not a randomized trial. [pmid: 12898858].
113 Burgess E. Conservative treatment to slow deterioration of renal function: evidence-based recommendations. Kidney International - Supplement. 1999;70:S17-25. Intervention not related to monitoring of CKD. [pmid: 10369191].
114 Bursztyn M, Motro M, Grossman E, et al. Accelerated coronary artery calcification in mildly reduced renal function of high-risk hypertensives: a 3-year prospective observation. Journal of Hypertension. 2003;21(10):1953-9. Not a randomized trial. [pmid: 14508203].
115 Butler JA, Peveler RC, Roderick P, et al. Modifiable risk factors for non-adherence to immunosuppressants in renal transplant recipients: a cross-sectional study. Nephrology Dialysis Transplantation. 2004;19(12):3144-9. Not a randomized trial.
116 Bybee KA, Lee JH, O'Keefe JH. Cumulative clinical trial data on atorvastatin for reducing cardiovascular events: the clinical impact of atorvastatin. Current Medical Research & Opinion. 2008;24(4):1217-29. Not a randomized trial. [pmid: 18358084].
117 Calkins DS, Degioanni JJ, Tan MN, et al. Human performance and physiological function during a 24-hr exposure to 1% bromotrifluoromethane (Halon 1301). Fundamental & Applied Toxicology. 1993;20(2):240-7. Not a randomized trial. [pmid: 8449396].
118 Campbell KL, Ash S, Bauer JD. The impact of nutrition intervention on quality of life in pre-dialysis chronic kidney disease patients. Clinical Nutrition. 2008;27(4):537-44. Not a randomized trial. [pmid: 18584924].
119 Campistol JM, Inigo P, Larios S, et al. Role of transforming growth factor-beta1 in the progression of chronic allograft nephropathy. Nephrology Dialysis Transplantation. Suppl 1. 2001;16:114-6. Not a randomized trial.
120 Cantarovich M. Renal protective strategies in heart transplant patients. Current Opinion in Cardiology. 2007;22(2):133-8. Not a randomized trial. [pmid: 17284993].
121 Cantarovich M, Giannetti N, Routy JP, et al. Long-term immunosuppression with anti-CD25 monoclonal antibodies in heart transplant patients with chronic kidney disease. Journal of Heart & Lung Transplantation. 2009;28(9):912-8. Not a randomized trial. [pmid: 19716044].
122 Cao C, Wan X, Chen Y, et al. Metabolic factors and microinflammatory state promote kidney injury in type 2 diabetes mellitus patients. Renal Failure. 2009;31(6):470-4. Not a randomized trial. [pmid: 19839824].
123 Carides GW, Shahinfar S, Dasbach EJ, et al. The impact of losartan on the lifetime incidence of end-stage renal disease and costs in patients with type 2 diabetes and nephropathy. Pharmacoeconomics. 2006;24(6):549-58. Not a randomized trial. [pmid: 16761903].
124 Casey ET, Murad MH, Rizvi AZ, et al. Surveillance of arteriovenous hemodialysis access: a systematic review and meta-analysis. Journal of Vascular Surgery. 2008;48(5 Suppl):48S-54S. Not a randomized trial. [pmid: 19000593].
125 Cass LM, Efthymiopoulos C, Marsh J, et al. Effect of renal impairment on the pharmacokinetics of intravenous zanamivir. Clinical Pharmacokinetics. Suppl 1. 1999;36:13-9. Not a randomized trial. [pmid: 10429836].
126 Cathelineau G, de Champvallins M, Bouallouche A, et al. Management of newly diagnosed non-insulin-dependent diabetes mellitus in the primary care setting: effects of 2 years of gliclazide treatment--the Diadem Study. Metabolism: Clinical & Experimental. 1997;46(12 Suppl 1):31-4. Not a randomized trial. [pmid: 9439556].
127 Cattran DC. Mycophenolate mofetil and cyclosporine therapy in membranous nephropathy. Seminars in Nephrology. 2003;23(3):272-7. Not a randomized trial. [pmid: 12838495].
128 Cattran DC. Cyclosporine in the treatment of idiopathic focal segmental glomerulosclerosis. Seminars in Nephrology. 2003;23(2):234-41. Not a randomized trial. [pmid: 12704584].
129 Cattran DC, Alexopoulos E, Heering P, et al. Cyclosporin in idiopathic glomerular disease associated with the nephrotic syndrome : workshop recommendations. Kidney International. 2007;72(12):1429-47. Not a randomized trial. [pmid: 17898700].
130 Chan JC, So WY, Yeung CY, et al. Effects of structured versus usual care on renal endpoint in type 2 diabetes: the SURE study: a randomized multicenter translational study. Diabetes Care. 2009;32(6):977-82. Intervention not related to monitoring of CKD. [pmid: 19460913].
131 Chapman AB. Improving clinical trial design for inquiries into the mechanisms of cyst growth in ADPKD. Kidney International. 2009;75(2):139-41. Not a randomized trial. [pmid: 19116643].
132 Chaudhary UB, Haldas JR. Long-term complications of chemotherapy for germ cell tumours. Drugs. 2003;63(15):1565-77. Not a randomized trial. [pmid: 12887263].
133 Chertow GM, Raggi P, Chasan-Taber S, et al. Determinants of progressive vascular calcification in haemodialysis patients. Nephrology Dialysis Transplantation. 2004;19(6):1489-96. Not a randomized trial.
134 Chesterton LJ, Selby NM, Burton JO, et al. Cool dialysate reduces asymptomatic intradialytic hypotension and increases baroreflex variability. Hemodialysis International. 2009;13(2):189-96. Not a randomized trial. [pmid: 19432693].
135 Chiang SS, Chen JB, Yang WC. Lanthanum carbonate (Fosrenol) efficacy and tolerability in the treatment of hyperphosphatemic patients with end-stage renal disease. Clinical Nephrology. 2005;63(6):461-70. Intervention not related to monitoring of CKD. [pmid: 15960148].
136 Chiurchiu C, Remuzzi G, Ruggenenti P. Angiotensin-converting enzyme inhibition and renal protection in nondiabetic patients: the data of the meta-analyses. Journal of the American Society of Nephrology. Suppl 1. 2005;16:S58-63. Not a randomized trial. [pmid: 15938036].
137 Choi KL, Elliott WJ. Antihypertensive, antiproteinuric therapy and myocardial infarction and stroke prevention. Current Hypertension Reports. 2005;7(5):367-73. Not a randomized trial. [pmid: 16157081].
138 Chonchol M, Goldenberg I, Moss AJ, et al. Risk factors for sudden cardiac death in patients with chronic renal insufficiency and left ventricular dysfunction. American Journal of Nephrology. 2007;27(1):7-14. Not a randomized trial. [pmid: 17204832].
139 Chrysant SG. Angiotensin II receptor blockers in the treatment of the cardiovascular disease continuum. Clinical Therapeutics. 2008;30(Pt 2):2181-90. Not a randomized trial. [pmid: 19281913].
140 Chrysochou C, Randhawa H, Reeve R, et al. Determinants of renal functional outcome in lupus nephritis: a single centre retrospective study. Qjm. 2008;101(4):313-6. Not a randomized trial. [pmid: 18270227].
141 Chu D, Lacouture ME, Fillos T, et al. Risk of hand-foot skin reaction with sorafenib: a systematic review and meta-analysis. Acta Oncologica. 2008;47(2):176-86. Not a randomized trial. [pmid: 18210295].
142 Chu D, Lacouture ME, Weiner E, et al. Risk of hand-foot skin reaction with the multitargeted kinase inhibitor sunitinib in patients with renal cell and non-renal cell carcinoma: a meta-analysis. Clinical Genitourinary Cancer. 2009;7(1):11-9. Not a randomized trial. [pmid: 19213662].
143 Cianci R, Gigante A, Polidori L, et al. In-stent restenosis of the renal artery in a single kidney patient: the role of ACEI in the therapeutic choice. Angiology. 2009;60(4):496-503. Not a randomized trial. [pmid: 18796449].
144 Cianciaruso B, Pota A, Bellizzi V, et al. Effect of a low- versus moderate-protein diet on progression of CKD: follow-up of a randomized controlled trial. American Journal of Kidney Diseases. 2009;54(6):1052-61. Intervention not related to monitoring of CKD. [pmid: 19800722].
145 Cianciaruso B, Pota A, Pisani A, et al. Metabolic effects of two low protein diets in chronic kidney disease stage 4-5--a randomized controlled trial. Nephrology Dialysis Transplantation. 2008;23(2):636-44. Intervention not related to monitoring of CKD.
146 Cianciaruso B, Ravani P, Barrett BJ, et al. Italian randomized trial of hemoglobin maintenance to prevent or delay left ventricular hypertrophy in chronic kidney disease. J Nephrol. 2008;21(6):861-70. Intervention not related to monitoring of CKD. [pmid: 19034870].
147 Ciancio G, Burke GW, Gaynor JJ, et al. A randomized trial of three renal transplant induction antibodies: early comparison of tacrolimus, mycophenolate mofetil, and steroid dosing, and newer immune-monitoring. Transplantation. 2005;80(4):457-65. Not patients with early CKD. [pmid: 16123718].
148 Ciancio G, Burke GW, Gaynor JJ, et al. Randomized trial of mycophenolate mofetil versus enteric-coated mycophenolate sodium in primary renal transplant recipients given tacrolimus and daclizumab/thymoglobulin: one year follow-up. Transplantation. 2008;86(1):67-74. Not patients with early CKD. [pmid: 18622280].
149 Ciancio G, Burke GW, Gaynor JJ, et al. A randomized long-term trial of tacrolimus/sirolimus versus tacrolimums/mycophenolate versus cyclosporine/sirolimus in renal transplantation: three-year analysis. Transplantation. 2006;81(6):845-52. Not patients with early CKD. [pmid: 16570006].
150 Cicinnati VR, Yu Z, Klein CG, et al. Clinical trial: switch to combined mycophenolate mofetil and minimal dose calcineurin inhibitor in stable liver transplant patients--assessment of renal and allograft function, cardiovascular risk factors and immune monitoring. Alimentary Pharmacology & Therapeutics. 2007;26(9):1195-208. Not patients with early CKD. [pmid: 17944734].
151 Cinotti GA, Zucchelli PC, Collaborative Study G. Effect of Lisinopril on the progression of renal insufficiency in mild proteinuric non-diabetic nephropathies. Nephrology Dialysis Transplantation. 2001;16(5):961-6. Intervention not related to monitoring of CKD.
152 Citterio F, Sparacino V, Altieri P, et al. Addition of sirolimus to cyclosporine in long-term kidney transplant recipients to withdraw steroid. Transplantation Proceedings. 2005;37(2):827-9. Not patients with early CKD. [pmid: 15848545].
153 Clark JI, Kancharla K, Qamar R, et al. Pilot study of sequential vinorelbine and cisplatin followed by docetaxel for selected IIIB and stage IV non-small cell lung cancer. Lung Cancer. 2001;34(2):271-7. Not a randomized trial. [pmid: 11679186].
154 Clark PE, Hall MC, Miller A, et al. Phase II trial of combination interferon-alpha and thalidomide as first-line therapy in metastatic renal cell carcinoma. Urology. 2004;63(6):1061-5. Not a randomized trial. [pmid: 15183950].
155 Cleland JG, Dargie HJ, Ball SG, et al. Effects of enalapril in heart failure: a double blind study of effects on exercise performance, renal function, hormones, and metabolic state. British Heart Journal. 1985;54(3):305-12. Not a randomized trial. [pmid: 2994698].
156 Coburn JW, Elangovan L. Prevention of metabolic bone disease in the pre-end-stage renal disease setting. Journal of the American Society of Nephrology. 1998;9(12 Suppl):S71-7. Not a randomized trial. [pmid: 11443772].
157 Coburn JW, Maung HM, Elangovan L, et al. Doxercalciferol safely suppresses PTH levels in patients with secondary hyperparathyroidism associated with chronic kidney disease stages 3 and 4. American Journal of Kidney Diseases. 2004;43(5):877-90. Duration of follow-up less than 1 year. [pmid: 15112179].
158 Cody J, Daly C, Campbell M, et al. Recombinant human erythropoietin for chronic renal failure anaemia in pre-dialysis patients. Cochrane Database of Systematic Reviews. 2001;(4):CD003266. Not a randomized trial. [pmid: 11687180].
159 Cody J, Daly C, Campbell M, et al. Recombinant human erythropoietin for chronic renal failure anaemia in pre-dialysis patients. Cochrane Database of Systematic Reviews. 2005;(3):CD003266. Not a randomized trial. [pmid: 16034896].
160 Coen G, Mazzaferro S, Bonucci E, et al. Bone GLA protein in predialysis chronic renal failure. Effects of 1,25(OH)2D3 administration in a long-term follow-up. Kidney International. 1985;28(5):783-90. Not a randomized trial. [pmid: 3878905].
161 Coen G, Mazzaferro S, Manni M, et al. No acceleration and possibly slower progression of renal failure during calcitriol treatment in predialysis chronic renal failure. Nephrology Dialysis Transplantation. 1994;9(10):1520. Intervention not related to monitoring of CKD.
162 Cofan F, Gilabert R, Zambon D, et al. Effect of pravastatin treatment on the evolution of extracoronary atherosclerosis in renal transplant patients. Transplantation Proceedings. 2002;34(1):384-8. Not patients with early CKD. [pmid: 11959338].
163 Colhoun HM, Betteridge DJ, Durrington PN, et al. Primary prevention of cardiovascular disease with atorvastatin in type 2 diabetes in the Collaborative Atorvastatin Diabetes Study (CARDS): multicentre randomised placebo-controlled trial. Lancet. 2004;364(9435):685-96. Intervention not related to monitoring of CKD. [pmid: 15325833].
164 Collins AC, Vincent J, Newall RG, et al. An aid to the early detection and management of diabetic nephropathy: assessment of a new point of care microalbuminuria system in the diabetic clinic. Diabetic Medicine. 2001;18(11):928-32. Not a randomized trial. [pmid: 11703439].
165 Conen D, Glynn RJ, Buring JE, et al. Association of renin-angiotensin and endothelial nitric oxide synthase gene polymorphisms with blood pressure progression and incident hypertension: prospective cohort study. Journal of Hypertension. 2008;26(9):1780-6. Not a randomized trial. [pmid: 18698212].
166 Conil JM, Georges B, Fourcade O, et al. Intermittent administration of ceftazidime to burns patients: influence of glomerular filtration. International Journal of Clinical Pharmacology & Therapeutics. 2007;45(3):133-42. Intervention not related to monitoring of CKD. [pmid: 17416108].
167 Cooper CJ, Murphy TP, Matsumoto A, et al. Stent revascularization for the prevention of cardiovascular and renal events among patients with renal artery stenosis and systolic hypertension: rationale and design of the CORAL trial. American Heart Journal. 2006;152(1):59-66. Intervention not related to monitoring of CKD. [pmid: 16824832].
168 Coppo R, Peruzzi L, Amore A, et al. IgACE: a placebo-controlled, randomized trial of angiotensin-converting enzyme inhibitors in children and young people with IgA nephropathy and moderate proteinuria. Journal of the American Society of Nephrology. 2007;18(6):1880-8. Not adult population. [pmid: 17513327].
169 Cortes-Sanabria L, Cabrera-Pivaral CE, Cueto-Manzano AM, et al. Improving care of patients with diabetes and CKD: a pilot study for a cluster-randomized trial. American Journal of Kidney Diseases. 2008;51(5):777-88. Intervention not related to monitoring of CKD. [pmid: 18436088].
170 Cotter G, Dittrich HC, Weatherley BD, et al. The PROTECT pilot study: a randomized, placebo-controlled, dose-finding study of the adenosine A1 receptor antagonist rolofylline in patients with acute heart failure and renal impairment. Journal of Cardiac Failure. 2008;14(8):631-40. Intervention not related to monitoring of CKD. [pmid: 18926433].
171 Couchoud C, Labeeuw M, Moranne O, et al. A clinical score to predict 6-month prognosis in elderly patients starting dialysis for end-stage renal disease. Nephrology Dialysis Transplantation. 2009;24(5):1553-61. Not a randomized trial.
172 Coyle D, Rodby R, Soroka S, et al. Cost-effectiveness of irbesartan 300 mg given early versus late in patients with hypertension and a history of type 2 diabetes and renal disease: a Canadian perspective. Clinical Therapeutics. 2007;29(7):1508-23. Not a randomized trial. [pmid: 17825702].
173 Coyne D, Acharya M, Qiu P, et al. Paricalcitol capsule for the treatment of secondary hyperparathyroidism in stages 3 and 4 CKD. American Journal of Kidney Diseases. 2006;47(2):263-76. Intervention not related to monitoring of CKD. [pmid: 16431255].
174 Cravedi P, Ruggenenti P, Remuzzi G. Intensified inhibition of renin-angiotensin system: a way to improve renal protection?. Current Hypertension Reports. 2007;9(5):430-6. Not a randomized trial. [pmid: 18177592].
175 Crepaldi G, Carta Q, Deferrari G, et al. Effects of lisinopril and nifedipine on the progression to overt albuminuria in IDDM patients with incipient nephropathy and normal blood pressure. The Italian Microalbuminuria Study Group in IDDM. Diabetes Care. 1998;21(1):104-10. Intervention not related to monitoring of CKD. [pmid: 9538979].
176 Cronberg S, Nordstrom L. Simplified monitoring of aminoglycoside treatment. Scandinavian Journal of Infectious Diseases Supplement. 1990;74:274-9. Intervention not related to monitoring of CKD. [pmid: 2097716].
177 Cruzado JM, Rico J, Grinyo JM. The renin angiotensin system blockade in kidney transplantation: pros and cons. Transplant International. 2008;21(4):304-13. Not a randomized trial. [pmid: 18266774].
178 Culp K, Flanigan M, Lowrie EG, et al. Modeling mortality risk in hemodialysis patients using laboratory values as time-dependent covariates. American Journal of Kidney Diseases. 1996;28(5):741-6. Not a randomized trial. [pmid: 9158214].
179 Cummings DM, Amadio P Jr., Nettler S, et al. Office-based evaluation of renal function in elderly patients receiving nonsteroidal anti-inflammatory drugs. Journal of the American Board of Family Practice. 1988;1(2):77-80. Intervention not related to monitoring of CKD. [pmid: 3046231].
180 Cummings ST, Fraser CG. Total amylase and pancreatic isoamylase in serum and urine: considerations from data on biological variation. Annals of Clinical Biochemistry. 1989;26(Pt 4):335-40. Not a randomized trial. [pmid: 2475049].
181 Cunningham MA, Huang XR, Dowling JP, et al. Prominence of cell-mediated immunity effectors in “pauci-immune” glomerulonephritis. Journal of the American Society of Nephrology. 1999;10(3):499-506. Not a randomized trial. [pmid: 10073600].
182 Cupisti A, Licitra R, Chisari C, et al. Skeletal muscle and nutritional assessment in chronic renal failure patients on a protein-restricted diet. Journal of Internal Medicine. 2004;255(1):115-24. Not a randomized trial. [pmid: 14687247].
183 Czupryniak L, Pawlowski M, Saryusz-Wolska M, et al. Circadian blood pressure variation and antihypertensive medication adjustment in normoalbuminuric type 2 diabetes patients. Kidney & Blood Pressure Research. 2007;30(3):182-6. Not a randomized trial. [pmid: 17536225].
184 Dailey GE, Boden GH, Creech RH, et al. Effects of pulsatile intravenous insulin therapy on the progression of diabetic nephropathy. Metabolism: Clinical & Experimental. 2000;49(11):1491-5. Intervention not related to monitoring of CKD. [pmid: 11092517].
185 D'Amico G, Gentile MG, Fellin G, et al. Effect of dietary protein restriction on the progression of renal failure: a prospective randomized trial. Nephrology Dialysis Transplantation. 1994;9(11):1590-4. Intervention not related to monitoring of CKD.
186 Damman K, Navis G, Voors AA, et al. Worsening renal function and prognosis in heart failure: systematic review and meta-analysis. Journal of Cardiac Failure. 2007;13(8):599-608. Intervention not related to monitoring of CKD. [pmid: 17923350].
187 Daumit GL, Hermann JA, Coresh J, et al. Use of cardiovascular procedures among black persons and white persons: a 7-year nationwide study in patients with renal disease. Annals of Internal Medicine. 1999;130(3):173-82. Not a randomized trial. [pmid: 10049195].
188 Daumit GL, Hermann JA, Powe NR. Relation of gender and health insurance to cardiovascular procedure use in persons with progression of chronic renal disease. Medical Care. 2000;38(4):354-65. Not a randomized trial. [pmid: 10752967].
189 Davidson MB, Karlan VJ, Hair TL. Effect of a pharmacist-managed diabetes care program in a free medical clinic. American Journal of Medical Quality. 2000;15(4):137-42. Not a randomized trial. [pmid: 10948785].
190 Davis ID, MacRae Dell K, Sweeney WE, et al. Can progression of autosomal dominant or autosomal recessive polycystic kidney disease be prevented?. Seminars in Nephrology. 2001;21(5):430-40. Not a randomized trial. [pmid: 11559884].
191 Davis NB, Taber DA, Ansari RH, et al. Phase II trial of PS-341 in patients with renal cell cancer: a University of Chicago phase II consortium study. Journal of Clinical Oncology. 2004;22(1):115-9. Not a randomized trial. [pmid: 14701773].
192 Davis R, Faulds D. Nadroparin calcium. A review of its pharmacology and clinical use in the prevention and treatment of thromboembolic disorders. Drugs & Aging. 1997;10(4):299-322. Intervention not related to monitoring of CKD. [pmid: 9108990].
193 de Brito-Ashurst I, Varagunam M, Raftery MJ, et al. Bicarbonate supplementation slows progression of CKD and improves nutritional status. Journal of the American Society of Nephrology. 2009;20(9):2075-84. Intervention not related to monitoring of CKD. [pmid: 19608703].
194 de Denus S, Tardif JC, White M, et al. Quantification of the risk and predictors of hyperkalemia in patients with left ventricular dysfunction: a retrospective analysis of the Studies of Left Ventricular Dysfunction (SOLVD) trials. American Heart Journal. 2006;152(4):705-12. Not a randomized trial. [pmid: 16996842].
195 de Denus S, Tardif JC, White M, et al. Temporal variations in hematocrit values in patients with left ventricular dysfunction: Relationship with cause-specific mortality and morbidity and optimal monitoring--further insights from SOLVD. Canadian Journal of Cardiology. 2008;24(1):45-8. Not a randomized trial. [pmid: 18209768].
196 de la Sierra A, Lluch MM, Coca A, et al. Fluid, ionic and hormonal changes induced by high salt intake in salt-sensitive and salt-resistant hypertensive patients. Clinical Science. 1996;91(2):155-61. Intervention not related to monitoring of CKD. [pmid: 8795438].
197 De Marchi S, Cecchin E. Hepatic computed tomography for monitoring the iron status of haemodialysis patients with haemosiderosis treated with recombinant human erythropoietin. Clinical Science. 1991;81(1):113-21. Not a randomized trial. [pmid: 1649718].
198 De Palo EF, Gatti R, Lancerin F, et al. Urinary insulin-like growth factor I in athletes, before and after physical exercise, and in sedentary subjects. Clinica Chimica Acta. 2002;322(1-2):51-7. Not a randomized trial.
199 De Sadeleer C, Piepsz A, Ham HR. How good is the slope on the second exponential for estimating 51Cr-EDTA renal clearance? A Monte Carlo simulation. Nuclear Medicine Communications. 2000;21(5):455-8. Not a randomized trial. [pmid: 10874703].
200 de Silva R, Nikitin NP, Bhandari S, et al. Atherosclerotic renovascular disease in chronic heart failure: should we intervene?. European Heart Journal. 2005;26(16):1596-605. Not a randomized trial. [pmid: 15919719].
201 De Vane GW, Czekala NM, Shideler SE, et al. Monitoring gonadotropin-releasing hormone administration by measurement of urinary steroid conjugates. Obstetrics & Gynecology. 1986;67(5):710-7. Not a randomized trial. [pmid: 3515262].
202 de Vinuesa SG, Goicoechea M, Kanter J, et al. Insulin resistance, inflammatory biomarkers, and adipokines in patients with chronic kidney disease: effects of angiotensin II blockade. Journal of the American Society of Nephrology. 2006;17(12 Suppl 3):S206-12. Not a randomized trial. [pmid: 17130263].
203 de Vries PJ, Verkooyen RP, Leguit P, et al. Prospective randomized study of once-daily versus thrice-daily netilmicin regimens in patients with intraabdominal infections. European Journal of Clinical Microbiology & Infectious Diseases. 1990;9(3):161-8. Not patients with early CKD.
204 Deehan DJ, Heys SD, Broom J, et al. Renal impairment associated with the pre-operative administration of recombinant interleukin-2. Clinical Science. 1994;87(5):513-8. Not patients with early CKD. [pmid: 7874838].
205 Deicher R, Horl WH. Anaemia as a risk factor for the progression of chronic kidney disease. Current Opinion in Nephrology & Hypertension. 2003;12(2):139-43. Not a randomized trial. [pmid: 12589173].
206 Delmez JA, Yan G, Bailey J, et al. Cerebrovascular disease in maintenance hemodialysis patients: results of the HEMO Study. American Journal of Kidney Diseases. 2006;47(1):131-8. Not patients with early CKD. [pmid: 16377394].
207 Dember LM, Hawkins PN, Hazenberg BPC, et al. Eprodisate for the treatment of renal disease in AA amyloidosis. New England Journal of Medicine. 2007;356(23):2349-60. Intervention not related to monitoring of CKD. [pmid: 17554116].
208 Depner TA, Keshaviah PR, Ebben JP, et al. Multicenter clinical validation of an on-line monitor of dialysis adequacy. Journal of the American Society of Nephrology. 1996;7(3):464-71. Not patients with early CKD. [pmid: 8704113].
209 Detournay B, Cros S, Charbonnel B, et al. Managing type 2 diabetes in France: the ECODIA survey. Diabetes & Metabolism. 2000;26(5):363-9. Not a randomized trial. [pmid: 11119015].
210 Devins GM, Hollomby DJ, Barre PE, et al. Long-term knowledge retention following predialysis psychoeducational intervention. Nephron. 2000;86(2):129-34. Not a randomized trial. [pmid: 11014981].
211 Devins GM, Mendelssohn DC, Barre PE, et al. Predialysis psychoeducational intervention and coping styles influence time to dialysis in chronic kidney disease. American Journal of Kidney Diseases. 2003;42(4):693-703. Intervention not related to monitoring of CKD. [pmid: 14520619].
212 Devins GM, Mendelssohn DC, Barre PE, et al. Predialysis psychoeducational intervention extends survival in CKD: a 20-year follow-up. American Journal of Kidney Diseases. 2005;46(6):1088-98. Intervention not related to monitoring of CKD. [pmid: 16310575].
213 Dijkman GA, Fernandez del Moral P, Debruyne FM, et al. Improved subjective responses to orchiectomy plus nilutamide (anandron) in comparison to orchiectomy plus placebo in metastatic prostate cancer. International Anandron Study Group. European Urology. 1995;27(3):196-201. Not a randomized trial. [pmid: 7601182].
214 Dimopoulos MA, Richardson PG, Schlag R, et al. VMP (Bortezomib, Melphalan, and Prednisone) is active and well tolerated in newly diagnosed patients with multiple myeloma with moderately impaired renal function, and results in reversal of renal impairment: cohort analysis of the phase III VISTA study. Journal of Clinical Oncology. 2009;27(36):6086-93. Intervention not related to monitoring of CKD. [pmid: 19858394].
215 Dittrich S, Kurschat K, Dahnert I, et al. Cyanotic nephropathy and use of non-ionic contrast agents during cardiac catherization in patients with cyanotic congenital heart disease. Cardiology in the Young. 2000;10(1):8-14. Not a randomized trial. [pmid: 10695534].
216 Doehn C, Richter A, Lehmacher W, et al. Adjuvant autologous tumour cell-lysate vaccine versus no adjuvant treatment in patients with M0 renal cell carcinoma after radical nephrectomy: 3-year interim analysis of a German multicentre phase-III trial. Folia Biologica. 2003;49(2):69-73. Intervention not related to monitoring of CKD. [pmid: 12779015].
217 Donadio JV, Bergstralh EJ, Bibus DM, et al. Is body size a biomarker for optimizing dosing of omega-3 polyunsaturated fatty acids in the treatment of patients with IgA nephropathy?. Clinical Journal of The American Society of Nephrology: CJASN. 2006;1(5):933-9. Intervention not related to monitoring of CKD. [pmid: 17699310].
218 Donadio JV, Grande JP. The role of fish oil/omega-3 fatty acids in the treatment of IgA nephropathy. Seminars in Nephrology. 2004;24(3):225-43. Not a randomized trial. [pmid: 15156528].
219 Donadio JV Jr., Grande JP, Bergstralh EJ, et al. The long-term outcome of patients with IgA nephropathy treated with fish oil in a controlled trial. Mayo Nephrology Collaborative Group. Journal of the American Society of Nephrology. 1999;10(8):1772-7. Intervention not related to monitoring of CKD. [pmid: 10446945].
220 Donskov F. Interleukin-2 based immunotherapy in patients with metastatic renal cell carcinoma. Danish Medical Bulletin. 2007;54(4):249-65. Not a randomized trial. [pmid: 18208677].
221 Dougados M, Awada H, Amor B. Cyclosporin in rheumatoid arthritis: a double blind, placebo controlled study in 52 patients. Annals of the Rheumatic Diseases. 1988;47(2):127-33. Intervention not related to monitoring of CKD. [pmid: 3281603].
222 Dougados M, Duchesne L, Awada H, et al. Assessment of efficacy and acceptability of low dose cyclosporin in patients with rheumatoid arthritis. Annals of the Rheumatic Diseases. 1989;48(7):550-6. Not patients with early CKD. [pmid: 2673081].
223 Douglas K, O'Malley PG, Jackson JL. Meta-analysis: the effect of statins on albuminuria. Annals of Internal Medicine. 2006;145(2):117-24. Not a randomized trial. [pmid: 16847294].
224 Dries DL, Exner DV, Domanski MJ, et al. The prognostic implications of renal insufficiency in asymptomatic and symptomatic patients with left ventricular systolic dysfunction. Journal of the American College of Cardiology. 2000;35(3):681-9. Not a randomized trial. [pmid: 10716471].
225 Drueke TB, Locatelli F, Clyne N, et al. Normalization of hemoglobin level in patients with chronic kidney disease and anemia. New England Journal of Medicine. 2006;355(20):2071-84. Not a randomized trial. [pmid: 17108342].
226 Dummer CD, Thome FS, Zingano B, et al. Acute effect of simvastatin on inflammation and oxidative stress in chronic kidney disease. Journal of Nephrology. 2008;21(6):900-8. Duration of follow-up less than 1 year. [pmid: 19034875].
227 Dundas S, Todd WT. Clinical presentation, complications and treatment of infection with verocytotoxin-producing Escherichia coli. Challenges for the clinician. Symposium Series/The Society for Applied Microbiology. 2000;(29):24S-30S. Not a randomized trial.
228 Dworkin LD, Gong R, Tolbert E, et al. Hepatocyte growth factor ameliorates progression of interstitial fibrosis in rats with established renal injury. Kidney International. 2004;65(2):409-19. Not human study. [pmid: 14717911].
229 Eardley KS, Lipkin GW. Atherosclerotic renal artery stenosis: is it worth diagnosing?. Journal of Human Hypertension. 1999;13(4):217-20. Not a randomized trial. [pmid: 10333337].
230 Ebbehoj E, Arildsen H, Hansen KW, et al. Effects of metoprolol on QT interval and QT dispersion in Type 1 diabetic patients with abnormal albuminuria. Diabetologia. 2004;47(6):1009-15. Intervention not related to monitoring of CKD. [pmid: 15184979].
231 Ebbehoj E, Poulsen PL, Hansen KW, et al. Effects on heart rate variability of metoprolol supplementary to ongoing ACE-inhibitor treatment in Type I diabetic patients with abnormal albuminuria. Diabetologia. 2002;45(7):965-75. Duration of follow-up less than 1 year. [pmid: 12136395].
232 Economides PA, Khaodhiar L, Caselli A, et al. The effect of vitamin E on endothelial function of micro- and macrocirculation and left ventricular function in type 1 and type 2 diabetic patients. Diabetes. 2005;54(1):204-11. Intervention not related to monitoring of CKD. [pmid: 15616030].
233 Edwards MS, Corriere MA. Contemporary management of atherosclerotic renovascular disease. Journal of Vascular Surgery. 2009;50(5):1197-210. Not a randomized trial. [pmid: 19595533].
234 Eidemak I, Haaber AB, Feldt-Rasmussen B, et al. Exercise training and the progression of chronic renal failure. Nephron. 1997;75(1):36-40. Not a randomized trial. [pmid: 9031268].
235 Eitner F, Ackermann D, Hilgers RD, et al. Supportive Versus Immunosuppressive Therapy of Progressive IgA nephropathy (STOP) IgAN trial: rationale and study protocol. Journal of Nephrology. 2008;21(3):284-9. Not a randomized trial. [pmid: 18587715].
236 Ejerblad E, Fored CM, Lindblad P, et al. Obesity and risk for chronic renal failure. Journal of the American Society of Nephrology. 2006;17(6):1695-702. Not a randomized trial. [pmid: 16641153].
237 El Kossi MMH, Ibrahim A, Lock TJ, et al. Impact of cardiac transplantation on kidney function: a single- center experience. Transplantation Proceedings. 2003;35(4):1527-31. Not a randomized trial. [pmid: 12826212].
238 Elsasser-Beile U, Kolble N, Grussenmeyer T, et al. Correlation of clinical and immunological parameters of metastatic renal cell carcinoma patients undergoing therapy with interleukin 2, interferon-alpha and retinoic acid. Anticancer Research. 1998;18(3B):1883-90. Not a randomized trial. [pmid: 9677439].
239 El-Sehemy MS, Al-Saaran AM, Baddour NM, et al. Comparative clinical prospective therapeutic study between cyclophosphamide, cyclosporine and azathioprine in the treatment of lupus nephritis. Egyptian Journal of Immunology/Egyptian Association of Immunologists. 2006;13(1):39-52. Less than 50 patients in study.
240 Endo K, Miyashita Y, Sasaki H, et al. Probucol delays progression of diabetic nephropathy. Diabetes Research & Clinical Practice. 2006;71(2):156-63. Intervention not related to monitoring of CKD. [pmid: 16009446].
241 Epstein M. The benefits of ACE inhibitors and calcium antagonists in slowing progressive renal failure: focus on fixed-dose combination antihypertensive therapy. Renal Failure. 1996;18(6):813-32. Not a randomized trial. [pmid: 8948517].
242 Epstein M. Calcium antagonists and renal protection: emerging perspectives. Journal of Hypertension - Supplement. 1998;16(4):S17-25. Not a randomized trial.
243 Epstein M. Aldosterone as a mediator of progressive renal dysfunction: evolving perspectives. Internal Medicine. 2001;40(7):573-83. Not a randomized trial. [pmid: 11506295].
244 Epstein M. Aldosterone and the hypertensive kidney: its emerging role as a mediator of progressive renal dysfunction: a paradigm shift. Journal of Hypertension. 2001;19(5):829-42. Not a randomized trial. [pmid: 11393664].
245 Escudier B, Eisen T, Stadler WM, et al. Sorafenib in advanced clear-cell renal-cell carcinoma. [Erratum appears in N Engl J Med. 2007 Jul 12;357(2):203]. New England Journal of Medicine. 2007;356(2):125-34. Intervention not related to monitoring of CKD. [pmid: 17215530].
246 Esmail ZN, Loewen PS. Losartan as an alternative to ACE inhibitors in patients with renal dysfunction. Annals of Pharmacotherapy. 1998;32(10):1096-8. Not a randomized trial. [pmid: 9793603].
247 Estacio RO, Coll JR, Tran ZV, et al. Effect of intensive blood pressure control with valsartan on urinary albumin excretion in normotensive patients with type 2 diabetes. American Journal of Hypertension. 2006;19(12):1241-8. Intervention not related to monitoring of CKD. [pmid: 17161769].
248 Ewald B, Attia J. Which test to detect microalbuminuria in diabetic patients? A systematic review. Aust Fam Physician. 2004;33(7):565-7. 71. Not a randomized trial. [pmid: 15301181].
249 Facchini FS, Saylor KL. A low-iron-available, polyphenol-enriched, carbohydrate-restricted diet to slow progression of diabetic nephropathy. Diabetes. 2003;52(5):1204-9. Intervention not related to monitoring of CKD. [pmid: 12716753].
250 Fagnani F, Souchet T, Labed D, et al. Management of hypertension and screening of renal complications by GPs in diabetic type 2 patients (France--2001). Diabetes & Metabolism. 2003;29(1):58-64. Not a randomized trial. [pmid: 12629449].
251 Farace F, Pallardy M, Angevin E, et al. Metastatic renal-cell carcinoma patients treated with interleukin 2 or interleukin 2 plus interferon gamma: immunological monitoring. International Journal of Cancer. 1994;57(6):814-21. Not a randomized trial.
252 Farbakhsh K, Kasiske BL. Dyslipidemias in patients who have chronic kidney disease. Medical Clinics of North America. 2005;89(3):689-99. Not a randomized trial. [pmid: 15755473].
253 Fassett RG, Ball MJ, Robertson IK, et al. The Lipid lowering and Onset of Renal Disease (LORD) Trial: a randomized double blind placebo controlled trial assessing the effect of atorvastatin on the progression of kidney disease. BMC Nephrology. 2008;9:4. Not a randomized trial. [pmid: 18366658].
254 Faull RJ, Russ GR. Tubular expression of intercellular adhesion molecule-1 during renal allograft rejection. Transplantation. 1989;48(2):226-30. Not a randomized trial. [pmid: 2667205].
255 Fayers PM, Cook PA, Machin D, et al. On the development of the Medical Research Council trial of alpha-interferon in metastatic renal carcinoma. Urological Working Party Renal Carcinoma Subgroup. Statistics in Medicine. 1994;13(21):2249-60. Not a randomized trial. [pmid: 7846423].
256 Ferramosca E, Burke S, Chasan-Taber S, et al. Potential antiatherogenic and anti-inflammatory properties of sevelamer in maintenance hemodialysis patients. American Heart Journal. 2005;149(5):820-5. Intervention not related to monitoring of CKD. [pmid: 15894962].
257 Ficarra V, Galfano A, Novara G, et al. Risk stratification and prognostication of renal cell carcinoma. World Journal of Urology. 2008;26(2):115-25. Not a randomized trial. [pmid: 18392834].
258 Fifer MA, Molina CR, Quiroz AC, et al. Hemodynamic and renal effects of atrial natriuretic peptide in congestive heart failure. American Journal of Cardiology. 1990;65(3):211-6. Intervention not related to monitoring of CKD. [pmid: 2136969].
259 Figlin RA, Thompson JA, Bukowski RM, et al. Multicenter, randomized, phase III trial of CD8(+) tumor-infiltrating lymphocytes in combination with recombinant interleukin-2 in metastatic renal cell carcinoma. Journal of Clinical Oncology. 1999;17(8):2521-9. Intervention not related to monitoring of CKD. [pmid: 10561318].
260 Finn WF, Joy MS, Group LAMS. A long-term, open-label extension study on the safety of treatment with lanthanum carbonate, a new phosphate binder, in patients receiving hemodialysis. Current Medical Research & Opinion. 2005;21(5):657-64. Not patients with early CKD. [pmid: 15969865].
261 Fischer U, Salzsieder E, Menzel R, et al. Primary health care of diabetic patients in a specialized outpatient setting: a DIABCARE-based analysis. Diabete et Metabolisme. 1993;19(1 Pt 2):188-94. Not a randomized trial. [pmid: 8314425].
262 Fitts SS, Guthrie MR, Blagg CR. Exercise coaching and rehabilitation counseling improve quality of life for predialysis and dialysis patients. Nephron. 1999;82(2):115-21. Less than 50 patients in study. [pmid: 10364702].
263 Flaherty KT. Sorafenib in renal cell carcinoma. Clinical Cancer Research. 2007;13(2 Pt 2):747s-52s. Not a randomized trial. [pmid: 17255304].
264 Flaherty KT, Rosen MA, Heitjan DF, et al. Pilot study of DCE-MRI to predict progression-free survival with sorafenib therapy in renal cell carcinoma. Cancer Biology & Therapy. 2008;7(4):496-501. Not a randomized trial. [pmid: 18219225].
265 Flechner SM. Sirolimus in kidney transplantation indications and practical guidelines: de novo sirolimus-based therapy without calcineurin inhibitors. Transplantation. 2009;87(8 Suppl):S1-6. Not a randomized trial. [pmid: 19384179].
266 Fliser D, Haller H. Angiotensin II subtype 1-receptor antagonists in the treatment of diabetic nephropathy. Journal of Hypertension - Supplement. 2001;19(1):S57-60. Not a randomized trial.
267 Floege J, Eitner F. Present and future therapy options in IgA-nephropathy. Journal of Nephrology. 2005;18(4):354-61. Not a randomized trial. [pmid: 16245237].
268 Forastiere AA, Belliveau JF, Goren MP, et al. Pharmacokinetic and toxicity evaluation of five-day continuous infusion versus intermittent bolus cis-diamminedichloroplatinum(II) in head and neck cancer patients. Cancer Research. 1988;48(13):3869-74. Not a randomized trial. [pmid: 3378222].
269 Fouque D, Aparicio M. Eleven reasons to control the protein intake of patients with chronic kidney disease. Nature Clinical Practice Nephrology. 2007;3(7):383-92. Not a randomized trial.
270 Fouque D, Laville M. Low protein diets for chronic kidney disease in non diabetic adults. Cochrane Database of Systematic Reviews. 2009;(3):CD001892. Intervention not related to monitoring of CKD. [pmid: 19588328].
271 Fouque D, Laville M, Boissel JP. Low protein diets for chronic kidney disease in non diabetic adults. Cochrane Database of Systematic Reviews. 2006;(2):CD001892. Intervention not related to monitoring of CKD. [pmid: 16625550].
272 Fox CH, Brooks A, Zayas LE, et al. Primary care physicians' knowledge and practice patterns in the treatment of chronic kidney disease: an Upstate New York Practice-based Research Network (UNYNET) study. Journal of the American Board of Family Medicine: JABFM. 2006;19(1):54-61. Not a randomized trial. [pmid: 16492006].
273 Freedman BI, Hicks PJ, Sale MM, et al. A leucine repeat in the carnosinase gene CNDP1 is associated with diabetic end-stage renal disease in European Americans. Nephrology Dialysis Transplantation. 2007;22(4):1131-5. Not a randomized trial.
274 Fried LF, Duckworth W, Zhang JH, et al. Design of combination angiotensin receptor blocker and angiotensin-converting enzyme inhibitor for treatment of diabetic nephropathy (VA NEPHRON-D). Clinical Journal of The American Society of Nephrology: CJASN. 2009;4(2):361-8. Not a randomized trial. [pmid: 19118120].
275 Fried LF, Forrest KY, Ellis D, et al. Lipid modulation in insulin-dependent diabetes mellitus: effect on microvascular outcomes. Journal of Diabetes & its Complications. 2001;15(3):113-9. Intervention not related to monitoring of CKD. [pmid: 11358679].
276 Fung MA, Warnock GL, Ao Z, et al. The effect of medical therapy and islet cell transplantation on diabetic nephropathy: an interim report. Transplantation. 2007;84(1):17-22. Not a randomized trial. [pmid: 17627232].
277 Furumatsu Y, Nagasawa Y, Tomida K, et al. Effect of renin-angiotensin-aldosterone system triple blockade on non-diabetic renal disease: addition of an aldosterone blocker, spironolactone, to combination treatment with an angiotensin-converting enzyme inhibitor and angiotensin II receptor blocker. Hypertension Research - Clinical & Experimental. 2008;31(1):59-67. Intervention not related to monitoring of CKD.
278 Furuta T, Hotta O, Horigome I, et al. Decreased CD4 lymphocyte count as a marker predicting high mortality rate in managing ANCA related rapidly progressive glomerulonephritis. Nephron. 2002;91(4):601-5. Not a randomized trial. [pmid: 12138261].
279 Gaede P, Hansen HP, Parving HH, et al. Impact of low-dose acetylsalicylic acid on kidney function in type 2 diabetic patients with elevated urinary albumin excretion rate. Nephrology Dialysis Transplantation. 2003;18(3):539-42. Duration of follow-up less than 1 year.
280 Gaede P, Vedel P, Parving HH, et al. Intensified multifactorial intervention in patients with type 2 diabetes mellitus and microalbuminuria: the Steno type 2 randomised study. Lancet. 1999;353(9153):617-22. Intervention not related to monitoring of CKD. [pmid: 10030326].
281 Gainer JV, Lipkowitz MS, Yu C, et al. Association of a CYP4A11 variant and blood pressure in black men. Journal of the American Society of Nephrology. 2008;19(8):1606-12. Intervention not related to monitoring of CKD. [pmid: 18385420].
282 Garcia-Tsao G, Lim JK, Members of Veterans Affairs Hepatitis CRCP. Management and treatment of patients with cirrhosis and portal hypertension: recommendations from the Department of Veterans Affairs Hepatitis C Resource Center Program and the National Hepatitis C Program. American Journal of Gastroenterology. 2009;104(7):1802-29. Not a randomized trial. [pmid: 19455106].
283 Gemperle O, Neuweiler J, Reutter FW, et al. Familial glomerulopathy with giant fibrillar (fibronectin-positive) deposits: 15-year follow-up in a large kindred. American Journal of Kidney Diseases. 1996;28(5):668-75. Not a randomized trial. [pmid: 9158203].
284 Germain DP, Waldek S, Banikazemi M, et al. Sustained, long-term renal stabilization after 54 months of agalsidase beta therapy in patients with Fabry disease. Journal of the American Society of Nephrology. 2007;18(5):1547-57. Intervention not related to monitoring of CKD. [pmid: 17409312].
285 Gerth WC, Remuzzi G, Viberti G, et al. Losartan reduces the burden and cost of ESRD: public health implications from the RENAAL study for the European Union. Kidney International - Supplement. 2002;(82):S68-72. Not a randomized trial. [pmid: 12410859].
286 Giatras I, Lau J, Levey AS. Effect of angiotensin-converting enzyme inhibitors on the progression of nondiabetic renal disease: a meta-analysis of randomized trials. Angiotensin-Converting-Enzyme Inhibition and Progressive Renal Disease Study Group. Annals of Internal Medicine. 1997;127(5):337-45. Not a randomized trial. [pmid: 9273824].
287 Gillis BP, Caggiula AW, Chiavacci AT, et al. Nutrition intervention program of the Modification of Diet in Renal Disease Study: a self-management approach. Journal of the American Dietetic Association. 1995;95(11):1288-94. Intervention not related to monitoring of CKD. [pmid: 7594125].
288 Glassock RJ. Glomerular therapeutics: looking back, looking forward. Heart Disease. 2001;3(4):276-81. Not a randomized trial. [pmid: 11975805].
289 Gleave ME, Elhilali M, Fradet Y, et al. Interferon gamma-1b compared with placebo in metastatic renal-cell carcinoma. Canadian Urologic Oncology Group. New England Journal of Medicine. 1998;338(18):1265-71. Intervention not related to monitoring of CKD. [pmid: 9562580].
290 Gonwa T, Mendez R, Yang HC, et al. Randomized trial of tacrolimus in combination with sirolimus or mycophenolate mofetil in kidney transplantation: results at 6 months. Transplantation. 2003;75(8):1213-20. Not patients with early CKD. [pmid: 12717205].
291 Gonzalez Vitores AM, Encabo Duro G, Bermejo Fraile B, et al. Utility of tumor marker CA 72.4 in patients with chronic renal failure. International Journal of Biological Markers. 1999;14(2):118-21. Not a randomized trial. [pmid: 10399632].
292 Gonzalgo ML, Eisenberger CF, Lee SM, et al. Prognostic significance of preoperative molecular serum analysis in renal cancer. Clinical Cancer Research. 2002;8(6):1878-81. Not a randomized trial. [pmid: 12060631].
293 Gore ME, Escudier B. Emerging efficacy endpoints for targeted therapies in advanced renal cell carcinoma. Oncology. 2006;20(6 Suppl 5):19-24. Not a randomized trial. [pmid: 16773841].
294 Gouva C, Nikolopoulos P, Ioannidis JPA, et al. Treating anemia early in renal failure patients slows the decline of renal function: a randomized controlled trial. Kidney International. 2004;66(2):753-60. Intervention not related to monitoring of CKD. [pmid: 15253730].
295 Grabe DW, Garrison GD. Comparison of natural product use between primary care and nephrology patients. Annals of Pharmacotherapy. 2004;38(7-8):1169-72. Not a randomized trial. [pmid: 15187203].
296 Gray DW, Richardson A, Hughes D, et al. A prospective, randomized, blind comparison of three biopsy techniques in the management of patients after renal transplantation. Transplantation. 1992;53(6):1226-32. Not patients with early CKD. [pmid: 1376503].
297 Groetzner J, Wittwer T, Kaczmarek I, et al. Conversion to sirolimus and mycophenolate can attenuate the progression of bronchiolitis obliterans syndrome and improves renal function after lung transplantation. Transplantation. 2006;81(3):355-60. Not a randomized trial. [pmid: 16477220].
298 Grootscholten C, Bajema IM, Florquin S, et al. Treatment with cyclophosphamide delays the progression of chronic lesions more effectively than does treatment with azathioprine plus methylprednisolone in patients with proliferative lupus nephritis. Arthritis & Rheumatism. 2007;56(3):924-37. Intervention not related to monitoring of CKD. [pmid: 17328070].
299 Grootscholten C, Dieker JWC, McGrath FD, et al. A prospective study of anti-chromatin and anti-C1q autoantibodies in patients with proliferative lupus nephritis treated with cyclophosphamide pulses or azathioprine/methylprednisolone. Annals of the Rheumatic Diseases. 2007;66(5):693-6. Intervention not related to monitoring of CKD. [pmid: 17135217].
300 Group ACEIiDNT. Should all patients with type 1 diabetes mellitus and microalbuminuria receive angiotensin-converting enzyme inhibitors? A meta-analysis of individual patient data. Annals of Internal Medicine. 2001;134(5):370-9. Not a randomized trial. [pmid: 11242497].
301 Guitterez NV, Diaz A, Timmis GC, et al. Determinants of serum creatinine trajectory in acute contrast nephropathy. Journal of Interventional Cardiology. 2002;15(5):349-54. Intervention not related to monitoring of CKD. [pmid: 12440177].
302 Gurley SB, Coffman TM. The renin-angiotensin system and diabetic nephropathy. Seminars in Nephrology. 2007;27(2):144-52. Not a randomized trial. [pmid: 17418683].
303 Guy JM, Brammah TB, Holt L, et al. Urinary excretion of albumin and retinol binding protein in systemic lupus erythematosus. Annals of Clinical Biochemistry. 1997;34(Pt 6):668-74. Not a randomized trial. [pmid: 9367006].
304 Guy M, Newall R, Borzomato J, et al. Use of a first-line urine protein-to-creatinine ratio strip test on random urines to rule out proteinuria in patients with chronic kidney disease. Nephrology Dialysis Transplantation. 2009;24(4):1189-93. Not a randomized trial.
305 Haider DG, Fuhrmann H, Kovarik J, et al. Postprandial intradialytic dysglycaemia and diabetes in maintenance haemodialysis patients. European Journal of Clinical Investigation. 2008;38(10):721-7. Not a randomized trial. [pmid: 18837797].
306 Hall AM, Edwards SG, Lapsley M, et al. Subclinical tubular injury in HIV-infected individuals on antiretroviral therapy: a cross-sectional analysis. American Journal of Kidney Diseases. 2009;54(6):1034-42. Not a randomized trial. [pmid: 19783343].
307 Halstenson CE, Wong MO, Herman CS, et al. Effect of concomitant administration of piperacillin on the dispositions of isepamicin and gentamicin in patients with end-stage renal disease. Antimicrobial Agents & Chemotherapy. 1992;36(9):1832-6. Not a randomized trial. [pmid: 1416875].
308 Han H, Bleyer AJ, Houser RF, et al. Dialysis and nutrition practices in Korean hemodialysis centers. Journal of Renal Nutrition. 2002;12(1):42-8. Not a randomized trial. [pmid: 11823993].
309 Hansen HP, Gaede PH, Jensen BR, et al. Lack of impact of low-dose acetylsalicylic acid on kidney function in type 1 diabetic patients with microalbuminuria. Diabetes Care. 2000;23(12):1742-5. Duration of follow-up less than 1 year. [pmid: 11128344].
310 Harris DCH, Rangan GK. Retardation of kidney failure -- applying principles to practice. Annals of the Academy of Medicine, Singapore. 2005;34(1):16-23. Not a randomized trial.
311 Haupt MT, Jastremski MS, Clemmer TP, et al. Effect of ibuprofen in patients with severe sepsis: a randomized, double-blind, multicenter study. The Ibuprofen Study Group. Critical Care Medicine. 1991;19(11):1339-47. Intervention not related to monitoring of CKD. [pmid: 1935150].
312 Havenetidis K, Bourdas D. Creatine supplementation: effects on urinary excretion and anaerobic performance. Journal of Sports Medicine & Physical Fitness. 2003;43(3):347-55. Less than 50 patients in study. [pmid: 14625517].
313 Hayes JK, Stanley TH, Lind GH, et al. A double-blind study to evaluate the safety of recombinant human hemoglobin in surgical patients during general anesthesia. Journal of Cardiothoracic & Vascular Anesthesia. 2001;15(5):593-602. Intervention not related to monitoring of CKD. [pmid: 11688001].
314 Hebert LA, Kusek JW, Greene T, et al. Effects of blood pressure control on progressive renal disease in blacks and whites. Modification of Diet in Renal Disease Study Group. Hypertension. 1997;30(3 Pt 1):428-35. Intervention not related to monitoring of CKD. [pmid: 9314428].
315 Hebert LA, Wilmer WA, Falkenhain ME, et al. Renoprotection: one or many therapies?. Kidney International. 2001;59(4):1211-26. Intervention not related to monitoring of CKD. [pmid: 11260381].
316 Hedayat S, Kershner RP, Su G. Relationship of whole-blood FK506 concentrations to rejection and toxicity in liver and kidney transplants. Journal of Biopharmaceutical Statistics. 1996;6(4):411-24. Not patients with early CKD. [pmid: 8969977].
317 Heering P, Morgera S, Schmitz FJ, et al. Cytokine removal and cardiovascular hemodynamics in septic patients with continuous venovenous hemofiltration. Intensive Care Medicine. 1997;23(3):288-96. Not a randomized trial. [pmid: 9083231].
318 Herlitz H, Harris K, Risler T, et al. The effects of an ACE inhibitor and a calcium antagonist on the progression of renal disease: the Nephros Study. Nephrology Dialysis Transplantation. 2001;16(11):2158-65. Intervention not related to monitoring of CKD.
319 Hernandez-Herrera G, Martin-Malo A, Rodriguez M, et al. Assessment of the length of each hemodialysis session by on-line dialysate urea monitoring. Nephron. 2001;89(1):37-42. Not patients with early CKD. [pmid: 11528230].
320 Higashihara E, Nutahara K, Horie S, et al. The effect of eicosapentaenoic acid on renal function and volume in patients with ADPKD. Nephrology Dialysis Transplantation. 2008;23(9):2847-52. Intervention not related to monitoring of CKD.
321 Hilton R, Tong CYW. Antiviral therapy for polyomavirus-associated nephropathy after renal transplantation. Journal of Antimicrobial Chemotherapy. 2008;62(5):855-9. Not a randomized trial. [pmid: 18658193].
322 Himmelfarb J, Tolkoff Rubin N, Chandran P, et al. A multicenter comparison of dialysis membranes in the treatment of acute renal failure requiring dialysis. Journal of the American Society of Nephrology. 1998;9(2):257-66. Not a randomized trial. [pmid: 9527402].
323 Hiremath S, Fergusson D, Doucette S, et al. Renin angiotensin system blockade in kidney transplantation: a systematic review of the evidence. American Journal of Transplantation. 2007;7(10):2350-60. Not a randomized trial. [pmid: 17845569].
324 Hirth RA, Turenne MN, Wheeler JRC, et al. Provider monitoring and pay-for-performance when multiple providers affect outcomes: An application to renal dialysis. Health Services Research. 2009;44(5 Pt 1):1585-602. Not a randomized trial. [pmid: 19555398].
325 Hogan TJ, Elliott WJ, Seto AH, et al. Antihypertensive treatment with and without benazepril in patients with chronic renal insufficiency: a US economic evaluation. Pharmacoeconomics. 2002;20(1):37-47. Not a randomized trial. [pmid: 11817991].
326 Hollenberg NK. Aldosterone in the development and progression of renal injury. Kidney International. 2004;66(1):1-9. Not a randomized trial. [pmid: 15200407].
327 Holm T, Andreassen AK, Aukrust P, et al. Omega-3 fatty acids improve blood pressure control and preserve renal function in hypertensive heart transplant recipients. European Heart Journal. 2001;22(5):428-36. Less than 50 patients in study. [pmid: 11207085].
328 Hong SJ, Cho KS, Cho HY, et al. A prospective, multicenter, open-label trial of zoledronic acid in patients with hormone refractory prostate cancer. Yonsei Medical Journal. 2007;48(6):1001-8. Not a randomized trial. [pmid: 18159593].
329 Hor T, Baldwin D. Urinary albumin excretion in patients with diabetes after renal transplantation. Transplantation Proceedings. 2006;38(9):2879-82. Not patients with early CKD. [pmid: 17112854].
330 Hou FF, Zhang X, Zhang GH, et al. Efficacy and safety of benazepril for advanced chronic renal insufficiency. New England Journal of Medicine. 2006;354(2):131-40. Intervention not related to monitoring of CKD. [pmid: 16407508].
331 Hu W, Liu C, Xie H, et al. Mycophenolate mofetil versus cyclophosphamide for inducing remission of ANCA vasculitis with moderate renal involvement. Nephrology Dialysis Transplantation. 2008;23(4):1307-12. Less than 50 patients in study.
332 Huland E, Heinzer H, Huland H. Treatment of pulmonary metastatic renal-cell carcinoma in 116 patients using inhaled interleukin-2 (IL-2). Anticancer Research. 1999;19(4A):2679-83. Not a randomized trial. [pmid: 10470219].
333 Hunsicker LG, Adler S, Caggiula A, et al. Predictors of the progression of renal disease in the Modification of Diet in Renal Disease Study. Kidney International. 1997;51(6):1908-19. Not a randomized trial. [pmid: 9186882].
334 Huskey J, Lindenfeld J, Cook T, et al. Effect of simvastatin on kidney function loss in patients with coronary heart disease: findings from the Scandinavian Simvastatin Survival Study (4S). Atherosclerosis. 2009;205(1):202-6. Intervention not related to monitoring of CKD. [pmid: 19124121].
335 Hutson TE, Davis ID, Machiels JP, et al. Efficacy and safety of pazopanib in patients with metastatic renal cell carcinoma. Journal of Clinical Oncology. 2010;28(3):475-80. Not a randomized trial. [pmid: 20008644].
336 Iaria G, Pisani F, Iorio B, et al. Long-term results of kidney transplantation with cyclosporine- and everolimus-based immunosuppression. Transplantation Proceedings. 2006;38(4):1018-9. Not patients with early CKD. [pmid: 16757249].
337 Ibsen H, Olsen MH, Wachtell K, et al. Reduction in albuminuria translates to reduction in cardiovascular events in hypertensive patients: losartan intervention for endpoint reduction in hypertension study. Hypertension. 2005;45(2):198-202. Intervention not related to monitoring of CKD. [pmid: 15655123].
338 Ideura T, Shimazui M, Morita H, et al. Protein intake of more than 0.5 g/kg BW/day is not effective in suppressing the progression of chronic renal failure. Contributions to Nephrology. 2007;155:40-9. Not a randomized trial. [pmid: 17369712].
339 Ihle BU, Whitworth JA, Shahinfar S, et al. Angiotensin-converting enzyme inhibition in nondiabetic progressive renal insufficiency: a controlled double-blind trial. American Journal of Kidney Diseases. 1996;27(4):489-95. Intervention not related to monitoring of CKD. [pmid: 8678058].
340 Ikuerowo SO, Kuczyk MA, Mengel M, et al. Alteration of subcellular and cellular expression patterns of cyclin B1 in renal cell carcinoma is significantly related to clinical progression and survival of patients. International Journal of Cancer. 2006;119(4):867-74. Not a randomized trial.
341 Imamura R, Ichimaru N, Moriyama T, et al. Long term efficacy of simvastatin in renal transplant recipients treated with cyclosporine or tacrolimus. Clinical Transplantation. 2005;19(5):616-21. Not a randomized trial. [pmid: 16146552].
342 Inoue S, Tomino Y. Effects of calcium antagonists in hypertensive patients with renal dysfunction: a prospective, randomized, parallel trial comparing benidipine and nifedipine. Nephrology. 2004;9(5):265-71. Intervention not related to monitoring of CKD. [pmid: 15504138].
343 Inrig JK, Patel UD, Gillespie BS, et al. Relationship between interdialytic weight gain and blood pressure among prevalent hemodialysis patients. American Journal of Kidney Diseases. 2007;50(1):108-18. Not a randomized trial. [pmid: 17591530].
344 Investigators RS, Bellomo R, Cass A, et al. Design and challenges of the Randomized Evaluation of Normal versus Augmented Level Replacement Therapy (RENAL) Trial: high-dose versus standard-dose hemofiltration in acute renal failure. Blood Purification. 2008;26(5):407-16. Not patients with early CKD. [pmid: 18856012].
345 Ishani A, Grandits GA, Grimm RH, et al. Association of single measurements of dipstick proteinuria, estimated glomerular filtration rate, and hematocrit with 25-year incidence of end-stage renal disease in the multiple risk factor intervention trial. Journal of the American Society of Nephrology. 2006;17(5):1444-52. Not a randomized trial. [pmid: 16611715].
346 Ishani A, Paudel M, Taylor BC, et al. Renal function and rate of hip bone loss in older men: the Osteoporotic Fractures in Men Study. Osteoporosis International. 2008;19(11):1549-56. Not a randomized trial. [pmid: 18392664].
347 Ishani A, Xue JL, Himmelfarb J, et al. Acute kidney injury increases risk of ESRD among elderly. Journal of the American Society of Nephrology. 2009;20(1):223-8. Not a randomized trial. [pmid: 19020007].
348 Ishida H, Satou T, Tsuji K, et al. The breath ammonia measurement of the hemodialysis with a QCM-NH3 sensor. Bio-Medical Materials & Engineering. 2008;18(2):99-106. Not a randomized trial. [pmid: 18408261].
349 Ishikawa J, Hoshide S, Shibasaki S, et al. The Japan Morning Surge-1 (JMS-1) study: protocol description. [Erratum appears in Hypertens Res. 2006 Sep;29(9):739]. Hypertension Research - Clinical & Experimental. 2006;29(3):153-9. Intervention not related to monitoring of CKD.
350 Ix JH, Shlipak MG, Sarnak MJ, et al. Fetuin-A is not associated with mortality in chronic kidney disease. Kidney International. 2007;72(11):1394-9. Not a randomized trial. [pmid: 17882149].
351 Jacobs C, Frei D, Perkins AC. Results of the European Survey on Anaemia Management 2003 (ESAM 2003): current status of anaemia management in dialysis patients, factors affecting epoetin dosage and changes in anaemia management over the last 5 years. Nephrology Dialysis Transplantation. Suppl 3. 2005;20:iii3-24. Not a randomized trial.
352 Jafar TH, Schmid CH, Landa M, et al. Angiotensin-converting enzyme inhibitors and progression of nondiabetic renal disease. A meta-analysis of patient-level data. [Erratum appears in Ann Intern Med 2002 Aug 20;137(4):299]. Annals of Internal Medicine. 2001;135(2):73-87. Intervention not related to monitoring of CKD. [pmid: 11453706].
353 Jafar TH, Schmid CH, Stark PC, et al. The rate of progression of renal disease may not be slower in women compared with men: a patient-level meta-analysis. Nephrology Dialysis Transplantation. 2003;18(10):2047-53. Not a randomized trial.
354 Jafar TH, Stark PC, Schmid CH, et al. Progression of chronic kidney disease: the role of blood pressure control, proteinuria, and angiotensin-converting enzyme inhibition: a patient-level meta-analysis. Annals of Internal Medicine. 2003;139(4):244-52. Intervention not related to monitoring of CKD. [pmid: 12965979].
355 Jafar TH, Stark PC, Schmid CH, et al. Proteinuria as a modifiable risk factor for the progression of non-diabetic renal disease. Kidney International. 2001;60(3):1131-40. Intervention not related to monitoring of CKD. [pmid: 11532109].
356 Jain L, Venitz J, Figg WD. Randomized discontinuation trial of sorafenib (BAY 43-9006). Cancer Biology & Therapy. 2006;5(10):1270-2. Not a randomized trial. [pmid: 16969070].
357 Jandeleit-Dahm K, Cao Z, Cox AJ, et al. Role of hyperlipidemia in progressive renal disease: focus on diabetic nephropathy. Kidney International - Supplement. 1999;71:S31-6. Not human study. [pmid: 10412733].
358 Jayne D. Challenges in the management of microscopic polyangiitis: past, present and future. Current Opinion in Rheumatology. 2008;20(1):3-9. Not a randomized trial. [pmid: 18281850].
359 Jensen NF, Todd MM, Block RI, et al. The efficacy of routine central venous monitoring in major head and neck surgery: a retrospective review. Journal of Clinical Anesthesia. 1995;7(2):119-25. Not a randomized trial. [pmid: 7598919].
360 Jeon SH, Chang SG, Kim JI. The role of adjuvant immunotherapy after radical nephrectomy and prognostic factors in pT3N0M0 renal cell carcinoma. Anticancer Research. 1999;19(6C):5593-7. Not patients with early CKD. [pmid: 10697624].
361 Jerums G, Allen TJ, Campbell DJ, et al. Long-term renoprotection by perindopril or nifedipine in non-hypertensive patients with Type 2 diabetes and microalbuminuria. Diabetic Medicine. 2004;21(11):1192-9. Intervention not related to monitoring of CKD. [pmid: 15498085].
362 Jin KK, Chen L, Pan JY, et al. Acupressure therapy inhibits the development of diabetic complications in Chinese patients with type 2 diabetes. Journal of Alternative & Complementary Medicine. 2009;15(9):1027-32. Intervention not related to monitoring of CKD.
363 Johnson CA, McCarthy J, Bailie GR, et al. Analysis of renal bone disease treatment in dialysis patients. American Journal of Kidney Diseases. 2002;39(6):1270-7. Not a randomized trial. [pmid: 12046041].
364 Johnson DW. Evidence-based guide to slowing the progression of early renal insufficiency. Internal Medicine Journal. 2004;34(1-2):50-7. Intervention not related to monitoring of CKD. [pmid: 14748914].
365 Johnson DW. Dietary protein restriction as a treatment for slowing chronic kidney disease progression: the case against. Nephrology. 2006;11(1):58-62. Not a randomized trial. [pmid: 16509934].
366 Jorres A. Acute renal failure. Extracorporeal treatment strategies. Minerva Medica. 2002;93(5):329-4. Not a randomized trial. [pmid: 12410165].
367 Jorres A. Extracorporeal treatment strategy in acute renal failure. International Journal of Artificial Organs. 2002;25(5):391-6. Not a randomized trial. [pmid: 12074336].
368 Jose P, Skali H, Anavekar N, et al. Increase in creatinine and cardiovascular risk in patients with systolic dysfunction after myocardial infarction. Journal of the American Society of Nephrology. 2006;17(10):2886-91. Intervention not related to monitoring of CKD. [pmid: 16928807].
369 Joss N, Jardine A, Gaffney D, et al. Influence of apolipoprotein E genotype on progression of diabetic nephropathy. Nephron. Experimental Nephrology. 2005;101(4):e127-33. Not a randomized trial. [pmid: 16113584].
370 Jungers P, Choukroun G, Oualim Z, et al. Beneficial influence of recombinant human erythropoietin therapy on the rate of progression of chronic renal failure in predialysis patients. Nephrology Dialysis Transplantation. 2001;16(2):307-12. Not a randomized trial.
371 Kadowaki D, Anraku M, Tasaki Y, et al. Effect of olmesartan on oxidative stress in hemodialysis patients. Hypertension Research - Clinical & Experimental. 2007;30(5):395-402. Not patients with early CKD.
372 Kahan BD, Dunn J, Fitts C, et al. Reduced inter- and intrasubject variability in cyclosporine pharmacokinetics in renal transplant recipients treated with a microemulsion formulation in conjunction with fasting, low-fat meals, or high-fat meals. Transplantation. 1995;59(4):505-11. Not patients with early CKD. [pmid: 7878754].
373 Kalpoe JS, Schippers EF, Eling Y, et al. Similar reduction of cytomegalovirus DNA load by oral valganciclovir and intravenous ganciclovir on pre-emptive therapy after renal and renal-pancreas transplantation. Antiviral Therapy. 2005;10(1):119-23. Not a randomized trial. [pmid: 15751769].
374 Kamgar M, Nobakhthaghighi N, Shamshirsaz AA, et al. Impaired fibrinolytic activity in type II diabetes: correlation with urinary albumin excretion and progression of renal disease. Kidney International. 2006;69(10):1899-903. Not a randomized trial. [pmid: 16598198].
375 Kamper AL, Holstein-Rathlou NH, Leyssac PP, et al. The influence of angiotensin-converting enzyme inhibition on renal tubular function in progressive chronic nephropathy. American Journal of Kidney Diseases. 1996;28(6):822-31. Intervention not related to monitoring of CKD. [pmid: 8957033].
376 Kaneko K, Someya T, Nishizaki N, et al. Simplified quantification of urinary protein excretion using a novel dipstick in children. Pediatric Nephrology. 2005;20(6):834-6. Not adult population. [pmid: 15778846].
377 Kanno Y, Okada H, Yamaji Y, et al. Angiotensin-converting-enzyme inhibitors slow renal decline in IgA nephropathy, independent of tubulointerstitial fibrosis at presentation. Qjm. 2005;98(3):199-203. Intervention not related to monitoring of CKD. [pmid: 15728401].
378 Kaplan AA. Therapeutic apheresis for cancer related hemolytic uremic syndrome. Therapeutic Apheresis. 2000;4(3):201-6. Intervention not related to monitoring of CKD. [pmid: 10910020].
379 Kaplan B, Wang Z, Keilani T, et al. The specificity of monoclonal fluorescence polarization immunoassay for cyclosporine in recipients of simultaneous pancreas-kidney transplants. Therapeutic Drug Monitoring. 1995;17(5):499-503. Intervention not related to monitoring of CKD. [pmid: 8585113].
380 Kasahara J, Kobayashi K, Maeshima Y, et al. Clinical significance of serum oxidized low-density lipoprotein/beta2-glycoprotein I complexes in patients with chronic renal diseases. Nephron. 2004;98(1):c15-24. Intervention not related to monitoring of CKD. [pmid: 15361700].
381 Kasimu H, Jakai T, Qilong C, et al. A brief evaluation for pre-estimating the severity of gallstone pancreatitis. Jop: Journal of the Pancreas [Electronic Resource]. 2009;10(2):147-51. Intervention not related to monitoring of CKD.
382 Kasiske BL, Heim-Duthoy K, Rao KV, et al. The relationship between cyclosporine pharmacokinetic parameters and subsequent acute rejection in renal transplant recipients. Transplantation. 1988;46(5):716-22. Not patients with early CKD. [pmid: 3057694].
383 Kasiske BL, Lakatua JD. The effects of dietary protein restriction on chronic progressive renal disease. Mineral & Electrolyte Metabolism. 1997;23(3-6):296-300. Not a randomized trial. [pmid: 9387137].
384 Kasiske BL, Lakatua JD, Ma JZ, et al. A meta-analysis of the effects of dietary protein restriction on the rate of decline in renal function. American Journal of Kidney Diseases. 1998;31(6):954-61. Not a randomized trial. [pmid: 9631839].
385 Katz-Brull R, Rofsky NM, Morrin MM, et al. Decreases in free cholesterol and fatty acid unsaturation in renal cell carcinoma demonstrated by breath-hold magnetic resonance spectroscopy. American Journal of Physiology - Renal Physiology. 2005;288(4):F637-41. Intervention not related to monitoring of CKD. [pmid: 15572523].
386 Kaufman JS, O'Connor TZ, Zhang JH, et al. Randomized controlled trial of clopidogrel plus aspirin to prevent hemodialysis access graft thrombosis. Journal of the American Society of Nephrology. 2003;14(9):2313-21. Not patients with early CKD. [pmid: 12937308].
387 Kaver I, Pecht M, Trainin N, et al. T lymphocyte subsets and function in the peripheral blood of patients with urological cancer. Oncology. 1992;49(2):108-13. Not a randomized trial. [pmid: 1574245].
388 Kawasaka K, Tatsumi N. D-amino acid oxidase activity in urine obtained from patients with renal disorders. Clinical Nephrology. 1998;49(4):214-20. Not a randomized trial. [pmid: 9582550].
389 Kell MJ. Utilization of plasma and urine methadone concentrations to optimize treatment in maintenance clinics: I. Measurement techniques for a clinical setting. Journal of Addictive Diseases. 1994;13(1):5-26. Not a randomized trial. [pmid: 8018740].
390 Kent DM, Jafar TH, Hayward RA, et al. Progression risk, urinary protein excretion, and treatment effects of angiotensin-converting enzyme inhibitors in nondiabetic kidney disease. Journal of the American Society of Nephrology. 2007;18(6):1959-65. Not a randomized trial. [pmid: 17475813].
391 Kershner RP, Fitzsimmons WE. Relationship of FK506 whole blood concentrations and efficacy and toxicity after liver and kidney transplantation. Transplantation. 1996;62(7):920-6. Not patients with early CKD. [pmid: 8878385].
392 Khan DA, Ahmad TM, Qureshil AH, et al. Assessment of proteinuria by using protein: creatinine index in random urine sample. JPMA - Journal of the Pakistan Medical Association. 2005;55(10):428-31. Not a randomized trial.
393 Khanna D, Clements PJ, Furst DE, et al. Recombinant human relaxin in the treatment of systemic sclerosis with diffuse cutaneous involvement: a randomized, double-blind, placebo-controlled trial. Arthritis & Rheumatism. 2009;60(4):1102-11. Intervention not related to monitoring of CKD. [pmid: 19333948].
394 Khoury JA, Storch GA, Bohl DL, et al. Prophylactic versus preemptive oral valganciclovir for the management of cytomegalovirus infection in adult renal transplant recipients. American Journal of Transplantation. 2006;6(9):2134-43. Intervention not related to monitoring of CKD. [pmid: 16780548].
395 Kimmel M, Butscheid M, Brenner S, et al. Improved estimation of glomerular filtration rate by serum cystatin C in preventing contrast induced nephropathy by N-acetylcysteine or zinc--preliminary results. Nephrology Dialysis Transplantation. 2008;23(4):1241-5. Intervention not related to monitoring of CKD.
396 Kimmel PL, Mishkin GJ, Umana WO. Captopril and renal survival in patients with human immunodeficiency virus nephropathy. American Journal of Kidney Diseases. 1996;28(2):202-8. Not a randomized trial. [pmid: 8768914].
397 Kincaid-Smith P, Fairley KF, Farish S, et al. Reduction of proteinuria by rosiglitazone in non-diabetic renal disease. Nephrology. 2008;13(1):58-62. Intervention not related to monitoring of CKD. [pmid: 18199105].
398 Kincaid-Smith P, Fairley KF, Packham D. Dual blockade of the renin-angiotensin system compared with a 50% increase in the dose of angiotensin-converting enzyme inhibitor: effects on proteinuria and blood pressure. Nephrology Dialysis Transplantation. 2004;19(9):2272-4. Intervention not related to monitoring of CKD.
399 Kinouchi T, Sakamoto J, Tsukamoto T, et al. Prospective randomized trial of natural interferon-alpha versus natural interferon-alpha plus cimetidine in advanced renal cell carcinoma with pulmonary metastasis. Journal of Cancer Research & Clinical Oncology. 2006;132(8):499-504. Not patients with early CKD. [pmid: 16586071].
400 Klahr S. Role of dietary protein and blood pressure in the progression of renal disease. Kidney International. 1996;49(6):1783-6. Not a randomized trial. [pmid: 8743497].
401 Klahr S. Prevention of progression of nephropathy. Nephrology Dialysis Transplantation. Suppl 2. 1997;12:63-6. Not a randomized trial.
402 Klahr S, Breyer JA, Beck GJ, et al. Dietary protein restriction, blood pressure control, and the progression of polycystic kidney disease. Modification of Diet in Renal Disease Study Group. [Erratum appears in J Am Soc Nephrol 1995 Oct;6(4):1318]. Journal of the American Society of Nephrology. 1995;5(12):2037-47. Not a randomized trial. [pmid: 7579052].
403 Kliem V, Fricke L, Wollbrink T, et al. Improvement in long-term renal graft survival due to CMV prophylaxis with oral ganciclovir: results of a randomized clinical trial. American Journal of Transplantation. 2008;8(5):975-83. Intervention not related to monitoring of CKD. [pmid: 18261177].
404 Kobayashi Y, Hiki Y, Kokubo T, et al. Steroid therapy during the early stage of progressive IgA nephropathy. A 10-year follow-up study. Nephron. 1996;72(2):237-42. Not patients with early CKD. [pmid: 8684533].
405 Koc E, Tunca M, Akgul EO, et al. Effects of etanercept on urine neopterin levels in patients with psoriasis in a controlled, open-label study. Journal of Dermatology. 2009;36(4):191-6. Not patients with early CKD. [pmid: 19348656].
406 Koch KM, Koene RA, Messinger D, et al. The use of epoetin beta in anemic predialysis patients with chronic renal failure. [Erratum appears in Clin Nephrol 1995 Oct;44(4):278]. Clinical Nephrology. 1995;44(3):201-8. Intervention not related to monitoring of CKD. [pmid: 8556837].
407 Kohen JA, Whitley KY, Kjellstrand CM. Continuous arteriovenous hemofiltration: a comparison with hemodialysis in acute renal failure. Transactions - American Society for Artificial Internal Organs. 1985;31:169-75. Not patients with early CKD. [pmid: 3837438].
408 Kopple JD, Greene T, Chumlea WC, et al. Relationship between nutritional status and the glomerular filtration rate: results from the MDRD study. Kidney International. 2000;57(4):1688-703. Not a randomized trial. [pmid: 10760105].
409 Kovesdy CP, Ahmadzadeh S, Anderson JE, et al. Association of activated vitamin D treatment and mortality in chronic kidney disease. Archives of Internal Medicine. 2008;168(4):397-403. Not a randomized trial. [pmid: 18299495].
410 Kowey PR, Dickson TZ, Zhang Z, et al. Losartan and end-organ protection--lessons from the RENAAL study. Clinical Cardiology. 2005;28(3):136-42. Not a randomized trial. [pmid: 15813620].
411 Koya D, Haneda M, Inomata S, et al. Long-term effect of modification of dietary protein intake on the progression of diabetic nephropathy: a randomised controlled trial. Diabetologia. 2009;52(10):2037-45. Intervention not related to monitoring of CKD. [pmid: 19652945].
412 Krairittichai U, Chaisuvannarat V. Effects of dual blockade of renin-angiotensin system in type 2 diabetes mellitus patients with diabetic nephropathy. Journal of the Medical Association of Thailand. 2009;92(5):611-7. Intervention not related to monitoring of CKD. [pmid: 19459520].
413 Kralovicova K, Spanik S, Halko J, et al. Do vancomycin serum levels predict failures of vancomycin therapy or nephrotoxicity in cancer patients?. Journal of Chemotherapy. 1997;9(6):420-6. Intervention not related to monitoring of CKD. [pmid: 9491842].
414 Kramer BK, Neumayer HH, Stahl R, et al. Graft function, cardiovascular risk factors, and sex hormones in renal transplant recipients on an immunosuppressive regimen of everolimus, reduced dose of cyclosporine, and basiliximab. Transplantation Proceedings. 2005;37(3):1601-4. Not patients with early CKD. [pmid: 15866684].
415 Krane V, Wanner C. Dyslipidaemia in chronic kidney disease. Minerva Urologica e Nefrologica. 2007;59(3):299-316. Not a randomized trial. [pmid: 17912226].
416 Kroencke TJ, Wasser MN, Pattynama PMT, et al. Gadobenate dimeglumine-enhanced MR angiography of the abdominal aorta and renal arteries. AJR. American Journal of Roentgenology. 2002;179(6):1573-82. Intervention not related to monitoring of CKD. [pmid: 12438058].
417 Kshirsagar AV, Joy MS, Hogan SL, et al. Effect of ACE inhibitors in diabetic and nondiabetic chronic renal disease: a systematic overview of randomized placebo-controlled trials. American Journal of Kidney Diseases. 2000;35(4):695-707. Not a randomized trial. [pmid: 10739792].
418 Kumar MSA, Xiao SG, Fyfe B, et al. Steroid avoidance in renal transplantation using basiliximab induction, cyclosporine-based immunosuppression and protocol biopsies. Clinical Transplantation. 2005;19(1):61-9. Not patients with early CKD. [pmid: 15659136].
419 Kuntz RA, Holt DW, Turner S, et al. Effects of conventional ultrafiltration on renal performance during adult cardiopulmonary bypass procedures. Journal of Extra-Corporeal Technology. 2006;38(2):144-53. Intervention not related to monitoring of CKD. [pmid: 16921688].
420 Kuriyama S, Tomonari H, Yoshida H, et al. Reversal of anemia by erythropoietin therapy retards the progression of chronic renal failure, especially in nondiabetic patients. Nephron. 1997;77(2):176-85. Intervention not related to monitoring of CKD. [pmid: 9346384].
421 Kutner NG. Quality of life and daily hemodialysis. Seminars in Dialysis. 2004;17(2):92-8. Not patients with early CKD. [pmid: 15043608].
422 Laczika K, Staudinger T, Hollenstein U, et al. Renal tolerability of four different once-daily dose regimen of netilmicin in critical care patients. Wiener Klinische Wochenschrift. 1997;109(21):840-4. Intervention not related to monitoring of CKD. [pmid: 9408981].
423 Laffel LM, McGill JB, Gans DJ. The beneficial effect of angiotensin-converting enzyme inhibition with captopril on diabetic nephropathy in normotensive IDDM patients with microalbuminuria. North American Microalbuminuria Study Group. American Journal of Medicine. 1995;99(5):497-504. Intervention not related to monitoring of CKD. [pmid: 7485207].
424 Laing C, Unwin RJ. Are calcium antagonists effective in preventing complications of hypertension and progression of renal disease?. Current Opinion in Nephrology & Hypertension. 2000;9(5):489-95. Not a randomized trial. [pmid: 10990366].
425 Lalezari JP, Holland GN, Kramer F, et al. Randomized, controlled study of the safety and efficacy of intravenous cidofovir for the treatment of relapsing cytomegalovirus retinitis in patients with AIDS. Journal of Acquired Immune Deficiency Syndromes & Human Retrovirology. 1998;17(4):339-44. Intervention not related to monitoring of CKD. [pmid: 9525435].
426 Lamuraglia M, Escudier B, Chami L, et al. To predict progression-free survival and overall survival in metastatic renal cancer treated with sorafenib: pilot study using dynamic contrast-enhanced Doppler ultrasound. [Erratum appears in Eur J Cancer. 2007 May;43(8):1336]. European Journal of Cancer. 2006;42(15):2472-9. Not patients with early CKD. [pmid: 16965911].
427 Lara PN Jr., Quinn DI, Margolin K, et al. SU5416 plus interferon alpha in advanced renal cell carcinoma: a phase II California Cancer Consortium Study with biological and imaging correlates of angiogenesis inhibition. Clinical Cancer Research. 2003;9(13):4772-81. Intervention not related to monitoring of CKD. [pmid: 14581348].
428 Laufs U, Custodis F, Bohm M. Who does not need a statin: too late in end-stage renal disease or heart failure?. Heart. 2008;94(9):1138-40. Not a randomized trial. [pmid: 18703694].
429 Lawrie AS, McDonald SJ, Purdy G, et al. Prothrombin time derived fibrinogen determination on Sysmex CA-6000. Journal of Clinical Pathology. 1998;51(6):462-6. Intervention not related to monitoring of CKD. [pmid: 9771446].
430 Le Meur Y, Buchler M, Thierry A, et al. Individualized mycophenolate mofetil dosing based on drug exposure significantly improves patient outcomes after renal transplantation. American Journal of Transplantation. 2007;7(11):2496-503. Not patients with early CKD. [pmid: 17908276].
431 Lea J, Cheek D, Thornley-Brown D, et al. Metabolic syndrome, proteinuria, and the risk of progressive CKD in hypertensive African Americans. American Journal of Kidney Diseases. 2008;51(5):732-40. Intervention not related to monitoring of CKD. [pmid: 18436083].
432 Lea J, Greene T, Hebert L, et al. The relationship between magnitude of proteinuria reduction and risk of end-stage renal disease: results of the African American study of kidney disease and hypertension. Archives of Internal Medicine. 2005;165(8):947-53. Intervention not related to monitoring of CKD. [pmid: 15851648].
433 Lee CP, Patel PM, Selby PJ, et al. Randomized phase II study comparing thalidomide with medroxyprogesterone acetate in patients with metastatic renal cell carcinoma. Journal of Clinical Oncology. 2006;24(6):898-903. Not patients with early CKD. [pmid: 16484699].
434 Lee D, Levin A, Roger SD, et al. Longitudinal analysis of performance of estimated glomerular filtration rate as renal function declines in chronic kidney disease. Nephrology Dialysis Transplantation. 2009;24(1):109-16. Not a randomized trial.
435 Lee JY, Kusek JW, Greene PG, et al. Assessing medication adherence by pill count and electronic monitoring in the African American Study of Kidney Disease and Hypertension (AASK) Pilot Study. American Journal of Hypertension. 1996;9(8):719-25. Intervention not related to monitoring of CKD. [pmid: 8862216].
436 Leenen FHH, Coletta E, Davies RA. Prevention of renal dysfunction and hypertension by amlodipine after heart transplant. American Journal of Cardiology. 2007;100(3):531-5. Intervention not related to monitoring of CKD. [pmid: 17659942].
437 Lehmkuhl HB, Arizon J, Vigano M, et al. Everolimus with reduced cyclosporine versus MMF with standard cyclosporine in de novo heart transplant recipients. Transplantation. 2009;88(1):115-22. Not patients with early CKD. [pmid: 19584690].
438 Lely AT, van der Kleij FGH, Kistemaker TJ, et al. Impact of the preintervention rate of renal function decline on outcome of renoprotective intervention. Clinical Journal of The American Society of Nephrology: CJASN. 2008;3(1):54-60. Intervention not related to monitoring of CKD. [pmid: 18077786].
439 Lemley KV, Abdullah I, Myers BD, et al. Evolution of incipient nephropathy in type 2 diabetes mellitus. [Erratum appears in Kidney Int 2000 Nov;58(5):2257]. Kidney International. 2000;58(3):1228-37. Not a randomized trial. [pmid: 10972685].
440 Levey AS, Adler S, Caggiula AW, et al. Effects of dietary protein restriction on the progression of advanced renal disease in the Modification of Diet in Renal Disease Study. American Journal of Kidney Diseases. 1996;27(5):652-63. Intervention not related to monitoring of CKD. [pmid: 8629624].
441 Levey AS, Greene T, Sarnak MJ, et al. Effect of dietary protein restriction on the progression of kidney disease: long-term follow-up of the Modification of Diet in Renal Disease (MDRD) Study. American Journal of Kidney Diseases. 2006;48(6):879-88. Intervention not related to monitoring of CKD. [pmid: 17162142].
442 Levin NW, Fishbane S, Canedo FV, et al. Intravenous methoxy polyethylene glycol-epoetin beta for haemoglobin control in patients with chronic kidney disease who are on dialysis: a randomised non-inferiority trial (MAXIMA). [Erratum appears in Lancet. 2008 Feb 2;371(9610):386]. Lancet. 2007;370(9596):1415-21. Not patients with early CKD. [pmid: 17950856].
443 Levine RJ, Hauth JC, Curet LB, et al. Trial of calcium to prevent preeclampsia. New England Journal of Medicine. 1997;337(2):69-76. Intervention not related to monitoring of CKD. [pmid: 9211675].
444 Lewis EJ. The role of angiotensin II receptor blockers in preventing the progression of renal disease in patients with type 2 diabetes. American Journal of Hypertension. 2002;15(10 Pt 2):123S-8S. Not a randomized trial. [pmid: 12383593].
445 Lewis EJ, Hunsicker LG, Rodby RA, et al. A clinical trial in type 2 diabetic nephropathy. American Journal of Kidney Diseases. 2001;38(4 Suppl 1):S191-4. Intervention not related to monitoring of CKD. [pmid: 11576953].
446 Lezaic VD, Marinkovic J, Ristic S, et al. Conversion of azathioprine to mycophenolate mofetil and chronic graft failure progression. Transplantation Proceedings. 2005;37(2):734-6. Not patients with early CKD. [pmid: 15848517].
447 Li PK, Mak TW, Wang AY, et al. The interaction of fluvastatin and cyclosporin A in renal transplant patients. International Journal of Clinical Pharmacology & Therapeutics. 1995;33(4):246-8. Not patients with early CKD. [pmid: 7620696].
448 Lievre M, Marre M, Chatellier G, et al. The non-insulin-dependent diabetes, hypertension, microalbuminuria or proteinuria, cardiovascular events, and ramipril (DIABHYCAR) study: design, organization, and patient recruitment. DIABHYCAR Study Group. Controlled Clinical Trials. 2000;21(4):383-96. Intervention not related to monitoring of CKD. [pmid: 10913814].
449 Lin JL, Lin-Tan DT, Yu CC, et al. Environmental exposure to lead and progressive diabetic nephropathy in patients with type II diabetes. Kidney International. 2006;69(11):2049-56. Not a randomized trial. [pmid: 16641918].
450 Lin JL, Lin-Tan DT, Hsu KH, et al. Environmental lead exposure and progression of chronic renal diseases in patients without diabetes. New England Journal of Medicine. 2003;348(4):277-86. Intervention not related to monitoring of CKD. [pmid: 12540640].
451 Lin SL, Chen YM, Chiang WC, et al. Effect of pentoxifylline in addition to losartan on proteinuria and GFR in CKD: a 12-month randomized trial. American Journal of Kidney Diseases. 2008;52(3):464-74. Intervention not related to monitoring of CKD. [pmid: 18617301].
452 Lin-Tan DT, Lin JL, Yen TH, et al. Long-term outcome of repeated lead chelation therapy in progressive non-diabetic chronic kidney diseases. Nephrology Dialysis Transplantation. 2007;22(10):2924-31. Intervention not related to monitoring of CKD.
453 Lipton A. The safety of zoledronic acid. Expert Opinion on Drug Safety. 2007;6(3):305-13. Intervention not related to monitoring of CKD. [pmid: 17480179].
454 Lipton A, Zheng M, Seaman J. Zoledronic acid delays the onset of skeletal-related events and progression of skeletal disease in patients with advanced renal cell carcinoma. Cancer. 2003;98(5):962-9. Intervention not related to monitoring of CKD. [pmid: 12942563].
455 Littlewood KJ, Greiner W, Baum D, et al. Adjunctive treatment with moxonidine versus nitrendipine for hypertensive patients with advanced renal failure: a cost-effectiveness analysis. BMC Nephrology. 2007;8:9. Not a randomized trial. [pmid: 17645811].
456 Liu KP, Lin CY, Chen HJ, et al. Renin-angiotensin system polymorphisms in Taiwanese primary vesicoureteral reflux. Pediatric Nephrology. 2004;19(6):594-601. Not a randomized trial. [pmid: 15045574].
457 Liu M, Zhang W, Gu M, et al. Protective effects of sirolimus by attenuating connective tissue growth factor expression in human chronic allograft nephropathy. Transplantation Proceedings. 2007;39(5):1410-5. Not patients with early CKD. [pmid: 17580150].
458 Llewelyn DEH, Garcia-Puig J. How different urinary albumin excretion rates can predict progression to nephropathy and the effect of treatment in hypertensive diabetics. Journal of the Renin-Angiotensin-Aldosterone System. 2004;5(3):141-5. Intervention not related to monitoring of CKD. [pmid: 15526250].
459 Lobo PI, Cortez MS, Stevenson W, et al. Normocalcemic hyperparathyroidism associated with relatively low 1:25 vitamin D levels post-renal transplant can be successfully treated with oral calcitriol. Clinical Transplantation. 1995;9(4):277-81. Not a randomized trial. [pmid: 7579733].
460 Locatelli F, Carbarns IR, Maschio G, et al. Long-term progression of chronic renal insufficiency in the AIPRI Extension Study. The Angiotensin-Converting-Enzyme Inhibition in Progressive Renal Insufficiency Study Group. Kidney International - Supplement. 1997;63:S63-6. Intervention not related to monitoring of CKD. [pmid: 9407424].
461 Locatelli F, Del Vecchio L, Andrulli S, et al. The role of underlying nephropathy in the progression of renal disease. Kidney International - Supplement. 2000;75:S49-55. Not a randomized trial. [pmid: 10828762].
462 Locatelli F, Del Vecchio L, Pozzoni P. Clinical benefits of slowing the progression of renal failure. Kidney International - Supplement. 2005;(99):S152-6. Not a randomized trial. [pmid: 16336569].
463 Locatelli F, Del Vecchio L, Pozzoni P, et al. Is it the agent or the blood pressure level that matters for renal and vascular protection in chronic nephropathies?. Kidney International - Supplement. 2005;(93):S15-9. Not a randomized trial. [pmid: 15613061].
464 Locatelli F, Manzoni C, Marcelli D. Factors affecting progression of renal insufficiency. Mineral & Electrolyte Metabolism. 1997;23(3-6):301-5. Not a randomized trial. [pmid: 9387138].
465 Locatelli F, Marcelli D, Comelli M, et al. Proteinuria and blood pressure as causal components of progression to end-stage renal failure. Northern Italian Cooperative Study Group. Nephrology Dialysis Transplantation. 1996;11(3):461-7. Intervention not related to monitoring of CKD.
466 Locatelli F, Pozzi C, Del Vecchio L, et al. Role of proteinuria reduction in the progression of IgA nephropathy. Renal Failure. 2001;23(3-4):495-505. Not patients with early CKD. [pmid: 11499564].
467 Locatelli F, Vecchio LD, Pozzi C. IgA glomerulonephritis: beyond angiotensin-converting enzyme inhibitors. Nature Clinical Practice Nephrology. 2006;2(1):24-31. Not a randomized trial.
468 Locatelli F, Vecchio LD, Pozzoni P. The importance of early detection of chronic kidney disease. Nephrology Dialysis Transplantation. Suppl 11. 2002;17:2-7. Not a randomized trial.
469 Lombardo F, Frijia F, Bongioanni P, et al. Diffusion tensor MRI and MR spectroscopy in long lasting upper motor neuron involvement in amyotrophic lateral sclerosis. Archives Italiennes de Biologie. 2009;147(3):69-82. Intervention not related to monitoring of CKD. [pmid: 20014653].
470 Lonn E, Yusuf S, Dzavik V, et al. Effects of ramipril and vitamin E on atherosclerosis: the study to evaluate carotid ultrasound changes in patients treated with ramipril and vitamin E (SECURE). Circulation. 2001;103(7):919-25. Intervention not related to monitoring of CKD. [pmid: 11181464].
471 Lopes RJ, Lourenco AP, Mascarenhas J, et al. Safety of spironolactone use in ambulatory heart failure patients. Clinical Cardiology. 2008;31(11):509-13. Intervention not related to monitoring of CKD. [pmid: 19006114].
472 Lorber MI, Mulgaonkar S, Butt KMH, et al. Everolimus versus mycophenolate mofetil in the prevention of rejection in de novo renal transplant recipients: a 3-year randomized, multicenter, phase III study. Transplantation. 2005;80(2):244-52. Not patients with early CKD. [pmid: 16041270].
473 Louis S, Audrain M, Cantarovich D, et al. Long-term cell monitoring of kidney recipients after an antilymphocyte globulin induction with and without steroids. Transplantation. 2007;83(6):712-21. Not patients with early CKD. [pmid: 17414703].
474 Loukovaara S, Immonen I, Teramo KA, et al. Progression of retinopathy during pregnancy in type 1 diabetic women treated with insulin lispro. Diabetes Care. 2003;26(4):1193-8. Intervention not related to monitoring of CKD. [pmid: 12663596].
475 Low CL, Bailie G, Morgan S, et al. Effect of a sliding scale protocol for heparin on the ability to maintain whole blood activated partial thromboplastin times within a desired range in hemodialysis patients. Clinical Nephrology. 1996;45(2):120-4. Not patients with early CKD. [pmid: 8846524].
476 Luchner A, Hengstenberg C, Lowel H, et al. Effect of compensated renal dysfunction on approved heart failure markers: direct comparison of brain natriuretic peptide (BNP) and N-terminal pro-BNP. Hypertension. 2005;46(1):118-23. Not a randomized trial. [pmid: 15939804].
477 Lumlertgul D, Noppakun K, Rojanasthien N, et al. Pharmacokinetic study of the combination of tacrolimus and fluconazole in renal transplant patients. Journal of the Medical Association of Thailand. Suppl 2. 2006;89:S73-8. Not patients with early CKD. [pmid: 17044457].
478 MacDonald AS, Group RGS. A worldwide, phase III, randomized, controlled, safety and efficacy study of a sirolimus/cyclosporine regimen for prevention of acute rejection in recipients of primary mismatched renal allografts. Transplantation. 2001;71(2):271-80. Not patients with early CKD. [pmid: 11213073].
479 MacGregor MS, Deighan CJ, Rodger RSC, et al. A prospective open-label randomised trial of quinapril and/or amlodipine in progressive non-diabetic renal failure. Nephron. 2005;101(3):c139-49. Intervention not related to monitoring of CKD. [pmid: 16015004].
480 Magee GM, Bilous RW, Cardwell CR, et al. Is hyperfiltration associated with the future risk of developing diabetic nephropathy? A meta-analysis. Diabetologia. 2009;52(4):691-7. Not a randomized trial. [pmid: 19198800].
481 Mahalati K, Lawen J, Kiberd B, et al. Is 3-hour cyclosporine blood level superior to trough level in early post-renal transplantation period?. Journal of Urology. 2000;163(1):37-41. Not patients with early CKD. [pmid: 10604309].
482 Mak G, Tan CY, Ben Khiaron O, et al. An evaluation of the effects of renal artery stenting in renovascular hypertension. Irish Medical Journal. 2007;100(3):397-8. Not a randomized trial. [pmid: 17491539].
483 Makino H, Haneda M, Babazono T, et al. Microalbuminuria reduction with telmisartan in normotensive and hypertensive Japanese patients with type 2 diabetes: a post-hoc analysis of The Incipient to Overt: Angiotensin II Blocker, Telmisartan, Investigation on Type 2 Diabetic Nephropathy (INNOVATION) study. Hypertension Research - Clinical & Experimental. 2008;31(4):657-64. Intervention not related to monitoring of CKD.
484 Malik J, Slavikova M, Svobodova J, et al. Regular ultrasonographic screening significantly prolongs patency of PTFE grafts. Kidney International. 2005;67(4):1554-8. Not patients with early CKD. [pmid: 15780111].
485 Mallett C, House AA, Spence JD, et al. Longitudinal ultrasound evaluation of carotid atherosclerosis in one, two and three dimensions. Ultrasound in Medicine & Biology. 2009;35(3):367-75. Intervention not related to monitoring of CKD. [pmid: 18996639].
486 Mallikaarjun S, Shoaf SE, Boulton DW, et al. Effects of hepatic or renal impairment on the pharmacokinetics of aripiprazole. Clinical Pharmacokinetics. 2008;47(8):533-42. Intervention not related to monitoring of CKD. [pmid: 18611062].
487 Mancini D, Pinney S, Burkhoff D, et al. Use of rapamycin slows progression of cardiac transplantation vasculopathy. Circulation. 2003;108(1):48-53. Intervention not related to monitoring of CKD. [pmid: 12742978].
488 Mani S, Poo WJ. Single institution experience with recombinant gamma-interferon in the treatment of patients with metastatic renal cell carcinoma. American Journal of Clinical Oncology. 1996;19(2):149-53. Not a randomized trial. [pmid: 8610639].
489 Manikandan R, Srinivasan V, Rane A. Which is the real gold standard for small-volume renal tumors? Radical nephrectomy versus nephron-sparing surgery. Journal of Endourology. 2004;18(1):39-44. Not a randomized trial. [pmid: 15006052].
490 Manley HJ. Role of angiotensin-converting-enzyme inhibition in patients with renal disease. American Journal of Health-System Pharmacy. Suppl 1. 2000;57:S12-8. Not a randomized trial. [pmid: 11030018].
491 Mann JFE, Gerstein HC, Yi QL, et al. Progression of renal insufficiency in type 2 diabetes with and without microalbuminuria: results of the Heart Outcomes and Prevention Evaluation (HOPE) randomized study. American Journal of Kidney Diseases. 2003;42(5):936-42. Not a randomized trial. [pmid: 14582037].
492 Mann JFE, Gerstein HC, Yi QL, et al. Development of renal disease in people at high cardiovascular risk: results of the HOPE randomized study. Journal of the American Society of Nephrology. 2003;14(3):641-7. Not a randomized trial. [pmid: 12595499].
493 Mann JFE, Schmieder RE, Dyal L, et al. Effect of telmisartan on renal outcomes: a randomized trial. [Summary for patients in Ann Intern Med. 2009 Jul 7;151(1):I28; PMID: 19451555]. Annals of Internal Medicine. 2009;151(1):1-10. Intervention not related to monitoring of CKD. [pmid: 19451556].
494 Manno C, Strippoli GFM, D'Altri C, et al. A novel simpler histological classification for renal survival in IgA nephropathy: a retrospective study. American Journal of Kidney Diseases. 2007;49(6):763-75. Not a randomized trial. [pmid: 17533019].
495 Marcantoni C, Zanoli L, Rastelli S, et al. Stenting of renal artery stenosis in coronary artery disease (RAS-CAD) study: a prospective, randomized trial. Journal of Nephrology. 2009;22(1):13-6. Intervention not related to monitoring of CKD. [pmid: 19229814].
496 Mariappan P, Smith G, Moussa SA, et al. One week of ciprofloxacin before percutaneous nephrolithotomy significantly reduces upper tract infection and urosepsis: a prospective controlled study. BJU International. 2006;98(5):1075-9. Intervention not related to monitoring of CKD. [pmid: 17034608].
497 Markowitz CE, Spitsin S, Zimmerman V, et al. The treatment of multiple sclerosis with inosine. Journal of Alternative & Complementary Medicine. 2009;15(6):619-25. Intervention not related to monitoring of CKD.
498 Martin PJ, Nelson BJ, Appelbaum FR, et al. Evaluation of a CD5-specific immunotoxin for treatment of acute graft-versus-host disease after allogeneic marrow transplantation. Blood. 1996;88(3):824-30. Intervention not related to monitoring of CKD. [pmid: 8704237].
499 Martinez-Castelao A, Sarrias X, Bestard O, et al. Arterial elasticity measurement in renal transplant patients under anticalcineurin immunosuppression. Transplantation Proceedings. 2005;37(9):3788-90. Not patients with early CKD. [pmid: 16386539].
500 Marto N, Bertolaccini ML, Calabuig E, et al. Anti-C1q antibodies in nephritis: correlation between titres and renal disease activity and positive predictive value in systemic lupus erythematosus. Annals of the Rheumatic Diseases. 2005;64(3):444-8. Not a randomized trial. [pmid: 15286009].
501 Mas VR, Mas LA, Archer KJ, et al. Evaluation of gene panel mRNAs in urine samples of kidney transplant recipients as a non-invasive tool of graft function. Molecular Medicine. 2007;13(5-6):315-24. Not a randomized trial. [pmid: 17622313].
502 Maschio G, Alberti D, Janin G, et al. Effect of the angiotensin-converting-enzyme inhibitor benazepril on the progression of chronic renal insufficiency. The Angiotensin-Converting-Enzyme Inhibition in Progressive Renal Insufficiency Study Group. New England Journal of Medicine. 1996;334(15):939-45. Intervention not related to monitoring of CKD. [pmid: 8596594].
503 Masuda Si, Tamura K, Wakui H, et al. Effects of angiotensin II type 1 receptor blocker on ambulatory blood pressure variability in hypertensive patients with overt diabetic nephropathy. Hypertension Research - Clinical & Experimental. 2009;32(11):950-5. Intervention not related to monitoring of CKD.
504 Matsumura C, Kemmotsu O, Kawano Y, et al. Serum and urine inorganic fluoride levels following prolonged low-dose sevoflurane anesthesia combined with epidural block. Journal of Clinical Anesthesia. 1994;6(5):419-24. Intervention not related to monitoring of CKD. [pmid: 7527229].
505 Matthews DR, Stratton IM, Aldington SJ, et al. Risks of progression of retinopathy and vision loss related to tight blood pressure control in type 2 diabetes mellitus: UKPDS 69. Archives of Ophthalmology. 2004;122(11):1631-40. Intervention not related to monitoring of CKD. [pmid: 15534123].
506 Mauer M, Zinman B, Gardiner R, et al. Renal and retinal effects of enalapril and losartan in type 1 diabetes. New England Journal of Medicine. 2009;361(1):40-51. Intervention not related to monitoring of CKD. [pmid: 19571282].
507 McClellan WM, Hodgin E, Pastan S, et al. A randomized evaluation of two health care quality improvement program (HCQIP) interventions to improve the adequacy of hemodialysis care of ESRD patients: feedback alone versus intensive intervention. Journal of the American Society of Nephrology. 2004;15(3):754-60. Not patients with early CKD. [pmid: 14978178].
508 McClellan WM, Langston RD, Presley R. Medicare patients with cardiovascular disease have a high prevalence of chronic kidney disease and a high rate of progression to end-stage renal disease. Journal of the American Society of Nephrology. 2004;15(7):1912-9. Not a randomized trial. [pmid: 15213281].
509 McClellan WM, Soucie JM, Krisher J, et al. Improving the care of patients treated with hemodialysis: a report from the Health Care Financing Administration's ESRD Core Indicators Project. American Journal of Kidney Diseases. 1998;31(4):584-92. Not patients with early CKD. [pmid: 9531173].
510 McCormack PM, Cox JP, Marron J, et al. The antihypertensive efficacy of ketanserin in the elderly evaluated by ambulatory blood pressure measurement. Journal of Human Hypertension. 1990;4(5):565-70. Intervention not related to monitoring of CKD. [pmid: 2283647].
511 McCormick PA, Greenslade L, Kibbler CC, et al. A prospective randomized trial of ceftazidime versus netilmicin plus mezlocillin in the empirical therapy of presumed sepsis in cirrhotic patients. Hepatology. 1997;25(4):833-6. Intervention not related to monitoring of CKD. [pmid: 9096584].
512 McCullough PA, Agrawal V, Danielewicz E, et al. Accelerated atherosclerotic calcification and Monckeberg's sclerosis: a continuum of advanced vascular pathology in chronic kidney disease. Clinical Journal of The American Society of Nephrology: CJASN. 2008;3(6):1585-98. Not a randomized trial. [pmid: 18667741].
513 McCullough PA, Bakris GL, Owen WF Jr., et al. Slowing the progression of diabetic nephropathy and its cardiovascular consequences. American Heart Journal. 2004;148(2):243-51. Not a randomized trial. [pmid: 15308993].
514 McDonald RA, Smith JM, Ho M, et al. Incidence of PTLD in pediatric renal transplant recipients receiving basiliximab, calcineurin inhibitor, sirolimus and steroids. American Journal of Transplantation. 2008;8(5):984-9. Not adult population. [pmid: 18416737].
515 McGill JB. Improving microvascular outcomes in patients with diabetes through management of hypertension. Postgraduate Medicine. 2009;121(2):89-101. Not a randomized trial. [pmid: 19332966].
516 McMahon LP, Roger SD, Levin A, et al. Development, prevention, and potential reversal of left ventricular hypertrophy in chronic kidney disease. Journal of the American Society of Nephrology. 2004;15(6):1640-7. Intervention not related to monitoring of CKD. [pmid: 15153576].
517 Melis D, Parenti G, Gatti R, et al. Efficacy of ACE-inhibitor therapy on renal disease in glycogen storage disease type 1: a multicentre retrospective study. Clinical Endocrinology. 2005;63(1):19-25. Not a randomized trial. [pmid: 15963056].
518 Menon V, Wang X, Sarnak MJ, et al. Long-term outcomes in nondiabetic chronic kidney disease. Kidney International. 2008;73(11):1310-5. Not a randomized trial. [pmid: 18337713].
519 Mezzano D, Tagle R, Pais E, et al. Endothelial cell markers in chronic uremia: relationship with hemostatic defects and severity of renal failure. Thrombosis Research. 1997;88(6):465-72. Not a randomized trial. [pmid: 9610957].
520 Midtvedt K, Fauchald P, Lien B, et al. Individualized T cell monitored administration of ATG versus OKT3 in steroid-resistant kidney graft rejection. Clinical Transplantation. 2003;17(1):69-74. Not patients with early CKD. [pmid: 12588325].
521 Milas NC, Nowalk MP, Akpele L, et al. Factors associated with adherence to the dietary protein intervention in the Modification of Diet in Renal Disease Study. Journal of the American Dietetic Association. 1995;95(11):1295-300. Not a randomized trial. [pmid: 7594126].
522 Miller PD, Bilezikian JP, Diaz-Curiel M, et al. Occurrence of hypercalciuria in patients with osteoporosis treated with teriparatide. Journal of Clinical Endocrinology & Metabolism. 2007;92(9):3535-41. Not patients with early CKD. [pmid: 17609307].
523 Miyazaki Y, Cersosimo E, Triplitt C, et al. Rosiglitazone decreases albuminuria in type 2 diabetic patients. Kidney International. 2007;72(11):1367-73. Intervention not related to monitoring of CKD. [pmid: 17805239].
524 Modine T, Decoene C, Al-Ruzzeh S, et al. Dobutamine improves thoracic aortic blood flow during off-pump coronary artery bypass surgery: results of a prospective randomised controlled trial. European Journal of Cardio-Thoracic Surgery. 2005;27(2):289-95. Intervention not related to monitoring of CKD. [pmid: 15691684].
525 Mohanram A, Zhang Z, Shahinfar S, et al. Anemia and end-stage renal disease in patients with type 2 diabetes and nephropathy. Kidney International. 2004;66(3):1131-8. Not a randomized trial. [pmid: 15327408].
526 Moist LM, Churchill DN, House AA, et al. Regular monitoring of access flow compared with monitoring of venous pressure fails to improve graft survival. Journal of the American Society of Nephrology. 2003;14(10):2645-53. Not patients with early CKD. [pmid: 14514744].
527 Monier-Faugere MC, Malluche HH. Calcitriol pulse therapy in patients with end-stage renal failure. Current Opinion in Nephrology & Hypertension. 1994;3(6):615-9. Not patients with early CKD. [pmid: 7881985].
528 Morita S, Fukuhara S, Akizawa T, et al. Prognostic factors for a composite end-point of renal outcomes in patients with chronic kidney disease. Therapeutic Apheresis & Dialysis: Official Peer-Reviewed Journal of the International Society for Apheresis, the Japanese Society for Apheresis, the Japanese Society for Dialysis Therapy. 2006;10(1):72-7. Not a randomized trial.
529 Mosca A, Paleari R, Ceriotti F, et al. Biological variability of albumin excretion rate and albumin-to-creatinine ratio in hypertensive type 2 diabetic patients. Clinical Chemistry & Laboratory Medicine. 2003;41(9):1229-33. Intervention not related to monitoring of CKD. [pmid: 14598874].
530 Motzer RJ, Hutson TE, Tomczak P, et al. Sunitinib versus interferon alfa in metastatic renal-cell carcinoma. New England Journal of Medicine. 2007;356(2):115-24. Not patients with early CKD. [pmid: 17215529].
531 Mpoy M, Vandeleene B, Ketelslegers JM, et al. Treatment of systemic hypertension in insulin-treated diabetes mellitus with rilmenidine. American Journal of Cardiology. 1988;61(7):91D-4D. Intervention not related to monitoring of CKD.
532 Muhlhauser I, Bender R, Bott U, et al. Cigarette smoking and progression of retinopathy and nephropathy in type 1 diabetes. Diabetic Medicine. 1996;13(6):536-43. Not a randomized trial. [pmid: 8799657].
533 Mulgaonkar S, Tedesco H, Oppenheimer F, et al. FTY720/cyclosporine regimens in de novo renal transplantation: a 1-year dose-finding study. [Erratum appears in Am J Transplant. 2006 Dec;6(12):3044]. American Journal of Transplantation. 2006;6(8):1848-57. Not patients with early CKD. [pmid: 16771816].
534 Munger MA, Gardner SF, Ateshkadi A, et al. Misoprostol effects on diclofenac-induced cardiorenal changes in salt-sensitive patients with hypertension: the MEDIC Study. Pharmacotherapy. 2008;28(7):834-42. Intervention not related to monitoring of CKD. [pmid: 18576898].
535 Myrup B, Mathiesen ER, Ronn B, et al. Endothelial function and serum lipids in the course of developing microalbuminuria in insulin-dependent diabetes mellitus. Diabetes Research. 1994;26(1):33-9. Not a randomized trial. [pmid: 7664535].
536 Nakamura T, Sugaya T, Kawagoe Y, et al. Effect of pitavastatin on urinary liver-type fatty-acid-binding protein in patients with nondiabetic mild chronic kidney disease. American Journal of Nephrology. 2006;26(1):82-6. Intervention not related to monitoring of CKD. [pmid: 16534182].
537 Nakamura T, Sugaya T, Kawagoe Y, et al. Effect of pitavastatin on urinary liver-type fatty acid-binding protein levels in patients with early diabetic nephropathy. Diabetes Care. 2005;28(11):2728-32. Intervention not related to monitoring of CKD. [pmid: 16249547].
538 Nakano S, Ishii T, Kitazawa M, et al. Altered circadian blood pressure rhythm and progression of diabetic nephropathy in non-insulin dependent diabetes mellitus subjects: an average three year follow-up study. Journal of Investigative Medicine. 1996;44(5):247-53. Not a randomized trial. [pmid: 8763975].
539 Nakao T, Kanazawa Y, Nagaoka Y, et al. Body protein index based on bioelectrical impedance analysis is a useful new marker assessing nutritional status: applications to patients with chronic renal failure on maintenance dialysis. Contributions to Nephrology. 2007;155:18-28. Not patients with early CKD. [pmid: 17369710].
540 Nakao T, Yoshino M, Matsumoto H, et al. Low-density lipoprotein apheresis retards the progression of hyperlipidemic overt diabetic nephropathy. Kidney International - Supplement. 1999;71:S206-9. Not a randomized trial. [pmid: 10412777].
541 Narenpitak S, Narenpitak A. Prevalence of chronic kidney disease in type 2 diabetes in primary health care unit of Udon Thani province, Thailand. Journal of the Medical Association of Thailand. 2008;91(10):1505-13. Not a randomized trial. [pmid: 18972892].
542 Navaneethan SD, Nigwekar SU, Sehgal AR, et al. Aldosterone antagonists for preventing the progression of chronic kidney disease. Cochrane Database of Systematic Reviews. 2009;(3):CD007004. Not a randomized trial. [pmid: 19588415].
543 Navaneethan SD, Nigwekar SU, Sehgal AR, et al. Aldosterone antagonists for preventing the progression of chronic kidney disease: a systematic review and meta-analysis. Clinical Journal of The American Society of Nephrology: CJASN. 2009;4(3):542-51. Not a randomized trial. [pmid: 19261819].
544 Navaneethan SD, Pansini F, Perkovic V, et al. HMG CoA reductase inhibitors (statins) for people with chronic kidney disease not requiring dialysis. Cochrane Database of Systematic Reviews. 2009;(2):CD007784. Not a randomized trial. [pmid: 19370693].
545 Negrier S, Escudier B, Lasset C, et al. Recombinant human interleukin-2, recombinant human interferon alfa-2a, or both in metastatic renal-cell carcinoma. Groupe Francais d'Immunotherapie. New England Journal of Medicine. 1998;338(18):1272-8. Not patients with early CKD. [pmid: 9562581].
546 Neuhaus P, Blumhardt G, Bechstein WO, et al. Comparison of FK506- and cyclosporine-based immunosuppression in primary orthotopic liver transplantation. A single center experience. Transplantation. 1995;59(1):31-40. Intervention not related to monitoring of CKD. [pmid: 7530868].
547 Neverov NI, Kaysen GA, Tareyeva IE. Effect of lipid-lowering therapy on the progression of renal disease in nondiabetic nephrotic patients. Contributions to Nephrology. 1997;120:68-78. Intervention not related to monitoring of CKD. [pmid: 9257049].
548 Newman DJ, Mattock MB, Dawnay ABS, et al. Systematic review on urine albumin testing for early detection of diabetic complications. Health Technology Assessment. 2005;9(30):iii-vi. xiii. 163. Not a randomized trial. [pmid: 16095545].
549 Ng CS, Wang X, Faria SC, et al. Perfusion CT in patients with metastatic renal cell carcinoma treated with interferon. AJR. 2010;194(1):166-71. Not patients with early CKD. [pmid: 20028919].
550 Nielsen FS, Jorgensen LN, Ipsen M, et al. Long-term comparison of human insulin analogue B10Asp and soluble human insulin in IDDM patients on a basal/bolus insulin regimen. Diabetologia. 1995;38(5):592-8. Intervention not related to monitoring of CKD. [pmid: 7489843].
551 Niwa T, Aoyama I, Takayama F, et al. Urinary indoxyl sulfate is a clinical factor that affects the progression of renal failure. Mineral & Electrolyte Metabolism. 1999;25(1-2):118-22. Not a randomized trial. [pmid: 10207273].
552 Niwa T, Tsukushi S, Ise M, et al. Indoxyl sulfate and progression of renal failure: effects of a low-protein diet and oral sorbent on indoxyl sulfate production in uremic rats and undialyzed uremic patients. Mineral & Electrolyte Metabolism. 1997;23(3-6):179-84. Not human study. [pmid: 9387112].
553 Nohria A, Hasselblad V, Stebbins A, et al. Cardiorenal interactions: insights from the ESCAPE trial. Journal of the American College of Cardiology. 2008;51(13):1268-74. Intervention not related to monitoring of CKD. [pmid: 18371557].
554 Norris KC, Greene T, Kopple J, et al. Baseline predictors of renal disease progression in the African American Study of Hypertension and Kidney Disease. Journal of the American Society of Nephrology. 2006;17(10):2928-36. Intervention not related to monitoring of CKD. [pmid: 16959828].
555 Northridge DB, Jardine AG, Findlay IN, et al. Inhibition of the metabolism of atrial natriuretic factor causes diuresis and natriuresis in chronic heart failure. American Journal of Hypertension. 1990;3(9):682-7. Intervention not related to monitoring of CKD. [pmid: 2145874].
556 Obialo CI, Conner AC, Lebon LF. Maintaining patency of tunneled hemodialysis catheters--efficacy of aspirin compared to warfarin. Scandinavian Journal of Urology & Nephrology. 2003;37(2):172-6. Intervention not related to monitoring of CKD. [pmid: 12745728].
557 O'Hare AM, Kaufman JS, Covinsky KE, et al. Current guidelines for using angiotensin-converting enzyme inhibitors and angiotensin II-receptor antagonists in chronic kidney disease: is the evidence base relevant to older adults?. Annals of Internal Medicine. 2009;150(10):717-24. Not a randomized trial. [pmid: 19451579].
558 Oliveras A, Hurtado S, Vazquez S, et al. Efficacy and safety of doxazosin GITS in hypertensive renal transplant patients: comparison of 8 and 4 mg. Transplantation Proceedings. 2003;35(5):1732-5. Not patients with early CKD. [pmid: 12962775].
559 Onuigbo MAC. Does concurrent renin-angiotensin-aldosterone blockade in (older) chronic kidney disease patients play a role in the acute renal failure epidemic in US hospitalized patients?--Three cases of severe acute renal failure encountered in a northwestern Wisconsin Nephrology practice. Hemodialysis International. Suppl 1. 2009;13:S24-9. Not a randomized trial. [pmid: 19775421].
560 Onuigbo MAC. Reno-prevention vs. reno-protection: a critical re-appraisal of the evidence-base from the large RAAS blockade trials after ONTARGET--a call for more circumspection. Qjm. 2009;102(3):155-67. Not a randomized trial. [pmid: 19098074].
561 Orth SR, Hallan SI. Smoking: a risk factor for progression of chronic kidney disease and for cardiovascular morbidity and mortality in renal patients--absence of evidence or evidence of absence?. Clinical Journal of The American Society of Nephrology: CJASN. 2008;3(1):226-36. Not a randomized trial. [pmid: 18003763].
562 Ortiz MA, De Prado A, Donate T, et al. Angiotensin-converting enzyme polymorphism gene and evolution of nephropathy to end-stage renal disease. Nephrology. 2003;8(4):171-6. Not a randomized trial. [pmid: 15012717].
563 Oudemans-van Straaten HM, Wester JPJ, de Pont ACJM, et al. Anticoagulation strategies in continuous renal replacement therapy: can the choice be evidence based?. Intensive Care Medicine. 2006;32(2):188-202. Not a randomized trial. [pmid: 16453140].
564 Oue T, Namba M, Nakajima H, et al. Risk factors for the progression of microalbuminuria in Japanese type 2 diabetic patients--a 10 year follow-up study. Diabetes Research & Clinical Practice. 1999;46(1):47-55. Not a randomized trial. [pmid: 10580616].
565 Owada A, Nakao M, Koike J, et al. Effects of oral adsorbent AST-120 on the progression of chronic renal failure: a randomized controlled study. Kidney International - Supplement. 1997;63:S188-90. Intervention not related to monitoring of CKD. [pmid: 9407455].
566 Owada A, Suda S, Hata T. Antiproteinuric effect of niceritrol, a nicotinic acid derivative, in chronic renal disease with hyperlipidemia: a randomized trial. American Journal of Medicine. 2003;114(5):347-53. Intervention not related to monitoring of CKD. [pmid: 12714122].
567 Oyibo SO, Pritchard GM, McLay L, et al. Blood glucose overestimation in diabetic patients on continuous ambulatory peritoneal dialysis for end-stage renal disease. Diabetic Medicine. 2002;19(8):693-6. Not patients with early CKD. [pmid: 12147153].
568 Paap CM, Simpson KS, Horton MW, et al. Multiple-dose pharmacokinetics of pentoxifylline and its metabolites during renal insufficiency. Annals of Pharmacotherapy. 1996;30(7-8):724-9. Intervention not related to monitoring of CKD. [pmid: 8826548].
569 Padrik P, Leppik K, Arak A. Combination therapy with capecitabine and interferon alfa-2A in patients with advanced renal cell carcinoma: a phase II study. Urologic Oncology. 2004;22(5):387-92. Not patients with early CKD. [pmid: 15464918].
570 Pakfetrat M, Nikoo MH, Malekmakan L, et al. A comparison of sodium bicarbonate infusion versus normal saline infusion and its combination with oral acetazolamide for prevention of contrast-induced nephropathy: a randomized, double-blind trial. International Urology & Nephrology. 2009;41(3):629-34. Intervention not related to monitoring of CKD. [pmid: 19137409].
571 Paoletti E, Amidone M, Cassottana P, et al. Effect of sirolimus on left ventricular hypertrophy in kidney transplant recipients: a 1-year nonrandomized controlled trial. American Journal of Kidney Diseases. 2008;52(2):324-30. Not a randomized trial. [pmid: 18585837].
572 Paoletti E, Cannella G. Update on erythropoietin treatment: should hemoglobin be normalized in patients with chronic kidney disease?. Journal of the American Society of Nephrology. 2006;17(4 Suppl 2):S74-7. Not a randomized trial. [pmid: 16565252].
573 Park CW, Yun SN, Yang CW, et al. Serum and urine soluble HLA class I antigen concentrations are increased in patients with hemorrhagic fever with renal syndrome. Korean Journal of Internal Medicine. 1997;12(1):52-7. Not a randomized trial. [pmid: 9159038].
574 Parving HH. Is antihypertensive treatment the same for NIDDM and IDDM patients?. Diabetes Research & Clinical Practice. 1998;39(Suppl):S43-7. Not a randomized trial. [pmid: 9649959].
575 Parving HH. Benefits and cost of antihypertensive treatment in incipient and overt diabetic nephropathy. Journal of Hypertension - Supplement. 1998;16(1):S99-101. Not a randomized trial.
576 Parving HH, Lehnert H, Brochner-Mortensen J, et al. The effect of irbesartan on the development of diabetic nephropathy in patients with type 2 diabetes. New England Journal of Medicine. 2001;345(12):870-8. Intervention not related to monitoring of CKD. [pmid: 11565519].
577 Parving HH, Lewis JB, Ravid M, et al. Prevalence and risk factors for microalbuminuria in a referred cohort of type II diabetic patients: a global perspective. Kidney International. 2006;69(11):2057-63. Not a randomized trial. [pmid: 16612330].
578 Parving HH, Rossing P. The use of antihypertensive agents in prevention and treatment of diabetic nephropathy. Current Opinion in Nephrology & Hypertension. 1994;3(3):292-300. Not a randomized trial. [pmid: 7922255].
579 Pasero G, Priolo F, Marubini E, et al. Slow progression of joint damage in early rheumatoid arthritis treated with cyclosporin A. Arthritis & Rheumatism. 1996;39(6):1006-15. Intervention not related to monitoring of CKD. [pmid: 8651963].
580 Pecherstorfer M, Rivkin S, Body JJ, et al. Long-term safety of intravenous ibandronic acid for up to 4 years in metastatic breast cancer: an open-label trial. Clinical Drug Investigation. 2006;26(6):315-22. Intervention not related to monitoring of CKD. [pmid: 17163265].
581 Pedrinelli R, Dell'Omo G, Giampietro O, et al. Dissociation between albuminuria and insulinaemia in hypertensive and atherosclerotic men. Journal of Human Hypertension. 1999;13(2):129-34. Not a randomized trial. [pmid: 10100062].
582 Pedrini MT, Levey AS, Lau J, et al. The effect of dietary protein restriction on the progression of diabetic and nondiabetic renal diseases: a meta-analysis. Annals of Internal Medicine. 1996;124(7):627-32. Not a randomized trial. [pmid: 8607590].
583 Penno G, Chaturvedi N, Talmud PJ, et al. Effect of angiotensin-converting enzyme (ACE) gene polymorphism on progression of renal disease and the influence of ACE inhibition in IDDM patients: findings from the EUCLID Randomized Controlled Trial. EURODIAB Controlled Trial of Lisinopril in IDDM. Diabetes. 1998;47(9):1507-11. Not a randomized trial. [pmid: 9726242].
584 Pereira TV, Nunes ACF, Rudnicki M, et al. Influence of ACE I/D gene polymorphism in the progression of renal failure in autosomal dominant polycystic kidney disease: a meta-analysis. Nephrology Dialysis Transplantation. 2006;21(11):3155-63. Not a randomized trial.
585 Perkins RM, Aboudara MC, Uy AL, et al. Effect of pentoxifylline on GFR decline in CKD: a pilot, double-blind, randomized, placebo-controlled trial. American Journal of Kidney Diseases. 2009;53(4):606-16. Intervention not related to monitoring of CKD. [pmid: 19216016].
586 Perrin NESS, Jaremko GA, Berg UB. The effects of candesartan on diabetes glomerulopathy: a double-blind, placebo-controlled trial. Pediatric Nephrology. 2008;23(6):947-54. Intervention not related to monitoring of CKD. [pmid: 18270751].
587 Persson F, Rossing P, Hovind P, et al. Endothelial dysfunction and inflammation predict development of diabetic nephropathy in the Irbesartan in Patients with Type 2 Diabetes and Microalbuminuria (IRMA 2) study. Scandinavian Journal of Clinical & Laboratory Investigation. 2008;68(8):731-8. Intervention not related to monitoring of CKD. [pmid: 18609080].
588 Pescovitz MD. A cost too high to bear? Prophylaxis versus preemptive therapy to prevent post-transplantation cytomegalovirus. Kidney International. 2007;72(8):912-3. Not patients with early CKD. [pmid: 17914417].
589 Petersen LJ, Petersen JR, Talleruphuus U, et al. A randomized and double-blind comparison of isradipine and spirapril as monotherapy and in combination on the decline in renal function in patients with chronic renal failure and hypertension. Clinical Nephrology. 2001;55(5):375-83. Intervention not related to monitoring of CKD. [pmid: 11393383].
590 Peterson GE, de Backer T, Gabriel A, et al. Prevalence and correlates of left ventricular hypertrophy in the African American Study of Kidney Disease Cohort Study. Hypertension. 2007;50(6):1033-9. Not a randomized trial. [pmid: 17968003].
591 Peterson JC, Adler S, Burkart JM, et al. Blood pressure control, proteinuria, and the progression of renal disease. The Modification of Diet in Renal Disease Study. Annals of Internal Medicine. 1995;123(10):754-62. Intervention not related to monitoring of CKD. [pmid: 7574193].
592 Pfaller W, Thorwartl U, Nevinny-Stickel M, et al. Clinical value of fructose 1,6 bisphosphatase in monitoring renal proximal tubular injury. Kidney International - Supplement. 1994;47:S68-75. Intervention not related to monitoring of CKD. [pmid: 7532742].
593 Pham PTT, Pham PCT, Wilkinson AH. Management of renal dysfunction in the liver transplant recipient. Current Opinion in Organ Transplantation. 2009;14(3):231-9. Not a randomized trial. [pmid: 19395967].
594 Phillips CA, Molitch ME. The relationship between glucose control and the development and progression of diabetic nephropathy. Current Diabetes Reports. 2002;2(6):523-9. Not a randomized trial. [pmid: 12643159].
595 Pierce HL, Stevermer JJ. Does losartan (Cozaar) slow the progression of renal disease in patients with type 2 diabetes and nephropathy?. Journal of Family Practice. 2001;50(12):1083. Intervention not related to monitoring of CKD. [pmid: 11742614].
596 Pimenta E, Gaddam KK, Oparil S, et al. Effects of dietary sodium reduction on blood pressure in subjects with resistant hypertension: results from a randomized trial. Hypertension. 2009;54(3):475-81. Intervention not related to monitoring of CKD. [pmid: 19620517].
597 Pioro EP, Antel JP, Cashman NR, et al. Detection of cortical neuron loss in motor neuron disease by proton magnetic resonance spectroscopic imaging in vivo. Neurology. 1994;44(10):1933-8. Intervention not related to monitoring of CKD. [pmid: 7936250].
598 Pisoni R, Ruggenenti P, Remuzzi G. Drug-induced thrombotic microangiopathy: incidence, prevention and management. Drug Safety. 2001;24(7):491-501. Intervention not related to monitoring of CKD. [pmid: 11444722].
599 Plantinga LC, Jaar BG. Preventing repeat hospitalizations in dialysis patients: a call for action. Kidney International. 2009;76(3):249-51. Not patients with early CKD. [pmid: 19904257].
600 Poirier LA, Brown AT, Fink LM, et al. Blood S-adenosylmethionine concentrations and lymphocyte methylenetetrahydrofolate reductase activity in diabetes mellitus and diabetic nephropathy. Metabolism: Clinical & Experimental. 2001;50(9):1014-8. Not a randomized trial. [pmid: 11555831].
601 Polkinghorne KR, Lau KKP, Saunder A, et al. Does monthly native arteriovenous fistula blood-flow surveillance detect significant stenosis--a randomized controlled trial. Nephrology Dialysis Transplantation. 2006;21(9):2498-506. Not patients with early CKD.
602 Ponticelli C, Rivolta E. Ciclosporin in minimal-change glomerulopathy and in focal segmental glomerular sclerosis. American Journal of Nephrology. Suppl 1. 1990;10:105-9. Not a randomized trial. [pmid: 2256469].
603 Pontrelli P, Rossini M, Infante B, et al. Rapamycin inhibits PAI-1 expression and reduces interstitial fibrosis and glomerulosclerosis in chronic allograft nephropathy. Transplantation. 2008;85(1):125-34. Not patients with early CKD. [pmid: 18192922].
604 Porta C. Maintenance biotherapy with interleukin-2 and interferon for metastatic renal cell cancer. Expert Review of Anticancer Therapy. 2006;6(1):141-52. Not a randomized trial. [pmid: 16375651].
605 Portaluppi F, Vergnani L, Manfredini R, et al. Time-dependent effect of isradipine on the nocturnal hypertension in chronic renal failure. American Journal of Hypertension. 1995;8(7):719-26. Intervention not related to monitoring of CKD. [pmid: 7546498].
606 Poschel KA, Bucha E, Esslinger HU, et al. Pharmacodynamics and pharmacokinetics of polyethylene glycol-hirudin in patients with chronic renal failure. Kidney International. 2000;58(6):2478-84. Intervention not related to monitoring of CKD. [pmid: 11115081].
607 Poulsen PL, Ebbehoj E, Hansen KW, et al. High normo- or low microalbuminuria: basis for intervention in insulin-dependent diabetes mellitus. Kidney International - Supplement. 1997;63:S15-8. Intervention not related to monitoring of CKD. [pmid: 9407413].
608 Poulsen PL, Hansen KW, Mogensen CE. Ambulatory blood pressure in the transition from normo- to microalbuminuria. A longitudinal study in IDDM patients. Diabetes. 1994;43(10):1248-53. Not a randomized trial. [pmid: 7926296].
609 Pozzi C, Andrulli S, Del Vecchio L, et al. Corticosteroid effectiveness in IgA nephropathy: long-term results of a randomized, controlled trial. Journal of the American Society of Nephrology. 2004;15(1):157-63. Not patients with early CKD. [pmid: 14694168].
610 Pozzi C, Del Vecchio L, Locatelli F. Can immunosuppressive therapy be useful in IgA nephropathy when the ‘Point of No Return’ has already been exceeded?. Nephron. 2002;92(3):699-701. Not a randomized trial. [pmid: 12372958].
611 Prisant LM, Loebl DH, Mulloy LL. Scleroderma renal crisis. Journal of Clinical Hypertension. 2003;5(2):168-70. Not a randomized trial. [pmid: 12671333].
612 Rachmani R, Slavachevski I, Berla M, et al. Teaching and motivating patients to control their risk factors retards progression of cardiovascular as well as microvascular sequelae of Type 2 diabetes mellitus- a randomized prospective 8 years follow-up study. Diabetic Medicine. 2005;22(4):410-4. Intervention not related to monitoring of CKD. [pmid: 15787665].
613 Rahman M, Baimbridge C, Davis BR, et al. Progression of kidney disease in moderately hypercholesterolemic, hypertensive patients randomized to pravastatin versus usual care: a report from the Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT). American Journal of Kidney Diseases. 2008;52(3):412-24. Intervention not related to monitoring of CKD. [pmid: 18676075].
614 Ramin SM, Vidaeff AC, Yeomans ER, et al. Chronic renal disease in pregnancy. Obstetrics & Gynecology. 2006;108(6):1531-9. Not a randomized trial. [pmid: 17138789].
615 Rammohan C, Fintel D. Dosing considerations and monitoring of low molecular weight heparins and glycoprotein IIb/IIIa antagonists in patients with renal insufficiency. Current Cardiology Reports. 2003;5(4):303-9. Not a randomized trial. [pmid: 12801450].
616 Ranich T, Bhathena SJ, Velasquez MT. Protective effects of dietary phytoestrogens in chronic renal disease. Journal of Renal Nutrition. 2001;11(4):183-93. Not a randomized trial. [pmid: 11679998].
617 Rasche FM, Keller F, Lepper PM, et al. High-dose intravenous immunoglobulin pulse therapy in patients with progressive immunoglobulin A nephropathy: a long-term follow-up. Clinical & Experimental Immunology. 2006;146(1):47-53. Not a randomized trial. [pmid: 16968397].
618 Rasmussen K, Pedersen E. Monitoring of renal allografts by Doppler ultrasound: precision and reference values. Scandinavian Journal of Clinical & Laboratory Investigation. 1990;50(1):51-5. Intervention not related to monitoring of CKD. [pmid: 2180058].
619 Ravid M, Neumann L, Lishner M. Plasma lipids and the progression of nephropathy in diabetes mellitus type II: effect of ACE inhibitors. Kidney International. 1995;47(3):907-10. Intervention not related to monitoring of CKD. [pmid: 7752591].
620 Reach I, Luong N, Chastang C, et al. Dose effect relationship of reviparin in chronic hemodialysis: a crossover study versus nadroparin. Artificial Organs. 2001;25(7):591-5. Not patients with early CKD. [pmid: 11493282].
621 Redman BG, Flaherty L, Martino S, et al. Effect of calcium replacement on the hemodynamic changes associated with high dose interleukin-2 therapy. American Journal of Clinical Oncology. 1992;15(4):340-3. Intervention not related to monitoring of CKD. [pmid: 1514532].
622 Regazzi MB, Rinaldi M, Molinaro M, et al. Clinical pharmacokinetics of tacrolimus in heart transplant recipients. Therapeutic Drug Monitoring. 1999;21(1):2-7. Not patients with early CKD. [pmid: 10051048].
623 Reichard P. Are there any glycemic thresholds for the serious microvascular diabetic complications?. Journal of Diabetes & its Complications. 1995;9(1):25-30. Intervention not related to monitoring of CKD. [pmid: 7734740].
624 Reichert LJ, Koene RA, Wetzels JF. Urinary excretion of beta 2-microglobulin predicts renal outcome in patients with idiopathic membranous nephropathy. Journal of the American Society of Nephrology. 1995;6(6):1666-9. Not a randomized trial. [pmid: 8749696].
625 Reilly JP, Ramee SR. Vascular brachytherapy in renal artery restenosis. Current Opinion in Cardiology. 2004;19(4):332-5. Not a randomized trial. [pmid: 15218392].
626 Remuzzi G, Macia M, Ruggenenti P. Prevention and treatment of diabetic renal disease in type 2 diabetes: the BENEDICT study. Journal of the American Society of Nephrology. 2006;17(4 Suppl 2):S90-7. Intervention not related to monitoring of CKD. [pmid: 16565256].
627 Remuzzi G, Perico N, Gotti E, et al. The kidney transplant program at the Bergamo Center. Clinical Transplants. 2000:179-91. Not a randomized trial.
628 Repmann R, Goldschmidt AJW, Richter A. Adjuvant therapy of renal cell carcinoma patients with an autologous tumor cell lysate vaccine: a 5-year follow-up analysis. [Erratum appears in Anticancer Res. 2003;23:5370]. Anticancer Research. 2003;23(2A):969-74. Not patients with early CKD. [pmid: 12820332].
629 Richer M, Robert S, Lebel M. Renal hemodynamics during norepinephrine and low-dose dopamine infusions in man. Critical Care Medicine. 1996;24(7):1150-6. Intervention not related to monitoring of CKD. [pmid: 8674327].
630 Ricos C, Jimenez CV, Hernandez A, et al. Biological variation in urine samples used for analyte measurements. Clinical Chemistry. 1994;40(3):472-7. Not a randomized trial. [pmid: 7510594].
631 Riess FC, Moshar S, Bader R, et al. Clinical outcome of patients with and without renal impairment undergoing a minimally invasive LIMA-to-LAD bypass operation. Heart Surgery Forum. 2000;3(4):313-8. Intervention not related to monitoring of CKD. [pmid: 11178293].
632 Rini BI, Halabi S, Taylor J, et al. Cancer and Leukemia Group B 90206: A randomized phase III trial of interferon-alpha or interferon-alpha plus anti-vascular endothelial growth factor antibody (bevacizumab) in metastatic renal cell carcinoma. Clinical Cancer Research. 2004;10(8):2584-6. Not patients with early CKD. [pmid: 15102658].
633 Rizzoni D, Porteri E, Boari GEM, et al. Prognostic significance of small-artery structure in hypertension. Circulation. 2003;108(18):2230-5. Not a randomized trial. [pmid: 14557363].
634 Roderick PJ, Atkins RJ, Smeeth L, et al. Detecting chronic kidney disease in older people; what are the implications?. [Erratum appears in Age Ageing. 2009 Sep;38(5):638 Note: Flectcher, Astrid E [corrected to Fletcher, Astrid E]]. Age & Ageing. 2008;37(2):179-86. Not a randomized trial. [pmid: 18083723].
635 Rodger RS, Muralikrishna GS, Halls DJ, et al. Ranitidine suppresses aluminium absorption in man. Clinical Science. 1991;80(5):505-8. Not patients with early CKD. [pmid: 1851692].
636 Rodger RS, Sheldon WL, Watson MJ, et al. Zinc deficiency and hyperprolactinaemia are not reversible causes of sexual dysfunction in uraemia. Nephrology Dialysis Transplantation. 1989;4(10):888-92. Intervention not related to monitoring of CKD.
637 Ronco C, Brendolan A, Milan M, et al. Impact of biofeedback-induced cardiovascular stability on hemodialysis tolerance and efficiency. Kidney International. 2000;58(2):800-8. Not patients with early CKD. [pmid: 10916105].
638 Rosner GL, Stadler W, Ratain MJ. Randomized discontinuation design: application to cytostatic antineoplastic agents. Journal of Clinical Oncology. 2002;20(22):4478-84. Intervention not related to monitoring of CKD. [pmid: 12431972].
639 Rossert J, Froissart M, Jacquot C. Anemia management and chronic renal failure progression. Kidney International - Supplement. 2005;(99):S76-81. Not a randomized trial. [pmid: 16336582].
640 Rossert J, Levin A, Roger SD, et al. Effect of early correction of anemia on the progression of CKD. American Journal of Kidney Diseases. 2006;47(5):738-50. Intervention not related to monitoring of CKD. [pmid: 16632012].
641 Rossert JA, McClellan WM, Roger SD, et al. Contribution of anaemia to progression of renal disease: a debate. Nephrology Dialysis Transplantation. Suppl 1. 2002;17:60-6. Not a randomized trial.
642 Roux C. The methodology of clinical trials of oral tiludronate in Paget's disease of bone. Bone. 1995;17(5 Suppl):497S-9S. Not a randomized trial. [pmid: 8573426].
643 Roy JN, Barama A, Poirier C, et al. Cyp3A4, Cyp3A5, and MDR-1 genetic influences on tacrolimus pharmacokinetics in renal transplant recipients. Pharmacogenetics & Genomics. 2006;16(9):659-65. Not a randomized trial. [pmid: 16906020].
644 Rudberg S, Rasmussen LM, Bangstad HJ, et al. Influence of insertion/deletion polymorphism in the ACE-I gene on the progression of diabetic glomerulopathy in type 1 diabetic patients with microalbuminuria. Diabetes Care. 2000;23(4):544-8. Not a randomized trial. [pmid: 10857950].
645 Ruggenenti P, Fassi A, Ilieva AP, et al. Preventing microalbuminuria in type 2 diabetes. New England Journal of Medicine. 2004;351(19):1941-51. Intervention not related to monitoring of CKD. [pmid: 15516697].
646 Ruggenenti P, Gaspari F, Perna A, et al. Cross sectional longitudinal study of spot morning urine protein:creatinine ratio, 24 hour urine protein excretion rate, glomerular filtration rate, and end stage renal failure in chronic renal disease in patients without diabetes. [Erratum appears in BMJ 1998 Nov 28;317(7171):1491]. BMJ. 1998;316(7130):504-9. Not a randomized trial. [pmid: 9501711].
647 Ruggenenti P, Pagano E, Tammuzzo L, et al. Ramipril prolongs life and is cost effective in chronic proteinuric nephropathies. Kidney International. 2001;59(1):286-94. Intervention not related to monitoring of CKD. [pmid: 11135082].
648 Ruggenenti P, Perna A, Gherardi G, et al. Chronic proteinuric nephropathies: outcomes and response to treatment in a prospective cohort of 352 patients with different patterns of renal injury. American Journal of Kidney Diseases. 2000;35(6):1155-65. Intervention not related to monitoring of CKD. [pmid: 10845831].
649 Ruggenenti P, Perna A, Lesti M, et al. Pretreatment blood pressure reliably predicts progression of chronic nephropathies. GISEN Group. Kidney International. 2000;58(5):2093-101. Not a randomized trial. [pmid: 11044230].
650 Ruggenenti P, Perna A, Loriga G, et al. Blood-pressure control for renoprotection in patients with non-diabetic chronic renal disease (REIN-2): multicentre, randomised controlled trial. Lancet. 2005;365(9463):939-46. Intervention not related to monitoring of CKD. [pmid: 15766995].
651 Ruggenenti P, Perna A, Mosconi L, et al. Proteinuria predicts end-stage renal failure in non-diabetic chronic nephropathies. The “Gruppo Italiano di Studi Epidemiologici in Nefrologia” (GISEN). Kidney International - Supplement. 1997;63:S54-7. Not patients with early CKD. [pmid: 9407422].
652 Ruggenenti P, Perna A, Remuzzi G, et al. Retarding progression of chronic renal disease: the neglected issue of residual proteinuria. Kidney International. 2003;63(6):2254-61. Not patients with early CKD. [pmid: 12753315].
653 Ruggenenti P, Perna A, Zoccali C, et al. Chronic proteinuric nephropathies. II. Outcomes and response to treatment in a prospective cohort of 352 patients: differences between women and men in relation to the ACE gene polymorphism. Gruppo Italiano di Studi Epidemologici in Nefrologia (Gisen). Journal of the American Society of Nephrology. 2000;11(1):88-96. Intervention not related to monitoring of CKD. [pmid: 10616844].
654 Ruilope LM, Casal MC, Guerrero L, et al. Sodium intake does not influence the effect of verapamil in hypertensive patients with mild renal insufficiency. Drugs. Suppl 1. 1992;44:94-8. Intervention not related to monitoring of CKD. [pmid: 1283591].
655 Ruiz JC, Campistol JM, Grinyo JM, et al. Early cyclosporine a withdrawal in kidney-transplant recipients receiving sirolimus prevents progression of chronic pathologic allograft lesions. Transplantation. 2004;78(9):1312-8. Not patients with early CKD. [pmid: 15548969].
656 Ruiz JC, Campistol JM, Mota A, et al. Early elimination of cyclosporine in kidney transplant recipients receiving sirolimus prevents progression of chronic pathologic allograft lesions. Transplantation Proceedings. 2003;35(5):1669-70. Not patients with early CKD. [pmid: 12962750].
657 Rush DN, Cockfield SM, Nickerson PW, et al. Factors associated with progression of interstitial fibrosis in renal transplant patients receiving tacrolimus and mycophenolate mofetil. Transplantation. 2009;88(7):897-903. Not patients with early CKD. [pmid: 19935461].
658 Ruzicka M, Burns KD, Culleton B, et al. Treatment of hypertension in patients with nondiabetic chronic kidney disease. Canadian Journal of Cardiology. 2007;23(7):595-601. Not a randomized trial. [pmid: 17534470].
659 Sagawa M, Oka M, Chaboyer W. The utility of cognitive behavioural therapy on chronic haemodialysis patients' fluid intake: a preliminary examination. International Journal of Nursing Studies. 2003;40(4):367-73. Not patients with early CKD. [pmid: 12667513].
660 Sahadevan M, Kasiske BL. Hyperlipidemia in kidney disease: causes and consequences. Current Opinion in Nephrology & Hypertension. 2002;11(3):323-9. Not a randomized trial. [pmid: 11981263].
661 Saidi JA, Newhouse JH, Sawczuk IS. Radiologic follow-up of patients with T1-3a,b,c or T4N+M0 renal cell carcinoma after radical nephrectomy. Urology. 1998;52(6):1000-3. Not patients with early CKD. [pmid: 9836544].
662 Salako BL, Finomo FO, Kadiri S, et al. Comparative effect of lisinopril and lacidipine on urinary albumin excretion in patients with type 11 diabetic nephropathy. African Journal of Medicine & Medical Sciences. 2002;31(1):53-7. Intervention not related to monitoring of CKD. [pmid: 12518931].
663 Sands JJ, Jabyac PA, Miranda CL, et al. Intervention based on monthly monitoring decreases hemodialysis access thrombosis. ASAIO Journal. 1999;45(3):147-50. Not patients with early CKD. [pmid: 10360713].
664 Sarapa N, Wickremasingha P, Ge N, et al. Lack of effect of DX-619, a novel des-fluoro(6)-quinolone, on glomerular filtration rate measured by serum clearance of cold iohexol. Antimicrobial Agents & Chemotherapy. 2007;51(6):1912-7. Intervention not related to monitoring of CKD. [pmid: 17371829].
665 Sarnak MJ, Greene T, Wang X, et al. The effect of a lower target blood pressure on the progression of kidney disease: long-term follow-up of the modification of diet in renal disease study. Annals of Internal Medicine. 2005;142(5):342-51. Intervention not related to monitoring of CKD. [pmid: 15738453].
666 Sattler FR, Cowan R, Nielsen DM, et al. Trimethoprim-sulfamethoxazole compared with pentamidine for treatment of Pneumocystis carinii pneumonia in the acquired immunodeficiency syndrome. A prospective, noncrossover study. Annals of Internal Medicine. 1988;109(4):280-7. Intervention not related to monitoring of CKD. [pmid: 3260759].
667 Sav T, Tokgoz B, Sipahioglu MH, et al. Is there a difference between the allergic potencies of the iron sucrose and low molecular weight iron dextran?. Renal Failure. 2007;29(4):423-6. Intervention not related to monitoring of CKD. [pmid: 17497463].
668 Sawicki PT, Muhlhauser I, Didjurgeit U, et al. Intensified antihypertensive therapy is associated with improved survival in type 1 diabetic patients with nephropathy. Journal of Hypertension. 1995;13(8):933-8. Intervention not related to monitoring of CKD. [pmid: 8557972].
669 Sawicki PT, Muhlhauser I, Didjurgeit U, et al. Effects of intensification of antihypertensive care in diabetic nephropathy. Journal of Diabetes & its Complications. 1995;9(4):315-7. Intervention not related to monitoring of CKD. [pmid: 8573755].
670 Scarpioni R, Michieletti E, Cristinelli L, et al. Atherosclerotic renovascular disease: medical therapy versus medical therapy plus renal artery stenting in preventing renal failure progression: the rationale and study design of a prospective, multicenter and randomized trial (NITER). Journal of Nephrology. 2005;18(4):423-8. Intervention not related to monitoring of CKD. [pmid: 16245247].
671 Schadewaldt P, Killius S, Kamalanathan L, et al. Renal excretion of galactose and galactitol in patients with classical galactosaemia, obligate heterozygous parents and healthy subjects. Journal of Inherited Metabolic Disease. 2003;26(5):459-79. Not patients with early CKD. [pmid: 14518827].
672 Schaeffner ES, Kurth T, Bowman TS, et al. Blood pressure measures and risk of chronic kidney disease in men. Nephrology Dialysis Transplantation. 2008;23(4):1246-51. Not a randomized trial.
673 Schetz M, Bove T, Morelli A, et al. Prevention of cardiac surgery-associated acute kidney injury. International Journal of Artificial Organs. 2008;31(2):179-89. Intervention not related to monitoring of CKD. [pmid: 18311734].
674 Schiele J, Nowack R, Julian BA, et al. Treatment of immunoglobulin A nephropathy. Annales de Medecine Interne. 1999;150(2):127-36. Intervention not related to monitoring of CKD. [pmid: 10392261].
675 Schjoedt KJ, Hansen HP, Tarnow L, et al. Long-term prevention of diabetic nephropathy: an audit. Diabetologia. 2008;51(6):956-61. Not a randomized trial. [pmid: 18385971].
676 Schlosser K, Scigalla P. Biochemical markers as surrogates in clinical trials in patients with metastatic bone disease and osteoporosis. Scandinavian Journal of Clinical and Laboratory Investigation Supplement. 1997;227:21-8. Intervention not related to monitoring of CKD. [pmid: 9127465].
677 Schluchter MD, Greene T, Beck GJ. Analysis of change in the presence of informative censoring: application to a longitudinal clinical trial of progressive renal disease. Statistics in Medicine. 2001;20(7):989-1007. Not a randomized trial. [pmid: 11276031].
678 Schmieder RE, Langenfeld MR, Gatzka CD, et al. Impact of alpha- versus beta-blockers on hypertensive target organ damage: results of a double-blind, randomized, controlled clinical trial. American Journal of Hypertension. 1997;10(9 Pt 1):985-91. Intervention not related to monitoring of CKD. [pmid: 9324103].
679 Schoffski P, Guillem V, Garcia M, et al. Phase II randomized study of Plitidepsin (Aplidin), alone or in association with L-carnitine, in patients with unresectable advanced renal cell carcinoma. Marine Drugs. 2009;7(1):57-70. Intervention not related to monitoring of CKD. [pmid: 19370171].
680 Schrier RW. Treating high-risk diabetic hypertensive patients with comorbid conditions. American Journal of Kidney Diseases. 2000;36(3 Suppl 1):S10-7. Not a randomized trial. [pmid: 10986154].
681 Schrier RW, Estacio RO. The effect of angiotensin-converting enzyme inhibitors on the progression of nondiabetic renal disease: a pooled analysis of individual-patient data from 11 randomized, controlled trials. Annals of Internal Medicine. 2001;135(2):138-9. Intervention not related to monitoring of CKD. [pmid: 11453714].
682 Schrier RW, Estacio RO, Esler A, et al. Effects of aggressive blood pressure control in normotensive type 2 diabetic patients on albuminuria, retinopathy and strokes. Kidney International. 2002;61(3):1086-97. Intervention not related to monitoring of CKD. [pmid: 11849464].
683 Schwartz MM, Korbet SM, Lewis EJ, et al. The prognosis and pathogenesis of severe lupus glomerulonephritis. Nephrology Dialysis Transplantation. 2008;23(4):1298-306. Not a randomized trial.
684 Senitzer D, Greenstein SM, Louis P, et al. Monitoring serum IL-2R levels in cadaver renal transplantation: a prospective, blinded study. Transplantation Proceedings. 1991;23(1 Pt 2):1279-81. Not patients with early CKD. [pmid: 1989212].
685 Seron D, Oppenheimer F, Pallardo LM, et al. Fluvastatin in the prevention of renal transplant vasculopathy: results of a prospective, randomized, double-blind, placebo-controlled trial. Transplantation. 2008;86(1):82-7. Not patients with early CKD. [pmid: 18622282].
686 Shah A, Lettieri J, Blum R, et al. Pharmacokinetics of intravenous ciprofloxacin in normal and renally impaired subjects. Journal of Antimicrobial Chemotherapy. 1996;38(1):103-16. Not a randomized trial. [pmid: 8858462].
687 Shah S, Paparello J, Danesh FR. Effects of statin therapy on the progression of chronic kidney disease. Advances in Chronic Kidney Disease. 2005;12(2):187-95. Not a randomized trial. [pmid: 15822054].
688 Sharma M, Rao M, Jacob S, et al. A controlled trial of intermittent enteral nutrient supplementation in maintenance hemodialysis patients. Journal of Renal Nutrition. 2002;12(4):229-37. Not patients with early CKD. [pmid: 12382215].
689 Shen Y, Fleming TR. Assessing effects on long-term survival after early termination of randomized trials. Lifetime Data Analysis. 1999;5(1):55-66. Not a randomized trial. [pmid: 10214002].
690 Shigenaga Ai, Tamura K, Dejima T. Effects of angiotensin II type 1 receptor blocker on blood pressure variability and cardiovascular remodeling in hypertensive patients on chronic peritoneal dialysis. Nephron. 2009;112(1):c31-40. Not patients with early CKD. [pmid: 19342867].
691 Shin YS, Yang CW, Ahn HJ, et al. Clinical significance of anti-endothelial cell antibody in renal transplant recipients. Korean Journal of Internal Medicine. 2001;16(1):24-9. Not patients with early CKD. [pmid: 11417301].
692 Siddiqi N, El Shahat O, Bokhari E, et al. The effect of use of dates on serum potassium in nondiabetic hemodialysis patients. Saudi Journal of Kidney Diseases & Transplantation. 2009;20(6):1018-22. Not patients with early CKD. [pmid: 19861864].
693 Simeckova A, Zamrazil V, Cerovska J, et al. Does a relationship exist between ioduria, magnesiuria and calciuria?. Journal of Trace Elements in Medicine & Biology. 2000;14(1):28-30. Not a randomized trial. [pmid: 10836531].
694 Sinert R, Doty CI. Evidence-based emergency medicine review. Prevention of contrast-induced nephropathy in the emergency department. Annals of Emergency Medicine. 2007;50(3):335-45. Not a randomized trial. [pmid: 17512638].
695 Singh-Franco D, Machado C, Tuteja S, et al. Trospium chloride for the treatment of overactive bladder with urge incontinence. Clinical Therapeutics. 2005;27(5):511-30. Not a randomized trial. [pmid: 15978301].
696 Sirken GR, Shah C, Raja R. Slow-flow venous pressure for detection of arteriovenous graft malfunction. Kidney International. 2003;63(5):1894-8. Not a randomized trial. [pmid: 12675869].
697 Siu YP, Leung KT, Tong MKH, et al. Use of allopurinol in slowing the progression of renal disease through its ability to lower serum uric acid level. American Journal of Kidney Diseases. 2006;47(1):51-9. Intervention not related to monitoring of CKD. [pmid: 16377385].
698 Skipper GE, Weinmann W, Thierauf A, et al. Ethyl glucuronide: a biomarker to identify alcohol use by health professionals recovering from substance use disorders. Alcohol & Alcoholism. 2004;39(5):445-9. Intervention not related to monitoring of CKD. [pmid: 15289206].
699 Slowik MM. Early education of patients with chronic renal insufficiency: the Healthy Start program. Case study of the anemic patient. Nephrology Nursing Journal: Journal of the American Nephrology Nurses' Association. 2001;28(6):643-6. Not a randomized trial. [pmid: 12143474].
700 Smith RJH, Alexander J, Barlow PN, et al. New approaches to the treatment of dense deposit disease. Journal of the American Society of Nephrology. 2007;18(9):2447-56. Not a randomized trial. [pmid: 17675665].
701 Smulders YM, van Eeden AE, Stehouwer CD, et al. Can reduction in hypertriglyceridaemia slow progression of microalbuminuria in patients with non-insulin-dependent diabetes mellitus?. European Journal of Clinical Investigation. 1997;27(12):997-1002. Intervention not related to monitoring of CKD. [pmid: 9466127].
702 Snyder S, Pendergraph B. Detection and evaluation of chronic kidney disease. American Family Physician. 2005;72(9):1723-32. Not a randomized trial. [pmid: 16300034].
703 Solomkin JS, Fant WK, Rivera JO, et al. Randomized trial of imipenem/cilastatin versus gentamicin and clindamycin in mixed flora infections. American Journal of Medicine. 1985;78(6A):85-91. Intervention not related to monitoring of CKD. [pmid: 3890538].
704 Solomon LR, Hendler ED. Prospective controlled study of androgen therapy in the anemia of chronic renal disease: effects on iron kinetics. Acta Haematologica. 1988;79(1):12-9. Not a randomized trial. [pmid: 3124456].
705 Soroka N, Silverberg DS, Greemland M, et al. Comparison of a vegetable-based (soya) and an animal-based low-protein diet in predialysis chronic renal failure patients. Nephron. 1998;79(2):173-80. Not patients with early CKD. [pmid: 9647497].
706 Souchet T, Durand Zaleski I, Hannedouche T, et al. An economic evaluation of Losartan therapy in type 2 diabetic patients with nephropathy: an analysis of the RENAAL study adapted to France. Diabetes & Metabolism. 2003;29(1):29-35. Not patients with early CKD. [pmid: 12629445].
707 Sozen S, Gurocak S, Erdem O, et al. Cyclooxygenase-2 expression: does it have a probable role in tumorigenesis mechanisms of renal cell carcinoma?. International Urology & Nephrology. 2008;40(2):295-301. Not a randomized trial. [pmid: 17899436].
708 Stefoni S, Mosconi G, La Manna G, et al. Low-dosage ibopamine treatment in progressive renal failure: a long-term multicentre trial. American Journal of Nephrology. 1996;16(6):489-99. Intervention not related to monitoring of CKD. [pmid: 8955760].
709 Stein WD, Yang J, Bates SE, et al. Bevacizumab reduces the growth rate constants of renal carcinomas: a novel algorithm suggests early discontinuation of bevacizumab resulted in a lack of survival advantage. Oncologist. 2008;13(10):1055-62. Intervention not related to monitoring of CKD. [pmid: 18827177].
710 Stevenson JC, Hillard TC, Lees B, et al. Postmenopausal bone loss: does HRT always work?. International Journal of Fertility & Menopausal Studies. Suppl 2. 1993;38:88-91. Intervention not related to monitoring of CKD. [pmid: 8252111].
711 Stoves J, Inglis H, Newstead CG. A randomized study of oral vs intravenous iron supplementation in patients with progressive renal insufficiency treated with erythropoietin. Nephrology Dialysis Transplantation. 2001;16(5):967-74. Not patients with early CKD.
712 Stoves J, Newstead CG, Baczkowski AJ, et al. A randomized controlled trial of immunosuppression conversion for the treatment of chronic allograft nephropathy. Nephrology Dialysis Transplantation. 2004;19(8):2113-20. Not patients with early CKD.
713 Strippoli GFM, Bonifati C, Craig M, et al. Angiotensin converting enzyme inhibitors and angiotensin II receptor antagonists for preventing the progression of diabetic kidney disease. Cochrane Database of Systematic Reviews. 2006;(4):CD006257. Not a randomized trial. [pmid: 17054288].
714 Strippoli GFM, Craig MC, Schena FP, et al. Role of blood pressure targets and specific antihypertensive agents used to prevent diabetic nephropathy and delay its progression. Journal of the American Society of Nephrology. 2006;17(4 Suppl 2):S153-5. Not a randomized trial. [pmid: 16565242].
715 Studies of Ocular Complications of ARGTACTG. The ganciclovir implant plus oral ganciclovir versus parenteral cidofovir for the treatment of cytomegalovirus retinitis in patients with acquired immunodeficiency syndrome: The Ganciclovir Cidofovir Cytomegalovirus Retinitis Trial. American Journal of Ophthalmology. 2001;131(4):457-67. Intervention not related to monitoring of CKD. [pmid: 11292409].
716 Sumethkul V, Changsirikulchai S, Lothuvachai T, et al. Sirolimus attenuates the rate of progression of early chronic allograft nephropathy. Transplantation Proceedings. 2006;38(10):3470-2. Not patients with early CKD. [pmid: 17175307].
717 Sundaram S, Mainali R, Norfolk ER, et al. Fibrillary glomerulopathy secondary to light chain deposition disease in a patient with monoclonal gammopathy. Annals of Clinical & Laboratory Science. 2007;37(4):370-4. Intervention not related to monitoring of CKD. [pmid: 18000296].
718 Sunder-Plassmann G, Horl WH. Importance of iron supply for erythropoietin therapy. Nephrology Dialysis Transplantation. 1995;10(11):2070-6. Not patients with early CKD.
719 Sussman SK. Nonvascular intervention in the genitourinary tract. Current Opinion in Radiology. 1991;3(5):669-80. Intervention not related to monitoring of CKD. [pmid: 1718382].
720 Suzuki H, Moriwaki K, Nakamoto H, et al. Blood pressure reduction in the morning yields beneficial effects on progression of chronic renal insufficiency with regression of left ventricular hypertrophy. Clinical & Experimental Hypertension. 2002;24(1-2):51-63. Intervention not related to monitoring of CKD. [pmid: 11848169].
721 Svensson M, Gustafsson F, Galatius S, et al. How prevalent is hyperkalemia and renal dysfunction during treatment with spironolactone in patients with congestive heart failure?. Journal of Cardiac Failure. 2004;10(4):297-303. Not a randomized trial. [pmid: 15309695].
722 Tabaei BP, Al-Kassab AS, Ilag LL, et al. Does microalbuminuria predict diabetic nephropathy?. Diabetes Care. 2001;24(9):1560-6. Not a randomized trial. [pmid: 11522699].
723 Takahashi T, Reed SD, Schulman KA. Cost-effectiveness of the oral adsorbent AST-120 versus placebo for chronic kidney disease. Nephrology. 2008;13(5):419-27. Not a randomized trial. [pmid: 18518936].
724 Takei T, Otsubo S, Uchida K, et al. Effects of sevelamer on the progression of vascular calcification in patients on chronic haemodialysis. Nephron. 2008;108(4):c278-83. Not patients with early CKD. [pmid: 18434749].
725 Talaulikar GS, Gallagher MP, Carney GM, et al. Switchover to generic cyclosporine in stable renal transplant recipients: a single unit experience. Nephrology. 2004;9(6):418-21. Not patients with early CKD. [pmid: 15663647].
726 Tamura S, Ueki K, Ideura H, et al. Corticosteroid therapy in patients with IgA nephropathy and impaired renal function. Clinical Nephrology. 2001;55(3):192-5. Not a randomized trial. [pmid: 11316238].
727 Tang IY, Murray PT. Prevention of perioperative acute renal failure: what works?. Best Practice & Research. Clinical Anaesthesiology. 2004;18(1):91-111. Intervention not related to monitoring of CKD.
728 Tang S, Ho YW, Leung CY, et al. Mycophenolate mofetil in the treatment of steroid-resistant primary focal segmental glomerulosclerosis. Journal of Nephrology. 2005;18(4):429-32. Not patients with early CKD. [pmid: 16245248].
729 Teachey DT, Seif AE, Brown VI, et al. Targeting Notch signaling in autoimmune and lymphoproliferative disease. Blood. 2008;111(2):705-14. Not human study. [pmid: 17925488].
730 Tedesco-Silva H Jr., Vitko S, Pascual J, et al. 12-month safety and efficacy of everolimus with reduced exposure cyclosporine in de novo renal transplant recipients. Transplant International. 2007;20(1):27-36. Not patients with early CKD. [pmid: 17181650].
731 Teschan PE, Beck GJ, Dwyer JT, et al. Effect of a ketoacid-aminoacid-supplemented very low protein diet on the progression of advanced renal disease: a reanalysis of the MDRD feasibility study. Clinical Nephrology. 1998;50(5):273-83. Not patients with early CKD. [pmid: 9840314].
732 Textor SC. Renovascular hypertension update. Current Hypertension Reports. 2006;8(6):521-7. Not a randomized trial. [pmid: 17087862].
733 Thall PF, Wooten LH, Tannir NM. Monitoring event times in early phase clinical trials: some practical issues. Clinical Trials. 2005;2(6):467-78. Not a randomized trial. [pmid: 16422307].
734 Thomas DH, Taylor JD, Barnaby OS, et al. Determination of free catecholamines in urine by tandem affinity/ion-pair chromatography and flow injection analysis. Clinica Chimica Acta. 2008;398(1-2):63-9. Intervention not related to monitoring of CKD.
735 Thomsen HS, Hvid-Jacobsen K, Nielsen SL. Alternating use of 123I and 131I hippuran for routine postoperative monitoring of transplanted kidneys is impracticable. Acta Radiologica. 1987;28(3):365-7. Not patients with early CKD. [pmid: 2958047].
736 Tiseo M, Martelli O, Mancuso A, et al. Short hydration regimen and nephrotoxicity of intermediate to high-dose cisplatin-based chemotherapy for outpatient treatment in lung cancer and mesothelioma. Tumori. 2007;93(2):138-44. Not a randomized trial. [pmid: 17557559].
737 Tobe S, Epstein M. The use of calcium antagonists in the treatment of hypertensive persons with kidney disease. Current Hypertension Reports. 2002;4(3):191-4. Not a randomized trial. [pmid: 12003700].
738 Tobita I, Suzuki S, Kobayashi T, et al. A programme to encourage participation of haemodialysis patients in an exercise regimen. Journal of Renal Care. 2009;35(1):48-53. Not patients with early CKD. [pmid: 19200278].
739 Tod M, Minozzi C, Beaucaire G, et al. Isepamicin in intensive care unit patients with nosocomial pneumonia: population pharmacokinetic-pharmacodynamic study. Journal of Antimicrobial Chemotherapy. 1999;44(1):99-108. Not patients with early CKD. [pmid: 10459816].
740 Tofe Povedano S, Garcia De La Villa B. 24-hour and nighttime blood pressures in type 2 diabetic hypertensive patients following morning or evening administration of olmesartan. Journal of Clinical Hypertension. 2009;11(8):426-31. Intervention not related to monitoring of CKD. [pmid: 19695030].
741 Tominaga Y, Kohara S, Namii Y, et al. Clonal analysis of nodular parathyroid hyperplasia in renal hyperparathyroidism. World Journal of Surgery. 1996;20(7):744-50. discussion 50-2. Not a randomized trial. [pmid: 8678945].
742 Tonelli M, Sacks F, Pfeffer M, et al. Biomarkers of inflammation and progression of chronic kidney disease. Kidney International. 2005;68(1):237-45. Intervention not related to monitoring of CKD. [pmid: 15954913].
743 Tong PCY, Ko GTC, Chan WB, et al. The efficacy and tolerability of fosinopril in Chinese type 2 diabetic patients with moderate renal insufficiency. Diabetes, Obesity & Metabolism. 2006;8(3):342-7. Intervention not related to monitoring of CKD.
744 Toto RD. Lessons from the African-American Study of Kidney Disease and Hypertension: an update. Current Hypertension Reports. 2006;8(5):409-12. Intervention not related to monitoring of CKD. [pmid: 16965728].
745 Trask PC, Bushmakin AG, Cappelleri JC, et al. Health-related quality of life during treatment for renal cell carcinoma: results from a phase II study of axitinib. Acta Oncologica. 2008;47(5):843-51. Not patients with early CKD. [pmid: 18568482].
746 Trivedi H, Lu N, Andresen BT, et al. Slower decline of renal function after initiation of rosiglitazone in diabetics -- a pilot study. Clinical Nephrology. 2009;72(3):181-5. Intervention not related to monitoring of CKD. [pmid: 19761722].
747 Tugwell P, Bombardier C, Gent M, et al. Low-dose cyclosporin versus placebo in patients with rheumatoid arthritis. Lancet. 1990;335(8697):1051-5. Intervention not related to monitoring of CKD. [pmid: 1970370].
748 Tugwell P, Ludwin D, Gent M, et al. Interaction between cyclosporin A and nonsteroidal antiinflammatory drugs. Journal of Rheumatology. 1997;24(6):1122-5. Intervention not related to monitoring of CKD. [pmid: 9195520].
749 Tumlin JA, Finkel KW, Murray PT, et al. Fenoldopam mesylate in early acute tubular necrosis: a randomized, double-blind, placebo-controlled clinical trial. American Journal of Kidney Diseases. 2005;46(1):26-34. Intervention not related to monitoring of CKD. [pmid: 15983954].
750 Turner R. Hepatic and renal tolerability of long-term naproxen treatment in patients with rheumatoid arthritis. Seminars in Arthritis & Rheumatism. 1988;17(3 Suppl 2):29-35. Intervention not related to monitoring of CKD. [pmid: 3334108].
751 Twyman S, Rowe D, Mansell P, et al. Longitudinal study of urinary albumin excretion in young diabetic patients--Wessex Diabetic Nephropathy Project. Diabetic Medicine. 2001;18(5):402-8. Not a randomized trial. [pmid: 11472452].
752 Tylicki L, Rutkowski P, Renke M, et al. Triple pharmacological blockade of the renin-angiotensin-aldosterone system in nondiabetic CKD: an open-label crossover randomized controlled trial. American Journal of Kidney Diseases. 2008;52(3):486-93. Intervention not related to monitoring of CKD. [pmid: 18423812].
753 Ulrich C, Bichel J, Euvrard S, et al. Topical immunomodulation under systemic immunosuppression: results of a multicentre, randomized, placebo-controlled safety and efficacy study of imiquimod 5% cream for the treatment of actinic keratoses in kidney, heart, and liver transplant patients. British Journal of Dermatology. Suppl 2. 2007;157:25-31. Intervention not related to monitoring of CKD. [pmid: 18067628].
754 van Essen GG, Apperloo AJ, Rensma PL, et al. Are angiotensin converting enzyme inhibitors superior to beta blockers in retarding progressive renal function decline?. Kidney International - Supplement. 1997;63:S58-62. Intervention not related to monitoring of CKD. [pmid: 9407423].
755 Van Poppel H, Da Pozzo L, Albrecht W, et al. A prospective randomized EORTC intergroup phase 3 study comparing the complications of elective nephron-sparing surgery and radical nephrectomy for low-stage renal cell carcinoma. European Urology. 2007;51(6):1606-15. Intervention not related to monitoring of CKD. [pmid: 17140723].
756 Vasavada N, Saha C, Agarwal R. A double-blind randomized crossover trial of two loop diuretics in chronic kidney disease. Kidney International. 2003;64(2):632-40. Intervention not related to monitoring of CKD. [pmid: 12846760].
757 Vegter S, Perna A, Hiddema W, et al. Cost-effectiveness of ACE inhibitor therapy to prevent dialysis in nondiabetic nephropathy: influence of the ACE insertion/deletion polymorphism. Pharmacogenetics & Genomics. 2009;19(9):695-703. Not a randomized trial. [pmid: 19696696].
758 Vercauteren SB, Bosmans JL, Elseviers MM, et al. A meta-analysis and morphological review of cyclosporine-induced nephrotoxicity in auto-immune diseases. Kidney International. 1998;54(2):536-45. Not a randomized trial. [pmid: 9690221].
759 Vezyroglou G, Mitropoulos A, Antoniadis C. A metabolic syndrome in diffuse idiopathic skeletal hyperostosis. A controlled study.[Erratum appears in J Rheumatol 1997 Aug; 24(8):1665]. [Erratum appears in J Rheumatol 1997 Aug; 24(8):1665]. Journal of Rheumatology. 1996;23(4):672-6. Intervention not related to monitoring of CKD. [pmid: 8730125].
760 Viberti G, Kahn SE, Greene DA, et al. A diabetes outcome progression trial (ADOPT): an international multicenter study of the comparative efficacy of rosiglitazone, glyburide, and metformin in recently diagnosed type 2 diabetes. Diabetes Care. 2002;25(10):1737-43. Intervention not related to monitoring of CKD. [pmid: 12351470].
761 Vidt DG, Cressman MD, Harris S, et al. Rosuvastatin-induced arrest in progression of renal disease. Cardiology. 2004;102(1):52-60. Intervention not related to monitoring of CKD. [pmid: 15073451].
762 Vincenti F, Lantz M, Birnbaum J, et al. A phase I trial of humanized anti-interleukin 2 receptor antibody in renal transplantation. Transplantation. 1997;63(1):33-8. Not patients with early CKD. [pmid: 9000657].
763 Vincenti F, Rostaing L, investigators D. Rationale and design of the DIRECT study: a comparative assessment of the hyperglycemic effects of tacrolimus and cyclosporine following renal transplantation. Contemporary Clinical Trials. 2005;26(1):17-24. Not patients with early CKD. [pmid: 15837449].
764 Vitko S, Margreiter R, Weimar W, et al. Three-year efficacy and safety results from a study of everolimus versus mycophenolate mofetil in de novo renal transplant patients. [Erratum appears in Am J Transplant. 2006 Jan;6(1):243]. American Journal of Transplantation. 2005;5(10):2521-30. Not patients with early CKD. [pmid: 16162203].
765 Vitko S, Tedesco H, Eris J, et al. Everolimus with optimized cyclosporine dosing in renal transplant recipients: 6-month safety and efficacy results of two randomized studies. American Journal of Transplantation. 2004;4(4):626-35. Not patients with early CKD. [pmid: 15023156].
766 Vogt L, Kocks MJA, Laverman GD, et al. Renoprotection by blockade of the renin-angiotensin-aldosterone system in diabetic and non-diabetic chronic kidney disease. Specific involvement of intra-renal angiotensin-converting enzyme activity in therapy resistance?. Minerva Medica. 2004;95(5):395-409. Not a randomized trial. [pmid: 15467515].
767 Vonend O, Marsalek P, Russ H, et al. Moxonidine treatment of hypertensive patients with advanced renal failure. Journal of Hypertension. 2003;21(9):1709-17. Not patients with early CKD. [pmid: 12923404].
768 Wade VL, Gleason BL. Dual blockade of the renin-angiotensin system in diabetic nephropathy. Annals of Pharmacotherapy. 2004;38(7-8):1278-82. Not a randomized trial. [pmid: 15187210].
769 Wahbah AM, el-Hefny MO, Wafa EM, et al. Perioperative renal protection in patients with obstructive jaundice using drug combinations. Hepato-Gastroenterology. 2000;47(36):1691-4. Intervention not related to monitoring of CKD. [pmid: 11149033].
770 Wallen NH, Andersson A, Hjemdahl P. Effects of treatment with oral isosorbide dinitrate on platelet function in vivo; a double-blind placebo-controlled study in patients with stable angina pectoris. British Journal of Clinical Pharmacology. 1994;38(1):63-70. Intervention not related to monitoring of CKD. [pmid: 7946939].
771 Walser M, Hill S. Effect of ketoconazole plus low-dose prednisone on progression of chronic renal failure. American Journal of Kidney Diseases. 1997;29(4):503-13. Intervention not related to monitoring of CKD. [pmid: 9100038].
772 Walters MR, Bolster A, Dyker AG, et al. Effect of perindopril on cerebral and renal perfusion in stroke patients with carotid disease. Stroke. 2001;32(2):473-8. Intervention not related to monitoring of CKD. [pmid: 11157185].
773 Wang G, Lai FMM, Lai KB, et al. Urinary messenger RNA expression of podocyte-associated molecules in patients with diabetic nephropathy treated by angiotensin-converting enzyme inhibitor and angiotensin receptor blocker. European Journal of Endocrinology. 2008;158(3):317-22. Intervention not related to monitoring of CKD. [pmid: 18299464].
774 Warrier I, Lusher JM. Development of anaphylactic shock in haemophilia B patients with inhibitors. Blood Coagulation & Fibrinolysis. Suppl 1. 1998;9:S125-8. Intervention not related to monitoring of CKD. [pmid: 9819043].
775 Webb DJ, Newman DJ, Chaturvedi N, et al. The use of the Micral-Test strip to identify the presence of microalbuminuria in people with insulin dependent diabetes mellitus (IDDM) participating in the EUCLID study. Diabetes Research & Clinical Practice. 1996;31(1-3):93-102. Not a randomized trial. [pmid: 8792107].
776 Webb JG, Pate GE, Humphries KH, et al. A randomized controlled trial of intravenous N-acetylcysteine for the prevention of contrast-induced nephropathy after cardiac catheterization: lack of effect. American Heart Journal. 2004;148(3):422-9. Intervention not related to monitoring of CKD. [pmid: 15389228].
777 Weimer R, Susal C, Yildiz S, et al. Post-transplant sCD30 and neopterin as predictors of chronic allograft nephropathy: impact of different immunosuppressive regimens. American Journal of Transplantation. 2006;6(8):1865-74. Intervention not related to monitoring of CKD. [pmid: 16771810].
778 Weinrauch LA, Bayliss G, Gleason RE, et al. A pilot study to assess utility of changes in elements of the Diabetes Impact Management Scale in evaluating diabetic patients for progressive nephropathy. Metabolism: Clinical & Experimental. 2009;58(4):492-6. Intervention not related to monitoring of CKD. [pmid: 19303969].
779 Weinrauch LA, Burger AJ, Aepfelbacher F, et al. A pilot study to test the effect of pulsatile insulin infusion on cardiovascular mechanisms that might contribute to attenuation of renal compromise in type 1 diabetes mellitus patients with proteinuria. Metabolism: Clinical & Experimental. 2007;56(11):1453-7. Intervention not related to monitoring of CKD. [pmid: 17950093].
780 Weinrauch LA, Kennedy FJ, Burger A, et al. Prospective evaluation of autonomic dysfunction in aggressive management of diabetic microangiopathy. American Journal of Hypertension. 1999;12(11 Pt 1):1135-9. Intervention not related to monitoring of CKD. [pmid: 10604492].
781 Weir MR, Dengel DR, Behrens MT, et al. Salt-induced increases in systolic blood pressure affect renal hemodynamics and proteinuria. Hypertension. 1995;25(6):1339-44. Intervention not related to monitoring of CKD. [pmid: 7768584].
782 Weir MR, Fink JC, Hanes DS, et al. Chronic allograft nephropathy: effect of cyclosporine reduction and addition of mycophenolate mofetil on progression of renal disease. Transplantation Proceedings. 1999;31(1-2):1286-7. Intervention not related to monitoring of CKD. [pmid: 10083574].
783 Weiss MF, Rodby RA, Justice AC, et al. Free pentosidine and neopterin as markers of progression rate in diabetic nephropathy. Collaborative Study Group. Kidney International. 1998;54(1):193-202. Not a randomized trial. [pmid: 9648079].
784 Welage LS, Mason NA, Hoffman EJ, et al. Influence of cellulose triacetate hemodialyzers on vancomycin pharmacokinetics. Journal of the American Society of Nephrology. 1995;6(4):1284-90. Not patients with early CKD. [pmid: 8589298].
785 Wexler D, Silverberg D, Blum M, et al. Anaemia as a contributor to morbidity and mortality in congestive heart failure. Nephrology Dialysis Transplantation. Suppl 7. 2005;20:vii11-5. Not a randomized trial.
786 White M, Lepage S, Lavoie J, et al. Effects of combined candesartan and ACE inhibitors on BNP, markers of inflammation and oxidative stress, and glucose regulation in patients with symptomatic heart failure. Journal of Cardiac Failure. 2007;13(2):86-94. Intervention not related to monitoring of CKD. [pmid: 17395047].
787 Wiegmann TB, Herron KG, Chonko AM, et al. Effect of angiotensin-converting enzyme inhibition on renal function and albuminuria in normotensive type I diabetic patients. Diabetes. 1992;41(1):62-7. Intervention not related to monitoring of CKD. [pmid: 1727741].
788 Wiland P, Szechcinski J. Proximal tubule damage in patients treated with gentamicin or amikacin. Polish Journal of Pharmacology. 2003;55(4):631-7. Intervention not related to monitoring of CKD. [pmid: 14581723].
789 Williams ME, Lacson E Jr, Teng M, et al. Hemodialyzed type I and type II diabetic patients in the US: Characteristics, glycemic control, and survival. Kidney International. 2006;70(8):1503-9. Not patients with early CKD. [pmid: 16941022].
790 Wilmer WA, Hebert LA, Lewis EJ, et al. Remission of nephrotic syndrome in type 1 diabetes: long-term follow-up of patients in the Captopril Study. American Journal of Kidney Diseases. 1999;34(2):308-14. Not patients with early CKD. [pmid: 10430979].
791 Wilson J, Wahbha MM, Martin PG, et al. The effect of nisoldipine on renal function in the long-term treatment of hypertension in patients with and without renal impairment. European Journal of Clinical Pharmacology. 1989;37(5):437-41. Intervention not related to monitoring of CKD. [pmid: 2689184].
792 Wirta OR, Pasternack AI, Mustonen JT, et al. Urinary albumin excretion rate and its determinants after 6 years in non-insulin-dependent diabetic patients. Nephrology Dialysis Transplantation. 1996;11(3):449-56. Not a randomized trial.
793 Womer KL, Huang Y, Herren H, et al. Dendritic cell deficiency associated with development of BK viremia and nephropathy in renal transplant recipients. Transplantation. 2010;89(1):115-23. Not patients with early CKD. [pmid: 20061927].
794 Woo J, Sea MMM, Tong P, et al. Effectiveness of a lifestyle modification programme in weight maintenance in obese subjects after cessation of treatment with Orlistat. Journal of Evaluation in Clinical Practice. 2007;13(6):853-9. Intervention not related to monitoring of CKD. [pmid: 18070255].
795 Woo KT, Lau YK, Chan CM, et al. ATRA therapy restores normal renal function and renal reserve and prevents renal failure. Annals of the Academy of Medicine, Singapore. 2005;34(1):52-9. Not a randomized trial.
796 Woo KT, Lau YK, Zhao Y, et al. Disease progression, response to ACEI/ATRA therapy and influence of ACE gene in IgA nephritis. Cellular & Molecular Immunology. 2007;4(3):227-32. Not patients with early CKD. [pmid: 17601378].
797 Woolerton J, Jury DR, Dunn PJ, et al. Urine albumin creatinine ratio and clinical correlates in a diabetic population. New Zealand Medical Journal. 1987;100(819):130-4. Not a randomized trial. [pmid: 3452021].
798 Woolfson RG, Neild GH. Cyclosporin nephrotoxicity following cardiac transplantation. Nephrology Dialysis Transplantation. 1997;12(10):2054-6. Not patients with early CKD.
799 Work J. Does vascular access monitoring work?. Advances in Renal Replacement Therapy. 2002;9(2):85-90. Not patients with early CKD. [pmid: 12085384].
800 Wright JT Jr, Bakris G, Greene T, et al. Effect of blood pressure lowering and antihypertensive drug class on progression of hypertensive kidney disease: results from the AASK trial. [Erratum appears in JAMA. 2006 Jun 21;295(23):2726]. JAMA. 2002;288(19):2421-31. Intervention not related to monitoring of CKD. [pmid: 12435255].
801 Wright S, Bogan A, Chokshi A. DaVita program advocates self-management of CKD. Nephrol News Issues. 2009;23(13):28-9. Not a randomized trial. [pmid: 20050436].
802 Xu J, Lee ET, Devereux RB, et al. A longitudinal study of risk factors for incident albuminuria in diabetic American Indians: the Strong Heart Study. American Journal of Kidney Diseases. 2008;51(3):415-24. Not a randomized trial. [pmid: 18295057].
803 Xu X, Wu Z, Zhou Q, et al. The role of determining the levels of serum collagen type IV in diagnosing early diabetic nephropathy. Renal Failure. 2002;24(6):747-53. Intervention not related to monitoring of CKD. [pmid: 12472197].
804 Yang CW, Kim YO, Kim YS, et al. Clinical course of cytomegalovirus (CMV) viremia with and without ganciclovir treatment in CMV-seropositive kidney transplant recipients. Longitudinal follow-up of CMV pp65 antigenemia assay. American Journal of Nephrology. 1998;18(5):373-8. Intervention not related to monitoring of CKD. [pmid: 9730559].
805 Yang JC, Haworth L, Sherry RM, et al. A randomized trial of bevacizumab, an anti-vascular endothelial growth factor antibody, for metastatic renal cancer. New England Journal of Medicine. 2003;349(5):427-34. Intervention not related to monitoring of CKD. [pmid: 12890841].
806 Yee CS, Gordon C, Dostal C, et al. EULAR randomised controlled trial of pulse cyclophosphamide and methylprednisolone versus continuous cyclophosphamide and prednisolone followed by azathioprine and prednisolone in lupus nephritis. Annals of the Rheumatic Diseases. 2004;63(5):525-9. Intervention not related to monitoring of CKD. [pmid: 15082482].
807 Yorioka N, Kiribayashi K, Naito T, et al. An oral adsorbent, AST-120, combined with a low-protein diet and RAS blocker, for chronic kidney disease. Journal of Nephrology. 2008;21(2):213-20. Intervention not related to monitoring of CKD. [pmid: 18446716].
808 Zanardo G, Michielon P, Rosi P, et al. Effects of a continuous diltiazem infusion on renal function during cardiac surgery. Journal of Cardiothoracic & Vascular Anesthesia. 1993;7(6):711-6. Intervention not related to monitoring of CKD. [pmid: 8305662].
809 Zhang A, Vertommen J, Van Gaal L, et al. Effects of pravastatin on lipid levels, in vitro oxidizability of non-HDL lipoproteins and microalbuminuria in IDDM patients. Diabetes Research & Clinical Practice. 1995;29(3):189-94. Intervention not related to monitoring of CKD. [pmid: 8591712].
810 Zhang J, Ding EL, Song Y. Adverse effects of cyclooxygenase 2 inhibitors on renal and arrhythmia events: meta-analysis of randomized trials. JAMA. 2006;296(13):1619-32. Not a randomized trial. [pmid: 16968832].
811 Zhu S, Liu Y, Wang L, et al. Transforming growth factor-beta1 is associated with kidney damage in patients with essential hypertension: renoprotective effect of ACE inhibitor and/or angiotensin II receptor blocker. Nephrology Dialysis Transplantation. 2008;23(9):2841-6. Intervention not related to monitoring of CKD.
812 Zhu X, Stergiopoulos K, Wu S. Risk of hypertension and renal dysfunction with an angiogenesis inhibitor sunitinib: systematic review and meta-analysis. Acta Oncologica. 2009;48(1):9-17. Not a randomized trial. [pmid: 18752081].
813 Ziakka S, Ursu M, Poulikakos D, et al. Predictive factors and therapeutic approach of renovascular disease: four years' follow-up. Renal Failure. 2008;30(10):965-70. Not a randomized trial. [pmid: 19016147].
814 Zucchelli P, Cagnoli L, Pasquali S, et al. Clinical and morphologic evolution of idiopathic membranous nephropathy. Clinical Nephrology. 1986;25(6):282-8. Not a randomized trial. [pmid: 3524923].
815 Zucchelli P, Ponticelli C, Cagnoli L, et al. Prognostic value of T lymphocyte subset ratio in idiopathic membranous nephropathy. American Journal of Nephrology. 1988;8(1):15-20. Duration of follow-up less than 1 year. [pmid: 2967032].
816 Zucchelli P, Zuccala A, Gaggi R. Comparison of the effects of ACE inhibitors and calcium channel blockers on the progression of renal failure. Nephrology Dialysis Transplantation. Suppl 9. 1995;10:46-51. Intervention not related to monitoring of CKD.

## CKD Treatment (KQ5, KQ6)

1 The Diabetes Control and Complications Trial (DCCT). Design and methodologic considerations for the feasibility phase. The DCCT Research Group. Diabetes. 1986;35(5):530-45. Not CKD treatment. [pmid: 2869996].
2 Dietary compliance in the trial of the European Study Group. A preliminary analysis. European Study Group for the Conservative Management of Chronic Renal Failure. Contributions to Nephrology. 1990;81:61-70. Not CKD treatment. [pmid: 2093513].
3 Comparative study of the efficacy of dipyrone, diclofenac sodium and pethidine in acute renal colic. Collaborative Group of the Spanish Society of Clinical Pharmacology. European Journal of Clinical Pharmacology. 1991;40(6):543-6. Not CKD treatment. [pmid: 1884733].
4 Effect of enalapril on survival in patients with reduced left ventricular ejection fractions and congestive heart failure. The SOLVD Investigators. New England Journal of Medicine. 1991;325(5):293-302. Not CKD treatment. [pmid: 2057034].
5 Comparison between perindopril and nifedipine in hypertensive and normotensive diabetic patients with microalbuminuria. Melbourne Diabetic Nephropathy Study Group. BMJ. 1991;302(6770):210-6. Not relevant to key questions. [pmid: 1998761].
6 Dietary compliance in the trial of the European Study Group. An interim analysis. European Study Group for the Conservative Management of Chronic Renal Failure. Contributions to Nephrology. 1992;98:133-41. Not CKD treatment. [pmid: 1493725].
7 Effect of enalapril on mortality and the development of heart failure in asymptomatic patients with reduced left ventricular ejection fractions. The SOLVD Investigators. [Erratum appears in N Engl J Med 1992 Dec 10;327(24):1768]. New England Journal of Medicine. 1992;327(10):685-91. Not CKD treatment. [pmid: 1463530].
8 The Modification of Diet in Renal Disease Study: design, methods, and results from the feasibility study. American Journal of Kidney Diseases. 1992;20(1):18-33. Not relevant to key questions. [pmid: 1621675].
9 The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial Research Group. New England Journal of Medicine. 1993;329(14):977-86. Not early CKD. [pmid: 8366922].
10 Results of the North American trial of piperacillin/tazobactam compared with clindamycin and gentamicin in the treatment of severe intra-abdominal infections. Investigators of the Piperacillin/Tazobactam Intra-abdominal Infection Study Group. European Journal of Surgery, Acta Chirurgica, Supplement. 1994;(573):61-6. Not early CKD.
11 Reduction of dietary protein and phosphorus in the Modification of Diet in Renal Disease Feasibility Study. The MDRD Study Group. Journal of the American Dietetic Association. 1994;94(9):986-90. quiz 91-2. Not CKD treatment. [pmid: 8071496].
12 The effect of age and renal function on the efficacy and toxicity of methotrexate in rheumatoid arthritis. Rheumatoid Arthritis Clinical Trial Archive Group. Journal of Rheumatology. 1995;22(2):218-23. Not CKD treatment. [pmid: 7738941].
13 SOCA research group stops enrollment. Studies of the Ocular Complications of AIDS. AIDS Patient Care & Stds. 1996;10(3):188. Not early CKD.
14 Effects of dietary protein restriction on the progression of moderate renal disease in the Modification of Diet in Renal Disease Study. [Erratum appears in J Am Soc Nephrol 1997 Mar;8(3):493]. Journal of the American Society of Nephrology. 1996;7(12):2616-26. Not early CKD. [pmid: 8989740].
15 Short-term effects of protein intake, blood pressure, and antihypertensive therapy on glomerular filtration rate in the Modification of Diet in Renal Disease Study. Journal of the American Society of Nephrology. 1996;7(10):2097-109. Not RCT or controlled trial. [pmid: 8915969].
16 Captopril reduces the risk of nephropathy in IDDM patients with microalbuminuria. The Microalbuminuria Captopril Study Group. Diabetologia. 1996;39(5):587-93. Not relevant to key questions. [pmid: 8739919].
17 Effects of diet and antihypertensive therapy on creatinine clearance and serum creatinine concentration in the Modification of Diet in Renal Disease Study. [Erratum appears in J Am Soc Nephrol 1997 Aug;8(8):1354]. Journal of the American Society of Nephrology. 1996;7(4):556-66. Not RCT or controlled trial. [pmid: 8724889].
18 Randomised placebo-controlled trial of lisinopril in normotensive patients with insulin-dependent diabetes and normoalbuminuria or microalbuminuria. The EUCLID Study Group. Lancet. 1997;349(9068):1787-92. Not relevant to key questions. [pmid: 9269212].
19 Heart failure treatment with angiotensin-converting enzyme inhibitors in hospitalized Medicare patients in 10 large states. The Large State Peer Review Organization Consortium. Archives of Internal Medicine. 1997;157(10):1103-8. Not RCT or controlled trial. [pmid: 9164376].
20 Parenteral cidofovir for cytomegalovirus retinitis in patients with AIDS: the HPMPC peripheral cytomegalovirus retinitis trial. A randomized, controlled trial. Studies of Ocular complications of AIDS Research Group in Collaboration with the AIDS Clinical Trials Group. Annals of Internal Medicine. 1997;126(4):264-74. Not CKD treatment. [pmid: 9036798].
21 Benazepril and the kidney: new indication. No better than the other ACE inhibitors. Prescrire International. 1998;7(38):174-6. Not relevant to key questions. [pmid: 10848048].
22 NESP researchers present latest data at ASN. Nephrology News & Issues. 2000;14(12):56. Not RCT or controlled trial.
23 Summaries for patients. Weight-training exercises to counteract the negative effects of low-protein diets in people with kidney disease. Annals of Internal Medicine. 2001;135(11):S-60. Not relevant to key questions.
24 Summaries for patients. Trial of a drug to decrease the risk for heart disease in patients with mild kidney failure. Annals of Internal Medicine. 2001;134(8):S-96. Not RCT or controlled trial.
25 Effect of 3 years of antihypertensive therapy on renal structure in type 1 diabetic patients with albuminuria: the European Study for the Prevention of Renal Disease in Type 1 Diabetes (ESPRIT). Diabetes. 2001;50(4):843-6. Sample size less than 50 patients. [pmid: 11289051].
26 Cinacalcet: AMG 073, Calcimimetics--Amgen/NPS Pharmaceuticals, KRN 1493, NPS 1493. Drugs in R & D. 2003;4(6):349-6. Sample size less than 50 patients.
27 Summaries for patients. Oral administration of an antibiotic (norfloxacin) may help treat the cardiac and circulatory complications of liver failure. Annals of Internal Medicine. 2003;139(3):I62. Not RCT or controlled trial. [pmid: 12899603].
28 Summaries for patients. Effects of blood pressure drugs in patients with diabetes and kidney disease. [Original report in Ann Intern Med. 2003 Apr 1;138(7):542-9; PMID:12667024]. Annals of Internal Medicine. 2003;138(7):I43. Not RCT or controlled trial. [pmid: 12667050].
29 Summaries for patients. Treating cholesterol in patients with mild kidney disease. [Original report in Ann Intern Med. 2003 Jan 21;138(2):98-104; PMID:12529091]. Annals of Internal Medicine. 2003;138(2):I28. Not RCT or controlled trial. [pmid: 12529112].
30 Bevacizumab (Avastin). Medical Letter on Drugs & Therapeutics. 2004;46(1184):47-8. Not CKD treatment. [pmid: 15212050].
31 New Premier study suggest Preterax as a first-line antihypertensive. Cardiovascular Journal of Southern Africa. 2004;15(1):40-1. Not CKD treatment.
32 Summaries for patients. Do the effects of blood pressure drugs differ by kidney function?. [Original report in Ann Intern Med. 2006 Feb 7;144(3):172-80; PMID:16461961]. Annals of Internal Medicine. 2006;144(2):I33. Not RCT or controlled trial. [pmid: 16461958].
33 Sorafenib: new drug. Second-line treatment of kidney cancer: better evaluated than sunitinib. Prescrire International. 2007;16(90):141-3. Not relevant to key questions. [pmid: 17724834].
34 Sunitinib: new drug. For some gastrointestinal stromal tumours. Prescrire International. 2007;16(90):138-6. Not early CKD. [pmid: 17724833].
35 Ruboxistaurin: LY 333531. Drugs in R & D. 2007;8(3):193-6. Not RCT or controlled trial.
36 Type 2 diabetes and HbA1c targets. Prescrire International. 2008;17(98):254. Not CKD treatment. [pmid: 19425272].
37 Telmisartan did not prevent renal disease in patients without proteinuria. [Original report in Ann Intern Med. 2009 Jul 7;151(1):1-10, W1-2; PMID:19451556]. Annals of Internal Medicine. 2009;151(1):I28. Not relevant to key questions. [pmid: 19451555].
38 Anti-HIV agents. Treatment interruption uncovers HIV's attack on the kidneys. Treatment Update. 2009;21(2):5-6. Not early CKD.
39 Anemia therapy in kidney disease What research reveals about ESA medication safety. Johns Hopkins Medical Letter, Health After 50. Nov. 2010;22(9):1-2. Not RCT or controlled trial.
40 Using NSAIDs in cardiovascular disease. Drug & Therapeutics Bulletin. Mar. 2010;48(3):26-9. Not early CKD. [pmid: 20200145].
41 Aarnoutse RE, Wasmuth JC, Fatkenheuer G, et al. Administration of indinavir and low-dose ritonavir (800/100 mg twice daily) with food reduces nephrotoxic peak plasma levels of indinavir. Antiviral Therapy. 2003;8(4):309-14. Not CKD treatment. [pmid: 14518700].
42 Abassi Z, Winaver J, Feuerstein GZ. The biochemical pharmacology of renin inhibitors: implications for translational medicine in hypertension, diabetic nephropathy and heart failure: expectations and reality. Biochemical Pharmacology. 2009;78(8):933-40. Not RCT or controlled trial. [pmid: 19477166].
43 Abbott K, Basta E, Bakris GL. Blood pressure control and nephroprotection in diabetes. Journal of Clinical Pharmacology. 2004;44(4):431-8. Not early CKD. [pmid: 15051752].
44 Abbott K, Smith A, Bakris GL. Effects of dihydropyridine calcium antagonists on albuminuria in patients with diabetes. Journal of Clinical Pharmacology. 1996;36(3):274-9. Sample size less than 50 patients. [pmid: 8690823].
45 Abbott KC, Bakris GL. Treatment of the diabetic patient: focus on cardiovascular and renal risk reduction. Progress in Brain Research. 2002;139:289-98. Not RCT or controlled trial. [pmid: 12436944].
46 Abbott KC, Bakris GL. What have we learned from the current trials?. Medical Clinics of North America. 2004;88(1):189-207. Not RCT or controlled trial. [pmid: 14871059].
47 Abboud H, Coyne D, Smolenski O, et al. A comparison of dosing regimens of paricalcitol capsule for the treatment of secondary hyperparathyroidism in CKD stages 3 and 4. American Journal of Nephrology. 2006;26(1):105-14. Sample size less than 50 patients. [pmid: 16543714].
48 Abdel-Raheem MM, Hebert B, Potti A, et al. Hyperhomocysteinemia and the risk of thromboembolic phenomenon in patients with chronic renal failure. Thrombosis Research. 2002;105(4):299-302. Not RCT or controlled trial. [pmid: 12031823].
49 Abdel-Rahman E, Bolton WK. Pimagedine: a novel therapy for diabetic nephropathy. Expert Opinion on Investigational Drugs. 2002;11(4):565-74. Not relevant to key questions. [pmid: 11922864].
50 Abdin AA, Hassanien MA, Ibrahim EA, et al. Modulating effect of atorvastatin on paraoxonase 1 activity in type 2 diabetic Egyptian patients with or without nephropathy. Journal of Diabetes & its Complications. Sep-Oct. 2010;24(5):325-33. Follow-up less than 6 months. [pmid: 19553142].
51 Abe K, Fujino Y, Sakakibara T. The effect of prostaglandin E1 during cardiopulmonary bypass on renal function after cardiac surgery. European Journal of Clinical Pharmacology. 1993;45(3):217-20. Not CKD treatment. [pmid: 8276044].
52 Abe K, Sakakibara T, Yoshiya I. The effect of prostaglandin E1 on renal function after cardiac surgery involving cardiopulmonary bypass. Prostaglandins Leukotrienes & Essential Fatty Acids. 1993;49(2):627-31. Sample size less than 50 patients.
53 Abe M, Okada K, Maruyama T, et al. Comparison of the antiproteinuric effects of the calcium channel blockers benidipine and amlodipine administered in combination with angiotensin receptor blockers to hypertensive patients with stage 3-5 chronic kidney disease. Hypertension Research - Clinical & Experimental. 2009;32(4):270-5. Follow-up less than 6 months.
54 Abe M, Okada K, Maruyama T, et al. Antiproteinuric and blood pressure-lowering effects of a fixed-dose combination of losartan and hydrochlorothiazide in hypertensive patients with stage 3 chronic kidney disease. Pharmacotherapy. 2009;29(9):1061-72. Follow-up less than 6 months. [pmid: 19698011].
55 Abe M, Okada K, Maruyama T, et al. Blood pressure-lowering and antiproteinuric effect of switching from high-dose angiotensin receptor blockers to normal-dose telmisartan and low-dose hydrochlorothiazide in hypertensive patients with chronic kidney disease. International Journal of Clinical Pharmacology & Therapeutics. Mar. 2010;48(3):206-13. Not RCT or controlled trial. [pmid: 20197015].
56 Abels R. Rate of progression of chronic renal failure in predialysis patients treated with erythropoietin. Seminars in Nephrology. 1990;10(2 Suppl 1):20-5. Not CKD treatment. [pmid: 2192413].
57 Abitbol CL, Chandar J, Onder AM, et al. Profiling proteinuria in pediatric patients. Pediatric Nephrology. 2006;21(7):995-1002. Not RCT or controlled trial. [pmid: 16773413].
58 Abizaid AS, Clark CE, Mintz GS, et al. Effects of dopamine and aminophylline on contrast-induced acute renal failure after coronary angioplasty in patients with preexisting renal insufficiency. American Journal of Cardiology. 1999;83(2):260-3. Not CKD treatment. [pmid: 10073832].
59 Abosaif NY, Tolba YA, Heap M, et al. The outcome of acute renal failure in the intensive care unit according to RIFLE: model application, sensitivity, and predictability. American Journal of Kidney Diseases. 2005;46(6):1038-48. Not relevant to key questions. [pmid: 16310569].
60 Abouljoud MS, Levy MF, Klintmalm GB. Hyperlipidemia after liver transplantation: long-term results of the FK506/cyclosporine A US Multicenter Trial. US Multicenter Study Group. Transplantation Proceedings. 1995;27(1):1121-3. Not early CKD. [pmid: 7533360].
61 Abouljoud MS, Levy MF, Klintmalm GB. Hyperlipidemia after liver transplantation: long-term results of the FK506/cyclosporine a US Multicenter trial. US Multicenter Study Group. Transplantation Proceedings. 1995;27(1):1121-3. Not early CKD. [pmid: 7533360].
62 Abraham PA, Halstenson CE, Matzke GR, et al. Comparison of antihypertensive, renal hemodynamic, and humoral effects of pinacidil and hydralazine monotherapy. Journal of Clinical Hypertension. 1987;3(4):439-51. Sample size less than 50 patients. [pmid: 3330986].
63 Abuissa H, O'Keefe J Jr. The role of renin-angiotensin-aldosterone system-based therapy in diabetes prevention and cardiovascular and renal protection. Diabetes, Obesity & Metabolism. 2008;10(12):1157-66. Not relevant to key questions.
64 Acanfora D, Lowenthal DT, Furgi G, et al. The effects of delapril in combination with indapamide on glomerular filtration rate in elderly hypertensive patients. American Journal of Therapeutics. 1997;4(11-12):405-8. Sample size less than 50 patients. [pmid: 10423638].
65 Acbay O. Effects of low-dose losartan treatment on persistent microalbuminuria in normotensive type 1 diabetic subjects. Journal of Endocrinological Investigation. 2001;24(8):608-11. Sample size less than 50 patients. [pmid: 11686543].
66 Accetta NA, Gladstone EH, DiSogra C, et al. Prevalence of estimated GFR reporting among US clinical laboratories. American Journal of Kidney Diseases. 2008;52(4):778-87. Not CKD treatment. [pmid: 18676076].
67 Acchiardo SR, Hayden AJ. Is Na+ modeling necessary in high flux dialysis?. ASAIO Transactions. 1991;37(3):M135-7. Not CKD treatment. [pmid: 1751081].
68 Acharya GP, Davis TM, Ho M, et al. Factors affecting the pharmacokinetics of parenteral chloramphenicol in enteric fever. Journal of Antimicrobial Chemotherapy. 1997;40(1):91-8. Sample size less than 50 patients. [pmid: 9249209].
69 Acker CG, Singh AR, Flick RP, et al. A trial of thyroxine in acute renal failure. Kidney International. 2000;57(1):293-8. Not CKD treatment. [pmid: 10620211].
70 Ackerman Z, Cominelli F, Reynolds TB. Effect of misoprostol on ibuprofen-induced renal dysfunction in patients with decompensated cirrhosis: results of a double-blind placebo-controlled parallel group study. American Journal of Gastroenterology. 2002;97(8):2033-9. Not CKD treatment. [pmid: 12190173].
71 Acton KJ, Shields R, Rith-Najarian S, et al. Applying the diabetes quality improvement project indicators in the Indian Health Service primary care setting. Diabetes Care. 2001;24(1):22-6. Not RCT or controlled trial. [pmid: 11194234].
72 Adabag AS, Ishani A, Bloomfield HE, et al. Efficacy of N-acetylcysteine in preventing renal injury after heart surgery: a systematic review of randomized trials. European Heart Journal. 2009;30(15):1910-7. Not early CKD. [pmid: 19282300].
73 Adabag AS, Ishani A, Koneswaran S, et al. Utility of N-acetylcysteine to prevent acute kidney injury after cardiac surgery: a randomized controlled trial. American Heart Journal. 2008;155(6):1143-9. Not early CKD. [pmid: 18513531].
74 Adler AI, Stevens RJ, Manley SE, et al. Development and progression of nephropathy in type 2 diabetes: the United Kingdom Prospective Diabetes Study (UKPDS 64). Kidney International. 2003;63(1):225-32. Not CKD treatment. [pmid: 12472787].
75 Adler SG, Schwartz S, Williams ME, et al. Phase 1 study of anti-CTGF monoclonal antibody in patients with diabetes and microalbuminuria. Clinical Journal of The American Society of Nephrology: CJASN. Aug. 2010;5(8):1420-8. Not RCT or controlled trial. [pmid: 20522536].
76 Adnan T, Elif AA, Ayse K, et al. Clonidine as an adjuvant for lidocaine in axillary brachial plexus block in patients with chronic renal failure. Acta Anaesthesiologica Scandinavica. 2005;49(4):563-8. Not relevant to key questions. [pmid: 15777307].
77 Adolph E, Holdt-Lehmann B, Chatterjee T, et al. Renal Insufficiency Following Radiocontrast Exposure Trial (REINFORCE): a randomized comparison of sodium bicarbonate versus sodium chloride hydration for the prevention of contrast-induced nephropathy. Coronary Artery Disease. 2008;19(6):413-9. Not CKD treatment. [pmid: 18955835].
78 Agarwal A, Silver MR, Walczyk M, et al. Once-monthly darbepoetin alfa for maintaining hemoglobin levels in older patients with chronic kidney disease. Journal of the American Medical Directors Association. 2007;8(2):83-6. Not RCT or controlled trial. [pmid: 17289537].
79 Agarwal R. Add-on angiotensin receptor blockade with maximized ACE inhibition. Kidney International. 2001;59(6):2282-9. Sample size less than 50 patients. [pmid: 11380832].
80 Agarwal R. Is i.v. iron really superior in CKD patients not on dialysis?. Kidney International. 2006;70(6):1188. author reply -9. Not CKD treatment. [pmid: 16957750].
81 Agarwal R. Effects of statins on renal function. American Journal of Cardiology. 2006;97(5):748-55. Not relevant to key questions. [pmid: 16490450].
82 Agarwal R. Anti-inflammatory effects of short-term pioglitazone therapy in men with advanced diabetic nephropathy. American Journal of Physiology - Renal Physiology. 2006;290(3):F600-5. Follow-up less than 6 months. [pmid: 16159895].
83 Agarwal R. Nonhematological benefits of iron. American Journal of Nephrology. 2007;27(6):565-71. Sample size less than 50 patients. [pmid: 17804903].
84 Agarwal R. Reproducibility of renal function measurements in adult men with diabetic nephropathy: research and clinical implications. American Journal of Nephrology. 2007;27(1):92-100. Not RCT or controlled trial. [pmid: 17284896].
85 Agarwal R. Vitamin D, proteinuria, diabetic nephropathy, and progression of CKD. Clinical Journal of The American Society of Nephrology: CJASN. 2009;4(9):1523-8. Not RCT or controlled trial. [pmid: 19478099].
86 Agarwal R. Blood pressure components and the risk for end-stage renal disease and death in chronic kidney disease. Clinical Journal of The American Society of Nephrology: CJASN. 2009;4(4):830-7. Not CKD treatment. [pmid: 19339424].
87 Agarwal R. Are vitamin D receptor agonists like angiotensin-converting enzyme inhibitors without side effects. Kidney International. Jun. 2010;77(11):943-5. Not RCT or controlled trial. [pmid: 20467430].
88 Agarwal R, Acharya M, Tian J, et al. Antiproteinuric effect of oral paricalcitol in chronic kidney disease. Kidney International. 2005;68(6):2823-8. Sample size less than 50 patients. [pmid: 16316359].
89 Agarwal R, Curley TM. The role of statins in chronic kidney disease. American Journal of the Medical Sciences. 2005;330(2):69-81. Follow-up less than 6 months. [pmid: 16103787].
90 Agarwal R, Gorski JC, Sundblad K, et al. Urinary protein binding does not affect response to furosemide in patients with nephrotic syndrome. Journal of the American Society of Nephrology. 2000;11(6):1100-5. Sample size less than 50 patients. [pmid: 10820174].
91 Agarwal R, Light RP. Physical activity and hemodynamic reactivity in chronic kidney disease. Clinical Journal of The American Society of Nephrology: CJASN. 2008;3(6):1660-8. Not CKD treatment. [pmid: 18922983].
92 Agarwal R, Rizkala AR, Bastani B, et al. A randomized controlled trial of oral versus intravenous iron in chronic kidney disease. American Journal of Nephrology. 2006;26(5):445-54. Follow-up less than 6 months. [pmid: 17035697].
93 Agarwal R, Rizkala AR, Kaskas MO, et al. Iron sucrose causes greater proteinuria than ferric gluconate in non-dialysis chronic kidney disease. Kidney International. 2007;72(5):638-42. Not RCT or controlled trial. [pmid: 17622274].
94 Agarwal R, Saha C, Battiwala M, et al. A pilot randomized controlled trial of renal protection with pioglitazone in diabetic nephropathy. Kidney International. 2005;68(1):285-92. Not relevant to key questions. [pmid: 15954919].
95 Agarwal R, Siva S, Dunn SR, et al. Add-on angiotensin II receptor blockade lowers urinary transforming growth factor-beta levels. American Journal of Kidney Diseases. 2002;39(3):486-92. Sample size less than 50 patients. [pmid: 11877567].
96 Agarwal R, Vasavada N, Sachs NG, et al. Oxidative stress and renal injury with intravenous iron in patients with chronic kidney disease. Kidney International. 2004;65(6):2279-89. Not relevant to key questions. [pmid: 15149341].
97 Agarwal SK, Irshad M, Dash SC. Comparison of two schedules of hepatitis B vaccination in patients with mild, moderate and severe renal failure. Journal of the Association of Physicians of India. 1999;47(2):183-5. Not CKD treatment. [pmid: 10999085].
98 Agewall S, Wikstrand J, Ljungman S, et al. Urinary albumin excretion is associated with the intima-media thickness of the carotid artery in hypertensive males with non-insulin-dependent diabetes mellitus. Journal of Hypertension. 1995;13(4):463-9. Not CKD treatment. [pmid: 7629407].
99 Aggarwal HK, Nand N, Singh S, et al. Comparison of oral versus intravenous iron therapy in predialysis patients of chronic renal failure receiving recombinant human erythropoietin. Journal of the Association of Physicians of India. 2003;51:170-4. Sample size less than 50 patients. [pmid: 12725261].
100 Agha A, Amer W, Anwar E, et al. Reduction of microalbuminuria by using losartan in normotensive patients with type 2 diabetes mellitus: A randomized controlled trial. Saudi Journal of Kidney Diseases & Transplantation. 2009;20(3):429-35. Not CKD treatment. [pmid: 19414946].
101 Agnes E, Prost JF, Laher MS. Additional benefits of combining beta-blockade and renal vasodilation in the treatment of mild to moderate hypertension: Tertatolol International Multicentre Study results. Journal of Hypertension - Supplement. 1989;7(6):S270-1. Not early CKD.
102 Agnoli GC, Borgatti R, Cacciari M, et al. Antagonistic effects of sulpiride--racemic and enantiomers--on renal response to low-dose dopamine infusion in normal women. Nephron. 1989;51(4):491-8. Sample size less than 50 patients. [pmid: 2739826].
103 Agnoli GC, Borgatti R, Cacciari M, et al. Interactions between the renin-angiotensin system and prostanoids in modulating renal function in potassium-depleted healthy women. Prostaglandins Leukotrienes & Essential Fatty Acids. 1994;50(6):347-52. Not CKD treatment.
104 Agnoli GC, Borgatti R, Cacciari M, et al. Urinary prostanoid excretion in healthy women with different degrees of induced potassium depletion. Prostaglandins Leukotrienes & Essential Fatty Acids. 1992;46(1):21-6. Not CKD treatment.
105 Agnoli GC, Borgatti R, Cacciari M, et al. Renal function and urinary prostanoid excretions in salt-depleted women: comparative effects of enalapril and indomethacin treatments. Prostaglandins Leukotrienes & Essential Fatty Acids. 1999;60(2):87-93. Not CKD treatment.
106 Agodoa L. Acute renal failure in the PACU. Journal of PeriAnesthesia Nursing. 2002;17(6):377-83. Not CKD treatment. [pmid: 12476403].
107 Agodoa LY, Francis ME, Eggers PW. Association of analgesic use with prevalence of albuminuria and reduced GFR in US adults. American Journal of Kidney Diseases. 2008;51(4):573-83. Not CKD treatment. [pmid: 18371533].
108 Agrawal RP, Dogra R, Mohta N, et al. Beneficial effect of camel milk in diabetic nephropathy. Acta Bio-Medica de l Ateneo Parmense. 2009;80(2):131-4. Sample size less than 50 patients.
109 Aguilar D, Goldhaber SZ, Gans DJ, et al. Clinically unrecognized Q-wave myocardial infarction in patients with diabetes mellitus, systemic hypertension, and nephropathy. American Journal of Cardiology. 2004;94(3):337-9. Not relevant to key questions. [pmid: 15276098].
110 Ahlmen M, Ahlmen J, Svalander C, et al. Cytotoxic drug treatment of reactive amyloidosis in rheumatoid arthritis with special reference to renal insufficiency. Clinical Rheumatology. 1987;6(1):27-38. Sample size less than 50 patients. [pmid: 3581696].
111 Ahmad J, Shafique S, Abidi SMA, et al. Effect of 5-year enalapril therapy on progression of microalbuminuria and glomerular structural changes in type 1 diabetic subjects. Diabetes Research & Clinical Practice. 2003;60(2):131-8. Not relevant to key questions. [pmid: 12706322].
112 Ahmad J, Siddiqui MA, Ahmad H. Effective postponement of diabetic nephropathy with enalapril in normotensive type 2 diabetic patients with microalbuminuria. Diabetes Care. 1997;20(10):1576-81. Not relevant to key questions. [pmid: 9314638].
113 Ahmadi J, Benrazavi L. Substance use among Iranian nephrologic patients. American Journal of Nephrology. 2002;22(1):11-3. Not CKD treatment. [pmid: 11919397].
114 Ahmed A. Use of angiotensin-converting enzyme inhibitors in patients with heart failure and renal insufficiency: how concerned should we be by the rise in serum creatinine?. Journal of the American Geriatrics Society. 2002;50(7):1297-300. Not relevant to key questions. [pmid: 12133029].
115 Ahmed A, Aronow WS, Fleg JL. Higher New York Heart Association classes and increased mortality and hospitalization in patients with heart failure and preserved left ventricular function. American Heart Journal. 2006;151(2):444-50. Not RCT or controlled trial. [pmid: 16442912].
116 Ahmed A, Love TE, Sui X, et al. Effects of angiotensin-converting enzyme inhibitors in systolic heart failure patients with chronic kidney disease: a propensity score analysis. Journal of Cardiac Failure. 2006;12(7):499-506. Not relevant to key questions. [pmid: 16952782].
117 Ai P, Yong G, Dingkun G, et al. Aqueous extract of Astragali Radix induces human natriuresis through enhancement of renal response to atrial natriuretic peptide. Journal of Ethnopharmacology. 2008;116(3):413-21. Not CKD treatment. [pmid: 18243612].
118 Aitken HA, Burns JW, McArdle CS, et al. Effects of ketorolac trometamol on renal function. British Journal of Anaesthesia. 1992;68(5):481-5. Not CKD treatment. [pmid: 1642936].
119 Akcicek F, Yalniz T, Basci A, et al. Diuretic effect of frusemide in patients with nephrotic syndrome: is it potentiated by intravenous albumin?. BMJ. 1995;310(6973):162-3. Follow-up less than 6 months. [pmid: 7833755].
120 Akesson A, Blom-Bulow B, Scheja A, et al. Long-term evaluation of penicillamine or cyclofenil in systemic sclerosis. Results from a two-year randomized study. Scandinavian Journal of Rheumatology. 1992;21(5):238-44. Not CKD treatment. [pmid: 1439632].
121 Akesson-Johansson A, Lernestedt JO, Ringden O, et al. Sensitivity of cytomegalovirus to intravenous foscarnet treatment. Bone Marrow Transplantation. 1986;1(2):215-20. Sample size less than 50 patients. [pmid: 2844334].
122 Akinsola W, Smith F, Alimi T, et al. Low protein/high calorie dietary regimen in the management of chronic renal failure. A preliminary study of Nigerian patients. African Journal of Medicine & Medical Sciences. 1991;20(1):53-9. Sample size less than 50 patients. [pmid: 1905472].
123 Akizawa T, Asano Y, Morita S, et al. Effect of a carbonaceous oral adsorbent on the progression of CKD: a multicenter, randomized, controlled trial. American Journal of Kidney Diseases. 2009;54(3):459-67. Not early CKD. [pmid: 19615804].
124 Akizawa T, Kino K, Koshikawa S, et al. Efficiency and biocompatibility of a polyethylene glycol grafted cellulosic membrane during hemodialysis. ASAIO Transactions. 1989;35(3):333-5. Not CKD treatment. [pmid: 2597476].
125 Al Suwaidi J, Reddan DN, Williams K, et al. Prognostic implications of abnormalities in renal function in patients with acute coronary syndromes. Circulation. 2002;106(8):974-80. Not CKD treatment. [pmid: 12186803].
126 Al-Ahmad A, Rand WM, Manjunath G, et al. Reduced kidney function and anemia as risk factors for mortality in patients with left ventricular dysfunction. Journal of the American College of Cardiology. 2001;38(4):955-62. Not RCT or controlled trial. [pmid: 11583864].
127 Alaupovic P, Attman PO, Knight-Gibson C, et al. Effect of fluvastatin on apolipoprotein-defined lipoprotein subclasses in patients with chronic renal insufficiency. Kidney International. 2006;69(10):1865-71. Sample size less than 50 patients. [pmid: 16572113].
128 Alavian SM, Tabatabaei SV. The effect of diabetes mellitus on immunological response to hepatitis B virus vaccine in individuals with chronic kidney disease: A meta-analysis of current literature. Vaccine. May. 14. 2010;28(22):3773-7. Not RCT or controlled trial. [pmid: 20371390].
129 Al-Badr W, Martin KJ. Vitamin D and kidney disease. Clinical Journal of The American Society of Nephrology: CJASN. 2008;3(5):1555-60. Not human studies. [pmid: 18450926].
130 Albers M, Romiti M, Braganca Pereira CA, et al. A meta-analysis of infrainguinal arterial reconstruction in patients with end-stage renal disease. European Journal of Vascular & Endovascular Surgery. 2001;22(4):294-300. Not RCT or controlled trial. [pmid: 11563886].
131 Albers M, Romiti M, De Luccia N, et al. An updated meta-analysis of infrainguinal arterial reconstruction in patients with end-stage renal disease. Journal of Vascular Surgery. 2007;45(3):536-42. Follow-up less than 6 months. [pmid: 17257801].
132 Albert JM, Gadbury GL, Mascha EJ. Assessing treatment effect heterogeneity in clinical trials with blocked binary outcomes. Biometrical Journal. 2005;47(5):662-73. Not relevant to key questions. [pmid: 16385907].
133 Albert SG, Shapiro MJ, Brown WW, et al. Analysis of radiocontrast-induced nephropathy by dual-labeled radionuclide clearance. Investigative Radiology. 1994;29(6):618-23. Not CKD treatment. [pmid: 8088970].
134 Alberti D, Locatelli F, Graziani G, et al. Hypertension and chronic renal insufficiency: the experience of the Northern Italian Cooperative Study Group. American Journal of Kidney Diseases. 1993;21(5 Suppl 2):124-30. Not RCT or controlled trial. [pmid: 8494011].
135 Albillos A, Garcia-Pagan JC, Iborra J, et al. Propranolol plus prazosin compared with propranolol plus isosorbide-5-mononitrate in the treatment of portal hypertension. Gastroenterology. 1998;115(1):116-23. Not CKD treatment. [pmid: 9649466].
136 Albillos A, Lledo JL, Rossi I, et al. Continuous prazosin administration in cirrhotic patients: effects on portal hemodynamics and on liver and renal function. Gastroenterology. 1995;109(4):1257-65. Follow-up less than 6 months. [pmid: 7557093].
137 Alborzi P, Patel NA, Peterson C, et al. Paricalcitol reduces albuminuria and inflammation in chronic kidney disease: a randomized double-blind pilot trial. Hypertension. 2008;52(2):249-55. Sample size less than 50 patients. [pmid: 18606901].
138 Al-Dameh A, Bedford JJ, Leader JP, et al. Urinary aquaporin-2 levels in healthy volunteers. Nephrology. 2003;8(3):139-41. Follow-up less than 6 months. [pmid: 15012730].
139 Alexander CM, Lyle PA, Keane WF, et al. Losartan and the United States costs of end-stage renal disease by baseline albuminuria in patients with type 2 diabetes and nephropathy. Kidney International - Supplement. 2004;(92):S115-7. Not RCT or controlled trial. [pmid: 15485403].
140 Ali A, Asif N, Yaqub S, et al. Spot urine protein: creatinine ratio versus 24 hour urine protein at various levels of GFR patients referred to a tertiary care hospital of Pakistan. JPMA - Journal of the Pakistan Medical Association. 2008;58(9):476-9. Not relevant to key questions.
141 Ali F, Boldur A, Winchester JF, et al. A quick and simple estimate of creatinine clearance. Journal of Nephrology. Jul-Aug. 2010;23(4):408-14. Not CKD treatment. [pmid: 20437395].
142 Ali ZA, Callaghan CJ, Lim E, et al. Remote ischemic preconditioning reduces myocardial and renal injury after elective abdominal aortic aneurysm repair: a randomized controlled trial. Circulation. 2007;116(11 Suppl):I98-105. Not CKD treatment. [pmid: 17846333].
143 Alicic RZ, Saha SA, Short RA, et al. Should albuminuria be a focus of antihypertensive therapy goals. Current Hypertension Reports. Oct. 2009;11(5):354-62. Not RCT or controlled trial. [pmid: 19737452].
144 Alimchandani A, Pai-dhungat JV. A study of gastric emptying in chronic renal failure. Journal of the Association of Physicians of India. 1997;45(11):835-8. Sample size less than 50 patients. [pmid: 11229179].
145 Al-Kateb H, Boright AP, Mirea L, et al. Multiple superoxide dismutase 1/splicing factor serine alanine 15 variants are associated with the development and progression of diabetic nephropathy: the Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications Genetics study. Diabetes. 2008;57(1):218-28. Not RCT or controlled trial. [pmid: 17914031].
146 Alkhalaf A, Klooster A, van Oeveren W, et al. A double-blind, randomized, placebo-controlled clinical trial on benfotiamine treatment in patients with diabetic nephropathy. Diabetes Care. Jul. 2010;33(7):1598-601. Follow-up less than 6 months. [pmid: 20413516].
147 Allaqaband S, Tumuluri R, Malik AM, et al. Prospective randomized study of N-acetylcysteine, fenoldopam, and saline for prevention of radiocontrast-induced nephropathy. Catheterization & Cardiovascular Interventions. 2002;57(3):279-83. Not CKD treatment. [pmid: 12410497].
148 Allen LA, Turer AT, Dewald T, et al. Continuous versus bolus dosing of Furosemide for patients hospitalized for heart failure. American Journal of Cardiology. Jun. 15. 2010;105(12):1794-7. Not CKD treatment. [pmid: 20538132].
149 Allen MJ, Ang VT, Bennett ED. Domperidone, a DA2-specific dopamine antagonist, has no effect on the renal or haemodynamic response to atrial natriuretic peptide in man. Clinical Science. 1988;75(6):569-75. Sample size less than 50 patients. [pmid: 2974769].
150 Allen SJ, McBride WT, McMurray TJ, et al. Cell salvage alters the systemic inflammatory response after off-pump coronary artery bypass grafting surgery. Annals of Thoracic Surgery. 2007;83(2):578-85. Sample size less than 50 patients. [pmid: 17257991].
151 Alli C, Lombardo M, Zanni D, et al. Albuminuria and transferrinuria in essential hypertension. Effects of antihypertensive therapy. American Journal of Hypertension. 1996;9(11):1068-76. Sample size less than 50 patients. [pmid: 8931831].
152 Allison NL, Dubb JW, Ziemniak JA, et al. The effect of fenoldopam, a dopaminergic agonist, on renal hemodynamics. Clinical Pharmacology & Therapeutics. 1987;41(3):282-8. Sample size less than 50 patients. [pmid: 2880688].
153 Al-Maskari F, El-Sadig M. Prevalence of risk factors for diabetic foot complications. BMC Family Practice. 2007:8-59. Not RCT or controlled trial.
154 Almquist T, Forslund L, Rehnqvist N, et al. Prognostic implications of renal dysfunction in patients with stable angina pectoris. Journal of Internal Medicine. 2006;260(6):537-44. Not CKD treatment. [pmid: 17116004].
155 al-Nahhas AM, Nimmon CC, Britton KE, et al. The effect of ramipril, a new angiotensin-converting enzyme inhibitor on cortical nephron flow and effective renal plasma flow in patients with essential hypertension. Nephron. 1990;54(1):47-52. Sample size less than 50 patients. [pmid: 2136939].
156 Aloia JF. Role of calcitriol in the treatment of postmenopausal osteoporosis. Metabolism: Clinical & Experimental. 1990;39(4 Suppl 1):35-8. Not CKD treatment. [pmid: 2182976].
157 Aloia JF, Patel M, Dimaano R, et al. Vitamin D intake to attain a desired serum 25-hydroxyvitamin D concentration. American Journal of Clinical Nutrition. 2008;87(6):1952-8. Not CKD treatment. [pmid: 18541590].
158 Alonso A, Lau J, Jaber BL, et al. Prevention of radiocontrast nephropathy with N-acetylcysteine in patients with chronic kidney disease: a meta-analysis of randomized, controlled trials. American Journal of Kidney Diseases. 2004;43(1):1-9. Not RCT or controlled trial. [pmid: 14712421].
159 Alper AB Jr., Tomlin H, Sadhwani U, et al. Effects of the selective cyclooxygenase-2 inhibitor analgesic celecoxib on renal carbonic anhydrase enzyme activity: a randomized, controlled trial. American Journal of Therapeutics. 2006;13(3):229-35. Not adult population. [pmid: 16772765].
160 al-Sahlawi KS, Tawfik OM. Comparative study of the efficacy of lysine acetylsalicylate, indomethacin and pethidine in acute renal colic. European Journal of Emergency Medicine. 1996;3(3):183-6. Not CKD treatment. [pmid: 9023498].
161 Altay B, Horasanli K, Sarica K, et al. Double-blind, placebo-controlled, randomized clinical trial of sublingual or intramuscular piroxicam in the treatment of renal colic. A comparative study. Urologia Internationalis. 2007;79(1):73-5. Sample size less than 50 patients. [pmid: 17627173].
162 Alvarez L, Puleo J, Balint JA. Investigation of gastrointestinal bleeding in patients with end stage renal disease. American Journal of Gastroenterology. 1993;88(1):30-3. Not RCT or controlled trial. [pmid: 8420270].
163 Alvelos M, Ferreira A, Bettencourt P, et al. Effect of saline load and metoclopramide on the renal dopaminergic system in patients with heart failure and healthy controls. Journal of Cardiovascular Pharmacology. 2005;45(3):197-203. Not RCT or controlled trial. [pmid: 15725943].
164 Alvelos M, Ferreira A, Bettencourt P, et al. The effect of dietary sodium restriction on neurohumoral activity and renal dopaminergic response in patients with heart failure. European Journal of Heart Failure. 2004;6(5):593-9. Not CKD treatment. [pmid: 15302007].
165 al-Waili NS, Saloom KY. Intravenous tenoxicam to treat acute renal colic: comparison with buscopan compositum. JPMA - Journal of the Pakistan Medical Association. 1998;48(12):370-2. Not CKD treatment.
166 Al-Waili NS, Saloom KY. Intramuscular piroxicam versus intramuscular diclofenac sodium in the treatment of acute renal colic: double-blind study. European Journal of Medical Research. 1999;4(1):23-6. Not CKD treatment. [pmid: 9892571].
167 Amador-Licona N, Guizar-Mendoza J, Vargas E, et al. The short-term effect of a switch from glibenclamide to metformin on blood pressure and microalbuminuria in patients with type 2 diabetes mellitus. Archives of Medical Research. 2000;31(6):571-5. Sample size less than 50 patients. [pmid: 11257323].
168 Amano J, Suzuki A, Sunamori M. Salutary effect of reduced glutathione on renal function in coronary artery bypass operation. Journal of the American College of Surgeons. 1994;179(6):714-20. Not CKD treatment. [pmid: 7952483].
169 Amano J, Suzuki A, Sunamori M, et al. Effect of calcium antagonist diltiazem on renal function in open heart surgery. Chest. 1995;107(5):1260-5. Sample size less than 50 patients. [pmid: 7750316].
170 Amaral CF, Campolina D, Dias MB, et al. Tourniquet ineffectiveness to reduce the severity of envenoming after Crotalus durissus snake bite in Belo Horizonte, Minas Gerais, Brazil. Toxicon. 1998;36(5):805-8. Not CKD treatment. [pmid: 9655642].
171 Amaresan MS, Geetha R. Early diagnosis of CKD and its prevention. Journal of the Association of Physicians of India. 2008;56:41-6. Not RCT or controlled trial. [pmid: 18472500].
172 Amato RJ. 5T4-modified vaccinia Ankara: progress in tumor-associated antigen-based immunotherapy. Expert Opinion on Biological Therapy. Feb. 2010;10(2):281-7. Not CKD treatment. [pmid: 20088718].
173 Ambwani J, Ubhrani D, Saad R, et al. Could atrial natriuretic peptide be a useful drug therapy for high-risk patients after cardiac surgery?. Interactive Cardiovascular & Thoracic Surgery. 2009;8(4):474-8. Not CKD treatment. [pmid: 19168461].
174 Amini M, Salarifar M, Amirbaigloo A, et al. N-acetylcysteine does not prevent contrast-induced nephropathy after cardiac catheterization in patients with diabetes mellitus and chronic kidney disease: a randomized clinical trial. Trials [Electronic Resource]. 2009;10:45. Not CKD treatment.
175 Aminorroaya A, Janghorbani M, Rezvanian H, et al. Comparison of the effect of pentoxifylline and captopril on proteinuria in patients with type 2 diabetes mellitus. Nephron. 2005;99(3):c73-7. Sample size less than 50 patients. [pmid: 15665549].
176 Amrein PC, Fabian RL. Treatment of recurrent head and neck cancer with cisplatin and 5-fluorouracil vs. the same plus bleomycin and methotrexate. Laryngoscope. 1992;102(8):901-6. Not CKD treatment. [pmid: 1379664].
177 An MM, Zou Z, Shen H, et al. Incidence and risk of significantly raised blood pressure in cancer patients treated with bevacizumab: an updated meta-analysis. European Journal of Clinical Pharmacology. Aug. 2010;66(8):813-21. Not CKD treatment. [pmid: 20401474].
178 Anand A, Anand A, Anand N. Recombinant human erythropoietin for the correction of cancer associated anemia with and without concomitant cytotoxic chemotherapy. Cancer. 1996;77(9):1960-1. Not RCT or controlled trial. [pmid: 8646701].
179 Anand IS, Deswal A, Kereiakes DJ, et al. Comparison of once-daily versus twice-daily dosing of valsartan in patients with chronic stable heart failure. Vascular Health & Risk Management. 2010;6:449-55. Not CKD treatment. [pmid: 20730060].
180 Anastassiades E, Howarth D, Howarth JE, et al. Influence of azathioprine on the ferrokinetics of patients with renal failure before and after treatment with erythropoietin. Nephron. 1994;67(3):291-6. Sample size less than 50 patients. [pmid: 7936018].
181 Anavekar NS, McMurray JJV, Velazquez EJ, et al. Relation between renal dysfunction and cardiovascular outcomes after myocardial infarction. New England Journal of Medicine. 2004;351(13):1285-95. Follow-up less than 6 months. [pmid: 15385655].
182 Anavekar NS, Solomon SD, McMurray JJV, et al. Comparison of renal function and cardiovascular risk following acute myocardial infarction in patients with and without diabetes mellitus. American Journal of Cardiology. 2008;101(7):925-9. Not CKD treatment. [pmid: 18359309].
183 Ancha HR, Spungen AM, Bauman WA, et al. Clinical trial: the efficacy and safety of routine bowel cleansing agents for elective colonoscopy in persons with spinal cord injury - a randomized prospective single-blind study. Alimentary Pharmacology & Therapeutics. Dec. 1. 2009;30(11-12):1110-7. Not CKD treatment. [pmid: 19769634].
184 Andel M, Grzeszczak W, Michalek J, et al. A multinational, multi-centre, observational, cross-sectional survey assessing diabetes secondary care in Central and Eastern Europe (DEPAC Survey). Diabetic Medicine. 2008;25(10):1195-203. Not early CKD. [pmid: 19046198].
185 Anders HJ, Rihl M, Loch O, et al. Prediction of creatinine clearance from serum creatinine in patients with rheumatoid arthritis: comparison of six formulae and one nomogram. Clinical Rheumatology. 2000;19(1):26-9. Not early CKD. [pmid: 10752495].
186 Andersen GS, Hartling OJ, Hein HO, et al. Changes in blood pressure, fluid volumes and glomerular filtration rate during long-term treatment with prizidilol, an antihypertensive drug with combined vasodilatator and beta-adrenoceptor blocking actions. Danish Medical Bulletin. 1985;32(5):280-3. Sample size less than 50 patients. [pmid: 2865088].
187 Andersen K, Weinberger MH, Constance CM, et al. Comparative effects of aliskiren-based and ramipril-based therapy on the renin system during long-term (6 months) treatment and withdrawal in patients with hypertension. Journal of the Renin-Angiotensin-Aldosterone System. 2009;10(3):157-67. Follow-up less than 6 months. [pmid: 19617271].
188 Andersen NH, Mogensen CE. Dual blockade of the renin angiotensin system in diabetic and nondiabetic kidney disease. Current Hypertension Reports. 2004;6(5):369-76. Not RCT or controlled trial. [pmid: 15341690].
189 Andersen PE, Bolstad B, Berg KJ, et al. Iodixanol and ioxaglate in cardioangiography: a double-blind randomized phase III study. Clinical Radiology. 1993;48(4):268-72. Not CKD treatment. [pmid: 8243006].
190 Andersen S, Blouch K, Bialek J, et al. Glomerular permselectivity in early stages of overt diabetic nephropathy. Kidney International. 2000;58(5):2129-37. Sample size less than 50 patients. [pmid: 11044234].
191 Andersen S, Brochner-Mortensen J, Parving HH, et al. Kidney function during and after withdrawal of long-term irbesartan treatment in patients with type 2 diabetes and microalbuminuria. Diabetes Care. 2003;26(12):3296-302. Not RCT or controlled trial. [pmid: 14633817].
192 Andersen S, Mischak H, Zurbig P, et al. Urinary proteome analysis enables assessment of renoprotective treatment in type 2 diabetic patients with microalbuminuria. BMC Nephrology. 2010;11:29. Not relevant to key questions. [pmid: 21040538].
193 Andersen S, Schalkwijk CG, Stehouwer CD, et al. Angiotensin II blockade is associated with decreased plasma leukocyte adhesion molecule levels in diabetic nephropathy. Diabetes Care. 2000;23(7):1031-2. Not CKD treatment. [pmid: 10895868].
194 Andersen S, Tarnow L, Cambien F, et al. Renoprotective effects of losartan in diabetic nephropathy: interaction with ACE insertion/deletion genotype?. Kidney International. 2002;62(1):192-8. Follow-up less than 6 months. [pmid: 12081578].
195 Andersen S, Tarnow L, Rossing P, et al. Renoprotective effects of angiotensin II receptor blockade in type 1 diabetic patients with diabetic nephropathy. Kidney International. 2000;57(2):601-6. Sample size less than 50 patients. [pmid: 10652037].
196 Anderson CM. Sodium chloride treatment of amphotericin B nephrotoxicity. Standard of care? Western Journal of Medicine. 1995;162(4):313-7. Not CKD treatment.
197 Anderson J, Glynn LG, Newell J, et al. The impact of renal insufficiency and anaemia on survival in patients with cardiovascular disease: a cohort study. BMC Cardiovascular Disorders. 2009;9:51. Not RCT or controlled trial. [pmid: 19909540].
198 Anderson JW, Blake JE, Turner J, et al. Effects of soy protein on renal function and proteinuria in patients with type 2 diabetes. American Journal of Clinical Nutrition. 1998;68(6 Suppl):1347S-53S. Sample size less than 50 patients. [pmid: 9848497].
199 Anderson TJ, Sun YH, Hubacek J, et al. Effects of folinic acid on forearm blood flow in patients with end-stage renal disease. Nephrology Dialysis Transplantation. 2006;21(7):1927-33. Sample size less than 50 patients.
200 Andersson LG, Jeppsson A, Bratteby LE, et al. Renal function during cardiopulmonary bypass: influence of the calcium entry blocker felodipine. Anesthesia & Analgesia. 1996;83(1):34-40. Follow-up less than 6 months. [pmid: 8659761].
201 Anderton JL, Gill M, Notghi A. Renal haemodynamic effects of bunazosin retard and prazosin in mild to moderately hypertensive patients with normal or moderately impaired renal function. Nephrology Dialysis Transplantation. 1994;9(6):607-12. Follow-up less than 6 months.
202 Anderton JL, Notghi A. An evaluation of the efficacy and safety of doxazosin in the treatment of hypertension associated with renal insufficiency. Journal of Human Hypertension. Suppl 3. 1990;4:52-7. Sample size less than 50 patients. [pmid: 2148196].
203 Ando K, Ohtsu H, Arakawa Y, et al. Rationale and design of the Eplerenone combination Versus conventional Agents to Lower blood pressure on Urinary Antialbuminuric Treatment Effect (EVALUATE) trial: a double-blinded randomized placebo-controlled trial to evaluate the antialbuminuric effects of an aldosterone blocker in hypertensive patients with albuminuria. Hypertension Research - Clinical & Experimental. Jun. 2010;33(6):616-21. Not RCT or controlled trial.
204 Ando Y, Minami H, Saka H, et al. Pharmacokinetic study of carboplatin given on a 5-day intravenous schedule. Japanese Journal of Cancer Research. 1997;88(5):517-21. Not CKD treatment. [pmid: 9247610].
205 Andrew E, Berg KJ, Nossen JO, et al. Renal effects of iodixanol in patients: a comparison with other radiographic contrast media. Academic Radiology. Suppl 2. 1996;3:S440-3. Not RCT or controlled trial. [pmid: 8796624].
206 Angeli P, Gatta A, Caregaro L, et al. Effects of iloprost, a prostacyclin analog derivative, on renal plasma flow, renal function, and renin-aldosterone system in humans. Clinical Pharmacology & Therapeutics. 1988;44(2):211-6. Sample size less than 50 patients. [pmid: 2456174].
207 Angermann CE, Stork S, Costard-Jackle A, et al. Reduction of cyclosporine after introduction of mycophenolate mofetil improves chronic renal dysfunction in heart transplant recipients--the IMPROVED multi-centre study. European Heart Journal. 2004;25(18):1626-34. Not early CKD. [pmid: 15351162].
208 Angevin E, Valteau-Couanet D, Farace F, et al. Phase I study of prolonged low-dose subcutaneous recombinant interleukin-2 (IL-2) in patients with advanced cancer. Journal of Immunotherapy with Emphasis on Tumor Immunology. 1995;18(3):188-95. Follow-up less than 6 months. [pmid: 8770775].
209 Angoulvant D, Cucherat M, Rioufol G, et al. Preventing acute decrease in renal function induced by coronary angiography (PRECORD): a prospective randomized trial. Archives of cardiovascular diseases. 2009;102(11):761-7. Not CKD treatment. [pmid: 19944392].
210 Angstwurm MW, Schottdorf J, Schopohl J, et al. Selenium replacement in patients with severe systemic inflammatory response syndrome improves clinical outcome. Critical Care Medicine. 1999;27(9):1807-13. Sample size less than 50 patients. [pmid: 10507602].
211 Annuk M, Fellstrom B, Lind L. Cyclooxygenase inhibition improves endothelium-dependent vasodilatation in patients with chronic renal failure. Nephrology Dialysis Transplantation. 2002;17(12):2159-63. Sample size less than 50 patients.
212 Anothaisintawee T, Rattanasiri S, Ingsathit A, et al. Prevalence of chronic kidney disease: a systematic review and meta-analysis. Clinical Nephrology. 2009;71(3):244-54. Not relevant to key questions. [pmid: 19281734].
213 Anselmino M, Biondi-Zoccai G, Sheiban I. Letter regarding article by Solomon et al, “Cardiac Angiography in REnally Impaired Patients (CARE) study: a randomized double-blind trial of contrast-induced nephropathy in patients with chronic kidney disease”. Circulation. 2008;117(7):e166. author reply e7. Not CKD treatment. [pmid: 18285573].
214 Ansquer JC, Foucher C, Aubonnet P, et al. Fibrates and microvascular complications in diabetes--insight from the FIELD study. Current Pharmaceutical Design. 2009;15(5):537-52. Not CKD treatment. [pmid: 19199980].
215 Ansquer JC, Dalton RN, Causse E, et al. Effect of fenofibrate on kidney function: a 6-week randomized crossover trial in healthy people. American Journal of Kidney Diseases. 2008;51(6):904-13. Not CKD treatment. [pmid: 18501783].
216 Ansquer JC, Foucher C, Rattier S, et al. Fenofibrate reduces progression to microalbuminuria over 3 years in a placebo-controlled study in type 2 diabetes: results from the Diabetes Atherosclerosis Intervention Study (DAIS). American Journal of Kidney Diseases. 2005;45(3):485-93. Not relevant to key questions. [pmid: 15754270].
217 Anthony J, Rees AE, Davey DA. Indoramin in the treatment of pregnancy hypertension. A placebo-controlled trial comparing the efficacy of indoramin with alpha-methyldopa. South African Medical Journal. Suid-Afrikaanse Tydskrif Vir Geneeskunde. 1990;78(8):458-61. Not CKD treatment. [pmid: 2218781].
218 Antonucci F, Calo L, Rizzolo M, et al. Nifedipine can preserve renal function in patients undergoing aortic surgery with infrarenal crossclamping. Nephron. 1996;74(4):668-73. Not CKD treatment. [pmid: 8956299].
219 Antrum R, Gorst K, Galvin K, et al. A comparison of teicoplanin vs. cephradine and metronidazole in surgical prophylaxis: an interim analysis. Scandinavian Journal of Infectious Diseases Supplement. 1990;72:45-53. Not CKD treatment. [pmid: 1982576].
220 Aoki J, Mintz GS, Weissman NJ, et al. Impact of mild or moderate renal insufficiency on the intravascular ultrasonic analysis of chronic vascular response to paclitaxel-eluting and bare-metal stents (from the TAXUS IV, V, and VI trials). American Journal of Cardiology. 2008;102(8):1009-16. Not CKD treatment. [pmid: 18929701].
221 Aoki J, Ong ATL, Hoye A, et al. Five year clinical effect of coronary stenting and coronary artery bypass grafting in renal insufficient patients with multivessel coronary artery disease: insights from ARTS trial. European Heart Journal. 2005;26(15):1488-93. Not RCT or controlled trial. [pmid: 15860519].
222 Apakkan Aksun S, Ozmen B, Ozmen D, et al. Serum and urinary nitric oxide in Type 2 diabetes with or without microalbuminuria: relation to glomerular hyperfiltration. Journal of Diabetes & its Complications. 2003;17(6):343-8. Not early CKD. [pmid: 14583179].
223 Appel GB. COX-2 inhibitors and the kidney. Clinical & Experimental Rheumatology. 2001;19(6 Suppl 25):S37-40. Not RCT or controlled trial. [pmid: 11695250].
224 Appel LJ, Middleton J, Miller ER 3rd, et al. The rationale and design of the AASK cohort study. Journal of the American Society of Nephrology. 2003;14(7 Suppl 2):S166-72. Not RCT or controlled trial. [pmid: 12819323].
225 Appel LJ, Wright JT Jr., Greene T, et al. Intensive blood-pressure control in hypertensive chronic kidney disease. New England Journal of Medicine. Sep. 2. 2010;363(10):918-29. Not relevant to key questions. [pmid: 20818902].
226 Appel LJ, Wright JT Jr., Greene T, et al. Long-term effects of renin-angiotensin system-blocking therapy and a low blood pressure goal on progression of hypertensive chronic kidney disease in African Americans. Archives of Internal Medicine. 2008;168(8):832-9. Not CKD treatment. [pmid: 18443258].
227 Apperloo AJ, de Zeeuw D, de Jong PE. Short-term antiproteinuric response to antihypertensive treatment predicts long-term GFR decline in patients with non-diabetic renal disease. Kidney International - Supplement. 1994;45:S174-8. Sample size less than 50 patients. [pmid: 8158890].
228 Apperloo AJ, de Zeeuw D, de Jong PE. A short-term antihypertensive treatment-induced fall in glomerular filtration rate predicts long-term stability of renal function. Kidney International. 1997;51(3):793-7. Follow-up less than 6 months. [pmid: 9067912].
229 Apperloo AJ, de Zeeuw D, Sluiter HE, et al. Differential effects of enalapril and atenolol on proteinuria and renal haemodynamics in non-diabetic renal disease. BMJ. 1991;303(6806):821-4. Sample size less than 50 patients. [pmid: 1932973].
230 Appleby C, Foley RN. Hypertension in end-stage renal disease. Minerva Urologica e Nefrologica. 2002;54(1):37-43. Not RCT or controlled trial. [pmid: 11912485].
231 Apseloff G, Wilner KD, von Deutsch DA, et al. Tenidap sodium decreases renal clearance and increases steady-state concentrations of lithium in healthy volunteers. British Journal of Clinical Pharmacology. Suppl 1. 1995;39:25S-8S. Sample size less than 50 patients. [pmid: 7547089].
232 Apseloff G, Wilner KD, von Deutsch DA, et al. Sertraline does not alter steady-state concentrations or renal clearance of lithium in healthy volunteers. Journal of Clinical Pharmacology. 1992;32(7):643-6. Not CKD treatment. [pmid: 1640004].
233 Aranda P, Segura J, Ruilope LM, et al. Long-term renoprotective effects of standard versus high doses of telmisartan in hypertensive nondiabetic nephropathies. American Journal of Kidney Diseases. 2005;46(6):1074-9. Sample size less than 50 patients. [pmid: 16310573].
234 Arcaro G, Zenere BM, Saggiani F, et al. ACE inhibitors improve endothelial function in type 1 diabetic patients with normal arterial pressure and microalbuminuria. Diabetes Care. 1999;22(9):1536-42. Sample size less than 50 patients. [pmid: 10480522].
235 Arguedas JA, Perez MI, Wright JM. Treatment blood pressure targets for hypertension. Cochrane Database of Systematic Reviews. 2009;(3):CD004349. Not RCT or controlled trial. [pmid: 19588353].
236 Arguedas JA, Perez MI, Wright JM. Treatment blood pressure targets for hypertension. Cochrane Database of Systematic Reviews. 2009;(3):CD004349. Not RCT or controlled trial. [pmid: 19588353].
237 Arici M, Usalan C, Altun B, et al. Radiocontrast-induced nephrotoxicity and urinary alpha-glutathione S-transferase levels: effect of amlodipine administration. International Urology & Nephrology. 2003;35(2):255-61. Not relevant to key questions. [pmid: 15072506].
238 Armstrong GD, Rowe PC, Goodyer P, et al. A phase I study of chemically synthesized verotoxin (Shiga-like toxin) Pk-trisaccharide receptors attached to chromosorb for preventing hemolytic-uremic syndrome. Journal of Infectious Diseases. 1995;171(4):1042-5. Not RCT or controlled trial. [pmid: 7706786].
239 Armstrong LE, Pumerantz AC, Roti MW, et al. Fluid, electrolyte, and renal indices of hydration during 11 days of controlled caffeine consumption. International Journal of Sport Nutrition & Exercise Metabolism. 2005;15(3):252-65. Not RCT or controlled trial. [pmid: 16131696].
240 Arns W, Gies M, Choi L, et al. Absorption characteristics of EC-MPS--an enteric-coated formulation of mycophenolic sodium. International Journal of Clinical Pharmacology & Therapeutics. 2006;44(8):375-85. Not early CKD. [pmid: 16961168].
241 Aronoff GR. Therapeutic implications associated with renal studies of nabumetone. Journal of Rheumatology - Supplement. 1992;36:25-31. Not CKD treatment.
242 Arora R, Clark L, Taylor M. Treatment of high-risk African American patients: left ventricular dysfunction, heart failure, renal disease, and postmyocardial infarction. Journal of Clinical Hypertension. 2003;5(1 Suppl 1):26-31. Not RCT or controlled trial. [pmid: 12556670].
243 Arora S, Clarke K, Srinivasan V, et al. Effect of nesiritide on renal function in patients admitted for decompensated heart failure. Qjm. 2007;100(11):699-706. Follow-up less than 6 months. [pmid: 17971392].
244 Arredondo A, Burke TA, Carides GW, et al. The impact of losartan on the lifetime incidence of ESRD and costs in Mexico. Revista de Investigacion Clinica. 2005;57(3):399-405. Sample size less than 50 patients. [pmid: 16187699].
245 Arroyo V, Fernandez J, Mas A, et al. Molecular adsorbents recirculating system (MARS) and the failing liver: a negative editorial for a positive trial?. Hepatology. 2008;47(6):2143-4. Not CKD treatment. [pmid: 18508305].
246 Artz AS, Fergusson D, Drinka PJ, et al. Mechanisms of unexplained anemia in the nursing home. Journal of the American Geriatrics Society. 2004;52(3):423-7. Not CKD treatment. [pmid: 14962159].
247 Arzilli F, Giovannetti R, Lenzi M, et al. Acute hemodynamic (systemic and renal) and humoral effects of three increasing doses of iloprost in essential hypertensives. American Journal of Hypertension. 1989;2(11 Pt 1):856-60. Sample size less than 50 patients. [pmid: 2480147].
248 Arzilli F, Magagna A, Giovannetti R, et al. Acute dose-response curve of enalapril in renovascular hypertensives. American Journal of Hypertension. 1988;1(3 Pt 3):75S-8S. Sample size less than 50 patients. [pmid: 2843201].
249 Ascione R, Lloyd CT, Underwood MJ, et al. On-pump versus off-pump coronary revascularization: evaluation of renal function. Annals of Thoracic Surgery. 1999;68(2):493-8. Follow-up less than 6 months. [pmid: 10475418].
250 Ashworth A, Webb ST. Does the prophylactic administration of N-acetylcysteine prevent acute kidney injury following cardiac surgery?. Interactive Cardiovascular & Thoracic Surgery. Sep. 2010;11(3):303-8. Not CKD treatment. [pmid: 20570977].
251 Asif A, Epstein DL, Epstein M. Dopamine-1 receptor agonist: renal effects and its potential role in the management of radiocontrast-induced nephropathy. Journal of Clinical Pharmacology. 2004;44(12):1342-51. Not relevant to key questions. [pmid: 15545304].
252 Aspelin P, Aubry P, Fransson SG, et al. Nephrotoxic effects in high-risk patients undergoing angiography. New England Journal of Medicine. 2003;348(6):491-9. Not CKD treatment. [pmid: 12571256].
253 Aspelin P, Aubry P, Fransson SG, et al. Cost-effectiveness of iodixanol in patients at high risk of contrast-induced nephropathy. American Heart Journal. 2005;149(2):298-303. Not RCT or controlled trial. [pmid: 15846268].
254 Asrani SK, Leise MD, West CP, et al. Use of sirolimus in liver transplant recipients with renal insufficiency: a systematic review and meta-analysis. Hepatology. Oct. 2010;52(4):1360-70. Not CKD treatment. [pmid: 20815021].
255 Assadi F. Acetazolamide for prevention of contrast-induced nephropathy: a new use for an old drug. Pediatric Cardiology. 2006;27(2):238-42. Not RCT or controlled trial. [pmid: 16391986].
256 Assan R, Blanchet F, Feutren G, et al. Normal renal function 8 to 13 years after cyclosporin A therapy in 285 diabetic patients. Diabetes/Metabolism Research Reviews. 2002;18(6):464-72. Not CKD treatment.
257 Asselbergs FW, van der Harst P, van Roon AM, et al. Long-term effects of pravastatin and fosinopril on peripheral endothelial function in albuminuric subjects. Atherosclerosis. 2008;196(1):349-55. Not RCT or controlled trial. [pmid: 17141245].
258 Asselbergs FW, van Gilst WH. Angiotensin converting enzyme inhibition in cardiovascular risk populations: a practical approach to identify the patient who will benefit most. Current Opinion in Cardiology. 2007;22(4):267-72. Not CKD treatment. [pmid: 17556876].
259 Asselbergs FW, van Roon AM, Hillege HL, et al. Effects of fosinopril and pravastatin on carotid intima-media thickness in subjects with increased albuminuria. Stroke. 2005;36(3):649-53. Sample size less than 50 patients. [pmid: 15692120].
260 Assy N, Kayal M, Mejirisky Y, et al. The changes in renal function after a single dose of intravenous furosemide in patients with compensated liver cirrhosis. BMC Gastroenterology. 2006;6:39. Sample size less than 50 patients. [pmid: 17134488].
261 Astor BC, Levey AS, Stevens LA, et al. Method of glomerular filtration rate estimation affects prediction of mortality risk. Journal of the American Society of Nephrology. 2009;20(10):2214-22. Not RCT or controlled trial. [pmid: 19762497].
262 Astor BC, Yi S, Hiremath L, et al. N-terminal prohormone brain natriuretic peptide as a predictor of cardiovascular disease and mortality in blacks with hypertensive kidney disease: the African American Study of Kidney Disease and Hypertension (AASK). Circulation. 2008;117(13):1685-92. Not CKD treatment. [pmid: 18362234].
263 Athyros VG, Mikhailidis DP, Papageorgiou AA, et al. The effect of statins versus untreated dyslipidaemia on renal function in patients with coronary heart disease. A subgroup analysis of the Greek atorvastatin and coronary heart disease evaluation (GREACE) study. Journal of Clinical Pathology. 2004;57(7):728-34. Not relevant to key questions. [pmid: 15220366].
264 Athyros VG, Papageorgiou AA, Elisaf M, et al. Statins and renal function in patients with diabetes mellitus. Current Medical Research & Opinion. 2003;19(7):615-7. Not CKD treatment. [pmid: 14606984].
265 Atkins RC, Briganti EM, Lewis JB, et al. Proteinuria reduction and progression to renal failure in patients with type 2 diabetes mellitus and overt nephropathy. American Journal of Kidney Diseases. 2005;45(2):281-7. Follow-up less than 6 months. [pmid: 15685505].
266 Atmaca A, Gedik O. Effects of angiotensin-converting enzyme inhibitors, angiotensin II receptor blockers, and their combination on microalbuminuria in normotensive patients with type 2 diabetes. Advances in Therapy. 2006;23(4):615-22. Not relevant to key questions. [pmid: 17050503].
267 Atthobari J, Brantsma AH, Gansevoort RT, et al. The effect of statins on urinary albumin excretion and glomerular filtration rate: results from both a randomized clinical trial and an observational cohort study. Nephrology Dialysis Transplantation. 2006;21(11):3106-14. Not RCT or controlled trial.
268 Atthobari J, Gansevoort RT, Visser ST, et al. The effect of screening for cardio-renal risk factors on drug use in the general population. British Journal of Clinical Pharmacology. 2007;64(6):810-8. Not CKD treatment. [pmid: 18078475].
269 Aulitzky WE, Grosse-Wilde H, Westhoff U, et al. Enhanced serum levels of soluble HLA class I molecules are induced by treatment with recombinant interferon-gamma (IFN-gamma). Clinical & Experimental Immunology. 1991;86(2):236-9. Not CKD treatment. [pmid: 1934591].
270 Aurell M, Bengtsson C, Bjorck S. Enalapril versus metoprolol in primary hypertension--effects on the glomerular filtration rate. Nephrology Dialysis Transplantation. 1997;12(11):2289-94. Not early CKD.
271 Austen SK, Coombes JS, Fassett RG. Homocysteine and cardiovascular disease in renal disease. Nephrology. 2003;8(6):285-95. Not CKD treatment. [pmid: 15012699].
272 Autier J, Escudier B, Wechsler J, et al. Prospective study of the cutaneous adverse effects of sorafenib, a novel multikinase inhibitor. Archives of Dermatology. 2008;144(7):886-92. Not CKD treatment. [pmid: 18645140].
273 Aviles RJ, Askari AT, Lindahl B, et al. Troponin T levels in patients with acute coronary syndromes, with or without renal dysfunction. [Summary for patients in CMAJ. 2002 Sep 17; 167(6):671; PMID:12358205]. New England Journal of Medicine. 2002;346(26):2047-52. Not RCT or controlled trial. [pmid: 12087140].
274 Axelsson J, Bergsten A, Qureshi AR, et al. Elevated resistin levels in chronic kidney disease are associated with decreased glomerular filtration rate and inflammation, but not with insulin resistance. Kidney International. 2006;69(3):596-604. Not RCT or controlled trial. [pmid: 16395259].
275 Axelsson J, Witasp A, Carrero JJ, et al. Circulating levels of visfatin/pre-B-cell colony-enhancing factor 1 in relation to genotype, GFR, body composition, and survival in patients with CKD. American Journal of Kidney Diseases. 2007;49(2):237-44. Not RCT or controlled trial. [pmid: 17261426].
276 Aybek Z, Turan T, Yonguc T, et al. Requirement of analgesia for extracorporeal shock wave lithotripsy and efficacy of a nonsteroidal antiinflammatory drug: piroxicam. European Urology. 1998;34(3):207-9. Not CKD treatment. [pmid: 9732194].
277 Azadbakht L, Esmaillzadeh A. Soy-protein consumption and kidney-related biomarkers among type 2 diabetics: a crossover, randomized clinical trial. Journal of Renal Nutrition. 2009;19(6):479-86. Follow-up less than 6 months. [pmid: 19758824].
278 Azadbakht L, Shakerhosseini R, Atabak S, et al. Beneficiary effect of dietary soy protein on lowering plasma levels of lipid and improving kidney function in type II diabetes with nephropathy. European Journal of Clinical Nutrition. 2003;57(10):1292-4. Sample size less than 50 patients. [pmid: 14506491].
279 Azar RR, Prpic R, Ho KK, et al. Impact of end-stage renal disease on clinical and angiographic outcomes after coronary stenting. American Journal of Cardiology. 2000;86(5):485-9. Sample size less than 50 patients. [pmid: 11009262].
280 Azevedo MJ, Pinotti AF, Gross JL, et al. Preserved left ventricular systolic and diastolic function in normoalbuminuric insulin-dependent diabetic patients with glomerular hyperfiltration. Diabetes Research & Clinical Practice. 1994;25(2):103-10. Sample size less than 50 patients. [pmid: 7821189].
281 Azizi M, Bissery A, Lamarre-Cliche M, et al. Integrating drug pharmacokinetics for phenotyping individual renin response to angiotensin II blockade in humans. Hypertension. 2004;43(4):785-90. Not relevant to key questions. [pmid: 15023936].
282 Azmus AD, Gottschall C, Manica A, et al. Effectiveness of acetylcysteine in prevention of contrast nephropathy. Journal of Invasive Cardiology. 2005;17(2):80-4. Not RCT or controlled trial. [pmid: 15687530].
283 Baas AF, Janssen KJM, Prinssen M, et al. The Glasgow Aneurysm Score as a tool to predict 30-day and 2-year mortality in the patients from the Dutch Randomized Endovascular Aneurysm Management trial. Journal of Vascular Surgery. 2008;47(2):277-81. Not CKD treatment. [pmid: 18241749].
284 Baba S, Group JMS. Nifedipine and enalapril equally reduce the progression of nephropathy in hypertensive type 2 diabetics. Diabetes Research & Clinical Practice. 2001;54(3):191-201. Not early CKD. [pmid: 11689274].
285 Baba T, Boku A, Ishizaki T, et al. Renal effects of nicardipine in patients with mild-to-moderate essential hypertension. American Heart Journal. 1986;111(3):552-7. Sample size less than 50 patients. [pmid: 3953366].
286 Baba T, Heinemann L, Berger M, et al. Effect of 4-hour hyperglycaemia and hyperinsulinaemia on plasma atrial natriuretic factor concentrations. Hormone & Metabolic Research. 1995;27(2):95-9. Not CKD treatment. [pmid: 7759064].
287 Baba T, Ishizaki T, Ido Y, et al. Renal effects of nicardipine, a calcium entry blocker, in hypertensive type II diabetic patients with nephropathy. Diabetes. 1986;35(11):1206-14. Sample size less than 50 patients. [pmid: 3530849].
288 Baba T, Ishizaki T, Murabayashi S, et al. Multiple oral doses of nicardipine, a calcium-entry blocker: effects on renal function, plasma renin activity, and aldosterone concentration in mild-to-moderate essential hypertension. Clinical Pharmacology & Therapeutics. 1987;42(2):232-9. Follow-up less than 6 months. [pmid: 3301155].
289 Baba T, Murabayashi S, Aoyagi K, et al. Effects of dilevalol, an R, R-isomer of labetalol, on blood pressure and renal function in patients with mild-to-moderate essential hypertension. European Journal of Clinical Pharmacology. 1988;35(1):9-15. Sample size less than 50 patients. [pmid: 2905992].
290 Baba T, Murabayashi S, Takebe K. Comparison of the renal effects of angiotensin converting enzyme inhibitor and calcium antagonist in hypertensive type 2 (non-insulin-dependent) diabetic patients with microalbuminuria: a randomised controlled trial. Diabetologia. 1989;32(1):40-4. Sample size less than 50 patients. [pmid: 2540054].
291 Baba T, Murabayashi S, Tomiyama T, et al. Comparison of the renal effects of dilevalol and carteolol in patients with mild to moderate essential hypertension. European Journal of Clinical Pharmacology. 1990;38(3):305-7. Sample size less than 50 patients. [pmid: 2187701].
292 Baba T, Tomiyama T, Murabayashi S, et al. Renal effects of bunazosin, a new alpha 1-adrenoceptor blocker, in patients with mild-to-moderate essential hypertension. Journal of Cardiovascular Pharmacology. 1990;15(5):826-30. Not relevant to key questions. [pmid: 1692944].
293 Baber U, Toto RD, de Lemos JA. Statins and cardiovascular risk reduction in patients with chronic kidney disease and end-stage renal failure. American Heart Journal. 2007;153(4):471-7. Not relevant to key questions. [pmid: 17383281].
294 Backlund M, Pere P, Lepantalo M, et al. Effect of intra-aortic magnesium on renal function during and after abdominal aortic surgery: a pilot study. Acta Anaesthesiologica Scandinavica. 2000;44(5):605-11. Not early CKD. [pmid: 10786750].
295 Backman L, Ringden O, Tollemar J, et al. An increased risk of relapse in cyclosporin-treated compared with methotrexate-treated patients: long-term follow-up of a randomized trial. Bone Marrow Transplantation. 1988;3(5):463-71. Not CKD treatment. [pmid: 2847843].
296 Badalamenti S, Salerno F, Lorenzano E, et al. Renal effects of dietary supplementation with fish oil in cyclosporine-treated liver transplant recipients. Hepatology. 1995;22(6):1695-71. Follow-up less than 6 months. [pmid: 7489976].
297 Badalamenti S, Salerno F, Salmeron JM, et al. Lack of renal effects of fish oil administration in patients with advanced cirrhosis and impaired glomerular filtration. Hepatology. 1997;25(2):313-6. Follow-up less than 6 months. [pmid: 9021940].
298 Bader BD, Berger ED, Heede MB, et al. What is the best hydration regimen to prevent contrast media-induced nephrotoxicity?. Clinical Nephrology. 2004;62(1):1-7. Not CKD treatment. [pmid: 15267006].
299 Bagshaw SM, Delaney A, Haase M, et al. Loop diuretics in the management of acute renal failure: a systematic review and meta-analysis. Critical Care & Resuscitation. 2007;9(1):60-8. Not RCT or controlled trial. [pmid: 17352669].
300 Bagshaw SM, Delaney A, Jones D, et al. Diuretics in the management of acute kidney injury: a multinational survey. Contributions to Nephrology. 2007;156:236-49. Not RCT or controlled trial. [pmid: 17464133].
301 Bagshaw SM, Ghali WA. Acetylcysteine for prevention of contrast-induced nephropathy after intravascular angiography: a systematic review and meta-analysis. BMC Medicine. 2004;2:38. Not relevant to key questions. [pmid: 15500690].
302 Bagshaw SM, Ghali WA. Theophylline for prevention of contrast-induced nephropathy: a systematic review and meta-analysis. Archives of Internal Medicine. 2005;165(10):1087-93. Not early CKD. [pmid: 15911721].
303 Bagshaw SM, Gibney RTN, McAlister FA, et al. The SPARK Study: a phase II randomized blinded controlled trial of the effect of furosemide in critically ill patients with early acute kidney injury. Trials [Electronic Resource]. 2010;11:50. Not RCT or controlled trial.
304 Bagshaw SM, McAlister FA, Manns BJ, et al. Acetylcysteine in the prevention of contrast-induced nephropathy: a case study of the pitfalls in the evolution of evidence. Archives of Internal Medicine. 2006;166(2):161-6. Not RCT or controlled trial. [pmid: 16432083].
305 Baigent C, Landray M. Which cardiovascular risk factors matter in chronic kidney disease?. Nephrology Dialysis Transplantation. 2007;22(1):9-11. Not CKD treatment.
306 Baigent C, Landray M, Warren M. Statin therapy in kidney disease populations: potential benefits beyond lipid lowering and the need for clinical trials. Current Opinion in Nephrology & Hypertension. 2004;13(6):601-5. Not RCT or controlled trial. [pmid: 15483449].
307 Bailey RR, Carlson RV, Walker RJ, et al. Effect of oral penbutolol on renal haemodynamics of hypertensive patients with renal insufficiency. New Zealand Medical Journal. 1985;98(785):683-5. Follow-up less than 6 months. [pmid: 3863029].
308 Bailey RR, Nairn PL, Walker RJ. Effect of doxazosin on blood pressure and renal haemodynamics of hypertensive patients with renal failure. New Zealand Medical Journal. 1986;99(815):942-5. Sample size less than 50 patients. [pmid: 2949169].
309 Bailey SR. Past and present attempts to prevent radiocontrast nephropathy. Reviews in Cardiovascular Medicine. Suppl 1. 2001;2:S14-8. Not CKD treatment. [pmid: 12439363].
310 Bain R, Rohde R, Hunsicker LG, et al. A controlled clinical trial of angiotensin-converting enzyme inhibition in type I diabetic nephropathy: study design and patient characteristics. The Collaborative Study Group. Journal of the American Society of Nephrology. 1992;3(4 Suppl):S97-103. Not RCT or controlled trial. [pmid: 1457767].
311 Bainbridge AD, Meredith PA, Elliott HL. A clinical pharmacological assessment of doxazosin and enalapril in combination. British Journal of Clinical Pharmacology. 1993;36(6):599-602. Sample size less than 50 patients. [pmid: 12959279].
312 Baker CSR, Wragg A, Kumar S, et al. A rapid protocol for the prevention of contrast-induced renal dysfunction: the RAPPID study. Journal of the American College of Cardiology. 2003;41(12):2114-8. Not CKD treatment. [pmid: 12821233].
313 Baker J, Cotter JD, Gerrard DF, et al. Effects of indomethacin and celecoxib on renal function in athletes. Medicine & Science in Sports & Exercise. 2005;37(5):712-7. Not RCT or controlled trial. [pmid: 15870622].
314 Baker LR, Abrams L, Roe CJ, et al. 1,25(OH)2D3 administration in moderate renal failure: a prospective double-blind trial. Kidney International. 1989;35(2):661-9. Sample size less than 50 patients. [pmid: 2651758].
315 Baker LR, Abrams SM, Roe CJ, et al. Early therapy of renal bone disease with calcitriol: a prospective double-blind study. Kidney International - Supplement. 1989;27:S140-2. Sample size less than 50 patients. [pmid: 2699994].
316 Bakris G. Inclusion of albuminuria in hypertension and heart guidelines. Kidney International - Supplement. 2004;(92):S124-5. Not RCT or controlled trial. [pmid: 15485406].
317 Bakris G, Viberti G, Weston WM, et al. Rosiglitazone reduces urinary albumin excretion in type II diabetes. Journal of Human Hypertension. 2003;17(1):7-12. Sample size less than 50 patients. [pmid: 12571611].
318 Bakris GL. Effects of diltiazem or lisinopril on massive proteinuria associated with diabetes mellitus. Annals of Internal Medicine. 1990;112(9):707-8. Sample size less than 50 patients. [pmid: 2159250].
319 Bakris GL. Role for beta-blockers in the management of diabetic kidney disease. American Journal of Hypertension. 2003;16(9 Pt 2):7S-12S. Not RCT or controlled trial. [pmid: 14511896].
320 Bakris GL. ACE inhibitors and ARBs: are they better than other agents to slow nephropathy progression?. Journal of Clinical Hypertension. 2007;9(6):413-5. Not relevant to key questions. [pmid: 17541325].
321 Bakris GL, Barnhill BW, Sadler R. Treatment of arterial hypertension in diabetic humans: importance of therapeutic selection. Kidney International. 1992;41(4):912-9. Sample size less than 50 patients. [pmid: 1325010].
322 Bakris GL, Fonseca V, Katholi RE, et al. Differential effects of beta-blockers on albuminuria in patients with type 2 diabetes. Hypertension. 2005;46(6):1309-15. Not relevant to key questions. [pmid: 16286578].
323 Bakris GL, Mangrum A, Copley JB, et al. Effect of calcium channel or beta-blockade on the progression of diabetic nephropathy in African Americans. Hypertension. 1997;29(3):744-50. Sample size less than 50 patients. [pmid: 9052890].
324 Bakris GL, Ruilope L, Locatelli F, et al. Treatment of microalbuminuria in hypertensive subjects with elevated cardiovascular risk: results of the IMPROVE trial. Kidney International. 2007;72(7):879-85. Not RCT or controlled trial. [pmid: 17667984].
325 Bakris GL, Ruilope L, Locatelli F, et al. Rationale and design of a study to evaluate management of proteinuria in patients at high risk for vascular events: the IMPROVE trial. Journal of Human Hypertension. 2006;20(9):693-700. Not relevant to key questions. [pmid: 16710287].
326 Bakris GL, Siomos M, Richardson D, et al. ACE inhibition or angiotensin receptor blockade: impact on potassium in renal failure. VAL-K Study Group. Kidney International. 2000;58(5):2084-92. Sample size less than 50 patients. [pmid: 11044229].
327 Bakris GL, Slataper R, Vicknair N, et al. ACE inhibitor mediated reductions in renal size and microalbuminuria in normotensive, diabetic subjects. Journal of Diabetes & its Complications. 1994;8(1):2-6. Sample size less than 50 patients. [pmid: 8167383].
328 Bakris GL, Starke U, Heifets M, et al. Renal effects of oral prostaglandin supplementation after ibuprofen in diabetic subjects: a double-blind, placebo-controlled, multicenter trial. Journal of the American Society of Nephrology. 1995;5(9):1684-8. Sample size less than 50 patients. [pmid: 7780057].
329 Bakris GL, Toto RD, McCullough PA. Rationale and design of a study comparing two fixed-dose combination regimens to reduce albuminuria in patients with type II diabetes and hypertension. Journal of Human Hypertension. 2005;19(2):139-44. Not relevant to key questions. [pmid: 15457206].
330 Bakris GL, Weir MR. Angiotensin-converting enzyme inhibitor-associated elevations in serum creatinine: is this a cause for concern?. Archives of Internal Medicine. 2000;160(5):685-93. Not relevant to key questions. [pmid: 10724055].
331 Bakris GL, Weir MR, DeQuattro V, et al. Effects of an ACE inhibitor/calcium antagonist combination on proteinuria in diabetic nephropathy. Kidney International. 1998;54(4):1283-9. Sample size less than 50 patients. [pmid: 9767545].
332 Bakris GL, Weir MR, Secic M, et al. Differential effects of calcium antagonist subclasses on markers of nephropathy progression. Kidney International. 2004;65(6):1991-2002. Not early CKD. [pmid: 15149313].
333 Bakris GL, Weir MR, Shanifar S, et al. Effects of blood pressure level on progression of diabetic nephropathy: results from the RENAAL study. Archives of Internal Medicine. 2003;163(13):1555-65. Not CKD treatment. [pmid: 12860578].
334 Bakris GL, Williams M, Dworkin L, et al. Preserving renal function in adults with hypertension and diabetes: a consensus approach. National Kidney Foundation Hypertension and Diabetes Executive Committees Working Group. American Journal of Kidney Diseases. 2000;36(3):646-61. Not relevant to key questions. [pmid: 10977801].
335 Balakrishnan VS, Coles GA, Williams JD. A potential role for endogenous adenosine in control of human glomerular and tubular function. American Journal of Physiology. 1993;265(4 Pt 2):F504-10. Not CKD treatment. [pmid: 8238379].
336 Balakrishnan VS, Coles GA, Williams JD. Functional role of endogenous adenosine in human chronic renal disease. Experimental Nephrology. 1996;4(1):26-36. Sample size less than 50 patients. [pmid: 8788597].
337 Balakrishnan VS, Rao M, Menon V, et al. Resistance training increases muscle mitochondrial biogenesis in patients with chronic kidney disease. Clinical Journal of The American Society of Nephrology: CJASN. Jun. 2010;5(6):996-1002. Follow-up less than 6 months. [pmid: 20498251].
338 Balamuthusamy S, Srinivasan L, Verma M, et al. Renin angiotensin system blockade and cardiovascular outcomes in patients with chronic kidney disease and proteinuria: a meta-analysis. [Erratum appears in Am Heart J. 2009 Mar;157(3):501 Note: Jalandara, Nishant [corrected to Jalandhara, Nishant]]. American Heart Journal. 2008;155(5):791-805. Not CKD treatment. [pmid: 18440325].
339 Balderramo DC, Verdu MB, Ramacciotti CF, et al. Renoprotective effect of high periprocedural doses of oral N-acetylcysteine in patients scheduled to undergo a same-day angiography. Revista de la Facultad de Ciencias Medicas de Cordoba. 2004;61(2):13-9. Sample size less than 50 patients.
340 Baldwin L, Henderson A, Hickman P. Effect of postoperative low-dose dopamine on renal function after elective major vascular surgery. Annals of Internal Medicine. 1994;120(9):744-7. Not CKD treatment. [pmid: 8147547].
341 Banach M, Mikhailidis DP, Kjeldsen SE, et al. Time for new indications for statins?. Medical Science Monitor. 2009;15(12):MS1-5. Not RCT or controlled trial. [pmid: 19946240].
342 Banerjee D, Materson BJ. Blood pressure-independent impact of antihypertensive agents on cardiovascular and renal disease. Current Hypertension Reports. 2002;4(6):445-52. Not relevant to key questions. [pmid: 12419173].
343 Bangstad HJ, Osterby R, Dahl-Jorgensen K, et al. Improvement of blood glucose control in IDDM patients retards the progression of morphological changes in early diabetic nephropathy. Diabetologia. 1994;37(5):483-90. Sample size less than 50 patients. [pmid: 8056186].
344 Bangstad HJ, Osterby R, Dahl-Jorgensen K, et al. Early glomerulopathy is present in young, type 1 (insulin-dependent) diabetic patients with microalbuminuria. Diabetologia. 1993;36(6):523-9. Sample size less than 50 patients. [pmid: 8335174].
345 Banikazemi M, Bultas J, Waldek S, et al. Agalsidase-beta therapy for advanced Fabry disease: a randomized trial. Annals of Internal Medicine. 2007;146(2):77-86. Sample size less than 50 patients. [pmid: 17179052].
346 Bansal N, Tighiouart H, Weiner D, et al. Anemia as a risk factor for kidney function decline in individuals with heart failure. American Journal of Cardiology. 2007;99(8):1137-42. Not relevant to key questions. [pmid: 17437743].
347 Baranska-Kosakowska A, Zakliczynski M, Przybylski R, et al. Role of N-acetylcysteine on renal function in patients after orthotopic heart transplantation undergoing coronary angiography. Transplantation Proceedings. 2007;39(9):2853-5. Not CKD treatment. [pmid: 18022000].
348 Barba G, Vallance PJ, Strazzullo P, et al. Effects of sodium intake on the pressor and renal responses to nitric oxide synthesis inhibition in normotensive individuals with different sodium sensitivity. Journal of Hypertension. 2000;18(5):615-21. Sample size less than 50 patients. [pmid: 10826565].
349 Barber TJ, Hughes A, Dinsmore WW, et al. How does HIV impact on non-AIDS events in the era of HAART?. International Journal of STD & AIDS. 2009;20(1):1-3. Not CKD treatment. [pmid: 19103883].
350 Barichella M, Savardi C, Mauri A, et al. Diet with LPP for renal patients increases daily energy expenditure and improves motor function in parkinsonian patients with motor fluctuations. Nutritional Neuroscience. 2007;10(3-4):129-35. Not RCT or controlled trial. [pmid: 18019394].
351 Barit D, Cooper ME. Diabetic patients and kidney protection: an attainable target. Journal of Hypertension - Supplement. 2008;26(2):S3-7. Not relevant to key questions.
352 Barit D, Cooper ME. Diabetic patients and kidney protection: an attainable target. Journal of Hypertension. Suppl 2. 2008;26:S3-7. Follow-up less than 6 months. [pmid: 18979716].
353 Barletta G, Lazzeri C, Vecchiarino S, et al. Low-dose C-type natriuretic peptide does not affect cardiac and renal function in humans. Hypertension. 1998;31(3):802-8. Sample size less than 50 patients. [pmid: 9495264].
354 Barlovic DP, Zaletel J, Prezelj J. Adipocytokines are associated with renal function in patients with normal range glomerular filtration rate and type 2 diabetes. Cytokine. 2009;46(1):142-5. Not early CKD. [pmid: 19223200].
355 Barman Balfour JA, Scott LJ. Cinacalcet hydrochloride. Drugs. 2005;65(2):271-81. Not CKD treatment. [pmid: 15631545].
356 Barnett A. Preventing renal complications in type 2 diabetes: results of the diabetics exposed to telmisartan and enalapril trial. Journal of the American Society of Nephrology. 2006;17(4 Suppl 2):S132-5. Not RCT or controlled trial. [pmid: 16565237].
357 Barnett A. Prevention of loss of renal function over time in patients with diabetic nephropathy. American Journal of Medicine. 2006;119(5 Suppl 1):S40-7. Follow-up less than 6 months. [pmid: 16563947].
358 Barnett AH. The role of angiotensin II receptor antagonists in the management of diabetes. Blood Pressure Supplement. 2001;1:21-6. Not RCT or controlled trial. [pmid: 11333010].
359 Barnett AH. Preventing renal complications in diabetic patients: the Diabetics Exposed to Telmisartan And enalaprIL (DETAIL) study. Acta Diabetologica. Suppl 1. 2005;42:S42-9. Not CKD treatment. [pmid: 15868119].
360 Baron F, Frere P, Baudoux E, et al. Low incidence of acute graft-versus-host disease after non-myeloablative stem cell transplantation with CD8-depleted peripheral blood stem cells: an update. Haematologica. 2003;88(7):835-7. Not CKD treatment. [pmid: 12857568].
361 Barone R, Borson-Chazot F, Valkema R, et al. Patient-specific dosimetry in predicting renal toxicity with (90)Y-DOTATOC: relevance of kidney volume and dose rate in finding a dose-effect relationship. Journal of Nuclear Medicine. Suppl 1. 2005;46:99S-106S. Not relevant to key questions. [pmid: 15653658].
362 Barone R, Pauwels S, De Camps J, et al. Metabolic effects of amino acid solutions infused for renal protection during therapy with radiolabelled somatostatin analogues. Nephrology Dialysis Transplantation. 2004;19(9):2275-81. Sample size less than 50 patients.
363 Barr J, Zaloga GP, Haupt MT, et al. Cation metabolism during propofol sedation with and without EDTA in patients with impaired renal function. Intensive Care Medicine. Suppl 4. 2000;26:S433-42. Not CKD treatment. [pmid: 11310906].
364 Barrantes F, Feng Y, Ivanov O, et al. Acute kidney injury predicts outcomes of non-critically ill patients. Mayo Clinic Proceedings. 2009;84(5):410-6. Not CKD treatment. [pmid: 19411437].
365 Barras MA, Duffull SB, Atherton JJ, et al. Modelling the occurrence and severity of enoxaparin-induced bleeding and bruising events. British Journal of Clinical Pharmacology. Nov. 2009;68(5):700-11. Not CKD treatment. [pmid: 19916994].
366 Barratt TM, Chantler C, Lederman S, et al. Assessment of renal function. American Journal of Kidney Diseases. 1986;7(4):347-9. Not CKD treatment. [pmid: 3515915].
367 Barrett BJ. Contrast-induced nephropathy: we need all the data to discern the truth. American Journal of Kidney Diseases. 2009;54(4):587-9. Not RCT or controlled trial. [pmid: 19781450].
368 Barrett SV, Paul J, Hay A, et al. Does body mass index affect progression-free or overall survival in patients with ovarian cancer? Results from SCOTROC I trial. Annals of Oncology. 2008;19(5):898-902. Not CKD treatment. [pmid: 18272913].
369 Barri YM, Wilcox CS. Salt intake determines the renal response to L-arginine infusion in normal human subjects. Kidney International. 1998;53(5):1299-304. Not CKD treatment. [pmid: 9573545].
370 Barrios V, Escobar C. Diabetes and hypertension. What is new?. Minerva Cardioangiologica. Dec. 2009;57(6):705-22. Not CKD treatment. [pmid: 19942843].
371 Barros Silva GE, Costa RS, Ravinal RC, et al. Evaluation of erythrocyte dysmorphism by light microscopy with lowering of the condenser lens: A simple and efficient method. Nephrology. Mar. 2010;15(2):171-7. Not CKD treatment. [pmid: 20470275].
372 Barton M, Mullins JJ, Bailey MA, et al. Role of endothelin receptors for renal protection and survival in hypertension: waiting for clinical trials. Hypertension. 2006;48(5):834-7. Not RCT or controlled trial. [pmid: 17015776].
373 Basic-Jukic N, Kes P, Mokos I, et al. Do we need more intensive enzyme replacement therapy for Anderson-Fabry disease?. Medical Hypotheses. 2009;72(4):476-7. Not RCT or controlled trial. [pmid: 19124204].
374 Baskurt M, Okcun B, Abaci O, et al. N-acetylcysteine versus N-acetylcysteine + theophylline for the prevention of contrast nephropathy. European Journal of Clinical Investigation. 2009;39(9):793-9. Not CKD treatment. [pmid: 19500141].
375 Battershill AJ, Scott LJ. Telmisartan: a review of its use in the management of hypertension. Drugs. 2006;66(1):51-83. Not RCT or controlled trial. [pmid: 16398568].
376 Bauer JH, Gaddy P. Effects of enalapril alone, and in combination with hydrochlorothiazide, on renin-angiotensin-aldosterone, renal function, salt and water excretion, and body fluid composition. American Journal of Kidney Diseases. 1985;6(4):222-32. Sample size less than 50 patients. [pmid: 2996332].
377 Bauer JH, Reams G, Gaddy P. Renal function and hemodynamics during treatment with enalapril in primary hypertension. Nephron. Suppl 1. 1986;44:83-6. Sample size less than 50 patients. [pmid: 3018603].
378 Bauer JH, Reams GP. Hemodynamic and renal function in essential hypertension during treatment with enalapril. American Journal of Medicine. 1985;79(3C):10-3. Sample size less than 50 patients. [pmid: 2996341].
379 Bauer JH, Reams GP, Hewett J, et al. A randomized, double-blind, placebo-controlled trial to evaluate the effect of enalapril in patients with clinical diabetic nephropathy. American Journal of Kidney Diseases. 1992;20(5):443-57. Sample size less than 50 patients. [pmid: 1442757].
380 Bauer JH, Reams GP, Lau A. A comparison of betaxolol and nadolol on renal function in essential hypertension. American Journal of Kidney Diseases. 1987;10(2):109-12. Sample size less than 50 patients. [pmid: 3300292].
381 Bauer LA, Black DJ, Lill JS, et al. Levofloxacin and ciprofloxacin decrease procainamide and N-acetylprocainamide renal clearances. Antimicrobial Agents & Chemotherapy. 2005;49(4):1649-51. Not RCT or controlled trial. [pmid: 15793163].
382 Bayerle-Eder M, Fuchsjager-Mayrl G, Sieder A, et al. Effect of pravastatin on responsiveness to N-monomethyl-L-arginine in patients with hypercholesterolaemia. Atherosclerosis. 2002;160(1):177-84. Not early CKD. [pmid: 11755936].
383 Bayerle-Eder M, Langenberger H, Pleiner J, et al. Endothelin ETA receptor-subtype specific antagonism does not mitigate the acute systemic or renal effects of exogenous angiotensin II in humans. European Journal of Clinical Investigation. 2002;32(4):230-5. Not early CKD. [pmid: 11952807].
384 Bayliss J, Canepa-Anson R, Norell M, et al. The renal response to neuroendocrine inhibition in chronic heart failure: double-blind comparison of captopril and prazosin. European Heart Journal. 1986;7(10):877-84. Follow-up less than 6 months. [pmid: 3539615].
385 Beatty OL, Ritchie CM, Hadden DR, et al. Is a random urinary albumin concentration a useful screening test in insulin-treated diabetic patients?. Irish Journal of Medical Science. 1994;163(9):406-9. Not RCT or controlled trial. [pmid: 7982765].
386 Bech JN, Nielsen CB, Ivarsen P, et al. Dietary sodium affects systemic and renal hemodynamic response to NO inhibition in healthy humans. American Journal of Physiology. 1998;274(5 Pt 2):F914-23. Not CKD treatment. [pmid: 9612329].
387 Bech JN, Nielsen CB, Pedersen EB. Effects of systemic NO synthesis inhibition on RPF, GFR, UNa, and vasoactive hormones in healthy humans. American Journal of Physiology. 1996;270(5 Pt 2):F845-51. Not CKD treatment. [pmid: 8928847].
388 Bech JN, Nielsen EH, Pedersen RS, et al. Enhanced sodium retention after acute nitric oxide blockade in mildly sodium loaded patients with essential hypertension. American Journal of Hypertension. 2007;20(3):287-95. Sample size less than 50 patients. [pmid: 17324742].
389 Beck GJ, Berg RL, Coggins CH, et al. Design and statistical issues of the Modification of Diet in Renal Disease Trial. The Modification of Diet in Renal Disease Study Group. Controlled Clinical Trials. 1991;12(5):566-86. Not CKD treatment. [pmid: 1664792].
390 Beckebaum S, Cicinnati V, Brokalaki E, et al. CNI-sparing regimens within the liver transplant setting: experiences of a single center. Clinical Transplants. 2004:215-20. Not relevant to key questions.
391 Beckebaum S, Cicinnati VR, Klein CG, et al. Impact of combined mycophenolate mofetil and low-dose calcineurin inhibitor therapy on renal function, cardiovascular risk factors, and graft function in liver transplant patients: preliminary results of an open prospective study. Transplantation Proceedings. 2004;36(9):2671-4. Sample size less than 50 patients. [pmid: 15621120].
392 Beckebaum S, Klein CG, Sotiropoulos GC, et al. Combined mycophenolate mofetil and minimal dose calcineurin inhibitor therapy in liver transplant patients: clinical results of a prospective randomized study. Transplantation Proceedings. 2009;41(6):2567-9. Not CKD treatment. [pmid: 19715976].
393 Beck-Nielsen H, Olesen T, Mogensen CE, et al. Effect of near normoglycemia for 5 years on progression of early diabetic retinopathy and renal involvement. Diabetes Research. 1990;15(4):185-90. Sample size less than 50 patients. [pmid: 2132407].
394 Beck-Nielsen H, Richelsen B, Mogensen CE, et al. Effect of insulin pump treatment for one year on renal function and retinal morphology in patients with IDDM. Diabetes Care. 1985;8(6):585-9. Sample size less than 50 patients. [pmid: 4075944].
395 Beeks E, van der Klauw MM, Kroon AA, et al. Alpha-adducin Gly460Trp polymorphism and renal hemodynamics in essential hypertension. Hypertension. 2004;44(4):419-23. Not CKD treatment. [pmid: 15326084].
396 Beermann B, Eriksson LO, Kallner M. A double blind comparison of naproxen and sulindac in female patients with heart failure. Scandinavian Journal of Rheumatology - Supplement. 1986;62:32-5. Sample size less than 50 patients. [pmid: 3541166].
397 Beevers DG, Lip GY. The protective effect of blocking angiotensin in both type I and type II diabetics with nephropathy. Journal of Human Hypertension. 2001;15(12):837-9. Not RCT or controlled trial. [pmid: 11773985].
398 Behets GJ, Verberckmoes SC, D'Haese PC, et al. Lanthanum carbonate: a new phosphate binder. Current Opinion in Nephrology & Hypertension. 2004;13(4):403-9. Not relevant to key questions. [pmid: 15199290].
399 Bektas F, Eken C, Karadeniz O, et al. Intravenous paracetamol or morphine for the treatment of renal colic: a randomized, placebo-controlled trial. Annals of Emergency Medicine. 2009;54(4):568-74. Not CKD treatment. [pmid: 19647342].
400 Bell N, Hawkins V, Holliman D, et al. Trandolapril and human diabetic neuropathy. Lancet. 1999;353(9156):927. Not RCT or controlled trial. [pmid: 10094010].
401 Bellinghieri G, Mazzaglia G, Savica V, et al. Effects of manidipine and nifedipine on blood pressure and renal function in patients with chronic renal failure: a multicenter randomized controlled trial. Renal Failure. 2003;25(5):681-9. Not CKD treatment. [pmid: 14575277].
402 Bellizzi V, Di Iorio BR, De Nicola L, et al. Very low protein diet supplemented with ketoanalogs improves blood pressure control in chronic kidney disease. Kidney International. 2007;71(3):245-51. Not RCT or controlled trial. [pmid: 17035939].
403 Bellizzi V, Scalfi L, Terracciano V, et al. Early changes in bioelectrical estimates of body composition in chronic kidney disease. Journal of the American Society of Nephrology. 2006;17(5):1481-7. Follow-up less than 6 months. [pmid: 16611719].
404 Bello E, Caramelo C, Martell N, et al. Impairment of renal vasodilation with l-arginine is related to more severe disease in untreated hypertensive patients. Hypertension. 2001;38(4):907-12. Not CKD treatment. [pmid: 11641307].
405 Bellomo R, Auriemma S, Fabbri A, et al. The pathophysiology of cardiac surgery-associated acute kidney injury (CSA-AKI). International Journal of Artificial Organs. 2008;31(2):166-78. Not CKD treatment. [pmid: 18311733].
406 Bellomo R, Chapman M, Finfer S, et al. Low-dose dopamine in patients with early renal dysfunction: a placebo-controlled randomised trial. Australian and New Zealand Intensive Care Society (ANZICS) Clinical Trials Group. Lancet. 2000;356(9248):2139-43. Follow-up less than 6 months. [pmid: 11191541].
407 Bellomo R, Ronco C, Kellum JA, et al. Acute renal failure - definition, outcome measures, animal models, fluid therapy and information technology needs: the Second International Consensus Conference of the Acute Dialysis Quality Initiative (ADQI) Group. Critical Care. 2004;8(4):R204-12. Not CKD treatment. [pmid: 15312219].
408 Belonje AMS, de Boer RA, Voors AA. Recombinant human Epo treatment: beneficial in chronic kidney disease, chronic heart failure, or both? Editorial to: “Correction of anemia with erythropoietin in chronic kidney disease (stage 3 or 4): effects on cardiac performance by Pappas et al.”. Cardiovascular Drugs & Therapy. 2008;22(1):1-2. Not CKD treatment. [pmid: 18219567].
409 Benavente D, Chue CD, Ferro CJ. The importance of renin-angiotensin blockade in patients with cardio-renal disease. Journal of Renal Care. May. Suppl 1. 2010;36:97-105. Not CKD treatment. [pmid: 20586905].
410 Benck U, Clorius JH, Zuna I, et al. Renal hemodynamic changes during smoking: effects of adrenoreceptor blockade. European Journal of Clinical Investigation. 1999;29(12):1010-8. Not CKD treatment. [pmid: 10583448].
411 Benck U, Haeckel S, Clorius JH, et al. Proteinuria-lowering effect of heparin therapy in diabetic nephropathy without affecting the renin-angiotensin-aldosterone system. Clinical Journal of The American Society of Nephrology: CJASN. 2007;2(1):58-67. Sample size less than 50 patients. [pmid: 17699388].
412 Bender A, Samtleben W, Elstner M, et al. Long-term creatine supplementation is safe in aged patients with Parkinson disease. Nutrition Research. 2008;28(3):172-8. Not CKD treatment. [pmid: 19083405].
413 Bender R. The effect of cholesterol-lowering therapy on the progression of diabetic nephropathy is unproved. [Erratum appears in Diabetologia 1996 Aug;39(8):1004]. Diabetologia. 1996;39(3):368-70. Not RCT or controlled trial. [pmid: 8721787].
414 Bending JJ, Dodds RA, Keen H, et al. Renal response to restricted protein intake in diabetic nephropathy. Diabetes. 1988;37(12):1641-6. Follow-up less than 6 months. [pmid: 3192038].
415 Bending JJ, Viberti GC, Watkins PJ, et al. Intermittent clinical proteinuria and renal function in diabetes: evolution and the effect of glycaemic control. British Medical Journal Clinical Research Ed. 1986;292(6513):83-6. Sample size less than 50 patients. [pmid: 3080101].
416 Benincosa LJ, Sagawa K, Massey LK, et al. Effects of acute caffeine ingestion and menopause on sulfate homeostasis in women. Life Sciences. 1995;57(16):1497-505. Sample size less than 50 patients. [pmid: 7564894].
417 Benndorf RA, Appel D, Maas R, et al. Telmisartan improves endothelial function in patients with essential hypertension. Journal of Cardiovascular Pharmacology. 2007;50(4):367-71. Not RCT or controlled trial. [pmid: 18049303].
418 Bennett WM. Side effects of erythropoietin therapy. American Journal of Kidney Diseases. 1991;18(4 Suppl 1):84-6. Not relevant to key questions. [pmid: 1928085].
419 Bennett WM. A multicenter clinical trial of epoetin beta for anemia of end-stage renal disease. Journal of the American Society of Nephrology. 1991;1(7):990-8. Not early CKD. [pmid: 1883969].
420 Benoehr P, Krueth P, Bokemeyer C, et al. Nephroprotection by theophylline in patients with cisplatin chemotherapy: a randomized, single-blinded, placebo-controlled trial. Journal of the American Society of Nephrology. 2005;16(2):452-8. Not RCT or controlled trial. [pmid: 15590762].
421 Benohr P, Grenz A, Hartmann JT, et al. Cystatin C--a marker for assessment of the glomerular filtration rate in patients with cisplatin chemotherapy. Kidney & Blood Pressure Research. 2006;29(1):32-5. Not relevant to key questions. [pmid: 16582575].
422 Benzoni D, Geoffroy J, Waeber B, et al. Atrial natriuretic peptide and urinary prostaglandins in man. British Journal of Clinical Pharmacology. 1989;28(4):397-402. Sample size less than 50 patients. [pmid: 2531604].
423 Berenson JR. Recommendations for zoledronic acid treatment of patients with bone metastases. Oncologist. 2005;10(1):52-62. Not RCT or controlled trial. [pmid: 15632252].
424 Berg KJ, Forre O, Djoseland O, et al. Renal side effects of high and low cyclosporin A doses in patients with rheumatoid arthritis. Clinical Nephrology. 1989;31(5):232-8. Not CKD treatment. [pmid: 2661065].
425 Berg KJ, Talseth T. Acute renal effects of sulindac and indomethacin in chronic renal failure. Clinical Pharmacology & Therapeutics. 1985;37(4):447-52. Sample size less than 50 patients. [pmid: 3884224].
426 Berger ED, Setzler BA, Werz U, et al. Blood pressure reduction is necessary for the reduction of proteinuria in diabetic nephropathy--comparison of different antihypertensive agents. Nephrology Dialysis Transplantation. Suppl 4. 1999;14:28-9. Sample size less than 50 patients.
427 Berger PB, Best PJM, Topol EJ, et al. The relation of renal function to ischemic and bleeding outcomes with 2 different glycoprotein IIb/IIIa inhibitors: the do Tirofiban and ReoPro Give Similar Efficacy Outcome (TARGET) trial. American Heart Journal. 2005;149(5):869-75. Not relevant to key questions. [pmid: 15894970].
428 Berghmans T, Klastersky J, Markiewicz E, et al. Cisplatin-carboplatin-gemcitabine or ifosfamide-gemcitabine in advanced non-small cell lung carcinoma: two pilot studies. Anticancer Research. 1999;19(6C):5651-5. Not early CKD. [pmid: 10697635].
429 Bergman A, Odar-Cederlof I, Westman L, et al. Effects of human atrial natriuretic peptide in patients after coronary artery bypass surgery. Journal of Cardiothoracic & Vascular Anesthesia. 1996;10(4):490-6. Sample size less than 50 patients. [pmid: 8776643].
430 Bergman ASF, Odar-Cederlof I, Westman L, et al. Diltiazem infusion for renal protection in cardiac surgical patients with preexisting renal dysfunction. Journal of Cardiothoracic & Vascular Anesthesia. 2002;16(3):294-9. Follow-up less than 6 months. [pmid: 12073199].
431 Bergner R, Diel IJ, Henrich D, et al. Differences in nephrotoxicity of intravenous bisphosphonates for the treatment of malignancy-related bone disease. Onkologie. 2006;29(11):534-40. Not relevant to key questions. [pmid: 17068390].
432 Bergstrom J, Alvestrand A, Bucht H, et al. Progression of chronic renal failure in man is retarded with more frequent clinical follow-ups and better blood pressure control. Clinical Nephrology. 1986;25(1):1-6. Sample size less than 50 patients. [pmid: 3955903].
433 Bergstrom J, Alvestrand A, Bucht H, et al. What is the role of controls in an outpatient department on progression of renal disease?. Blood Purification. 1988;6(6):336-42. Not relevant to key questions. [pmid: 3061400].
434 Bergstrom J, Alvestrand A, Bucht H, et al. Stockholm clinical study on progression of chronic renal failure--an interim report. Kidney International - Supplement. 1989;27:S110-4. Sample size less than 50 patients. [pmid: 2636644].
435 Bergstrom J, Alvestrand A, Bucht H, et al. Is chronic renal disease always progressive?. Contributions to Nephrology. 1989;75:60-7. Sample size less than 50 patients. [pmid: 2697508].
436 Bergus GR. Pain relief for renal colic. Journal of Family Practice. 1996;43(5):438-40. Not CKD treatment. [pmid: 8917139].
437 Beri A, Sural N, Mahajan SB. Non-atheroprotective effects of statins: a systematic review. American Journal of Cardiovascular Drugs. 2009;9(6):361-70. Not RCT or controlled trial. [pmid: 19929034].
438 Beringer PM, Hidayat L, Heed A, et al. GFR estimates using cystatin C are superior to serum creatinine in adult patients with cystic fibrosis. Journal of Cystic Fibrosis. 2009;8(1):19-25. Sample size less than 50 patients. [pmid: 18799365].
439 Beringer PM, Kriengkauykiat J, Zhang X, et al. Lack of effect of P-glycoprotein inhibition on renal clearance of dicloxacillin in patients with cystic fibrosis. Pharmacotherapy. 2008;28(7):883-94. Not human studies. [pmid: 18576903].
440 Berl T, Hunsicker LG, Lewis JB, et al. Impact of achieved blood pressure on cardiovascular outcomes in the Irbesartan Diabetic Nephropathy Trial. Journal of the American Society of Nephrology. 2005;16(7):2170-9. Follow-up less than 6 months. [pmid: 15930097].
441 Bernard S, Fouque D, Laville M, et al. Effects of low-protein diet supplemented with ketoacids on plasma lipids in adult chronic renal failure. Mineral & Electrolyte Metabolism. 1996;22(1-3):143-6. Sample size less than 50 patients. [pmid: 8676807].
442 Bernardi M, De Palma R, Trevisani F, et al. Effects of a new loop diuretic (muzolimine) in cirrhosis with ascites: comparison with furosemide. Hepatology. 1986;6(3):400-5. Sample size less than 50 patients. [pmid: 3519416].
443 Bernardi M, De Palma R, Trevisani F, et al. Comparative pharmacodynamics of furosemide and muzolimine in cirrhosis. Study on renal sodium and potassium handling and renin-aldosterone axis. Zeitschrift fur Kardiologie. Suppl 2. 1985;74:129-34. Sample size less than 50 patients. [pmid: 3890391].
444 Bernardi M, D'Intino PE, Trevisani F, et al. Effects of prolonged ingestion of graded doses of licorice by healthy volunteers. Life Sciences. 1994;55(11):863-72. Not CKD treatment. [pmid: 8072387].
445 Bernasconi AR, Liste A, Del Pino N, et al. Folic acid 5 or 15 mg/d similarly reduces plasma homocysteine in patients with moderate-advanced chronic renal failure. Nephrology. 2006;11(2):137-41. Not RCT or controlled trial. [pmid: 16669976].
446 Bernhard J, Beaufrere B, Laville M, et al. Adaptive response to a low-protein diet in predialysis chronic renal failure patients. Journal of the American Society of Nephrology. 2001;12(6):1249-54. Sample size less than 50 patients. [pmid: 11373349].
447 Bersten AD, Holt AW. Vasoactive drugs and the importance of renal perfusion pressure. New Horizons. 1995;3(4):650-61. Not RCT or controlled trial. [pmid: 8574595].
448 Berthold H, del Pozo E. Antidiuretic effect of Sandostatin (SMS 201-995) in healthy volunteers. Acta Endocrinologica. 1989;120(6):708-14. Sample size less than 50 patients. [pmid: 2658454].
449 Bertolissi M, Antonucci F, De Monte A, et al. Effects on renal function of a continuous infusion of nifedipine during cardiopulmonary bypass. Journal of Cardiothoracic & Vascular Anesthesia. 1996;10(2):238-42. Sample size less than 50 patients. [pmid: 8850405].
450 Bertolotto M, Quaia E, Gasparini C, et al. Resistive index in patients with renal colic: differences after medical treatment with indomethacin and ketorolac. Radiologia Medica. 2003;106(4):370-5. Not relevant to key questions. [pmid: 14612828].
451 Bertoluci MC, Uebel D, Schmidt A, et al. Urinary TGF-beta1 reduction related to a decrease of systolic blood pressure in patients with type 2 diabetes and clinical diabetic nephropathy. Diabetes Research & Clinical Practice. 2006;72(3):258-64. Follow-up less than 6 months. [pmid: 16414143].
452 Bertram D, Summers R. Serum creatinine levels during cardiac surgery: absence of effect by aminoglycosides. Journal of Clinical Pharmacy & Therapeutics. 1993;18(3):165-70. Not RCT or controlled trial. [pmid: 8345000].
453 Besarab A, Frinak S, Yee J. What is so bad about a hemoglobin level of 12 to 13 g/dL for chronic kidney disease patients anyway?. Advances in Chronic Kidney Disease. 2009;16(2):131-42. Not CKD treatment. [pmid: 19233072].
454 Besarab A, Horl WH, Silverberg D. Iron metabolism, iron deficiency, thrombocytosis, and the cardiorenal anemia syndrome. Oncologist. Suppl 1. 2009;14:22-33. Not CKD treatment. [pmid: 19762514].
455 Best PJM, Berger PB, Davis BR, et al. Impact of mild or moderate chronic kidney disease on the frequency of restenosis: results from the PRESTO trial. Journal of the American College of Cardiology. 2004;44(9):1786-91. Sample size less than 50 patients. [pmid: 15519008].
456 Best PJM, Steinhubl SR, Berger PB, et al. The efficacy and safety of short- and long-term dual antiplatelet therapy in patients with mild or moderate chronic kidney disease: results from the Clopidogrel for the Reduction of Events During Observation (CREDO) trial. American Heart Journal. 2008;155(4):687-93. Not CKD treatment. [pmid: 18371477].
457 Best R, Walker BR. Additional value of measurement of urinary cortisone and unconjugated cortisol metabolites in assessing the activity of 11 beta-hydroxysteroid dehydrogenase in vivo. Clinical Endocrinology. 1997;47(2):231-6. Sample size less than 50 patients. [pmid: 9302399].
458 Bestle MH, Olsen NV, Christensen P, et al. Cardiovascular, endocrine, and renal effects of urodilatin in normal humans. American Journal of Physiology. 1999;276(3 Pt 2):R684-95. Sample size less than 50 patients. [pmid: 10070128].
459 Beyer I, Compte N, Busuioc A, et al. Anemia and transfusions in geriatric patients: a time for evaluation. Hematology. Apr. 2010;15(2):116-21. Not CKD treatment. [pmid: 20423572].
460 Beyer KH Jr., Gelarden RT, Vary JE, et al. Novel multivalent effects of pyrazinoylguanidine in patients with azotemia. Clinical Pharmacology & Therapeutics. 1990;47(5):629-38. Not CKD treatment. [pmid: 2188773].
461 Bhatnagar V, Garcia EP, O'Connor DT, et al. CYP3A4 and CYP3A5 polymorphisms and blood pressure response to amlodipine among African-American men and women with early hypertensive renal disease. American Journal of Nephrology. 2010;31(2):95-103. Not relevant to key questions. [pmid: 19907160].
462 Bhatnagar V, O'Connor DT, Brophy VH, et al. G-protein-coupled receptor kinase 4 polymorphisms and blood pressure response to metoprolol among African Americans: sex-specificity and interactions. American Journal of Hypertension. 2009;22(3):332-8. Not CKD treatment. [pmid: 19119263].
463 Bhatnagar V, O'Connor DT, Schork NJ, et al. Angiotensin-converting enzyme gene polymorphism predicts the time-course of blood pressure response to angiotensin converting enzyme inhibition in the AASK trial. Journal of Hypertension. 2007;25(10):2082-92. Not early CKD. [pmid: 17885551].
464 Bhatnagar V, O'Connor DT, Schork NJ, et al. Angiotensin-converting enzyme gene polymorphism predicts the time-course of blood pressure response to angiotensin converting enzyme inhibition in the AASK trial. Journal of Hypertension. 2007;25(10):2082-92. Follow-up less than 6 months. [pmid: 17885551].
465 Bhattacharya N. Placental umbilical cord blood transfusion: a new method of treatment of patients with diabetes and microalbuminuria in the background of anemia. Clinical & Experimental Obstetrics & Gynecology. 2006;33(3):164-8. Not RCT or controlled trial.
466 Bianchi S, Bigazzi R, Baldari G, et al. Long-term effects of enalapril and nicardipine on urinary albumin excretion in patients with chronic renal insufficiency: a 1-year follow-up. American Journal of Nephrology. 1991;11(2):131-7. Sample size less than 50 patients. [pmid: 1951474].
467 Bianchi S, Bigazzi R, Baldari G, et al. Microalbuminuria in patients with essential hypertension. Effects of an angiotensin converting enzyme inhibitor and of a calcium channel blocker. American Journal of Hypertension. 1991;4(4 Pt 1):291-6. Sample size less than 50 patients. [pmid: 2059393].
468 Bianchi S, Bigazzi R, Baldari G, et al. Microalbuminuria in patients with essential hypertension: effects of several antihypertensive drugs. American Journal of Medicine. 1992;93(5):525-8. Follow-up less than 6 months. [pmid: 1442855].
469 Bianchi S, Bigazzi R, Caiazza A, et al. A controlled, prospective study of the effects of atorvastatin on proteinuria and progression of kidney disease. [Erratum appears in Am J Kidney Dis. 2004 Jan;43(1):193]. American Journal of Kidney Diseases. 2003;41(3):565-70. Not relevant to key questions. [pmid: 12612979].
470 Bianchi S, Bigazzi R, Campese VM. Antagonists of aldosterone and proteinuria in patients with CKD: an uncontrolled pilot study. American Journal of Kidney Diseases. 2005;46(1):45-51. Follow-up less than 6 months. [pmid: 15983956].
471 Bianchi S, Bigazzi R, Campese VM. Long-term effects of spironolactone on proteinuria and kidney function in patients with chronic kidney disease. Kidney International. 2006;70(12):2116-23. Not relevant to key questions. [pmid: 17035949].
472 Biancofiore G, Della Rocca G, Bindi L, et al. Use of fenoldopam to control renal dysfunction early after liver transplantation. Liver Transplantation. 2004;10(8):986-92. Sample size less than 50 patients. [pmid: 15390323].
473 Bibbins-Domingo K, Lin F, Vittinghoff E, et al. Renal insufficiency as an independent predictor of mortality among women with heart failure. Journal of the American College of Cardiology. 2004;44(8):1593-600. Not RCT or controlled trial. [pmid: 15489091].
474 Bichet DG, Kortas C, Mettauer B, et al. Modulation of plasma and platelet vasopressin by cardiac function in patients with heart failure. Kidney International. 1986;29(6):1188-96. Sample size less than 50 patients. [pmid: 3528612].
475 Bichu P, Nistala R, Khan A, et al. Angiotensin receptor blockers for the reduction of proteinuria in diabetic patients with overt nephropathy: results from the AMADEO study. Vascular Health & Risk Management. 2009;5(1):129-40. Not CKD treatment. [pmid: 19436679].
476 Bidiville J, Waeber G, Porchet M, et al. Hemodynamic, renal, and endocrine effects of 4-h infusions of human atrial natriuretic peptide in normal volunteers. Fundamental & Clinical Pharmacology. 1988;2(5):413-29. Sample size less than 50 patients. [pmid: 2976727].
477 Bierkens AF, Maes RM, Hendrikx JM, et al. The use of local anesthesia in second generation extracorporeal shock wave lithotripsy: eutectic mixture of local anesthetics. Journal of Urology. 1991;146(2):287-9. Not CKD treatment. [pmid: 1856917].
478 Bigazzi R, Bianchi S, Baldari D, et al. Long-term effects of a converting enzyme inhibitor and a calcium channel blocker on urinary albumin excretion in patients with essential hypertension. American Journal of Hypertension. 1993;6(2):108-13. Sample size less than 50 patients. [pmid: 8471229].
479 Biggi A, Musiari L, Iori M, et al. Contribution of bradykinin B2 receptors to the inhibition by valsartan of systemic and renal effects of exogenous angiotensin II in salt-repleted humans. Journal of Pharmacology & Experimental Therapeutics. Sep. 1. 2010;334(3):911-6. Not CKD treatment. [pmid: 20504911].
480 Billstrom A, Hietala SO, Lithner F, et al. Nephrotoxicity of contrast media in patients with diabetes mellitus. A comparative urographic and angiographic study with iohexol and metrizoate. Acta Radiologica. 1989;30(5):509-15. Not CKD treatment. [pmid: 2692666].
481 Bilo H, Kluitman E, van Ballegooie E, et al. Long term use of captopril or nifedipine in normotensive microalbuminuric patients with insulin-dependent diabetes mellitus. Diabetes Research. 1993;23(3):115-22. Sample size less than 50 patients. [pmid: 7712685].
482 Bilous R. Microvascular disease: what does the UKPDS tell us about diabetic nephropathy?. Diabetic Medicine. Suppl 2. 2008;25:25-9. Not CKD treatment. [pmid: 18717975].
483 Bilous R, Chaturvedi N, Sjolie AK, et al. Effect of candesartan on microalbuminuria and albumin excretion rate in diabetes: three randomized trials. Annals of Internal Medicine. 2009;151(1):11-20. Not RCT or controlled trial. [pmid: 19451554].
484 Binet I, Wallnofer A, Weber C, et al. Renal hemodynamics and pharmacokinetics of bosentan with and without cyclosporine A. Kidney International. 2000;57(1):224-31. Not CKD treatment. [pmid: 10620203].
485 Biollaz J, Bidiville J, Diezi J, et al. Site of the action of a synthetic atrial natriuretic peptide evaluated in humans. Kidney International. 1987;32(4):537-46. Sample size less than 50 patients. [pmid: 2963166].
486 Biollaz J, Nussberger J, Porchet M, et al. Four-hour infusions of synthetic atrial natriuretic peptide in normal volunteers. Hypertension. 1986;8(6 Pt 2):II96-105. Sample size less than 50 patients. [pmid: 2941372].
487 Biondi-Zoccai GGL, Lotrionte M, Abbate A, et al. Compliance with QUOROM and quality of reporting of overlapping meta-analyses on the role of acetylcysteine in the prevention of contrast associated nephropathy: case study. BMJ. 2006;332(7535):202-9. Sample size less than 50 patients. [pmid: 16415336].
488 Bito H, Ikeda K. Renal and hepatic function in surgical patients after low-flow sevoflurane or isoflurane anesthesia. Anesthesia & Analgesia. 1996;82(1):173-6. Not CKD treatment. [pmid: 8712397].
489 Bito H, Ikeuchi Y, Ikeda K. Effects of low-flow sevoflurane anesthesia on renal function: comparison with high-flow sevoflurane anesthesia and low-flow isoflurane anesthesia. Anesthesiology. 1997;86(6):1231-7. Not CKD treatment. [pmid: 9197291].
490 Bjorck S, Aurell M. Angiotensin-converting enzyme inhibitors in diabetes: effect on the kidney and on blood pressure. Journal of the American Society of Nephrology. 1990;1(5 Suppl 2):S59-63. Not CKD treatment. [pmid: 16989067].
491 Bjorck S, Mulec H, Johnsen SA, et al. Renal protective effect of enalapril in diabetic nephropathy. BMJ. 1992;304(6823):339-43. Sample size less than 50 patients. [pmid: 1540729].
492 Bjorck S, Mulec H, Johnsen SA, et al. Contrasting effects of enalapril and metoprolol on proteinuria in diabetic nephropathy. [Erratum appears in BMJ 1990 May 5;300(6733):1170]. BMJ. 1990;300(6729):904-7. Follow-up less than 6 months. [pmid: 2337713].
493 Black C, Sharma P, Scotland G, et al. Early referral strategies for management of people with markers of renal disease: a systematic review of the evidence of clinical effectiveness, cost-effectiveness and economic analysis. Health Technology Assessment. Apr. 2010;14(21):1-184. Not relevant to key questions. [pmid: 20441712].
494 Blake GM, Moore AEB, Park-Holohan SJ, et al. A direct in vivo measurement of 99mTc-methylene diphosphonate protein binding. Nuclear Medicine Communications. 2003;24(7):829-35. Not CKD treatment. [pmid: 12813203].
495 Blanchard J, Sawers SJ, Jonkman JH, et al. Comparison of the urinary metabolite profile of caffeine in young and elderly males. British Journal of Clinical Pharmacology. 1985;19(2):225-32. Sample size less than 50 patients. [pmid: 3986081].
496 Blaser J, Simmen HP, Thurnheer U, et al. Nephrotoxicity, high frequency ototoxicity, efficacy and serum kinetics of once versus thrice daily dosing of netilmicin in patients with serious infections. Journal of Antimicrobial Chemotherapy. 1995;36(5):803-14. Not CKD treatment. [pmid: 8626261].
497 Blau A, Herzog D, Shechter P, et al. Calcium channel blocker nisoldipine in chronic renal failure. Renal Failure. 1990;12(2):113-9. Not early CKD. [pmid: 2236726].
498 Ble A, Fink JC, Woodman RC, et al. Renal function, erythropoietin, and anemia of older persons: the InCHIANTI study. Archives of Internal Medicine. 2005;165(19):2222-7. Not relevant to key questions. [pmid: 16246987].
499 Bleie O, Semb AG, Grundt H, et al. Homocysteine-lowering therapy does not affect inflammatory markers of atherosclerosis in patients with stable coronary artery disease. Journal of Internal Medicine. 2007;262(2):244-53. Not CKD treatment. [pmid: 17645592].
500 Bliss DZ, Stein TP, Schleifer CR, et al. Supplementation with gum arabic fiber increases fecal nitrogen excretion and lowers serum urea nitrogen concentration in chronic renal failure patients consuming a low-protein diet. American Journal of Clinical Nutrition. 1996;63(3):392-8. Sample size less than 50 patients. [pmid: 8602598].
501 Block GA, Persky MS, Ketteler M, et al. A randomized double-blind pilot study of serum phosphorus normalization in chronic kidney disease: a new paradigm for clinical outcomes studies in nephrology. Hemodialysis International. 2009;13(3):360-2. Not RCT or controlled trial. [pmid: 19601992].
502 Boccalandro F, Amhad M, Smalling RW, et al. Oral acetylcysteine does not protect renal function from moderate to high doses of intravenous radiographic contrast. Catheterization & Cardiovascular Interventions. 2003;58(3):336-41. Not CKD treatment. [pmid: 12594698].
503 Bochud M, Staessen JA, Maillard M, et al. Ethnic differences in proximal and distal tubular sodium reabsorption are heritable in black and white populations. Journal of Hypertension. 2009;27(3):606-12. Not early CKD. [pmid: 19262228].
504 Bocksch W, Fateh-Moghadam S, Mueller E, et al. Percutaneous coronary intervention in patients with end-stage renal disease. Kidney & Blood Pressure Research. 2005;28(5-6):275-9. Not relevant to key questions. [pmid: 16534221].
505 Boddy AV, Griffin MJ, Sludden J, et al. Pharmacological study of paclitaxel duration of infusion combined with GFR-based carboplatin in the treatment of ovarian cancer. Cancer Chemotherapy & Pharmacology. 2001;48(1):15-21. Not early CKD. [pmid: 11488519].
506 Bodei L, Cremonesi M, Zoboli S, et al. Receptor-mediated radionuclide therapy with 90Y-DOTATOC in association with amino acid infusion: a phase I study. European Journal of Nuclear Medicine & Molecular Imaging. 2003;30(2):207-16. Not CKD treatment. [pmid: 12552338].
507 Bodmer CW, Lake D, Savage MW, et al. Hand vein responses to noradrenaline in normotensive patients with insulin-dependent diabetes mellitus and microalbuminuria: effects of alpha-adrenoceptor blockade with doxazosin. Current Medical Research & Opinion. 1999;15(3):169-76. Sample size less than 50 patients. [pmid: 10621923].
508 Bodnar L, Wcislo G, Gasowska-Bodnar A, et al. Renal protection with magnesium subcarbonate and magnesium sulphate in patients with epithelial ovarian cancer after cisplatin and paclitaxel chemotherapy: a randomised phase II study. European Journal of Cancer. 2008;44(17):2608-14. Not CKD treatment. [pmid: 18796350].
509 Body JJ, Diel I, Bell R. Profiling the safety and tolerability of bisphosphonates. Seminars in Oncology. 2004;31(5 Suppl 10):73-8. Follow-up less than 6 months. [pmid: 15490380].
510 Boelaert J, Lijnen P, Robbens E, et al. Impairment of renal function due to sulphinpyrazone after coronary artery bypass surgery: a prospective double-blind study. Journal of Cardiovascular Pharmacology. 1986;8(2):386-91. Not CKD treatment. [pmid: 2422479].
511 Boero R, Prodi E, Elia F, et al. How well are hypertension and albuminuria treated in type II diabetic patients?. Journal of Human Hypertension. 2003;17(6):413-8. Not relevant to key questions. [pmid: 12764404].
512 Boero R, Rollino C, Massara C, et al. The verapamil versus amlodipine in nondiabetic nephropathies treated with trandolapril (VVANNTT) study. American Journal of Kidney Diseases. 2003;42(1):67-75. Not relevant to key questions. [pmid: 12830458].
513 Boero R, Rollino C, Massara C, et al. Verapamil versus amlodipine in proteinuric non-diabetic nephropathies treated with trandolapril (VVANNTT study): design of a prospective randomized multicenter trial. Journal of Nephrology. 2001;14(1):15-8. Not CKD treatment. [pmid: 11281338].
514 Boerrigter G, Costello-Boerrigter LC, Abraham WT, et al. Cardiac resynchronization therapy improves renal function in human heart failure with reduced glomerular filtration rate. Journal of Cardiac Failure. 2008;14(7):539-46. Not CKD treatment. [pmid: 18722318].
515 Boers M, Bensen WG, Ludwin D, et al. Cyclosporine nephrotoxicity in rheumatoid arthritis: no effect of short term misoprostol treatment. Journal of Rheumatology. 1992;19(4):534-7. Not CKD treatment. [pmid: 1593573].
516 Boers M, Dijkmans BA, Breedveld FC, et al. No effect of misoprostol on renal function of rheumatoid patients treated with diclofenac. British Journal of Rheumatology. 1991;30(1):56-9. Sample size less than 50 patients. [pmid: 1899350].
517 Boers M, Dijkmans BA, van Rijthoven AW, et al. Reversible nephrotoxicity of cyclosporine in rheumatoid arthritis. Journal of Rheumatology. 1990;17(1):38-42. Not CKD treatment. [pmid: 2179550].
518 Boesgaard S, Aldershvile J, Poulsen HE, et al. N-acetylcysteine inhibits angiotensin converting enzyme in vivo. Journal of Pharmacology & Experimental Therapeutics. 1993;265(3):1239-44. Not human studies. [pmid: 8389858].
519 Boesken WH, Kult J. High-dose torasemide, given once daily intravenously for one week, in patients with advanced chronic renal failure. Clinical Nephrology. 1997;48(1):22-8. Sample size less than 50 patients. [pmid: 9247774].
520 Boey O, Van Hooland S, Woestenburg A, et al. Methotrexate should not be used for patients with end-stage kidney disease. Acta Clinica Belgica. 2006;61(4):166-9. Not CKD treatment. [pmid: 17091912].
521 Boger RH, Schwedhelm E, Maas R, et al. ADMA and oxidative stress may relate to the progression of renal disease: rationale and design of the VIVALDI study. Vascular Medicine. Suppl 1. 2005;10:S97-102. Not RCT or controlled trial. [pmid: 16444875].
522 Bog-Hansen E, Lindblad U, Ranstam J, et al. Impaired glucose metabolism and obesity in Swedish patients with borderline isolated systolic hypertension: Skaraborg Hypertension and Diabetes Project. Diabetes, Obesity & Metabolism. 2001;3(1):25-31. Not RCT or controlled trial.
523 Bohe J, Ding H, Qing DP, et al. IGF-I binding proteins, IGF-I binding protein mRNA and IGF-I receptor mRNA in rats with acute renal failure given IGF-I. Kidney International. 1998;54(4):1070-82. Not human studies. [pmid: 9767523].
524 Bohler J, Woitas R, Keller E, et al. Effect of nifedipine and captopril on glomerular hyperfiltration in normotensive man. American Journal of Kidney Diseases. 1992;20(2):132-9. Sample size less than 50 patients. [pmid: 1496965].
525 Bokemeyer C, Fels LM, Dunn T, et al. Silibinin protects against cisplatin-induced nephrotoxicity without compromising cisplatin or ifosfamide anti-tumour activity. British Journal of Cancer. 1996;74(12):2036-41. Not CKD treatment. [pmid: 8980410].
526 Boldt J, Brenner T, Lehmann A, et al. Influence of two different volume replacement regimens on renal function in elderly patients undergoing cardiac surgery: comparison of a new starch preparation with gelatin. Intensive Care Medicine. 2003;29(5):763-9. Sample size less than 50 patients. [pmid: 12665995].
527 Boldt J, Brosch C, Rohm K, et al. Is albumin administration in hypoalbuminemic elderly cardiac surgery patients of benefit with regard to inflammation, endothelial activation, and long-term kidney function?. Anesthesia & Analgesia. 2008;107(5):1496-503. Not RCT or controlled trial. [pmid: 18931204].
528 Boldt J, Mayer J, Brosch C, et al. Volume replacement with a balanced hydroxyethyl starch (HES) preparation in cardiac surgery patients. Journal of Cardiothoracic & Vascular Anesthesia. Jun. 2010;24(3):399-407. Not CKD treatment. [pmid: 20510247].
529 Boldt J, Muller M, Heesen M, et al. The effects of pentoxifylline on circulating adhesion molecules in critically ill patients with acute renal failure treated by continuous veno-venous hemofiltration. Intensive Care Medicine. 1996;22(4):305-11. Not CKD treatment. [pmid: 8708167].
530 Boldt J, Suttner S, Brosch C, et al. Cardiopulmonary bypass priming using a high dose of a balanced hydroxyethyl starch versus an albumin-based priming strategy. Anesthesia & Analgesia. 2009;109(6):1752-62. Not CKD treatment. [pmid: 19923501].
531 Boldt J, Suttner S, Brosch C, et al. The influence of a balanced volume replacement concept on inflammation, endothelial activation, and kidney integrity in elderly cardiac surgery patients. Intensive Care Medicine. 2009;35(3):462-70. Not CKD treatment. [pmid: 18807007].
532 Bolognese L, Falsini G, Grotti S, et al. The contrast media and nephrotoxicity following coronary revascularization by primary angioplasty for acute myocardial infarction study: design and rationale of the CONTRAST-AMI study. Journal of Cardiovascular Medicine. Mar. 2010;11(3):199-206. Not CKD treatment. [pmid: 19829124].
533 Bolognesi M, Sacerdoti D, Merkel C, et al. Effects of chronic therapy with nadolol on portal hemodynamics and on splanchnic impedance indices using Doppler sonography: comparison between acute and chronic effects. Journal of Hepatology. 1997;26(2):305-11. Sample size less than 50 patients. [pmid: 9059951].
534 Bolton WK, Cattran DC, Williams ME, et al. Randomized trial of an inhibitor of formation of advanced glycation end products in diabetic nephropathy. American Journal of Nephrology. 2004;24(1):32-40. Not CKD treatment. [pmid: 14685005].
535 Bomback AS, Kshirsagar AV, Amamoo MA, et al. Change in proteinuria after adding aldosterone blockers to ACE inhibitors or angiotensin receptor blockers in CKD: a systematic review. American Journal of Kidney Diseases. 2008;51(2):199-211. Not CKD treatment. [pmid: 18215698].
536 Bommer J, Jaber BL. Ultrapure dialysate: facts and myths. Seminars in Dialysis. 2006;19(2):115-9. Not early CKD. [pmid: 16551288].
537 Bond GG, Reeve GR, Ott MG, et al. Mortality among a sample of chemical company employees. American Journal of Industrial Medicine. 1985;7(2):109-21. Not early CKD. [pmid: 3976661].
538 Boner G, Cooper ME, McCarroll K, et al. Adverse effects of left ventricular hypertrophy in the reduction of endpoints in NIDDM with the angiotensin II antagonist losartan (RENAAL) study. Diabetologia. 2005;48(10):1980-7. Not RCT or controlled trial. [pmid: 16082528].
539 Bonne JF, Fournier A, Massy Z, et al. Overview of randomised trials of ACE inhibitors. Lancet. 2006;368(9542):1152-3. Follow-up less than 6 months. [pmid: 17011937].
540 Bonner G, Lederle RM, Scholze J, et al. Therapeutic safety of perindopril in the treatment of mild hypertension with concomitant nephropathy. Arzneimittel-Forschung. 1993;43(8):852-5. Follow-up less than 6 months. [pmid: 8216441].
541 Bonney SL, Northington RS, Hedrich DA, et al. Renal safety of two analgesics used over the counter: ibuprofen and aspirin. Clinical Pharmacology & Therapeutics. 1986;40(4):373-7. Not CKD treatment. [pmid: 3530585].
542 Boogaard PJ, Houtsma AT, Journee HL, et al. Effects of exposure to elemental mercury on the nervous system and the kidneys of workers producing natural gas. Archives of Environmental Health. 1996;51(2):108-15. Not CKD treatment. [pmid: 8638960].
543 Boonen S, Sellmeyer DE, Lippuner K, et al. Renal safety of annual zoledronic acid infusions in osteoporotic postmenopausal women. Kidney International. 2008;74(5):641-8. Not CKD treatment. [pmid: 18509324].
544 Boor P, Casper S, Celec P, et al. Renal, vascular and cardiac fibrosis in rats exposed to passive smoking and industrial dust fibre amosite. Journal of Cellular & Molecular Medicine. Nov-Dec. 2009;13(11-12):4484-91. Not human studies. [pmid: 19292733].
545 Borcea V, Morcos M, Isermann B, et al. Influence of ramipril on the course of plasma thrombomodulin in patients with diabetes mellitus. Vasa. 1999;28(3):172-80. Not RCT or controlled trial. [pmid: 10483322].
546 Borzecki AM, Wong AT, Hickey EC, et al. Hypertension control: how well are we doing?. Archives of Internal Medicine. 2003;163(22):2705-11. Not CKD treatment. [pmid: 14662624].
547 Boscheri A, Weinbrenner C, Botzek B, et al. Failure of ascorbic acid to prevent contrast-media induced nephropathy in patients with renal dysfunction. Clinical Nephrology. 2007;68(5):279-86. Sample size less than 50 patients. [pmid: 18044259].
548 Bostom AG, Culleton BF. Hyperhomocysteinemia in chronic renal disease. Journal of the American Society of Nephrology. 1999;10(4):891-900. Not RCT or controlled trial. [pmid: 10203375].
549 Botker HE, Jensen HK, Krusell LR, et al. Renal effects of xamoterol in patients with moderate heart failure. Cardiovascular Drugs & Therapy. 1993;7(1):111-6. Sample size less than 50 patients. [pmid: 8485065].
550 Bouhanick B. Equivalent effects of nicardipine and captopril on urinary albumin excretion of type 2, non-insulin-dependent diabetic subjects with mild to moderate hypertension. Therapie. 1996;51(1):41-7. Follow-up less than 6 months. [pmid: 8762219].
551 Boulware LE, Troll MU, Jaar BG, et al. Identification and referral of patients with progressive CKD: a national study. American Journal of Kidney Diseases. 2006;48(2):192-204. Not relevant to key questions. [pmid: 16860184].
552 Bouzas-Mosquera A, Vazquez-Rodriguez JM, Peteiro J. Sodium bicarbonate vs sodium chloride in preventing contrast medium-induced nephropathy. JAMA. 2009;301(4):378-9. author reply 9-80. Not CKD treatment. [pmid: 19176437].
553 Bouzidi N, Mekki K, Boukaddoum A, et al. Effects of omega-3 polyunsaturated fatty-acid supplementation on redox status in chronic renal failure patients with dyslipidemia. Journal of Renal Nutrition. Sep. 2010;20(5):321-8. Follow-up less than 6 months. [pmid: 20303788].
554 Bove T, Landoni G, Calabro MG, et al. Renoprotective action of fenoldopam in high-risk patients undergoing cardiac surgery: a prospective, double-blind, randomized clinical trial. Circulation. 2005;111(24):3230-5. Not CKD treatment. [pmid: 15967861].
555 Bowden RG, Wilson RL, Deike E, et al. Fish oil supplementation lowers C-reactive protein levels independent of triglyceride reduction in patients with end-stage renal disease. Nutrition in Clinical Practice. 2009;24(4):508-12. Sample size less than 50 patients. [pmid: 19461006].
556 Bowling CB, Pitt B, Ahmed MI, et al. Hypokalemia and outcomes in patients with chronic heart failure and chronic kidney disease: findings from propensity-matched studies. Circulation: Heart Failure. Mar. 2010;3(2):253-60. Not CKD treatment. [pmid: 20103777].
557 Boyden TF, Gurm HS. Does gadolinium-based angiography protect against contrast-induced nephropathy?: a systematic review of the literature. Catheterization & Cardiovascular Interventions. 2008;71(5):687-93. Not CKD treatment. [pmid: 18360867].
558 Boyle JA. Controlled trials of amphotericin B lipid complex. Clinical Infectious Diseases. 2000;31(4):1117-8. Not relevant to key questions. [pmid: 11049803].
559 Braden GL, von Oeyen PT, Germain MJ, et al. Ritodrine- and terbutaline-induced hypokalemia in preterm labor: mechanisms and consequences. Kidney International. 1997;51(6):1867-75. Sample size less than 50 patients. [pmid: 9186877].
560 Bradley RT, Ebbs P, Young WY, et al. Specialty practice in dietetics: empirical models and results. [Erratum appears in J Am Diet Assoc 1993 Mar;93(3):271].[Erratum appears in J Am Diet Assoc 1993 Apr; 93(4):402]. Journal of the American Dietetic Association. 1993;93(2):203-10. Not RCT or controlled trial. [pmid: 8423289].
561 Brady CB, Gaziano JM, Cxypoliski RA, et al. Homocysteine lowering and cognition in CKD: the Veterans Affairs homocysteine study. American Journal of Kidney Diseases. 2009;54(3):440-9. Not early CKD. [pmid: 19628319].
562 Braith RW, Mills RM, Wilcox CS, et al. High-dose angiotensin-converting enzyme inhibition restores body fluid homeostasis in heart-transplant recipients. Journal of the American College of Cardiology. 2003;41(3):426-32. Sample size less than 50 patients. [pmid: 12575970].
563 Bramlage P, Durand-Zaleski I, Desai N, et al. The value of irbesartan in the management of hypertension. Expert Opinion on Pharmacotherapy. 2009;10(11):1817-31. Not RCT or controlled trial. [pmid: 19601700].
564 Brancati FL, Cusumano AM. Epidemiology and prevention of diabetic nephropathy. Current Opinion in Nephrology & Hypertension. 1995;4(3):223-9. Not relevant to key questions. [pmid: 7648216].
565 Branch RA. Prevention of amphotericin B-induced renal impairment. A review on the use of sodium supplementation. Archives of Internal Medicine. 1988;148(11):2389-94. Not CKD treatment. [pmid: 3056312].
566 Brandao-Neto J, Silva CA, Shuhama T, et al. Renal handling of zinc in insulin-dependent diabetes mellitus patients. BioMetals. 2001;14(1):75-80. Not CKD treatment. [pmid: 11368278].
567 Brandli DW, Sarkissian E, Ng SC, et al. Individual variability in concentrations of urinary sulindac sulfide. Clinical Pharmacology & Therapeutics. 1991;50(6):650-5. Not CKD treatment. [pmid: 1752108].
568 Brandstrom E, Grzegorczyk A, Jacobsson L, et al. GFR measurement with iohexol and 51Cr-EDTA. A comparison of the two favoured GFR markers in Europe. Nephrology Dialysis Transplantation. 1998;13(5):1176-82. Sample size less than 50 patients.
569 Brandt JR, Avner ED, Hickman RO, et al. Safety and efficacy of erythropoietin in children with chronic renal failure. Pediatric Nephrology. 1999;13(2):143-7. Sample size less than 50 patients. [pmid: 10229004].
570 Brar SS, Hiremath S, Dangas G, et al. Sodium bicarbonate for the prevention of contrast induced-acute kidney injury: a systematic review and meta-analysis. Clinical Journal of The American Society of Nephrology: CJASN. 2009;4(10):1584-92. Not RCT or controlled trial. [pmid: 19713291].
571 Brar SS, Shen AYJ, Jorgensen MB, et al. Sodium bicarbonate vs sodium chloride for the prevention of contrast medium-induced nephropathy in patients undergoing coronary angiography: a randomized trial. JAMA. 2008;300(9):1038-46. Not CKD treatment. [pmid: 18768415].
572 Brater DC, Anderson S, Baird B, et al. Effects of ibuprofen, naproxen, and sulindac on prostaglandins in men. Kidney International. 1985;27(1):66-73. Sample size less than 50 patients. [pmid: 3884880].
573 Brater DC, Leinfelder J, Anderson SA. Clinical pharmacology of torasemide, a new loop diuretic. Clinical Pharmacology & Therapeutics. 1987;42(2):187-92. Sample size less than 50 patients. [pmid: 3608350].
574 Brater DC, Rudy DR, Voelker JR, et al. Pharmacokinetics and pharmacodynamics of torasemide in patients with chronic renal insufficiency--preliminary evaluation. Cardiovascular Drugs & Therapy. Suppl 1. 1993;7:69-73. Sample size less than 50 patients. [pmid: 8435379].
575 Braunstein JB, Anderson GF, Gerstenblith G, et al. Noncardiac comorbidity increases preventable hospitalizations and mortality among Medicare beneficiaries with chronic heart failure. Journal of the American College of Cardiology. 2003;42(7):1226-33. Not CKD treatment. [pmid: 14522486].
576 Brenner BM. Remission of renal disease: recounting the challenge, acquiring the goal. Journal of Clinical Investigation. 2002;110(12):1753-8. Not RCT or controlled trial. [pmid: 12488422].
577 Brenner BM, Cooper ME, de Zeeuw D, et al. The losartan renal protection study--rationale, study design and baseline characteristics of RENAAL (Reduction of Endpoints in NIDDM with the Angiotensin II Antagonist Losartan). Journal of the Renin-Angiotensin-Aldosterone System. 2000;1(4):328-35. Not RCT or controlled trial. [pmid: 11967819].
578 Brenner P, Meyer M, Reichenspurner H, et al. Significance of prophylactic urodilatin (INN: ularitide) infusion for the prevention of acute renal failure in patients after heart transplantation. European Journal of Medical Research. 1995;1(3):137-43. Sample size less than 50 patients. [pmid: 9389675].
579 Brenner RM, Chertow GM. The rise and fall of atrial natriuretic peptide for acute renal failure. Current Opinion in Nephrology & Hypertension. 1997;6(5):474-6. Not RCT or controlled trial. [pmid: 9327207].
580 Bretzel RG. Prevention and slowing down the progression of the diabetic nephropathy through antihypertensive therapy. Journal of Diabetes & its Complications. 1997;11(2):112-22. Not RCT or controlled trial. [pmid: 9101397].
581 Breyer JA, Hunsicker LG, Bain RP, et al. Angiotensin converting enzyme inhibition in diabetic nephropathy. The Collaborative Study Group. Kidney International - Supplement. 1994;45:S156-60. Not CKD treatment. [pmid: 8158886].
582 Brichard S, Ketelslegers JM, Lambert AE. Renal function, glycemic control and perindopril in diabetic patients. Clinical & Experimental Hypertension - Part A, Theory & Practice. Suppl 2. 1989;11:545-54. Sample size less than 50 patients.
583 Brichard S, Ketelslegers JM, Lambert AE. Renal function, glycaemic control and perindopril in diabetic patients. Archives des Maladies du Coeur et des Vaisseaux. Spec No 1. 1989;82:57-61. Sample size less than 50 patients. [pmid: 2505714].
584 Brichard SM, Santoni JP, Thomas JR, et al. Long term reduction of microalbuminuria after 1 year of angiotensin converting enzyme inhibition by perindopril in hypertensive insulin-treated diabetic patients. Diabete et Metabolisme. 1990;16(1):30-6. Sample size less than 50 patients. [pmid: 2185055].
585 Brienza N, Giglio MT, Marucci M, et al. Does perioperative hemodynamic optimization protect renal function in surgical patients? A meta-analytic study. Critical Care Medicine. 2009;37(6):2079-90. Not CKD treatment. [pmid: 19384211].
586 Brienza N, Malcangi V, Dalfino L, et al. A comparison between fenoldopam and low-dose dopamine in early renal dysfunction of critically ill patients. Critical Care Medicine. 2006;34(3):707-14. Sample size less than 50 patients. [pmid: 16505657].
587 Briganti EM, Branley P, Chadban SJ, et al. Smoking is associated with renal impairment and proteinuria in the normal population: the AusDiab kidney study. Australian Diabetes, Obesity and Lifestyle Study. American Journal of Kidney Diseases. 2002;40(4):704-12. Not CKD treatment. [pmid: 12324904].
588 Briggs DE, French JA. Levetiracetam safety profiles and tolerability in epilepsy patients. Expert Opinion on Drug Safety. 2004;3(5):415-24. Not CKD treatment. [pmid: 15335297].
589 Briguori C, Airoldi F, D'Andrea D, et al. Renal Insufficiency Following Contrast Media Administration Trial (REMEDIAL): a randomized comparison of 3 preventive strategies. Circulation. 2007;115(10):1211-7. Not CKD treatment. [pmid: 17309916].
590 Briguori C, Colombo A, Airoldi F, et al. N-Acetylcysteine versus fenoldopam mesylate to prevent contrast agent-associated nephrotoxicity. Journal of the American College of Cardiology. 2004;44(4):762-5. Not CKD treatment. [pmid: 15312855].
591 Briguori C, Colombo A, Violante A, et al. Standard vs double dose of N-acetylcysteine to prevent contrast agent associated nephrotoxicity. European Heart Journal. 2004;25(3):206-11. Not CKD treatment. [pmid: 14972420].
592 Briguori C, Manganelli F, Scarpato P, et al. Acetylcysteine and contrast agent-associated nephrotoxicity. Journal of the American College of Cardiology. 2002;40(2):298-303. Not early CKD. [pmid: 12106935].
593 Briguori C, Marenzi G. Contrast-induced nephropathy: pharmacological prophylaxis. Kidney International - Supplement. 2006;(100):S30-8. Not relevant to key questions. [pmid: 16612399].
594 Brinkmann A, Seeling W, Wolf CF, et al. Ibuprofen does not impair renal function in patients undergoing infrarenal aortic surgery with epidural anaesthesia. Intensive Care Medicine. 1998;24(4):322-8. Sample size less than 50 patients. [pmid: 9609409].
595 Brinkworth GD, Buckley JD, Noakes M, et al. Renal function following long-term weight loss in individuals with abdominal obesity on a very-low-carbohydrate diet vs high-carbohydrate diet. Journal of the American Dietetic Association. Apr. 2010;110(4):633-8. Not CKD treatment. [pmid: 20338292].
596 Brocco E, Velussi M, Cernigoi AM, et al. Evidence of a threshold value of glycated hemoglobin to improve the course of renal function in type 2 diabetes with typical diabetic glomerulopathy. Journal of Nephrology. 2001;14(6):461-71. Not RCT or controlled trial. [pmid: 11783602].
597 Brockenbrough AT, Dittrich MO, Page ST, et al. Transdermal androgen therapy to augment EPO in the treatment of anemia of chronic renal disease. American Journal of Kidney Diseases. 2006;47(2):251-62. Not relevant to key questions. [pmid: 16431254].
598 Bromage PR, el-Faqih S, Husain I, et al. Epinephrine and fentanyl as adjuvants to 0.5% bupivacaine for epidural analgesia. Regional Anesthesia. 1989;14(4):189-94. Not CKD treatment. [pmid: 2487934].
599 Bronas UG. Exercise training and reduction of cardiovascular disease risk factors in patients with chronic kidney disease. Advances in Chronic Kidney Disease. 2009;16(6):449-58. Not RCT or controlled trial. [pmid: 19801135].
600 Brooks D, Charleston J, Dowie D, et al. Predictors of participant adherence and retention in the African American Study of Kidney Disease and Hypertension. Nephrology Nursing Journal: Journal of the American Nephrology Nurses' Association. 2008;35(2):133-42. Not RCT or controlled trial. [pmid: 18472682].
601 Brow TD, Kakkar VV, Das SK. The significance of creatine kinase in cardiac patients with acute limb ischaemia. Journal of Cardiovascular Surgery. 1999;40(5):637-44. Not CKD treatment. [pmid: 10596995].
602 Brown J. Effects of interrupting the renin-angiotensin system on sodium excretion in man. Journal of Physiology. 1988;395:17-40. Sample size less than 50 patients. [pmid: 3045295].
603 Brown J, O'Flynn MA. Acute effects of physiological increments of alpha-atrial natriuretic peptide in man. Kidney International. 1989;36(4):645-52. Sample size less than 50 patients. [pmid: 2530384].
604 Brown LC, Brown EA, Greenhalgh RM, et al. Renal function and abdominal aortic aneurysm (AAA): the impact of different management strategies on long-term renal function in the UK EndoVascular Aneurysm Repair (EVAR) Trials. Annals of Surgery. May. 2010;251(5):966-75. Not CKD treatment. [pmid: 20395842].
605 Brown WV. Safety of statins. Current Opinion in Lipidology. 2008;19(6):558-62. Not relevant to key questions. [pmid: 18957877].
606 Bruce R, Daniels A, Cundy T. Renal function changes in diabetic nephropathy induced by bezafibrate. Nephron. 1996;73(3):490. Sample size less than 50 patients. [pmid: 8832617].
607 Bruce R, Rutland M, Cundy T. Glomerular hyperfiltration in young Polynesians with type 2 diabetes. Diabetes Research & Clinical Practice. 1994;25(3):155-60. Sample size less than 50 patients. [pmid: 7851269].
608 Brugts JJ, Boersma E, Chonchol M, et al. The cardioprotective effects of the angiotensin-converting enzyme inhibitor perindopril in patients with stable coronary artery disease are not modified by mild to moderate renal insufficiency: insights from the EUROPA trial. Journal of the American College of Cardiology. 2007;50(22):2148-55. Not RCT or controlled trial. [pmid: 18036453].
609 Brunton C, Varghese Z, Moorhead JF. Lipopheresis in the nephrotic syndrome. Kidney International - Supplement. 1999;71:S6-9. Sample size less than 50 patients. [pmid: 10412726].
610 Bruun NE, Dige-Pedersen H, Skott P. Normal responses of atrial natriuretic factor and renal tubular function to sodium loading in hypertension-prone humans. Blood Pressure. 2000;9(4):206-13. Not early CKD. [pmid: 11055473].
611 Bruun NE, Ibsen H, Nielsen F, et al. Lack of effect of nifedipine on counterregulatory mechanisms in essential hypertension. Hypertension. 1986;8(8):655-61. Sample size less than 50 patients. [pmid: 3525403].
612 Bruun NE, Ibsen H, Skott P, et al. Lithium clearance and renal tubular sodium handling during acute and long-term nifedipine treatment in essential hypertension. Clinical Science. 1988;75(6):609-13. Follow-up less than 6 months. [pmid: 3208493].
613 Bruun NE, Skott P, Giese J. Renal and endocrine effects of physiological variations of atrial natriuretic factor in normal humans. American Journal of Physiology. 1991;260(1 Pt 2):R217-24. Not CKD treatment. [pmid: 1847023].
614 Bryan AG, Bolsin SN, Vianna PT, et al. Modification of the diuretic and natriuretic effects of a dopamine infusion by fluid loading in preoperative cardiac surgical patients. Journal of Cardiothoracic & Vascular Anesthesia. 1995;9(2):158-63. Follow-up less than 6 months. [pmid: 7780071].
615 Bucchi F, Bodzenta A, de Gaetano G, et al. Effects of 1 gram oral or intravenous aspirin on urinary excretion of thromboxane B2 and 6-keto-PGF1 alpha in healthy subjects. Prostaglandins. 1986;32(5):691-701. Sample size less than 50 patients. [pmid: 3103169].
616 Buchet JP, Lauwerys R, Roels H, et al. Renal effects of cadmium body burden of the general population. [Erratum appears in Lancet 1991 Jun 22;337(8756):1554]. Lancet. 1990;336(8717):699-702. Not CKD treatment. [pmid: 1975890].
617 Buckalew VM Jr. End-stage renal disease: can dietary protein restriction prevent it?. Southern Medical Journal. 1994;87(10):1034-7. Not RCT or controlled trial. [pmid: 7939916].
618 Buclin T, Pechere-Bertschi A, Sechaud R, et al. Sinistrin clearance for determination of glomerular filtration rate: a reappraisal of various approaches using a new analytical method. Journal of Clinical Pharmacology. 1997;37(8):679-92. Sample size less than 50 patients. [pmid: 9378840].
619 Buclin T, Sechaud R, Bertschi AP, et al. Estimation of glomerular filtration rate by sinistrin clearance using various approaches. Renal Failure. 1998;20(2):267-76. Not CKD treatment. [pmid: 9574452].
620 Budoff MJ, Kessler P, Gao YL, et al. The interscan variation of CT coronary artery calcification score: analysis of the Calcium Acetate Renagel Comparison (CARE)-2 study. Academic Radiology. 2008;15(1):58-61. Not RCT or controlled trial. [pmid: 18078907].
621 Bueter M, Dubb SS, Gill A, et al. Renal cytokines improve early after bariatric surgery. British Journal of Surgery. Dec. 2010;97(12):1838-44. Not CKD treatment. [pmid: 20862711].
622 Bunke M, Sloan R, Brier M, et al. An improved glomerular filtration rate in cardiac transplant recipients with once-a-day cyclosporine dosing. Transplantation. 1995;59(4):537-40. Sample size less than 50 patients. [pmid: 7878758].
623 Burgess E. Conservative treatment to slow deterioration of renal function: evidence-based recommendations. Kidney International - Supplement. 1999;70:S17-25. Not RCT or controlled trial. [pmid: 10369191].
624 Burgess ED, Carides GW, Gerth WC, et al. Losartan reduces the costs associated with nephropathy and end-stage renal disease from type 2 diabetes: Economic evaluation of the RENAAL study from a Canadian perspective. Canadian Journal of Cardiology. 2004;20(6):613-8. Not CKD treatment. [pmid: 15152291].
625 Burgess W, Merten GJ, Rittase RA. Sodium bicarbonate vs sodium chloride in preventing contrast medium-induced nephropathy. JAMA. 2009;301(4):377. author reply 9-80. Not CKD treatment. [pmid: 19176436].
626 Burnier M, Brunner HR. Angiotensin II receptor antagonists in hypertension. Kidney International - Supplement. 1998;68:S107-11. Not RCT or controlled trial. [pmid: 9839293].
627 Burnier M, Hagman M, Nussberger J, et al. Short-term and sustained renal effects of angiotensin II receptor blockade in healthy subjects. Hypertension. 1995;25(4 Pt 1):602-9. Sample size less than 50 patients. [pmid: 7721404].
628 Burnier M, Mooser V, Wauters JP, et al. Bolus injections of synthetic atrial natriuretic peptide in patients with chronic renal failure or nephrotic syndrome. Journal of Cardiovascular Pharmacology. 1989;13(5):682-90. Not CKD treatment. [pmid: 2472515].
629 Burnier M, Rutschmann B, Nussberger J, et al. Salt-dependent renal effects of an angiotensin II antagonist in healthy subjects. Hypertension. 1993;22(3):339-47. Sample size less than 50 patients. [pmid: 8349327].
630 Burns KEA, Chu MWA, Novick RJ, et al. Perioperative N-acetylcysteine to prevent renal dysfunction in high-risk patients undergoing cabg surgery: a randomized controlled trial. JAMA. 2005;294(3):342-50. Not CKD treatment. [pmid: 16030279].
631 Burodom A. Renal response to egg white protein loading in healthy young adults. Journal of the Medical Association of Thailand. Jul. 2010;93(7):824-9. Not CKD treatment. [pmid: 20649063].
632 Bursztyn M, Kobrin I, Fidel J, et al. Improved kidney function with cilazapril in hypertensive type II diabetics with chronic renal failure. Journal of Cardiovascular Pharmacology. 1991;18(3):337-41. Sample size less than 50 patients. [pmid: 1720832].
633 Bursztyn M, Motro M, Grossman E, et al. Accelerated coronary artery calcification in mildly reduced renal function of high-risk hypertensives: a 3-year prospective observation. Journal of Hypertension. 2003;21(10):1953-9. Not CKD treatment. [pmid: 14508203].
634 Burton CJ, Tomson CR. Can the use of low-dose dopamine for treatment of acute renal failure be justified?. Postgraduate Medical Journal. 1999;75(883):269-74. Not CKD treatment. [pmid: 10533629].
635 Bus SA, Maas M, de Lange A, et al. Elevated plantar pressures in neuropathic diabetic patients with claw/hammer toe deformity. Journal of Biomechanics. 2005;38(9):1918-25. Not relevant to key questions. [pmid: 16023481].
636 Busch M, Franke S, Wolf G, et al. Serum levels of the advanced glycation end products Nepsilon-carboxymethyllysine and pentosidine are not influenced by treatment with the angiotensin receptor II type 1 blocker irbesartan in patients with type 2 diabetic nephropathy and hypertension. Nephron. 2008;108(4):c291-7. Not early CKD. [pmid: 18434751].
637 Buter H, Navis G, Dullaart RP, et al. Time course of the antiproteinuric and renal haemodynamic responses to losartan in microalbuminuric IDDM. Nephrology Dialysis Transplantation. 2001;16(4):771-5. Sample size less than 50 patients.
638 Butler J, Emerman C, Peacock WF, et al. The efficacy and safety of B-type natriuretic peptide (nesiritide) in patients with renal insufficiency and acutely decompensated congestive heart failure. Nephrology Dialysis Transplantation. 2004;19(2):391-9. Not relevant to key questions.
639 Bybee KA, Lee JH, O'Keefe JH. Cumulative clinical trial data on atorvastatin for reducing cardiovascular events: the clinical impact of atorvastatin. Current Medical Research & Opinion. 2008;24(4):1217-29. Not CKD treatment. [pmid: 18358084].
640 Caglar K, Yilmaz MI, Saglam M, et al. Short-term treatment with sevelamer increases serum fetuin-a concentration and improves endothelial dysfunction in chronic kidney disease stage 4 patients. Clinical Journal of The American Society of Nephrology: CJASN. 2008;3(1):61-8. Follow-up less than 6 months. [pmid: 18057307].
641 Cahill CJ, Pain JA, Bailey ME. Bile salts, endotoxin and renal function in obstructive jaundice. Surgery, Gynecology & Obstetrics. 1987;165(6):519-22. Sample size less than 50 patients.
642 Caidahl K, Eden S, Bengtsson BA. Cardiovascular and renal effects of growth hormone. Clinical Endocrinology. 1994;40(3):393-400. Not CKD treatment. [pmid: 8187304].
643 Caillot D, Reny G, Solary E, et al. A controlled trial of the tolerance of amphotericin B infused in dextrose or in Intralipid in patients with haematological malignancies. Journal of Antimicrobial Chemotherapy. 1994;33(3):603-13. Not CKD treatment. [pmid: 8040124].
644 Caimmi PP, Pagani L, Micalizzi E, et al. Fenoldopam for renal protection in patients undergoing cardiopulmonary bypass. Journal of Cardiothoracic & Vascular Anesthesia. 2003;17(4):491-4. Not CKD treatment. [pmid: 12968238].
645 Callahan MB, LeSage L, Johnstone S. A model for patient participation in quality of life measurement to improve rehabilitation outcomes. Nephrology News & Issues. 1999;13(1):33-7. Not RCT or controlled trial. [pmid: 10335187].
646 Callis A, Magnan de Bornier B, Serrano JJ, et al. Activity of citrulline malate on acid-base balance and blood ammonia and amino acid levels. Study in the animal and in man. Arzneimittel-Forschung. 1991;41(6):660-3. Not CKD treatment. [pmid: 1930358].
647 Camacho P, Pitale S, Abraira C. Beneficial and detrimental effects of intensive glycaemic control, with emphasis on type 2 diabetes mellitus. Drugs & Aging. 2000;17(6):463-76. Not relevant to key questions. [pmid: 11200307].
648 Camargo EG, Weinert LS, Lavinsky J, et al. The effect of aspirin on the antiproteinuric properties of enalapril in microalbuminuric type 2 diabetic patients: a randomized, double-blind, placebo-controlled study. Diabetes Care. 2007;30(7):e66. Sample size less than 50 patients. [pmid: 17596489].
649 Camisasca P, Avanzini F, Alli C, et al. Overall cardiovascular risk still ignored in general practice care of hypertension. Journal of Cardiovascular Risk. 2002;9(3):147-52. Not relevant to key questions. [pmid: 12202837].
650 Camp MJ, Wingard JR, Gilmore CE, et al. Efficacy of low-dose dopamine in preventing amphotericin B nephrotoxicity in bone marrow transplant patients and leukemia patients. Antimicrobial Agents & Chemotherapy. 1998;42(12):3103-6. Not CKD treatment. [pmid: 9835498].
651 Campbell DR, Flemming BK, Mason WF, et al. A comparative study of the nephrotoxicity of iohexol, iopamidol and ioxaglate in peripheral angiography. Canadian Association of Radiologists Journal. 1990;41(3):133-7. Not CKD treatment. [pmid: 2354386].
652 Campbell KL, Ash S, Bauer JD. The impact of nutrition intervention on quality of life in pre-dialysis chronic kidney disease patients. Clinical Nutrition. 2008;27(4):537-44. Not early CKD. [pmid: 18584924].
653 Campbell KL, Ash S, Davies PSW, et al. Randomized controlled trial of nutritional counseling on body composition and dietary intake in severe CKD. American Journal of Kidney Diseases. 2008;51(5):748-58. Not early CKD. [pmid: 18436085].
654 Campbell MS, Rai J, Kozin E, et al. Effects of sirolimus vs. calcineurin inhibitors on renal dysfunction after orthotopic liver transplantation. Clinical Transplantation. 2007;21(3):377-84. Sample size less than 50 patients. [pmid: 17488388].
655 Campbell RC, Sui X, Filippatos G, et al. Association of chronic kidney disease with outcomes in chronic heart failure: a propensity-matched study. Nephrology Dialysis Transplantation. 2009;24(1):186-93. Not CKD treatment.
656 Campbell RC, Sui X, Filippatos G, et al. Association of chronic kidney disease with outcomes in chronic heart failure: a propensity-matched study. Nephrology Dialysis Transplantation. 2009;24(1):186-93. Not CKD treatment.
657 Campbell WW, Joseph LJO, Ostlund RE Jr., et al. Resistive training and chromium picolinate: effects on inositols and liver and kidney functions in older adults. International Journal of Sport Nutrition & Exercise Metabolism. 2004;14(4):430-42. Not RCT or controlled trial. [pmid: 15467101].
658 Campo C, Garcia-Vallejo O, Barrios V, et al. The natriuretic effect of nifedipine gastrointestinal therapeutic system remains despite the presence of mild-to-moderate renal failure. Journal of Hypertension. 1997;15(12 Pt 2):1803-8. Follow-up less than 6 months. [pmid: 9488243].
659 Cangiano JL, Figueroa J, Palmer R. Renal hemodynamic effects of nabumetone, sulindac, and placebo in patients with osteoarthritis. Clinical Therapeutics. 1999;21(3):503-12. Not CKD treatment. [pmid: 10321419].
660 Cantaluppi V, Assenzio B, Pasero D, et al. Polymyxin-B hemoperfusion inactivates circulating proapoptotic factors. Intensive Care Medicine. 2008;34(9):1638-45. Not RCT or controlled trial. [pmid: 18463848].
661 Cantarovich F, Rangoonwala B, Lorenz H, et al. High-dose furosemide for established ARF: a prospective, randomized, double-blind, placebo-controlled, multicenter trial. American Journal of Kidney Diseases. 2004;44(3):402-9. Not CKD treatment. [pmid: 15332212].
662 Cantarovich M. Renal protective strategies in heart transplant patients. Current Opinion in Cardiology. 2007;22(2):133-8. Not RCT or controlled trial. [pmid: 17284993].
663 Cantarovich M, Besner JG, Fitchett DH, et al. Efficacy and side-effects of cyclosporine dose monitoring with levels 6 h after the morning dose in heart transplant patients. Clinical Transplantation. 1997;11(5 Pt 1):399-405. Sample size less than 50 patients. [pmid: 9361930].
664 Cantarovich M, Yoshida EM, Peltekian KM, et al. Poor prediction of the glomerular filtration rate using current formulas in de novo liver transplant patients. Transplantation. 2006;82(3):433-6. Not CKD treatment. [pmid: 16906045].
665 Cantor TL. Lack of evidence for administering vitamin D analogs to kidney failure patients to improve survivability. Clinical Nephrology. 2009;72(2):97-104. Not early CKD. [pmid: 19640366].
666 Cao Y, Zhao J, Yang Z, et al. CD4+FOXP3+ regulatory T cell depletion by low-dose cyclophosphamide prevents recurrence in patients with large condylomata acuminata after laser therapy. Clinical Immunology. Jul. 2010;136(1):21-9. Not CKD treatment. [pmid: 20338811].
667 Capek M, Schnack C, Ludvik B, et al. Effects of captopril treatment versus placebo on renal function in type 2 diabetic patients with microalbuminuria: a long-term study. Clinical Investigator. 1994;72(12):961-6. Sample size less than 50 patients. [pmid: 7711427].
668 Capes SE, Gerstein HC, Negassa A, et al. Enalapril prevents clinical proteinuria in diabetic patients with low ejection fraction. Diabetes Care. 2000;23(3):377-80. Not CKD treatment. [pmid: 10868869].
669 Cappelli P, Di Liberato L, Stuard S, et al. N-3 polyunsaturated fatty acid supplementation in chronic progressive renal disease. Journal of Nephrology. 1997;10(3):157-62. Sample size less than 50 patients. [pmid: 9238624].
670 Cappuccio FP, Antonios TF, Markandu ND, et al. Acute natriuretic effect of nifedipine on different sodium intakes in essential hypertension: evidence for distal tubular effect?. Journal of Human Hypertension. 1994;8(8):627-30. Not CKD treatment. [pmid: 7990097].
671 Caravaca F, Cubero JJ, Jimenez F, et al. Effect of the mode of calcitriol administration on PTH-ionized calcium relationship in uraemic patients with secondary hyperparathyroidism. Nephrology Dialysis Transplantation. 1995;10(5):665-70. Sample size less than 50 patients.
672 Carbonell N, Blasco M, Sanjuan R, et al. Intravenous N-acetylcysteine for preventing contrast-induced nephropathy: a randomised trial. International Journal of Cardiology. 2007;115(1):57-62. Not CKD treatment. [pmid: 16814414].
673 Carbonell N, Sanjuan R, Blasco M, et al. N-acetylcysteine: short-term clinical benefits after coronary angiography in high-risk renal patients. Revista Espanola de Cardiologia. Jan. 2010;63(1):12-9. Not relevant to key questions. [pmid: 20089221].
674 Carcoana OV, Hines RL. Is renal dose dopamine protective or therapeutic? Yes. Critical Care Clinics. 1996;12(3):677-85. Not CKD treatment. [pmid: 8839599].
675 Carcoana OV, Mathew JP, Davis E, et al. Mannitol and dopamine in patients undergoing cardiopulmonary bypass: a randomized clinical trial. Anesthesia & Analgesia. 2003;97(5):1222-9. Not CKD treatment. [pmid: 14570627].
676 Cardiel MH. Abetimus sodium: a new therapy for delaying the time to, and reducing the incidence of, renal flare and/or major systemic lupus erythematosus flares in patients with systemic lupus erythematosus who have a history of renal disease. Expert Opinion on Investigational Drugs. 2005;14(1):77-88. Not RCT or controlled trial. [pmid: 15709924].
677 Carella MJ, Gossain VV, Jones J. The effects of a low-dose regimen of fosinopril on elevated urinary albumin excretion in normotensive type 1 diabetic patients. Journal of Medicine. 1999;30(5-6):305-20. Sample size less than 50 patients. [pmid: 10851564].
678 Carides GW, Shahinfar S, Dasbach EJ, et al. The impact of losartan on the lifetime incidence of end-stage renal disease and costs in patients with type 2 diabetes and nephropathy. Pharmacoeconomics. 2006;24(6):549-58. Not relevant to key questions. [pmid: 16761903].
679 Carlsen JE, Jensen HA, Rehling M, et al. Long term haemodynamic effects of pinacidil and hydralazine in arterial hypertension. Drugs. Suppl 7. 1988;36:55-63. Sample size less than 50 patients. [pmid: 3076136].
680 Carlson K, Hjorth M, Knudsen LM, et al. Toxicity in standard melphalan-prednisone therapy among myeloma patients with renal failure--a retrospective analysis and recommendations for dose adjustment. British Journal of Haematology. 2005;128(5):631-5. Not RCT or controlled trial. [pmid: 15725084].
681 Carr AA, Kowey PR, Devereux RB, et al. Hospitalizations for new heart failure among subjects with diabetes mellitus in the RENAAL and LIFE studies. American Journal of Cardiology. 2005;96(11):1530-6. Not RCT or controlled trial. [pmid: 16310435].
682 Carraro M, Malalan F, Antonione R, et al. Effects of a dimeric vs a monomeric nonionic contrast medium on renal function in patients with mild to moderate renal insufficiency: a double-blind, randomized clinical trial. European Radiology. 1998;8(1):144-7. Not CKD treatment. [pmid: 9442148].
683 Carraro M, Mancini W, Artero M, et al. Dose effect of nitrendipine on urinary enzymes and microproteins following non-ionic radiocontrast administration. Nephrology Dialysis Transplantation. 1996;11(3):444-8. Not CKD treatment.
684 Carraro M, Stacul F, Collari P, et al. Contrast media nephrotoxicity: urinary protein and enzyme pattern in patients with or without saline infusion during digital subtracting angiography. Contributions to Nephrology. 1993;101:251-4. Not CKD treatment. [pmid: 8467682].
685 Carrier M, Leblanc MH, Perrault LP, et al. Basiliximab and rabbit anti-thymocyte globulin for prophylaxis of acute rejection after heart transplantation: a non-inferiority trial. Journal of Heart & Lung Transplantation. 2007;26(3):258-63. Not RCT or controlled trial. [pmid: 17346628].
686 Carrier M, Pelletier GB, White M, et al. Effect of pentoxifylline on renal toxicity of cyclosporine: preliminary results. Transplantation Proceedings. 1994;26(5):2745-6. Sample size less than 50 patients. [pmid: 7940862].
687 Carrier M, Pelletier GB, White M, et al. Effect of pentoxifylline on renal toxicity of cyclosporine: results of a clinical trial after heart transplantation. Journal of Heart & Lung Transplantation. 1996;15(12):1179-83. Not CKD treatment. [pmid: 8981202].
688 Carstens J, Greisen J, Jensen KT, et al. Renal effects of a urodilatin infusion in patients with liver cirrhosis, with and without ascites. Journal of the American Society of Nephrology. 1998;9(8):1489-98. Not CKD treatment. [pmid: 9697672].
689 Carstens J, Gronbaek H, Larsen HK, et al. Effects of urodilatin on natriuresis in cirrhosis patients with sodium retention. BMC Gastroenterology. 2007;7:1. Follow-up less than 6 months. [pmid: 17257428].
690 Carstens J, Jensen KT, Pedersen EB. Effect of urodilatin infusion on renal haemodynamics, tubular function and vasoactive hormones. Clinical Science. 1997;92(4):397-407. Sample size less than 50 patients. [pmid: 9176040].
691 Carstens J, Jensen KT, Pedersen EB. Metabolism and action of urodilatin infusion in healthy volunteers. Clinical Pharmacology & Therapeutics. 1998;64(1):73-86. Follow-up less than 6 months. [pmid: 9695722].
692 Carstens J, Pedersen EB. Renal effects of urodilatin in healthy subjects are independent of blockade of the cyclooxygenase and angiotensin II receptor. Scandinavian Journal of Clinical & Laboratory Investigation. 2008;68(1):2-10. Not RCT or controlled trial. [pmid: 17852806].
693 Carswell CI, Goa KL. Losartan in diabetic nephropathy. Drugs. 2003;63(4):407-14. discussion 15-6. Not RCT or controlled trial. [pmid: 12558462].
694 Carter JL, O'Riordan SE, Eaglestone GL, et al. Chronic kidney disease prevalence in a UK residential care home population. Nephrology Dialysis Transplantation. 2008;23(4):1257-64. Not RCT or controlled trial.
695 Caruso D, D'Avino M, Acampora C, et al. Effects of losartan and chlorthalidone on blood pressure and renal vascular resistance index in non-diabetic patients with essential hypertension and normal renal function. Journal of Cardiovascular Pharmacology. 2004;44(5):520-4. Not RCT or controlled trial. [pmid: 15505487].
696 Casas JP, Chua W, Loukogeorgakis S, et al. Effect of inhibitors of the renin-angiotensin system and other antihypertensive drugs on renal outcomes: systematic review and meta-analysis. Lancet. 2005;366(9502):2026-33. Not RCT or controlled trial. [pmid: 16338452].
697 Castaneda C, Gordon PL, Parker RC, et al. Resistance training to reduce the malnutrition-inflammation complex syndrome of chronic kidney disease. American Journal of Kidney Diseases. 2004;43(4):607-16. Not relevant to key questions. [pmid: 15042537].
698 Castaneda C, Gordon PL, Uhlin KL, et al. Resistance training to counteract the catabolism of a low-protein diet in patients with chronic renal insufficiency. A randomized, controlled trial. Annals of Internal Medicine. 2001;135(11):965-76. Sample size less than 50 patients. [pmid: 11730397].
699 Castellani S, Scarti L, Chen JL, et al. The antihypertensive and renal activities of potassium canrenoate are associated with increased renal prostaglandin excretion. Clinical Science. 1989;77(2):217-22. Sample size less than 50 patients. [pmid: 2766661].
700 Castellani S, Scarti L, Masotti G, et al. Selective stimulation of renal PGE2 by potassium canrenoate in essential hypertension. Progress in Clinical & Biological Research. 1989;301:297-301. Sample size less than 50 patients. [pmid: 2678128].
701 Castellano M, Beschi M, Agabiti-Rosei E, et al. Renal and hemodynamic effects of atrial natriuretic peptide infusion are not mediated by peripheral dopaminergic mechanisms. American Journal of Hypertension. 1991;4(4 Pt 1):385-8. Not CKD treatment. [pmid: 1829372].
702 Castellino P, Hunt W, DeFronzo RA. Regulation of renal hemodynamics by plasma amino acid and hormone concentrations. Kidney International - Supplement. 1987;22:S15-20. Not relevant to key questions. [pmid: 3323609].
703 Castro-Gonzalez I, Miranda-Becerra D, Montano-Benavides S. Evaluation of phosphorus, protein, and n-3 fatty-acid content in 15 marine fish species identifies the species most beneficial to renal patients. Journal of Renal Nutrition. 2009;19(6):462-8. Not human studies. [pmid: 19818298].
704 Catella-Lawson F, McAdam B, Morrison BW, et al. Effects of specific inhibition of cyclooxygenase-2 on sodium balance, hemodynamics, and vasoactive eicosanoids. Journal of Pharmacology & Experimental Therapeutics. 1999;289(2):735-41. Sample size less than 50 patients. [pmid: 10215647].
705 Cattaneo D, Remuzzi G. Lipid oxidative stress and the anti-inflammatory properties of statins and ACE inhibitors. Journal of Renal Nutrition. 2005;15(1):71-6. Sample size less than 50 patients. [pmid: 15648011].
706 Cattran DC, Alexopoulos E, Heering P, et al. Cyclosporin in idiopathic glomerular disease associated with the nephrotic syndrome: workshop recommendations. Kidney International. 2007;72(12):1429-47. Not RCT or controlled trial. [pmid: 17898700].
707 Cavalcanti AB, Goncalves AR, Almeida CS, et al. Teicoplanin versus vancomycin for proven or suspected infection. Cochrane Database of Systematic Reviews. 2010;(6):CD007022. Not CKD treatment. [pmid: 20556772].
708 Cavaliere G, Arrigo G, D'Amico G, et al. Tubular nephrotoxicity after intravenous urography with ionic high-osmolal and nonionic low-osmolal contrast media in patients with chronic renal insufficiency. Nephron. 1987;46(2):128-33. Sample size less than 50 patients. [pmid: 2885767].
709 Cavatorta A, Buzio C, Pucci F, et al. Effects of antihypertensive drugs on glomerular function in normotensive and hypertensive subjects: hormonal aspects. Journal of Hypertension - Supplement. 1991;9(6):S218-9. Sample size less than 50 patients.
710 Cazzola M. Erythropoietin pathophysiology and erythropoietin deficiency anemia. Hematology Journal. Suppl 3. 2004;5:S100-3. Sample size less than 50 patients. [pmid: 15190288].
711 Celik JB, Gormus N, Topal A, et al. Effect of off-pump and on-pump coronary artery bypass grafting on renal function. Renal Failure. 2005;27(2):183-8. Not RCT or controlled trial. [pmid: 15807183].
712 Centonza L, Castoldi G, Busca G, et al. Behavioural stress blunts the creatinine clearance increase induced by a protein load in healthy subjects. Journal of Nephrology. 2001;14(5):403-9. Not RCT or controlled trial. [pmid: 11730275].
713 Cetina L, Rivera L, Candelaria M, et al. Chemoradiation with gemcitabine for cervical cancer in patients with renal failure. Anti-Cancer Drugs. 2004;15(8):761-6. Not relevant to key questions. [pmid: 15494637].
714 Cetinkaya R, Odabas AR, Selcuk Y. Anti-proteinuric effects of combination therapy with enalapril and losartan in patients with nephropathy due to type 2 diabetes. International Journal of Clinical Practice. 2004;58(5):432-5. Not CKD treatment. [pmid: 15206496].
715 Ceyhan C, Akar H, Tekten T, et al. Microalbuminuria is associated with reduced cardiac cyclic variation of integrated backscatter signal in severe hypertension. Echocardiography. 2004;21(6):495-501. Sample size less than 50 patients. [pmid: 15298684].
716 Chalmers J, Joshi R, Kengne AP, et al. Blood pressure lowering with fixed combination perindopril-indapamide: key findings from ADVANCE. Journal of Hypertension - Supplement. 2008;26(2):S11-5. Not RCT or controlled trial.
717 Chalmers N, Jackson RW. Comparison of iodixanol and iohexol in renal impairment. British Journal of Radiology. 1999;72(859):701-3. Not CKD treatment. [pmid: 10624328].
718 Chan C, Maurer J, Cardella C, et al. A randomized controlled trial of verapamil on cyclosporine nephrotoxicity in heart and lung transplant recipients. Transplantation. 1997;63(10):1435-40. Sample size less than 50 patients. [pmid: 9175807].
719 Chan JC, Cheung CK, Cheung MY, et al. Abnormal albuminuria as a predictor of mortality and renal impairment in Chinese patients with NIDDM. Diabetes Care. 1995;18(7):1013-6. Not RCT or controlled trial. [pmid: 7555533].
720 Chan JC, Critchley JA, Tomlinson B, et al. Antihypertensive and anti-albuminuric effects of losartan potassium and felodipine in Chinese elderly hypertensive patients with or without non-insulin-dependent diabetes mellitus. American Journal of Nephrology. 1997;17(1):72-80. Sample size less than 50 patients. [pmid: 9057957].
721 Chan JC, Ko GT, Leung DH, et al. Long-term effects of angiotensin-converting enzyme inhibition and metabolic control in hypertensive type 2 diabetic patients. Kidney International. 2000;57(2):590-600. Not relevant to key questions. [pmid: 10652036].
722 Chan JCN, Scott R, Arjona Ferreira JC, et al. Safety and efficacy of sitagliptin in patients with type 2 diabetes and chronic renal insufficiency. Diabetes, Obesity & Metabolism. 2008;10(7):545-55. Not CKD treatment.
723 Chan JCN, Wat NMS, So WY, et al. Renin angiotensin aldosterone system blockade and renal disease in patients with type 2 diabetes. An Asian perspective from the RENAAL Study. Diabetes Care. 2004;27(4):874-9. Not relevant to key questions. [pmid: 15047641].
724 Chan MY, Becker RC, Sim LL, et al. Reperfusion strategy and mortality in ST-elevation myocardial infarction among patients with and without impaired renal function. Annals of the Academy of Medicine, Singapore. Mar. 2010;39(3):179-84. Not CKD treatment.
725 Chandra P, Binongo JNG, Ziegler TR, et al. Cholecalciferol (vitamin D3) therapy and vitamin D insufficiency in patients with chronic kidney disease: a randomized controlled pilot study. Endocrine Practice. 2008;14(1):10-7. Not CKD treatment. [pmid: 18238736].
726 Chang GJ, Mahanty HD, Quan D, et al. Experience with the use of sirolimus in liver transplantation--use in patients for whom calcineurin inhibitors are contraindicated. Liver Transplantation. 2000;6(6):734-40. Not early CKD. [pmid: 11084060].
727 Chanu P, Gieschke R, Charoin JE, et al. Population pharmacokinetic/pharmacodynamic model for C.E.R.A. in both ESA-naive and ESA-treated chronic kidney disease patients with renal anemia. Journal of Clinical Pharmacology. May. 2010;50(5):507-20. Not RCT or controlled trial. [pmid: 20179322].
728 Chapman JR, Griffiths D, Harding NG, et al. Reversibility of cyclosporin nephrotoxicity after three months' treatment. Lancet. 1985;1(8421):128-30. Follow-up less than 6 months. [pmid: 2857212].
729 Charloux A, Chaouat A, Piquard F, et al. Renal hyporesponsiveness to brain natriuretic peptide: both generation and renal activity of cGMP are decreased in patients with pulmonary hypertension. Peptides. 2006;27(11):2993-9. Not relevant to key questions. [pmid: 16822585].
730 Chartapisak W, Opastiraku S, Willis NS, et al. Prevention and treatment of renal disease in Henoch-Schonlein purpura: a systematic review. Archives of Disease in Childhood. 2009;94(2):132-7. Not CKD treatment. [pmid: 18701559].
731 Charytan C, Coburn JW, Chonchol M, et al. Cinacalcet hydrochloride is an effective treatment for secondary hyperparathyroidism in patients with CKD not receiving dialysis. American Journal of Kidney Diseases. 2005;46(1):58-67. Follow-up less than 6 months. [pmid: 15983958].
732 Charytan C, Qunibi W, Bailie GR, et al. Comparison of intravenous iron sucrose to oral iron in the treatment of anemic patients with chronic kidney disease not on dialysis. Nephron. 2005;100(3):c55-62. Not RCT or controlled trial. [pmid: 15824508].
733 Charytan D, Forman JP, Cutlip DE. Risk of target lesion revascularization after coronary stenting in patients with and without chronic kidney disease. Nephrology Dialysis Transplantation. 2007;22(9):2578-85. Sample size less than 50 patients.
734 Charytan DM, Kuntz RE, Chhabra A, et al. Relationship of chronic kidney disease to cardiovascular death and myocardial infarction following coronary stenting. Journal of Nephrology. 2006;19(6):764-70. Not early CKD. [pmid: 17173250].
735 Chase HP, Garg SK, Harris S, et al. Angiotensin-converting enzyme inhibitor treatment for young normotensive diabetic subjects: a two-year trial. Annals of Ophthalmology. 1993;25(8):284-9. Sample size less than 50 patients. [pmid: 8239321].
736 Chattington PD, Anderson JV, Rees LH, et al. Atrial natriuretic peptide in type 2 diabetes mellitus: response to a physiological mixed meal and relationship to renal function. Diabetic Medicine. 1998;15(5):375-9. Sample size less than 50 patients. [pmid: 9609358].
737 Chaturvedi N. Modulation of the renin-angiotensin system and retinopathy. Heart. Suppl 1. 2000;84:i29-31. discussion i50. Not relevant to key questions. [pmid: 10956318].
738 Chauveau P, Chadefaux B, Coude M, et al. Long-term folic acid (but not pyridoxine) supplementation lowers elevated plasma homocysteine level in chronic renal failure. Mineral & Electrolyte Metabolism. 1996;22(1-3):106-9. Sample size less than 50 patients. [pmid: 8676798].
739 Chawla V, Greene T, Beck GJ, et al. Hyperlipidemia and long-term outcomes in nondiabetic chronic kidney disease. Clinical Journal of The American Society of Nephrology: CJASN. Sep. 2010;5(9):1582-7. Not relevant to key questions. [pmid: 20558558].
740 Cheer SM, McClellan K. Manidipine: a review of its use in hypertension. Drugs. 2001;61(12):1777-99. Not RCT or controlled trial. [pmid: 11693466].
741 Chellingsworth MC, Kendall MJ. Effects of nifedipine, verapamil and diltiazem on renal function. British Journal of Clinical Pharmacology. 1988;25(5):599-602. Sample size less than 50 patients. [pmid: 3044425].
742 Chemla ES, Morsy M. Randomized clinical trial comparing decellularized bovine ureter with expanded polytetrafluoroethylene for vascular access. British Journal of Surgery. 2009;96(1):34-9. Not CKD treatment. [pmid: 19108001].
743 Chen BH. COX-2 inhibitors and renal function in elderly people. CMAJ Canadian Medical Association Journal. 2000;163(5):604. Not relevant to key questions.
744 Chen BH. Combination treatment effective option for hypertensive, diabetic patients with microalbuminuria. CMAJ Canadian Medical Association Journal. 2001;164(6):861. Not RCT or controlled trial.
745 Chen DT, Wynia MK, Moloney RM, et al. U.S. physician knowledge of the FDA-approved indications and evidence base for commonly prescribed drugs: results of a national survey. Pharmacoepidemiology & Drug Safety. Nov. 2009;18(11):1094-100. Not CKD treatment. [pmid: 19697444].
746 Chen HC, Hsieh MT, Chang SS, et al. Long-term reno-cardiovascular effects of orally administered aconiti tuber in humans. American Journal of Chinese Medicine. 1990;18(1-2):25-33. Not CKD treatment. [pmid: 2239812].
747 Chen HH, Redfield MM, Nordstrom LJ, et al. Angiotensin II AT1 receptor antagonism prevents detrimental renal actions of acute diuretic therapy in human heart failure. American Journal of Physiology - Renal Physiology. 2003;284(5):F1115-9. Sample size less than 50 patients. [pmid: 12676739].
748 Chen HH, Sundt TM, Cook DJ, et al. Low dose nesiritide and the preservation of renal function in patients with renal dysfunction undergoing cardiopulmonary-bypass surgery: a double-blind placebo-controlled pilot study. Circulation. 2007;116(11 Suppl):I134-8. Follow-up less than 6 months. [pmid: 17846293].
749 Chen HH, Tarng DC, Lee KF, et al. Epoetin alfa and darbepoetin alfa: effects on ventricular hypertrophy in patients with chronic kidney disease. Journal of Nephrology. 2008;21(4):543-9. Not CKD treatment. [pmid: 18651544].
750 Chen HX. Expanding the clinical development of bevacizumab. Oncologist. Suppl 1. 2004;9:27-35. Not CKD treatment. [pmid: 15178813].
751 Chen JLT, Lerner D, Ruthazer R, et al. Association of physical activity with mortality in chronic kidney disease. Journal of Nephrology. 2008;21(2):243-52. Not early CKD. [pmid: 18446720].
752 Chen SL, Zhang J, Yei F, et al. Clinical outcomes of contrast-induced nephropathy in patients undergoing percutaneous coronary intervention: a prospective, multicenter, randomized study to analyze the effect of hydration and acetylcysteine. International Journal of Cardiology. 2008;126(3):407-13. Not CKD treatment. [pmid: 17651830].
753 Chen X, Zheng F, Chen P, et al. An open-label, randomized, controlled, 4-week comparative clinical trial of barnidipine hydrochloride, a calcium-channel blocker, and benazepril, an angiotensin-converting enzyme inhibitor, in Chinese patients with renal parenchymal hypertension. Journal of International Medical Research. 2006;34(2):121-8. Not CKD treatment. [pmid: 16749407].
754 Chen Y, Lipkowitz MS, Salem RM, et al. Progression of chronic kidney disease: Adrenergic genetic influence on glomerular filtration rate decline in hypertensive nephrosclerosis. American Journal of Nephrology. 2010;32(1):23-30. Not relevant to key questions. [pmid: 20484896].
755 Cheng HC, Kao AW, Chuang CH, et al. The efficacy of high- and low-dose intravenous omeprazole in preventing rebleeding for patients with bleeding peptic ulcers and comorbid illnesses. Digestive Diseases & Sciences. 2005;50(7):1194-201. Not RCT or controlled trial. [pmid: 16047459].
756 Cheng IK, Lam KS, Janus ED, et al. Treatment of hyperlipidaemia in patients with non-insulin-dependent diabetes mellitus with progressive nephropathy. Contributions to Nephrology. 1997;120:79-87. Not RCT or controlled trial. [pmid: 9257050].
757 Cheng IK, Ma JT, Yeh GR, et al. Comparison of captopril and enalapril in the treatment of hypertension in patients with non-insulin dependent diabetes mellitus and nephropathy. International Urology & Nephrology. 1990;22(3):295-303. Sample size less than 50 patients. [pmid: 2210987].
758 Cheng JWM. Ambrisentan for the management of pulmonary arterial hypertension. Clinical Therapeutics. 2008;30(5):825-33. Not RCT or controlled trial. [pmid: 18555930].
759 Cheng S, Coyne D. Paricalcitol capsules for the control of secondary hyperparathyroidism in chronic kidney disease. Expert Opinion on Pharmacotherapy. 2006;7(5):617-21. Not relevant to key questions. [pmid: 16553577].
760 Cheng YF, Strid S, Borga O, et al. Active renal secretion of NXY-059, a novel neuroprotectant, is mediated via an organic acid transporter. Journal of Clinical Pharmacology. 2007;47(7):909-14. Sample size less than 50 patients. [pmid: 17585119].
761 Chen-Scarabelli C, Scarabelli TM. Chronic renal insufficiency is an independent predictor of mortality in implantable cardioverter-defibrillator recipients. Pacing & Clinical Electrophysiology. 2007;30(3):371-6. Not RCT or controlled trial. [pmid: 17367356].
762 Chernausek SD, Backeljauw PF, Frane J, et al. Long-term treatment with recombinant insulin-like growth factor (IGF)-I in children with severe IGF-I deficiency due to growth hormone insensitivity. Journal of Clinical Endocrinology & Metabolism. 2007;92(3):902-10. Not human studies. [pmid: 17192294].
763 Cherney DZI, Miller JA, Scholey JW, et al. The effect of cyclooxygenase-2 inhibition on renal hemodynamic function in humans with type 1 diabetes. Diabetes. 2008;57(3):688-95. Not RCT or controlled trial. [pmid: 18083781].
764 Chertow GM, Dillon M, Burke SK, et al. A randomized trial of sevelamer hydrochloride (RenaGel) with and without supplemental calcium. Strategies for the control of hyperphosphatemia and hyperparathyroidism in hemodialysis patients. Clinical Nephrology. 1999;51(1):18-26. Not early CKD. [pmid: 9988142].
765 Cheung R, Lewanczuk RZ, Rodger NW, et al. The effect of valsartan and captopril on lipid parameters in patients with type II diabetes mellitus and nephropathy. International Journal of Clinical Practice. 1999;53(8):584-92. Not CKD treatment. [pmid: 10692751].
766 Chew DP, Bhatt DL, Kimball W, et al. Bivalirudin provides increasing benefit with decreasing renal function: a meta-analysis of randomized trials. American Journal of Cardiology. 2003;92(8):919-23. Not CKD treatment. [pmid: 14556866].
767 Chew DP, Lincoff AM, Gurm H, et al. Bivalirudin versus heparin and glycoprotein IIb/IIIa inhibition among patients with renal impairment undergoing percutaneous coronary intervention (a subanalysis of the REPLACE-2 trial). American Journal of Cardiology. 2005;95(5):581-5. Sample size less than 50 patients. [pmid: 15721095].
768 Chi Y. Multiple testing procedures based on weighted Kaplan-Meier statistics for right-censored survival data. Statistics in Medicine. 2005;24(1):23-35. Not CKD treatment. [pmid: 15515153].
769 Chiarelli F, Di Marzio D, Santilli F, et al. Effects of irbesartan on intracellular antioxidant enzyme expression and activity in adolescents and young adults with early diabetic angiopathy. Diabetes Care. 2005;28(7):1690-7. Follow-up less than 6 months. [pmid: 15983321].
770 Chin HJ, Song YR, Lee JJ, et al. Moderately decreased renal function negatively affects the health-related quality of life among the elderly Korean population: a population-based study. Nephrology Dialysis Transplantation. 2008;23(9):2810-7. Not CKD treatment.
771 Chiolero A, Maillard M, Nussberger J, et al. Proximal sodium reabsorption: An independent determinant of blood pressure response to salt. Hypertension. 2000;36(4):631-7. Sample size less than 50 patients. [pmid: 11040249].
772 Chiurchiu C, Remuzzi G, Ruggenenti P. Angiotensin-converting enzyme inhibition and renal protection in nondiabetic patients: the data of the meta-analyses. Journal of the American Society of Nephrology. Suppl 1. 2005;16:S58-63. Not relevant to key questions. [pmid: 15938036].
773 Chmielewski M, Carrero JJ, Nordfors L, et al. Lipid disorders in chronic kidney disease: reverse epidemiology and therapeutic approach. Journal of Nephrology. 2008;21(5):635-44. Not early CKD. [pmid: 18949717].
774 Chmielewski M, Carrero JJ, Stenvinkel P, et al. Metabolic abnormalities in chronic kidney disease that contribute to cardiovascular disease, and nutritional initiatives that may diminish the risk. Current Opinion in Lipidology. 2009;20(1):3-9. Follow-up less than 6 months. [pmid: 19133406].
775 Cho HY, Blum RA, Sunderland T, et al. Pharmacokinetic and pharmacodynamic modeling of a copper-selective chelator (TETA) in healthy adults. Journal of Clinical Pharmacology. 2009;49(8):916-28. Not CKD treatment. [pmid: 19602718].
776 Cho JE, Shim JK, Chang JH, et al. Effect of nicardipine on renal function after robot-assisted laparoscopic radical prostatectomy. Urology. 2009;73(5):1056-60. Not CKD treatment. [pmid: 19394503].
777 Chodjania Y, Tharaux PL, Ragueneau I, et al. Renal and vascular effects of S21402, a dual inhibitor of angiotensin-converting enzyme and neutral endopeptidase, in healthy subjects with hypovolemia. Clinical Pharmacology & Therapeutics. 2002;71(6):468-78. Sample size less than 50 patients. [pmid: 12087350].
778 Choi KC, Lee J, Kim SW, et al. Cimetidine improves the accuracy of creatinine clearance as an indicator for glomerular filtration rate. Korean Journal of Internal Medicine. 1993;8(1):28-33. Sample size less than 50 patients. [pmid: 8268144].
779 Choi KL, Elliott WJ. Antihypertensive, antiproteinuric therapy and myocardial infarction and stroke prevention. Current Hypertension Reports. 2005;7(5):367-73. Follow-up less than 6 months. [pmid: 16157081].
780 Chonchol M, Goldenberg I, Moss AJ, et al. Risk factors for sudden cardiac death in patients with chronic renal insufficiency and left ventricular dysfunction. American Journal of Nephrology. 2007;27(1):7-14. Follow-up less than 6 months. [pmid: 17204832].
781 Choudhury D, Tuncel M, Levi M. Disorders of lipid metabolism and chronic kidney disease in the elderly. Seminars in Nephrology. Nov. 2009;29(6):610-20. Not RCT or controlled trial. [pmid: 20006793].
782 Christensen CK, Christiansen JS, Christensen T, et al. The effect of six months continuous subcutaneous insulin infusion on kidney function and size in insulin-dependent diabetics. Diabetic Medicine. 1986;3(1):29-32. Sample size less than 50 patients. [pmid: 2951131].
783 Christensen CK, Christiansen JS, Schmitz A, et al. Effect of continuous subcutaneous insulin infusion on kidney function and size in IDDM patients: a 2 year controlled study. Journal of Diabetic Complications. 1987;1(3):91-5. Sample size less than 50 patients. [pmid: 2969912].
784 Christensen CK, Krusell LR. Acute and long-term effect of antihypertensive treatment on exercise induced microalbuminuria in essential hypertension. Journal of Clinical Hypertension. 1987;3(4):704-12. Sample size less than 50 patients. [pmid: 3134518].
785 Christensen CK, Mogensen CE. Acute and long-term effect of antihypertensive treatment on exercise-induced albuminuria in incipient diabetic nephropathy. Scandinavian Journal of Clinical & Laboratory Investigation. 1986;46(6):553-9. Sample size less than 50 patients. [pmid: 3535002].
786 Christensen PK, Akram K, Konig KB, et al. Autoregulation of glomerular filtration rate in patients with type 2 diabetes during isradipine therapy. Diabetes Care. 2003;26(1):156-62. Sample size less than 50 patients. [pmid: 12502673].
787 Christensen PK, Hansen HP, Parving HH. Impaired autoregulation of GFR in hypertensive non-insulin dependent diabetic patients. Kidney International. 1997;52(5):1369-74. Sample size less than 50 patients. [pmid: 9350661].
788 Christensen PK, Hommel EE, Clausen P, et al. Impaired autoregulation of the glomerular filtration rate in patients with nondiabetic nephropathies. Kidney International. 1999;56(4):1517-23. Sample size less than 50 patients. [pmid: 10504503].
789 Christensen PK, Lund S, Parving HH. Autoregulated glomerular filtration rate during candesartan treatment in hypertensive type 2 diabetic patients. Kidney International. 2001;60(4):1435-42. Sample size less than 50 patients. [pmid: 11576357].
790 Christensen PK, Lund S, Parving HH. The impact of glycaemic control on autoregulation of glomerular filtration rate in patients with non-insulin dependent diabetes. Scandinavian Journal of Clinical & Laboratory Investigation. 2001;61(1):43-50. Sample size less than 50 patients. [pmid: 11300610].
791 Christiansen H, Segura J, Ruilope LM. Renal endpoints in hypertension trials. Clinical & Experimental Hypertension. 2004;26(7-8):721-6. Not relevant to key questions. [pmid: 15702626].
792 Christiansen JS, Feldt-Rasmussen B, Parving HH. Short-term inhibition of prostaglandin synthesis has no effect on the elevated glomerular filtration rate of early insulin-dependent diabetes. Diabetic Medicine. 1985;2(1):17-20. Sample size less than 50 patients. [pmid: 2951060].
793 Chrysant SG. Angiotensin II receptor blockers in the treatment of the cardiovascular disease continuum. Clinical Therapeutics. 2008;30 Pt 2:2181-90. Not CKD treatment. [pmid: 19281913].
794 Chrysant SG, Chrysant GS. Pharmacological and clinical profile of moexipril: a concise review. Journal of Clinical Pharmacology. 2004;44(8):827-36. Not CKD treatment. [pmid: 15286086].
795 Chrysochou C, Kalra PA. Current management of atherosclerotic renovascular disease--what have we learned from ASTRAL?. Nephron. 2010;115(1):c73-81. Not RCT or controlled trial. [pmid: 20185934].
796 Chrysostomou A, Pedagogos E, MacGregor L, et al. Double-blind, placebo-controlled study on the effect of the aldosterone receptor antagonist spironolactone in patients who have persistent proteinuria and are on long-term angiotensin-converting enzyme inhibitor therapy, with or without an angiotensin II receptor blocker. Clinical Journal of The American Society of Nephrology: CJASN. 2006;1(2):256-62. Not RCT or controlled trial. [pmid: 17699214].
797 Chu D, Lacouture ME, Fillos T, et al. Risk of hand-foot skin reaction with sorafenib: a systematic review and meta-analysis. Acta Oncologica. 2008;47(2):176-86. Not CKD treatment. [pmid: 18210295].
798 Chuang FR, Chen TC, Wang IK, et al. Comparison of iodixanol and iohexol in patients undergoing intravenous pyelography: a prospective controlled study. Renal Failure. 2009;31(3):181-8. Not CKD treatment. [pmid: 19288321].
799 Chuang LM, Jou TS, Wu HP, et al. Effect of treatment of borderline hypertension on microalbuminuria in non-insulin-dependent diabetes mellitus. Journal of the Formosan Medical Association. 1991;90(6):531-5. Not relevant to key questions. [pmid: 1680996].
800 Chung FM, Yang YH, Shieh TY, et al. Effect of alcohol consumption on estimated glomerular filtration rate and creatinine clearance rate. Nephrology Dialysis Transplantation. 2005;20(8):1610-6. Follow-up less than 6 months.
801 Cianciaruso B, Pota A, Bellizzi V, et al. Effect of a low- versus moderate-protein diet on progression of CKD: follow-up of a randomized controlled trial. American Journal of Kidney Diseases. 2009;54(6):1052-61. Not early CKD. [pmid: 19800722].
802 Cianciaruso B, Pota A, Bellizzi V, et al. Effect of a low- versus moderate-protein diet on progression of CKD: follow-up of a randomized controlled trial. American Journal of Kidney Diseases. 2009;54(6):1052-61. Not early CKD. [pmid: 19800722].
803 Cianciaruso B, Pota A, Pisani A, et al. Metabolic effects of two low protein diets in chronic kidney disease stage 4-5--a randomized controlled trial. Nephrology Dialysis Transplantation. 2008;23(2):636-44. Not RCT or controlled trial.
804 Cianciaruso B, Ravani P, Barrett BJ, et al. Italian randomized trial of hemoglobin maintenance to prevent or delay left ventricular hypertrophy in chronic kidney disease. Journal of Nephrology. 2008;21(6):861-70. Follow-up less than 6 months. [pmid: 19034870].
805 Cianciolo G, La Manna G, Coli L, et al. 5-methyltetrahydrofolate administration is associated with prolonged survival and reduced inflammation in ESRD patients. American Journal of Nephrology. 2008;28(6):941-8. Not early CKD. [pmid: 18587236].
806 Cianciolo G, La Manna G, Coli L, et al. 5-methyltetrahydrofolate administration is associated with prolonged survival and reduced inflammation in ESRD patients. American Journal of Nephrology. 2008;28(6):941-8. Not RCT or controlled trial. [pmid: 18587236].
807 Ciavarella A, Di Mizio G, Stefoni S, et al. Reduced albuminuria after dietary protein restriction in insulin-dependent diabetic patients with clinical nephropathy. Diabetes Care. 1987;10(4):407-13. Sample size less than 50 patients. [pmid: 3622197].
808 Ciavarella A, Vannini P, Flammini M, et al. Effect of long-term near-normoglycemia on the progression of diabetic nephropathy. Diabete et Metabolisme. 1985;11(1):3-8. Sample size less than 50 patients. [pmid: 3884404].
809 Ciavarella D. The use of protein A columns in the treatment of cancer and allied diseases. International Journal of Clinical & Laboratory Research. 1992;21(3):210-3. Not CKD treatment. [pmid: 1591370].
810 Cicconetti A, Bartoli A, Ripari F, et al. COX-2 selective inhibitors: a literature review of analgesic efficacy and safety in oral-maxillofacial surgery. Oral Surgery Oral Medicine Oral Pathology Oral Radiology & Endodontics. 2004;97(2):139-46. Not CKD treatment.
811 Cicek M, Koroglu A, Demirbilek S, et al. Comparison of propofol-alfentanil and propofol-remifentanil anaesthesia in percutaneous nephrolithotripsy. European Journal of Anaesthesiology. 2005;22(9):683-8. Not RCT or controlled trial. [pmid: 16163915].
812 Cicinnati VR, Yu Z, Klein CG, et al. Clinical trial: switch to combined mycophenolate mofetil and minimal dose calcineurin inhibitor in stable liver transplant patients--assessment of renal and allograft function, cardiovascular risk factors and immune monitoring. Alimentary Pharmacology & Therapeutics. 2007;26(9):1195-208. Sample size less than 50 patients. [pmid: 17944734].
813 Cifkova R, Nilsson PM. Statins and hypertension. Journal of Hypertension. 2009;27(3):662-5. Sample size less than 50 patients. [pmid: 19262236].
814 Cinquegrani MP, Liang CS. Indomethacin attenuates the hypotensive action of hydralazine. Clinical Pharmacology & Therapeutics. 1986;39(5):564-70. Sample size less than 50 patients. [pmid: 3698464].
815 Claas GJ, Julg B, Goebel FD, et al. Metabolic and anthropometric changes one year after switching from didanosine/stavudine to tenofovir in HIV-infected patients. European Journal of Medical Research. 2007;12(2):54-60. Sample size less than 50 patients. [pmid: 17369118].
816 Claria J, Kent JD, Lopez-Parra M, et al. Effects of celecoxib and naproxen on renal function in nonazotemic patients with cirrhosis and ascites. Hepatology. 2005;41(3):579-87. Not RCT or controlled trial. [pmid: 15723448].
817 Claris-Appiani A, Assael BM, Tirelli AS, et al. Lack of glomerular hemodynamic stimulation after infusion of branched-chain amino acids. Kidney International. 1988;33(1):91-4. Sample size less than 50 patients. [pmid: 3352163].
818 Clark WF, Forzley BR, Sontrop JM, et al. TTP/HUS: observational studies generate hypotheses that lead to randomized controlled trials. Kidney International - Supplement. 2009;(112):S50-1. Not early CKD. [pmid: 19180136].
819 Clarke WL. The Diabetes Control and Complications Trial: new challenges for the primary physician. Virginia Medical Quarterly. 1994;121(3):185-8. Not RCT or controlled trial. [pmid: 8061070].
820 Clasen W, Khartabil T, Imm S, et al. Torasemide for diuretic treatment of advanced chronic renal failure. Arzneimittel-Forschung. 1988;38(1A):209-11. Sample size less than 50 patients. [pmid: 3285836].
821 Clavijo LC, Pinto TL, Kuchulakanti PK, et al. Effect of a rapid intra-arterial infusion of dextrose 5% prior to coronary angiography on frequency of contrast-induced nephropathy in high-risk patients. American Journal of Cardiology. 2006;97(7):981-3. Not CKD treatment. [pmid: 16563900].
822 Cleland JG, Dargie HJ, Gillen G, et al. Captopril in heart failure: a double-blind study of the effects on renal function. Journal of Cardiovascular Pharmacology. 1986;8(4):700-6. Sample size less than 50 patients. [pmid: 2427807].
823 Cleland JG, Dargie HJ, Pettigrew A, et al. The effects of captopril on serum digoxin and urinary urea and digoxin clearances in patients with congestive heart failure. American Heart Journal. 1986;112(1):130-5. Sample size less than 50 patients. [pmid: 3524169].
824 Cleland JG, Gillen G, Dargie HJ. The effects of frusemide and angiotensin-converting enzyme inhibitors and their combination on cardiac and renal haemodynamics in heart failure. European Heart Journal. 1988;9(2):132-41. Sample size less than 50 patients. [pmid: 2832173].
825 Cleland JG, Shah D, Krikler S, et al. Effects of lisinopril on cardiorespiratory, neuroendocrine, and renal function in patients with asymptomatic left ventricular dysfunction. British Heart Journal. 1993;69(6):512-5. Follow-up less than 6 months. [pmid: 8393685].
826 Cleland JG, Shah D, Krikler S, et al. Angiotensin-converting enzyme inhibitors, left ventricular dysfunction, and early heart failure. American Journal of Cardiology. 1992;70(10):55C-61C. Sample size less than 50 patients.
827 Clement JG, Bailey DG, Madill HD, et al. The acetylcholinesterase oxime reactivator HI-6 in man: pharmacokinetics and tolerability in combination with atropine. Biopharmaceutics & Drug Disposition. 1995;16(5):415-25. Sample size less than 50 patients.
828 Cleveringa FGW, Welsing PMJ, van den Donk M, et al. Cost-effectiveness of the diabetes care protocol, a multifaceted computerized decision support diabetes management intervention that reduces cardiovascular risk. Diabetes Care. 2010;33(2):258-63. Not CKD treatment. [pmid: 19933991].
829 Clifton GG, Cook ME, Poland M, et al. The renal function and blood pressure effects of dilevalol in the normotensive and hypertensive elderly. Journal of Clinical Pharmacology. 1989;29(7):603-8. Sample size less than 50 patients. [pmid: 2760254].
830 Clifton GG, Cook ME, Wallin JD. Effects of dilevalol on renal function. American Journal of Cardiology. 1989;63(19):75I-8I. Sample size less than 50 patients.
831 Clyne N, Jogestrand T. Effect of erythropoietin treatment on physical exercise capacity and on renal function in predialytic uremic patients. Nephron. 1992;60(4):390-6. Not early CKD. [pmid: 1584314].
832 Coburn JW, Maung HM. Use of active vitamin D sterols in patients with chronic kidney disease, stages 3 and 4. Kidney International - Supplement. 2003;(85):S49-53. Not early CKD. [pmid: 12753265].
833 Coburn JW, Maung HM, Elangovan L, et al. Doxercalciferol safely suppresses PTH levels in patients with secondary hyperparathyroidism associated with chronic kidney disease stages 3 and 4. American Journal of Kidney Diseases. 2004;43(5):877-90. Not CKD treatment. [pmid: 15112179].
834 Coca A. Manidipine plus delapril in patients with Type 2 diabetes and hypertension: reducing cardiovascular risk and end-organ damage. Expert Review of Cardiovascular Therapy. 2007;5(2):147-59. Not RCT or controlled trial. [pmid: 17338661].
835 Coca SG. Acute kidney injury in elderly persons. American Journal of Kidney Diseases. Jul. 2010;56(1):122-31. Not RCT or controlled trial. [pmid: 20346560].
836 Coca SG. Long-term outcomes of acute kidney injury. Current Opinion in Nephrology & Hypertension. May. 2010;19(3):266-72. Not RCT or controlled trial. [pmid: 20164766].
837 Cochrane R, Regan L. Undetected gynaecological disorders in women with renal disease. Human Reproduction. 1997;12(4):667-70. Not early CKD. [pmid: 9159421].
838 Coco M, Glicklich D, Faugere MC, et al. Prevention of bone loss in renal transplant recipients: a prospective, randomized trial of intravenous pamidronate. Journal of the American Society of Nephrology. 2003;14(10):2669-76. Not early CKD. [pmid: 14514747].
839 Cody J, Daly C, Campbell M, et al. Recombinant human erythropoietin for chronic renal failure anaemia in pre-dialysis patients. Cochrane Database of Systematic Reviews. 2001;(4):CD003266. Not CKD treatment. [pmid: 11687180].
840 Cody J, Daly C, Campbell M, et al. Recombinant human erythropoietin for chronic renal failure anaemia in pre-dialysis patients. Cochrane Database of Systematic Reviews. 2005;(3):CD003266. Not relevant to key questions. [pmid: 16034896].
841 Coen G, Mazzaferro S, Bonucci E, et al. Bone GLA protein in predialysis chronic renal failure. Effects of 1,25(OH)2D3 administration in a long-term follow-up. Kidney International. 1985;28(5):783-90. Sample size less than 50 patients. [pmid: 3878905].
842 Coggins CH, Breyer Lewis J, Caggiula AW, et al. Differences between women and men with chronic renal disease. Nephrology Dialysis Transplantation. 1998;13(6):1430-7. Not relevant to key questions.
843 Coggins CH, Dwyer JT, Greene T, et al. Serum lipid changes associated with modified protein diets: results from the feasibility phase of the Modification of Diet in Renal Disease Study. American Journal of Kidney Diseases. 1994;23(4):514-23. Not RCT or controlled trial. [pmid: 8154486].
844 Cogliati AA, Vellutini R, Nardini A, et al. Fenoldopam infusion for renal protection in high-risk cardiac surgery patients: a randomized clinical study. Journal of Cardiothoracic & Vascular Anesthesia. 2007;21(6):847-50. Not RCT or controlled trial. [pmid: 18068064].
845 Cohen AF, Harkin N, Posner J. Cardiovascular effects of a novel enkephalin analogue, 443C81, in humans. Journal of Cardiovascular Pharmacology. 1990;16(3):455-60. Not CKD treatment. [pmid: 1700218].
846 Cohen D, Dodds R, Viberti G. Effect of protein restriction in insulin dependent diabetics at risk of nephropathy. British Medical Journal Clinical Research Ed. 1987;294(6575):795-8. Sample size less than 50 patients. [pmid: 3105747].
847 Cohen E, Hafner R, Rotenberg Z, et al. Comparison of ketorolac and diclofenac in the treatment of renal colic. European Journal of Clinical Pharmacology. 1998;54(6):455-8. Not CKD treatment. [pmid: 9776434].
848 Cohen EP, Irving AA, Drobyski WR, et al. Captopril to mitigate chronic renal failure after hematopoietic stem cell transplantation: a randomized controlled trial. International Journal of Radiation Oncology, Biology, Physics. 2008;70(5):1546-51. Not CKD treatment.
849 Cohen JA, Jeffers BW, Stabler S, et al. Increasing homocysteine levels and diabetic autonomic neuropathy. Autonomic Neuroscience-Basic & Clinical. 2001;87(2-3):268-73. Not early CKD.
850 Cohen SD, Norris L, Acquaviva K, et al. Screening, diagnosis, and treatment of depression in patients with end-stage renal disease. Clinical Journal of The American Society of Nephrology: CJASN. 2007;2(6):1332-42. Not relevant to key questions. [pmid: 17942763].
851 Cole RS, Palfrey EL, Smith SE, et al. Indomethacin as prophylaxis against ureteral colic following extracorporeal shock wave lithotripsy. Journal of Urology. 1989;141(1):9-12. Not CKD treatment. [pmid: 2635871].
852 Collins AC, Vincent J, Newall RG, et al. An aid to the early detection and management of diabetic nephropathy: assessment of a new point of care microalbuminuria system in the diabetic clinic. Diabetic Medicine. 2001;18(11):928-32. Not CKD treatment. [pmid: 11703439].
853 Colson P, Capdevilla X, Barlet H, et al. Effects of halothane and isoflurane on transient renal dysfunction associated with infrarenal aortic cross-clamping. Journal of Cardiothoracic & Vascular Anesthesia. 1992;6(3):295-8. Not CKD treatment. [pmid: 1610994].
854 Colson P, Capdevilla X, Cuchet D, et al. Does choice of the anesthetic influence renal function during infrarenal aortic surgery?. Anesthesia & Analgesia. 1992;74(4):481-5. Not CKD treatment. [pmid: 1554112].
855 Colson P, Ribstein J, Mimran A, et al. Effect of angiotensin converting enzyme inhibition on blood pressure and renal function during open heart surgery. Anesthesiology. 1990;72(1):23-7. Not CKD treatment. [pmid: 2404429].
856 Colson P, Ribstein J, Seguin JR, et al. Mechanisms of renal hemodynamic impairment during infrarenal aortic cross-clamping. Anesthesia & Analgesia. 1992;75(1):18-23. Not CKD treatment. [pmid: 1616156].
857 Coltamai L, Maillard M, Simon A, et al. Comparative vascular and renal tubular effects of angiotensin II receptor blockers combined with a thiazide diuretic in humans. Journal of Hypertension. Mar. 2010;28(3):520-6. Follow-up less than 6 months. [pmid: 20104189].
858 Compton A. A practical cost analysis of bivalirudin. Pharmacotherapy. 2002;22(6 Pt 2):119S-27S. Not early CKD. [pmid: 12064569].
859 Conant EF, Fox KR, Miller WT. Pulmonary edema as a complication of interleukin-2 therapy. AJR. American Journal of Roentgenology. 1989;152(4):749-52. Sample size less than 50 patients. [pmid: 2784257].
860 Conen D, Buerkle G, Perruchoud AP, et al. Hypertension is an independent risk factor for contrast nephropathy after percutaneous coronary intervention. International Journal of Cardiology. 2006;110(2):237-41. Sample size less than 50 patients. [pmid: 16298441].
861 Conen D, Glynn RJ, Buring JE, et al. Association of renin-angiotensin and endothelial nitric oxide synthase gene polymorphisms with blood pressure progression and incident hypertension: prospective cohort study. Journal of Hypertension. 2008;26(9):1780-6. Not RCT or controlled trial. [pmid: 18698212].
862 Conil JM, Georges B, Fourcade O, et al. Intermittent administration of ceftazidime to burns patients: influence of glomerular filtration. International Journal of Clinical Pharmacology & Therapeutics. 2007;45(3):133-42. Not RCT or controlled trial. [pmid: 17416108].
863 Connell JM, Whitworth JA, Davies DL, et al. Effects of ACTH and cortisol administration on blood pressure, electrolyte metabolism, atrial natriuretic peptide and renal function in normal man. Journal of Hypertension. 1987;5(4):425-33. Sample size less than 50 patients. [pmid: 2822795].
864 Constantiner M, Sehgal AR, Humbert L, et al. A dipstick protein and specific gravity algorithm accurately predicts pathological proteinuria. American Journal of Kidney Diseases. 2005;45(5):833-41. Not relevant to key questions. [pmid: 15861348].
865 Conte G, Dal Canton A, Imperatore P, et al. Acute increase in plasma osmolality as a cause of hyperkalemia in patients with renal failure. Kidney International. 1990;38(2):301-7. Sample size less than 50 patients. [pmid: 2402122].
866 Contreras F, de la Parte MA, Cabrera J, et al. Role of angiotensin II AT1 receptor blockers in the treatment of arterial hypertension. American Journal of Therapeutics. 2003;10(6):401-8. Not CKD treatment. [pmid: 14624277].
867 Contreras G, Greene T, Agodoa LY, et al. Blood pressure control, drug therapy, and kidney disease. Hypertension. 2005;46(1):44-50. Not early CKD. [pmid: 15897360].
868 Contreras I, Reiser KM, Martinez N, et al. Effects of aspirin or basic amino acids on collagen cross-links and complications in NIDDM. Diabetes Care. 1997;20(5):832-5. Follow-up less than 6 months. [pmid: 9135951].
869 Conway SP, Pond MN, Watson A, et al. Intravenous colistin sulphomethate in acute respiratory exacerbations in adult patients with cystic fibrosis. Thorax. 1997;52(11):987-93. Not CKD treatment. [pmid: 9487348].
870 Conzen PF, Kharasch ED, Czerner SFA, et al. Low-flow sevoflurane compared with low-flow isoflurane anesthesia in patients with stable renal insufficiency. Anesthesiology. 2002;97(3):578-84. Not CKD treatment. [pmid: 12218523].
871 Conzen PF, Nuscheler M, Melotte A, et al. Renal function and serum fluoride concentrations in patients with stable renal insufficiency after anesthesia with sevoflurane or enflurane. Anesthesia & Analgesia. 1995;81(3):569-75. Sample size less than 50 patients. [pmid: 7653825].
872 Cook DJ, Crowther MA. Thromboprophylaxis in the intensive care unit: focus on medical-surgical patients. Critical Care Medicine. 2010;38(2 Suppl):S76-82. Not RCT or controlled trial. [pmid: 20083918].
873 Cook ME, Wallin JD, Clifton GG, et al. Renal function effects of dilevalol, a nonselective beta-adrenergic blocking drug with beta-2 agonist activity. Clinical Pharmacology & Therapeutics. 1988;43(4):393-9. Not relevant to key questions. [pmid: 3356083].
874 Cook ME, Wallin JD, Thakur VD, et al. Comparative effects of nabumetone, sulindac, and ibuprofen on renal function. Journal of Rheumatology. 1997;24(6):1137-44. Sample size less than 50 patients. [pmid: 9195523].
875 Cook RJ, Neerhut R, Thomas DG. Does combined epidural lignocaine and fentanyl provide better anaesthesia for ESWL than lignocaine alone?. Anaesthesia & Intensive Care. 1991;19(3):357-64. Not CKD treatment. [pmid: 1767903].
876 Cooper ME. Renal protection and angiotensin converting enzyme inhibition in microalbuminuric type I and type II diabetic patients. Journal of Hypertension - Supplement. 1996;14(6):S11-4. Not RCT or controlled trial.
877 Copley JB, Rosario R. Hypertension: a review and rationale of treatment. Disease-A-Month. 2005;51(10-11):548-614. Follow-up less than 6 months. [pmid: 16360376].
878 Cordell WH, Larson TA, Lingeman JE, et al. Indomethacin suppositories versus intravenously titrated morphine for the treatment of ureteral colic. Annals of Emergency Medicine. 1994;23(2):262-9. Not CKD treatment. [pmid: 8304606].
879 Cordell WH, Wright SW, Wolfson AB, et al. Comparison of intravenous ketorolac, meperidine, and both (balanced analgesia) for renal colic. Annals of Emergency Medicine. 1996;28(2):151-8. Not CKD treatment. [pmid: 8759578].
880 Cordonnier DJ, Pinel N, Barro C, et al. Expansion of cortical interstitium is limited by converting enzyme inhibition in type 2 diabetic patients with glomerulosclerosis. The Diabiopsies Group. Journal of the American Society of Nephrology. 1999;10(6):1253-63. Sample size less than 50 patients. [pmid: 10361863].
881 Coresh J, Astor BC, McQuillan G, et al. Calibration and random variation of the serum creatinine assay as critical elements of using equations to estimate glomerular filtration rate. American Journal of Kidney Diseases. 2002;39(5):920-9. Not RCT or controlled trial. [pmid: 11979335].
882 Coresh J, Toto RD, Kirk KA, et al. Creatinine clearance as a measure of GFR in screenees for the African-American Study of Kidney Disease and Hypertension pilot study. American Journal of Kidney Diseases. 1998;32(1):32-42. Not CKD treatment. [pmid: 9669421].
883 Cornish SM, Candow DG, Jantz NT, et al. Conjugated linoleic acid combined with creatine monohydrate and whey protein supplementation during strength training. International Journal of Sport Nutrition & Exercise Metabolism. 2009;19(1):79-96. Not CKD treatment. [pmid: 19403955].
884 Cortes-Sanabria L, Cabrera-Pivaral CE, Cueto-Manzano AM, et al. Improving care of patients with diabetes and CKD: a pilot study for a cluster-randomized trial. American Journal of Kidney Diseases. 2008;51(5):777-88. Not CKD treatment. [pmid: 18436088].
885 Cosenzi A, Carraro M, Sacerdote A, et al. Nifedipine reduces postexercise proteinuria in young volunteers. Renal Physiology & Biochemistry. 1995;18(6):306-10. Sample size less than 50 patients. [pmid: 8711268].
886 Cosgrove SE, Vigliani GA, Fowler VG Jr., et al. Initial low-dose gentamicin for Staphylococcus aureus bacteremia and endocarditis is nephrotoxic. Clinical Infectious Diseases. 2009;48(6):713-21. Not RCT or controlled trial. [pmid: 19207079].
887 Cosman F, Nieves J, Herbert J, et al. High-dose glucocorticoids in multiple sclerosis patients exert direct effects on the kidney and skeleton. Journal of Bone & Mineral Research. 1994;9(7):1097-105. Not CKD treatment. [pmid: 7942157].
888 Costa P, Ottino GM, Matani A, et al. Low-dose dopamine during cardiopulmonary bypass in patients with renal dysfunction. Journal of Cardiothoracic Anesthesia. 1990;4(4):469-73. Sample size less than 50 patients. [pmid: 2132343].
889 Costa S, Nucci M. Can we decrease amphotericin nephrotoxicity?. Current Opinion in Critical Care. 2001;7(6):379-83. Not early CKD. [pmid: 11805538].
890 Costello-Boerrigter LC, Smith WB, Boerrigter G, et al. Vasopressin-2-receptor antagonism augments water excretion without changes in renal hemodynamics or sodium and potassium excretion in human heart failure. American Journal of Physiology - Renal Physiology. 2006;290(2):F273-8. Sample size less than 50 patients. [pmid: 16189291].
891 Cotter G, Dittrich HC, Weatherley BD, et al. The PROTECT pilot study: a randomized, placebo-controlled, dose-finding study of the adenosine A1 receptor antagonist rolofylline in patients with acute heart failure and renal impairment. Journal of Cardiac Failure. 2008;14(8):631-40. Not CKD treatment. [pmid: 18926433].
892 Cotter G, Metra M, Weatherley BD, et al. Physician-determined worsening heart failure: a novel definition for early worsening heart failure in patients hospitalized for acute heart failure--association with signs and symptoms, hospitalization duration, and 60-day outcomes. Cardiology. 2010;115(1):29-36. Not CKD treatment. [pmid: 19844102].
893 Cotter G, Weissgarten J, Metzkor E, et al. Increased toxicity of high-dose furosemide versus low-dose dopamine in the treatment of refractory congestive heart failure. Clinical Pharmacology & Therapeutics. 1997;62(2):187-93. Sample size less than 50 patients. [pmid: 9284855].
894 Courtney AE, Maxwell AP. Critiques of clinical guidelines in nephrology: anaemia. Nephron. 2008;110(2):c115-25. Not CKD treatment. [pmid: 18931515].
895 Courtney MJ, Pannu N. Calcific uremic arteriolopathy should be treated conservatively. Seminars in Dialysis. Jan-Feb. 2010;23(1):34-7. Not RCT or controlled trial. [pmid: 20331816].
896 Couverchel L, Maugars Y, Prost A. Outcomes of thirty-four rheumatoid arthritis patients with renal amyloidosis, including twelve given alkylating agents. Revue du Rhumatisme. 1995;62(2):79-85. Not RCT or controlled trial. [pmid: 7600076].
897 Cox JP, O'Boyle CA, Mee F, et al. The antihypertensive efficacy of verapamil in the elderly evaluated by ambulatory blood pressure measurement. Journal of Human Hypertension. 1988;2(1):41-7. Sample size less than 50 patients. [pmid: 3070032].
898 Coyle LC, Rodriguez A, Jeschke RE, et al. Acetylcysteine In Diabetes (AID): a randomized study of acetylcysteine for the prevention of contrast nephropathy in diabetics. American Heart Journal. 2006;151(5):1032.e9-12. Sample size less than 50 patients. [pmid: 16644332].
899 Coyne D, Acharya M, Qiu P, et al. Paricalcitol capsule for the treatment of secondary hyperparathyroidism in stages 3 and 4 CKD. American Journal of Kidney Diseases. 2006;47(2):263-76. Not relevant to key questions. [pmid: 16431255].
900 Coyne DW. From anemia trials to clinical practice: understanding the risks and benefits when setting goals for therapy. Seminars in Dialysis. 2008;21(3):212-6. Not relevant to key questions. [pmid: 18363603].
901 Coyne DW. Managing anemia in for-profit dialysis chains: when ethics and business conflict. Seminars in Dialysis. 2009;22(1):18-21. Not CKD treatment. [pmid: 19250444].
902 Coyne T, Olson M, Bradham K, et al. Dietary satisfaction correlated with adherence in the Modification of Diet in Renal Disease Study. Journal of the American Dietetic Association. 1995;95(11):1301-6. Not CKD treatment. [pmid: 7594127].
903 Craig JC. Can ACE inhibitor therapy prevent end-stage renal failure?. Medical Journal of Australia. 2001;175(5):276. Not RCT or controlled trial. [pmid: 11587263].
904 Craig JC, Barratt A, Cumming R, et al. Feasibility study of the early detection and treatment of renal disease by mass screening. Internal Medicine Journal. 2002;32(1-2):6-14. Not RCT or controlled trial. [pmid: 11783681].
905 Craig JC, Irwig LM, Knight JF, et al. Does treatment of vesicoureteric reflux in childhood prevent end-stage renal disease attributable to reflux nephropathy?. Pediatrics. 2000;105(6):1236-41. Not adult population. [pmid: 10835063].
906 Craig KJ, Donovan K, Munnery M, et al. Identification and management of diabetic nephropathy in the diabetes clinic. Diabetes Care. 2003;26(6):1806-11. Not CKD treatment. [pmid: 12766114].
907 Cravedi P, Remuzzi G. Treating the kidney to cure the heart. Kidney International - Supplement. 2008;(111):S2-3. Not CKD treatment. [pmid: 19034321].
908 Cravedi P, Ruggenenti P, Remuzzi G. Intensified inhibition of renin-angiotensin system: a way to improve renal protection?. Current Hypertension Reports. 2007;9(5):430-6. Not CKD treatment. [pmid: 18177592].
909 Cribier B, Couilliet D, Meyer P, et al. The severity of histopathological changes of leukocytoclastic vasculitis is not predictive of extracutaneous involvement. American Journal of Dermatopathology. 1999;21(6):532-6. Not CKD treatment. [pmid: 10608245].
910 Crofford LJ. Specific cyclooxygenase-2 inhibitors: what have we learned since they came into widespread clinical use?. Current Opinion in Rheumatology. 2002;14(3):225-30. Not RCT or controlled trial. [pmid: 11981317].
911 Crofford OB. Diabetes control and complications. Annual Review of Medicine. 1995;46:267-79. Not CKD treatment.
912 Cronberg S, Nordstrom L. Simplified monitoring of aminoglycoside treatment. Scandinavian Journal of Infectious Diseases Supplement. 1990;74:274-9. Not CKD treatment. [pmid: 2097716].
913 Cronin RE. Contrast-induced nephropathy: pathogenesis and prevention. Pediatric Nephrology. Feb. 2010;25(2):191-204. Not CKD treatment. [pmid: 19444480].
914 Crook ED, Preddie DC. Therapeutic controversies in hypertension management: angiotensin converting enzyme (ACE) inhibitors or angiotensin receptor blockers for diabetic nephropathy? A case for ACE inhibitors. Ethnicity & Disease. 2002;12(4):S3-49-52. Not RCT or controlled trial.
915 Crook ED, Velusamy L. Are low target blood pressure goals justified in persons with diabetes mellitus?. Current Hypertension Reports. 2003;5(3):231-8. Not RCT or controlled trial. [pmid: 12724056].
916 Croom KF, Curran MP, Goa KL, et al. Irbesartan: a review of its use in hypertension and in the management of diabetic nephropathy. Drugs. 2004;64(9):999-1028. Not RCT or controlled trial. [pmid: 15101793].
917 Crowe AV, Howse M, Vinjamuri S, et al. The antiproteinuric effect of losartan is systemic blood pressure dependent. Nephrology Dialysis Transplantation. 2003;18(10):2160-4. Sample size less than 50 patients.
918 Crowther MA, Cook DJ. Preventing venous thromboembolism in critically ill patients. Seminars in Thrombosis & Hemostasis. 2008;34(5):469-74. Not CKD treatment. [pmid: 18956287].
919 Cruickshank JK, Anderson NM, Wadsworth J, et al. Treating hypertension in black compared with white non-insulin dependent diabetics: a double blind trial of verapamil and metoprolol. BMJ. 1988;297(6657):1155-9. Follow-up less than 6 months. [pmid: 3144329].
920 Cruickshanks KJ, Ritter LL, Klein R, et al. The association of microalbuminuria with diabetic retinopathy. The Wisconsin Epidemiologic Study of Diabetic Retinopathy. Ophthalmology. 1993;100(6):862-7. Not RCT or controlled trial. [pmid: 8510898].
921 Cserti C, Haspel R, Stowell C, et al. Light-chain removal by plasmapheresis in myeloma-associated renal failure. Transfusion. 2007;47(3):511-4. Not RCT or controlled trial. [pmid: 17319833].
922 Cuculich PS, Sanchez JM, Kerzner R, et al. Poor prognosis for patients with chronic kidney disease despite ICD therapy for the primary prevention of sudden death. Pacing & Clinical Electrophysiology. 2007;30(2):207-13. Sample size less than 50 patients. [pmid: 17338717].
923 Cummings DM, Amadio P Jr., Nettler S, et al. Office-based evaluation of renal function in elderly patients receiving nonsteroidal anti-inflammatory drugs. Journal of the American Board of Family Practice. 1988;1(2):77-80. Follow-up less than 6 months. [pmid: 3046231].
924 Cummings MH, Watts GF, Tavakolian A, et al. Prevalence of microalbuminuria, lipoprotein (a) and coronary artery disease in the lipid clinic. Journal of Clinical Pathology. 1996;49(1):19-23. Not RCT or controlled trial. [pmid: 8666679].
925 Cunningham J, Danese M, Olson K, et al. Effects of the calcimimetic cinacalcet HCl on cardiovascular disease, fracture, and health-related quality of life in secondary hyperparathyroidism. Kidney International. 2005;68(4):1793-800. Sample size less than 50 patients. [pmid: 16164656].
926 Cuocolo A, Volpe M, Mele AF, et al. Effects of atrial natriuretic peptide on glomerular filtration rate in essential hypertension: a radionuclide study. European Journal of Nuclear Medicine. 1991;18(1):32-7. Sample size less than 50 patients. [pmid: 1826883].
927 Curry C, Kelly AM. Intravenous tenoxicam for the treatment of renal colic. New Zealand Medical Journal. 1995;108(1001):229-30. Not CKD treatment. [pmid: 7603654].
928 Curtis JJ, Laskow DA, Jones PA, et al. Captopril-induced fall in glomerular filtration rate in cyclosporine-treated hypertensive patients. Journal of the American Society of Nephrology. 1993;3(9):1570-4. Follow-up less than 6 months. [pmid: 8507812].
929 Curtis JR. Interventions in chronic renal failure. BMJ. 1990;301(6753):622-4. Not RCT or controlled trial. [pmid: 2224215].
930 Curtis JR. Randomised controlled trial of hydroquinine in muscle cramps. Lancet. 1997;349(9061):1325. author reply 6. Not RCT or controlled trial. [pmid: 9142087].
931 Curtiss FR. Antihypertensive drug effects on renal function and myocardial infarction and implications of the ALLHAT study results. Journal of Managed Care Pharmacy. 2003;9(1):93-4. Not CKD treatment.
932 Curtiss FR, Fairman KA. No TREATment with darbepoetin dosed to hemoglobin 13 grams per deciliter in type 2 diabetes with pre-dialysis chronic kidney disease--safety warnings for erythropoiesis-stimulating agents. Journal of Managed Care Pharmacy. 2009;15(9):759-65. Not RCT or controlled trial. [pmid: 19954267].
933 Cushner HM, Copley JB, Lindberg JS, et al. Calcium citrate, a nonaluminum-containing phosphate-binding agent for treatment of CRF. [Erratum appears in Kidney Int 1988 May; 33(5):1047]. Kidney International. 1988;33(1):95-9. Follow-up less than 6 months. [pmid: 3280855].
934 Cusson JR, du Souich P, Le Morvan P, et al. Effect of ketoprofen on blood pressure, endocrine and renal responses to chronic dosing with captopril in patients with essential hypertension. Blood Pressure. 1992;1(3):162-7. Sample size less than 50 patients. [pmid: 1345049].
935 Czapla K, Rodger RS, Halls DJ, et al. Ranitidine reduces aluminium toxicity in patients with renal failure. Nephrology Dialysis Transplantation. 1992;7(12):1246-8. Not CKD treatment.
936 Czupryniak L, Pawlowski M, Saryusz-Wolska M, et al. Circadian blood pressure variation and antihypertensive medication adjustment in normoalbuminuric type 2 diabetes patients. Kidney & Blood Pressure Research. 2007;30(3):182-6. Sample size less than 50 patients. [pmid: 17536225].
937 Dahl-Jorgensen K, Bjoro T, Kierulf P, et al. Long-term glycemic control and kidney function in insulin-dependent diabetes mellitus. Kidney International. 1992;41(4):920-3. Sample size less than 50 patients. [pmid: 1513113].
938 Dailey GE, Boden GH, Creech RH, et al. Effects of pulsatile intravenous insulin therapy on the progression of diabetic nephropathy. Metabolism: Clinical & Experimental. 2000;49(11):1491-5. Sample size less than 50 patients. [pmid: 11092517].
939 Dal Canton A, Fuiano G, Conte G, et al. Mechanism of increased plasma urea after diuretic therapy in uraemic patients. Clinical Science. 1985;68(3):255-61. Follow-up less than 6 months. [pmid: 3971659].
940 Dalla Vestra M, Pozza G, Mosca A, et al. Effect of lercanidipine compared with ramipril on albumin excretion rate in hypertensive Type 2 diabetic patients with microalbuminuria: DIAL study (diabete, ipertensione, albuminuria, lercanidipina). Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2004;17(5):259-66. Follow-up less than 6 months.
941 Dalla Vestra M, Simioni N, Masiero A. Aliskiren: a new inhibitor of renin-angiotensin aldosterone system activity. Minerva Endocrinologica. Dec. 2009;34(4):333-8. Not RCT or controlled trial. [pmid: 20046162].
942 Dalton RN, Chetty R, Stuart M, et al. Effects of the Src inhibitor saracatinib (AZD0530) on renal function in healthy subjects. Anticancer Research. Jul. 2010;30(7):2935-42. Not early CKD. [pmid: 20683035].
943 Damasceno A, Santos A, Pestana M, et al. Acute hypotensive, natriuretic, and hormonal effects of nifedipine in salt-sensitive and salt-resistant black normotensive and hypertensive subjects. Journal of Cardiovascular Pharmacology. 1999;34(3):346-53. Sample size less than 50 patients. [pmid: 10470991].
944 D'Ambra MN, Akins CW, Blackstone EH, et al. Aprotinin in primary valve replacement and reconstruction: a multicenter, double-blind, placebo-controlled trial. Journal of Thoracic & Cardiovascular Surgery. 1996;112(4):1081-9. Not CKD treatment. [pmid: 8873736].
945 D'Ambrosio G, Filippi A, Labriola R, et al. Identification of patients with asymptomatic left ventricular dysfunction: ‘real practice’ results in primary care. Family Practice. Aug. 2010;27(4):359-62. Not early CKD. [pmid: 20403925].
946 D'Amico G, Gentile MG. Pharmacological and dietary treatment of lipid abnormalities in nephrotic patients. Kidney International - Supplement. 1991;31:S65-9. Not RCT or controlled trial. [pmid: 2046273].
947 D'Amico G, Gentile MG. Effect of dietary manipulation on the lipid abnormalities and urinary protein loss in nephrotic patients. Mineral & Electrolyte Metabolism. 1992;18(2-5):203-6. Sample size less than 50 patients. [pmid: 1465059].
948 Damman K, Navis G, Voors AA, et al. Worsening renal function and prognosis in heart failure: systematic review and meta-analysis. Journal of Cardiac Failure. 2007;13(8):599-608. Sample size less than 50 patients. [pmid: 17923350].
949 Damman K, Voors AA, Hillege HL, et al. Congestion in chronic systolic heart failure is related to renal dysfunction and increased mortality. European Journal of Heart Failure. Sep. 2010;12(9):974-82. Not CKD treatment. [pmid: 20685688].
950 Dana R, Kachhwaha VS. Comparison of oral and intravenous hydration and diuretic, choice for protecting cisplatin induced nephrotoxicity. Indian Journal of Cancer. 1996;33(4):168-70. Not CKD treatment. [pmid: 9254992].
951 Darko W, Medicis JJ, Smith A, et al. Mississippi mud no more: cost-effectiveness of pharmacokinetic dosage adjustment of vancomycin to prevent nephrotoxicity. Pharmacotherapy. 2003;23(5):643-50. Not CKD treatment. [pmid: 12741439].
952 Darling JR, Murray JM, McBride DR, et al. Serum glutathione S-transferase concentrations and creatinine clearance after sevoflurane anaesthesia. Anaesthesia. 1997;52(2):121-6. Not CKD treatment. [pmid: 9059093].
953 Darragh AS. The effects of isoxicam and piroxicam on renal function in healthy subjects. British Journal of Clinical Practice. 1985;39(4):144-7. Not early CKD. [pmid: 3940157].
954 Dasgupta A, Steinhubl SR, Bhatt DL, et al. Clinical outcomes of patients with diabetic nephropathy randomized to clopidogrel plus aspirin versus aspirin alone (a post hoc analysis of the clopidogrel for high atherothrombotic risk and ischemic stabilization, management, and avoidance [CHARISMA] trial). American Journal of Cardiology. 2009;103(10):1359-63. Not CKD treatment. [pmid: 19427428].
955 Daugirdas JT. Proposed controlled trials of phosphate reduction in CKD: which whey should we go?. Kidney International. May. 2010;77(10):929-30. author reply 30. Not RCT or controlled trial. [pmid: 20431578].
956 Daumit GL, Hermann JA, Coresh J, et al. Use of cardiovascular procedures among black persons and white persons: a 7-year nationwide study in patients with renal disease. Annals of Internal Medicine. 1999;130(3):173-82. Not RCT or controlled trial. [pmid: 10049195].
957 Daumit GL, Hermann JA, Powe NR. Relation of gender and health insurance to cardiovascular procedure use in persons with progression of chronic renal disease. Medical Care. 2000;38(4):354-65. Not early CKD. [pmid: 10752967].
958 Daumit GL, Powe NR. Factors influencing access to cardiovascular procedures in patients with chronic kidney disease: race, sex, and insurance. Seminars in Nephrology. 2001;21(4):367-76. Not RCT or controlled trial. [pmid: 11455525].
959 Davidson IJ. Renal impact of fluid management with colloids: a comparative review. European Journal of Anaesthesiology. 2006;23(9):721-38. Follow-up less than 6 months. [pmid: 16723059].
960 Davidson MB, Karlan VJ, Hair TL. Effect of a pharmacist-managed diabetes care program in a free medical clinic. American Journal of Medical Quality. 2000;15(4):137-42. Sample size less than 50 patients. [pmid: 10948785].
961 Davidson MB, Wong A, Hamrahian AH, et al. Effect of spironolactone therapy on albuminuria in patients with type 2 diabetes treated with angiotensin-converting enzyme inhibitors. Endocrine Practice. 2008;14(8):985-92. Not RCT or controlled trial. [pmid: 19095597].
962 Davis KL, Nappi JM. The cardiovascular effects of eplerenone, a selective aldosterone-receptor antagonist. Clinical Therapeutics. 2003;25(11):2647-68. Not relevant to key questions. [pmid: 14693297].
963 Davis ME, Pemberton CJ, Yandle TG, et al. Urocortin 2 infusion in healthy humans: hemodynamic, neurohormonal, and renal responses. Journal of the American College of Cardiology. 2007;49(4):461-71. Not relevant to key questions. [pmid: 17258092].
964 Davis ME, Pemberton CJ, Yandle TG, et al. Urocortin 2 infusion in human heart failure. European Heart Journal. 2007;28(21):2589-97. Not early CKD. [pmid: 17720993].
965 de Boer IH, Kestenbaum B. Vitamin D in chronic kidney disease: is the jury in?. Kidney International. 2008;74(8):985-7. Not CKD treatment. [pmid: 18827796].
966 de Brito-Ashurst I, Varagunam M, Raftery MJ, et al. Bicarbonate supplementation slows progression of CKD and improves nutritional status. Journal of the American Society of Nephrology. 2009;20(9):2075-84. Not CKD treatment. [pmid: 19608703].
967 De Caprio L, De Rosa ML, Di Palma A, et al. Regression of left ventricular hypertrophy and improvement of renal hemodynamics in hypertensive patients treated with quinapril. Cardiovascular Drugs & Therapy. 1994;8(5):735-40. Follow-up less than 6 months. [pmid: 7873470].
968 De Cesaris R, Ranieri G, Andriani A, et al. Effects of benazepril and nicardipine on microalbuminuria in normotensive and hypertensive patients with diabetes. Clinical Pharmacology & Therapeutics. 1996;60(4):472-8. Not relevant to key questions. [pmid: 8873695].
969 De Cesaris R, Ranieri G, Filitti V, et al. Effects of atenolol and enalapril on kidney function in hypertensive diabetic patients. Journal of Cardiovascular Pharmacology. 1993;22(2):208-14. Sample size less than 50 patients. [pmid: 7692159].
970 De Cosmo S, Earle K, Morocutti A, et al. Glucose-induced changes in renal haemodynamics in proteinuric type 1 (insulin-dependent) diabetic patients: inhibition by acetylsalicilic acid infusion. Diabetologia. 1993;36(7):622-7. Sample size less than 50 patients. [pmid: 8359579].
971 De Cosmo S, Motterlini N, Prudente S, et al. Impact of the PPAR-gamma2 Pro12Ala polymorphism and ACE inhibitor therapy on new-onset microalbuminuria in type 2 diabetes: evidence from BENEDICT. Diabetes. 2009;58(12):2920-9. Not CKD treatment. [pmid: 19720797].
972 de Denus S, Tardif JC, White M, et al. Temporal variations in hematocrit values in patients with left ventricular dysfunction: Relationship with cause-specific mortality and morbidity and optimal monitoring--further insights from SOLVD. Canadian Journal of Cardiology. 2008;24(1):45-8. Not CKD treatment. [pmid: 18209768].
973 De Feo ML, La Villa G, Lazzeri C, et al. Urinary endothelin-1 excretion is enhanced by low-dose infusion of brain natriuretic peptide in normal humans. Hypertension. 1997;29(1 Pt 1):70-4. Sample size less than 50 patients. [pmid: 9039083].
974 de Gaetano G, Bucchi F, Gambino MC, et al. Does oral aspirin spare the kidney?. Lancet. 1986;1(8483):736. Not RCT or controlled trial. [pmid: 2870241].
975 de Galan BE, Perkovic V, Ninomiya T, et al. Lowering blood pressure reduces renal events in type 2 diabetes. Journal of the American Society of Nephrology. 2009;20(4):883-92. Follow-up less than 6 months. [pmid: 19225038].
976 de Graeff PA, Kingma JH, Viersma JW, et al. Acute and chronic effects of ramipril and captopril in congestive heart failure. International Journal of Cardiology. 1989;23(1):59-67. Sample size less than 50 patients. [pmid: 2523870].
977 De Jager J, Kooy A, Lehert P, et al. Effects of short-term treatment with metformin on markers of endothelial function and inflammatory activity in type 2 diabetes mellitus: a randomized, placebo-controlled trial. Journal of Internal Medicine. 2005;257(1):100-9. Follow-up less than 6 months. [pmid: 15606381].
978 De Jong PE, Navis G, de Zeeuw D. Renoprotective therapy: titration against urinary protein excretion. Lancet. 1999;354(9176):352-3. Not RCT or controlled trial. [pmid: 10437857].
979 de la Rosette JJMCH, Tsakiris P, Ferrandino MN, et al. Beyond prone position in percutaneous nephrolithotomy: a comprehensive review. European Urology. 2008;54(6):1262-9. Not RCT or controlled trial. [pmid: 18707807].
980 de La Sierra A, Ruilope LM. Treatment of hypertension in diabetes mellitus. Current Hypertension Reports. 2000;2(3):335-42. Not RCT or controlled trial. [pmid: 10981168].
981 de Lasson L, Hansen HE, Juhl B, et al. A randomised, clinical study of the effect of low-dose dopamine on central and renal haemodynamics in infrarenal aortic surgery. [Erratum appears in Eur J Vasc Endovasc Surg 1997 Oct; 14(4):323]. European Journal of Vascular & Endovascular Surgery. 1995;10(1):82-90. Sample size less than 50 patients. [pmid: 7633974].
982 de Lasson L, Hansen HE, Juhl B, et al. Effect of felodipine on renal function and vasoactive hormones in infrarenal aortic surgery. British Journal of Anaesthesia. 1997;79(6):719-25. Sample size less than 50 patients. [pmid: 9496202].
983 de Leeuw PW. Renal function in the elderly: results from the European Working Party on High Blood Pressure in the Elderly trial. American Journal of Medicine. 1991;90(3A):45S-9S. Not CKD treatment. [pmid: 2006660].
984 de Leeuw PW, Ruilope LM, Palmer CR, et al. Clinical significance of renal function in hypertensive patients at high risk: results from the INSIGHT trial. Archives of Internal Medicine. 2004;164(22):2459-64. Not RCT or controlled trial. [pmid: 15596636].
985 De Leeuw PW, Thijs L, Birkenhager WH, et al. Prognostic significance of renal function in elderly patients with isolated systolic hypertension: results from the Syst-Eur trial. Journal of the American Society of Nephrology. 2002;13(9):2213-22. Not CKD treatment. [pmid: 12191965].
986 De Luca L, Tomai F, Verdoia M, et al. Evaluation and management of special subgroups after primary percutaneous coronary intervention. American Heart Journal. Dec. 2010;160(6 Suppl):S22-7. Not CKD treatment. [pmid: 21147288].
987 de Mello VDF, Zelmanovitz T, Azevedo MJ, et al. Long-term effect of a chicken-based diet versus enalapril on albuminuria in type 2 diabetic patients with microalbuminuria. Journal of Renal Nutrition. 2008;18(5):440-7. Not CKD treatment. [pmid: 18721739].
988 de Mello VDF, Zelmanovitz T, Perassolo MS, et al. Withdrawal of red meat from the usual diet reduces albuminuria and improves serum fatty acid profile in type 2 diabetes patients with macroalbuminuria. American Journal of Clinical Nutrition. 2006;83(5):1032-8. Not RCT or controlled trial. [pmid: 16685043].
989 De Nicola L, Bellizzi V, Minutolo R, et al. Randomized, double-blind, placebo-controlled study of arginine supplementation in chronic renal failure. Kidney International. 1999;56(2):674-84. Sample size less than 50 patients. [pmid: 10432408].
990 De Nicola L, Libetta C, Memoli B, et al. Acute renal and immunological effects of low-dose cyclosporin in humans. Nephrology Dialysis Transplantation. 1995;10(9):1739-44. Not CKD treatment.
991 de Oliveira MM, Conti CF, Valbuza JS, et al. The pharmacological treatment for uremic restless legs syndrome: evidence-based review. Movement Disorders. Jul. 30. 2010;25(10):1335-42. Not early CKD. [pmid: 20544816].
992 de Pablos-Velasco PL, Pazos Toral F, Esmatjes JE, et al. Losartan titration versus diuretic combination in type 2 diabetic patients. Journal of Hypertension. 2002;20(4):715-9. Follow-up less than 6 months. [pmid: 11910308].
993 De Rosa ML, Cardace P, Rossi M, et al. Comparative effects of chronic ACE inhibition and AT1 receptor blocked losartan on cardiac hypertrophy and renal function in hypertensive patients. Journal of Human Hypertension. 2002;16(2):133-40. Not early CKD. [pmid: 11850771].
994 De Rosa ML, de Cristofaro A, Rossi M, et al. Irbesartan effects on renal function in patients with renal impairment and hypertension: a drug-withdrawal study. Journal of Cardiovascular Pharmacology. 2001;38(3):482-9. Not CKD treatment. [pmid: 11486253].
995 De Rosa ML, Maddaluno G, Lionetti F, et al. Effects of enalapril and isradipine alone and in combination on blood pressure, renal function and echocardiographic parameters in mild hypertension. International Journal of Cardiology. 2000;74(1):77-84. Not early CKD. [pmid: 10854683].
996 de Saint-Aurin RG, Kloeckner M, Annane D. Crystalloids versus colloids for fluid resuscitation in critically-ill patients. Acta Clinica Belgica - Supplementum. 2007;(2):412-6. Not CKD treatment. [pmid: 18284012].
997 De Santo NG, Anastasio P, Spitali L, et al. Renal reserve is normal in adults born with unilateral renal agenesis and is not related to hyperfiltration or renal failure. Mineral & Electrolyte Metabolism. 1997;23(3-6):283-6. Sample size less than 50 patients. [pmid: 9387134].
998 De Shong D, Mathis AS. Lessons in formulary management: the case of fenoldopam for radiographic contrast material-induced nephropathy. Pharmacotherapy. 2004;24(6):819-20. author reply 20. Follow-up less than 6 months. [pmid: 15222676].
999 de Smet MD, Rubin BI, Whitcup SM, et al. Combined use of cyclosporine and ketoconazole in the treatment of endogenous uveitis. American Journal of Ophthalmology. 1992;113(6):687-90. Not CKD treatment. [pmid: 1598960].
1000 de Vinuesa SG, Goicoechea M, Kanter J, et al. Insulin resistance, inflammatory biomarkers, and adipokines in patients with chronic kidney disease: effects of angiotensin II blockade. Journal of the American Society of Nephrology. 2006;17(12 Suppl 3):S206-12. Follow-up less than 6 months. [pmid: 17130263].
1001 de Vries PJ, Verkooyen RP, Leguit P, et al. Prospective randomized study of once-daily versus thrice-daily netilmicin regimens in patients with intraabdominal infections. European Journal of Clinical Microbiology & Infectious Diseases. 1990;9(3):161-8. Not CKD treatment.
1002 De Vriese AS, Coster RV, Smet J, et al. Linezolid-induced inhibition of mitochondrial protein synthesis. Clinical Infectious Diseases. 2006;42(8):1111-7. Sample size less than 50 patients. [pmid: 16575728].
1003 De Vriese AS, Verbeke F, Schrijvers BF, et al. Is folate a promising agent in the prevention and treatment of cardiovascular disease in patients with renal failure?. Kidney International. 2002;61(4):1199-209. Not RCT or controlled trial. [pmid: 11918726].
1004 de Vroege R, Stooker W, van Oeveren W, et al. The impact of heparin coated circuits upon metabolism in vital organs: effect upon cerebral and renal function during and after cardiopulmonary bypass. ASAIO Journal. 2005;51(1):103-9. Not CKD treatment. [pmid: 15745143].
1005 de Zeeuw D, Agarwal R, Amdahl M, et al. Selective vitamin D receptor activation with paricalcitol for reduction of albuminuria in patients with type 2 diabetes (VITAL study): a randomised controlled trial. Lancet. Nov. 6. 2010;376(9752):1543-51. Follow-up less than 6 months. [pmid: 21055801].
1006 de Zeeuw D, Gansevoort RT, Dullaart RP, et al. Angiotensin II antagonism improves the lipoprotein profile in patients with nephrotic syndrome. Journal of Hypertension - Supplement. 1995;13(1):S53-8. Follow-up less than 6 months.
1007 de Zeeuw D, Remuzzi G, Parving HH, et al. Albuminuria, a therapeutic target for cardiovascular protection in type 2 diabetic patients with nephropathy. Circulation. 2004;110(8):921-7. Not relevant to key questions. [pmid: 15302780].
1008 de Zeeuw D, Remuzzi G, Parving HH, et al. Proteinuria, a target for renoprotection in patients with type 2 diabetic nephropathy: lessons from RENAAL. Kidney International. 2004;65(6):2309-20. Not CKD treatment. [pmid: 15149345].
1009 Decatris M, Santhanam S, O'Byrne K. Potential of interferon-alpha in solid tumours: part 1. Biodrugs. 2002;16(4):261-81. Not CKD treatment. [pmid: 12196039].
1010 Dedov I, Shestakova M, Vorontzov A, et al. A randomized, controlled study of sulodexide therapy for the treatment of diabetic nephropathy. Nephrology Dialysis Transplantation. 1997;12(11):2295-300. Sample size less than 50 patients.
1011 Deehan DJ, Heys SD, Broom J, et al. Pre-operative recombinant interleukin-2 and increased nephrotoxicity. Biochemical Society Transactions. 1994;22(4):425S. Not RCT or controlled trial. [pmid: 7698444].
1012 Deehan DJ, Heys SD, Broom J, et al. Renal impairment associated with the pre-operative administration of recombinant interleukin-2. Clinical Science. 1994;87(5):513-8. Follow-up less than 6 months. [pmid: 7874838].
1013 Deerochanawong C, Kornthong P, Phongwiratchai S, et al. Effects on urinary albumin excretion and renal function changes by delapril and manidipine in normotensive type 2 diabetic patients with microalbuminuria. Journal of the Medical Association of Thailand. 2001;84(2):234-41. Sample size less than 50 patients. [pmid: 11336083].
1014 Deferrari G, Ravera M, Deferrari L, et al. Renal and cardiovascular protection in type 2 diabetes mellitus: angiotensin II receptor blockers. Journal of the American Society of Nephrology. Suppl 3. 2002;13:S224-9. Not RCT or controlled trial. [pmid: 12466318].
1015 Degiannis D, Mowat AM, Tsakiris D, et al. The effect of random blood transfusions on immunoglobulin production by peripheral blood mononuclear cells from uraemic patients. Clinical & Experimental Immunology. 1988;73(1):155-9. Not RCT or controlled trial. [pmid: 3048812].
1016 Dehne MG, Klein TF, Muhling J, et al. Impairment of renal function after cardiopulmonary bypass is not influenced by dopexamine. Renal Failure. 2001;23(2):217-30. Not CKD treatment. [pmid: 11417953].
1017 Dehne MG, Muhling J, Sablotzki A, et al. Hydroxyethyl starch (HES) does not directly affect renal function in patients with no prior renal impairment. Journal of Clinical Anesthesia. 2001;13(2):103-11. Not early CKD. [pmid: 11331169].
1018 Deicher R, Horl WH. Differentiating factors between erythropoiesis-stimulating agents: a guide to selection for anaemia of chronic kidney disease. Drugs. 2004;64(5):499-509. Not CKD treatment. [pmid: 14977387].
1019 Deighan CJ, Caslake MJ, McConnell M, et al. Comparative effects of cerivastatin and fenofibrate on the atherogenic lipoprotein phenotype in proteinuric renal disease. Journal of the American Society of Nephrology. 2001;12(2):341-8. Sample size less than 50 patients. [pmid: 11158224].
1020 Del Vecchio L, Pozzi M, Salvetti A, et al. Efficacy and tolerability of manidipine in the treatment of hypertension in patients with non-diabetic chronic kidney disease without glomerular disease. Prospective, randomized, double-blind study of parallel groups in comparison with enalapril. Journal of Nephrology. 2004;17(2):261-9. Not relevant to key questions. [pmid: 15293527].
1021 Delahanty LM. Implications of the diabetes control and complications trial for renal outcomes and medical nutrition therapy. Journal of Renal Nutrition. 1998;8(2):59-63. Not relevant to key questions. [pmid: 9724486].
1022 Delic-Brkljacic D, Galesic K, Ivanac G, et al. Influence of ATII blockers and calcium channel blockers on renal vascular resistance in patients with essential hypertension. Collegium Antropologicum. 2009;33(4):1129-38. Not RCT or controlled trial. [pmid: 20102058].
1023 Delles C, Jacobi J, Schlaich MP, et al. Assessment of endothelial function of the renal vasculature in human subjects. American Journal of Hypertension. 2002;15(1 Pt 1):3-9. Not early CKD. [pmid: 11824856].
1024 Delles C, Klingbeil AU, Schneider MP, et al. Direct comparison of the effects of valsartan and amlodipine on renal hemodynamics in human essential hypertension. American Journal of Hypertension. 2003;16(12):1030-5. Sample size less than 50 patients. [pmid: 14643577].
1025 Delmas A, Leone M, Rousseau S, et al. Clinical review: Vasopressin and terlipressin in septic shock patients. Critical Care. 2005;9(2):212-22. Not CKD treatment. [pmid: 15774080].
1026 DeMarco PJ, Weisman MH, Seibold JR, et al. Predictors and outcomes of scleroderma renal crisis: the high-dose versus low-dose D-penicillamine in early diffuse systemic sclerosis trial. Arthritis & Rheumatism. 2002;46(11):2983-9. Not RCT or controlled trial. [pmid: 12428241].
1027 Demarie BK, Bakris GL. Effects of different calcium antagonists on proteinuria associated with diabetes mellitus. Annals of Internal Medicine. 1990;113(12):987-8. Sample size less than 50 patients. [pmid: 2240922].
1028 Dember LM, Hawkins PN, Hazenberg BPC, et al. Eprodisate for the treatment of renal disease in AA amyloidosis. New England Journal of Medicine. 2007;356(23):2349-60. Not RCT or controlled trial. [pmid: 17554116].
1029 Dengel DR, Brown MD, Ferrell RE, et al. A preliminary study on T-786C endothelial nitric oxide synthase gene and renal hemodynamic and blood pressure responses to dietary sodium. Physiological Research. 2007;56(4):393-401. Not relevant to key questions. [pmid: 16925467].
1030 Denig P, Haaijer-Ruskamp FM, Zijsling DH. Impact of a drug bulletin on the knowledge, perception of drug utility, and prescribing behavior of physicians. DICP. 1990;24(1):87-93. Not CKD treatment. [pmid: 2301192].
1031 Dennis VW. Decoding the modification of diet in renal disease study. Cleveland Clinic Journal of Medicine. 1994;61(4):254-7. Not RCT or controlled trial. [pmid: 7923742].
1032 Deo R, Lin F, Vittinghoff E, et al. Kidney dysfunction and sudden cardiac death among women with coronary heart disease. Hypertension. 2008;51(6):1578-82. Not CKD treatment. [pmid: 18391103].
1033 Depre M, Van Hecken A, Verbesselt R, et al. Pharmacokinetic and pharmacodynamic interaction between the lipoxygenase inhibitor MK-0591 and the cyclooxygenase inhibitor ibuprofen in man. International Journal of Clinical Pharmacology Research. 1998;18(2):53-61. Sample size less than 50 patients. [pmid: 9675622].
1034 DeQuattro V, Lee DP. Equivalent reduction of proteinuria in hypertensives by either nifedipine GITS or enalapril: disparate effects on neurohormones and ambulatory blood pressure and the influence of salt. Cardiology. Suppl 3. 1997;88:38-42. Sample size less than 50 patients. [pmid: 9397292].
1035 Deray G. Amphotericin B nephrotoxicity. Journal of Antimicrobial Chemotherapy. Suppl 1. 2002;49:37-41. Not early CKD. [pmid: 11801579].
1036 Deray G, Bellin MF, Boulechfar H, et al. Nephrotoxicity of contrast media in high-risk patients with renal insufficiency: comparison of low- and high-osmolar contrast agents. American Journal of Nephrology. 1991;11(4):309-12. Not CKD treatment. [pmid: 1799190].
1037 Deray G, Khayat D, Cacoub P, et al. The effects of diltiazem on methotrexate-induced nephrotoxicity. European Journal of Clinical Pharmacology. 1989;37(4):337-40. Not CKD treatment. [pmid: 2689182].
1038 Derlatka P, Bidzinski M, Stachurska E, et al. Nadroparine activated fibrinolysis and improvement of glomerular filtration rate in patients with FIGO IIB-IIIB cervical cancer treated with radiochemotherapy. Gynecologic Oncology. 2007;104(1):24-31. Not relevant to key questions. [pmid: 16959304].
1039 Despas F, Detis N, Dumonteil N, et al. Excessive sympathetic activation in heart failure with chronic renal failure: role of chemoreflex activation. Journal of Hypertension. 2009;27(9):1849-54. Follow-up less than 6 months. [pmid: 19542895].
1040 Detrenis S, Meschi M, del Mar Jordana, Sanchez M, et al. Contrast medium induced nephropathy in urological practice. Journal of Urology. 2007;178(4 Pt 1):1164-70. Follow-up less than 6 months. [pmid: 17698088].
1041 Deyneli O, Yavuz D, Velioglu A, et al. Effects of ACE inhibition and angiotensin II receptor blockade on glomerular basement membrane protein excretion and charge selectivity in type 2 diabetic patients. Journal of the Renin-Angiotensin-Aldosterone System. 2006;7(2):98-103. Not early CKD. [pmid: 17083064].
1042 Dhaene M, Sabot JP, Philippart Y, et al. Effects of acute protein loads of different sources on glomerular filtration rate. Kidney International - Supplement. 1987;22:S25-8. Sample size less than 50 patients. [pmid: 3480993].
1043 D'Haens G, Lemmens L, Geboes K, et al. Intravenous cyclosporine versus intravenous corticosteroids as single therapy for severe attacks of ulcerative colitis. Gastroenterology. 2001;120(6):1323-9. Not early CKD. [pmid: 11313301].
1044 Dharmarajan TS. Anemia and response to epoetin alfa: the cause of anemia matters!. Journal of the American Geriatrics Society. 2008;56(8):1574-5. Not relevant to key questions. [pmid: 18808607].
1045 Dharmarajan TS, Widjaja D. Adverse consequences with use of erythropoiesis-stimulating agents in anemia prompt release of guidelines to ensure safe use and maximize benefit. Geriatrics. 2008;63(6):13-29. Not CKD treatment. [pmid: 18512996].
1046 Dhaun N, Macintyre IM, Melville V, et al. Blood pressure-independent reduction in proteinuria and arterial stiffness after acute endothelin-a receptor antagonism in chronic kidney disease. Hypertension. 2009;54(1):113-9. Sample size less than 50 patients. [pmid: 19506099].
1047 Di Iorio B, Gaudiano G, Altieri C, et al. Aluminum urinary excretion in patients with chronic renal failure in treatment with conservative conventional therapy and with ketoanalogs: research on fasting patients and after a pharmacological load. Nephron. 1995;71(3):371-2. Not CKD treatment. [pmid: 8569997].
1048 Di Iorio BR, Minutolo R, De Nicola L, et al. Supplemented very low protein diet ameliorates responsiveness to erythropoietin in chronic renal failure. Kidney International. 2003;64(5):1822-8. Not early CKD. [pmid: 14531817].
1049 Di Lullo L, Addesse R, Comegna C, et al. Effects of fluvastatin treatment on lipid profile, C-reactive protein trend, and renal function in dyslipidemic patients with chronic renal failure. Advances in Therapy. 2005;22(6):601-12. Sample size less than 50 patients. [pmid: 16510377].
1050 Di Mario U, Bacci S, Morano S, et al. Selective decrement of anionic immunoglobulin clearance after induced renal hemodynamic changes in diabetic patients. American Journal of Physiology. 1992;262(3 Pt 2):F381-8. Not CKD treatment. [pmid: 1558156].
1051 Diabetes Prevention Program Research G. Changes in albumin excretion in the diabetes prevention program. Diabetes Care. 2009;32(4):720-5. Not RCT or controlled trial. [pmid: 19131464].
1052 Diaz-Mitoma F, Harding GK, Louie TJ, et al. Prospective randomized comparison of imipenem/cilastatin and cefotaxime for treatment of lung, soft tissue, and renal infections. Reviews of Infectious Diseases. Suppl 3. 1985;7(7):S452. Sample size less than 50 patients. [pmid: 3901207].
1053 Diaz-Sandoval LJ, Kosowsky BD, Losordo DW. Acetylcysteine to prevent angiography-related renal tissue injury (the APART trial). American Journal of Cardiology. 2002;89(3):356-8. Not early CKD. [pmid: 11809444].
1054 Dick IM, St John A, Heal S, et al. The effect of estrogen deficiency on bone mineral density, renal calcium and phosphorus handling and calcitropic hormones in the rat. Calcified Tissue International. 1996;59(3):174-8. Sample size less than 50 patients. [pmid: 8694894].
1055 Didjurgeit U, Kruse J, Schmitz N, et al. A time-limited, problem-orientated psychotherapeutic intervention in Type 1 diabetic patients with complications: a randomized controlled trial. Diabetic Medicine. 2002;19(10):814-21. Sample size less than 50 patients. [pmid: 12358867].
1056 DiDomenico RJ, Eyrich HM. Did contrast nephropathyin RAPPID really occur?. Journal of the American College of Cardiology. 2003;42(12):2167. author reply -9. Not CKD treatment. [pmid: 14680745].
1057 Diercks GF, Janssen WM, van Boven AJ, et al. Rationale, design, and baseline characteristics of a trial of prevention of cardiovascular and renal disease with fosinopril and pravastatin in nonhypertensive, nonhypercholesterolemic subjects with microalbuminuria (the Prevention of REnal and Vascular ENdstage Disease Intervention Trial [PREVEND IT]). American Journal of Cardiology. 2000;86(6):635-8. Not RCT or controlled trial. [pmid: 10980214].
1058 Dilek K, Usta M, Ersoy A, et al. Long-term effects of losartan on proteinuria and renal function in patients with renal amyloidosis. Scandinavian Journal of Urology & Nephrology. 2002;36(6):443-6. Sample size less than 50 patients. [pmid: 12623509].
1059 Dilger K, Herrlinger C, Peters J, et al. Effects of celecoxib and diclofenac on blood pressure, renal function, and vasoactive prostanoids in young and elderly subjects. Journal of Clinical Pharmacology. 2002;42(9):985-94. Not CKD treatment. [pmid: 12211224].
1060 Dillman RO. The clinical experience with interleukin-2 in cancer therapy. Cancer Biotherapy. 1994;9(3):183-209. Not CKD treatment. [pmid: 7820182].
1061 Dillman RO, Wiemann M, Nayak SK, et al. Interferon-gamma or granulocyte-macrophage colony-stimulating factor administered as adjuvants with a vaccine of irradiated autologous tumor cells from short-term cell line cultures: a randomized phase 2 trial of the cancer biotherapy research group. Journal of Immunotherapy. 2003;26(4):367-73. Not CKD treatment. [pmid: 12843799].
1062 Dimopoulos M, Alegre A, Stadtmauer EA, et al. The efficacy and safety of lenalidomide plus dexamethasone in relapsed and/or refractory multiple myeloma patients with impaired renal function. Cancer. Aug. 15. 2010;116(16):3807-14. Not CKD treatment. [pmid: 20564094].
1063 Dimopoulos MA, Richardson PG, Schlag R, et al. VMP (Bortezomib, Melphalan, and Prednisone) is active and well tolerated in newly diagnosed patients with multiple myeloma with moderately impaired renal function, and results in reversal of renal impairment: cohort analysis of the phase III VISTA study. Journal of Clinical Oncology. 2009;27(36):6086-93. Not CKD treatment. [pmid: 19858394].
1064 Dinits-Pensy M, Forrest GN, Cross AS, et al. The use of vaccines in adult patients with renal disease. American Journal of Kidney Diseases. 2005;46(6):997-1011. Not relevant to key questions. [pmid: 16310566].
1065 Dittrich HC, Gupta DK, Hack TC, et al. The effect of KW-3902, an adenosine A1 receptor antagonist, on renal function and renal plasma flow in ambulatory patients with heart failure and renal impairment. Journal of Cardiac Failure. 2007;13(8):609-17. Not early CKD. [pmid: 17923351].
1066 Dittrich S, Kurschat K, Dahnert I, et al. Renal function after cardiopulmonary bypass surgery in cyanotic congenital heart disease. International Journal of Cardiology. 2000;73(2):173-9. Not early CKD. [pmid: 10817857].
1067 Dittrich S, Kurschat K, Dahnert I, et al. Cyanotic nephropathy and use of non-ionic contrast agents during cardiac catherization in patients with cyanotic congenital heart disease. Cardiology in the Young. 2000;10(1):8-14. Sample size less than 50 patients. [pmid: 10695534].
1068 Dixey JJ, Noormohamed FH, Lant AF, et al. The effects of naproxen and sulindac on renal function and their interaction with hydrochlorothiazide and piretanide in man. British Journal of Clinical Pharmacology. 1987;23(1):55-63. Sample size less than 50 patients. [pmid: 3814463].
1069 Dixey JJ, Noormohamed FH, Lant AF, et al. Effect of maximal hydration on the renal responses to pretreatment with nonsteroidal anti-inflammatory drugs and probenecid in man. British Journal of Clinical Pharmacology. 1988;25(5):614-7. Follow-up less than 6 months. [pmid: 3408640].
1070 Dixey JJ, Noormohamed FH, Pawa JS, et al. The influence of nonsteroidal anti-inflammatory drugs and probenecid on the renal response to and kinetics of piretanide in man. Clinical Pharmacology & Therapeutics. 1988;44(5):531-9. Sample size less than 50 patients. [pmid: 3180634].
1071 Djabarouti S, Duffau P, Lazaro E, et al. Therapeutic drug monitoring of mycophenolate mofetil and enteric-coated mycophenolate sodium in patients with systemic lupus erythematosus. Expert Opinion on Pharmacotherapy. Apr. 2010;11(5):689-99. Not CKD treatment. [pmid: 20210680].
1072 Doggrell SA. Sarpogrelate: cardiovascular and renal clinical potential. Expert Opinion on Investigational Drugs. 2004;13(7):865-74. Not CKD treatment. [pmid: 15212624].
1073 Dogra G, Irish A, Chan D, et al. A randomized trial of the effect of statin and fibrate therapy on arterial function in CKD. American Journal of Kidney Diseases. 2007;49(6):776-85. Not RCT or controlled trial. [pmid: 17533020].
1074 Dogra GK, Watts GF, Chan DC, et al. Statin therapy improves brachial artery vasodilator function in patients with Type 1 diabetes and microalbuminuria. Diabetic Medicine. 2005;22(3):239-42. Not RCT or controlled trial. [pmid: 15717868].
1075 Doig JK, MacFadyen RJ, Sweet CS, et al. Haemodynamic and renal responses to oral losartan potassium during salt depletion or salt repletion in normal human volunteers. Journal of Cardiovascular Pharmacology. 1995;25(4):511-7. Sample size less than 50 patients. [pmid: 7596116].
1076 Dolecek TA, Olson MB, Caggiula AW, et al. Registered dietitian time requirements in the Modification of Diet in Renal Disease Study. Journal of the American Dietetic Association. 1995;95(11):1307-12. Not CKD treatment. [pmid: 7594128].
1077 Dolegowska B, Pikula E, Safranow K, et al. Metabolism of eicosanoids and their action on renal function during ischaemia and reperfusion: the effect of alprostadil. Prostaglandins Leukotrienes & Essential Fatty Acids. 2006;75(6):403-11. Not RCT or controlled trial.
1078 Don BR, Kaysen GA, Hutchison FN, et al. The effect of angiotensin-converting enzyme inhibition and dietary protein restriction in the treatment of proteinuria. American Journal of Kidney Diseases. 1991;17(1):10-7. Sample size less than 50 patients. [pmid: 1986564].
1079 Donadio C, Lucchesi A, Tramonti G, et al. Creatinine clearance can be predicted from plasma creatinine and body composition analysis by means of electrical bioimpedance. Renal Failure. 1998;20(2):285-93. Not CKD treatment. [pmid: 9574454].
1080 Donadio C, Lucchesi A, Tramonti G, et al. Glomerular and tubular effects of contrast media diatrizoate and iopromide. Renal Failure. 1996;18(4):657-66. Sample size less than 50 patients. [pmid: 8875693].
1081 Dones L, Wiltshaw E, Birkhead BG, et al. Towards an assessment of toxicity in the treatment of ovarian cancer. Cancer Chemotherapy & Pharmacology. 1987;20(3):213-8. Not relevant to key questions. [pmid: 3315279].
1082 Dong F, Cheng J, Lin S, et al. The clinical research on serum cystatin-C alteration on stage II chronic kidney disease with gubenquduyishen decoction treatment. Journal of Ethnopharmacology. Oct. 5. 2010;31(3):581-4. Not CKD treatment. [pmid: 20659545].
1083 Donnelly R, Elliott HL, Meredith PA, et al. Clinical studies with the potassium channel activator cromakalim in normotensive and hypertensive subjects. Journal of Cardiovascular Pharmacology. 1990;16(5):790-5. Sample size less than 50 patients. [pmid: 1703602].
1084 Donnelly R, Molyneaux LM, Willey KA, et al. Comparative effects of indapamide and captopril on blood pressure and albumin excretion rate in diabetic microalbuminuria. American Journal of Cardiology. 1996;77(6):26B-30B. Follow-up less than 6 months.
1085 Donnelly S. Why is erythropoietin made in the kidney? The kidney functions as a ‘critmeter’ to regulate the hematocrit. Advances in Experimental Medicine & Biology. 2003;543:73-87. Not CKD treatment. [pmid: 14713115].
1086 Donner KM, Hiltunen TP, Suonsyrja T, et al. CYP2C9 genotype modifies activity of the renin-angiotensin-aldosterone system in hypertensive men. Journal of Hypertension. 2009;27(10):2001-9. Not CKD treatment. [pmid: 19593208].
1087 Doorenbos CJ, Iestra JA, Papapoulos SE, et al. Atrial natriuretic peptide and chronic renal effects of changes in dietary protein and sodium intake in man. Clinical Science. 1990;78(6):565-72. Sample size less than 50 patients. [pmid: 2165888].
1088 Dorio PJ, Lee FT Jr., Henseler KP, et al. Using a saline chaser to decrease contrast media in abdominal CT. AJR. American Journal of Roentgenology. 2003;180(4):929-34. Not CKD treatment. [pmid: 12646431].
1089 Dorner GT, Pehamberger H, Kornek G, et al. Cisplatin-induced renal effects and thromboxane A2 receptor blockade. European Journal of Clinical Investigation. 1997;27(10):836-9. Not CKD treatment. [pmid: 9373762].
1090 Dougados M, Awada H, Amor B. Cyclosporin in rheumatoid arthritis: a double blind, placebo controlled study in 52 patients. Annals of the Rheumatic Diseases. 1988;47(2):127-33. Follow-up less than 6 months. [pmid: 3281603].
1091 Dougados M, Duchesne L, Awada H, et al. Assessment of efficacy and acceptability of low dose cyclosporin in patients with rheumatoid arthritis. Annals of the Rheumatic Diseases. 1989;48(7):550-6. Not CKD treatment. [pmid: 2673081].
1092 Doughty RN, White HD. Carvedilol: use in chronic heart failure. Expert Review of Cardiovascular Therapy. 2007;5(1):21-31. Not early CKD. [pmid: 17187454].
1093 Douglas JG, Agodoa L. ACE inhibition is effective and renoprotective in hypertensive nephrosclerosis: the African American Study of Kidney Disease and Hypertension (AASK) trial. Kidney International - Supplement. 2003;(83):S74-6. Not early CKD. [pmid: 12864879].
1094 Douglas K, O'Malley PG, Jackson JL. Meta-analysis: the effect of statins on albuminuria. Annals of Internal Medicine. 2006;145(2):117-24. Sample size less than 50 patients. [pmid: 16847294].
1095 Drager LF, Andrade L, Barros de Toledo JF, et al. Renal effects of N-acetylcysteine in patients at risk for contrast nephropathy: decrease in oxidant stress-mediated renal tubular injury. Nephrology Dialysis Transplantation. 2004;19(7):1803-7. Not relevant to key questions.
1096 Dragu R, Behar S, Sandach A, et al. Should primary percutaneous coronary intervention be the preferred method of reperfusion therapy for patients with renal failure and ST-elevation acute myocardial infarction?. American Journal of Cardiology. 2006;97(8):1142-5. Follow-up less than 6 months. [pmid: 16616015].
1097 Dreicer R. Locally advanced and metastatic bladder cancer. Current Treatment Options in Oncology. 2001;2(5):431-6. Not early CKD. [pmid: 12057106].
1098 Drescher P, Pereira F, Will JA, et al. Nephrotoxicity from contrast media: attenuation with theophylline. Radiology. 1995;197(2):547-8. Not RCT or controlled trial. [pmid: 7480714].
1099 Drion I. B-vitamin therapy for diabetic nephropathy. JAMA. Aug. 11. 2010;304(6):636. author reply -7. Not CKD treatment. [pmid: 20699452].
1100 Drueke TB, Landais P. Paricalcitol for treatment of secondary hyperparathyroidism in CKD patients. American Journal of Kidney Diseases. 2006;47(6):1083. author reply -4. Not RCT or controlled trial. [pmid: 16731305].
1101 Druml W. Supplements of keto acids in patients with chronic renal failure--more than modulators of nitrogen economy. Wiener Klinische Wochenschrift. 2001;113(17-18):638-40. Not relevant to key questions. [pmid: 11603097].
1102 Dugandzic RM, Sketris IS, Belitsky P, et al. Effect of coadministration of acyclovir and cyclosporine on kidney function and cyclosporine concentrations in renal transplant patients. DICP. 1991;25(3):316-7. Not early CKD. [pmid: 2028640].
1103 Dullaart RP, Beusekamp BJ, Meijer S, et al. Long-term effects of linoleic-acid-enriched diet on albuminuria and lipid levels in type 1 (insulin-dependent) diabetic patients with elevated urinary albumin excretion. Diabetologia. 1992;35(2):165-72. Sample size less than 50 patients. [pmid: 1547922].
1104 Dullaart RP, Beusekamp BJ, Meijer S, et al. Long-term effects of protein-restricted diet on albuminuria and renal function in IDDM patients without clinical nephropathy and hypertension. Diabetes Care. 1993;16(2):483-92. Sample size less than 50 patients. [pmid: 8432221].
1105 Dumas M, de Gislain C, d'Athis P, et al. Evaluation of the effect of furosemide on ultrafilterable platinum kinetics in patients treated with cis-diamminedichloroplatinum. Cancer Chemotherapy & Pharmacology. 1989;23(1):37-40. Sample size less than 50 patients. [pmid: 2909288].
1106 Dumas M, de Gislain C, d'Athis P, et al. Influence of hydration on ultrafilterable platinum kinetics and kidney function in patients treated with cis-diamminedichloroplatinum(II). Cancer Chemotherapy & Pharmacology. 1990;26(4):278-82. Not CKD treatment. [pmid: 2369792].
1107 Dumler F. Dietary sodium intake and arterial blood pressure. Journal of Renal Nutrition. 2009;19(1):57-60. Not CKD treatment. [pmid: 19121772].
1108 Dummer CD, Thome FS, Zingano B, et al. Acute effect of simvastatin on inflammation and oxidative stress in chronic kidney disease. Journal of Nephrology. 2008;21(6):900-8. Sample size less than 50 patients. [pmid: 19034875].
1109 Dunn CJ, Markham A. Epoetin beta. A review of its pharmacological properties and clinical use in the management of anaemia associated with chronic renal failure. Drugs. 1996;51(2):299-318. Not RCT or controlled trial. [pmid: 8808169].
1110 Duong MH, MacKenzie TA, Malenka DJ. N-acetylcysteine prophylaxis significantly reduces the risk of radiocontrast-induced nephropathy: comprehensive meta-analysis. Catheterization & Cardiovascular Interventions. 2005;64(4):471-9. Sample size less than 50 patients. [pmid: 15789388].
1111 Dupont AG. Effects of carvedilol on renal function. European Journal of Clinical Pharmacology. Suppl 2. 1990;38:S96-100. Follow-up less than 6 months. [pmid: 1974513].
1112 Dupont AG, Gerlo E, Van der Niepen P, et al. Renal pharmacodynamic effects of torasemide and furosemide in normal man. Arzneimittel-Forschung. 1988;38(1A):172-5. Sample size less than 50 patients. [pmid: 3285829].
1113 Dupont AG, Van der Niepen P, Taeymans Y, et al. Effect of carvedilol on ambulatory blood pressure, renal hemodynamics, and cardiac function in essential hypertension. Journal of Cardiovascular Pharmacology. Suppl 11. 1987;10:S130-6. Follow-up less than 6 months. [pmid: 2454359].
1114 Dupont AG, Van der Niepen P, Volckaert A, et al. Improved renal function during chronic lisinopril treatment in moderate to severe primary hypertension. Journal of Cardiovascular Pharmacology. Suppl 7. 1987;10:S148-50. Sample size less than 50 patients. [pmid: 2485052].
1115 Dupuis J, Lalonde G, Bichet D, et al. Captopril does not prevent nitroglycerin tolerance in heart failure. Canadian Journal of Cardiology. 1990;6(7):281-6. Not CKD treatment. [pmid: 2121325].
1116 Dural O, Kanbak M, Ciliv G, et al. Comparison of halothane, enflurane and isoflurane kidney effects through alanine aminopeptidase/urine creatinine values. Anaesthesia & Intensive Care. 1995;23(2):162-4. Sample size less than 50 patients. [pmid: 7793585].
1117 Durand D, Ader JL, Rey JP, et al. Inducing hyperkalemia by converting enzyme inhibitors and heparin. Kidney International - Supplement. 1988;25:S196-7. Sample size less than 50 patients. [pmid: 3184611].
1118 Duranteau J, Pussard E, Edouard A, et al. Flosequinan does not affect systemic and regional vascular responses to simulated orthostatic stress in healthy volunteers. British Journal of Clinical Pharmacology. 1992;34(3):207-14. Not CKD treatment. [pmid: 1389945].
1119 Durham JD, Caputo C, Dokko J, et al. A randomized controlled trial of N-acetylcysteine to prevent contrast nephropathy in cardiac angiography. Kidney International. 2002;62(6):2202-7. Not CKD treatment. [pmid: 12427146].
1120 Durie BGM, Kyle RA, Belch A, et al. Myeloma management guidelines: a consensus report from the Scientific Advisors of the International Myeloma Foundation. Hematology Journal. 2003;4(6):379-98. Sample size less than 50 patients. [pmid: 14671610].
1121 Dussaule JC, Michel C, Peraldi MN, et al. Inhibition of neutral endopeptidase stimulates renal sodium excretion in patients with chronic renal failure. Clinical Science. 1993;84(1):31-9. Sample size less than 50 patients. [pmid: 8382131].
1122 Dussol B, Morange S, Loundoun A, et al. A randomized trial of saline hydration to prevent contrast nephropathy in chronic renal failure patients. Nephrology Dialysis Transplantation. 2006;21(8):2120-6. Not CKD treatment.
1123 Dyadyk AI, Bagriy AE, Lebed IA, et al. ACE inhibitors captopril and enalapril induce regression of left ventricular hypertrophy in hypertensive patients with chronic renal failure. Nephrology Dialysis Transplantation. 1997;12(5):945-51. Not CKD treatment.
1124 Eadington DW, Freestone S, Waugh CJ, et al. Lithium pretreatment affects renal and systemic responses to angiotensin II infusion in normal man. Clinical Science. 1992;82(5):543-9. Sample size less than 50 patients. [pmid: 1317764].
1125 Eadington DW, Frier BM, Swainson CP. Renal tubular responses to low-dose infusion of angiotensin II in type 1 diabetes mellitus; relation to chronic glycaemic control. Nephrology Dialysis Transplantation. 1994;9(9):1264-70. Sample size less than 50 patients.
1126 Eadington DW, Swainson CP, Lee MR. Oral carbidopa has no effect on the renal response to angiotensin II in normal man. Clinical Science. 1991;80(2):149-54. Sample size less than 50 patients. [pmid: 1848167].
1127 Easthope SE, Jarvis B. Candesartan cilexetil: an update of its use in essential hypertension. Drugs. 2002;62(8):1253-87. Not relevant to key questions. [pmid: 12010090].
1128 Ebbehoj E, Arildsen H, Hansen KW, et al. Effects of metoprolol on QT interval and QT dispersion in Type 1 diabetic patients with abnormal albuminuria. Diabetologia. 2004;47(6):1009-15. Not relevant to key questions. [pmid: 15184979].
1129 Ebbehoj E, Poulsen PL, Hansen KW, et al. Effects on heart rate variability of metoprolol supplementary to ongoing ACE-inhibitor treatment in Type I diabetic patients with abnormal albuminuria. Diabetologia. 2002;45(7):965-75. Sample size less than 50 patients. [pmid: 12136395].
1130 Ebell MH. NSAIDs vs. opiates for pain in acute renal colic. American Family Physician. 2004;70(9):1682. Sample size less than 50 patients. [pmid: 15554485].
1131 Ebert TJ, Arain SR. Renal responses to low-flow desflurane, sevoflurane, and propofol in patients. Anesthesiology. 2000;93(6):1401-6. Not early CKD. [pmid: 11149433].
1132 Ebert TJ, Groban L, Muzi M, et al. ANP-mediated volume depletion attenuates renal responses in humans. American Journal of Physiology. 1992;263(6 Pt 2):R1303-8. Sample size less than 50 patients. [pmid: 1481943].
1133 Ecder T. Influence of protein-restricted diets on proteinuria and endothelial dysfunction. Journal of Renal Nutrition. 2009;19(5 Suppl):S13-4. Not RCT or controlled trial. [pmid: 19712868].
1134 Echevarria J, Seas C, Cruz M, et al. Oral rehydration solution to prevent nephrotoxicity of amphotericin B. American Journal of Tropical Medicine & Hygiene. 2006;75(6):1108-12. Not RCT or controlled trial. [pmid: 17172377].
1135 Eckardt KU. Anaemia in end-stage renal disease: pathophysiological considerations. Nephrology Dialysis Transplantation. Suppl 7. 2001;16:2-8. Not RCT or controlled trial.
1136 Eckardt KU. Cardiovascular risk Reduction by Early Anemia Treatment with Epoetin Beta T. The CREATE trial--building the evidence. Nephrology Dialysis Transplantation. Suppl 2. 2001;16:16-8. Not CKD treatment.
1137 Edwards NC, Steeds RP, Ferro CJ, et al. The treatment of coronary artery disease in patients with chronic kidney disease. Qjm. 2006;99(11):723-36. Not RCT or controlled trial. [pmid: 17040978].
1138 Edwards NC, Steeds RP, Stewart PM, et al. Effect of spironolactone on left ventricular mass and aortic stiffness in early-stage chronic kidney disease: a randomized controlled trial. Journal of the American College of Cardiology. 2009;54(6):505-12. Not CKD treatment. [pmid: 19643310].
1139 Efrati S, Dishy V, Averbukh M, et al. The effect of N-acetylcysteine on renal function, nitric oxide, and oxidative stress after angiography. Kidney International. 2003;64(6):2182-7. Not relevant to key questions. [pmid: 14633141].
1140 Egan B, Gleim G, Panish J. Use of losartan in diabetic patients in the primary care setting: review of the results in LIFE and RENAAL. Current Medical Research & Opinion. 2004;20(12):1909-17. Not RCT or controlled trial. [pmid: 15701209].
1141 Eggers KM, Lagerqvist B, Venge P, et al. Prognostic value of biomarkers during and after non-ST-segment elevation acute coronary syndrome. Journal of the American College of Cardiology. 2009;54(4):357-64. Not CKD treatment. [pmid: 19608034].
1142 Egleston BL, Wong YN. Sensitivity analysis to investigate the impact of a missing covariate on survival analyses using cancer registry data. Statistics in Medicine. 2009;28(10):1498-511. Not CKD treatment. [pmid: 19235263].
1143 Eguchi A, Takei T, Yoshida T, et al. Combined cyclosporine and prednisolone therapy in adult patients with the first relapse of minimal-change nephrotic syndrome. Nephrology Dialysis Transplantation. 2010;25(1):124-9. Follow-up less than 6 months.
1144 Ehrich JHH, Geerlings C, Zivicnjak M, et al. Steroid-resistant idiopathic childhood nephrosis: overdiagnosed and undertreated. Nephrology Dialysis Transplantation. 2007;22(8):2183-93. Not RCT or controlled trial.
1145 Ehrlich M, Grabenwoger M, Cartes-Zumelzu F, et al. Operations on the thoracic aorta and hypothermic circulatory arrest: is aprotinin safe?. Journal of Thoracic & Cardiovascular Surgery. 1998;115(1):220-5. Sample size less than 50 patients. [pmid: 9451066].
1146 Eidemak I, Haaber AB, Feldt-Rasmussen B, et al. Exercise training and the progression of chronic renal failure. Nephron. 1997;75(1):36-40. Sample size less than 50 patients. [pmid: 9031268].
1147 Eijkelkamp WBA, Zhang Z, Brenner BM, et al. Renal function and risk for cardiovascular events in type 2 diabetic patients with hypertension: the RENAAL and LIFE studies. Journal of Hypertension. 2007;25(4):871-6. Not RCT or controlled trial. [pmid: 17351381].
1148 Eijkelkamp WBA, Zhang Z, Remuzzi G, et al. Albuminuria is a target for renoprotective therapy independent from blood pressure in patients with type 2 diabetic nephropathy: post hoc analysis from the Reduction of Endpoints in NIDDM with the Angiotensin II Antagonist Losartan (RENAAL) trial. Journal of the American Society of Nephrology. 2007;18(5):1540-6. Not RCT or controlled trial. [pmid: 17409317].
1149 Eikelboom JW, Hankey GJ. Associations of homocysteine, C-reactive protein and cardiovascular disease in patients with renal disease. Current Opinion in Nephrology & Hypertension. 2001;10(3):377-83. Not CKD treatment. [pmid: 11342801].
1150 Eisenberger U, Sollinger D, Stickel F, et al. Relationship between renal resistance index and renal function in liver transplant recipients after cessation of calcineurin inhibitor. Clinical Transplantation. 2009;23(4):499-504. Not CKD treatment. [pmid: 19486346].
1151 Eisenstein EL. DRIVE it home: making the case for prospective economic data collection in randomized clinical trials. Kidney International. 2008;74(12):1507-9. Not RCT or controlled trial. [pmid: 19034299].
1152 Eiskjaer H, Nielsen CB, Pedersen EB. Pressure-dependent, enhanced natriuretic response to low-dose, atrial natriuretic peptide infusion in essential hypertension. Journal of Internal Medicine. 1994;236(6):665-74. Not RCT or controlled trial. [pmid: 7989902].
1153 Eiskjaer H, Nielsen CB, Pedersen EB. Pressure-dependent distal tubular action of atrial natriuretic peptide in healthy humans. Journal of Hypertension. 1996;14(1):99-106. Not early CKD. [pmid: 12013501].
1154 Eiskjaer H, Nielsen CB, Sorensen SS, et al. Renal and hormonal actions of atrial natriuretic peptide during angiotensin II or noradrenaline infusion in man. European Journal of Clinical Investigation. 1996;26(7):584-95. Not CKD treatment. [pmid: 8864421].
1155 Eiskjaer H, Pedersen EB. Dose-response study of atrial natriuretic peptide bolus injection in healthy man. European Journal of Clinical Investigation. 1993;23(1):37-45. Follow-up less than 6 months. [pmid: 8383057].
1156 Eiskjaer H, Pedersen EB, Rasmussen LM, et al. Sustained release verapamil in renal hypertension. European Journal of Clinical Pharmacology. 1988;33(6):549-55. Sample size less than 50 patients. [pmid: 2966736].
1157 Eiskjaer H, Pedersen EB, Rasmussen LM, et al. Verapamil sustained-release in renal parenchymal hypertension: effect on blood pressure, kidney function, angiotensin II, aldosterone, arginine vasopressin, atrial natriuretic peptide, and lipoproteins. Journal of Cardiovascular Pharmacology. Suppl 4. 1989;13:S17-22. Sample size less than 50 patients. [pmid: 2475677].
1158 Eiskjaer H, Schmiegelow M, Jespersen B, et al. Renal and hormonal effects and tolerance of an ANP analogue in healthy man. European Journal of Clinical Pharmacology. 1991;41(6):547-54. Sample size less than 50 patients. [pmid: 1840038].
1159 Eiskjaer H, Sorensen SS, Danielsen H, et al. Glomerular and tubular antinatriuretic actions of low-dose angiotensin II infusion in man. Journal of Hypertension. 1992;10(9):1033-40. Sample size less than 50 patients. [pmid: 1328362].
1160 Ejaz AA, Beaver TM, Shimada M, et al. Uric acid: a novel risk factor for acute kidney injury in high-risk cardiac surgery patients?. American Journal of Nephrology. 2009;30(5):425-9. Not RCT or controlled trial. [pmid: 19752530].
1161 Ejerblad E, Fored CM, Lindblad P, et al. Obesity and risk for chronic renal failure. Journal of the American Society of Nephrology. 2006;17(6):1695-702. Sample size less than 50 patients. [pmid: 16641153].
1162 Ekinci EI, Thomas G, Thomas D, et al. Effects of salt supplementation on the albuminuric response to telmisartan with or without hydrochlorothiazide therapy in hypertensive patients with type 2 diabetes are modulated by habitual dietary salt intake. Diabetes Care. 2009;32(8):1398-403. Follow-up less than 6 months. [pmid: 19549737].
1163 Eknoyan G. Emergence of quantification in clinical investigation and the quest for certainty in therapeutics: the road from Hammurabi to Kefauver. Advances in Chronic Kidney Disease. 2005;12(1):88-95. Not RCT or controlled trial. [pmid: 15719339].
1164 Ekundayo OJ, Muchimba M, Aban IB, et al. Multimorbidity due to diabetes mellitus and chronic kidney disease and outcomes in chronic heart failure. American Journal of Cardiology. 2009;103(1):88-92. Not CKD treatment. [pmid: 19101236].
1165 Ekundayo OJ, Muchimba M, Aban IB, et al. Multimorbidity due to diabetes mellitus and chronic kidney disease and outcomes in chronic heart failure. American Journal of Cardiology. 2009;103(1):88-92. Not CKD treatment. [pmid: 19101236].
1166 El Kossi MMH, Ibrahim A, Lock TJ, et al. Impact of cardiac transplantation on kidney function: a single- center experience. Transplantation Proceedings. 2003;35(4):1527-31. Not CKD treatment. [pmid: 12826212].
1167 Elapavaluru S, Kellum JA. Why do patients die of acute kidney injury?. Acta Clinica Belgica - Supplementum. 2007;(2):326-31. Not CKD treatment. [pmid: 18283993].
1168 Eliahou HE, Cohen D, Ben-David A, et al. The calcium channel blocker nisoldipine delays progression of chronic renal failure in humans (preliminary communication). Cardiovascular Drugs & Therapy. 1988;1(5):523-8. Sample size less than 50 patients. [pmid: 3154680].
1169 Eliahou HE, Cohen D, Hellberg B, et al. Effect of the calcium channel blocker nisoldipine on the progression of chronic renal failure in man. American Journal of Nephrology. 1988;8(4):285-90. Sample size less than 50 patients. [pmid: 3189422].
1170 Elkayam U, Janmohamed M, Hatamizadeh P, et al. Impact of acute serum creatinine elevation in patients treated with nesiritide. Clinical Cardiology. 2009;32(4):215-9. Not CKD treatment. [pmid: 19353723].
1171 Ellis CN, Fradin MS, Messana JM, et al. Cyclosporine for plaque-type psoriasis. Results of a multidose, double-blind trial. New England Journal of Medicine. 1991;324(5):277-84. Not CKD treatment. [pmid: 1986287].
1172 Ellis M, Bernsen R, Ali-Zadeh H, et al. A safety and feasibility study comparing an intermittent high dose with a daily standard dose of liposomal amphotericin B for persistent neutropenic fever. Journal of Medical Microbiology. 1474. 2009;(Pt 11):58-85. Not CKD treatment.
1173 el-Sayed YM. Correlation between nephrotoxicity and pharmacokinetic parameters of gentamicin. Journal of Clinical Pharmacy & Therapeutics. 1994;19(4):267-71. Not CKD treatment. [pmid: 7989408].
1174 Elsendoorn TJ, Weijl NI, Mithoe S, et al. Chemotherapy-induced chromosomal damage in peripheral blood lymphocytes of cancer patients supplemented with antioxidants or placebo. Mutation Research. 2001;498(1-2):145-58. Not early CKD. [pmid: 11673080].
1175 Elseviers MM, Waller I, Nenoy D, et al. Evaluation of diagnostic criteria for analgesic nephropathy in patients with end-stage renal failure: results of the ANNE study. Analgesic Nephropathy Network of Europe. Nephrology Dialysis Transplantation. 1995;10(6):808-14. Follow-up less than 6 months.
1176 el-Sherif AE, Foda R, Norlen LJ, et al. Treatment of renal colic by prostaglandin synthetase inhibitors and avafortan (analgesic antispasmodic). British Journal of Urology. 1990;66(6):602-5. Not CKD treatment. [pmid: 2265331].
1177 Elung-Jensen T, Heisterberg J, Kamper AL, et al. Blood pressure response to conventional and low-dose enalapril in chronic renal failure. British Journal of Clinical Pharmacology. 2003;55(2):139-46. Sample size less than 50 patients. [pmid: 12580985].
1178 Elung-Jensen T, Heisterberg J, Sonne J, et al. Enalapril dosage in progressive chronic nephropathy: a randomised, controlled trial. European Journal of Clinical Pharmacology. 2005;61(2):87-96. Not relevant to key questions. [pmid: 15761754].
1179 Elung-Jensen T, Strandgaard S, Kamper AL. Longitudinal observations on circadian blood pressure variation in chronic kidney disease stages 3-5. Nephrology Dialysis Transplantation. 2008;23(9):2873-8. Sample size less than 50 patients.
1180 Elving LD, Wetzels JF, van Lier HJ, et al. Captopril and atenolol are equally effective in retarding progression of diabetic nephropathy. Results of a 2-year prospective, randomized study. Diabetologia. 1994;37(6):604-9. Sample size less than 50 patients. [pmid: 7926346].
1181 Ely H. Is pentoxifylline the drug of the decade?. Journal of the American Academy of Dermatology. 1994;30(4):639-42. Not RCT or controlled trial. [pmid: 8157792].
1182 Emery P. Cyclooxygenase-2: a major therapeutic advance?. American Journal of Medicine. 2001;110(1A):42S-5S. Not RCT or controlled trial. [pmid: 11165996].
1183 Endemann D, Marienhagen J, Stubanus M, et al. Volume independent stimulation of renin secretion by a single dose of amiloride in man. Arzneimittel-Forschung. 2002;52(9):677-83. Sample size less than 50 patients. [pmid: 12404882].
1184 Endre ZH, Walker RJ, Pickering JW, et al. Early intervention with erythropoietin does not affect the outcome of acute kidney injury (the EARLYARF trial). Kidney International. Jun. 2010;77(11):1020-30. Not CKD treatment. [pmid: 20164823].
1185 Engeler DS, Ackermann DK, Osterwalder JJ, et al. A double-blind, placebo controlled comparison of the morphine sparing effect of oral rofecoxib and diclofenac for acute renal colic. Journal of Urology. 2005;174(3):933-6. Not relevant to key questions. [pmid: 16093996].
1186 Engoren M. Does erythrocyte blood transfusion prevent acute kidney injury? Propensity-matched case control analysis. Anesthesiology. Nov. 2010;113(5):1126-33. Not CKD treatment. [pmid: 20966666].
1187 Ensrud KE, Lui LY, Taylor BC, et al. Renal function and risk of hip and vertebral fractures in older women. Archives of Internal Medicine. 2007;167(2):133-9. Not CKD treatment. [pmid: 17242313].
1188 Epstein M. Effects of ACE inhibitors and calcium antagonists on progression of chronic renal disease. Blood Pressure Supplement. 1995;2:108-12. Not CKD treatment. [pmid: 7582066].
1189 Epstein M. The benefits of ACE inhibitors and calcium antagonists in slowing progressive renal failure: focus on fixed-dose combination antihypertensive therapy. Renal Failure. 1996;18(6):813-32. Not RCT or controlled trial. [pmid: 8948517].
1190 Epstein M. Calcium antagonists and renal protection: emerging perspectives. Journal of Hypertension - Supplement. 1998;16(4):S17-25. Not RCT or controlled trial.
1191 Epstein M. Aldosterone as a determinant of cardiovascular and renal dysfunction. Journal of the Royal Society of Medicine. 2001;94(8):378-83. Not RCT or controlled trial. [pmid: 11461980].
1192 Epstein M. Aldosterone as a mediator of progressive renal disease: pathogenetic and clinical implications. American Journal of Kidney Diseases. 2001;37(4):677-88. Not RCT or controlled trial. [pmid: 11273866].
1193 Epstein M. Recent landmark clinical trials: how do they modify the therapeutic paradigm?. American Journal of Hypertension. 2002;15(7 Pt 2):82S-4S. Not RCT or controlled trial. [pmid: 12121010].
1194 Epstein M, Campese VM. Evolving role of calcium antagonists in the management of hypertension. Medical Clinics of North America. 2004;88(1):149-65. Not relevant to key questions. [pmid: 14871057].
1195 Epstein M, Leary E, Laskey R, et al. Atorvastatin does not induce glomerular or tubular dysfunction even at high doses. Journal of the CardioMetabolic Syndrome. 2007;2(3):163-7. Sample size less than 50 patients. [pmid: 17786079].
1196 Epstein M, Tobe S. What is the optimal strategy to intensify blood pressure control and prevent progression of renal failure?. Current Hypertension Reports. 2001;3(5):422-8. Not RCT or controlled trial. [pmid: 11551378].
1197 Epstein M, Williams GH, Weinberger M, et al. Selective aldosterone blockade with eplerenone reduces albuminuria in patients with type 2 diabetes. Clinical Journal of The American Society of Nephrology: CJASN. 2006;1(5):940-51. Follow-up less than 6 months. [pmid: 17699311].
1198 Eray O, Cete Y, Oktay C, et al. Intravenous single-dose tramadol versus meperidine for pain relief in renal colic. European Journal of Anaesthesiology. 2002;19(5):368-70. Not CKD treatment. [pmid: 12095018].
1199 Erdine S, Ari O, Zanchetti A, et al. ESH-ESC guidelines for the management of hypertension. Herz. 2006;31(4):331-8. Not early CKD. [pmid: 16810473].
1200 Erdogan A, Davidson CJ. Recent clinical trials of iodixanol. Reviews in Cardiovascular Medicine. Suppl 5. 2003;4:S43-50. Not CKD treatment. [pmid: 14668709].
1201 Eriksson LO, Beermann B, Kallner M. Renal function and tubular transport effects of sulindac and naproxen in chronic heart failure. Clinical Pharmacology & Therapeutics. 1987;42(6):646-54. Sample size less than 50 patients. [pmid: 3319349].
1202 Eriksson LO, Sturfelt G, Thysell H, et al. Effects of sulindac and naproxen on prostaglandin excretion in patients with impaired renal function and rheumatoid arthritis. American Journal of Medicine. 1990;89(3):313-21. Not CKD treatment. [pmid: 2203262].
1203 Erley CM, Bader B, Scheu M, et al. Renal hemodynamics in essential hypertensives treated with losartan. Clinical Nephrology. Suppl 1. 1995;43:S8-11. Sample size less than 50 patients. [pmid: 7781206].
1204 Erley CM, Duda SH, Rehfuss D, et al. Prevention of radiocontrast-media-induced nephropathy in patients with pre-existing renal insufficiency by hydration in combination with the adenosine antagonist theophylline. Nephrology Dialysis Transplantation. 1999;14(5):1146-9. Follow-up less than 6 months.
1205 Erley CM, Duda SH, Schlepckow S, et al. Adenosine antagonist theophylline prevents the reduction of glomerular filtration rate after contrast media application. Kidney International. 1994;45(5):1425-31. Not CKD treatment. [pmid: 8072255].
1206 Erley CM, Haefele U, Heyne N, et al. Microalbuminuria in essential hypertension. Reduction by different antihypertensive drugs. Hypertension. 1993;21(6 Pt 1):810-5. Sample size less than 50 patients. [pmid: 8500862].
1207 Erley CM, Harrer U, Kramer BK, et al. Renal hemodynamics and reduction of proteinuria by a vasodilating beta blocker versus an ACE inhibitor. Kidney International. 1992;41(5):1297-303. Sample size less than 50 patients. [pmid: 1614045].
1208 Ermolenko VM, Kukhtevich AV, Dedov II, et al. Parlodel treatment of uremic hypogonadism in men. Nephron. 1986;42(1):19-22. Sample size less than 50 patients. [pmid: 3079888].
1209 Erstad BL, Gales BJ, Rappaport WD. The use of albumin in clinical practice. Archives of Internal Medicine. 1991;151(5):901-11. Not CKD treatment. [pmid: 1902657].
1210 Eschbach JW, Abdulhadi MH, Browne JK, et al. Recombinant human erythropoietin in anemic patients with end-stage renal disease. Results of a phase III multicenter clinical trial. Annals of Internal Medicine. 1989;111(12):992-1000. Not early CKD. [pmid: 2688507].
1211 Escobedo J, Rana JS, Lombardero MS, et al. Association between albuminuria and duration of diabetes and myocardial dysfunction and peripheral arterial disease among patients with stable coronary artery disease in the BARI 2D study. Mayo Clinic Proceedings. 2010;85(1):41-6. Not CKD treatment. [pmid: 20042560].
1212 Escudier B, Lethiec JL, Angevin E, et al. Totally implanted catheters to reduce catheter-related infections in patients receiving interleukin-2: a 2-year experience. Supportive Care in Cancer. 1995;3(5):297-300. Not CKD treatment. [pmid: 8520875].
1213 Eskens FALM, Sleijfer S. The use of bevacizumab in colorectal, lung, breast, renal and ovarian cancer: where does it fit?. European Journal of Cancer. 2008;44(16):2350-6. Not CKD treatment. [pmid: 18789679].
1214 Esmail ZN, Loewen PS. Losartan as an alternative to ACE inhibitors in patients with renal dysfunction. Annals of Pharmacotherapy. 1998;32(10):1096-8. Not RCT or controlled trial. [pmid: 9793603].
1215 Esnault VL, Potiron-Josse M, Testa A, et al. Captopril but not acebutolol, prazosin or indomethacin decreases postexercise proteinuria. Nephron. 1991;58(4):437-42. Sample size less than 50 patients. [pmid: 1922609].
1216 Esnault VLM. Radiocontrast media-induced nephrotoxicity in patients with renal failure: rationale for a new double-blind, prospective, randomized trial testing calcium channel antagonists. Nephrology Dialysis Transplantation. 2002;17(8):1362-4. Not RCT or controlled trial.
1217 Esnault VLM, Brown EA, Apetrei E, et al. The effects of amlodipine and enalapril on renal function in adults with hypertension and nondiabetic nephropathies: a 3-year, randomized, multicenter, double-blind, placebo-controlled study. Clinical Therapeutics. 2008;30(3):482-98. Not CKD treatment. [pmid: 18405787].
1218 Esnault VLM, Ekhlas A, Delcroix C, et al. Diuretic and enhanced sodium restriction results in improved antiproteinuric response to RAS blocking agents. Journal of the American Society of Nephrology. 2005;16(2):474-81. Not relevant to key questions. [pmid: 15615822].
1219 Esnault VLM, Ekhlas A, Nguyen JM, et al. Diuretic uptitration with half dose combined ACEI + ARB better decreases proteinuria than combined ACEI + ARB uptitration. Nephrology Dialysis Transplantation. Jul. 2010;25(7):2218-24. Follow-up less than 6 months.
1220 Estacio RO, Coll JR, Tran ZV, et al. Effect of intensive blood pressure control with valsartan on urinary albumin excretion in normotensive patients with type 2 diabetes. American Journal of Hypertension. 2006;19(12):1241-8. Not CKD treatment. [pmid: 17161769].
1221 Estacio RO, Regensteiner JG, Wolfel EE, et al. The association between diabetic complications and exercise capacity in NIDDM patients. Diabetes Care. 1998;21(2):291-5. Not RCT or controlled trial. [pmid: 9539998].
1222 Estacio RO, Savage S, Nagel NJ, et al. Baseline characteristics of participants in the Appropriate Blood Pressure Control in Diabetes trial. Controlled Clinical Trials. 1996;17(3):242-57. Not RCT or controlled trial. [pmid: 8877260].
1223 Euser AM, Zoccali C, Jager KJ, et al. Cohort studies: prospective versus retrospective. Nephron. 2009;113(3):c214-7. Not RCT or controlled trial. [pmid: 19690438].
1224 Evans DA, Buring J, Mayrent S, et al. Qualitative overview of randomized trials of aminoglycosides. American Journal of Medicine. 1986;80(6B):39-43. Not relevant to key questions. [pmid: 3524219].
1225 Eyileten T, Sonmez A, Saglam M, et al. Effect of renin-angiotensin-aldosterone system (RAAS) blockade on visfatin levels in diabetic nephropathy. Nephrology. Mar. 2010;15(2):225-9. Follow-up less than 6 months. [pmid: 20470283].
1226 Fabrizi F, Ganeshan SV, Dixit V, et al. Meta-analysis: the adjuvant role of granulocyte macrophage-colony stimulating factor on immunological response to hepatitis B virus vaccine in end-stage renal disease. Alimentary Pharmacology & Therapeutics. 2006;24(5):789-96. Sample size less than 50 patients. [pmid: 16918882].
1227 Faddy SC. Significant statistical heterogeneity in a meta-analysis of the usefulness of acetylcysteine for prevention of contrast nephropathy. American Journal of Cardiology. 2004;94(3):414. Not relevant to key questions. [pmid: 15276125].
1228 Faenza A, Catena F, Nardo B, et al. Kidney preservation with university of Wisconsin and Celsior solution: a prospective multicenter randomized study. Transplantation. 2001;72(7):1274-7. Not CKD treatment. [pmid: 11602855].
1229 Fagher B, Henningsen N, Hulthen L, et al. Antihypertensive and renal effects of enalapril and slow-release verapamil in essential hypertension. A double-blind, randomized study. European Journal of Clinical Pharmacology. Suppl 1. 1990;39:S41-3. Sample size less than 50 patients. [pmid: 2261943].
1230 Fagnani F, Souchet T, Labed D, et al. Management of hypertension and screening of renal complications by GPs in diabetic type 2 patients (France--2001). Diabetes & Metabolism. 2003;29(1):58-64. Not RCT or controlled trial. [pmid: 12629449].
1231 Fakeye TO, Adegoke AO, Omoyeni OC, et al. Effects of water extract of Hibiscus sabdariffa, Linn (Malvaceae) ‘Roselle’ on excretion of a diclofenac formulation. Phytotherapy Research. 2007;21(1):96-8. Not relevant to key questions. [pmid: 17094172].
1232 Falardeau P, Champagne P, Poyet P, et al. Neovastat, a naturally occurring multifunctional antiangiogenic drug, in phase III clinical trials. Seminars in Oncology. 2001;28(6):620-5. Not early CKD. [pmid: 11740820].
1233 Falkiewicz K, Nahaczewska W, Boratynska M, et al. Tacrolimus decreases tubular phosphate wasting in renal allograft recipients. Transplantation Proceedings. 2003;35(6):2213-5. Not CKD treatment. [pmid: 14529892].
1234 Fallo F, Gregianin M, Bui F, et al. Comparison of the antihypertensive and renal effects of tertatolol and nadolol in hypertensive patients with mild renal impairment. European Journal of Clinical Pharmacology. 1991;40(3):309-11. Follow-up less than 6 months. [pmid: 1676368].
1235 Fanti P, Asmis R, Stephenson TJ, et al. Positive effect of dietary soy in ESRD patients with systemic inflammation--correlation between blood levels of the soy isoflavones and the acute-phase reactants. Nephrology Dialysis Transplantation. 2006;21(8):2239-46. Not RCT or controlled trial.
1236 Farbakhsh K, Kasiske BL. Dyslipidemias in patients who have chronic kidney disease. Medical Clinics of North America. 2005;89(3):689-99. Not RCT or controlled trial. [pmid: 15755473].
1237 Farbom P, Wahlstrand B, Almgren P, et al. Interaction between renal function and microalbuminuria for cardiovascular risk in hypertension: the nordic diltiazem study. Hypertension. 2008;52(1):115-22. Not early CKD. [pmid: 18504324].
1238 Farkas G, Degi R, Voros P. Long-term effects of fetal islet transplantation on complication of diabetes, as compared with effects of intensive insulin therapy. Transplantation Proceedings. 1995;27(6):3145. Not RCT or controlled trial. [pmid: 8539883].
1239 Farker K, Merkel U, Schweer H, et al. Effects of short-term treatment with diclofenac-colestyramine on renal function and urinary prostanoid excretion in patients with type-2 diabetes. European Journal of Clinical Pharmacology. 2002;58(2):85-91. Sample size less than 50 patients. [pmid: 12012138].
1240 Farker K, Nassr N, Huck F, et al. Dipyrone and diclofenac do not influence creatinine-clearance, inulin-clearance or PAH-clearance in healthy male volunteers. International Journal of Clinical Pharmacology & Therapeutics. 1995;33(3):125-30. Sample size less than 50 patients. [pmid: 7599909].
1241 Farquhar W, Kenney L. Renal effects of ibuprofen during sodium restriction in the aged. Journal of the American Geriatrics Society. 2000;48(1):106-8. Not CKD treatment. [pmid: 10642036].
1242 Farquhar WB, Kenney WL. Age and renal prostaglandin inhibition during exercise and heat stress. Journal of Applied Physiology. 1999;86(6):1936-43. Not CKD treatment. [pmid: 10368359].
1243 Farquhar WB, Morgan AL, Zambraski EJ, et al. Effects of acetaminophen and ibuprofen on renal function in the stressed kidney. Journal of Applied Physiology. 1999;86(2):598-604. Not CKD treatment. [pmid: 9931196].
1244 Farvid MS, Jalali M, Siassi F, et al. Comparison of the effects of vitamins and/or mineral supplementation on glomerular and tubular dysfunction in type 2 diabetes. Diabetes Care. 2005;28(10):2458-64. Sample size less than 50 patients. [pmid: 16186280].
1245 Fassbinder W, Quarder O, Waltz A. Treatment with carvedilol is associated with a significant reduction in microalbuminuria: a multicentre randomised study. International Journal of Clinical Practice. 1999;53(7):519-22. Follow-up less than 6 months. [pmid: 10692737].
1246 Fassett RG, Ball MJ, Robertson IK, et al. Baseline serum lipids and renal function in chronic kidney disease patients entering the LORD trial. International Journal of Clinical Pharmacology & Therapeutics. 2006;44(11):580-8. Not early CKD. [pmid: 17176625].
1247 Fassett RG, Ball MJ, Robertson IK, et al. The Lipid lowering and Onset of Renal Disease (LORD) Trial: a randomized double blind placebo controlled trial assessing the effect of atorvastatin on the progression of kidney disease. BMC Nephrology. 2008;9(4). Not relevant to key questions.
1248 Fassett RG, Gobe GC, Peake JM, et al. Omega-3 polyunsaturated fatty acids in the treatment of kidney disease. American Journal of Kidney Diseases. Oct. 2010;56(4):728-42. Not CKD treatment. [pmid: 20493605].
1249 Fassett RG, Robertson IK, Ball MJ, et al. Effects of atorvastatin on arterial stiffness in chronic kidney disease: a randomised controlled trial. Journal of Atherosclerosis & Thrombosis. Mar. 31. 2010;17(3):235-41. Sample size less than 50 patients. [pmid: 20032570].
1250 Fauli A, Gomar C, Campistol JM, et al. Kidney-specific proteins in patients receiving aprotinin at high- and low-dose regimens during coronary artery bypass graft with cardiopulmonary bypass. European Journal of Anaesthesiology. 2005;22(9):666-71. Sample size less than 50 patients. [pmid: 16163912].
1251 Fauvel JP, Najem R, Maakel N, et al. Effects of moxonidine on stress-induced peak blood pressure and renal function: a randomized, double-blind, placebo-controlled crossover study. Journal of Cardiovascular Pharmacology. 1998;32(3):495-9. Follow-up less than 6 months. [pmid: 9733365].
1252 Fauvel JP, Najem R, Ryon B, et al. Effects of rilmenidine on stress-induced peak blood pressure and renal function. Journal of Cardiovascular Pharmacology. 1999;34(1):41-5. Follow-up less than 6 months. [pmid: 10413065].
1253 Fauvel JP, Velon S, Berra N, et al. Effects of losartan on renal function in patients with essential hypertension. Journal of Cardiovascular Pharmacology. 1996;28(2):259-63. Sample size less than 50 patients. [pmid: 8856482].
1254 Fava S, Azzopardi J, Hattersley AT, et al. Increased prevalence of proteinuria in diabetic sibs of proteinuric type 2 diabetic subjects. American Journal of Kidney Diseases. 2000;35(4):708-12. Not RCT or controlled trial. [pmid: 10739793].
1255 Favre H, Miescher PA, Lemoine R. Use of cyclosporine in the treatment of autoimmune disorders. Transplantation Proceedings. 1994;26(6):3194-6. Not RCT or controlled trial. [pmid: 7998112].
1256 Fedoruk LM, Wang H, Conaway MR, et al. Statin therapy improves outcomes after valvular heart surgery. Annals of Thoracic Surgery. 2008;85(5):1521-5. discussion 5-6. Not CKD treatment. [pmid: 18442531].
1257 Feindt PR, Walcher S, Volkmer I, et al. Effects of high-dose aprotinin on renal function in aortocoronary bypass grafting. Annals of Thoracic Surgery. 1995;60(4):1076-80. Sample size less than 50 patients. [pmid: 7574952].
1258 Feiten SF, Draibe SA, Watanabe R, et al. Short-term effects of a very-low-protein diet supplemented with ketoacids in nondialyzed chronic kidney disease patients. European Journal of Clinical Nutrition. 2005;59(1):129-36. Not CKD treatment. [pmid: 15354199].
1259 Feldt-Rasmussen B. The development of nephropathy in insulin-dependent diabetes mellitus is associated with poor glycemic control. Transplantation Proceedings. 1994;26(2):371-2. Sample size less than 50 patients. [pmid: 8171466].
1260 Feldt-Rasmussen B, El Nahas M. Potential role of growth factors with particular focus on growth hormone and insulin-like growth factor-1 in the management of chronic kidney disease. Seminars in Nephrology. 2009;29(1):50-8. Not relevant to key questions. [pmid: 19121474].
1261 Feldt-Rasmussen B, Jensen T, Dieperink H, et al. Nephrotoxicity of cyclosporin A in patients with newly diagnosed type 1 diabetes mellitus. Diabetic Medicine. 1990;7(5):429-33. Sample size less than 50 patients. [pmid: 2142040].
1262 Feldt-Rasmussen B, Mathiesen ER, Deckert T. Effect of two years of strict metabolic control on progression of incipient nephropathy in insulin-dependent diabetes. Lancet. 1986;2(8519):1300-4. Sample size less than 50 patients. [pmid: 2878175].
1263 Feldt-Rasmussen B, Mathiesen ER, Hegedus L, et al. Kidney function during 12 months of strict metabolic control in insulin-dependent diabetic patients with incipient nephropathy. New England Journal of Medicine. 1986;314(11):665-70. Sample size less than 50 patients. [pmid: 3513009].
1264 Felisart J, Rimola A, Arroyo V, et al. Cefotaxime is more effective than is ampicillin-tobramycin in cirrhotics with severe infections. Hepatology. 1985;5(3):457-62. Not early CKD. [pmid: 3888810].
1265 Fellstrom B, Holdaas H, Jardine AG, et al. Cardiovascular disease in patients with renal disease: the role of statins. Current Medical Research & Opinion. 2009;25(1):271-85. Follow-up less than 6 months. [pmid: 19210158].
1266 Feramisco JD, Berger TG, Steinhoff M. Innovative management of pruritus. Dermatologic Clinics. Jul. 2010;28(3):467-78. Not CKD treatment. [pmid: 20510757].
1267 Ferder L, Daccordi H, Martello M, et al. Angiotensin converting enzyme inhibitors versus calcium antagonists in the treatment of diabetic hypertensive patients. Hypertension. 1992;19(2 Suppl):II237-42. Sample size less than 50 patients. [pmid: 1735586].
1268 Ferdinand KC, Taylor C. The management of hypertension with angiotensin receptor blockers in special populations. Clinical Cornerstone. Suppl 3. 2009;9:S5-17. Not CKD treatment. [pmid: 19409356].
1269 Ferguson JA, Sundblad KJ, Becker PK, et al. Role of duration of diuretic effect in preventing sodium retention. Clinical Pharmacology & Therapeutics. 1997;62(2):203-8. Sample size less than 50 patients. [pmid: 9284857].
1270 Fernandez PG, Snedden W, Vasdev S, et al. Bevantolol attenuates thiazide stimulated renin secretion and catecholamine release in diuretic resistant hypertensives. Canadian Journal of Cardiology. 1989;5(2):93-7. Sample size less than 50 patients. [pmid: 2565158].
1271 Fernandez R, Puig JG, Rodriguez-Perez JC, et al. Effect of two antihypertensive combinations on metabolic control in type-2 diabetic hypertensive patients with albuminuria: a randomised, double-blind study. Journal of Human Hypertension. 2001;15(12):849-56. Follow-up less than 6 months. [pmid: 11773987].
1272 Fernandez-Andrade C, Russo D, Iversen B, et al. Comparison of losartan and amlodipine in renally impaired hypertensive patients. Kidney International - Supplement. 1998;68:S120-4. Sample size less than 50 patients. [pmid: 9839295].
1273 Ferrari P, Gadient G, Cozzio A, et al. Reduced plasma cyclic GMP but normal renal responses to atrial natriuretic factor in pre-hypertension. Blood Pressure. 1996;5(1):16-26. Follow-up less than 6 months. [pmid: 8777468].
1274 Ferrari P, Marti HP, Pfister M, et al. Additive antiproteinuric effect of combined ACE inhibition and angiotensin II receptor blockade. Journal of Hypertension. 2002;20(1):125-30. Sample size less than 50 patients. [pmid: 11791035].
1275 Ferrario F, Barone MT, Landoni G, et al. Acetylcysteine and non-ionic isosmolar contrast-induced nephropathy--a randomized controlled study. Nephrology Dialysis Transplantation. 2009;24(10):3103-7. Not CKD treatment.
1276 Ferretti A, Judd JT, Ballard-Barbash R, et al. Effect of fish oil supplementation on the excretion of the major metabolite of prostaglandin E in healthy male subjects. Lipids. 1991;26(7):500-3. Not CKD treatment. [pmid: 1943493].
1277 Ferri C, Baldoncini R, Bellini C, et al. Hormonal and renal responses to atrial natriuretic peptide infusion in low-renin hypertension. American Journal of Nephrology. 1995;15(3):222-9. Sample size less than 50 patients. [pmid: 7618647].
1278 Ferris M, Shoham DA, Pierre-Louis M, et al. High prevalence of unlabeled chronic kidney disease among inpatients at a tertiary-care hospital. American Journal of the Medical Sciences. 2009;337(2):93-7. Not CKD treatment. [pmid: 19214023].
1279 Feutren G, von Graffenried B. Pharmacology of cyclosporin A (Sandimmun) and clinical experience in inflammatory bowel diseases. Schweizerische Medizinische Wochenschrift. Journal Suisse de Medecine. 1991;121(20):748-53. Not CKD treatment. [pmid: 2057741].
1280 Fiaccadori E, Maggiore U, Rotelli C, et al. Effects of different energy intakes on nitrogen balance in patients with acute renal failure: a pilot study. Nephrology Dialysis Transplantation. 2005;20(9):1976-80. Not relevant to key questions.
1281 Field TS, Rochon P, Lee M, et al. Computerized clinical decision support during medication ordering for long-term care residents with renal insufficiency. Journal of the American Medical Informatics Association. 2009;16(4):480-5. Not CKD treatment. [pmid: 19390107].
1282 Field TS, Rochon P, Lee M, et al. Computerized clinical decision support during medication ordering for long-term care residents with renal insufficiency. Journal of the American Medical Informatics Association. 2009;16(4):480-5. Not CKD treatment. [pmid: 19390107].
1283 Fifer MA, Molina CR, Quiroz AC, et al. Hemodynamic and renal effects of atrial natriuretic peptide in congestive heart failure. American Journal of Cardiology. 1990;65(3):211-6. Not CKD treatment. [pmid: 2136969].
1284 Fine JD, Johnson LB, Weiner M, et al. Cause-specific risks of childhood death in inherited epidermolysis bullosa. Journal of Pediatrics. 2008;152(2):276-80. Not CKD treatment. [pmid: 18206702].
1285 Fischbach R, Landwehr P, Lackner K, et al. Iodixanol vs iopamidol in intravenous DSA of the abdominal aorta and lower extremity arteries: a comparative phase-III trial. European Radiology. 1996;6(1):9-13. Not CKD treatment. [pmid: 8797943].
1286 Fischer D, Cline K, Plone MA, et al. Results of a randomized crossover study comparing once-daily and thrice-daily sevelamer dosing. American Journal of Kidney Diseases. 2006;48(3):437-44. Not relevant to key questions. [pmid: 16931217].
1287 Fischer U, Salzsieder E, Menzel R, et al. Primary health care of diabetic patients in a specialized outpatient setting: a DIABCARE-based analysis. Diabete et Metabolisme. 1993;19(1 Pt 2):188-94. Not RCT or controlled trial. [pmid: 8314425].
1288 Fischer UM, Tossios P, Mehlhorn U. Renal protection by radical scavenging in cardiac surgery patients. Current Medical Research & Opinion. 2005;21(8):1161-4. Not relevant to key questions. [pmid: 16083524].
1289 Fishbane S, Chittineni H, Packman M, et al. Oral paricalcitol in the treatment of patients with CKD and proteinuria: a randomized trial. American Journal of Kidney Diseases. 2009;54(4):647-52. Not early CKD. [pmid: 19596163].
1290 Fishbane S, Miyawaki N, Szczech LA. Hypothesis: an erythropoietin honeymoon phase exists. Kidney International. Oct. 2010;78(7):646-9. Not CKD treatment. [pmid: 20631675].
1291 Fishbane S, Pannier A, Liogier X, et al. Pharmacokinetic and pharmacodynamic properties of methoxy polyethylene glycol-epoetin beta are unaffected by the site of subcutaneous administration. Journal of Clinical Pharmacology. 2007;47(11):1390-7. Not RCT or controlled trial. [pmid: 17962427].
1292 Fisher AR, Jones P, Barlow P, et al. The influence of mannitol on renal function during and after open-heart surgery. Perfusion. 1998;13(3):181-6. Not CKD treatment. [pmid: 9638715].
1293 Fisher CJ Jr., Opal SM, Lowry SF, et al. Role of interleukin-1 and the therapeutic potential of interleukin-1 receptor antagonist in sepsis. Circulatory Shock. 1994;44(1):1-8. Not RCT or controlled trial. [pmid: 7704933].
1294 Fitchett D. Have angiotensin receptor blockers lived up to expectations?. Canadian Journal of Cardiology. 2005;21(7):569-75. Sample size less than 50 patients. [pmid: 15940354].
1295 Flaa A, Aksnes TA, Strand A, et al. Complications of hypertension and the role of angiotensin receptor blockers in hypertension trials. Expert Review of Cardiovascular Therapy. 2007;5(3):451-61. Not human studies. [pmid: 17489670].
1296 Flaa A, Kjeldsen SE. Are all the hypertensives made equal?. Herz. 2006;31(4):323-30. Not RCT or controlled trial. [pmid: 16810472].
1297 Flack JM. Effect of ramipril versus amlodipine on renal outcomes in hypertensive nephrosclerosis. Current Hypertension Reports. 2002;4(3):183-4. Not RCT or controlled trial. [pmid: 12003698].
1298 Flack JM. Maximising antihypertensive effects of angiotensin II receptor blockers with thiazide diuretic combination therapy: focus on irbesartan/hydrochlorothiazide. International Journal of Clinical Practice. 2007;61(12):2093-102. Not relevant to key questions. [pmid: 17887997].
1299 Flack JR, Molyneaux L, Willey K, et al. Regression of microalbuminuria: results of a controlled study, indapamide versus captopril. Journal of Cardiovascular Pharmacology. Suppl 6. 1993;22:S75-7. Follow-up less than 6 months. [pmid: 7508065].
1300 Flapan AD, Davies E, Waugh C, et al. Posture determines the nature of the interaction between angiotensin converting enzyme inhibitors and loop diuretics in patients with chronic cardiac failure. International Journal of Cardiology. 1991;33(3):377-83. Follow-up less than 6 months. [pmid: 1761331].
1301 Fleisch M, Sutsch G, Yan XW, et al. Systemic, pulmonary, and renal hemodynamic effects of endothelin ET(A/B)-receptor blockade in patients with maintained left ventricular function. Journal of Cardiovascular Pharmacology. 2000;36(3):302-9. Not early CKD. [pmid: 10975586].
1302 Fleming JS, Persaud L, Zivanovic MA. A general equation for estimating glomerular filtration rate from a single plasma sample. [Erratum appears in Nucl Med Commun. 2005 Oct; 26(10):933]. Nuclear Medicine Communications. 2005;26(8):743-8. Sample size less than 50 patients. [pmid: 16000995].
1303 Fleming JS, Persaud L, Zivanovic MA. Quality control of slope-intercept measurements of glomerular filtration rate using single-sample estimates. Nuclear Medicine Communications. 2005;26(8):737-42. Follow-up less than 6 months. [pmid: 16000994].
1304 Flesch M, Knipp S, Kessler G, et al. ARTA: AT1-receptor blocker therapy in patients undergoing coronary artery bypass grafting. Clinical Research in Cardiology. 2009;98(1):33-43. Not CKD treatment. [pmid: 18853093].
1305 Fliser D, Dikow R, Demukaj S, et al. Opposing effects of angiotensin II on muscle and renal blood flow under euglycemic conditions. Journal of the American Society of Nephrology. 2000;11(11):2001-6. Sample size less than 50 patients. [pmid: 11053475].
1306 Fliser D, Haller H. Angiotensin II subtype 1-receptor antagonists in the treatment of diabetic nephropathy. Journal of Hypertension - Supplement. 2001;19(1):S57-60. Not RCT or controlled trial.
1307 Fliser D, Rett K, Hubinger A, et al. Influence of ACE inhibition on glucose tolerance in patients with stable chronic renal failure. Nephrology Dialysis Transplantation. 1995;10(5):643-7. Sample size less than 50 patients.
1308 Fliser D, Ritz E. Serum cystatin C concentration as a marker of renal dysfunction in the elderly. American Journal of Kidney Diseases. 2001;37(1):79-83. Not RCT or controlled trial. [pmid: 11136171].
1309 Fliser D, Schroter M, Neubeck M, et al. Coadministration of thiazides increases the efficacy of loop diuretics even in patients with advanced renal failure. Kidney International. 1994;46(2):482-8. Not early CKD. [pmid: 7967362].
1310 Fliser D, Zurbruggen I, Mutschler E, et al. Coadministration of albumin and furosemide in patients with the nephrotic syndrome. Kidney International. 1999;55(2):629-34. Sample size less than 50 patients. [pmid: 9987087].
1311 Flordal PA, Ljungstrom KG. Renal effects of high dose desmopressin and dextran. A study in normal subjects and in patients undergoing total hip replacement. Acta Anaesthesiologica Scandinavica. 1993;37(1):1-6. Sample size less than 50 patients. [pmid: 7678711].
1312 Fluck RJ, Raine AE. ACE inhibitors in non-diabetic renal disease. British Heart Journal. 1994;72(3 Suppl):S46-51. Not RCT or controlled trial. [pmid: 7946803].
1313 Fogari R, Corradi L, Zoppi A, et al. Addition of manidipine improves the antiproteinuric effect of candesartan in hypertensive patients with type II diabetes and microalbuminuria. American Journal of Hypertension. 2007;20(10):1092-6. Not RCT or controlled trial. [pmid: 17903693].
1314 Fogari R, Derosa G, Zoppi A, et al. Effect of telmisartan-amlodipine combination at different doses on urinary albumin excretion in hypertensive diabetic patients with microalbuminuria. American Journal of Hypertension. 2007;20(4):417-22. Not CKD treatment. [pmid: 17386350].
1315 Fogari R, Mugellini A, Zoppi A, et al. Effect of successful hypertension control by manidipine or lisinopril on albuminuria and left ventricular mass in diabetic hypertensive patients with microalbuminuria. European Journal of Clinical Pharmacology. 2005;61(7):483-90. Not CKD treatment. [pmid: 16021438].
1316 Fogari R, Zoppi A, Corradi L, et al. Long-term effects of ramipril and nitrendipine on albuminuria in hypertensive patients with type II diabetes and impaired renal function. Journal of Human Hypertension. 1999;13(1):47-53. Not relevant to key questions. [pmid: 9928752].
1317 Foley RN. Do we know the correct hemoglobin target for anemic patients with chronic kidney disease?. Clinical Journal of The American Society of Nephrology: CJASN. 2006;1(4):678-84. Not relevant to key questions. [pmid: 17699272].
1318 Foley RN. Target hemoglobin trials in chronic kidney disease: design and interpretation issues. Pediatric Nephrology. 2009;24(12):2279-85. Not CKD treatment. [pmid: 19221807].
1319 Fontsere N, Bonal J, Navarro M, et al. A comparison of prediction equations for estimating glomerular filtration rate in adult patients with chronic kidney disease stages 4-5. Effect of nutritional status and age. Nephron. 4. 2006;104:c160-8. Not RCT or controlled trial. [pmid: 16943683].
1320 Forbes JM, Soulis T, Thallas V, et al. Renoprotective effects of a novel inhibitor of advanced glycation. Diabetologia. 2001;44(1):108-14. Not human studies. [pmid: 11206401].
1321 Ford I, Bezlyak V, Stott DJ, et al. Reduced glomerular filtration rate and its association with clinical outcome in older patients at risk of vascular events: secondary analysis. PLoS Medicine / Public Library of Science. 2009;6(1):e16. Not CKD treatment.
1322 Foreman BH, Chambliss ML. Clinical inquiries. Are ARBs or ACE inhibitors preferred for nephropathy in diabetes?. Journal of Family Practice. 2004;53(3):241-2. Not early CKD. [pmid: 15000928].
1323 Fornos JA, Andres NF, Andres JC, et al. A pharmacotherapy follow-up program in patients with type-2 diabetes in community pharmacies in Spain. Pharmacy World & Science. 2006;28(2):65-72. Not relevant to key questions. [pmid: 16791717].
1324 Forrester DL, Britton J, Lewis SA, et al. Impact of adopting low sodium diet on biomarkers of inflammation and coagulation: a randomised controlled trial. Journal of Nephrology. Jan-Feb. 2010;23(1):49-54. Not CKD treatment. [pmid: 20091486].
1325 Forsblom C, Hiukka A, Leinonen ES, et al. Effects of long-term fenofibrate treatment on markers of renal function in type 2 diabetes: the FIELD Helsinki substudy. Diabetes Care. 2010;33(2):215-20. Not CKD treatment. [pmid: 19846798].
1326 Forsyth DR, Roberts CJ. Nitrendipine and renal tubular function in human volunteers. Journal of Clinical Pharmacology. 1992;32(3):284-9. Not CKD treatment. [pmid: 1564134].
1327 Forzley BR, Sontrop JM, Macnab JJ, et al. Treating TTP/HUS with plasma exchange: a single centre's 25-year experience. British Journal of Haematology. 2008;143(1):100-6. Not CKD treatment. [pmid: 18691172].
1328 Foucan L, Bourhis V, Bangou J, et al. A randomized trial of captopril for microalbuminuria in normotensive adults with sickle cell anemia. American Journal of Medicine. 1998;104(4):339-42. Sample size less than 50 patients. [pmid: 9576406].
1329 Foucher C, Brugere L, Ansquer JC. Fenofibrate, homocysteine and renal function. Current Vascular Pharmacology. Sep. 2010;8(5):589-603. Not RCT or controlled trial. [pmid: 20507276].
1330 Fouque D, Aparicio M. Eleven reasons to control the protein intake of patients with chronic kidney disease. Nature Clinical Practice Nephrology. 2007;3(7):383-92. Not CKD treatment.
1331 Fouque D, Guebre-Egziabher F. Do low-protein diets work in chronic kidney disease patients?. Seminars in Nephrology. 2009;29(1):30-8. Not RCT or controlled trial. [pmid: 19121472].
1332 Fouque D, Laville M. Low protein diets for chronic kidney disease in non diabetic adults. Cochrane Database of Systematic Reviews. 2009;(3):CD001892. Not RCT or controlled trial. [pmid: 19588328].
1333 Fouque D, Laville M, Boissel JP. Low protein diets for chronic kidney disease in non diabetic adults. Cochrane Database of Systematic Reviews. 2006;(2):CD001892. Not RCT or controlled trial. [pmid: 16625550].
1334 Fouque D, Le Bouc Y, Laville M, et al. Insulin-like growth factor-1 and its binding proteins during a low-protein diet in chronic renal failure. Journal of the American Society of Nephrology. 1995;6(5):1427-33. Sample size less than 50 patients. [pmid: 8589318].
1335 Fouque D, Wang P, Laville M, et al. Low protein diets delay end-stage renal disease in non-diabetic adults with chronic renal failure. Nephrology Dialysis Transplantation. 2000;15(12):1986-92. Not relevant to key questions.
1336 Fouque D, Wang P, Laville M, et al. Low protein diets delay end-stage renal disease in non diabetic adults with chronic renal failure. Cochrane Database of Systematic Reviews. 2000;(2):CD001892. Not relevant to key questions. [pmid: 10796832].
1337 Fouque D, Wang P, Laville M, et al. Low protein diets for chronic renal failure in non diabetic adults. Cochrane Database of Systematic Reviews. 2001;(2):CD001892. Not relevant to key questions. [pmid: 11406017].
1338 Fournier A, Moriniere PH, Oprisiu R, et al. 1-alpha-Hydroxyvitamin D3 derivatives in the treatment of renal bone diseases: justification and optimal modalities of administration. Nephron. 1995;71(3):254-83. Not CKD treatment. [pmid: 8569975].
1339 Fox CH, Brooks A, Zayas LE, et al. Primary care physicians' knowledge and practice patterns in the treatment of chronic kidney disease: an Upstate New York Practice-based Research Network (UNYNET) study. Journal of the American Board of Family Medicine: JABFM. 2006;19(1):54-61. Follow-up less than 6 months. [pmid: 16492006].
1340 Fox KAA, Antman EM, Montalescot G, et al. The impact of renal dysfunction on outcomes in the ExTRACT-TIMI 25 trial. Journal of the American College of Cardiology. 2007;49(23):2249-55. Follow-up less than 6 months. [pmid: 17560289].
1341 Fox KAA, Bassand JP, Mehta SR, et al. Influence of renal function on the efficacy and safety of fondaparinux relative to enoxaparin in non ST-segment elevation acute coronary syndromes. Annals of Internal Medicine. 2007;147(5):304-10. Not CKD treatment. [pmid: 17785485].
1342 Franceschini N, Joy MS, Kshirsagar A. Cinacalcet HCl: a calcimimetic agent for the management of primary and secondary hyperparathyroidism. Expert Opinion on Investigational Drugs. 2003;12(8):1413-21. Not CKD treatment. [pmid: 12882626].
1343 Frank H, Schobel HP, Vitkowsky J, et al. Effects of angiotensin II receptor antagonism on the renal hemodynamic response to cardiovascular stress. Kidney International. 2003;63(2):617-23. Sample size less than 50 patients. [pmid: 12631126].
1344 Frank H, Werner D, Lorusso V, et al. Simultaneous hemodialysis during coronary angiography fails to prevent radiocontrast-induced nephropathy in chronic renal failure. Clinical Nephrology. 2003;60(3):176-82. Not CKD treatment. [pmid: 14524580].
1345 Franklin SC, Moulton M, Sicard GA, et al. Insulin-like growth factor I preserves renal function postoperatively. American Journal of Physiology. 1997;272(2 Pt 2):F257-9. Follow-up less than 6 months. [pmid: 9124404].
1346 Franklin SS, Smith RD. Comparison of effects of enalapril plus hydrochlorothiazide versus standard triple therapy on renal function in renovascular hypertension. American Journal of Medicine. 1985;79(3C):14-23. Follow-up less than 6 months. [pmid: 2996342].
1347 Franklin SS, Smith RD. A comparison of enalapril plus hydrochlorothiazide with standard triple therapy in renovascular hypertension. Nephron. Suppl 1. 1986;44:73-82. Not CKD treatment. [pmid: 3018602].
1348 Frassetto LA, Nash E, Morris RC Jr., et al. Comparative effects of potassium chloride and bicarbonate on thiazide-induced reduction in urinary calcium excretion. Kidney International. 2000;58(2):748-52. Not early CKD. [pmid: 10916098].
1349 Frederick PR, Frankenfield DL, Biddle MG, et al. Changes in dialysis units' quality improvement practices from 1994 to 1996. Anna Journal. 1998;25(5):469-78. Not RCT or controlled trial. [pmid: 9887699].
1350 Fredman B, Jedeikin R, Olsfanger D, et al. The opioid-sparing effect of diclofenac sodium in outpatient extracorporeal shock wave lithotripsy (ESWL). Journal of Clinical Anesthesia. 1993;5(2):141-4. Not CKD treatment. [pmid: 8097400].
1351 Fredman B, Zohar E, Golan E, et al. Diclofenac does not decrease renal blood flow or glomerular filtration in elderly patients undergoing orthopedic surgery. Anesthesia & Analgesia. 1999;88(1):149-54. Not CKD treatment. [pmid: 9895083].
1352 Freedman BI, Wuerth JP, Cartwright K, et al. Design and baseline characteristics for the aminoguanidine Clinical Trial in Overt Type 2 Diabetic Nephropathy (ACTION II). Controlled Clinical Trials. 1999;20(5):493-510. Not RCT or controlled trial. [pmid: 10503809].
1353 Freeman RV, Mehta RH, Al Badr W, et al. Influence of concurrent renal dysfunction on outcomes of patients with acute coronary syndromes and implications of the use of glycoprotein IIb/IIIa inhibitors. Journal of the American College of Cardiology. 2003;41(5):718-24. Not CKD treatment. [pmid: 12628712].
1354 Freestone S, Jeffrey RF, Bonner CV, et al. Effect of lithium on the renal actions of alpha-human atrial natriuretic peptide in normal man. Clinical Science. 1990;78(4):371-5. Sample size less than 50 patients. [pmid: 2160354].
1355 Freestone S, McAuslane JA, Prescott LF. Effects of tenoxicam on renal function and the disposition of inulin and p-aminohippurate in healthy volunteers and patients with chronic renal failure. British Journal of Clinical Pharmacology. 1991;32(4):495-500. Sample size less than 50 patients. [pmid: 1958445].
1356 Frei U, Wagner K. Renal function in liver transplant patients receiving FK506 or cyclosporin A immunosuppressive therapy. Transplantation Proceedings. 1994;26(6):3270-1. Not early CKD. [pmid: 7527963].
1357 Freidlin B, Korn EL. A testing procedure for survival data with few responders. Statistics in Medicine. 2002;21(1):65-78. Not RCT or controlled trial. [pmid: 11782051].
1358 Frenken LA, van Lier HJ, Jordans JG, et al. Identification of the component part in an epoetin alfa preparation that causes pain after subcutaneous injection. American Journal of Kidney Diseases. 1993;22(4):553-6. Sample size less than 50 patients. [pmid: 8213795].
1359 Freudenberger RS, Kim J, Tawfik I, et al. Optimal medical therapy is superior to transplantation for the treatment of class I, II, and III heart failure: a decision analytic approach. Circulation. 2006;114(1 Suppl):I62-6. Not RCT or controlled trial. [pmid: 16820647].
1360 Freudenthaler S, Benohr P, Grenz A, et al. Do alterations of endogenous angiotensin II levels regulate erythropoietin production in humans?. British Journal of Clinical Pharmacology. 2003;56(4):378-87. Sample size less than 50 patients. [pmid: 12968982].
1361 Fricker AF, Nussberger J, Meilenbrock S, et al. Effect of indomethacin on the renal response to angiotensin II receptor blockade in healthy subjects. Kidney International. 1998;54(6):2089-97. Sample size less than 50 patients. [pmid: 9853274].
1362 Fridman K, Andersson OK, Wysocki M, et al. Acute effects of candesartan cilexetil (the new angiotensin II antagonist) on systemic and renal haemodynamics in hypertensive patients. European Journal of Clinical Pharmacology. 1998;54(7):497-501. Sample size less than 50 patients. [pmid: 9832289].
1363 Fried LF, Forrest KY, Ellis D, et al. Lipid modulation in insulin-dependent diabetes mellitus: effect on microvascular outcomes. Journal of Diabetes & its Complications. 2001;15(3):113-9. Sample size less than 50 patients. [pmid: 11358679].
1364 Friedman AN. Omega-3 fatty acid supplementation in advanced kidney disease. Seminars in Dialysis. Jul-Aug. 2010;23(4):396-400. Not RCT or controlled trial. [pmid: 20701719].
1365 Friedman AN, Hunsicker LG, Selhub J, et al. C-reactive protein as a predictor of total arteriosclerotic outcomes in type 2 diabetic nephropathy. Kidney International. 2005;68(2):773-8. Not relevant to key questions. [pmid: 16014055].
1366 Friedman AN, Yu Z, Juliar BE, et al. Independent influence of dietary protein on markers of kidney function and disease in obesity. Kidney International. Oct. 2010;78(7):693-7. Follow-up less than 6 months. [pmid: 20664561].
1367 Friedrich JO, Adhikari N, Herridge MS, et al. Meta-analysis: low-dose dopamine increases urine output but does not prevent renal dysfunction or death. Annals of Internal Medicine. 2005;142(7):510-24. Not relevant to key questions. [pmid: 15809463].
1368 Frimodt-Moller M, Hoj Nielsen A, Strandgaard S, et al. Feasibility of combined treatment with enalapril and candesartan in advanced chronic kidney disease. Nephrology Dialysis Transplantation. Mar. 2010;25(3):842-7. Follow-up less than 6 months.
1369 Frohling PT, Krupki F, Kokot F, et al. What are the most important factors in the progression of renal failure?. Kidney International - Supplement. 1989;27:S106-9. Not early CKD. [pmid: 2636643].
1370 Frossard V, Ketterer N, Rosselet A, et al. Early intensification and autologous stem cell transplantation in patients with systemic AL amyloidosis: a single-centre experience. Annals of Hematology. 2009;88(7):681-5. Not CKD treatment. [pmid: 19066891].
1371 Frumento RJ, Logginidou HG, Wahlander S, et al. Dexmedetomidine infusion is associated with enhanced renal function after thoracic surgery. Journal of Clinical Anesthesia. 2006;18(6):422-6. Not early CKD. [pmid: 16980158].
1372 Fuiano G, Esposito C, Sepe V, et al. Effects of hypercholesterolemia of renal hemodynamics: study in patients with nephrotic syndrome. Nephron. 1996;73(3):430-5. Sample size less than 50 patients. [pmid: 8832603].
1373 Fuiano G, Mancuso D, Indolfi C, et al. Early detection of progressive renal dysfunction in patients with coronary artery disease. Kidney International. 2005;68(6):2773-80. Not relevant to key questions. [pmid: 16316352].
1374 Fujii N, Hamano T, Mikami S, et al. Risedronate, an effective treatment for glucocorticoid-induced bone loss in CKD patients with or without concomitant active vitamin D (PRIUS-CKD). Nephrology Dialysis Transplantation. 2007;22(6):1601-7. Not RCT or controlled trial.
1375 Fujisaki T, Hida M, Hiraga S, et al. Cellular proliferation and secretion in secondary hyperparathyroidism during renal failure. Nephron. 1997;77(1):68-75. Sample size less than 50 patients. [pmid: 9380241].
1376 Fujita T, Ando K, Nishimura H, et al. Antiproteinuric effect of the calcium channel blocker cilnidipine added to renin-angiotensin inhibition in hypertensive patients with chronic renal disease. Kidney International. 2007;72(12):1543-9. Not RCT or controlled trial. [pmid: 17943080].
1377 Fukuoka N, Aibiki M. Recommended dose of arbekacin, an aminoglycoside against methicillin-resistant Staphylococcus aureus, does not achieve desired serum concentration in critically ill patients with lowered creatinine clearance. Journal of Clinical Pharmacy & Therapeutics. 2008;33(5):521-7. Not CKD treatment. [pmid: 18834367].
1378 Fullerton T, Sica DA, Blum RA. Evaluation of the renal protective effect of misoprostol in elderly, osteoarthritic patients at risk for nonsteroidal anti-inflammatory drug-induced renal dysfunction. Journal of Clinical Pharmacology. 1993;33(12):1225-32. Not CKD treatment. [pmid: 8126257].
1379 Fung JWH, Szeto CC, Chan WWM, et al. Effect of N-acetylcysteine for prevention of contrast nephropathy in patients with moderate to severe renal insufficiency: a randomized trial. American Journal of Kidney Diseases. 2004;43(5):801-8. Not early CKD. [pmid: 15112170].
1380 Fung MA, Warnock GL, Ao Z, et al. The effect of medical therapy and islet cell transplantation on diabetic nephropathy: an interim report. Transplantation. 2007;84(1):17-22. Sample size less than 50 patients. [pmid: 17627232].
1381 Furey SA, Vargas R, McMahon FG. Renovascular effects of nonprescription ibuprofen in elderly hypertensive patients with mild renal impairment. Pharmacotherapy. 1993;13(2):143-8. Not CKD treatment. [pmid: 8469621].
1382 Furumatsu Y, Nagasawa Y, Tomida K, et al. Effect of renin-angiotensin-aldosterone system triple blockade on non-diabetic renal disease: addition of an aldosterone blocker, spironolactone, to combination treatment with an angiotensin-converting enzyme inhibitor and angiotensin II receptor blocker. Hypertension Research - Clinical & Experimental. 2008;31(1):59-67. Not CKD treatment.
1383 Gabrielsen A, Bie P, Holstein-Rathlou NH, et al. Neuroendocrine and renal effects of intravascular volume expansion in compensated heart failure. American Journal of Physiology - Regulatory Integrative & Comparative Physiology. 2001;281(2):R459-67. Not early CKD.
1384 Gadano A, Moreau R, Vachiery F, et al. Natriuretic response to the combination of atrial natriuretic peptide and terlipressin in patients with cirrhosis and refractory ascites. Journal of Hepatology. 1997;26(6):1229-34. Not CKD treatment. [pmid: 9210608].
1385 Gaede P, Hansen HP, Parving HH, et al. Impact of low-dose acetylsalicylic acid on kidney function in type 2 diabetic patients with elevated urinary albumin excretion rate. Nephrology Dialysis Transplantation. 2003;18(3):539-42. Sample size less than 50 patients.
1386 Gaede P, Poulsen HE, Parving HH, et al. Double-blind, randomised study of the effect of combined treatment with vitamin C and E on albuminuria in Type 2 diabetic patients. Diabetic Medicine. 2001;18(9):756-60. Sample size less than 50 patients. [pmid: 11606175].
1387 Gaede P, Vedel P, Parving HH, et al. Elevated levels of plasma von Willebrand factor and the risk of macro- and microvascular disease in type 2 diabetic patients with microalbuminuria. Nephrology Dialysis Transplantation. 2001;16(10):2028-33. Not RCT or controlled trial.
1388 Gaedeke J, Neumayer HH, Peters H. Pharmacological management of renal fibrotic disease. Expert Opinion on Pharmacotherapy. 2006;7(4):377-86. Not relevant to key questions. [pmid: 16503810].
1389 Gainer JV, Morrow JD, Loveland A, et al. Effect of bradykinin-receptor blockade on the response to angiotensin-converting-enzyme inhibitor in normotensive and hypertensive subjects. New England Journal of Medicine. 1998;339(18):1285-92. Sample size less than 50 patients. [pmid: 9791144].
1390 Galassi A, Brancaccio D, Cozzolino M, et al. Awareness of hypertension and proteinuria in randomly selected patients in 11 Italian cities. A 2005 report of the National Kidney Foundation of Italy. Journal of Clinical Hypertension. 2009;11(3):138-43. Not CKD treatment. [pmid: 19302425].
1391 Galera SC, Fechine FV, Teixeira MJ, et al. The safety of oral use of L-glutamine in middle-aged and elderly individuals. Nutrition. Apr. 2010;26(4):375-81. Follow-up less than 6 months. [pmid: 19765954].
1392 Gall MA, Rossing P, Skott P, et al. Placebo-controlled comparison of captopril, metoprolol, and hydrochlorothiazide therapy in non-insulin-dependent diabetic patients with primary hypertension. American Journal of Hypertension. 1992;5(5 Pt 1):257-65. Sample size less than 50 patients. [pmid: 1581012].
1393 Gallagher DJ, Milowsky MI, Iasonos A, et al. Sequential adjuvant chemotherapy after surgical resection of high-risk urothelial carcinoma. Cancer. 2009;115(22):5193-201. Not CKD treatment. [pmid: 19670454].
1394 Gallagher H, de Lusignan S, Harris K, et al. Quality-improvement strategies for the management of hypertension in chronic kidney disease in primary care: a systematic review. British Journal of General Practice. Jun. 2010;60(575):258-65. Not RCT or controlled trial.
1395 Gallagher JC, Rapuri P, Smith L. Falls are associated with decreased renal function and insufficient calcitriol production by the kidney. Journal of Steroid Biochemistry & Molecular Biology. 2007;103(3-5):610-3. Not RCT or controlled trial. [pmid: 17236758].
1396 Gallagher PM, Carrithers JA, Godard MP, et al. Beta-hydroxy-beta-methylbutyrate ingestion, part II: effects on hematology, hepatic and renal function. Medicine & Science in Sports & Exercise. 2000;32(12):2116-9. Not early CKD. [pmid: 11128860].
1397 Gallant JE, Winston JA, DeJesus E, et al. The 3-year renal safety of a tenofovir disoproxil fumarate vs. a thymidine analogue-containing regimen in antiretroviral-naive patients. AIDS. 2008;22(16):2155-63. Not CKD treatment. [pmid: 18832879].
1398 Gallicchio L, Helzlsouer KJ, Chow WH, et al. Circulating 25-hydroxyvitamin D and the risk of rarer cancers: Design and methods of the Cohort Consortium Vitamin D Pooling Project of Rarer Cancers. American Journal of Epidemiology. Jul. 1. 2010;172(1):10-20. Not CKD treatment. [pmid: 20562188].
1399 Galsky MD, Iasonos A, Mironov S, et al. Phase II trial of dose-dense doxorubicin plus gemcitabine followed by paclitaxel plus carboplatin in patients with advanced urothelial carcinoma and impaired renal function. Cancer. 2007;109(3):549-55. Not CKD treatment. [pmid: 17200962].
1400 Gambaro G, Kinalska I, Oksa A, et al. Oral sulodexide reduces albuminuria in microalbuminuric and macroalbuminuric type 1 and type 2 diabetic patients: the Di.N.A.S. randomized trial. Journal of the American Society of Nephrology. 2002;13(6):1615-25. Not CKD treatment. [pmid: 12039991].
1401 Gambini G, Rossi S, Valori C. Absence of effects of ketanserin on renal prostacyclin and thromboxane A2 in essential hypertension. European Heart Journal. 1991;12(4):550-3. Sample size less than 50 patients. [pmid: 2065689].
1402 Gandhi MR, Brown P, Romanowski CA, et al. The use of theophylline, an adenosine antagonist in the prevention of contrast media induced nephrotoxicity. [Republished from Br J Radiol 1992 May; 65(773):459]. British Journal of Radiology. 1992;65(777):838. Not RCT or controlled trial. [pmid: 1393430].
1403 Gandhi SK, Ryder DH, Brown NJ. Losartan blocks aldosterone and renal vascular responses to angiotensin II in humans. Hypertension. 1996;28(6):961-6. Sample size less than 50 patients. [pmid: 8952583].
1404 Gandra SR, Finkelstein FO, Bennett AV, et al. Impact of erythropoiesis-stimulating agents on energy and physical function in nondialysis CKD patients with anemia: a systematic review. American Journal of Kidney Diseases. Mar. 2010;55(3):519-34. Not RCT or controlled trial. [pmid: 20031287].
1405 Ganguli A, Kohli HS, Khullar M, et al. Lipid peroxidation products formation with various intravenous iron preparations in chronic kidney disease. Renal Failure. 2009;31(2):106-10. Not CKD treatment. [pmid: 19212906].
1406 Gansevoort RT, de Zeeuw D, de Jong PE. Is the antiproteinuric effect of ACE inhibition mediated by interference in the renin-angiotensin system?. Kidney International. 1994;45(3):861-7. Not relevant to key questions. [pmid: 8196289].
1407 Gansevoort RT, de Zeeuw D, de Jong PE. Additive antiproteinuric effect of ACE inhibition and a low-protein diet in human renal disease. Nephrology Dialysis Transplantation. 1995;10(4):497-504. Sample size less than 50 patients.
1408 Gansevoort RT, de Zeeuw D, Shahinfar S, et al. Effects of the angiotensin II antagonist losartan in hypertensive patients with renal disease. Journal of Hypertension - Supplement. 1994;12(2):S37-42. Follow-up less than 6 months.
1409 Gansevoort RT, Verhave JC, Hillege HL, et al. The validity of screening based on spot morning urine samples to detect subjects with microalbuminuria in the general population. Kidney International - Supplement. 2005;(94):S28-35. Not CKD treatment. [pmid: 15752236].
1410 Gao Y, Lu R, Wang X, et al. A clinical trial of tang shen ning for treatment of diabetic nephropathy. Journal of Traditional Chinese Medicine. 1998;18(4):247-52. Not relevant to key questions. [pmid: 10453590].
1411 Garattini L, Brunetti M, Salvioni F, et al. Economic evaluation of ACE inhibitor treatment of nephropathy in patients with insulin-dependent diabetes mellitus in Italy. Pharmacoeconomics. 1997;12(1):67-75. Not RCT or controlled trial. [pmid: 10169388].
1412 Garcia CA, Abell-Aleff PC, Gamb SI, et al. Ultrastructural analysis of amyloidoma. Ultrastructural Pathology. 2009;33(3):123-7. Not CKD treatment. [pmid: 19479652].
1413 Garcia de Vinuesa S, Luno J, Gomez-Campdera F, et al. Effect of strict blood pressure control on proteinuria in renal patients treated with different antihypertensive drugs. Nephrology Dialysis Transplantation. Suppl 1. 2001;16:78-81. Sample size less than 50 patients.
1414 Garcia-Donaire JA, Segura J, Ruilope LM. An update of irbesartan and renin-angiotensin system blockade in diabetic nephropathy. Expert Opinion on Pharmacotherapy. 2005;6(9):1587-96. Sample size less than 50 patients. [pmid: 16086646].
1415 Gare M, Haviv YS, Ben-Yehuda A, et al. The renal effect of low-dose dopamine in high-risk patients undergoing coronary angiography. Journal of the American College of Cardiology. 1999;34(6):1682-8. Not CKD treatment. [pmid: 10577557].
1416 Garg AX, Kiberd BA, Clark WF, et al. Albuminuria and renal insufficiency prevalence guides population screening: results from the NHANES III. Kidney International. 2002;61(6):2165-75. Not relevant to key questions. [pmid: 12028457].
1417 Garg JP, Ellis R, Elliott WJ, et al. Angiotensin receptor blockade and arterial compliance in chronic kidney disease: a pilot study. American Journal of Nephrology. 2005;25(4):393-9. Not relevant to key questions. [pmid: 16088080].
1418 Garg P, Charytan DM, Novack L, et al. Impact of moderate renal insufficiency on restenosis and adverse clinical events after sirolimus-eluting and bare metal stent implantation (from the SIRIUS trials). American Journal of Cardiology. Nov. 15. 2010;106(10):1436-42. Not CKD treatment. [pmid: 21059433].
1419 Garini G, Mazzi A, Allegri L, et al. Effectiveness of dietary protein augmentation associated with angiotensin-converting enzyme inhibition in the management of the nephrotic syndrome. Mineral & Electrolyte Metabolism. 1996;22(1-3):123-7. Sample size less than 50 patients. [pmid: 8676802].
1420 Garneata L. Pharmaco-economic evaluation of keto acid/amino acid-supplemented protein-restricted diets. Journal of Renal Nutrition. 2009;19(5 Suppl):S19-21. Not early CKD. [pmid: 19712870].
1421 Garneata L, Mircescu G. Nutritional intervention in uremia--myth or reality?. Journal of Renal Nutrition. Sep. 2010;20(5 Suppl):S31-4. Not RCT or controlled trial. [pmid: 20797568].
1422 Garovic V, Textor SC. Renovascular hypertension: current concepts. Seminars in Nephrology. 2005;25(4):261-71. Sample size less than 50 patients. [pmid: 16202699].
1423 Garty M, Perry G, Shmueli H, et al. Effect of cimetidine on digoxin disposition in peptic ulcer patients. European Journal of Clinical Pharmacology. 1986;30(4):489-91. Sample size less than 50 patients. [pmid: 3743626].
1424 Garufi C, Levi F, Giunta S, et al. Chronomodulated 5-day infusion of floxuridine and L-folinic acid in patients with advanced malignancies: a feasibility and tolerability study. Journal of Infusional Chemotherapy. 1995;5(3 Suppl 1):134-7. Sample size less than 50 patients. [pmid: 8528973].
1425 Garwood S, Swamidoss CP, Davis EA, et al. A case series of low-dose fenoldopam in seventy cardiac surgical patients at increased risk of renal dysfunction. Journal of Cardiothoracic & Vascular Anesthesia. 2003;17(1):17-21. Not RCT or controlled trial. [pmid: 12635055].
1426 Gaspari F, Perico N, Ruggenenti P, et al. Plasma clearance of nonradioactive iohexol as a measure of glomerular filtration rate. Journal of the American Society of Nephrology. 1995;6(2):257-63. Sample size less than 50 patients. [pmid: 7579093].
1427 Gassman JJ, Greene T, Wright JT Jr., et al. Design and statistical aspects of the African American Study of Kidney Disease and Hypertension (AASK). Journal of the American Society of Nephrology. 2003;14(7 Suppl 2):S154-65. Not relevant to key questions. [pmid: 12819322].
1428 Gates GF. Filtration fraction and its implications for radionuclide renography using diethylenetriaminepentaacetic acid and mercaptoacetyltriglycine. Clinical Nuclear Medicine. 2004;29(4):231-7. Sample size less than 50 patients. [pmid: 15096969].
1429 Gatling W, Knight C, Hill RD. Screening for early diabetic nephropathy: which sample to detect microalbuminuria?. Diabetic Medicine. 1985;2(6):451-5. Not RCT or controlled trial. [pmid: 2951116].
1430 Gatot I, Abramov D, Tsodikov V, et al. Should we give prophylactic renal-dose dopamine after coronary artery bypass surgery?. Journal of Cardiac Surgery. 2004;19(2):128-33. Not relevant to key questions. [pmid: 15016048].
1431 Gatti AM, Rivasi F. Biocompatibility of micro- and nanoparticles. Part I: in liver and kidney. Biomaterials. 2002;23(11):2381-7. Not CKD treatment. [pmid: 12013186].
1432 Gaudry SE, Sitar DS, Smyth DD, et al. Gender and age as factors in the inhibition of renal clearance of amantadine by quinine and quinidine. Clinical Pharmacology & Therapeutics. 1993;54(1):23-7. Follow-up less than 6 months. [pmid: 8330461].
1433 Gaweda AE, Jacobs AA, Aronoff GR, et al. Model predictive control of erythropoietin administration in the anemia of ESRD. American Journal of Kidney Diseases. 2008;51(1):71-9. Not early CKD. [pmid: 18155535].
1434 Gay F, Palumbo A. Multiple myeloma: management of adverse events. Medical Oncology. Sep. 2010;27(3):646-53. Not CKD treatment. [pmid: 19582597].
1435 Gayet-Ageron A, Ananworanich J, Jupimai T, et al. No change in calculated creatinine clearance after tenofovir initiation among Thai patients. Journal of Antimicrobial Chemotherapy. 2007;59(5):1034-7. Not CKD treatment. [pmid: 17376791].
1436 Gazis A, Page SR. Microalbuminuria screening in the UK: are we meeting European standards?. Diabetic Medicine. 1996;13(8):764-7. Not RCT or controlled trial. [pmid: 8862954].
1437 Gelber RP, Kurth T, Kausz AT, et al. Association between body mass index and CKD in apparently healthy men. American Journal of Kidney Diseases. 2005;46(5):871-80. Not RCT or controlled trial. [pmid: 16253727].
1438 Geluk CA, Asselbergs FW, Hillege HL, et al. Impact of statins in microalbuminuric subjects with the metabolic syndrome: a substudy of the PREVEND Intervention Trial. European Heart Journal. 2005;26(13):1314-20. Sample size less than 50 patients. [pmid: 15820998].
1439 Gentile MG, Ciceri R, Manna GM, et al. The role of fibre in the treatment of secondary hyperlipidaemia in nephrotic patients. European Journal of Clinical Nutrition. Suppl 3. 1995;49:S239-41. Sample size less than 50 patients. [pmid: 8549536].
1440 Gentilini P, La Villa G, Marra F, et al. Pharmacokinetics and pharmacodynamics of torasemide and furosemide in patients with diuretic resistant ascites. Journal of Hepatology. 1996;25(4):481-90. Sample size less than 50 patients. [pmid: 8912147].
1441 Gentilini P, Romanelli RG, La Villa G, et al. Effects of low-dose captopril on renal hemodynamics and function in patients with cirrhosis of the liver. Gastroenterology. 1993;104(2):588-94. Follow-up less than 6 months. [pmid: 8425702].
1442 Genuth S. Insights from the diabetes control and complications trial/epidemiology of diabetes interventions and complications study on the use of intensive glycemic treatment to reduce the risk of complications of type 1 diabetes. Endocrine Practice. Suppl 1. 2006;12:34-41. Not relevant to key questions. [pmid: 16627378].
1443 Georges B, Conil JM, Seguin T, et al. Population pharmacokinetics of ceftazidime in intensive care unit patients: influence of glomerular filtration rate, mechanical ventilation, and reason for admission. Antimicrobial Agents & Chemotherapy. 2009;53(10):4483-9. Sample size less than 50 patients. [pmid: 19635962].
1444 Gerbes AL, Gulberg V, Gines P, et al. Therapy of hyponatremia in cirrhosis with a vasopressin receptor antagonist: a randomized double-blind multicenter trial. Gastroenterology. 2003;124(4):933-9. Not CKD treatment. [pmid: 12671890].
1445 Gerhardt T, Terjung B, Knipper P, et al. Renal impairment after liver transplantation - a pilot trial of calcineurin inhibitor-free vs. calcineurin inhibitor sparing immunosuppression in patients with mildly impaired renal function after liver transplantation. European Journal of Medical Research. 2009;14(5):210-5. Sample size less than 50 patients. [pmid: 19541578].
1446 Germain DP, Waldek S, Banikazemi M, et al. Sustained, long-term renal stabilization after 54 months of agalsidase beta therapy in patients with Fabry disease. Journal of the American Society of Nephrology. 2007;18(5):1547-57. Follow-up less than 6 months. [pmid: 17409312].
1447 Gerrah R, Ehrlich S, Tshori S, et al. Beneficial effect of aspirin on renal function in patients with renal insufficiency postcardiac surgery. Journal of Cardiovascular Surgery. 2004;45(6):545-50. Not CKD treatment. [pmid: 15746633].
1448 Gerstein HC. Diabetes and the HOPE study: implications for macrovascular and microvascular disease. International Journal of Clinical Practice. Supplement. 2001;(117):8-12. Not CKD treatment. [pmid: 11715357].
1449 Gerstein HC. Reduction of cardiovascular events and microvascular complications in diabetes with ACE inhibitor treatment: HOPE and MICRO-HOPE. Diabetes/Metabolism Research Reviews. Suppl 3. 2002;18:S82-5. Not relevant to key questions.
1450 Gerstein HC, Bosch J, Pogue J, et al. Rationale and design of a large study to evaluate the renal and cardiovascular effects of an ACE inhibitor and vitamin E in high-risk patients with diabetes. The MICRO-HOPE Study. Microalbuminuria, cardiovascular, and renal outcomes. Heart Outcomes Prevention Evaluation. Diabetes Care. 1996;19(11):1225-8. Not RCT or controlled trial. [pmid: 8908384].
1451 Gerth WC, Remuzzi G, Viberti G, et al. Losartan reduces the burden and cost of ESRD: public health implications from the RENAAL study for the European Union. Kidney International - Supplement. 2002;(82):S68-72. Not CKD treatment. [pmid: 12410859].
1452 Ghebremariam YT, Engelbrecht G, Tyler M, et al. Vaccinia virus complement control protein (VCP) improves kidney structure and function following ischemia/reperfusion injury in rats. Journal of Surgical Research. Apr. 2010;159(2):747-54. Not human studies. [pmid: 19691975].
1453 Gheith O, Sheashaa H, Abdelsalam M, et al. Efficacy and safety of Monascus purpureus Went rice in subjects with secondary hyperlipidemia. Clinical & Experimental Nephrology. 2008;12(3):189-94. Not CKD treatment. [pmid: 18363032].
1454 Gheith O, Sheashaa H, Abdelsalam M, et al. Efficacy and safety of Monascus purpureus Went rice in children and young adults with secondary hyperlipidemia: a preliminary report. European Journal of Internal Medicine. 2009;20(3):e57-61. Not CKD treatment. [pmid: 19393480].
1455 Gheith OA, Sobh MAK, Mohamed KES, et al. Impact of treatment of dyslipidemia on renal function, fat deposits and scarring in patients with persistent nephrotic syndrome. Nephron. 2002;91(4):612-9. Sample size less than 50 patients. [pmid: 12138263].
1456 Giamarellou H, Yiallouros K, Petrikkos G, et al. Comparative kinetics and efficacy of amikacin administered once or twice daily in the treatment of systemic gram-negative infections. Journal of Antimicrobial Chemotherapy. Suppl C. 1991;27:73-9. Not CKD treatment. [pmid: 1906864].
1457 Giannini C, Lombardo F, Curro F, et al. Effects of high-dose vitamin E supplementation on oxidative stress and microalbuminuria in young adult patients with childhood onset type 1 diabetes mellitus. Diabetes/Metabolism Research Reviews. 2007;23(7):539-46. Not RCT or controlled trial.
1458 Giatras I, Lau J, Levey AS. Effect of angiotensin-converting enzyme inhibitors on the progression of nondiabetic renal disease: a meta-analysis of randomized trials. Angiotensin-Converting-Enzyme Inhibition and Progressive Renal Disease Study Group. Annals of Internal Medicine. 1997;127(5):337-45. Not RCT or controlled trial. [pmid: 9273824].
1459 Gibson CM, Dumaine RL, Gelfand EV, et al. Association of glomerular filtration rate on presentation with subsequent mortality in non-ST-segment elevation acute coronary syndrome; observations in 13,307 patients in five TIMI trials. European Heart Journal. 2004;25(22):1998-2005. Sample size less than 50 patients. [pmid: 15541835].
1460 Gilbert DN, Lee BL, Dworkin RJ, et al. A randomized comparison of the safety and efficacy of once-daily gentamicin or thrice-daily gentamicin in combination with ticarcillin-clavulanate. American Journal of Medicine. 1998;105(3):182-91. Not CKD treatment. [pmid: 9753020].
1461 Gilbert RE, Kim SA, Tuttle KR, et al. Effect of ruboxistaurin on urinary transforming growth factor-beta in patients with diabetic nephropathy and type 2 diabetes. Diabetes Care. 2007;30(4):995-6. Not CKD treatment. [pmid: 17229944].
1462 Gilbert S, Zuo C, Epstein FH. Effect of specific and non-specific inhibition of COX-2 on renal oxygenation before and after water diuresis. Nephron. Physiology. 2005;99(4):p101-4. Not relevant to key questions. [pmid: 15692221].
1463 Gille J, Spieth K, Kaufmann R. Metronomic low-dose chemotherapy as antiangiogenic therapeutic strategy for cancer. Journal der Deutschen Dermatologischen Gesellschaft. 2005;3(1):26-32. Not RCT or controlled trial. [pmid: 16353746].
1464 Gillespie EA, Gillespie BW, Stevens MJ. Painful diabetic neuropathy: impact of an alternative approach. Diabetes Care. 2007;30(4):999-1001. Not RCT or controlled trial. [pmid: 17392561].
1465 Gillis BP, Averbach FM, Caggiula AW, et al. Features of the nutrient database and analysis system for the Modification of Diet in Renal Disease Study. [Erratum appears in Control Clin Trials 1994 Aug; 15(4):326]. Controlled Clinical Trials. 1994;15(1):44-58. Not RCT or controlled trial. [pmid: 8149770].
1466 Gillis BP, Caggiula AW, Chiavacci AT, et al. Nutrition intervention program of the Modification of Diet in Renal Disease Study: a self-management approach. Journal of the American Dietetic Association. 1995;95(11):1288-94. Not CKD treatment. [pmid: 7594125].
1467 Ginifer C, Kelly AM. Administration of rectal indomethacin does not reduce the requirement for intravenous narcotic analgesia in acute renal colic. European Journal of Emergency Medicine. 1996;3(2):92-4. Not CKD treatment. [pmid: 9028752].
1468 Ginsberg AM, Laurenzi MW, Rouse DJ, et al. Assessment of the effects of the nitroimidazo-oxazine PA-824 on renal function in healthy subjects. Antimicrobial Agents & Chemotherapy. 2009;53(9):3726-33. Follow-up less than 6 months. [pmid: 19528286].
1469 Giordano M, Castellino P, McConnell EL, et al. Effect of amino acid infusion on renal hemodynamics in humans: a dose-response study. American Journal of Physiology. 1994;267(5 Pt 2):F703-8. Sample size less than 50 patients. [pmid: 7977774].
1470 Giordano M, Sanders LR, Castellino P, et al. Effect of alpha-adrenergic blockers, ACE inhibitors, and calcium channel antagonists on renal function in hypertensive non-insulin-dependent diabetic patients. Nephron. 1996;72(3):447-53. Sample size less than 50 patients. [pmid: 8852495].
1471 Giovannetti S, Barsotti G, Cupisti A, et al. Oral activated charcoal in patients with uremic pruritus. Nephron. 1995;70(2):193-6. Sample size less than 50 patients. [pmid: 7566302].
1472 Girbes AR, Smit AJ, Meijer S, et al. Lithium and the renal response to gludopa, fenoldopam and dopamine. British Journal of Clinical Pharmacology. 1990;30(4):652-3. Not RCT or controlled trial. [pmid: 1981323].
1473 Girbes AR, Smit AJ, Meijer S, et al. Renal and endocrine effects of fenoldopam and metoclopramide in normal man. Nephron. 1990;56(2):179-85. Sample size less than 50 patients. [pmid: 1978736].
1474 Girbes AR, van Veldhuisen DJ, Smit AJ, et al. Renal and neurohumoral effects of ibopamine and metoclopramide in normal man. British Journal of Clinical Pharmacology. 1991;31(6):701-4. Sample size less than 50 patients. [pmid: 1678273].
1475 Girndt M, Pietsch M, Kohler H. Tetanus immunization and its association to hepatitis B vaccination in patients with chronic renal failure. American Journal of Kidney Diseases. 1995;26(3):454-60. Sample size less than 50 patients. [pmid: 7645553].
1476 Gisclon LG, Boyd RA, Williams RL, et al. The effect of probenecid on the renal elimination of cimetidine. Clinical Pharmacology & Therapeutics. 1989;45(4):444-52. Not RCT or controlled trial. [pmid: 2702802].
1477 Giugliano D, Acampora R, Marfella R, et al. Hemodynamic and metabolic effects of transdermal clonidine in patients with hypertension and non-insulin-dependent diabetes mellitus. American Journal of Hypertension. 1998;11(2):184-9. Sample size less than 50 patients. [pmid: 9524046].
1478 Giustina A, Bossoni S, Cimino A, et al. Picotamide, a dual TXB synthetase inhibitor and TXB receptor antagonist, reduces exercise-induced albuminuria in microalbuminuric patients with NIDDM. Diabetes. 1993;42(1):178-82. Sample size less than 50 patients. [pmid: 8420815].
1479 Giustina A, Bossoni S, Macca C, et al. Isradipine decreases exercise-induced albuminuria in patients with essential hypertension. Renal Failure. 1993;15(4):509-14. Sample size less than 50 patients. [pmid: 8210563].
1480 Giustina A, Perini P, Desenzani P, et al. Long-term treatment with the dual antithromboxane agent picotamide decreases microalbuminuria in normotensive type 2 diabetic patients. Diabetes. 1998;47(3):423-30. Sample size less than 50 patients. [pmid: 9519749].
1481 Givertz MM, Massie BM, Fields TK, et al. The effects of KW-3902, an adenosine A1-receptor antagonist, on diuresis and renal function in patients with acute decompensated heart failure and renal impairment or diuretic resistance. Journal of the American College of Cardiology. 2007;50(16):1551-60. Not CKD treatment. [pmid: 17936154].
1482 Glasser SP. Angiotensin converting enzyme inhibitors: are they preferred first-line therapy?. Current Hypertension Reports. 2000;2(4):392-7. Not RCT or controlled trial. [pmid: 10981175].
1483 Glassock RJ. Uremia (end-stage renal disease): how cost-effective are preventive strategies?. Journal of Renal Nutrition. Sep. 2010;20(5 Suppl):S131-4. Not RCT or controlled trial. [pmid: 20797562].
1484 Gleiter CH, Becker T, Schreeb KH, et al. Fenoterol but not dobutamine increases erythropoietin production in humans. Clinical Pharmacology & Therapeutics. 1997;61(6):669-76. Sample size less than 50 patients. [pmid: 9209250].
1485 Glorioso N, Manunta P, Troffa C, et al. Effects of nitrendipine on blood pressure, renin-angiotensin system, and kidney function in essential hypertension. Journal of Cardiovascular Pharmacology. Suppl 4. 1988;12:S142-5. Sample size less than 50 patients. [pmid: 2468859].
1486 Glynn LG, Buckley B, Reddan D, et al. Multimorbidity and risk among patients with established cardiovascular disease: a cohort study. British Journal of General Practice. 2008;58(552):488-94. Not CKD treatment. [pmid: 18611315].
1487 Glynn LG, Reddan D, Newell J, et al. Chronic kidney disease and mortality and morbidity among patients with established cardiovascular disease: a West of Ireland community-based cohort study. Nephrology Dialysis Transplantation. 2007;22(9):2586-94. Sample size less than 50 patients.
1488 Gobburu JVS, Sekar VJ. Application of modeling and simulation to integrate clinical pharmacology knowledge across a new drug application. International Journal of Clinical Pharmacology & Therapeutics. 2002;40(7):281-8. Not early CKD. [pmid: 12139204].
1489 Goddard J, Johnston NR, Cumming AD, et al. Fractional urinary excretion of endothelin-1 is reduced by acute ETB receptor blockade. American Journal of Physiology - Renal Physiology. 2007;293(5):F1433-8. Not relevant to key questions. [pmid: 17855483].
1490 Goddard J, Johnston NR, Hand MF, et al. Endothelin-A receptor antagonism reduces blood pressure and increases renal blood flow in hypertensive patients with chronic renal failure: a comparison of selective and combined endothelin receptor blockade. Circulation. 2004;109(9):1186-93. Not CKD treatment. [pmid: 14981006].
1491 Goenka N, Kotonya C, Penney MD, et al. Thiazolidinediones and the renal and hormonal response to water immersion-induced volume expansion in type 2 diabetes mellitus. American Journal of Physiology - Endocrinology & Metabolism. 2008;294(4):E733-9. Not CKD treatment. [pmid: 18230694].
1492 Goeters C, Reinhardt C, Gronau E, et al. Minimal flow sevoflurane and isoflurane anaesthesia and impact on renal function. European Journal of Anaesthesiology. 2001;18(1):43-50. Not early CKD. [pmid: 11270009].
1493 Goicoechea M, de Vinuesa SG, Lahera V, et al. Effects of atorvastatin on inflammatory and fibrinolytic parameters in patients with chronic kidney disease. Journal of the American Society of Nephrology. 2006;17(12 Suppl 3):S231-5. Not relevant to key questions. [pmid: 17130267].
1494 Goicoechea M, de Vinuesa SG, Verdalles U, et al. Effect of allopurinol in chronic kidney disease progression and cardiovascular risk. Clinical Journal of The American Society of Nephrology: CJASN. Aug. 2010;5(8):1388-93. Not CKD treatment. [pmid: 20538833].
1495 Goicoechea M, Liu S, Best B, et al. Greater tenofovir-associated renal function decline with protease inhibitor-based versus nonnucleoside reverse-transcriptase inhibitor-based therapy. Journal of Infectious Diseases. 2008;197(1):102-8. Follow-up less than 6 months. [pmid: 18171292].
1496 Golan L, Birkmeyer JD, Welch HG. The cost-effectiveness of treating all patients with type 2 diabetes with angiotensin-converting enzyme inhibitors. Annals of Internal Medicine. 1999;131(9):660-7. Not CKD treatment. [pmid: 10577328].
1497 Goldberg DI, Dillon MA, Slatopolsky EA, et al. Effect of RenaGel, a non-absorbed, calcium- and aluminium-free phosphate binder, on serum phosphorus, calcium, and intact parathyroid hormone in end-stage renal disease patients. Nephrology Dialysis Transplantation. 1998;13(9):2303-10. Follow-up less than 6 months.
1498 Goldenberg I, Chonchol M, Guetta V. Reversible acute kidney injury following contrast exposure and the risk of long-term mortality. American Journal of Nephrology. 2009;29(2):136-44. Not CKD treatment. [pmid: 18753738].
1499 Goldenberg I, Moss AJ, McNitt S, et al. Relations among renal function, risk of sudden cardiac death, and benefit of the implanted cardiac defibrillator in patients with ischemic left ventricular dysfunction. American Journal of Cardiology. 2006;98(4):485-90. Not RCT or controlled trial. [pmid: 16893702].
1500 Goldenberg I, Shechter M, Matetzky S, et al. Oral acetylcysteine as an adjunct to saline hydration for the prevention of contrast-induced nephropathy following coronary angiography. A randomized controlled trial and review of the current literature. European Heart Journal. 2004;25(3):212-8. Not CKD treatment. [pmid: 14972421].
1501 Goldfarb B, Pardoux CM. Exploring series of multivariate censored temporal data through fuzzy coding and correspondence analysis. Statistics in Medicine. 2006;25(10):1741-50. Not RCT or controlled trial. [pmid: 16143983].
1502 Goldfarb S, Spinler S, Berns JS, et al. Low-osmolality contrast media and the risk of contrast-associated nephrotoxicity. Investigative Radiology. Suppl 5. 1993;28:S7-10. discussion S1-2. Not CKD treatment. [pmid: 8282507].
1503 Goldfarb S, Walker BR, Agus ZS. The uricosuric effect of oxaprozin in humans. Journal of Clinical Pharmacology. 1985;25(2):144-8. Sample size less than 50 patients. [pmid: 3886710].
1504 Goldfarb-Rumyantzev AS, Pappas L. Prediction of renal insufficiency in Pima Indians with nephropathy of type 2 diabetes mellitus. American Journal of Kidney Diseases. 2002;40(2):252-64. Not CKD treatment. [pmid: 12148097].
1505 Goldsmith D. 2009: a requiem for rHuEPOs--but should we nail down the coffin in 2010?. Clinical Journal of The American Society of Nephrology: CJASN. May. 2010;5(5):929-35. Not RCT or controlled trial. [pmid: 20413441].
1506 Goldsmith DJ, Covic A. Coronary artery disease in uremia: Etiology, diagnosis, and therapy. Kidney International. 2001;60(6):2059-78. Not early CKD. [pmid: 11737581].
1507 Goldstein DJ, Wang O, Gitter BD, et al. Dose-response study of the analgesic effect of lanepitant in patients with painful diabetic neuropathy. Clinical Neuropharmacology. 2001;24(1):16-22. Not CKD treatment. [pmid: 11290877].
1508 Golightly LK, O'Fallon CL, Moran WD, et al. Pharmacist monitoring of drug therapy in patients with abnormal serum creatinine levels. Hospital Pharmacy. 1993;28(8):725-7. Sample size less than 50 patients. [pmid: 10127574].
1509 Golper TA, Illingworth DR, Morris CD, et al. Lovastatin in the treatment of multifactorial hyperlipidemia associated with proteinuria. American Journal of Kidney Diseases. 1989;13(4):312-20. Sample size less than 50 patients. [pmid: 2650539].
1510 Gomes VO, Poli de Figueredo CE, Caramori P, et al. N-acetylcysteine does not prevent contrast induced nephropathy after cardiac catheterisation with an ionic low osmolality contrast medium: a multicentre clinical trial. Heart. 2005;91(6):774-8. Not relevant to key questions. [pmid: 15894775].
1511 Gonzalez GL, Manrique CM, Sowers JR. High cardiovascular risk in patients with diabetes and the cardiometabolic syndrome: mandate for statin therapy. Journal of the CardioMetabolic Syndrome. 2006;1(3):178-83. Not RCT or controlled trial. [pmid: 17679817].
1512 Gonzalez RP, Falimirski M, Holevar MR, et al. Surgical management of renal trauma: is vascular control necessary?. Journal of Trauma-Injury Infection & Critical Care. 1999;47(6):1039-42. discussion 42-4. Not CKD treatment.
1513 Gonzalez-Abraldes J, Albillos A, Banares R, et al. Randomized comparison of long-term losartan versus propranolol in lowering portal pressure in cirrhosis. Gastroenterology. 2001;121(2):382-8. Not early CKD. [pmid: 11487547].
1514 Gonzalez-Ortiz M, Mora-Martinez JM, Martinez-Abundis E, et al. Effect of valsartan on renal handling of uric acid in healthy subjects. Journal of Nephrology. 2000;13(2):126-8. Not early CKD. [pmid: 10858975].
1515 Good J, Frost G, Oakley CM, et al. The renal effects of dopamine and dobutamine in stable chronic heart failure. Postgraduate Medical Journal. Suppl 2. 1992;68:S7-11. Not CKD treatment. [pmid: 1461870].
1516 Good JM, Brady AJ, Noormohamed FH, et al. Effect of intense angiotensin II suppression on the diuretic response to furosemide during chronic ACE inhibition. Circulation. 1994;90(1):220-4. Sample size less than 50 patients. [pmid: 8026000].
1517 Goodman WG, Frazao JM, Goodkin DA, et al. A calcimimetic agent lowers plasma parathyroid hormone levels in patients with secondary hyperparathyroidism. Kidney International. 2000;58(1):436-45. Not early CKD. [pmid: 10886592].
1518 Gookin JL, McWhorter D, Vaden S, et al. Outcome assessment of a computer-animated model for learning about the regulation of glomerular filtration rate. Advances in Physiology Education. Jun. 2010;34(2):97-105. Not CKD treatment. [pmid: 20522905].
1519 Goonasekera CD, Dillon MJ. Random zero sphygmomanometer versus automatic oscillometric blood pressure monitor; is either the instrument of choice?. Journal of Human Hypertension. 1995;9(11):885-9. Not CKD treatment. [pmid: 8583467].
1520 Gordon AC, Russell JA, Walley KR, et al. The effects of vasopressin on acute kidney injury in septic shock. Intensive Care Medicine. Jan. 2010;36(1):83-91. Not CKD treatment. [pmid: 19841897].
1521 Gordon EJ, Prohaska TR, Gallant MP, et al. Longitudinal analysis of physical activity, fluid intake, and graft function among kidney transplant recipients. Transplant International. 2009;22(10):990-8. Not RCT or controlled trial. [pmid: 19619168].
1522 Gorse GJ, Bernstein JM, Cronin RE, et al. A comparison of netilmicin and tobramycin therapy in patients with renal impairment. Scandinavian Journal of Infectious Diseases. 1992;24(4):503-14. Not CKD treatment. [pmid: 1411317].
1523 Goswami K, Gachhui R, Bandopadhyay A. Hepatorenal dysfunctions in lead pollution. Journal of Environmental Science & Engineering. 2005;47(1):75-80. Sample size less than 50 patients. [pmid: 16669340].
1524 Goto F, Kato S, Sudo I. Treatment of intraoperative hypertension with enflurane, nicardipine, or human atrial natriuretic peptide: haemodynamic and renal effects. Canadian Journal of Anaesthesia. 1992;39(9):932-7. Not CKD treatment. [pmid: 1451221].
1525 Gottesman RF, Sozio SM. Management of symptomatic carotid stenosis in individuals with CKD. Journal of the American Society of Nephrology. 2010;21(1):9-11. Not RCT or controlled trial. [pmid: 19959712].
1526 Gottlieb SS. Adenosine A1 antagonists and the cardiorenal syndrome. Current Heart Failure Reports. 2008;5(2):105-9. Not CKD treatment. [pmid: 18765081].
1527 Gottlieb SS, Brater DC, Thomas I, et al. BG9719 (CVT-124), an A1 adenosine receptor antagonist, protects against the decline in renal function observed with diuretic therapy. [Erratum appears in Circulation 2002 Sep 24; 106(13):1743]. Circulation. 2002;105(11):1348-53. Follow-up less than 6 months. [pmid: 11901047].
1528 Gottlieb SS, Skettino SL, Wolff A, et al. Effects of BG9719 (CVT-124), an A1-adenosine receptor antagonist, and furosemide on glomerular filtration rate and natriuresis in patients with congestive heart failure. Journal of the American College of Cardiology. 2000;35(1):56-9. Sample size less than 50 patients. [pmid: 10636259].
1529 Gould MM, Mohamed-Ali V, Goubet SA, et al. Associations of urinary albumin excretion rate with vascular disease in europid nondiabetic subjects. Journal of Diabetes & its Complications. 1994;8(3):180-8. Not RCT or controlled trial. [pmid: 8086657].
1530 Gouva C, Nikolopoulos P, Ioannidis JPA, et al. Treating anemia early in renal failure patients slows the decline of renal function: a randomized controlled trial. Kidney International. 2004;66(2):753-60. Not relevant to key questions. [pmid: 15253730].
1531 Govindarajan G, Saab G, Whaley-Connell A. Outcomes of carotid revascularization in patients with chronic kidney disease. Advances in Chronic Kidney Disease. 2008;15(4):347-54. Not CKD treatment. [pmid: 18805380].
1532 Graber SE, Krantz SB. Erythropoietin: biology and clinical use. Hematology - Oncology Clinics of North America. 1989;3(3):369-400. Not relevant to key questions.
1533 Gradman AH. Evolving understanding of the renin-angiotensin-aldosterone system: pathophysiology and targets for therapeutic intervention. American Heart Journal. 2009;157(6 Suppl):S1-6. Not RCT or controlled trial. [pmid: 19450719].
1534 Graiff C, Bezza M, Ziller F, et al. Caerulein in the treatment of biliary and renal colic. Peptides. Suppl 3. 1985;6:47-51. Not CKD treatment. [pmid: 3831972].
1535 Grande L, Rimola A, Cugat E, et al. Effect of venovenous bypass on perioperative renal function in liver transplantation: results of a randomized, controlled trial. Hepatology. 1996;23(6):1418-28. Not CKD treatment. [pmid: 8675159].
1536 Grant MC, Kon Z, Joshi A, et al. Is aprotinin safe to use in a cohort at increased risk for thrombotic events: results from a randomized, prospective trial in off-pump coronary artery bypass. Annals of Thoracic Surgery. 2008;86(3):815-22. discussion -22. Sample size less than 50 patients. [pmid: 18721566].
1537 Gras J, Llenas J, Jansat JM, et al. Almotriptan, a new anti-migraine agent: a review. CNS Drug Reviews. 2002;8(3):217-34. Not CKD treatment. [pmid: 12353056].
1538 Grases F, Garcia-Gonzalez R, Redondo E, et al. Effects of escin on indinavir crystallization time in the urine of patients with HIV-I infection: a multicenter, randomized, open-label, controlled, four-period crossover trial. Clinical Therapeutics. 2004;26(12):2045-55. Follow-up less than 6 months. [pmid: 15823768].
1539 Grassegger A, Schuler G, Hessenberger G, et al. Interferon-gamma in the treatment of systemic sclerosis: a randomized controlled multicentre trial. British Journal of Dermatology. 1998;139(4):639-48. Sample size less than 50 patients. [pmid: 9892907].
1540 Greenbaum R, Zucchelli P, Caspi A, et al. Comparison of the pharmacokinetics of fosinoprilat with enalaprilat and lisinopril in patients with congestive heart failure and chronic renal insufficiency. British Journal of Clinical Pharmacology. 2000;49(1):23-31. Follow-up less than 6 months. [pmid: 10606834].
1541 Greenberg B, Thomas I, Banish D, et al. Effects of multiple oral doses of an A1 adenosine antagonist, BG9928, in patients with heart failure: results of a placebo-controlled, dose-escalation study. Journal of the American College of Cardiology. 2007;50(7):600-6. Not RCT or controlled trial. [pmid: 17692744].
1542 Greene T, Daugirdas JT, Depner TA, et al. Solute clearances and fluid removal in the frequent hemodialysis network trials. American Journal of Kidney Diseases. 2009;53(5):835-44. Not early CKD. [pmid: 19339093].
1543 Greenstone MA, Shaw AB. Alternate day corticosteroid causes alternate day hyperglycaemia. Postgraduate Medical Journal. 1987;63(743):761-4. Not RCT or controlled trial. [pmid: 3444801].
1544 Greenwood V. ARBs vs ACE inhibitors for preventing diabetic nephropathy. Journal of Family Practice. 2005;54(5):453. discussion -4. Not RCT or controlled trial. [pmid: 15865904].
1545 Gregory DD, Sarnak MJ, Konstam MA, et al. Impact of chronic kidney disease and anemia on hospitalization expense in patients with left ventricular dysfunction. American Journal of Cardiology. 2003;92(11):1300-5. Not CKD treatment. [pmid: 14636907].
1546 Greminger P, Foerster E, Vetter H, et al. Minoxidil and captopril in severe hypertension. Klinische Wochenschrift. 1986;64(7):327-32. Sample size less than 50 patients. [pmid: 3520132].
1547 Gretz N, Strauch M. Statistical problems in designing, conducting, and analysing nutritional trials in patients with chronic renal failure. Contributions to Nephrology. 1986;53:82-91. Not RCT or controlled trial. [pmid: 3802826].
1548 Grima KM. Therapeutic apheresis in hematological and oncological diseases. Journal of Clinical Apheresis. 2000;15(1-2):28-52. Not relevant to key questions. [pmid: 10767050].
1549 Grimm RH Jr., Svendsen KH, Kasiske B, et al. Proteinuria is a risk factor for mortality over 10 years of follow-up. MRFIT Research Group. Multiple Risk Factor Intervention Trial. Kidney International - Supplement. 1997;63:S10-4. Not RCT or controlled trial. [pmid: 9407412].
1550 Groban L, Ebert TJ, Kreis DU, et al. Hemodynamic, renal, and hormonal responses to incremental ANF infusions in humans. American Journal of Physiology. 1989;256(5 Pt 2):F780-6. Sample size less than 50 patients. [pmid: 2524166].
1551 Groetzner J, Kaczmarek I, Landwehr P, et al. Renal recovery after conversion to a calcineurin inhibitor-free immunosuppression in late cardiac transplant recipients. European Journal of Cardio-Thoracic Surgery. 2004;25(3):333-41. Sample size less than 50 patients. [pmid: 15019657].
1552 Groetzner J, Kaczmarek I, Schulz U, et al. Mycophenolate and sirolimus as calcineurin inhibitor-free immunosuppression improves renal function better than calcineurin inhibitor-reduction in late cardiac transplant recipients with chronic renal failure. [Erratum appears in Transplantation. 2009 Apr 27; 87(8):1264]. Transplantation. 2009;87(5):726-33. Not CKD treatment. [pmid: 19295318].
1553 Groetzner J, Meiser B, Landwehr P, et al. Mycophenolate mofetil and sirolimus as calcineurin inhibitor-free immunosuppression for late cardiac-transplant recipients with chronic renal failure. Transplantation. 2004;77(4):568-74. Not CKD treatment. [pmid: 15084937].
1554 Groetzner J, Meiser BM, Schirmer J, et al. Tacrolimus or cyclosporine for immunosuppression after cardiac transplantation: which treatment reveals more side effects during long-term follow-up?. Transplantation Proceedings. 2001;33(1-2):1461-4. Not CKD treatment. [pmid: 11267373].
1555 Groetzner J, Wittwer T, Kaczmarek I, et al. Conversion to sirolimus and mycophenolate can attenuate the progression of bronchiolitis obliterans syndrome and improves renal function after lung transplantation. Transplantation. 2006;81(3):355-60. Sample size less than 50 patients. [pmid: 16477220].
1556 Groggel GC, Cheung AK, Ellis-Benigni K, et al. Treatment of nephrotic hyperlipoproteinemia with gemfibrozil. Kidney International. 1989;36(2):266-71. Sample size less than 50 patients. [pmid: 2779095].
1557 Gross AS, McLachlan AJ, Minns I, et al. Simultaneous administration of a cocktail of markers to measure renal drug elimination pathways: absence of a pharmacokinetic interaction between fluconazole and sinistrin, p-aminohippuric acid and pindolol. British Journal of Clinical Pharmacology. 2001;51(6):547-55. Not CKD treatment. [pmid: 11422014].
1558 Gross JL, Zelmanovitz T, Moulin CC, et al. Effect of a chicken-based diet on renal function and lipid profile in patients with type 2 diabetes: a randomized crossover trial. Diabetes Care. 2002;25(4):645-51. Sample size less than 50 patients. [pmid: 11919119].
1559 Gross P, Schirutschke H, Barnett K. Should we prescribe blood pressure lowering drugs to every patient with advanced chronic kidney disease? A comment on two recent meta-analyses. Polskie Archiwum Medycyny Wewnetrznej. Oct. 2009;119(10):644-7. Not RCT or controlled trial. [pmid: 19847140].
1560 Grossman E, Messerli FH. Why beta-blockers are not cardioprotective in elderly patients with hypertension. Current Cardiology Reports. 2002;4(6):468-73. Not RCT or controlled trial. [pmid: 12379165].
1561 Grossman PD, Burroughs M, Guthmann RA. Clinical inquiries. What interventions reduce the risk of contrast nephropathy for high-risk patients?. Journal of Family Practice. 2005;54(4):365-7. Not RCT or controlled trial. [pmid: 15833230].
1562 Grossman RM, Chevret S, Abi-Rached J, et al. Long-term safety of cyclosporine in the treatment of psoriasis. Archives of Dermatology. 1996;132(6):623-9. Not CKD treatment. [pmid: 8651712].
1563 Grostern RJ, Bryar PJ, Zimbric ML, et al. Toxicity and dose-response studies of 1alpha-hydroxyvitamin D2 in a retinoblastoma xenograft model. Archives of Ophthalmology. 2002;120(5):607-12. Not human studies. [pmid: 12003610].
1564 Groth S, Nielsen H, Sorensen JB, et al. Acute and long-term nephrotoxicity of cis-platinum in man. Cancer Chemotherapy & Pharmacology. 1986;17(2):191-6. Not CKD treatment. [pmid: 2424627].
1565 Group ACEIiPRDS. Summaries for patients. Using a type of blood pressure medicine, angiotensin-converting enzyme inhibitors, to prevent worsening of kidney disease unrelated to diabetes. Annals of Internal Medicine. 2001;135(2):S-21. Not RCT or controlled trial.
1566 Group ACEIiDNT. Should all patients with type 1 diabetes mellitus and microalbuminuria receive angiotensin-converting enzyme inhibitors? A meta-analysis of individual patient data. Annals of Internal Medicine. 2001;134(5):370-9. Not relevant to key questions. [pmid: 11242497].
1567 Group AS, Cushman WC, Evans GW, et al. Effects of intensive blood-pressure control in type 2 diabetes mellitus. New England Journal of Medicine. Apr. 29. 2010;362(17):1575-85. Not CKD treatment. [pmid: 20228401].
1568 Group B. The BErgamo NEphrologic DIabetes Complications Trial (BENEDICT): design and baseline characteristics. Controlled Clinical Trials. 2003;24(4):442-61. Not RCT or controlled trial. [pmid: 12865039].
1569 Group PS. Dissociation between blood pressure reduction and fall in proteinuria in primary renal disease: a randomized double-blind trial. Journal of Hypertension. 2002;20(4):729-37. Not CKD treatment. [pmid: 11910310].
1570 Grover-Paez F, Villegas Rivera G, Guillen Ortiz R. Sildenafil citrate diminishes microalbuminuria and the percentage of A1c in male patients with type 2 diabetes. Diabetes Research & Clinical Practice. 2007;78(1):136-40. Follow-up less than 6 months. [pmid: 17374416].
1571 Gruberg L, Waksman R, Ajani AE, et al. The effect of intracoronary radiation for the treatment of recurrent in-stent restenosis in patients with chronic renal failure. Journal of the American College of Cardiology. 2001;38(4):1049-53. Not RCT or controlled trial. [pmid: 11583881].
1572 Gruss E, Tomas JF, Bernis C, et al. Nephroprotective effect of cilastatin in allogeneic bone marrow transplantation. Results from a retrospective analysis. Bone Marrow Transplantation. 1996;18(4):761-5. Not RCT or controlled trial. [pmid: 8899192].
1573 Gualano B, Ugrinowitsch C, Novaes RB, et al. Effects of creatine supplementation on renal function: a randomized, double-blind, placebo-controlled clinical trial. European Journal of Applied Physiology. 2008;103(1):33-40. Not CKD treatment. [pmid: 18188581].
1574 Guasch A. Improving renal outcomes in chronic anemia: learning from paroxysmal nocturnal hemoglobinuria. American Journal of Hematology. Aug. 2010;85(8):551-2. Not RCT or controlled trial. [pmid: 20658585].
1575 Guasch A, Parham M, Zayas CF, et al. Contrasting effects of calcium channel blockade versus converting enzyme inhibition on proteinuria in African Americans with non-insulin-dependent diabetes mellitus and nephropathy. Journal of the American Society of Nephrology. 1997;8(5):793-8. Sample size less than 50 patients. [pmid: 9176849].
1576 Guastalla JP, Vermorken JB, Wils JA, et al. Phase II trial for intraperitoneal cisplatin plus intravenous sodium thiosulphate in advanced ovarian carcinoma patients with minimal residual disease after cisplatin-based chemotherapy--a phase II study of the EORTC Gynaecological Cancer Cooperative Group. European Journal of Cancer. 1994;30A(1):45-9. Not CKD treatment. [pmid: 8142163].
1577 Gubern JM, Sancho JJ, Simo J, et al. A randomized trial on the effect of mannitol on postoperative renal function in patients with obstructive jaundice. Surgery. 1988;103(1):39-44. Sample size less than 50 patients. [pmid: 3122349].
1578 Gudbjornsdottir S, Friberg P, Elam M, et al. The effect of metformin and insulin on sympathetic nerve activity, norepinephrine spillover and blood pressure in obese, insulin resistant, normoglycemic, hypertensive men. Blood Pressure. 1994;3(6):394-403. Sample size less than 50 patients. [pmid: 7704288].
1579 Gude E, Gullestad L, Arora S, et al. Benefit of early conversion from CNI-based to everolimus-based immunosuppression in heart transplantation. Journal of Heart & Lung Transplantation. Jun. 2010;29(6):641-7. Not CKD treatment. [pmid: 20304681].
1580 Guerin C, Girard R, Selli JM, et al. Initial versus delayed acute renal failure in the intensive care unit. A multicenter prospective epidemiological study. Rhone-Alpes Area Study Group on Acute Renal Failure. [Erratum appears in Am J Respir Crit Care Med 2001 Mar; 163(3 Pt 1):793-4]. American Journal of Respiratory & Critical Care Medicine. 2000;161(3 Pt 1):872-9. Not RCT or controlled trial. [pmid: 10712336].
1581 Guerra JG, Casalino E, Palomino JC, et al. Imipenem/cilastatin vs. gentamicin/clindamycin for the treatment of moderate to severe infections in hospitalized patients. Reviews of Infectious Diseases. Suppl 3. 1985;7:S463-70. Not early CKD. [pmid: 3901209].
1582 Guerrero-Romero F, Rodriguez-Moran M, Paniagua-Sierra JR, et al. Pentoxifylline reduces proteinuria in insulin-dependent and non insulin-dependent diabetic patients. Clinical Nephrology. 1995;43(2):116-21. Follow-up less than 6 months. [pmid: 7736673].
1583 Guglielmi G, de Terlizzi F, Aucella F, et al. Quantitative ultrasound technique at the phalanges in discriminating between uremic and osteoporotic patients. European Journal of Radiology. 2006;60(1):108-14. Not RCT or controlled trial. [pmid: 16750341].
1584 Guh JY. Proteinuria versus albuminuria in chronic kidney disease. Nephrology. Jun. Suppl 2. 2010;15:53-6. Not CKD treatment. [pmid: 20586950].
1585 Guillet C. Overview of novel renal properties of tertatolol. Cardiology. Suppl 1. 1993;83:64-9. Sample size less than 50 patients. [pmid: 7903218].
1586 Guillevin L, Le Thi Huong Du, Godeau P, et al. Clinical findings and prognosis of polyarteritis nodosa and Churg-Strauss angiitis: a study in 165 patients. British Journal of Rheumatology. 1988;27(4):258-64. Not RCT or controlled trial. [pmid: 2900659].
1587 Guitterez NV, Diaz A, Timmis GC, et al. Determinants of serum creatinine trajectory in acute contrast nephropathy. Journal of Interventional Cardiology. 2002;15(5):349-54. Not CKD treatment. [pmid: 12440177].
1588 Guizar JM, Kornhauser C, Malacara JM, et al. Renal functional reserve in patients with recently diagnosed Type 2 diabetes mellitus with and without microalbuminuria. Nephron. 2001;87(3):223-30. Not RCT or controlled trial. [pmid: 11287757].
1589 Gulel O, Keles T, Eraslan H, et al. Prophylactic acetylcysteine usage for prevention of contrast nephropathy after coronary angiography. Journal of Cardiovascular Pharmacology. 2005;46(4):464-7. Follow-up less than 6 months. [pmid: 16160598].
1590 Gullestad L, Iversen M, Mortensen SA, et al. Everolimus with reduced calcineurin inhibitor in thoracic transplant recipients with renal dysfunction: a multicenter, randomized trial. Transplantation. Apr. 15. 2010;89(7):864-72. Not CKD treatment. [pmid: 20061999].
1591 Gulmann C, Rudberg S, Osterby R. Renal arterioles in patients with type I diabetes and microalbuminuria before and after treatment with antihypertensive drugs. Virchows Archiv. 1999;434(6):523-8. Sample size less than 50 patients. [pmid: 10394887].
1592 Guney I, Selcuk NY, Altintepe L, et al. Antifibrotic effects of aldosterone receptor blocker (spironolactone) in patients with chronic kidney disease. Renal Failure. 2009;31(9):779-84. Sample size less than 50 patients. [pmid: 19925284].
1593 Gunning TC, Brown MR, Swygert TH, et al. Perioperative renal function in patients undergoing orthotopic liver transplantation. A randomized trial of the effects of verapamil. Transplantation. 1991;51(2):422-7. Not CKD treatment. [pmid: 1994537].
1594 Gunst J, Schetz M. Clinical benefits of tight glycaemic control: effect on the kidney. Best Practice & Research. Clinical Anaesthesiology. 2009;23(4):431-9. Not RCT or controlled trial.
1595 Guo LL, Pan Y, Jin HM. Adiponectin is positively associated with insulin resistance in subjects with type 2 diabetic nephropathy and effects of angiotensin II type 1 receptor blocker losartan. Nephrology Dialysis Transplantation. 2009;24(6):1876-83. Not relevant to key questions.
1596 Gupta AK, Rocher LL, Schmaltz SP, et al. Short-term changes in renal function, blood pressure, and electrolyte levels in patients receiving cyclosporine for dermatologic disorders. Archives of Internal Medicine. 1991;151(2):356-62. Not CKD treatment. [pmid: 1992963].
1597 Gupta R, Birnbaum Y, Uretsky BF. The renal patient with coronary artery disease: current concepts and dilemmas. Journal of the American College of Cardiology. 2004;44(7):1343-53. Follow-up less than 6 months. [pmid: 15464310].
1598 Gupta RK, Kapoor A, Tewari S, et al. Captopril for prevention of contrast-induced nephropathy in diabetic patients: a randomised study. Indian Heart Journal. 1999;51(5):521-6. Not early CKD. [pmid: 10721643].
1599 Gupta RK, Kjeldsen SE, Krause L, et al. Hemodynamic effects of quinapril, a novel angiotensin-converting enzyme inhibitor. Clinical Pharmacology & Therapeutics. 1990;48(1):41-9. Sample size less than 50 patients. [pmid: 2196144].
1600 Gupta SK, Parker RA, Robbins GK, et al. The effects of highly active antiretroviral therapy on albuminuria in HIV-infected persons: results from a randomized trial. Nephrology Dialysis Transplantation. 2005;20(10):2237-42. Not CKD treatment.
1601 Gupta SK, Smurzynski M, Franceschini N, et al. The effects of HIV type-1 viral suppression and non-viral factors on quantitative proteinuria in the highly active antiretroviral therapy era. Antiviral Therapy. 2009;14(4):543-9. Not RCT or controlled trial. [pmid: 19578239].
1602 Gurley SB, Coffman TM. The renin-angiotensin system and diabetic nephropathy. Seminars in Nephrology. 2007;27(2):144-52. Not RCT or controlled trial. [pmid: 17418683].
1603 Gurm HS, Lincoff AM, Kleiman NS, et al. Double jeopardy of renal insufficiency and anemia in patients undergoing percutaneous coronary interventions. American Journal of Cardiology. 2004;94(1):30-4. Not CKD treatment. [pmid: 15219504].
1604 Guru V, Fremes SE. The role of N-acetylcysteine in preventing radiographic contrast-induced nephropathy. Clinical Nephrology. 2004;62(2):77-83. Not CKD treatment. [pmid: 15356963].
1605 Gutzwiller JP, Tschopp S, Bock A, et al. Glucagon-like peptide 1 induces natriuresis in healthy subjects and in insulin-resistant obese men. Journal of Clinical Endocrinology & Metabolism. 2004;89(6):3055-61. Not relevant to key questions. [pmid: 15181098].
1606 Guy M, Newall R, Borzomato J, et al. Use of a first-line urine protein-to-creatinine ratio strip test on random urines to rule out proteinuria in patients with chronic kidney disease. Nephrology Dialysis Transplantation. 2009;24(4):1189-93. Not CKD treatment.
1607 Guy M, Newall R, Borzomato J, et al. Diagnostic accuracy of the urinary albumin: creatinine ratio determined by the CLINITEK Microalbumin and DCA 2000+ for the rule-out of albuminuria in chronic kidney disease. Clinica Chimica Acta. 2009;399(1-2):54-8. Not CKD treatment.
1608 Guy M, Newall R, Borzomato J, et al. Use of a first-line urine protein-to-creatinine ratio strip test on random urines to rule out proteinuria in patients with chronic kidney disease. Nephrology Dialysis Transplantation. 2009;24(4):1189-93. Not CKD treatment.
1609 Haanpaa ML, Gourlay GK, Kent JL, et al. Treatment considerations for patients with neuropathic pain and other medical comorbidities. Mayo Clinic Proceedings. Mar. 2010;85(3 Suppl):S15-25. Not CKD treatment. [pmid: 20194144].
1610 Haase M, Haase-Fielitz A, Bagshaw SM, et al. Phase II, randomized, controlled trial of high-dose N-acetylcysteine in high-risk cardiac surgery patients. Critical Care Medicine. 2007;35(5):1324-31. Not RCT or controlled trial. [pmid: 17414730].
1611 Haase M, Haase-Fielitz A, Bellomo R, et al. Sodium bicarbonate to prevent increases in serum creatinine after cardiac surgery: a pilot double-blind, randomized controlled trial. Critical Care Medicine. 2009;37(1):39-47. Not RCT or controlled trial. [pmid: 19112278].
1612 Haase M, Haase-Fielitz A, Ratnaike S, et al. N-Acetylcysteine does not artifactually lower plasma creatinine concentration. Nephrology Dialysis Transplantation. 2008;23(5):1581-7. Follow-up less than 6 months.
1613 Hadjadj S, Gourdy P, Zaoui P, et al. Effect of raloxifene -- a selective oestrogen receptor modulator -- on kidney function in post-menopausal women with Type 2 diabetes: results from a randomized, placebo-controlled pilot trial. Diabetic Medicine. 2007;24(8):906-10. Not relevant to key questions. [pmid: 17451421].
1614 Hadj-Aissa A, Bankir L, Fraysse M, et al. Influence of the level of hydration on the renal response to a protein meal. Kidney International. 1992;42(5):1207-16. Sample size less than 50 patients. [pmid: 1453605].
1615 Hadjibabaie M, Alimoghaddam K, Shamshiri AR, et al. Continuous bladder irrigation prevents hemorrhagic cystitis after allogeneic hematopoietic cell transplantation. Urologic Oncology. 2008;26(1):43-6. Sample size less than 50 patients. [pmid: 18190829].
1616 Haffner CA, Kendall MJ, Struthers AD, et al. Effects of captopril and enalapril on renal function in elderly patients with chronic heart failure. Postgraduate Medical Journal. 1995;71(835):287-92. Follow-up less than 6 months. [pmid: 7596934].
1617 Hafner J, Keusch G, Wahl C, et al. Uremic small-artery disease with medial calcification and intimal hyperplasia (so-called calciphylaxis): a complication of chronic renal failure and benefit from parathyroidectomy. Journal of the American Academy of Dermatology. 1995;33(6):954-62. Not RCT or controlled trial. [pmid: 7490365].
1618 Hager B, Betschart M, Krapf R. Effect of postoperative intravenous loop diuretic on renal function after major surgery. Schweizerische Medizinische Wochenschrift. Journal Suisse de Medecine. 1996;126(16):666-73. Follow-up less than 6 months. [pmid: 8658094].
1619 Hagg E, Carlberg BC, Hillorn VS, et al. Magnesium therapy in type 1 diabetes. A double blind study concerning the effects on kidney function and serum lipid levels. Magnesium Research. 1999;12(2):123-30. Sample size less than 50 patients. [pmid: 10423707].
1620 Haghi D, Papavassiliu T, Hach C, et al. Utility of combined parameters of common carotid intima-media thickness or albuminuria in diagnosis of coronary artery disease in women. International Journal of Cardiology. 2005;105(2):134-40. Follow-up less than 6 months. [pmid: 16243103].
1621 Haight AE, Kaste SC, Goloubeva OG, et al. Nephrotoxicity of iopamidol in pediatric, adolescent, and young adult patients who have undergone allogeneic bone marrow transplantation. Radiology. 2003;226(2):399-404. Not CKD treatment. [pmid: 12563132].
1622 Hailpern SM, Melamed ML, Cohen HW, et al. Moderate chronic kidney disease and cognitive function in adults 20 to 59 years of age: Third National Health and Nutrition Examination Survey (NHANES III). Journal of the American Society of Nephrology. 2007;18(7):2205-13. Not CKD treatment. [pmid: 17554148].
1623 Haines AP, Sanders TA, Imeson JD, et al. Effects of a fish oil supplement on platelet function, haemostatic variables and albuminuria in insulin-dependent diabetics. Thrombosis Research. 1986;43(6):643-55. Sample size less than 50 patients. [pmid: 3020732].
1624 Hale WA, Nashelsky J, Wilson SA. Clinical inquiries. Does screening for microalbuminuria in diabetes prevent complications?. Journal of Family Practice. 2003;52(3):229-31. Not RCT or controlled trial. [pmid: 12620179].
1625 Halimi JM, Asmar R, Ribstein J. Optimal nephroprotection: use, misuse and misconceptions about blockade of the renin-angiotensin system. Lessons from the ONTARGET and other recent trials. Diabetes & Metabolism. 2009;35(6):425-30. Not RCT or controlled trial. [pmid: 19786360].
1626 Halkin A, Mehran R, Casey CW, et al. Impact of moderate renal insufficiency on restenosis and adverse clinical events after paclitaxel-eluting and bare metal stent implantation: results from the TAXUS-IV Trial. American Heart Journal. 2005;150(6):1163-70. Not relevant to key questions. [pmid: 16338253].
1627 Hall AM, Edwards SG, Lapsley M, et al. Subclinical tubular injury in HIV-infected individuals on antiretroviral therapy: a cross-sectional analysis. American Journal of Kidney Diseases. 2009;54(6):1034-42. Not RCT or controlled trial. [pmid: 19783343].
1628 Hall WD, Kusek JW, Kirk KA, et al. Short-term effects of blood pressure control and antihypertensive drug regimen on glomerular filtration rate: the African-American Study of Kidney Disease and Hypertension Pilot Study. American Journal of Kidney Diseases. 1997;29(5):720-8. Follow-up less than 6 months. [pmid: 9159306].
1629 Hallab M, Gallois Y, Chatellier G, et al. Comparison of reduction in microalbuminuria by enalapril and hydrochlorothiazide in normotensive patients with insulin dependent diabetes. BMJ. 1993;306(6871):175-82. Sample size less than 50 patients. [pmid: 8443481].
1630 Hallan H, Romundstad S, Kvenild K, et al. Microalbuminuria in diabetic and hypertensive patients and the general population--consequences of various diagnostic criteria--the Nord-Trondelag Health Study (HUNT). Scandinavian Journal of Urology & Nephrology. 2003;37(2):151-8. Not CKD treatment. [pmid: 12745725].
1631 Hallen B, Guilbaud O, Stromberg S, et al. Single-dose pharmacokinetics of terodiline, including a stable isotope technique for improvement of statistical evaluations. Biopharmaceutics & Drug Disposition. 1988;9(3):229-50. Sample size less than 50 patients.
1632 Haller H, Viberti GC, Mimran A, et al. Preventing microalbuminuria in patients with diabetes: rationale and design of the Randomised Olmesartan and Diabetes Microalbuminuria Prevention (ROADMAP) study. Journal of Hypertension. 2006;24(2):403-8. Not relevant to key questions. [pmid: 16508590].
1633 Halpenny M, Lakshmi S, O'Donnell A, et al. Fenoldopam: renal and splanchnic effects in patients undergoing coronary artery bypass grafting. Anaesthesia. 2001;56(10):953-60. Sample size less than 50 patients. [pmid: 11576097].
1634 Halpenny M, Rushe C, Breen P, et al. The effects of fenoldopam on renal function in patients undergoing elective aortic surgery. European Journal of Anaesthesiology. 2002;19(1):32-9. Not early CKD. [pmid: 11913801].
1635 Halperin AK, Cubeddu LX. The role of calcium channel blockers in the treatment of hypertension. American Heart Journal. 1986;111(2):363-82. Not RCT or controlled trial. [pmid: 3511651].
1636 Halperin M, Lan KK, Wright EC, et al. Stochastic curtailing for comparison of slopes in longitudinal studies. Controlled Clinical Trials. 1987;8(4):315-26. Not RCT or controlled trial. [pmid: 3327652].
1637 Hamazaki T, Takazakura E, Osawa K, et al. Reduction in microalbuminuria in diabetics by eicosapentaenoic acid ethyl ester. Lipids. 1990;25(9):541-5. Sample size less than 50 patients. [pmid: 2250591].
1638 Hamilton RA, Kane MP, Demers J. Angiotensin-converting enzyme inhibitors and type 2 diabetic nephropathy: a meta-analysis. Pharmacotherapy. 2003;23(7):909-15. Not RCT or controlled trial. [pmid: 12885103].
1639 Hammond PJ, Wade AF, Gwilliam ME, et al. Amino acid infusion blocks renal tubular uptake of an indium-labelled somatostatin analogue. British Journal of Cancer. 1993;67(6):1437-9. Not CKD treatment. [pmid: 8099808].
1640 Hampl H, Steinmuller T, Frohling P, et al. Long-term results of total parathyroidectomy without autotransplantation in patients with and without renal failure. Mineral & Electrolyte Metabolism. 1999;25(3):161-70. Not early CKD. [pmid: 10436401].
1641 Han SS, Kim KW, Na KY, et al. Quality of life and mortality from a nephrologist's view: a prospective observational study. BMC Nephrology. 2009:10-39. Not CKD treatment.
1642 Haneda M, Kikkawa R, Sakai H, et al. Antiproteinuric effect of candesartan cilexetil in Japanese subjects with type 2 diabetes and nephropathy. Diabetes Research & Clinical Practice. 2004;66(1):87-95. Not relevant to key questions. [pmid: 15364166].
1643 Hannedouche T, Chanard J, Baumelou B, et al. Evaluation of the safety and efficacy of telmisartan and enalapril, with the potential addition of frusemide, in moderate-renal failure patients with mild-to-moderate hypertension. Journal of the Renin-Angiotensin-Aldosterone System. 2001;2(4):246-54. Follow-up less than 6 months. [pmid: 11881131].
1644 Hannedouche T, Natov S, Ikeni A, et al. Does lithium affect renal sodium handling and renal haemodynamics in normal man?. Nephrology Dialysis Transplantation. 1990;5(12):1007-12. Not CKD treatment.
1645 Hannedouche TP, Natov S, Boitard C, et al. Angiotensin converting enzyme inhibition and chronic cyclosporine-induced renal dysfunction in type 1 diabetes. Nephrology Dialysis Transplantation. 1996;11(4):673-8. Follow-up less than 6 months.
1646 Hannisdal E, Kildahl-Andersen O, Grottum KA, et al. Prognostic factors in multiple myeloma in a population-based trial. European Journal of Haematology. 1990;45(4):198-202. Not CKD treatment. [pmid: 2226737].
1647 Hans B, Hans SS, Mittal VK, et al. Renal functional response to dopamine during and after arteriography in patients with chronic renal insufficiency. Radiology. 1990;176(3):651-4. Not CKD treatment. [pmid: 2202010].
1648 Hans SS, Hans BA, Dhillon R, et al. Effect of dopamine on renal function after arteriography in patients with pre-existing renal insufficiency. American Surgeon. 1998;64(5):432-6. Not CKD treatment. [pmid: 9585778].
1649 Hansen HP, Christensen PK, Tauber-Lassen E, et al. Low-protein diet and kidney function in insulin-dependent diabetic patients with diabetic nephropathy. Kidney International. 1999;55(2):621-8. Sample size less than 50 patients. [pmid: 9987086].
1650 Hansen HP, Gaede PH, Jensen BR, et al. Lack of impact of low-dose acetylsalicylic acid on kidney function in type 1 diabetic patients with microalbuminuria. Diabetes Care. 2000;23(12):1742-5. Sample size less than 50 patients. [pmid: 11128344].
1651 Hansen HP, Rossing K, Jacobsen P, et al. The acute effect of smoking on systemic haemodynamics, kidney and endothelial functions in insulin-dependent diabetic patients with microalbuminuria. Scandinavian Journal of Clinical & Laboratory Investigation. 1996;56(5):393-9. Follow-up less than 6 months. [pmid: 8869661].
1652 Hansen HP, Rossing P, Tarnow L, et al. Increased glomerular filtration rate after withdrawal of long-term antihypertensive treatment in diabetic nephropathy. Kidney International. 1995;47(6):1726-31. Not relevant to key questions. [pmid: 7643542].
1653 Hansen JM, Fogh-Andersen N, Christensen NJ, et al. Cyclosporine-induced hypertension and decline in renal function in healthy volunteers. Journal of Hypertension. 1997;15(3):319-26. Sample size less than 50 patients. [pmid: 9468460].
1654 Hansen KW, Klein F, Christensen PD, et al. Effects of captopril on ambulatory blood pressure, renal and cardiac function in microalbuminuric type 1 diabetic patients. Diabete et Metabolisme. 1994;20(5):485-93. Sample size less than 50 patients. [pmid: 7859897].
1655 Hansen KW, Pedersen MM, Christiansen JS, et al. Acute renal effects of angiotensin converting enzyme inhibition in microalbuminuric type 1 diabetic patients. Acta Diabetologica. 1993;30(3):149-53. Sample size less than 50 patients. [pmid: 8111075].
1656 Hansen PM, Mathiesen ER, Kofoed-Enevoldsen A, et al. Possible effect of angiotensin-converting enzyme inhibition on glomerular charge selectivity. Journal of Diabetes & its Complications. 1995;9(3):158-62. Sample size less than 50 patients. [pmid: 7548979].
1657 Hansen RA, Chin H, Blalock S, et al. Predialysis chronic kidney disease: evaluation of quality of life in clinic patients receiving comprehensive anemia care. Research In Social & Administrative Pharmacy. 2009;5(2):143-53. Not early CKD. [pmid: 19524862].
1658 Hansen TK, Moller J, Thomsen K, et al. Effects of growth hormone on renal tubular handling of sodium in healthy humans. American Journal of Physiology - Endocrinology & Metabolism. 2001;281(6):E1326-32. Not early CKD. [pmid: 11701449].
1659 Hanssen KF, Dahl-Jorgensen K, Brinchmann-Hansen O. The influence of strict control on diabetic complications. Acta Endocrinologica Supplementum. 1985;272:57-60. Sample size less than 50 patients. [pmid: 3914805].
1660 Hansson L. Effects of angiotensin-converting enzyme inhibition versus conventional antihypertensive therapy on the glomerular filtration rate. Cardiology. Suppl 1. 1995;86:30-3. Not CKD treatment. [pmid: 7614504].
1661 Hara K, Koga H, Kohno S, et al. The administration regimen of isepamicin in patients with chronic respiratory tract infection. Chemotherapy. 1995;41(6):462-9. Sample size less than 50 patients. [pmid: 8529437].
1662 Hardiek KJ, Katholi RE, Robbs RS, et al. Renal effects of contrast media in diabetic patients undergoing diagnostic or interventional coronary angiography. Journal of Diabetes & its Complications. 2008;22(3):171-7. Not RCT or controlled trial. [pmid: 18413220].
1663 Harding MB, Davidson CJ, Pieper KS, et al. Comparison of cardiovascular and renal toxicity after cardiac catheterization using a nonionic versus ionic radiographic contrast agent. American Journal of Cardiology. 1991;68(10):1117-9. Not CKD treatment. [pmid: 1927936].
1664 Haria M, Plosker GL, Markham A. Felodipine/metoprolol: a review of the fixed dose controlled release formulation in the management of essential hypertension. Drugs. 2000;59(1):141-57. Not CKD treatment. [pmid: 10718104].
1665 Harman C. Putting clinical trials on trial. Nature Reviews Nephrology. 2009;5(6):301. Not RCT or controlled trial.
1666 Harman-Boehm I. Angiotensin receptor blockers do not have an advantage over angiotensin-converting inhibitors [corrected]. Israel Medical Association Journal: Imaj. 2004;6(5):296-8. Not CKD treatment.
1667 Harmankaya O, Seber S, Yilmaz M. Combination of pentoxifylline with angiotensin converting enzyme inhibitors produces an additional reduction in microalbuminuria in hypertensive type 2 diabetic patients. Renal Failure. 2003;25(3):465-70. Not relevant to key questions. [pmid: 12803510].
1668 Harper PL, Williamson L, Park G, et al. A pilot study of antithrombin replacement in intensive care management: the effects on mortality, coagulation and renal function. Transfusion Medicine. 1991;1(2):121-8. Not CKD treatment. [pmid: 9259838].
1669 Harris DCH, Rangan GK. Retardation of kidney failure -- applying principles to practice. Annals of the Academy of Medicine, Singapore. 2005;34(1):16-23. Not RCT or controlled trial.
1670 Harris LE, Luft FC, Rudy DW, et al. Clinical correlates of functional status in patients with chronic renal insufficiency. American Journal of Kidney Diseases. 1993;21(2):161-6. Not RCT or controlled trial. [pmid: 8430676].
1671 Harris RZ, Salfi M, Sullivan JT, et al. Pharmacokinetics of cinacalcet hydrochloride when administered with ketoconazole. Clinical Pharmacokinetics. 2007;46(6):495-501. Not relevant to key questions. [pmid: 17518508].
1672 Harten J, Crozier JEM, McCreath B, et al. Effect of intraoperative fluid optimisation on renal function in patients undergoing emergency abdominal surgery: a randomised controlled pilot study (ISRCTN 11799696). International Journal Of Surgery. 2008;6(3):197-204. Not CKD treatment. [pmid: 18424200].
1673 Hartmann JT, Fels LM, Franzke A, et al. Comparative study of the acute nephrotoxicity from standard dose cisplatin +/- ifosfamide and high-dose chemotherapy with carboplatin and ifosfamide. Anticancer Research. 2000;20(5C):3767-73. Not RCT or controlled trial. [pmid: 11268452].
1674 Hartmann JT, Fels LM, Knop S, et al. A randomized trial comparing the nephrotoxicity of cisplatin/ifosfamide-based combination chemotherapy with or without amifostine in patients with solid tumors. Investigational New Drugs. 2000;18(3):281-9. Not early CKD. [pmid: 10958599].
1675 Hartmann JT, Knop S, Fels LM, et al. The use of reduced doses of amifostine to ameliorate nephrotoxicity of cisplatin/ifosfamide-based chemotherapy in patients with solid tumors. Anti-Cancer Drugs. 2000;11(1):1-6. Not early CKD. [pmid: 10757556].
1676 Harvey JN, Worth DP, Brown J, et al. The effect of oral fenoldopam (SKF 82526-J), a peripheral dopamine receptor agonist, on blood pressure and renal function in normal man. British Journal of Clinical Pharmacology. 1985;19(1):21-7. Sample size less than 50 patients. [pmid: 2858215].
1677 Harvey JN, Worth DP, Brown J, et al. Studies with fenoldopam, a dopamine receptor DA1 agonist, in essential hypertension. British Journal of Clinical Pharmacology. 1986;21(1):53-61. Sample size less than 50 patients. [pmid: 2868748].
1678 Harwood PJ, Giannoudis PV. The safety and efficacy of linezolid in orthopaedic practice for the treatment of infection due to antibiotic-resistant organisms. Expert Opinion on Drug Safety. 2004;3(5):405-14. Not CKD treatment. [pmid: 15335296].
1679 Hasebe N, Kikuchi K, Group NCS. Controlled-release nifedipine and candesartan low-dose combination therapy in patients with essential hypertension: the NICE Combi (Nifedipine and Candesartan Combination) Study. Journal of Hypertension. 2005;23(2):445-53. Sample size less than 50 patients. [pmid: 15662234].
1680 Hashim H, Malmberg L, Graugaard-Jensen C, et al. Desmopressin, as a “designer-drug,” in the treatment of overactive bladder syndrome. Neurourology & Urodynamics. 2009;28(1):40-6. Not CKD treatment. [pmid: 18726947].
1681 Hashizume M, Kitano S, Yamaga H, et al. Haptoglobin to protect against renal damage from ethanolamine oleate sclerosant. Lancet. 1988;2(8606):340-1. Follow-up less than 6 months. [pmid: 2899760].
1682 Hassan Y, Al-Ramahi RJ, Aziz NA, et al. Impact of a renal drug dosing service on dose adjustment in hospitalized patients with chronic kidney disease. Annals of Pharmacotherapy. 2009;43(10):1598-605. Not RCT or controlled trial. [pmid: 19776297].
1683 Hassan Y, Al-Ramahi RJ, Aziz NA, et al. Adverse drug events in hospitalized patients with chronic kidney disease. International Journal of Clinical Pharmacology & Therapeutics. Sep. 2010;48(9):571-6. Not RCT or controlled trial. [pmid: 20860910].
1684 Hasselblad V, Gattis Stough W, Shah MR, et al. Relation between dose of loop diuretics and outcomes in a heart failure population: results of the ESCAPE trial. European Journal of Heart Failure. 2007;9(10):1064-9. Follow-up less than 6 months. [pmid: 17719273].
1685 Hasselgren B, Edgar B, Johnsson G, et al. The acute haemodynamic and renal effects of oral felodipine and ramipril in healthy subjects. European Journal of Clinical Pharmacology. 1993;45(4):327-32. Sample size less than 50 patients. [pmid: 8299664].
1686 Haug K, Bakke A, Daae LN, et al. Screening for hematuria, glucosuria and proteinuria in people aged 55-64. Technical, clinical and cost-benefit experience from a pilot study. Scandinavian Journal of Primary Health Care. 1985;3(1):31-4. Not CKD treatment. [pmid: 3933072].
1687 Hausmann DF, Nutz V, Rommelsheim K, et al. Anabolic steroids in polytrauma patients. Influence on renal nitrogen and amino acid losses: a double-blind study. Jpen: Journal of Parenteral & Enteral Nutrition. 1990;14(2):111-4. Not CKD treatment. [pmid: 2112616].
1688 Hawkey CJ. Cyclooxygenase inhibition: between the devil and the deep blue sea. Gut. Suppl 3. 2002;50:III25-30. Not early CKD. [pmid: 11953329].
1689 Hawkins MJ. Interleukin-2 antitumor and effector cell responses. Seminars in Oncology. 1993;20(6 Suppl 9):52-9. Not RCT or controlled trial. [pmid: 8284693].
1690 Hawkins RG, Houston MC. Is population-wide diuretic use directly associated with the incidence of end-stage renal disease in the United States? A hypothesis. American Journal of Hypertension. 2005;18(6):744-9. Not relevant to key questions. [pmid: 15925729].
1691 Hayakawa T, Shouzu A, Nishikawa M, et al. Effects of beraprost and cilostazol and renal function on serum thrombomodulin levels in diabetic patients. Arzneimittel-Forschung. 2000;50(6):535-8. Not CKD treatment. [pmid: 10918946].
1692 Hayami S, Ishigooka M, Suzuki Y, et al. Comparison of the nephrotoxicity between ioversol and iohexol. International Urology & Nephrology. 1996;28(5):615-9. Sample size less than 50 patients. [pmid: 9061418].
1693 Hayashi K, Kumagai H, Saruta T. Effect of efonidipine and ACE inhibitors on proteinuria in human hypertension with renal impairment. American Journal of Hypertension. 2003;16(2):116-22. Not relevant to key questions. [pmid: 12559677].
1694 Hayashi K, Matsuda H, Honda M, et al. Impact of calcium antagonists on bleeding time in patients with chronic renal failure. Journal of Human Hypertension. 2002;16(3):199-203. Not CKD treatment. [pmid: 11896510].
1695 Hayashi M, Numaguchi M, Watabe H, et al. Cisplatin-induced nephrotoxicity and the protective effect of fosfomycin on it as demonstrated by using a crossover study of urinary metabolite levels. Acta Obstetricia et Gynecologica Scandinavica. 1997;76(6):590-5. Not CKD treatment. [pmid: 9246969].
1696 Hayashi Y, Ohtani M, Sawa Y, et al. Synthetic human alpha-atrial natriuretic peptide improves the management of postoperative hypertension and renal dysfunction after the repair of abdominal aortic aneurysm. Journal of Cardiovascular Pharmacology. 2003;42(5):636-41. Not CKD treatment. [pmid: 14576512].
1697 Hayashida N, Isomura T, Sato T, et al. Effects of minimal-dose aprotinin on coronary artery bypass grafting. Journal of Thoracic & Cardiovascular Surgery. 1997;114(2):261-9. Not CKD treatment. [pmid: 9270645].
1698 Hayashino Y, Fukuhara S, Akiba T, et al. Diabetes, glycaemic control and mortality risk in patients on haemodialysis: the Japan Dialysis Outcomes and Practice Pattern Study. Diabetologia. 2007;50(6):1170-7. Not relevant to key questions. [pmid: 17393134].
1699 Hayes C, Alam A, Black-Peart J, et al. Mitigating the cardiovascular risk of anemia in patients with type 2 diabetes and CKD: Does darbepoetin help? The TREAT Trial. Current Diabetes Reports. Apr. 2010;10(2):87-9. Not RCT or controlled trial. [pmid: 20425565].
1700 Hayes TG, Falchook GS, Varadhachary A. Phase IB trial of oral talactoferrin in the treatment of patients with metastatic solid tumors. Investigational New Drugs. Apr. 2010;28(2):156-62. Not CKD treatment. [pmid: 19238327].
1701 Haynes WG. Hyperhomocysteinemia, vascular function and atherosclerosis: effects of vitamins. Cardiovascular Drugs & Therapy. 2002;16(5):391-9. Not RCT or controlled trial. [pmid: 12652108].
1702 Haynes WG, Hand MF, Dockrell ME, et al. Physiological role of nitric oxide in regulation of renal function in humans. American Journal of Physiology. 1997;272(3 Pt 2):F364-71. Not RCT or controlled trial. [pmid: 9087680].
1703 He FJ, Marciniak M, Carney C, et al. Effects of potassium chloride and potassium bicarbonate on endothelial function, cardiovascular risk factors, and bone turnover in mild hypertensives. Hypertension. 2010;55(3):681-8. Follow-up less than 6 months. [pmid: 20083724].
1704 He J, Whelton PK. Elevated systolic blood pressure as a risk factor for cardiovascular and renal disease. Journal of Hypertension - Supplement. 1999;17(2):S7-13. Not RCT or controlled trial.
1705 Head JE, Bryant BJ, Grills BL, et al. Effects of short-term use of ibuprofen or acetaminophen on bone resorption in healthy men: a double-blind, placebo-controlled pilot study. Bone. 2001;29(5):437-41. Not early CKD. [pmid: 11704495].
1706 Heaney RP. Calcium intake and disease prevention. Arquivos Brasileiros de Endocrinologia e Metabologia. 2006;50(4):685-93. Not RCT or controlled trial. [pmid: 17117294].
1707 Hebert LA. Renoprotective therapy: how good can it get?. Kidney International. 2000;57(1):343-4. Not RCT or controlled trial. [pmid: 10620219].
1708 Hebert LA, Bain RP, Verme D, et al. Remission of nephrotic range proteinuria in type I diabetes. Collaborative Study Group. Kidney International. 1994;46(6):1688-93. Not relevant to key questions. [pmid: 7700028].
1709 Hebert LA, Birmingham DJ, Shidham G, et al. Random spot urine protein/creatinine ratio is unreliable for estimating 24-hour proteinuria in individual systemic lupus erythematosus nephritis patients. Nephron. 2009;113(3):c177-82. Not CKD treatment. [pmid: 19672116].
1710 Hebert LA, Kusek JW, Greene T, et al. Effects of blood pressure control on progressive renal disease in blacks and whites. Modification of Diet in Renal Disease Study Group. Hypertension. 1997;30(3 Pt 1):428-35. Not RCT or controlled trial. [pmid: 9314428].
1711 Hebert LA, Wilmer WA, Falkenhain ME, et al. Renoprotection: one or many therapies?. Kidney International. 2001;59(4):1211-26. Not relevant to key questions. [pmid: 11260381].
1712 Hebert MJ, Masse M, Vigneault N, et al. Soluble Fas is a marker of coronary artery disease in patients with end-stage renal disease. American Journal of Kidney Diseases. 2001;38(6):1271-6. Not early CKD. [pmid: 11728960].
1713 Heeg JE, de Jong PE, van der Hem GK, et al. Efficacy and variability of the antiproteinuric effect of ACE inhibition by lisinopril. Kidney International. 1989;36(2):272-9. Sample size less than 50 patients. [pmid: 2550696].
1714 Heeg JE, de Jong PE, van der Hem GK, et al. Angiotensin II does not acutely reverse the reduction of proteinuria by long-term ACE inhibition. Kidney International. 1991;40(4):734-41. Sample size less than 50 patients. [pmid: 1660550].
1715 Heeg JE, de Jong PE, Vriesendorp R, et al. Additive antiproteinuric effect of the NSAID indomethacin and the ACE inhibitor lisinopril. American Journal of Nephrology. Suppl 1. 1990;10:94-7. Sample size less than 50 patients. [pmid: 2175149].
1716 Heemskerk S, Masereeuw R, Moesker O, et al. Alkaline phosphatase treatment improves renal function in severe sepsis or septic shock patients. Critical Care Medicine. 2009;37(2):417-23. Not RCT or controlled trial. [pmid: 19114895].
1717 Heerspink HL, Greene T, Lewis JB, et al. Effects of sulodexide in patients with type 2 diabetes and persistent albuminuria. Nephrology Dialysis Transplantation. 2008;23(6):1946-54. Not RCT or controlled trial.
1718 Heinemann L, Janicke I, Bender R, et al. Effects of enalapril and nitrendipine on exercise albuminuria in normotensive type I diabetic patients with incipient nephropathy. Hormone & Metabolic Research. 1996;28(10):549-52. Follow-up less than 6 months. [pmid: 8934214].
1719 Heise D, Waeschle RM, Schlobohm J, et al. Utility of cystatin C for assessment of renal function after cardiac surgery. Nephron. 2009;112(2):c107-14. Not CKD treatment. [pmid: 19390210].
1720 Heise T, Magnusson K, Grobel B, et al. A cross-over evaluation of different methods and devices to measure blood pressure in type 1 diabetic patients with nephropathy. Blood Pressure Monitoring. 2000;5(3):175-80. Sample size less than 50 patients. [pmid: 10915231].
1721 Helaly MA, Sheashaa HA, Hatata ESZ, et al. Endothelial dysfunction in geriatric diabetic patients: the role of microalbuminuria in elderly type 2 diabetic patients? A randomized controlled study. International Urology & Nephrology. 2007;39(1):333-8. Follow-up less than 6 months. [pmid: 17031505].
1722 Helenglass G, Powles RL, McElwain TJ, et al. Melphalan and total body irradiation (TBI) versus cyclophosphamide and TBI as conditioning for allogeneic matched sibling bone marrow transplants for acute myeloblastic leukaemia in first remission. Bone Marrow Transplantation. 1988;3(1):21-9. Sample size less than 50 patients. [pmid: 3048467].
1723 Hemmelder MH, de Zeeuw D, de Jong PE. Antiproteinuric efficacy of verapamil in comparison to trandolapril in non-diabetic renal disease. Nephrology Dialysis Transplantation. 1999;14(1):98-104. Follow-up less than 6 months.
1724 Hemmelder MH, de Zeeuw D, Gansevoort RT, et al. Blood pressure reduction initiates the antiproteinuric effect of ACE inhibition. Kidney International. 1996;49(1):174-80. Sample size less than 50 patients. [pmid: 8770965].
1725 Hemmelgarn BR, Ghali WA, Quan H, et al. Poor long-term survival after coronary angiography in patients with renal insufficiency. American Journal of Kidney Diseases. 2001;37(1):64-72. Not RCT or controlled trial. [pmid: 11136169].
1726 Hemmelgarn BR, Manns BJ, Zhang J, et al. Association between multidisciplinary care and survival for elderly patients with chronic kidney disease. Journal of the American Society of Nephrology. 2007;18(3):993-9. Sample size less than 50 patients. [pmid: 17267742].
1727 Heng AE, Cellarier E, Aublet-Cuvelier B, et al. Is treatment with N-acetylcysteine to prevent contrast-induced nephropathy when using bicarbonate hydration out of date?. Clinical Nephrology. 2008;70(6):475-84. Not CKD treatment. [pmid: 19049703].
1728 Henrich WL. Optimal cardiovascular therapy for patients with ESRD over the next several years. Clinical Journal of The American Society of Nephrology: CJASN. Suppl 1. 2009;4:S106-9. Not RCT or controlled trial. [pmid: 19995991].
1729 Henry H 2nd, Nordan J, Tomlin EM. Comparison of butorphanol tartrate and meperidine in moderate to severe renal colic. Urology. 1987;29(3):339-45. Not CKD treatment. [pmid: 3548009].
1730 Henry HH 2nd. Urological applications of butorphanol tartrate: postoperative pain and renal colic. Acute Care. Suppl 1. 1988;12:22-30. Not RCT or controlled trial. [pmid: 3344597].
1731 Herbert MK, Ginzel S, Muhlschlegel S, et al. Concomitant treatment with urodilatin (ularitide) does not improve renal function in patients with acute renal failure after major abdominal surgery--a randomized controlled trial. Wiener Klinische Wochenschrift. 1999;111(4):141-7. Sample size less than 50 patients. [pmid: 10192146].
1732 Hering R, Wrigge H, Vorwerk R, et al. The effects of prone positioning on intraabdominal pressure and cardiovascular and renal function in patients with acute lung injury. Anesthesia & Analgesia. 2001;92(5):1226-31. Not early CKD. [pmid: 11323351].
1733 Herlitz H, Harris K, Risler T, et al. The effects of an ACE inhibitor and a calcium antagonist on the progression of renal disease: the Nephros Study. Nephrology Dialysis Transplantation. 2001;16(11):2158-65. Not early CKD.
1734 Herman WH, Shahinfar S, Carides GW, et al. Losartan reduces the costs associated with diabetic end-stage renal disease: the RENAAL study economic evaluation. Diabetes Care. 2003;26(3):683-7. Not CKD treatment. [pmid: 12610022].
1735 Hermans MP, Brichard SM, Colin I, et al. Long-term reduction of microalbuminuria after 3 years of angiotensin-converting enzyme inhibition by perindopril in hypertensive insulin-treated diabetic patients. American Journal of Medicine. 1992;92(4B):102S-7S. Sample size less than 50 patients. [pmid: 1580274].
1736 Hernandez C, Rodriguez B, Losada E, et al. Normoalbuminuric type 1 diabetic patients with retinopathy have an impaired tubular response to desmopressin: its relationship with plasma endothelin-1. Journal of Clinical Endocrinology & Metabolism. 2009;94(6):2060-5. Not RCT or controlled trial. [pmid: 19293263].
1737 Hernberg M. Lymphocyte subsets as prognostic markers for cancer patients receiving immunomodulative therapy. Medical Oncology. 1999;16(3):145-53. Not CKD treatment. [pmid: 10523794].
1738 Herselman MG, Albertse EC, Lombard CJ, et al. Supplemented low-protein diets--are they superior in chronic renal failure?. South African Medical Journal. Suid-Afrikaanse Tydskrif Vir Geneeskunde. 1995;85(5):361-5. Sample size less than 50 patients. [pmid: 7638685].
1739 Herzog S, Cunze T, Martin M, et al. Pulsatile vs. continuous parenteral tocolysis: comparison of side effects. European Journal of Obstetrics, Gynecology, & Reproductive Biology. 1999;85(2):199-204. Not CKD treatment.
1740 Hesselvik F, Brodin B, Carlsson C, et al. Cryoprecipitate infusion fails to improve organ function in septic shock. Critical Care Medicine. 1987;15(5):475-83. Sample size less than 50 patients. [pmid: 3552444].
1741 Hetherington JW, Philp NH. Diclofenac sodium versus pethidine in acute renal colic. British Medical Journal Clinical Research Ed. 1986;292(6515):237-8. Not CKD treatment. [pmid: 3081085].
1742 Heydendael VMR, Spuls PI, Ten Berge IJM, et al. Cyclosporin trough levels: is monitoring necessary during short-term treatment in psoriasis? A systematic review and clinical data on trough levels. British Journal of Dermatology. 2002;147(1):122-9. Not CKD treatment. [pmid: 12100194].
1743 Hiemstra TF, Walsh M, Mahr A, et al. Mycophenolate mofetil vs azathioprine for remission maintenance in antineutrophil cytoplasmic antibody-associated vasculitis: a randomized controlled trial. JAMA. Dec. 1. 2010;304(21):2381-8. Not CKD treatment. [pmid: 21060104].
1744 Higashi Y, Oshima T, Ono N, et al. Intravenous administration of L-arginine inhibits angiotensin-converting enzyme in humans. Journal of Clinical Endocrinology & Metabolism. 1995;80(7):2198-202. Sample size less than 50 patients. [pmid: 7608279].
1745 Higashi Y, Oshima T, Sasaki S, et al. Angiotensin-converting enzyme inhibition, but not calcium antagonism, improves a response of the renal vasculature to L-arginine in patients with essential hypertension. Hypertension. 1998;32(1):16-24. Sample size less than 50 patients. [pmid: 9674632].
1746 Higuchi H, Arimura S, Sumikura H, et al. Urine concentrating ability after prolonged sevoflurane anaesthesia. British Journal of Anaesthesia. 1994;73(2):239-40. Sample size less than 50 patients. [pmid: 7917743].
1747 Higuchi H, Wada H, Usui Y, et al. Effects of probenecid on renal function in surgical patients anesthetized with low-flow sevoflurane. Anesthesiology. 2001;94(1):21-31. Not early CKD. [pmid: 11135718].
1748 Hill AJ, Feneck RO, Walesby RK. A comparison of fenoldopam and nitroprusside in the control of hypertension following coronary artery surgery. Journal of Cardiothoracic & Vascular Anesthesia. 1993;7(3):279-84. Sample size less than 50 patients. [pmid: 8100152].
1749 Hillege HL, Girbes AR, de Kam PJ, et al. Renal function, neurohormonal activation, and survival in patients with chronic heart failure. Circulation. 2000;102(2):203-10. Not early CKD. [pmid: 10889132].
1750 Hillege HL, van Gilst WH, van Veldhuisen DJ, et al. Accelerated decline and prognostic impact of renal function after myocardial infarction and the benefits of ACE inhibition: the CATS randomized trial. European Heart Journal. 2003;24(5):412-20. Not early CKD. [pmid: 12633543].
1751 Hilleman DE. Role of angiotensin-converting-enzyme inhibitors in the treatment of hypertension. American Journal of Health-System Pharmacy. Suppl 1. 2000;57:S8-11. Not RCT or controlled trial. [pmid: 11030017].
1752 Hillmen P, Elebute M, Kelly R, et al. Long-term effect of the complement inhibitor eculizumab on kidney function in patients with paroxysmal nocturnal hemoglobinuria. [Erratum appears in Am J Hematol. 2010 Nov; 85(11):911]. American Journal of Hematology. Aug. 2010;85(8):553-9. Not CKD treatment. [pmid: 20658586].
1753 Hillock RJ, Frampton CM, Yandle TG, et al. B-type natriuretic peptide infusions in acute myocardial infarction. Heart. 2008;94(5):617-22. Not early CKD. [pmid: 17639095].
1754 Hilmi IA, Peng Z, Planinsic RM, et al. N-acetylcysteine does not prevent hepatorenal ischaemia-reperfusion injury in patients undergoing orthotopic liver transplantation. Nephrology Dialysis Transplantation. Jul. 2010;25(7):2328-33. Not CKD treatment.
1755 Himmelfarb J, Hakim RM. Oxidative stress in uremia. Current Opinion in Nephrology & Hypertension. 2003;12(6):593-8. Not CKD treatment. [pmid: 14564195].
1756 Himmelmann A, Hansson L, Hansson BG, et al. ACE inhibition preserves renal function better than beta-blockade in the treatment of essential hypertension. Blood Pressure. 1995;4(2):85-90. Not CKD treatment. [pmid: 7599759].
1757 Himmelmann A, Hansson L, Hansson BG, et al. Long-term renal preservation in essential hypertension. Angiotensin converting enzyme inhibition is superior to beta-blockade. American Journal of Hypertension. 1996;9(9):850-3. Not relevant to key questions. [pmid: 8879340].
1758 Hirakata H, Tsubakihara Y, Gejyo F, et al. Maintaining high hemoglobin levels improved the left ventricular mass index and quality of life scores in pre-dialysis Japanese chronic kidney disease patients. Clinical & Experimental Nephrology. Feb. 2010;14(1):28-35. Not CKD treatment. [pmid: 19763743].
1759 Hirosawa A, Niitani H, Hayashibara K, et al. Effects of sodium thiosulfate in combination therapy of cis-dichlorodiammineplatinum and vindesine. Cancer Chemotherapy & Pharmacology. 1989;23(4):255-8. Not CKD treatment. [pmid: 2538252].
1760 Hirschberg R. Biologically active peptides in acute renal failure: recent clinical trials. Nephrology Dialysis Transplantation. 1997;12(8):1563-6. Not RCT or controlled trial.
1761 Hirschberg R, Brunori G, Kopple JD, et al. Effects of insulin-like growth factor I on renal function in normal men. Kidney International. 1993;43(2):387-97. Not adult population. [pmid: 8441234].
1762 Hirschberg R, Kopple JD. Role of growth hormone in the amino acid-induced acute rise in renal function in man. Kidney International. 1987;32(3):382-7. Sample size less than 50 patients. [pmid: 3669497].
1763 Hirschberg RR, Zipser RD, Slomowitz LA, et al. Glucagon and prostaglandins are mediators of amino acid-induced rise in renal hemodynamics. Kidney International. 1988;33(6):1147-55. Sample size less than 50 patients. [pmid: 3404814].
1764 Hjorth M, Holmberg E, Rodjer S, et al. Impact of active and passive exclusions on the results of a clinical trial in multiple myeloma. The Myeloma Group of Western Sweden. British Journal of Haematology. 1992;80(1):55-61. Not CKD treatment. [pmid: 1536810].
1765 Hladunewich MA, Derby GC, Lafayette RA, et al. Effect of L-arginine therapy on the glomerular injury of preeclampsia: a randomized controlled trial. Obstetrics & Gynecology. 2006;107(4):886-95. Sample size less than 50 patients. [pmid: 16582128].
1766 Hlatky MA. Underuse of evidence-based therapies. Circulation. 2004;110(6):644-5. Not CKD treatment. [pmid: 15302805].
1767 Ho Jd, Liou SW, Lin HC. Retinal vein occlusion and the risk of stroke development: a five-year follow-up study. American Journal of Ophthalmology. 2009;147(2):283-90.e2. Follow-up less than 6 months. [pmid: 18835470].
1768 Ho KM, Morgan DJ. Use of isotonic sodium bicarbonate to prevent radiocontrast nephropathy in patients with mild pre-existing renal impairment: a meta-analysis. Anaesthesia & Intensive Care. 2008;36(5):646-53. Sample size less than 50 patients. [pmid: 18853581].
1769 Ho KM, Morgan DJR. Meta-analysis of N-acetylcysteine to prevent acute renal failure after major surgery. American Journal of Kidney Diseases. 2009;53(1):33-40. Not early CKD. [pmid: 18649982].
1770 Ho KM, Power BM. Benefits and risks of furosemide in acute kidney injury. Anaesthesia. Mar. 2010;65(3):283-93. Not CKD treatment. [pmid: 20085566].
1771 Ho KM, Sheridan DJ. Meta-analysis of frusemide to prevent or treat acute renal failure. BMJ. 2006;333:7565-420. Not relevant to key questions.
1772 Hobbs H, Stevens P, Klebe B, et al. Referral patterns to renal services: what has changed in the past 4 years?. Nephrology Dialysis Transplantation. 2009;24(11):3411-9. Not RCT or controlled trial.
1773 Hochman JS, Shah NR. What price pain relief?. [Erratum appears in Circulation. 2006 Aug 22; 114(8):e364]. Circulation. 2006;113(25):2868-70. Not RCT or controlled trial. [pmid: 16785335].
1774 Hodge EE, Reich DJ, Clavien PA, et al. Use of mycophenolate mofetil in liver transplant recipients experiencing renal dysfunction on cyclosporine or tacrolimus-randomized, prospective, multicenter study results. Transplantation Proceedings. 2002;34(5):1546-7. Sample size less than 50 patients. [pmid: 12176477].
1775 Hoek FJ, Korevaar JC, Dekker FW, et al. Estimation of residual glomerular filtration rate in dialysis patients from the plasma cystatin C level. Nephrology Dialysis Transplantation. 2007;22(6):1633-8. Follow-up less than 6 months.
1776 Hoffer LJ, Saboohi F, Golden M, et al. Cobalamin dose regimen for maximum homocysteine reduction in end-stage renal disease. Metabolism: Clinical & Experimental. 2005;54(6):835-40. Not RCT or controlled trial. [pmid: 15931623].
1777 Hoffler D, Koeppe P. Temocillin pharmacokinetics in normal and impaired renal function. Drugs. Suppl 5. 1985;29:135-9. Sample size less than 50 patients. [pmid: 4029017].
1778 Hogan SE, L'Allier P, Chetcuti S, et al. Current role of sodium bicarbonate-based preprocedural hydration for the prevention of contrast-induced acute kidney injury: a meta-analysis. American Heart Journal. 2008;156(3):414-21. Not CKD treatment. [pmid: 18760120].
1779 Hoieggen A, Alderman MH, Kjeldsen SE, et al. The impact of serum uric acid on cardiovascular outcomes in the LIFE study. Kidney International. 2004;65(3):1041-9. Not early CKD. [pmid: 14871425].
1780 Hojs R, Bevc S, Ekart R, et al. Serum cystatin C-based equation compared to serum creatinine-based equations for estimation of glomerular filtration rate in patients with chronic kidney disease. Clinical Nephrology. 2008;70(1):10-7. Sample size less than 50 patients. [pmid: 18793543].
1781 Holdaas H, Hartmann A, Berg KJ, et al. Contrasting effects of angiotensin converting inhibitor and alpha-1-antagonist on albuminuria in insulin-dependent diabetes mellitus patients with nephropathy. Journal of Internal Medicine. 1995;237(1):63-71. Sample size less than 50 patients. [pmid: 7830033].
1782 Holdaas H, Hartmann A, Berg KJ, et al. Renal effects of losartan and amlodipine in hypertensive patients with non-diabetic nephropathy. Nephrology Dialysis Transplantation. 1998;13(12):3096-102. Follow-up less than 6 months.
1783 Holdaas H, Hartmann A, Lien MG, et al. Contrasting effects of lisinopril and nifedipine on albuminuria and tubular transport functions in insulin dependent diabetics with nephropathy. Journal of Internal Medicine. 1991;229(2):163-70. Sample size less than 50 patients. [pmid: 1847721].
1784 Holdaas H, Wanner C, Abletshauser C, et al. The renal safety profile of fluvastatin: results of a pooled analysis. Renal Failure. 2006;28(6):487-92. Not relevant to key questions. [pmid: 16928618].
1785 Holdgate A, Oh CM. Is there a role for antimuscarinics in renal colic? A randomized controlled trial. Journal of Urology. 2005;174(2):572-5. discussion 5. Sample size less than 50 patients. [pmid: 16006900].
1786 Holdgate A, Pollock T. Systematic review of the relative efficacy of non-steroidal anti-inflammatory drugs and opioids in the treatment of acute renal colic. BMJ. 2004;328(7453):1401. Not CKD treatment. [pmid: 15178585].
1787 Holdgate A, Pollock T. Nonsteroidal anti-inflammatory drugs (NSAIDs) versus opioids for acute renal colic. Cochrane Database of Systematic Reviews. 2004;(1):CD004137. Not RCT or controlled trial. [pmid: 14974058].
1788 Holdgate A, Pollock T. Nonsteroidal anti-inflammatory drugs (NSAIDs) versus opioids for acute renal colic. Cochrane Database of Systematic Reviews. 2005;(2):CD004137. Follow-up less than 6 months. [pmid: 15846699].
1789 Holl MG, Allen LH. Comparative effects of meals high in protein, sucrose, or starch on human mineral metabolism and insulin secretion. American Journal of Clinical Nutrition. 1988;48(5):1219-25. Sample size less than 50 patients. [pmid: 3055929].
1790 Hollenberg NK. Non-insulin-dependent diabetes mellitus, nephropathy, and the renin system. Journal of Hypertension - Supplement. 1997;15(7):S7-13. Not RCT or controlled trial.
1791 Hollenberg NK, Parving HH, Viberti G, et al. Albuminuria response to very high-dose valsartan in type 2 diabetes mellitus. Journal of Hypertension. 2007;25(9):1921-6. Not relevant to key questions. [pmid: 17762658].
1792 Holmberg B, Brannstrom M, Bucht B, et al. Safety and efficacy of atorvastatin in patients with severe renal dysfunction. Scandinavian Journal of Urology & Nephrology. 2005;39(6):503-10. Sample size less than 50 patients. [pmid: 16303728].
1793 Holme I, Fayyad R, Faergeman O, et al. Cardiovascular outcomes and their relationships to lipoprotein components in patients with and without chronic kidney disease: results from the IDEAL trial. Journal of Internal Medicine. Jun. 2010;267(6):567-75. Not RCT or controlled trial. [pmid: 20141566].
1794 Holmes CL, Walley KR. Bad medicine: low-dose dopamine in the ICU. Chest. 2003;123(4):1266-75. Not CKD treatment. [pmid: 12684320].
1795 Holmes DI, Abdel Wahab N, Mason RM. Identification of glucose-regulated genes in human mesangial cells by mRNA differential display. Biochemical & Biophysical Research Communications. 1997;238(1):179-84. Not RCT or controlled trial. [pmid: 9299475].
1796 Holmes SJ, Espiner EA, Richards AM, et al. Renal, endocrine, and hemodynamic effects of human brain natriuretic peptide in normal man. Journal of Clinical Endocrinology & Metabolism. 1993;76(1):91-6. Not CKD treatment. [pmid: 8380606].
1797 Homma K, Hayashi K, Kanda T, et al. Beneficial action of candesartan cilexetil plus amlodipine or ACE inhibitors in chronic nondiabetic renal disease. Journal of Human Hypertension. 2004;18(12):879-84. Sample size less than 50 patients. [pmid: 15295613].
1798 Hommel E, Andersen P, Gall MA, et al. Plasma lipoproteins and renal function during simvastatin treatment in diabetic nephropathy. Diabetologia. 1992;35(5):447-51. Sample size less than 50 patients. [pmid: 1521727].
1799 Hommel E, Mathiesen E, Arnold-Larsen S, et al. Effects of indomethacin on kidney function in type 1 (insulin-dependent) diabetic patients with nephropathy. Diabetologia. 1987;30(2):78-81. Sample size less than 50 patients. [pmid: 3471610].
1800 Hommel E, Mathiesen E, Edsberg B, et al. Acute reduction of arterial blood pressure reduces urinary albumin excretion in type 1 (insulin-dependent) diabetic patients with incipient nephropathy. Diabetologia. 1986;29(4):211-5. Sample size less than 50 patients. [pmid: 3710012].
1801 Hommel E, Parving HH, Mathiesen E, et al. Effect of captopril on kidney function in insulin-dependent diabetic patients with nephropathy. British Medical Journal Clinical Research Ed. 1986;293(6545):467-70. Sample size less than 50 patients. [pmid: 3091164].
1802 Hon G, Vaziri ND, Kaupke CJ, et al. Lack of a fast-acting effect of erythropoietin on arterial blood pressure and endothelin level. Artificial Organs. 1995;19(2):188-91. Sample size less than 50 patients. [pmid: 7763199].
1803 Honing ML, Hijmering ML, Ballard DE, et al. Selective ET(A) receptor antagonism with ABT-627 attenuates all renal effects of endothelin in humans. Journal of the American Society of Nephrology. 2000;11(8):1498-504. Not early CKD. [pmid: 10906163].
1804 Honore PM, Joannes-Boyau O, Boer W, et al. Acute kidney injury in the ICU: time has come for an early biomarker kit!. Acta Clinica Belgica - Supplementum. 2007;(2):318-21. Not CKD treatment. [pmid: 18283991].
1805 Hoogenberg K, Sluiter WJ, Navis G, et al. Exogenous norepinephrine induces an enhanced microproteinuric response in microalbuminuric insulin-dependent diabetes mellitus. Journal of the American Society of Nephrology. 1998;9(4):643-54. Sample size less than 50 patients. [pmid: 9555667].
1806 Hoogenberg K, Smit AJ, Girbes AR. Effects of low-dose dopamine on renal and systemic hemodynamics during incremental norepinephrine infusion in healthy volunteers. Critical Care Medicine. 1998;26(2):260-5. Not CKD treatment. [pmid: 9468162].
1807 Hoogeveen EK, Kostense PJ, Jager A, et al. Serum homocysteine level and protein intake are related to risk of microalbuminuria: the Hoorn Study. Kidney International. 1998;54(1):203-9. Not RCT or controlled trial. [pmid: 9648080].
1808 Hoogkamer JF, Kleinbloesem CH, Nokhodian A, et al. Pharmacokinetics of imidapril and its active metabolite imidaprilat following single dose and during steady state in patients with chronic renal failure. European Journal of Clinical Pharmacology. 1998;54(1):59-61. Sample size less than 50 patients. [pmid: 9591932].
1809 Hoogwerf BJ, Young JB. The HOPE study. Ramipril lowered cardiovascular risk, but vitamin E did not. Cleveland Clinic Journal of Medicine. 2000;67(4):287-93. Not early CKD. [pmid: 10780101].
1810 Hooper AH, Tindall H, Barker MJ, et al. Renal scintigraphy and survival of indium-111-labelled platelets in patients with diabetic nephropathy. Nuclear Medicine Communications. 1986;7(5):349-54. Sample size less than 50 patients. [pmid: 3737031].
1811 Hoos A, Levey DL. Vaccination with heat shock protein-peptide complexes: from basic science to clinical applications. Expert Review of Vaccines. 2003;2(3):369-79. Not CKD treatment. [pmid: 12903802].
1812 Hopper AH, Tindall H, Davies JA. Administration of aspirin-dipyridamole reduces proteinuria in diabetic nephropathy. Nephrology Dialysis Transplantation. 1989;4(2):140-3. Sample size less than 50 patients.
1813 Hopper AH, Tindall H, Urquhart S, et al. Reduction of exercise-induced albuminuria by aspirin-dipyridamole in patients with diabetes mellitus. Hormone & Metabolic Research. 1987;19(5):201-3. Sample size less than 50 patients. [pmid: 3583229].
1814 Hoque R, Rahman MS, Iqbal M. Effect of enalapril and losartan on proteinuria in type 2 diabetic nephropathy patients. Bangladesh Medical Research Council Bulletin. 2009;35(2):44-8. Sample size less than 50 patients. [pmid: 20120778].
1815 Horita Y, Hayashida K, Fukuchi K, et al. Acetazolamide assisted Tc-99m MAG3 renography to assess renal blood flow reserve. Annals of Nuclear Medicine. 2003;17(2):139-44. Not CKD treatment. [pmid: 12790363].
1816 Horl WH. A need for an individualized approach to end-stage renal disease patients. Nephrology Dialysis Transplantation. Suppl 6. 2002;17:17-21. Not early CKD.
1817 Horl WH. Anemia: What can we learn from a secondary analysis of CHOIR?. Nature Reviews Nephrology. May. 2010;6(5):251-2. Not RCT or controlled trial.
1818 Horl WH, Steinhauer HB, Riegel W, et al. Effect of different dialyzer membranes on plasma levels of granulocyte elastase. Kidney International - Supplement. 1988;24:S90-1. Sample size less than 50 patients. [pmid: 3163062].
1819 Hornberger J, Wrone E. When to base clinical policies on observational versus randomized trial data. Annals of Internal Medicine. 1997;127(8 Pt 2):697-703. Not RCT or controlled trial. [pmid: 9382383].
1820 Hornberger JC, Garber AM, Jeffery JR. Mortality, hospital admissions, and medical costs of end-stage renal disease in the United States and Manitoba, Canada. Medical Care. 1997;35(7):686-700. Not early CKD. [pmid: 9219496].
1821 Hoste EAJ, De Waele JJ, Gevaert SA, et al. Sodium bicarbonate for prevention of contrast-induced acute kidney injury: a systematic review and meta-analysis. Nephrology Dialysis Transplantation. Mar. 2010;25(3):747-58. Not CKD treatment.
1822 Hotu C, Bagg W, Collins J, et al. A community-based model of care improves blood pressure control and delays progression of proteinuria, left ventricular hypertrophy and diastolic dysfunction in Maori and Pacific patients with type 2 diabetes and chronic kidney disease: a randomized controlled trial. Nephrology Dialysis Transplantation. Oct. 2010;25(10):3260-6. Not relevant to key questions.
1823 Hou FF, Xie D, Zhang X, et al. Renoprotection of Optimal Antiproteinuric Doses (ROAD) Study: a randomized controlled study of benazepril and losartan in chronic renal insufficiency. Journal of the American Society of Nephrology. 2007;18(6):1889-98. Follow-up less than 6 months. [pmid: 17494885].
1824 Hou FF, Zhang X, Zhang GH, et al. Efficacy and safety of benazepril for advanced chronic renal insufficiency. New England Journal of Medicine. 2006;354(2):131-40. Not RCT or controlled trial. [pmid: 16407508].
1825 Houben AJ, Krekels MM, Schaper NC, et al. Microvascular effects of atrial natriuretic peptide (ANP) in man: studies during high and low salt diet. Cardiovascular Research. 1998;39(2):442-50. Sample size less than 50 patients. [pmid: 9798529].
1826 House AA, Eliasziw M, Cattran DC, et al. Effect of B-vitamin therapy on progression of diabetic nephropathy: a randomized controlled trial. JAMA. Apr. 28. 2010;303(16):1603-9. Not CKD treatment. [pmid: 20424250].
1827 Hovind P, Tarnow L, Parving HH. Remission and regression of diabetic nephropathy. Current Hypertension Reports. 2004;6(5):377-82. Not CKD treatment. [pmid: 15341691].
1828 Howard K, White S, Salkeld G, et al. Cost-effectiveness of screening and optimal management for diabetes, hypertension, and chronic kidney disease: a modeled analysis. Value in Health. Mar-Apr. 2010;13(2):196-208. Not relevant to key questions. [pmid: 19878493].
1829 Hoy W, McDonald SP. Albuminuria: marker or target in indigenous populations. Kidney International - Supplement. 2004;(92):S25-31. Not CKD treatment. [pmid: 15485412].
1830 Hoy WE, Wang Z, Baker PRA, et al. Reduction in natural death and renal failure from a systematic screening and treatment program in an Australian Aboriginal community. Kidney International - Supplement. 2003;(83):S66-73. Not RCT or controlled trial. [pmid: 12864878].
1831 Hoy WE, Wang Z, Baker PRA, et al. Secondary prevention of renal and cardiovascular disease: results of a renal and cardiovascular treatment program in an Australian aboriginal community. Journal of the American Society of Nephrology. 2003;14(7 Suppl 2):S178-85. Not RCT or controlled trial. [pmid: 12819325].
1832 Hoy WE, Wang Z, VanBuynder P, et al. The natural history of renal disease in Australian Aborigines. Part 1. Changes in albuminuria and glomerular filtration rate over time. Kidney International. 2001;60(1):243-8. Not RCT or controlled trial. [pmid: 11422757].
1833 Hricik DE, Levine BS, Adrogue HJ, et al. Evaluation of enalapril/diltiazem ER in hypertensive patients with coexisting renal dysfunction. Enalapril/Diltiazem ER in Hypertensive Renal Disease Group. Journal of Human Hypertension. 1996;10(11):769-74. Follow-up less than 6 months. [pmid: 9004108].
1834 Hsia HC, Lin HC, Tsai YT, et al. The effects of chronic administration of indomethacin and misoprostol on renal function in cirrhotic patients with and without ascites. Scandinavian Journal of Gastroenterology. 1995;30(12):1194-9. Sample size less than 50 patients. [pmid: 9053973].
1835 Hsu CY. Does treatment of non-malignant hypertension reduce the incidence of renal dysfunction? A meta-analysis of 10 randomised, controlled trials. Journal of Human Hypertension. 2001;15(2):99-106. Not relevant to key questions. [pmid: 11317188].
1836 Hu YJ, Chen Y, Zhang YQ, et al. The protective role of selenium on the toxicity of cisplatin-contained chemotherapy regimen in cancer patients. Biological Trace Element Research. 1997;56(3):331-41. Sample size less than 50 patients. [pmid: 9197929].
1837 Hu YY, Ye SD, Zhao LL, et al. Hydrochloride pioglitazone decreases urinary TGF-beta1 excretion in type 2 diabetics. European Journal of Clinical Investigation. Jul. 2010;40(7):571-4. Not CKD treatment. [pmid: 20482594].
1838 Huang M, Yu J, Hu W. Effect of yitangning granule on glycometabolism and urinary micro albumin of diabetes B patients. Journal of Traditional Chinese Medicine. 2004;24(4):270-3. Follow-up less than 6 months. [pmid: 15688693].
1839 Huber W, Eckel F, Hennig M, et al. Prophylaxis of contrast material-induced nephropathy in patients in intensive care: acetylcysteine, theophylline, or both? A randomized study. Radiology. 2006;239(3):793-804. Sample size less than 50 patients. [pmid: 16714461].
1840 Huber W, Ilgmann K, Page M, et al. Effect of theophylline on contrast material-nephropathy in patients with chronic renal insufficiency: controlled, randomized, double-blinded study. Radiology. 2002;223(3):772-9. Not early CKD. [pmid: 12034949].
1841 Huber W, Schipek C, Ilgmann K, et al. Effectiveness of theophylline prophylaxis of renal impairment after coronary angiography in patients with chronic renal insufficiency. American Journal of Cardiology. 2003;91(10):1157-62. Not CKD treatment. [pmid: 12745095].
1842 Huggins JT, Sahn SA. Causes and management of pleural fibrosis. Respirology. 2004;9(4):441-7. Not RCT or controlled trial. [pmid: 15612954].
1843 Huitema AD, Mathot RA, Tibben MM, et al. Validation of techniques for the prediction of carboplatin exposure: application of Bayesian methods. Clinical Pharmacology & Therapeutics. 2000;67(6):621-30. Not RCT or controlled trial. [pmid: 10872644].
1844 Huledal G, Jonzon B, Malmenas M, et al. Renal effects of the cyclooxygenase-inhibiting nitric oxide donator AZD3582 compared with rofecoxib and naproxen during normal and low sodium intake. Clinical Pharmacology & Therapeutics. 2005;77(5):437-50. Not CKD treatment. [pmid: 15900289].
1845 Humphrey LL, Ballard DJ. Renal complications in non-insulin-dependent diabetes mellitus. Clinics in Geriatric Medicine. 1990;6(4):807-25. Not relevant to key questions. [pmid: 2224748].
1846 Humphreys MR, Lingeman JE, Terry C, et al. Renal injury and the application of polysaccharide hemospheres: a laparoscopic experimental model. Journal of Endourology. 2008;22(6):1375-81. Not CKD treatment. [pmid: 18578666].
1847 Hunsicker LG. Emerging trends for prevention and treatment of diabetic nephropathy: blockade of the RAAS and BP control. Journal of Managed Care Pharmacy. 2004;10(5 Suppl A):S12-7. Not RCT or controlled trial. [pmid: 15369420].
1848 Hunsicker LG, Adler S, Caggiula A, et al. Predictors of the progression of renal disease in the Modification of Diet in Renal Disease Study. Kidney International. 1997;51(6):1908-19. Not RCT or controlled trial. [pmid: 9186882].
1849 Hunter DW, Chamsuddin A, Bjarnason H, et al. Preventing contrast-induced nephropathy with fenoldopam. Techniques in Vascular & Interventional Radiology. 2001;4(1):53-6. Not early CKD. [pmid: 11981789].
1850 Huntress JD, Papadakos PJ. The role of calcium-channel antagonists in solid organ transplantation. New Horizons. 1996;4(1):129-33. Not RCT or controlled trial. [pmid: 8689268].
1851 Hurst M, Jarvis B. Perindopril: an updated review of its use in hypertension. Drugs. 2001;61(6):867-96. Not RCT or controlled trial. [pmid: 11398915].
1852 Hussain SA, Moffitt DD, Glaholm JG, et al. A phase I-II study of synchronous chemoradiotherapy for poor prognosis locally advanced bladder cancer. Annals of Oncology. 2001;12(7):929-35. Not early CKD. [pmid: 11521797].
1853 Hussain SA, Stocken DD, Riley P, et al. A phase I/II study of gemcitabine and fractionated cisplatin in an outpatient setting using a 21-day schedule in patients with advanced and metastatic bladder cancer. British Journal of Cancer. 2004;91(5):844-9. Not relevant to key questions. [pmid: 15292922].
1854 Huxtable L, Raney CRK, Khera GS. Should intravenous N-acetylcysteine be considered standard of care for prevention of radio-contrast-induced nephropathy?. Journal of the American College of Cardiology. 2003;42(12):2169. author reply -70. Not relevant to key questions. [pmid: 14680748].
1855 Huybregts RAJM, Morariu AM, Rakhorst G, et al. Attenuated renal and intestinal injury after use of a mini-cardiopulmonary bypass system. Annals of Thoracic Surgery. 2007;83(5):1760-6. Not CKD treatment. [pmid: 17462395].
1856 Huyen VTT, Phan DV, Thang P, et al. Antidiabetic effect of Gynostemma pentaphyllum tea in randomly assigned type 2 diabetic patients. Hormone & Metabolic Research. May. 2010;42(5):353-7. Not CKD treatment. [pmid: 20213586].
1857 Hwang WYK, Koh LP, Ng HJ, et al. A randomized trial of amifostine as a cytoprotectant for patients receiving myeloablative therapy for allogeneic hematopoietic stem cell transplantation. Bone Marrow Transplantation. 2004;34(1):51-6. Not CKD treatment. [pmid: 15208650].
1858 Hyndman ME, Manns BJ, Snyder FF, et al. Vitamin B12 decreases, but does not normalize, homocysteine and methylmalonic acid in end-stage renal disease: a link with glycine metabolism and possible explanation of hyperhomocysteinemia in end-stage renal disease. Metabolism: Clinical & Experimental. 2003;52(2):168-72. Not early CKD. [pmid: 12601627].
1859 Hynes DM, Stroupe KT, Greer JW, et al. Potential cost savings of erythropoietin administration in end-stage renal disease. American Journal of Medicine. 2002;112(3):169-75. Not RCT or controlled trial. [pmid: 11893342].
1860 Hynninen MS, Niemi TT, Poyhia R, et al. N-acetylcysteine for the prevention of kidney injury in abdominal aortic surgery: a randomized, double-blind, placebo-controlled trial. Anesthesia & Analgesia. 2006;102(6):1638-45. Not relevant to key questions. [pmid: 16717300].
1861 Hynynen M, Palojoki R, Heinonen J, et al. Renal and vascular effects of atrial natriuretic factor during cardiopulmonary bypass. Chest. 1991;100(5):1203-9. Not CKD treatment. [pmid: 1834440].
1862 Ibbotson T, Goa KL. Darbepoetin alfa. Drugs. 2001;61(14):2097-104. discussion 105-6. Not RCT or controlled trial. [pmid: 11735636].
1863 Ibrahim A, Scher N, Williams G, et al. Approval summary for zoledronic acid for treatment of multiple myeloma and cancer bone metastases. Clinical Cancer Research. 2003;9(7):2394-9. Not CKD treatment. [pmid: 12855610].
1864 Ibrahim H, Mondress M, Tello A, et al. An alternative formula to the Cockcroft-Gault and the modification of diet in renal diseases formulas in predicting GFR in individuals with type 1 diabetes. Journal of the American Society of Nephrology. 2005;16(4):1051-60. Not relevant to key questions. [pmid: 15716336].
1865 Ibrahim HN, Rogers T, Tello A, et al. The performance of three serum creatinine-based formulas in estimating GFR in former kidney donors. American Journal of Transplantation. 2006;6(6):1479-85. Not CKD treatment. [pmid: 16686774].
1866 Ibrahim S, Derde MP, Kaufman L, et al. Safety, pharmacokinetics and efficacy of once-a-day netilmicin and amikacin versus their conventional schedules in patients suffering from pelvic inflammatory disease. Renal Failure. 1990;12(3):199-203. Not CKD treatment. [pmid: 2287773].
1867 Ichai C, Passeron C, Carles M, et al. Prolonged low-dose dopamine infusion induces a transient improvement in renal function in hemodynamically stable, critically ill patients: a single-blind, prospective, controlled study. Critical Care Medicine. 2000;28(5):1329-35. Sample size less than 50 patients. [pmid: 10834674].
1868 Ichai C, Soubielle J, Carles M, et al. Comparison of the renal effects of low to high doses of dopamine and dobutamine in critically ill patients: a single-blind randomized study. Critical Care Medicine. 2000;28(4):921-8. Not early CKD. [pmid: 10809260].
1869 Ichihara A, Kaneshiro Y, Sakoda M, et al. Add-on amlodipine improves arterial function and structure in hypertensive patients treated with an angiotensin receptor blocker. Journal of Cardiovascular Pharmacology. 2007;49(3):161-6. Follow-up less than 6 months. [pmid: 17414228].
1870 Ichihara A, Kaneshiro Y, Takemitsu T, et al. Benefits of candesartan on arterial and renal damage of non-diabetic hypertensive patients treated with calcium channel blockers. American Journal of Nephrology. 2006;26(5):462-8. Follow-up less than 6 months. [pmid: 17063001].
1871 Ifudu O, Dawood M, Homel P. Erythropoietin-induced elevation in blood pressure is immediate and dose dependent. Nephron. 1998;79(4):486-7. Not RCT or controlled trial. [pmid: 9689173].
1872 Ifudu O, Homel P. Effect of serum parathyroid hormone and aluminum levels on the response to erythropoietin in uremia. Nephron. 1998;79(4):477-8. Not RCT or controlled trial. [pmid: 9689168].
1873 Igarashi M, Hirata A, Kadomoto Y, et al. Dual blockade of angiotensin II with enalapril and losartan reduces proteinuria in hypertensive patients with type 2 diabetes. Endocrine Journal. 2006;53(4):493-501. Sample size less than 50 patients. [pmid: 16829707].
1874 Iglesias J, Marik PE, Levine JS, et al. Elevated serum levels of the type I and type II receptors for tumor necrosis factor-alpha as predictive factors for ARF in patients with septic shock. American Journal of Kidney Diseases. 2003;41(1):62-75. Not CKD treatment. [pmid: 12500222].
1875 Iguchi M, Katoh Y, Koike H, et al. Randomized trial of trigger point injection for renal colic. International Journal of Urology. 2002;9(9):475-9. Not CKD treatment. [pmid: 12410926].
1876 Ihle BU, Becker GJ, Whitworth JA, et al. The effect of protein restriction on the progression of renal insufficiency. New England Journal of Medicine. 1989;321(26):1773-7. Not early CKD. [pmid: 2512486].
1877 Ihle BU, Whitworth JA, Shahinfar S, et al. Angiotensin-converting enzyme inhibition in nondiabetic progressive renal insufficiency: a controlled double-blind trial. American Journal of Kidney Diseases. 1996;27(4):489-95. Not early CKD. [pmid: 8678058].
1878 Iino Y, Hayashi M, Kawamura T, et al. Interim evidence of the renoprotective effect of the angiotensin II receptor antagonist losartan versus the calcium channel blocker amlodipine in patients with chronic kidney disease and hypertension: a report of the Japanese Losartan Therapy Intended for Global Renal Protection in Hypertensive Patients (JLIGHT) Study. Clinical & Experimental Nephrology. 2003;7(3):221-30. Not relevant to key questions. [pmid: 14586719].
1879 Iino Y, Hayashi M, Kawamura T, et al. Renoprotective effect of losartan in comparison to amlodipine in patients with chronic kidney disease and hypertension--a report of the Japanese Losartan Therapy Intended for the Global Renal Protection in Hypertensive Patients (JLIGHT) study. Hypertension Research - Clinical & Experimental. 2004;27(1):21-30. Not relevant to key questions.
1880 Ikeda K, Terashima M, Kawamura H, et al. Pharmacokinetics of cisplatin in combined cisplatin and 5-fluorouracil therapy: a comparative study of three different schedules of cisplatin administration. Japanese Journal of Clinical Oncology. 1998;28(3):168-75. Not CKD treatment. [pmid: 9614438].
1881 Ikeda T, Nakayama D, Gomi T, et al. Captopril, an angiotensin I-converting enzyme inhibitor, decreases proteinuria in hypertensive patients with renal diseases. Nephron. 1989;52(1):72-5. Sample size less than 50 patients. [pmid: 2651951].
1882 Ilag LL, Martin CL, Tabaei BP, et al. Improving diabetes processes of care in managed care. Diabetes Care. 2003;26(10):2722-7. Not relevant to key questions. [pmid: 14514570].
1883 Imai E, Ito S, Haneda M, et al. Olmesartan reducing incidence of endstage renal disease in diabetic nephropathy trial (ORIENT): rationale and study design. Hypertension Research - Clinical & Experimental. 2006;29(9):703-9. Not early CKD.
1884 Imai H, Hotta O, Yoshimura M, et al. Deoxyspergualin, an immunosuppressant, in patients suffering from nephropathies with crescent formation: an open-label trial to evaluate safety and efficacy. Clinical & Experimental Nephrology. 2006;10(1):40-54. Sample size less than 50 patients. [pmid: 16544177].
1885 Imai Y, Suzuki H, Saito T, et al. The effect of pravastatin on renal function and lipid metabolism in patients with renal dysfunction with hypertension and hyperlipidemia. Pravastatin and Renal Function Research Group. Clinical & Experimental Hypertension. 1999;21(8):1345-55. Not relevant to key questions. [pmid: 10574417].
1886 Imamura Y, Murayama N, Okudaira N, et al. Prediction of fluoroquinolone-induced elevation in serum creatinine levels: a case of drug-endogenous substance interaction involving the inhibition of renal secretion. Clinical Pharmacology & Therapeutics. Jan. 2011;89(1):81-8. Not CKD treatment. [pmid: 21124314].
1887 Imanishi M, Yoshioka K, Okumura M, et al. Mechanism of decreased albuminuria caused by angiotensin converting enzyme inhibitor in early diabetic nephropathy. Kidney International- Supplement. 1997;63:S198-200. Sample size less than 50 patients. [pmid: 9407458].
1888 Imbasciati E, Gusmano R, Edefonti A, et al. Controlled trial of methylprednisolone pulses and low dose oral prednisone for the minimal change nephrotic syndrome. British Medical Journal Clinical Research Ed. 1985;291(6505):1305-8. Not early CKD. [pmid: 3933645].
1889 Indermitte J, Burkolter S, Drewe J, et al. Risk factors associated with a high velocity of the development of hyperkalaemia in hospitalised patients. Drug Safety. 2007;30(1):71-80. Not relevant to key questions. [pmid: 17194172].
1890 Innes A, Gemmell HG, Smith FW, et al. The short term effects of oral labetalol in patients with chronic renal disease and hypertension. Journal of Human Hypertension. 1992;6(3):211-4. Follow-up less than 6 months. [pmid: 1629891].
1891 Inoue S, Tomino Y. Effects of calcium antagonists in hypertensive patients with renal dysfunction: a prospective, randomized, parallel trial comparing benidipine and nifedipine. Nephrology. 2004;9(5):265-71. Not early CKD. [pmid: 15504138].
1892 Insua A, Ribstein J, Mimran A. Comparative effect of captopril and nifedipine in normotensive patients with incipient diabetic nephropathy. Postgraduate Medical Journal. Suppl 3. 1988;64:59-62. discussion 90-2. Follow-up less than 6 months. [pmid: 3074298].
1893 Inthorn D, Hoffmann JN, Hartl WH, et al. Antithrombin III supplementation in severe sepsis: beneficial effects on organ dysfunction. Shock. 1997;8(5):328-34. Not CKD treatment. [pmid: 9361342].
1894 Investigators ACTT. Rationale, design, and baseline characteristics of the Acetylcystein for Contrast-Induced nephropaThy (ACT) Trial: a pragmatic randomized controlled trial to evaluate the efficacy of acetylcysteine for the prevention of contrast-induced nephropathy. Trials [Electronic Resource]. 2009;10:38. Not CKD treatment.
1895 Investigators DT, Dagenais GR, Gerstein HC, et al. Effects of ramipril and rosiglitazone on cardiovascular and renal outcomes in people with impaired glucose tolerance or impaired fasting glucose: results of the Diabetes REduction Assessment with ramipril and rosiglitazone Medication (DREAM) trial. Diabetes Care. 2008;31(5):1007-14. Not CKD treatment. [pmid: 18268075].
1896 Ip-Yam PC, Murphy S, Baines M, et al. Renal function and proteinuria after cardiopulmonary bypass: the effects of temperature and mannitol. Anesthesia & Analgesia. 1994;78(5):842-7. Sample size less than 50 patients. [pmid: 8160980].
1897 Irish A, Dogra G, Mori T, et al. Preventing AVF thrombosis: the rationale and design of the Omega-3 fatty acids (Fish Oils) and Aspirin in Vascular access OUtcomes in REnal Disease (FAVOURED) study. BMC Nephrology. 2009;10:1. Not CKD treatment. [pmid: 19159453].
1898 Irwin MG, Roulson CJ, Jones RD, et al. Peri-operative administration of rectal diclofenac sodium. The effect on renal function in patients undergoing minor orthopaedic surgery. European Journal of Anaesthesiology. 1995;12(4):403-6. Sample size less than 50 patients. [pmid: 7588670].
1899 Isakova T, Gutierrez O, Shah A, et al. Postprandial mineral metabolism and secondary hyperparathyroidism in early CKD. [Erratum appears in J Am Soc Nephrol 2009 Jan; 20(1):229]. Journal of the American Society of Nephrology. 2008;19(3):615-23. Sample size less than 50 patients. [pmid: 18216315].
1900 Isakova T, Gutierrez OM, Wolf M. A blueprint for randomized trials targeting phosphorus metabolism in chronic kidney disease. Kidney International. 2009;76(7):705-16. Not RCT or controlled trial. [pmid: 19606082].
1901 Isakova T, Gutierrez OM, Wolf M. A blueprint for randomized trials targeting phosphorus metabolism in chronic kidney disease. Kidney International. 2009;76(7):705-16. Not RCT or controlled trial. [pmid: 19606082].
1902 Isbel NM, Haluska B, Johnson DW, et al. Increased targeting of cardiovascular risk factors in patients with chronic kidney disease does not improve atheroma burden or cardiovascular function. American Heart Journal. 2006;151(3):745-53. Not relevant to key questions. [pmid: 16504645].
1903 Iseki K, Osato S, Onoyama K, et al. Role of calcium supplementation in patients with mild renal failure. Contributions to Nephrology. 1991;90:155-60. Sample size less than 50 patients. [pmid: 1959341].
1904 Isenbarger DW, Kent SM, O'Malley PG. Meta-analysis of randomized clinical trials on the usefulness of acetylcysteine for prevention of contrast nephropathy. American Journal of Cardiology. 2003;92(12):1454-8. Not CKD treatment. [pmid: 14675586].
1905 Ishani A, Blackwell T, Jamal SA, et al. The effect of raloxifene treatment in postmenopausal women with CKD. Journal of the American Society of Nephrology. 2008;19(7):1430-8. Follow-up less than 6 months. [pmid: 18400939].
1906 Ishani A, Grandits GA, Grimm RH, et al. Association of single measurements of dipstick proteinuria, estimated glomerular filtration rate, and hematocrit with 25-year incidence of end-stage renal disease in the multiple risk factor intervention trial. Journal of the American Society of Nephrology. 2006;17(5):1444-52. Not RCT or controlled trial. [pmid: 16611715].
1907 Ishani A, Herzog CA, Collins AJ, et al. Cardiac medications and their association with cardiovascular events in incident dialysis patients: cause or effect?. Kidney International. 2004;65(3):1017-25. Not relevant to key questions. [pmid: 14871422].
1908 Ishani A, Paudel M, Taylor BC, et al. Renal function and rate of hip bone loss in older men: the Osteoporotic Fractures in Men Study. Osteoporosis International. 2008;19(11):1549-56. Not CKD treatment. [pmid: 18392664].
1909 Ishani A, Xue JL, Himmelfarb J, et al. Acute kidney injury increases risk of ESRD among elderly. Journal of the American Society of Nephrology. 2009;20(1):223-8. Not CKD treatment. [pmid: 19020007].
1910 Ishani A, Xue JL, Himmelfarb J, et al. Acute kidney injury increases risk of ESRD among elderly. Journal of the American Society of Nephrology. 2009;20(1):223-8. Not CKD treatment. [pmid: 19020007].
1911 Ishibashi F. Glomerular clearance and tubular reabsorption of transferrin in microtransferrinuric patients with non-insulin-dependent diabetes. Diabetes Research & Clinical Practice. 1994;25(3):169-75. Not CKD treatment. [pmid: 7851271].
1912 Ishikawa J, Hoshide S, Shibasaki S, et al. Relationship between morning hypertension identified by home blood pressure monitoring and brain natriuretic peptide and estimated glomerular filtration rate: the Japan Morning Surge 1 (JMS-1) Study. Journal of Clinical Hypertension. 2008;10(1):34-42. Not RCT or controlled trial. [pmid: 18174769].
1913 Ishimitsu T, Akashiba A, Kameda T, et al. Benazepril slows progression of renal dysfunction in patients with non-diabetic renal disease. Nephrology. 2007;12(3):294-8. Not RCT or controlled trial. [pmid: 17498126].
1914 Ishimitsu T, Numabe A, Masuda T, et al. Angiotensin-II receptor antagonist combined with calcium channel blocker or diuretic for essential hypertension. Hypertension Research - Clinical & Experimental. 2009;32(11):962-8. Sample size less than 50 patients.
1915 Ishimura E, Nishizawa Y, Okuno S, et al. Diabetes mellitus increases the severity of anemia in non-dialyzed patients with renal failure. Journal of Nephrology. 1998;11(2):83-6. Sample size less than 50 patients. [pmid: 9589379].
1916 Isles C, Main J, O'Connell J, et al. Survival associated with renovascular disease in Glasgow and Newcastle: a collaborative study. Scottish Medical Journal. 1990;35(3):70-3. Not RCT or controlled trial. [pmid: 2374912].
1917 Ismail T, Ayres R, Kiff P, et al. Enisoprost in liver transplantation. Transplantation. 1995;59(9):1298-301. Follow-up less than 6 months. [pmid: 7762065].
1918 Ismail-Beigi F, Craven T, Banerji MA, et al. Effect of intensive treatment of hyperglycaemia on microvascular outcomes in type 2 diabetes: an analysis of the ACCORD randomised trial. [Erratum appears in Lancet.2010 Oct 30;376(9751):1466]. Lancet. Aug. 7. 2010;376(9739):419-30. Not relevant to key questions. [pmid: 20594588].
1919 Isnard F, Tilleul P, Laporte JP, et al. A benefit for renal function after early switch to liposomal amphotericin B from conventional formulation in empirical antifungal treatment. Nephrology Dialysis Transplantation. 2007;22(10):3090-1. Not relevant to key questions.
1920 Isomaa B, Henricsson M, Almgren P, et al. The metabolic syndrome influences the risk of chronic complications in patients with type II diabetes. Diabetologia. 2001;44(9):1148-54. Not CKD treatment. [pmid: 11596670].
1921 Ito S. Usefulness of RAS inhibition depends on baseline albuminuria. Nature Reviews Nephrology. 2010;6(1):10-1. Not RCT or controlled trial.
1922 Ito S, Nakura N, Le Breton S, et al. Efficacy and safety of aliskiren in Japanese hypertensive patients with renal dysfunction. Hypertension Research - Clinical & Experimental. 2010;33(1):62-6. Follow-up less than 6 months.
1923 Itoh K. Comparison of methods for determination of glomerular filtration rate: Tc-99m-DTPA renography, predicted creatinine clearance method and plasma sample method. Annals of Nuclear Medicine. 2003;17(7):561-5. Not CKD treatment. [pmid: 14651355].
1924 Itoh K, Tsushima S, Tsukamoto E, et al. Reappraisal of single-sample and gamma camera methods for determination of the glomerular filtration rate with 99mTc-DTPA. Annals of Nuclear Medicine. 2000;14(3):143-50. Not early CKD. [pmid: 10921477].
1925 Ivanovski O, Nikolov IG, Drueke BT, et al. Atherosclerosis and vascular calcification in uraemia - a new experimental model. Makedonska Akademija na Naukite i Umetnostite Oddelenie Za Bioloshki i Meditsinski Nauki Prilozi. 2007;28(2):11-24. Not CKD treatment.
1926 Ivanyi B. Development of chronic renal failure in patients with multiple myeloma. Archives of Pathology & Laboratory Medicine. 1993;117(8):837-40. Sample size less than 50 patients. [pmid: 8343049].
1927 Ives NJ, Wheatley K, Stowe RL, et al. Continuing uncertainty about the value of percutaneous revascularization in atherosclerotic renovascular disease: a meta-analysis of randomized trials. Nephrology Dialysis Transplantation. 2003;18(2):298-304. Not relevant to key questions.
1928 Ix JH, McCulloch CE, Chertow GM. Theophylline for the prevention of radiocontrast nephropathy: a meta-analysis. Nephrology Dialysis Transplantation. 2004;19(11):2747-53. Sample size less than 50 patients.
1929 Ix JH, Shlipak MG, Sarnak MJ, et al. Fetuin-A is not associated with mortality in chronic kidney disease. Kidney International. 2007;72(11):1394-9. Not RCT or controlled trial. [pmid: 17882149].
1930 Iyengar A, Damle H, Kulkarni C, et al. Steroid sparing effect of a herbal preparation in steroid-dependent nephrotic syndrome. Pediatric Nephrology. 2006;21(7):1031-3. Sample size less than 50 patients. [pmid: 16773418].
1931 Iyengar SK, Adler SG. The application of the HapMap to diabetic nephropathy and other causes of chronic renal failure. Seminars in Nephrology. 2007;27(2):223-36. Not relevant to key questions. [pmid: 17418690].
1932 Izhar M, Alausa T, Folker A, et al. Effects of COX inhibition on blood pressure and kidney function in ACE inhibitor-treated blacks and hispanics. Hypertension. 2004;43(3):573-7. Not RCT or controlled trial. [pmid: 14744921].
1933 Izumi K, Eishi K, Yamachika S, et al. The efficacy of human atrial natriuretic peptide in patients with renal dysfunction undergoing cardiac surgery. Annals of Thoracic & Cardiovascular Surgery. 2008;14(5):294-302. Not CKD treatment. [pmid: 18989245].
1934 Izzedine H, Hulot JS, Launay-Vacher V, et al. Renal safety of adefovir dipivoxil in patients with chronic hepatitis B: two double-blind, randomized, placebo-controlled studies. Kidney International. 2004;66(3):1153-8. Not early CKD. [pmid: 15327411].
1935 Izzo JL Jr, Purkayastha D, Hall D, et al. Comparative efficacy and safety of amlodipine/benazepril combination therapy and amlodipine monotherapy in severe hypertension. Journal of Human Hypertension. Jun. 2010;24(6):403-9. Not CKD treatment. [pmid: 19890370].
1936 Jackson GH. Renal safety of ibandronate. Oncologist. Suppl 1. 2005;10:14-8. Not relevant to key questions. [pmid: 16264108].
1937 Jacobi J, Schmieder RE. Nephroprotection by antihypertensive therapy. Basic Research in Cardiology. Suppl 2. 1998;93:109-19. Not RCT or controlled trial. [pmid: 9833172].
1938 Jacobs DR Jr, Gross MD, Steffen L, et al. The effects of dietary patterns on urinary albumin excretion: results of the Dietary Approaches to Stop Hypertension (DASH) Trial. American Journal of Kidney Diseases. 2009;53(4):638-46. Not CKD treatment. [pmid: 19167797].
1939 Jacobs ML, Derkx FH, Stijnen T, et al. Effect of long-acting somatostatin analog (Somatulin) on renal hyperfiltration in patients with IDDM. Diabetes Care. 1997;20(4):632-6. Sample size less than 50 patients. [pmid: 9096993].
1940 Jacobsen BA, Fjeldborg P. Renal haemodynamics during propranolol treatment in patients with arterial hypertension and chronic renal failure. Scandinavian Journal of Clinical & Laboratory Investigation. 1986;46(3):289-92. Follow-up less than 6 months. [pmid: 3715380].
1941 Jacobsen P, Andersen S, Jensen BR, et al. Additive effect of ACE inhibition and angiotensin II receptor blockade in type I diabetic patients with diabetic nephropathy. Journal of the American Society of Nephrology. 2003;14(4):992-9. Sample size less than 50 patients. [pmid: 12660333].
1942 Jacobsen P, Andersen S, Rossing K, et al. Dual blockade of the renin-angiotensin system in type 1 patients with diabetic nephropathy. Nephrology Dialysis Transplantation. 2002;17(6):1019-24. Follow-up less than 6 months.
1943 Jacobsen P, Andersen S, Rossing K, et al. Dual blockade of the renin-angiotensin system versus maximal recommended dose of ACE inhibition in diabetic nephropathy. Kidney International. 2003;63(5):1874-80. Sample size less than 50 patients. [pmid: 12675866].
1944 Jacobsen P, Parving HH. Beneficial impact on cardiovascular risk factors by dual blockade of the renin-angiotensin system in diabetic nephropathy. Kidney International - Supplement. 2004;(92):S108-10. Not CKD treatment. [pmid: 15485400].
1945 Jacobson P, Uberti J, Davis W, et al. Tacrolimus: a new agent for the prevention of graft-versus-host disease in hematopoietic stem cell transplantation. Bone Marrow Transplantation. 1998;22(3):217-25. Not CKD treatment. [pmid: 9720734].
1946 Jacobson SH, Ostenson CG. Effects of alpha 2-adrenergic blockade on renal hemodynamics in patients with insulin dependent diabetes mellitus. Diabetes Research & Clinical Practice. 1991;14(3):197-203. Sample size less than 50 patients. [pmid: 1685705].
1947 Jaehde U, Sorgel F, Reiter A, et al. Effect of probenecid on the distribution and elimination of ciprofloxacin in humans. Clinical Pharmacology & Therapeutics. 1995;58(5):532-41. Sample size less than 50 patients. [pmid: 7586947].
1948 Jaehde U, Sorgel F, Stephan U, et al. Effect of an antacid containing magnesium and aluminum on absorption, metabolism, and mechanism of renal elimination of pefloxacin in humans. Antimicrobial Agents & Chemotherapy. 1994;38(5):1129-33. Follow-up less than 6 months. [pmid: 8067750].
1949 Jafar TH, Schmid CH, Landa M, et al. Angiotensin-converting enzyme inhibitors and progression of nondiabetic renal disease. A meta-analysis of patient-level data. [Erratum appears in Ann Intern Med 2002 Aug 20; 137(4):299]. Annals of Internal Medicine. 2001;135(2):73-87. Not relevant to key questions. [pmid: 11453706].
1950 Jafar TH, Schmid CH, Stark PC, et al. The rate of progression of renal disease may not be slower in women compared with men: a patient-level meta-analysis. Nephrology Dialysis Transplantation. 2003;18(10):2047-53. Not RCT or controlled trial.
1951 Jafar TH, Stark PC, Schmid CH, et al. Progression of chronic kidney disease: the role of blood pressure control, proteinuria, and angiotensin-converting enzyme inhibition: a patient-level meta-analysis. Annals of Internal Medicine. 2003;139(4):244-52. Not RCT or controlled trial. [pmid: 12965979].
1952 Jafar TH, Stark PC, Schmid CH, et al. Proteinuria as a modifiable risk factor for the progression of non-diabetic renal disease. Kidney International. 2001;60(3):1131-40. Not RCT or controlled trial. [pmid: 11532109].
1953 Jager A, Kostense PJ, Nijpels G, et al. Microalbuminuria is strongly associated with NIDDM and hypertension, but not with the insulin resistance syndrome: the Hoorn Study. Diabetologia. 1998;41(6):694-700. Not CKD treatment. [pmid: 9662052].
1954 Jakobsen JA. Renal experience with Visipaque. European Radiology. Suppl 2. 1996;6:S16-9. Not RCT or controlled trial. [pmid: 8798051].
1955 Jakobsen JA, Berg KJ, Brodahl U, et al. Renal effects of nonionic contrast media after cardioangiography. Acta Radiologica. 1994;35(2):191-6. Not CKD treatment. [pmid: 8172750].
1956 Jakobsen JA, Berg KJ, Kjaersgaard P, et al. Angiography with nonionic X-ray contrast media in severe chronic renal failure: renal function and contrast retention. Nephron. 1996;73(4):549-56. Sample size less than 50 patients. [pmid: 8856250].
1957 Jakobsen JA, Kolbenstvedt AN, Berg KJ. Renal effects of iopentol and iohexol after intravenous injection. Acta Radiologica. 1991;32(4):320-4. Not CKD treatment. [pmid: 1863505].
1958 Jakobsen JA, Kolbenstvedt AN, Levorstad K, et al. Renal effects of nonionic contrast media after intravenous cardiac, and lumbar aortic injections. Investigative Radiology. Suppl 1. 1990;25:S135-6. Sample size less than 50 patients. [pmid: 2283233].
1959 Jamal SA, Bauer DC, Ensrud KE, et al. Alendronate treatment in women with normal to severely impaired renal function: an analysis of the fracture intervention trial. Journal of Bone & Mineral Research. 2007;22(4):503-8. Not relevant to key questions. [pmid: 17243862].
1960 Jamal SA, Fitchett D, Lok CE, et al. The effects of calcium-based versus non-calcium-based phosphate binders on mortality among patients with chronic kidney disease: a meta-analysis. Nephrology Dialysis Transplantation. 2009;24(10):3168-74. Not RCT or controlled trial.
1961 Jamar F, Barone R, Mathieu I, et al. 86Y-DOTA0)-D-Phe1-Tyr3-octreotide (SMT487)--a phase 1 clinical study: pharmacokinetics, biodistribution and renal protective effect of different regimens of amino acid co-infusion. European Journal of Nuclear Medicine & Molecular Imaging. 2003;30(4):510-8. Not CKD treatment. [pmid: 12582815].
1962 James S, Budaj A, Aylward P, et al. Ticagrelor versus clopidogrel in acute coronary syndromes in relation to renal function: results from the Platelet Inhibition and Patient Outcomes (PLATO) trial. Circulation. Sep. 14. 2010;122(11):1056-67. Not CKD treatment. [pmid: 20805430].
1963 Jamieson MJ, Webster J, Fowler G, et al. A comparison of the chronic effects of oral xamoterol and enalapril on blood pressure and renal function in mild to moderate heart failure. British Journal of Clinical Pharmacology. 1991;31(3):305-12. Follow-up less than 6 months. [pmid: 1675867].
1964 Jamison RL, Hartigan P, Kaufman JS, et al. Effect of homocysteine lowering on mortality and vascular disease in advanced chronic kidney disease and end-stage renal disease: a randomized controlled trial. [Erratum appears in JAMA.2008 Jul 9;300(2):170]. JAMA. 2007;298(10):1163-70. Sample size less than 50 patients. [pmid: 17848650].
1965 Jamison RL, Shih MC, Humphries DE, et al. Effect of the MTHFR C677T and A1298C polymorphisms on survival in patients with advanced CKD and ESRD: a prospective study. American Journal of Kidney Diseases. 2009;53(5):779-89. Not CKD treatment. [pmid: 19272686].
1966 Jandeleit-Dahm K, Cao Z, Cox AJ, et al. Role of hyperlipidemia in progressive renal disease: focus on diabetic nephropathy. Kidney International - Supplement. 1999;71:S31-6. Not human studies. [pmid: 10412733].
1967 Jansen JJ, Maassen JA, van der Woude FJ, et al. Mutation in mitochondrial tRNA(Leu(UUR)) gene associated with progressive kidney disease. Journal of the American Society of Nephrology. 1997;8(7):1118-24. Not RCT or controlled trial. [pmid: 9219161].
1968 Jansen PM, Danser AHJ, Imholz BP, et al. Aldosterone-receptor antagonism in hypertension. Journal of Hypertension. 2009;27(4):680-91. Not RCT or controlled trial. [pmid: 19516169].
1969 Janssen JJ, Gans RO, van der Meulen J, et al. Comparison between the effects of amlodipine and lisinopril on proteinuria in nondiabetic renal failure: a double-blind, randomized prospective study. American Journal of Hypertension. 1998;11(9):1074-9. Sample size less than 50 patients. [pmid: 9752892].
1970 Janssen van Doorn K, Spapen H, Geers C, et al. Sepsis-related acute kidney injury: a protective effect of drotrecogin alpha (activated) treatment?. [Erratum appears in Acta Anaesthesiol Scand. 2009 Feb; 53(2):275. Note: van Doorn, K J [ corrected to Janssen van Doorn, K]]. Acta Anaesthesiologica Scandinavica. 2008;52(9):1259-64. Sample size less than 50 patients. [pmid: 18823466].
1971 Janssen-Heijnen MLG, van Spronsen DJ, Lemmens VEPP, et al. A population-based study of severity of comorbidity among patients with non-Hodgkin's lymphoma: prognostic impact independent of International Prognostic Index. British Journal of Haematology. 2005;129(5):597-606. Not relevant to key questions. [pmid: 15916681].
1972 Januzzi JL, Cannon CP, DiBattiste PM, et al. Effects of renal insufficiency on early invasive management in patients with acute coronary syndromes (The TACTICS-TIMI 18 Trial). American Journal of Cardiology. 2002;90(11):1246-9. Not CKD treatment. [pmid: 12450608].
1973 Januzzi JL Jr., Snapinn SM, DiBattiste PM, et al. Benefits and safety of tirofiban among acute coronary syndrome patients with mild to moderate renal insufficiency: results from the Platelet Receptor Inhibition in Ischemic Syndrome Management in Patients Limited by Unstable Signs and Symptoms (PRISM-PLUS) trial. Circulation. 2002;105(20):2361-6. Not CKD treatment. [pmid: 12021221].
1974 Jardine AG, Connell JM, Northridge D, et al. The atriopeptidase inhibitor UK 69,578 increases atrial natriuretic factor and causes a natriuresis in normal humans. American Journal of Hypertension. 1990;3(9):661-7. Not CKD treatment. [pmid: 2145871].
1975 Jardine MJ, Ninomiya T, Perkovic V, et al. Aspirin is beneficial in hypertensive patients with chronic kidney disease: a post-hoc subgroup analysis of a randomized controlled trial. Journal of the American College of Cardiology. Sep. 14. 2010;56(12):956-65. Not CKD treatment. [pmid: 20828648].
1976 Jarnberg PO. Renal protection strategies in the perioperative period. Best Practice & Research. Clinical Anaesthesiology. 2004;18(4):645-60. Not RCT or controlled trial.
1977 Jasani NB, O'Conner RE, Bouzoukis JK. Comparison of hydromorphone and meperidine for ureteral colic. Academic Emergency Medicine. 1994;1(6):539-43. Not CKD treatment. [pmid: 7541310].
1978 Jaschevatzky OE, Rosenberg RP, Shalit A, et al. Protein/creatinine ratio in random urine specimens for quantitation of proteinuria in preeclampsia. Obstetrics & Gynecology. 1990;75(4):604-6. Not CKD treatment. [pmid: 2314778].
1979 Jawa A, Nachimuthu S, Pendergrass M, et al. Beta-blockers have a beneficial effect upon endothelial function and microalbuminuria in African-American subjects with diabetes and hypertension. Journal of Diabetes & its Complications. 2008;22(5):303-8. Not CKD treatment. [pmid: 18413195].
1980 Jean R, Ducasse JL, Montastruc JL, et al. Treatment of acute renal colic in a French emergency department: a comparison of simulated cases and real cases in acute pain assessment and management. European Journal of Clinical Pharmacology. 2001;57(9):685-9. Not early CKD. [pmid: 11791900].
1981 Jeevanandam V, Russell H, Mather P, et al. Donor tricuspid annuloplasty during orthotopic heart transplantation: long-term results of a prospective controlled study. Annals of Thoracic Surgery. 2006;82(6):2089-95. discussion 95. Follow-up less than 6 months. [pmid: 17126116].
1982 Jeffres MN, Isakow W, Doherty JA, et al. A retrospective analysis of possible renal toxicity associated with vancomycin in patients with health care-associated methicillin-resistant Staphylococcus aureus pneumonia. Clinical Therapeutics. 2007;29(6):1107-15. Follow-up less than 6 months. [pmid: 17692725].
1983 Jeffrey RF, MacDonald TM, Freestone S, et al. The effect of carbidopa and lithium on the systemic and renal response to acute intravenous saline loading in normal man. Nephrology Dialysis Transplantation. 1989;4(4):271-7. Not CKD treatment.
1984 Jeffrey RF, MacDonald TM, Lee MR. A comparison of the renal actions of gamma-L-glutamyl-L-dopa and gamma-L-glutamyl-L-tyrosine in normal man. Clinical Science. 1988;74(1):37-40. Sample size less than 50 patients. [pmid: 3123118].
1985 Jenkins DA, Cowan P, Patrick AW, et al. Renal responses to nifedipine and captopril in hypertensive insulin-dependent diabetic men: a randomized cross-over study. Nephrology Dialysis Transplantation. 1993;8(3):200-5. Follow-up less than 6 months.
1986 Jenkins DJ, Kendall CW, Vidgen E, et al. High-protein diets in hyperlipidemia: effect of wheat gluten on serum lipids, uric acid, and renal function. American Journal of Clinical Nutrition. 2001;74(1):57-63. Not early CKD. [pmid: 11451718].
1987 Jensen HV, Plenge P, Mellerup ET, et al. Lithium prophylaxis of manic-depressive disorder: daily lithium dosing schedule versus every second day. Acta Psychiatrica Scandinavica. 1995;92(1):69-74. Follow-up less than 6 months. [pmid: 7572251].
1988 Jensen JS, Feldt-Rasmussen B, Borch-Johnsen K, et al. Increased transvascular lipoprotein transport in diabetes: association with albuminuria and systolic hypertension. Journal of Clinical Endocrinology & Metabolism. 2005;90(8):4441-5. Not early CKD. [pmid: 15899947].
1989 Jensen KT, Carstens J, Pedersen EB. Effect of BNP on renal hemodynamics, tubular function and vasoactive hormones in humans. American Journal of Physiology. 1998;274(1 Pt 2):F63-72. Sample size less than 50 patients. [pmid: 9458824].
1990 Jensen T, Stender S, Goldstein K, et al. Partial normalization by dietary cod-liver oil of increased microvascular albumin leakage in patients with insulin-dependent diabetes and albuminuria. New England Journal of Medicine. 1989;321(23):1572-7. Sample size less than 50 patients. [pmid: 2685599].
1991 Jentzer JC, DeWald TA, Hernandez AF. Combination of loop diuretics with thiazide-type diuretics in heart failure. Journal of the American College of Cardiology. Nov. 2. 2010;56(19). Not CKD treatment.
1992 Jeppsson A, Ekroth R, Friberg P, et al. Renal effects of amino acid infusion in cardiac surgery. Journal of Cardiothoracic & Vascular Anesthesia. 2000;14(1):51-5. Sample size less than 50 patients. [pmid: 10698393].
1993 Jeppsson A, Ekroth R, Friberg P, et al. Renal effects of alpha-ketoglutarate early after coronary operations. Annals of Thoracic Surgery. 1998;65(3):684-90. Not CKD treatment. [pmid: 9527195].
1994 Jeppsson A, Ekroth R, Kirno K, et al. Insulin and amino acid infusion after cardiac operations: effects on systemic and renal perfusion. Journal of Thoracic & Cardiovascular Surgery. 1997;113(3):594-602. Sample size less than 50 patients. [pmid: 9081107].
1995 Jerums G, Allen TJ, Campbell DJ, et al. Long-term renoprotection by perindopril or nifedipine in non-hypertensive patients with Type 2 diabetes and microalbuminuria. Diabetic Medicine. 2004;21(11):1192-9. Not relevant to key questions. [pmid: 15498085].
1996 Jerums G, Allen TJ, Campbell DJ, et al. Long-term comparison between perindopril and nifedipine in normotensive patients with type 1 diabetes and microalbuminuria. American Journal of Kidney Diseases. 2001;37(5):890-9. Sample size less than 50 patients. [pmid: 11325669].
1997 Jerums G, Allen TJ, Gilbert RE, et al. Natural history of early diabetic nephropathy: what are the effects of therapeutic intervention? Melbourne Diabetic Nephropathy Study Group. Journal of Diabetes & its Complications. 1995;9(4):308-14. Not RCT or controlled trial. [pmid: 8573754].
1998 Jerums G, Murray RM, Seeman E, et al. Lack of effect of gliclazide on early diabetic nephropathy and retinopathy: a two-year controlled study. Diabetes Research & Clinical Practice. 1987;3(2):71-80. Sample size less than 50 patients. [pmid: 3552537].
1999 Jespersen B, Randlov A, Abrahamsen J, et al. Acute cardiovascular effect of 1,25-dihydroxycholecalciferol in essential hypertension. American Journal of Hypertension. 1998;11(6 Pt 1):659-66. Sample size less than 50 patients. [pmid: 9657624].
2000 Jevnikar AM, Finnie KJ, Dennis B, et al. Nephrotoxicity of high- and low-osmolality contrast media. Nephron. 1988;48(4):300-5. Sample size less than 50 patients. [pmid: 3362276].
2001 Ji H, Yao S, Luo Q, et al. TCM treatment of rheumatoid arthritis by supplementing the kidney and invigorating the blood circulation. Journal of Traditional Chinese Medicine. 2002;22(4):252-5. Not RCT or controlled trial. [pmid: 16579083].
2002 Jiang F, Jones GT, Dusting GJ. Failure of antioxidants to protect against angiotensin II-induced aortic rupture in aged apolipoprotein(E)-deficient mice. British Journal of Pharmacology. 2007;152(6):880-90. Sample size less than 50 patients. [pmid: 17828285].
2003 Jin HM, Pan Y. Renoprotection provided by losartan in combination with pioglitazone is superior to renoprotection provided by losartan alone in patients with type 2 diabetic nephropathy. Kidney & Blood Pressure Research. 2007;30(4):203-11. Not RCT or controlled trial. [pmid: 17575467].
2004 Jin HM, Pan Y. Angiotensin type-1 receptor blockade with losartan increases insulin sensitivity and improves glucose homeostasis in subjects with type 2 diabetes and nephropathy. Nephrology Dialysis Transplantation. 2007;22(7):1943-9. Follow-up less than 6 months.
2005 Jin KK, Chen L, Pan JY, et al. Acupressure therapy inhibits the development of diabetic complications in Chinese patients with type 2 diabetes. Journal of Alternative & Complementary Medicine. 2009;15(9):1027-32. Not CKD treatment.
2006 Jin X. A clinical investigation on 30 cases of senile benign renal arteriolosclerosis treated by huang qi gu jing yin. Journal of Traditional Chinese Medicine. 2001;21(3):177-80. Not early CKD. [pmid: 11789320].
2007 Jin Z. Chai ling tang in the treatment of steroid-dependent nephrosis syndrome. Journal of Traditional Chinese Medicine. 1994;14(4):254-8. Not CKD treatment. [pmid: 7877332].
2008 Jindal RM, Popescu I, Emre S, et al. Serum lipid changes in liver transplant recipients in a prospective trial of cyclosporine versus FK506. Transplantation. 1994;57(9):1395-8. Not early CKD. [pmid: 7514317].
2009 Jo SH, Koo BK, Park JS, et al. Prevention of radiocontrast medium-induced nephropathy using short-term high-dose simvastatin in patients with renal insufficiency undergoing coronary angiography (PROMISS) trial--a randomized controlled study. American Heart Journal. 2008;155(3):499.e1-8. Not CKD treatment. [pmid: 18294484].
2010 Jo SH, Koo BK, Park JS, et al. N-acetylcysteine versus AScorbic acid for preventing contrast-Induced nephropathy in patients with renal insufficiency undergoing coronary angiography NASPI study-a prospective randomized controlled trial. American Heart Journal. 2009;157(3):576-83. Not early CKD. [pmid: 19249432].
2011 Jo SH, Koo BK, Youn TJ, et al. Conclusion of recent ‘osmolality trials’ in preventing contrast-induced nephropathy by NAC--what is the standard?. Nephrology Dialysis Transplantation. 2008;23(7):2424. author reply -5. Sample size less than 50 patients.
2012 Joannidis M. Medical therapy of acute kidney injury. Acta Clinica Belgica - Supplementum. 2007;(2):353-6. Not CKD treatment. [pmid: 18283998].
2013 Jodrell DI. Formula-based dosing for carboplatin. European Journal of Cancer. 1999;35(9):1299-301. Not RCT or controlled trial. [pmid: 10658517].
2014 Joffe HV, Kwong RY, Gerhard-Herman MD, et al. Beneficial effects of eplerenone versus hydrochlorothiazide on coronary circulatory function in patients with diabetes mellitus. Journal of Clinical Endocrinology & Metabolism. 2007;92(7):2552-8. Not RCT or controlled trial. [pmid: 17488800].
2015 Johansson BL, Borg K, Fernqvist-Forbes E, et al. Beneficial effects of C-peptide on incipient nephropathy and neuropathy in patients with Type 1 diabetes mellitus. Diabetic Medicine. 2000;17(3):181-9. Sample size less than 50 patients. [pmid: 10784221].
2016 Johansson BL, Kernell A, Sjoberg S, et al. Influence of combined C-peptide and insulin administration on renal function and metabolic control in diabetes type 1. Journal of Clinical Endocrinology & Metabolism. 1993;77(4):976-81. Sample size less than 50 patients. [pmid: 8408474].
2017 Johnson AG, Crawford GA, Kelly D, et al. Arginine vasopressin and osmolality in the elderly. Journal of the American Geriatrics Society. 1994;42(4):399-404. Not RCT or controlled trial. [pmid: 8144825].
2018 Johnson CA. Use of androgens in patients with renal failure. Seminars in Dialysis. 2000;13(1):36-9. Not CKD treatment. [pmid: 10740670].
2019 Johnson DW. Evidence-based guide to slowing the progression of early renal insufficiency. Internal Medicine Journal. 2004;34(1-2):50-7. Not CKD treatment. [pmid: 14748914].
2020 Johnson DW. Dietary protein restriction as a treatment for slowing chronic kidney disease progression: the case against. Nephrology. 2006;11(1):58-62. Not relevant to key questions. [pmid: 16509934].
2021 Johnson DW, Armstrong K, Campbell SB, et al. Metabolic syndrome in severe chronic kidney disease: Prevalence, predictors, prognostic significance and effects of risk factor modification. Nephrology. 2007;12(4):391-8. Not RCT or controlled trial. [pmid: 17635756].
2022 Johnson DW, Forman C, Vesey DA. Novel renoprotective actions of erythropoietin: new uses for an old hormone. Nephrology. 2006;11(4):306-12. Not CKD treatment. [pmid: 16889570].
2023 Johnson DW, Hawley CM, Rosser B, et al. Oxpentifylline versus placebo in the treatment of erythropoietin-resistant anaemia: a randomized controlled trial. BMC Nephrology. 2008;9:8. Not RCT or controlled trial. [pmid: 18671885].
2024 Johnston CS, Day CS, Swan PD. Postprandial thermogenesis is increased 100% on a high-protein, low-fat diet versus a high-carbohydrate, low-fat diet in healthy, young women. Journal of the American College of Nutrition. 2002;21(1):55-61. Not early CKD. [pmid: 11838888].
2025 Johnston GD, Passmore AP. The effects of cilazapril alone and in combination with frusemide in healthy subjects. British Journal of Clinical Pharmacology. Suppl 2. 1989;27:235S-42S. Not CKD treatment. [pmid: 2527536].
2026 Jones D, Bellomo R. Renal-dose dopamine: from hypothesis to paradigm to dogma to myth and, finally, superstition?. Journal of Intensive Care Medicine. 2005;20(4):199-211. Not relevant to key questions. [pmid: 16061903].
2027 Jones E, Goldman M. Lipid formulations of amphotericin B. Cleveland Clinic Journal of Medicine. 1998;65(8):423-7. Not CKD treatment. [pmid: 9769563].
2028 Jones M, Ibels L, Schenkel B, et al. Impact of epoetin alfa on clinical end points in patients with chronic renal failure: a meta-analysis. Kidney International. 2004;65(3):757-67. Not early CKD. [pmid: 14871396].
2029 Jones RB, Tervaert JWC, Hauser T, et al. Rituximab versus cyclophosphamide in ANCA-associated renal vasculitis. New England Journal of Medicine. Jul. 15. 2010;363(3):211-20. Not CKD treatment. [pmid: 20647198].
2030 Jones RD, Endre Z, Miles W, et al. Tenoxicam i.v. for major gynaecological surgery--effects on renal function. Anaesthesia & Intensive Care. 2000;28(5):501-9. Sample size less than 50 patients. [pmid: 11094664].
2031 Jones SL, Kontessis P, Wiseman M, et al. Protein intake and blood glucose as modulators of GFR in hyperfiltering diabetic patients. Kidney International. 1992;41(6):1620-8. Sample size less than 50 patients. [pmid: 1501418].
2032 Jonsson O, Herlitz H, Lindholm E, et al. Prophylaxis against bone loss in Kock reservoir patients with reduced glomerular filtration rate. Scandinavian Journal of Urology & Nephrology. 2005;39(3):200-5. Sample size less than 50 patients. [pmid: 16118090].
2033 Jonsson PE, Olsson AM, Petersson BA, et al. Intravenous indomethacin and oxycone-papaverine in the treatment of acute renal colic. A double-blind study. British Journal of Urology. 1987;59(5):396-400. Follow-up less than 6 months. [pmid: 3297230].
2034 Jorgensen JO, Pedersen SA, Thuesen L, et al. Beneficial effects of growth hormone treatment in GH-deficient adults. Lancet. 1989;1(8649):1221-5. Not CKD treatment. [pmid: 2566779].
2035 Jose P, Skali H, Anavekar N, et al. Increase in creatinine and cardiovascular risk in patients with systolic dysfunction after myocardial infarction. Journal of the American Society of Nephrology. 2006;17(10):2886-91. Sample size less than 50 patients. [pmid: 16928807].
2036 Josephson CD, Castillejo MI, Grima K, et al. ABO-mismatched platelet transfusions: strategies to mitigate patient exposure to naturally occurring hemolytic antibodies. Transfusion & Apheresis Science. Feb. 2010;42(1):83-8. Not CKD treatment. [pmid: 20034854].
2037 Joss N, Jardine A, Gaffney D, et al. Influence of apolipoprotein E genotype on progression of diabetic nephropathy. Nephron. Experimental Nephrology. 2005;101(4):e127-33. Not CKD treatment. [pmid: 16113584].
2038 Joy MS. Darbepoetin alfa: a novel erythropoiesis-stimulating protein. Annals of Pharmacotherapy. 2002;36(7-8):1183-92. Not RCT or controlled trial. [pmid: 12086553].
2039 Juergens CP, Winter JP, Nguyen-Do P, et al. Nephrotoxic effects of iodixanol and iopromide in patients with abnormal renal function receiving N-acetylcysteine and hydration before coronary angiography and intervention: a randomized trial. Internal Medicine Journal. 2009;39(1):25-31. Not CKD treatment. [pmid: 18771430].
2040 Juhanson P, Kepp K, Org E, et al. N-acetyltransferase 8, a positional candidate for blood pressure and renal regulation: resequencing, association and in silico study. BMC Medical Genetics. 2008;9:25. Not CKD treatment. [pmid: 18402670].
2041 Juhlin T, Bjorkman S, Gunnarsson B, et al. Acute administration of diclofenac, but possibly not long term low dose aspirin, causes detrimental renal effects in heart failure patients treated with ACE-inhibitors. European Journal of Heart Failure. 2004;6(7):909-16. Not relevant to key questions. [pmid: 15556053].
2042 Juhlin T, Bjorkman S, Hoglund P. Cyclooxygenase inhibition causes marked impairment of renal function in elderly subjects treated with diuretics and ACE-inhibitors. European Journal of Heart Failure. 2005;7(6):1049-56. Not RCT or controlled trial. [pmid: 16227143].
2043 Juhlin T, Erhardt LR, Ottosson H, et al. Treatments with losartan or enalapril are equally sensitive to deterioration in renal function from cyclooxygenase inhibition. European Journal of Heart Failure. 2007;9(2):191-6. Not relevant to key questions. [pmid: 16859993].
2044 Juhlin T, Jonsson BAG, Hoglund P. Renal effects of aspirin are clearly dose-dependent and are of clinical importance from a dose of 160 mg. European Journal of Heart Failure. 2008;10(9):892-8. Not CKD treatment. [pmid: 18794027].
2045 Julier K, da Silva R, Garcia C, et al. Preconditioning by sevoflurane decreases biochemical markers for myocardial and renal dysfunction in coronary artery bypass graft surgery: a double-blinded, placebo-controlled, multicenter study. Anesthesiology. 2003;98(6):1315-27. Not CKD treatment. [pmid: 12766638].
2046 Jungers P, Chauveau P, Ployard F, et al. Comparison of ketoacids and low protein diet on advanced chronic renal failure progression. Kidney International - Supplement. 1987;22:S67-71. Sample size less than 50 patients. [pmid: 3323621].
2047 Jungers P, Choukroun G, Oualim Z, et al. Beneficial influence of recombinant human erythropoietin therapy on the rate of progression of chronic renal failure in predialysis patients. Nephrology Dialysis Transplantation. 2001;16(2):307-12. Not RCT or controlled trial.
2048 Jungmann E, Haak T, Althoff PH, et al. Dopaminergic effects on kidney function and responsiveness of aldosterone, plasma renin activity, prolactin, catecholamines, and blood pressure to stimulation in patients with prolactinoma. Comparison of the efficacy of pergolide and bromocriptine therapy. Arzneimittel-Forschung. 1988;38(2):296-300. Sample size less than 50 patients. [pmid: 3285838].
2049 Jungmann E, Malanyn M, Mortasawi N, et al. Effect of 1-year treatment with nitrendipine versus enalapril on urinary albumin and alpha 1-microglobulin excretion in microalbuminuric patients with type 1 diabetes mellitus. A randomized, single-blind comparative study. Arzneimittel-Forschung. 1994;44(3):313-7. Sample size less than 50 patients. [pmid: 7514874].
2050 Jungmann E, Usadel KH. Effect of captopril on renal functional reserve in type 1 (insulin-dependent) diabetes mellitus. Diabetologia. 1991;34(11):843-4. Not early CKD. [pmid: 1769444].
2051 Jungmann E, Walter-Schrader MC, Haak T, et al. Impaired renal responsiveness to human atrial natriuretic peptide (hANP) in normotensive patients with type 1 diabetes mellitus. Klinische Wochenschrift. 1988;66(12):527-32. Sample size less than 50 patients. [pmid: 2971131].
2052 Junyent M, Martinez M, Borras M, et al. Predicting cardiovascular disease morbidity and mortality in chronic kidney disease in Spain. The rationale and design of NEFRONA: a prospective, multicenter, observational cohort study. BMC Nephrology. 2010;11:14. Not RCT or controlled trial. [pmid: 20609210].
2053 Jurkovitz C, Franch H, Shoham D, et al. Family members of patients treated for ESRD have high rates of undetected kidney disease. American Journal of Kidney Diseases. 2002;40(6):1173-8. Not CKD treatment. [pmid: 12460035].
2054 Kaasjager KA, Koomans HA, Rabelink TJ. Effectiveness of enalapril versus nifedipine to antagonize blood pressure and the renal response to endothelin in humans. Hypertension. 1995;25(4 Pt 1):620-5. Not RCT or controlled trial. [pmid: 7721406].
2055 Kaasjager KA, Koomans HA, Rabelink TJ. Endothelin-1-induced vasopressor responses in essential hypertension. Hypertension. 1997;30(1 Pt 1):15-21. Sample size less than 50 patients. [pmid: 9231815].
2056 Kabat-Koperska J, Motyl W, Domanski L, et al. Methods of GFR determination--creatinine clearance after cimetidine administration in clinical practice. Acta Medica Austriaca. 2004;31(2):51-5. Follow-up less than 6 months. [pmid: 15359983].
2057 Kadam S, Kulshrestha S, Swaminathan S. B-vitamin therapy for diabetic nephropathy. JAMA. Aug. 11. 2010;304(6):636. author reply -7. Not CKD treatment. [pmid: 20699451].
2058 Kadhim HM, Ismail SH, Hussein KI, et al. Effects of melatonin and zinc on lipid profile and renal function in type 2 diabetic patients poorly controlled with metformin. Journal of Pineal Research. 2006;41(2):189-93. Not RCT or controlled trial. [pmid: 16879326].
2059 Kageyama S, Brown J, Causon R, et al. DOPA decarboxylase inhibition does not influence the diuretic and natriuretic response to exogenous alpha-atrial natriuretic peptide in man. European Journal of Clinical Pharmacology. 1990;38(3):223-7. Not CKD treatment. [pmid: 2140325].
2060 Kahn D, Ben-Haim S, Bushnell DL, et al. Captopril-enhanced 99Tcm-MAG3 renal scintigraphy in subjects with suspected renovascular hypertension. Nuclear Medicine Communications. 1994;15(7):515-28. Sample size less than 50 patients. [pmid: 7970428].
2061 Kaisar MO, Isbel NM, Johnson DW. Recent clinical trials of pharmacologic cardiovascular interventions in patients with chronic kidney disease. Reviews on Recent Clinical Trials. 2008;3(2):79-88. Not CKD treatment. [pmid: 18474017].
2062 Kalaitzidis RG, Bakris GL. Should proteinuria reduction be the criterion for antihypertensive drug selection for patients with kidney disease?. Current Opinion in Nephrology & Hypertension. 2009;18(5):386-91. Not RCT or controlled trial. [pmid: 19561494].
2063 Kalambokis G, Economou M, Fotopoulos A, et al. Effects of nitric oxide inhibition by methylene blue in cirrhotic patients with ascites. Digestive Diseases & Sciences. 2005;50(10):1771-7. Not relevant to key questions. [pmid: 16187171].
2064 Kalambokis G, Fotopoulos A, Economou M, et al. Effects of a 7-day treatment with midodrine in non-azotemic cirrhotic patients with and without ascites. Journal of Hepatology. 2007;46(2):213-21. Sample size less than 50 patients. [pmid: 17156883].
2065 Kalantarinia K, Okusa MD. The renin-angiotensin system and its blockade in diabetic renal and cardiovascular disease. Current Diabetes Reports. 2006;6(1):8-16. Follow-up less than 6 months. [pmid: 16522275].
2066 Kalantar-Zadeh K, Kovesdy CP. Clinical outcomes with active versus nutritional vitamin D compounds in chronic kidney disease. Clinical Journal of The American Society of Nephrology: CJASN. 2009;4(9):1529-39. Not RCT or controlled trial. [pmid: 19661219].
2067 Kalayjian RC, Franceschini N, Gupta SK, et al. Suppression of HIV-1 replication by antiretroviral therapy improves renal function in persons with low CD4 cell counts and chronic kidney disease. AIDS. 2008;22(4):481-7. Not CKD treatment. [pmid: 18301060].
2068 Kale K, Sawant S. Clinical significance and evaluation of proteinuria in NIDDM patients. Indian Journal of Medical Sciences. 1999;53(3):103-7. Not relevant to key questions. [pmid: 10798009].
2069 Kamali F, Edwards C. Possible role of metabolite in flosequinan-related mortality. Clinical Pharmacokinetics. 1995;29(6):396-403. Not RCT or controlled trial. [pmid: 8787946].
2070 Kamiyama N, Ogawa R, Hamada H, et al. Preventive effect of N-acetylcysteine on contrast-induced nephropathy following coronary angiography and angioplasty. Yakugaku Zasshi - Journal of the Pharmaceutical Society of Japan. 2008;128(9):1333-9. Not CKD treatment. [pmid: 18758148].
2071 Kammerl MC, Grimm D, Nabel C, et al. Effects of growth hormone on renal renin gene expression in normal rats and rats with myocardial infarction. Nephrology Dialysis Transplantation. 2000;15(6):786-90. Not human studies.
2072 Kamper AL, Holstein-Rathlou NH, Leyssac PP, et al. The influence of angiotensin-converting enzyme inhibition on renal tubular function in progressive chronic nephropathy. American Journal of Kidney Diseases. 1996;28(6):822-31. Not RCT or controlled trial. [pmid: 8957033].
2073 Kamper AL, Nielsen OJ. Effect of enalapril on haemoglobin and serum erythropoietin in patients with chronic nephropathy. Scandinavian Journal of Clinical & Laboratory Investigation. 1990;50(6):611-8. Not relevant to key questions. [pmid: 2247767].
2074 Kamper AL, Strandgaard S, Leyssac PP. Effect of enalapril on the progression of chronic renal failure. A randomized controlled trial. American Journal of Hypertension. 1992;5(7):423-30. Not relevant to key questions. [pmid: 1637513].
2075 Kamper AL, Strandgaard S, Leyssac PP. Late outcome of a controlled trial of enalapril treatment in progressive chronic renal failure. Hard end-points and influence of proteinuria. Nephrology Dialysis Transplantation. 1995;10(7):1182-8. Not early CKD.
2076 Kanbay M, Covic A, Coca SG, et al. Sodium bicarbonate for the prevention of contrast-induced nephropathy: a meta-analysis of 17 randomized trials. International Urology & Nephrology. 2009;41(3):617-27. Sample size less than 50 patients. [pmid: 19396567].
2077 Kanbay M, Kasapoglu B, Akcay A. Sodium bicarbonate vs sodium chloride in preventing contrast medium-induced nephropathy. JAMA. 2009;301(4):378. author reply 9-80. Not CKD treatment. [pmid: 19176438].
2078 Kandarpa K, Becker GJ, Hunink MG, et al. Transcatheter interventions for the treatment of peripheral atherosclerotic lesions: part I. Journal of Vascular & Interventional Radiology. 2001;12(6):683-95. Not CKD treatment. [pmid: 11389219].
2079 Kandula P, Shah R, Singh N, et al. Statins for prevention of contrast-induced nephropathy in patients undergoing non-emergent percutaneous coronary intervention. Nephrology. Mar. 2010;15(2):165-70. Not CKD treatment. [pmid: 20470274].
2080 Kaneshiro Y, Ichihara A, Sakoda M, et al. Add-on benefits of amlodipine and thiazide in nondiabetic chronic kidney disease stage 1/2 patients treated with valsartan. Kidney & Blood Pressure Research. 2009;32(1):51-8. Not early CKD. [pmid: 19258723].
2081 Kang YS, Han KH, Han SY, et al. Characteristics of population with normal serum creatinine impaired renal function and: the validation of a MDRD formula in a healthy general population. Clinical Nephrology. 2005;63(4):258-66. Sample size less than 50 patients. [pmid: 15847252].
2082 Kanno Y, Takenaka T, Nakamura T, et al. Add-on angiotensin receptor blocker in patients who have proteinuric chronic kidney diseases and are treated with angiotensin-converting enzyme inhibitors. Clinical Journal of The American Society of Nephrology: CJASN. 2006;1(4):730-7. Follow-up less than 6 months. [pmid: 17699280].
2083 Kantarci F, Mihmanli I, Adaletli I, et al. The effect of fluid intake on renal length measurement in adults. Journal of Clinical Ultrasound. 2006;34(3):128-33. Not relevant to key questions. [pmid: 16547994].
2084 Kantor TG. Use of diclofenac in analgesia. American Journal of Medicine. 1986;80(4B):64-9. Not RCT or controlled trial. [pmid: 2939715].
2085 Kaplan AA. Therapeutic apheresis for cancer related hemolytic uremic syndrome. Therapeutic Apheresis. 2000;4(3):201-6. Not early CKD. [pmid: 10910020].
2086 Kaplan NM. The place of diuretics in preventing cardiovascular events. Journal of Human Hypertension. Suppl 2. 2004;18:S29-32. Not RCT or controlled trial. [pmid: 15592570].
2087 Kaplan-Pavlovcic S, Nadja C. Captopril renography and duplex Doppler sonography in the diagnosis of renovascular hypertension. Nephrology Dialysis Transplantation. 1998;13(2):313-7. Sample size less than 50 patients.
2088 Kapoor A, Figlin RA. Targeted inhibition of mammalian target of rapamycin for the treatment of advanced renal cell carcinoma. Cancer. 2009;115(16):3618-30. Not CKD treatment. [pmid: 19479976].
2089 Kapoor A, Kumar S, Gulati S, et al. The role of theophylline in contrast-induced nephropathy: a case-control study. Nephrology Dialysis Transplantation. 2002;17(11):1936-41. Not CKD treatment.
2090 Kapoor A, Sinha N, Sharma RK, et al. Use of dopamine in prevention of contrast induced acute renal failure--a randomised study. International Journal of Cardiology. 1996;53(3):233-6. Not CKD treatment. [pmid: 8793575].
2091 Karabina SA, Pappas H, Miltiadous G, et al. Compositional lipoprotein changes and low-density lipoprotein susceptibility to oxidation in chronic renal failure patients with heavy proteinuria. Nephron. 2003;95(3):c77-83. Not CKD treatment. [pmid: 14646367].
2092 Karalliedde J, Smith A, DeAngelis L, et al. Valsartan improves arterial stiffness in type 2 diabetes independently of blood pressure lowering. Hypertension. 2008;51(6):1617-23. Not CKD treatment. [pmid: 18426991].
2093 Kario K, Hoshide S, Shimizu M, et al. Effect of dosing time of angiotensin II receptor blockade titrated by self-measured blood pressure recordings on cardiorenal protection in hypertensives: the Japan Morning Surge-Target Organ Protection (J-TOP) study. Journal of Hypertension. Jul. 2010;28(7):1574-83. Not relevant to key questions. [pmid: 20404743].
2094 Kario K, Matsui Y, Shibasaki S, et al. An alpha-adrenergic blocker titrated by self-measured blood pressure recordings lowered blood pressure and microalbuminuria in patients with morning hypertension: the Japan Morning Surge-1 Study. Journal of Hypertension. 2008;26(6):1257-65. Not CKD treatment. [pmid: 18475166].
2095 Karnik AM, Bashir R, Khan FA, et al. Renal involvement in the systemic inflammatory reaction syndrome. Renal Failure. 1998;20(1):103-16. Not CKD treatment. [pmid: 9509564].
2096 Karthik S, Lisbon A. Low-dose dopamine in the intensive care unit. Seminars in Dialysis. 2006;19(6):465-71. Not RCT or controlled trial. [pmid: 17150046].
2097 Kasiakou SK, Sermaides GJ, Michalopoulos A, et al. Continuous versus intermittent intravenous administration of antibiotics: a meta-analysis of randomised controlled trials. The Lancet Infectious Diseases. 2005;5(9):581-9. Follow-up less than 6 months. [pmid: 16122681].
2098 Kasiske BL. Questions and answers from controlled clinical trials of antihypertensive therapy in progressive renal disease. American Journal of Hypertension. 1992;5(10):778-9. Not RCT or controlled trial. [pmid: 1418845].
2099 Kasiske BL, Kalil RS, Ma JZ, et al. Effect of antihypertensive therapy on the kidney in patients with diabetes: a meta-regression analysis. Annals of Internal Medicine. 1993;118(2):129-38. Not RCT or controlled trial. [pmid: 8416309].
2100 Kasiske BL, Lakatua JD. The effects of dietary protein restriction on chronic progressive renal disease. Mineral & Electrolyte Metabolism. 1997;23(3-6):296-300. Not RCT or controlled trial. [pmid: 9387137].
2101 Kasiske BL, Lakatua JD, Ma JZ, et al. A meta-analysis of the effects of dietary protein restriction on the rate of decline in renal function. American Journal of Kidney Diseases. 1998;31(6):954-61. Not RCT or controlled trial. [pmid: 9631839].
2102 Kasiske BL, Velosa JA, Halstenson CE, et al. The effects of lovastatin in hyperlipidemic patients with the nephrotic syndrome. American Journal of Kidney Diseases. 1990;15(1):8-15. Sample size less than 50 patients. [pmid: 2294737].
2103 Kassimatis TI, Goldsmith DJA. New hope for chronic kidney disease patients after the JUPITER trial: myth or reality?. Journal of the American College of Cardiology. Aug. 3. 2010;56(6):529. Not RCT or controlled trial. [pmid: 20670770].
2104 Kassimatis TI, Konstantinopoulos PA. The role of statins in chronic kidney disease (CKD): friend or foe?. Pharmacology & Therapeutics. 2009;122(3):312-23. Not early CKD. [pmid: 19351546].
2105 Kastarinen H, Vasunta RL, Ukkola O, et al. Glomerular filtration rate is related to dipping pattern in ambulatory blood pressure monitoring--a cross-sectional population-based study. Journal of Human Hypertension. Apr. 2010;24(4):247-53. Not CKD treatment. [pmid: 19675588].
2106 Kastarinen M, Juutilainen A, Kastarinen H, et al. Risk factors for end-stage renal disease in a community-based population: 26-year follow-up of 25,821 men and women in eastern Finland. Journal of Internal Medicine. Jun. 2010;267(6):612-20. Not CKD treatment. [pmid: 20210838].
2107 Katavetin P, Eiam-Ong S, Suwanwalaikorn S. Pioglitazone reduces urinary protein and urinary transforming growth factor-beta excretion in patients with type 2 diabetes and overt nephropathy. Journal of the Medical Association of Thailand. 2006;89(2):170-7. Not RCT or controlled trial. [pmid: 16579002].
2108 Katayama K, Nomura S, Ishikawa H, et al. Comparison between valsartan and valsartan plus cilnidipine in type II diabetics with normo- and microalbuminuria. Kidney International. 2006;70(1):151-6. Not CKD treatment. [pmid: 16710356].
2109 Katayama S, Kawamori R, Iwamoto Y, et al. In half of hypertensive diabetics, co-administration of a calcium channel blocker and an angiotensin-converting enzyme inhibitor achieved a target blood pressure of <130/80 mmHg: the azelnidipine and temocapril in hypertensive patients with type 2 diabetes (ATTEST) study. Hypertension Research - Clinical & Experimental. 2008;31(8):1499-508. Not CKD treatment.
2110 Katayama Y, Haraoka J, Hirabayashi H, et al. A randomized controlled trial of hydrocortisone against hyponatremia in patients with aneurysmal subarachnoid hemorrhage. Stroke. 2007;38(8):2373-5. Not RCT or controlled trial. [pmid: 17585086].
2111 Katholi RE, Taylor GJ, McCann WP, et al. Nephrotoxicity from contrast media: attenuation with theophylline. Radiology. 1995;195(1):17-22. Not CKD treatment. [pmid: 7892462].
2112 Katholi RE, Taylor GJ, Woods WT, et al. Nephrotoxicity of nonionic low-osmolality versus ionic high-osmolality contrast media: a prospective double-blind randomized comparison in human beings. Radiology. 1993;186(1):183-7. Not CKD treatment. [pmid: 8416561].
2113 Katholi RE, Woods WT Jr., Taylor GJ, et al. Oxygen free radicals and contrast nephropathy. American Journal of Kidney Diseases. 1998;32(1):64-71. Not CKD treatment. [pmid: 9669426].
2114 Katiyar CK, Arora D, Mehrotra R, et al. Management of chronic hepatitis B with New Livfit in end stage renal disease. Indian Journal of Physiology & Pharmacology. 2005;49(1):83-8. Sample size less than 50 patients. [pmid: 15881863].
2115 Katzman PL, DiBona GF, Hokfelt B, et al. Acute renal tubular and hemodynamic effects of the calcium antagonist felodipine in healthy volunteers. Journal of the American Society of Nephrology. 1991;2(5):1000-6. Sample size less than 50 patients. [pmid: 1760535].
2116 Katzman PL, Henningsen NC, Fagher B, et al. Renal and endocrine effects of long-term converting enzyme inhibition as compared with calcium antagonism in essential hypertension. Journal of Cardiovascular Pharmacology. 1990;15(3):360-4. Sample size less than 50 patients. [pmid: 1691357].
2117 Kawamori R, Kamado K, Kamada T. Recent progress in the treatment of diabetic nephropathy: importance of strict glycemic control on the regression of diabetic nephropathy. Journal of Diabetic Complications. 1991;5(2-3):88-90. Sample size less than 50 patients. [pmid: 1770063].
2118 Kawamoto R, Kohara K, Tabara Y, et al. An association between body mass index and estimated glomerular filtration rate. Hypertension Research - Clinical & Experimental. 2008;31(8):1559-64. Not CKD treatment.
2119 Kawamoto R, Kohara K, Tabara Y, et al. An association between decreased estimated glomerular filtration rate and arterial stiffness. Internal Medicine. 2008;47(7):593-8. Not CKD treatment. [pmid: 18379142].
2120 Kay J, Chow WH, Chan TM, et al. Acetylcysteine for prevention of acute deterioration of renal function following elective coronary angiography and intervention: a randomized controlled trial. JAMA. 2003;289(5):553-8. Not CKD treatment. [pmid: 12578487].
2121 Kaya K, Oguz M, Akar AR, et al. The effect of sodium nitroprusside infusion on renal function during reperfusion period in patients undergoing coronary artery bypass grafting: a prospective randomized clinical trial. European Journal of Cardio-Thoracic Surgery. 2007;31(2):290-7. Sample size less than 50 patients. [pmid: 17174559].
2122 Kaysen GA, Gambertoglio J, Felts J, et al. Albumin synthesis, albuminuria and hyperlipemia in nephrotic patients. Kidney International. 1987;31(6):1368-76. Sample size less than 50 patients. [pmid: 3613408].
2123 Keane WF, Hirata-Dulas CA, Bullock ML, et al. Adjunctive therapy with intravenous human immunoglobulin G improves survival of patients with acute renal failure. Journal of the American Society of Nephrology. 1991;2(4):841-7. Not CKD treatment. [pmid: 1751787].
2124 Keane WF, Lyle PA. Reduction of Endpoints in NwtAIIRALs. Recent advances in management of type 2 diabetes and nephropathy: lessons from the RENAAL study. American Journal of Kidney Diseases. 2003;41(3 Suppl 1):S22-5. Not RCT or controlled trial. [pmid: 12612946].
2125 Keeley EC, McCullough PA. Coronary revascularization in patients with end-stage renal disease: risks, benefits, and optimal strategies. Reviews in Cardiovascular Medicine. 2003;4(3):125-30. Not CKD treatment. [pmid: 12949440].
2126 Keeley EC, McCullough PA. Coronary revascularization in patients with coronary artery disease and chronic kidney disease. Advances in Chronic Kidney Disease. 2004;11(3):254-60. Not CKD treatment. [pmid: 15241740].
2127 Keeton GR, Smit RvZ, Bryer A. Renal outcome of type 2 diabetes in South Africa--a 12-year follow-up study. South African Medical Journal. Suid-Afrikaanse Tydskrif Vir Geneeskunde. 2004;94(9):771-5. Not RCT or controlled trial. [pmid: 15487844].
2128 Kefer JM, Hanet CE, Boitte S, et al. Acetylcysteine, coronary procedure and prevention of contrast-induced worsening of renal function: which benefit for which patient?. Acta Cardiologica. 2003;58(6):555-60. Not relevant to key questions. [pmid: 14713182].
2129 Keilani T, Danesh FR, Schlueter WA, et al. A subdepressor low dose of ramipril lowers urinary protein excretion without increasing plasma potassium. American Journal of Kidney Diseases. 1999;33(3):450-7. Sample size less than 50 patients. [pmid: 10070908].
2130 Keilani T, Schlueter WA, Levin ML, et al. Improvement of lipid abnormalities associated with proteinuria using fosinopril, an angiotensin-converting enzyme inhibitor. Annals of Internal Medicine. 1993;118(4):246-54. Follow-up less than 6 months. [pmid: 8420442].
2131 Keithi-Reddy SR, Addabbo F, Patel TV, et al. Association of anemia and erythropoiesis stimulating agents with inflammatory biomarkers in chronic kidney disease. Kidney International. 2008;74(6):782-90. Sample size less than 50 patients. [pmid: 18547996].
2132 Keithi-Reddy SR, Singh AK. Hemoglobin target in chronic kidney disease: a pediatric perspective. Pediatric Nephrology. 2009;24(3):431-4. Sample size less than 50 patients. [pmid: 18604563].
2133 Kekec Z, Yilmaz U, Sozuer E. The effectiveness of tenoxicam vs isosorbide dinitrate plus tenoxicam in the treatment of acute renal colic. BJU International. 2000;85(7):783-5. Not early CKD. [pmid: 10792152].
2134 Kell MJ. Utilization of plasma and urine methadone concentrations to optimize treatment in maintenance clinics: I. Measurement techniques for a clinical setting. Journal of Addictive Diseases. 1994;13(1):5-26. Not RCT or controlled trial. [pmid: 8018740].
2135 Kellum JA. Prophylactic fenoldopam for renal protection? No, thank you, not for me--not yet at least. Critical Care Medicine. 2005;33(11):2681-3. Not RCT or controlled trial. [pmid: 16276198].
2136 Kellum JA, Leblanc M, Venkataraman R. Acute renal failure. Clinical Evidence. 2002;(7):757-74. Not RCT or controlled trial. [pmid: 12230702].
2137 Kelly AM, Dwamena B, Cronin P, et al. Meta-analysis: effectiveness of drugs for preventing contrast-induced nephropathy. [Erratum appears in Ann Intern Med. 2008 Aug 5;149(3):219]. Annals of Internal Medicine. 2008;148(4):284-94. Not CKD treatment. [pmid: 18283206].
2138 Kelly DJ, Edgley AJ, Zhang Y, et al. Protein kinase C-beta inhibition attenuates the progression of nephropathy in non-diabetic kidney disease. Nephrology Dialysis Transplantation. 2009;24(6):1782-90. Not CKD treatment.
2139 Keltai M, Tonelli M, Mann JFE, et al. Renal function and outcomes in acute coronary syndrome: impact of clopidogrel. European Journal of Cardiovascular Prevention & Rehabilitation. 2007;14(2):312-8. Sample size less than 50 patients. [pmid: 17446813].
2140 Kemp G, Rose P, Lurain J, et al. Amifostine pretreatment for protection against cyclophosphamide-induced and cisplatin-induced toxicities: results of a randomized control trial in patients with advanced ovarian cancer. Journal of Clinical Oncology. 1996;14(7):2101-12. Not CKD treatment. [pmid: 8683243].
2141 Kennedy C, Rickards D, Lee S, et al. A double-blind study comparing the efficiency, tolerance and renal effects of iopromide and iopamidol. British Journal of Radiology. 1988;61(724):288-93. Not relevant to key questions. [pmid: 3285943].
2142 Kennedy L, Solano MP, Meneghini L, et al. Anti-glycation and anti-albuminuric effects of GLY-230 in human diabetes. American Journal of Nephrology. 2010;31(2):110-6. Not CKD treatment. [pmid: 19923796].
2143 Kenny GN. Potential renal, haematological and allergic adverse effects associated with nonsteroidal anti-inflammatory drugs. Drugs. 1992;44. Suppl 5. discussion 7. Not CKD treatment.
2144 Kent DM, Jafar TH, Hayward RA, et al. Progression risk, urinary protein excretion, and treatment effects of angiotensin-converting enzyme inhibitors in nondiabetic kidney disease. Journal of the American Society of Nephrology. 2007;18(6):1959-65. Not RCT or controlled trial. [pmid: 17475813].
2145 Kentsch M, Ludwig D, Drummer C, et al. Haemodynamic and renal effects of urodilatin bolus injections in patients with congestive heart failure. European Journal of Clinical Investigation. 1992;22(10):662-9. Sample size less than 50 patients. [pmid: 1333960].
2146 Kentsch M, Ludwig D, Drummer C, et al. Haemodynamic and renal effects of urodilatin in healthy volunteers. European Journal of Clinical Investigation. 1992;22(5):319-25. Sample size less than 50 patients. [pmid: 1317296].
2147 Keown PA. Quality of life in end-stage renal disease patients during recombinant human erythropoietin therapy. The Canadian Erythropoietin Study Group. Contributions to Nephrology. 1991;88:81-6. discussion 7-9. Not early CKD. [pmid: 2040199].
2148 Kerr E, Craig D, McGuinness B, et al. Reduced estimated glomerular filtration rate in Alzheimer's disease. International Journal of Geriatric Psychiatry. Sep. 2009;24(9):927-32. Not CKD treatment. [pmid: 19194887].
2149 Kerstens MN, Buter H, Navis GJ, et al. 11beta-hydroxysteroid dehydrogenase activity in proteinuric patients and the effect of angiotensin-II receptor blockade. European Journal of Clinical Investigation. 2002;32(7):513-8. Sample size less than 50 patients. [pmid: 12153552].
2150 Kerstetter JE, O'Brien KO, Insogna KL. Dietary protein affects intestinal calcium absorption. American Journal of Clinical Nutrition. 1998;68(4):859-65. Sample size less than 50 patients. [pmid: 9771863].
2151 Kestenbaum B, Gillen DL, Sherrard DJ, et al. Calcium channel blocker use and mortality among patients with end-stage renal disease. Kidney International. 2002;61(6):2157-64. Not early CKD. [pmid: 12028456].
2152 Ketelhut R, Bramlage P. Candesartan cilexetil/hydrochlorothiazide treatment in high-risk patients with type 2 diabetes mellitus and microalbuminuria: the CHILI T2D study. Clinical Drug Investigation. 2010;30(5):301-11. Not RCT or controlled trial. [pmid: 20384386].
2153 Khajehdehi P, Roozbeh J, Mostafavi H. A comparative randomized and placebo-controlled short-term trial of aspirin and dipyridamole for overt type-2 diabetic nephropathy. Scandinavian Journal of Urology & Nephrology. 2002;36(2):145-8. Follow-up less than 6 months. [pmid: 12028688].
2154 Khan DA, Ahmad TM, Qureshil AH, et al. Assessment of proteinuria by using protein: creatinine index in random urine sample. JPMA - Journal of the Pakistan Medical Association. 2005;55(10):428-31. Not relevant to key questions.
2155 Khan NA, Campbell NR, Frost SD, et al. Risk of intraoperative hypotension with loop diuretics: a randomized controlled trial. American Journal of Medicine. Nov. 2010;123(11):1059.e1-8. Not CKD treatment. [pmid: 21035594].
2156 Khan NA, Hemmelgarn BR, Tonelli M, et al. Prognostic value of troponin T and I among asymptomatic patients with end-stage renal disease: a meta-analysis. Circulation. 2005;112(20):3088-96. Sample size less than 50 patients. [pmid: 16286604].
2157 Khan NA, Ma I, Thompson CR, et al. Kidney function and mortality among patients with left ventricular systolic dysfunction. Journal of the American Society of Nephrology. 2006;17(1):244-53. Not relevant to key questions. [pmid: 16291840].
2158 Khan NA, McAlister FA, Rabkin SW, et al. The 2006 Canadian Hypertension Education Program recommendations for the management of hypertension: Part II - Therapy. Canadian Journal of Cardiology. 2006;22(7):583-93. Follow-up less than 6 months. [pmid: 16755313].
2159 Khan NA, Susa D, van den Berg JW, et al. Amelioration of renal ischaemia-reperfusion injury by synthetic oligopeptides related to human chorionic gonadotropin. Nephrology Dialysis Transplantation. 2009;24(9):2701-8. Not CKD treatment.
2160 Khandekar JD, Elson PJ, DeWys WD, et al. Comparative activity and toxicity of cis-diamminedichloroplatinum (DDP) and a combination of doxorubicin, cyclophosphamide, and DDP in disseminated transitional cell carcinomas of the urinary tract. Journal of Clinical Oncology. 1985;3(4):539-45. Follow-up less than 6 months. [pmid: 3884746].
2161 Kharasch ED, Frink EJ Jr., Artru A, et al. Long-duration low-flow sevoflurane and isoflurane effects on postoperative renal and hepatic function. Anesthesia & Analgesia. 2001;93(6):1511-20. Not CKD treatment. [pmid: 11726433].
2162 Kharasch ED, Frink EJ Jr., Zager R, et al. Assessment of low-flow sevoflurane and isoflurane effects on renal function using sensitive markers of tubular toxicity. Anesthesiology. 1997;86(6):1238-53. Not CKD treatment. [pmid: 9197292].
2163 Khoury Z, Schlicht JR, Como J, et al. The effect of prophylactic nifedipine on renal function in patients administered contrast media. Pharmacotherapy. 1995;15(1):59-65. Sample size less than 50 patients. [pmid: 7739947].
2164 Kiberd BA. Atorvastatin has no beneficial effect on cardiovascular outcomes in patients with advanced chronic kidney disease. Nature Clinical Practice Nephrology. 2006;2(7):354-5. Not RCT or controlled trial.
2165 Kielstein JT, Salpeter SR, Bode-Boeger SM, et al. Symmetric dimethylarginine (SDMA) as endogenous marker of renal function--a meta-analysis. Nephrology Dialysis Transplantation. 2006;21(9):2446-51. Follow-up less than 6 months.
2166 Kielstein JT, Simmel S, Bode-Boger SM, et al. Subpressor dose asymmetric dimethylarginine modulates renal function in humans through nitric oxide synthase inhibition. Kidney & Blood Pressure Research. 2004;27(3):143-7. Not early CKD. [pmid: 15192321].
2167 Kim BJ, Sung KC, Kim BS, et al. Effect of N-acetylcysteine on cystatin C-based renal function after elective coronary angiography (ENABLE Study): a prospective, randomized trial. International Journal of Cardiology. Feb. 4. 2010;138(3):239-45. Follow-up less than 6 months. [pmid: 18793808].
2168 Kim H, Rosenberg SA, Steinberg SM, et al. A randomized double-blinded comparison of the antiemetic efficacy of ondansetron and droperidol in patients receiving high-dose interleukin-2. Journal of Immunotherapy with Emphasis on Tumor Immunology. 1994;16(1):60-5. Not CKD treatment. [pmid: 8081560].
2169 Kim JY, Lee KC, Kim HS, et al. Effect of diltiazem on kidney function during laparoscopic surgery. Surgical Endoscopy. 2009;23(8):1785-90. Not CKD treatment. [pmid: 19067065].
2170 Kim KH, Lee MS, Kang KW, et al. Role of acupressure in symptom management in patients with end-stage renal disease: a systematic review. Journal of Palliative Medicine. Jul. 2010;13(7):885-92. Not CKD treatment. [pmid: 20636160].
2171 Kim KS, Fan WH, Kim YD, et al. Effectiveness of open-label losartan/hydrochlorothiazide combination therapy in Asian patients with hypertension not controlled with ACE inhibitor or ARB monotherapy. Hypertension Research - Clinical & Experimental. 2009;32(6):520-6. Not CKD treatment.
2172 Kimel M, Leidy NK, Mannix S, et al. Does epoetin alfa improve health-related quality of life in chronically ill patients with anemia? Summary of trials of cancer, HIV/AIDS, and chronic kidney disease. Value in Health. 2008;11(1):57-75. Follow-up less than 6 months. [pmid: 18237361].
2173 Kimmel M, Butscheid M, Brenner S, et al. Improved estimation of glomerular filtration rate by serum cystatin C in preventing contrast induced nephropathy by N-acetylcysteine or zinc--preliminary results. Nephrology Dialysis Transplantation. 2008;23(4):1241-5. Not RCT or controlled trial.
2174 Kimmel PL, Barisoni L, Kopp JB. Pathogenesis and treatment of HIV-associated renal diseases: lessons from clinical and animal studies, molecular pathologic correlations, and genetic investigations. Annals of Internal Medicine. 2003;139(3):214-26. Not CKD treatment. [pmid: 12899589].
2175 Kimmelstiel CD, Perrone R, Kilcoyne L, et al. Effects of renal neutral endopeptidase inhibition on sodium excretion, renal hemodynamics and neurohormonal activation in patients with congestive heart failure. Cardiology. 1996;87(1):46-53. Sample size less than 50 patients. [pmid: 8631044].
2176 Kimura G, Uzu T, Nakamura S, et al. High sodium sensitivity and glomerular hypertension/hyperfiltration in primary aldosteronism. Journal of Hypertension. 1996;14(12):1463-8. Sample size less than 50 patients. [pmid: 8986931].
2177 Kinbara T, Hayano T, Ohtani N, et al. Efficacy of N-acetylcysteine and aminophylline in preventing contrast-induced nephropathy. Journal of Cardiology. Mar. 2010;55(2):174-9. Not CKD treatment. [pmid: 20206069].
2178 Kincaid-Smith P, Fairley K, Packham D. Randomized controlled crossover study of the effect on proteinuria and blood pressure of adding an angiotensin II receptor antagonist to an angiotensin converting enzyme inhibitor in normotensive patients with chronic renal disease and proteinuria. [Erratum appears in Nephrol Dial Transplant 2002 Jun;17(6):1153]. Nephrology Dialysis Transplantation. 2002;17(4):597-601. Follow-up less than 6 months.
2179 Kincaid-Smith P, Fairley KF, Farish S, et al. Reduction of proteinuria by rosiglitazone in non-diabetic renal disease. Nephrology. 2008;13(1):58-62. Sample size less than 50 patients. [pmid: 18199105].
2180 Kincaid-Smith P, Fairley KF, Packham D. Dual blockade of the renin-angiotensin system compared with a 50% increase in the dose of angiotensin-converting enzyme inhibitor: effects on proteinuria and blood pressure. Nephrology Dialysis Transplantation. 2004;19(9):2272-4. Not CKD treatment.
2181 Kindler J, Schunkert H, Gassmann M, et al. Therapeutic efficacy and tolerance of ramipril in hypertensive patients with renal failure. Journal of Cardiovascular Pharmacology. Suppl 3. 1989;13:S55-8. Sample size less than 50 patients. [pmid: 2474105].
2182 Kini AA, Sharma SK. Managing the high-risk patient: experience with fenoldopam, a selective dopamine receptor agonist, in prevention of radiocontrast nephropathy during percutaneous coronary intervention. Reviews in Cardiovascular Medicine. Suppl 1. 2001;2:S19-25. Not CKD treatment. [pmid: 12439364].
2183 Kinoshita Y, Yahata K, Yoshioka T, et al. Long-term renal preservation after brain death maintained with vasopressin and epinephrine. Transplant International. 1990;3(1):15-8. Sample size less than 50 patients. [pmid: 2369475].
2184 Kinouchi K, Ichihara A, Sakoda M, et al. Safety and benefits of a tablet combining losartan and hydrochlorothiazide in Japanese diabetic patients with hypertension. Hypertension Research - Clinical & Experimental. 2009;32(12):1143-7. Sample size less than 50 patients.
2185 Kinouchi K, Ichihara A, Sakoda M, et al. Effects of telmisartan on arterial stiffness assessed by the cardio-ankle vascular index in hypertensive patients. Kidney & Blood Pressure Research. 2010;33(4):304-12. Not CKD treatment. [pmid: 20664284].
2186 Kirch W, Stroemer K, Hoogkamer JF, et al. The influence of prostaglandin inhibition by indomethacin on blood pressure and renal function in hypertensive patients treated with cilazapril. British Journal of Clinical Pharmacology. Suppl 2. 1989;27:297S-301S. Sample size less than 50 patients. [pmid: 2527542].
2187 Kirchhoff KT, Hammes BJ, Kehl KA, et al. Effect of a disease-specific planning intervention on surrogate understanding of patient goals for future medical treatment. Journal of the American Geriatrics Society. Jul. 2010;58(7):1233-40. Not CKD treatment. [pmid: 20649686].
2188 Kirsten R, Heintz B, Nelson K, et al. Magnesium pyridoxal 5-phosphate glutamate reduces hyperlipidaemia in patients with chronic renal insufficiency. European Journal of Clinical Pharmacology. 1988;34(2):133-7. Sample size less than 50 patients. [pmid: 3383985].
2189 Kitazato H, Fujita H, Shimotomai T, et al. Effects of chronic intake of vegetable protein added to animal or fish protein on renal hemodynamics. Nephron. 2002;90(1):31-6. Not early CKD. [pmid: 11744802].
2190 Kiya Y, Miura SI, Fujino M, et al. Clinical and pharmacotherapeutic relevance of the double-chain domain of the angiotensin II type 1 receptor blocker olmesartan. Clinical & Experimental Hypertension. Jan. 2010;32(2):129-36. Not CKD treatment. [pmid: 20374187].
2191 Kjaersgaard P, Jakobsen JA, Nossen JO, et al. Determination of glomerular filtration rate with Visipaque in patients with severely reduced renal function. European Radiology. 1996;6(6):865-71. Sample size less than 50 patients. [pmid: 8972324].
2192 Klag MJ, Whelton PK, Randall BL, et al. End-stage renal disease in African-American and white men. 16-year MRFIT findings. JAMA. 1997;277(16):1293-8. Not RCT or controlled trial. [pmid: 9109467].
2193 Klahr S. Primary and secondary results of the modification of diet in renal disease study. Mineral & Electrolyte Metabolism. 1996;22(1-3):138-42. Not relevant to key questions. [pmid: 8676806].
2194 Klahr S. Prevention of progression of nephropathy. Nephrology Dialysis Transplantation. Suppl 2. 1997;12:63-6. Not RCT or controlled trial.
2195 Kleber FX. Socioeconomic aspects of ACE inhibition in the secondary prevention in cardiovascular diseases. American Journal of Hypertension. 1994;7(9 Pt 2):112S-6S. Not CKD treatment. [pmid: 7818836].
2196 Klein F, Juhl B, Christiansen JS. Unchanged renal haemodynamics following high dose ascorbic acid administration in normoalbuminuric IDDM patients. Scandinavian Journal of Clinical & Laboratory Investigation. 1995;55(1):53-9. Follow-up less than 6 months. [pmid: 7624737].
2197 Klein H, Abassi Z, Keiser HR. Effects of angiotensin II and phenylephrine on urinary endothelin in normal female volunteers. Metabolism: Clinical & Experimental. 1995;44(1):115-8. Follow-up less than 6 months. [pmid: 7854155].
2198 Klein IHHT, Abrahams A, van Ede T, et al. Different effects of tacrolimus and cyclosporine on renal hemodynamics and blood pressure in healthy subjects. Transplantation. 2002;73(5):732-6. Not early CKD. [pmid: 11907418].
2199 Klein IHHT, Ligtenberg G, Oey PL, et al. Enalapril and losartan reduce sympathetic hyperactivity in patients with chronic renal failure. Journal of the American Society of Nephrology. 2003;14(2):425-30. Sample size less than 50 patients. [pmid: 12538743].
2200 Klein L, Massie BM, Leimberger JD, et al. Admission or changes in renal function during hospitalization for worsening heart failure predict postdischarge survival: results from the Outcomes of a Prospective Trial of Intravenous Milrinone for Exacerbations of Chronic Heart Failure (OPTIME-CHF). Circulation: Heart Failure. 2008;1(1):25-33. Not RCT or controlled trial. [pmid: 19808267].
2201 Klein R. Is intensive management of blood pressure to prevent visual loss in persons with type 2 diabetes indicated?. Archives of Ophthalmology. 2004;122(11):1707-9. Not CKD treatment. [pmid: 15534135].
2202 Klein R, Klein BE, Moss SE, et al. Blood pressure and hypertension in diabetes. American Journal of Epidemiology. 1985;122(1):75-89. Not RCT or controlled trial. [pmid: 4014203].
2203 Klein R, Moss SE, Sinaiko AR, et al. The relation of ambulatory blood pressure and pulse rate to retinopathy in type 1 diabetes mellitus: the renin-angiotensin system study. Ophthalmology. 2006;113(12):2231-6. Not CKD treatment. [pmid: 16996597].
2204 Kloke HJ, Huysmans FT, Wetzels JF, et al. Antihypertensive effects of nitrendipine and cilazapril alone, and in combination in hypertensive patients with chronic renal failure. British Journal of Clinical Pharmacology. Suppl 2. 1989;27:289S-96S. Sample size less than 50 patients. [pmid: 2527541].
2205 Kloke HJ, Wetzels JF, van Hamersvelt HW, et al. Effects of nitrendipine and cilazapril on renal hemodynamics and albuminuria in hypertensive patients with chronic renal failure. Journal of Cardiovascular Pharmacology. 1990;16(6):924-30. Follow-up less than 6 months. [pmid: 1704985].
2206 Klotz U, Arvela P, Rosenkranz B. Famotidine, a new H2-receptor antagonist, does not affect hepatic elimination of diazepam or tubular secretion of procainamide. European Journal of Clinical Pharmacology. 1985;28(6):671-5. Sample size less than 50 patients. [pmid: 2866097].
2207 Klow NE, Levorstad K, Berg KJ, et al. Iodixanol in cardioangiography in patients with coronary artery disease. Tolerability, cardiac and renal effects. Acta Radiologica. 1993;34(1):72-7. Not CKD treatment. [pmid: 8427753].
2208 Klutsch K, Grosswendt J, Haecker W. Single dose comparison of torasemide and furosemide in patients with advanced renal failure. Arzneimittel-Forschung. 1988;38(1A):200-4. Not relevant to key questions. [pmid: 3285834].
2209 Knauf H, Bailey MA, Hasenfuss G, et al. The influence of cardiovascular and antiinflammatory drugs on thiazide-induced hemodynamic and saluretic effects. European Journal of Clinical Pharmacology. 2006;62(11):885-92. Not relevant to key questions. [pmid: 16964522].
2210 Knauf H, Mutschler E. Diuretic effectiveness of hydrochlorothiazide and furosemide alone and in combination in chronic renal failure. Journal of Cardiovascular Pharmacology. 1995;26(3):394-400. Sample size less than 50 patients. [pmid: 8583780].
2211 Knauf H, Wenk E, Scholmerich J, et al. Prediction of diuretic mobilization of cirrhotic ascites by pretreatment fractional sodium excretion. Klinische Wochenschrift. 1990;68(11):545-51. Not CKD treatment. [pmid: 2198378].
2212 Knight EL, Glynn RJ, McIntyre KM, et al. Predictors of decreased renal function in patients with heart failure during angiotensin-converting enzyme inhibitor therapy: results from the studies of left ventricular dysfunction (SOLVD). American Heart Journal. 1999;138(5 Pt 1):849-55. Not CKD treatment. [pmid: 10539815].
2213 Knudsen ST, Andersen NH, Poulsen SH, et al. Pulse pressure lowering effect of dual blockade with candesartan and lisinopril vs. high-dose ACE inhibition in hypertensive type 2 diabetic subjects: a CALM II study post-hoc analysis. American Journal of Hypertension. 2008;21(2):172-6. Not CKD treatment. [pmid: 18188164].
2214 Knupp CA, Hak LJ, Coakley DF, et al. Disposition of didanosine in HIV-seropositive patients with normal renal function or chronic renal failure: influence of hemodialysis and continuous ambulatory peritoneal dialysis. Clinical Pharmacology & Therapeutics. 1996;60(5):535-42. Sample size less than 50 patients. [pmid: 8941026].
2215 Ko DT, Juurlink DN, Mamdani MM, et al. Appropriateness of spironolactone prescribing in heart failure patients: a population-based study. Journal of Cardiac Failure. 2006;12(3):205-10. Not relevant to key questions. [pmid: 16624686].
2216 Ko GTC, Tsang CC, Chan HCK. Stabilization and regression of albuminuria in Chinese patients with type 2 diabetes: a one-year randomized study of valsartan versus enalapril. Advances in Therapy. 2005;22(2):155-62. Sample size less than 50 patients. [pmid: 16020405].
2217 Ko JS, Gwak MS, Choi SJ, et al. The effects of desflurane and propofol-remifentanil on postoperative hepatic and renal functions after right hepatectomy in liver donors. Liver Transplantation. 2008;14(8):1150-8. Not early CKD. [pmid: 18668648].
2218 Ko JS, Gwak MS, Choi SJ, et al. The effects of desflurane and sevoflurane on hepatic and renal functions after right hepatectomy in living donors*. Transplant International. Jul. 2010;23(7):736-44. Not CKD treatment. [pmid: 20102552].
2219 Kobashigawa JA, Meiser BM. Review of major clinical trials with mycophenolate mofetil in cardiac transplantation. Transplantation. 2005;80(2 Suppl):S235-43. Follow-up less than 6 months. [pmid: 16251856].
2220 Kobayashi M, To H, Tokue A, et al. Cisplatin-induced vomiting depends on circadian timing. Chronobiology International. 2001;18(5):851-63. Not early CKD. [pmid: 11763992].
2221 Kobayashi M, Wood PA, Hrushesky WJM. Circadian chemotherapy for gynecological and genitourinary cancers. Chronobiology International. 2002;19(1):237-51. Not early CKD. [pmid: 11962679].
2222 Kobayashi S. Applications of LDL-apheresis in nephrology. Clinical & Experimental Nephrology. 2008;12(1):9-15. Not relevant to key questions. [pmid: 18175056].
2223 Kober A, Dobrovits M, Djavan B, et al. Local active warming: an effective treatment for pain, anxiety and nausea caused by renal colic. Journal of Urology. 2003;170(3):741-4. Not CKD treatment. [pmid: 12913687].
2224 Kobori H, Urushihara M, Xu JH, et al. Urinary angiotensinogen is correlated with blood pressure in men (Bogalusa Heart Study). Journal of Hypertension. Jul. 2010;28(7):1422-8. Not CKD treatment. [pmid: 20375906].
2225 Kocakulak M, Askin G, Kucukaksu S, et al. Pulsatile flow improves renal function in high-risk cardiac operations. Blood Purification. 2005;23(4):263-7. Not relevant to key questions. [pmid: 15838160].
2226 Kocakulak M, Kucukaksu S, Piskin E. Pulsatile roller pump perfusion is safe in high risk patients. International Journal of Artificial Organs. 2004;27(5):433-9. Not CKD treatment. [pmid: 15202823].
2227 Koch G, Fransson L, Karlegard L, et al. Responses of glomerular filtration, renal blood flow and salt-water handling to acute cardioselective and non-selective beta-adrenoceptor blockade in essential hypertension. European Journal of Clinical Pharmacology. 1989;36(4):343-5. Sample size less than 50 patients. [pmid: 2567670].
2228 Koch JA, Plum J, Grabensee B, et al. Prostaglandin E1 (PGE1)--prophylaxis against radiocontrast-induced nephrotoxicity in patients with pre-existing renal dysfunction. PGE1 Study Group. Nephrology Dialysis Transplantation. Suppl 4. 1999;14:15. Follow-up less than 6 months.
2229 Koch JA, Plum J, Grabensee B, et al. Prostaglandin E1: a new agent for the prevention of renal dysfunction in high risk patients caused by radiocontrast media? PGE1 Study Group. Nephrology Dialysis Transplantation. 2000;15(1):43-9. Not CKD treatment.
2230 Koch KM, Koene RA, Messinger D, et al. The use of epoetin beta in anemic predialysis patients with chronic renal failure. [Erratum appears in Clin Nephrol 1995 Oct; 44(4):278]. Clinical Nephrology. 1995;44(3):201-8. Not RCT or controlled trial. [pmid: 8556837].
2231 Koenig K, Padalino P, Alexandrides G, et al. Bioavailability of potassium and magnesium, and citraturic response from potassium-magnesium citrate. Journal of Urology. 1991;145(2):330-4. Not CKD treatment. [pmid: 1988724].
2232 Kohlmann O Jr., Roca-Cusachs A, Laurent S, et al. Fixed-dose manidipine/delapril versus losartan/hydrochlorothiazide in hypertensive patients with type 2 diabetes and microalbuminuria. Advances in Therapy. 2009;26(3):313-24. Not RCT or controlled trial. [pmid: 19330493].
2233 Kohzuki M, Yasujima M, Kanazawa M, et al. Effects of recombinant human erythropoietin on blood pressure and renal function in SHR with chronic renal failure. Clinical & Experimental Pharmacology & Physiology - Supplement. 1995;22(1):S165-6. Not RCT or controlled trial. [pmid: 9072339].
2234 Kojima S, Shida M, Yokoyama H. Comparison between cilnidipine and amlodipine besilate with respect to proteinuria in hypertensive patients with renal diseases. Hypertension Research - Clinical & Experimental. 2004;27(6):379-85. Not early CKD.
2235 Kokubo Y, Nakamura S, Okamura T, et al. Relationship between blood pressure category and incidence of stroke and myocardial infarction in an urban Japanese population with and without chronic kidney disease: the Suita Study. Stroke. 2009;40(8):2674-9. Not RCT or controlled trial. [pmid: 19478215].
2236 Koller-Strametz J, Wolzt M, Fuchs C, et al. Renal hemodynamic effects of L-arginine and sodium nitroprusside in heart transplant recipients. Kidney International. 1999;55(5):1871-7. Sample size less than 50 patients. [pmid: 10231449].
2237 Kolonko A, Wiecek A, Kokot F. The nonselective adenosine antagonist theophylline does prevent renal dysfunction induced by radiographic contrast agents. Journal of Nephrology. 1998;11(3):151-6. Not CKD treatment. [pmid: 9650124].
2238 Komajda M, Genevray B, Grosgogeat Y. Long-term experience with tertatolol in hypertension. American Journal of Nephrology. Suppl 2. 1986;6:106-12. Not relevant to key questions. [pmid: 2879465].
2239 Komajda M, Lutiger B, Madeira H, et al. Tolerability of carvedilol and ACE-Inhibition in mild heart failure. Results of CARMEN (Carvedilol ACE-Inhibitor Remodelling Mild CHF EvaluatioN). European Journal of Heart Failure. 2004;6(4):467-75. Not adult population. [pmid: 15182773].
2240 Komajda M, Wimart MC. Angiotensin converting enzyme inhibition: from viper to patient. Heart. Suppl 1. 2000;84:i11-4. discussion i50. Not CKD treatment. [pmid: 10956312].
2241 Komenda P, Zalunardo N, Burnett S, et al. Conservative outpatient renoprotective protocol in patients with low GFR undergoing contrast angiography: a case series. Clinical & Experimental Nephrology. 2007;11(3):209-13. Not relevant to key questions. [pmid: 17891347].
2242 Komers R, Komersova K, Kazdova L, et al. Effect of ACE inhibition and angiotensin AT1 receptor blockade on renal and blood pressure response to L-arginine in humans. Journal of Hypertension. 2000;18(1):51-9. Sample size less than 50 patients. [pmid: 10678543].
2243 Komers R, Simkova R, Kazdova L, et al. Effects of ACE inhibition and AT1-receptor blockade on haemodynamic responses to L-arginine in Type 1 diabetes. Journal of the Renin-Angiotensin-Aldosterone System. 2004;5(1):33-8. Not relevant to key questions. [pmid: 15136972].
2244 Komisarof JA, Gilkey GM, Peters DM, et al. N-acetylcysteine for patients with prolonged hypotension as prophylaxis for acute renal failure (NEPHRON). Critical Care Medicine. 2007;35(2):435-41. Not CKD treatment. [pmid: 17205018].
2245 Kong KL, Tyler JE, Willatts SM, et al. Isoflurane sedation for patients undergoing mechanical ventilation: metabolism to inorganic fluoride and renal effects. British Journal of Anaesthesia. 1990;64(2):159-62. Not CKD treatment. [pmid: 2317417].
2246 Konishi K, Nakano S, Tsuda Si, et al. AST-120 (Kremezin) initiated in early stage chronic kidney disease stunts the progression of renal dysfunction in type 2 diabetic subjects. Diabetes Research & Clinical Practice. 2008;81(3):310-5. Not CKD treatment. [pmid: 18550198].
2247 Kontessis P, Jones S, Dodds R, et al. Renal, metabolic and hormonal responses to ingestion of animal and vegetable proteins. Kidney International. 1990;38(1):136-44. Sample size less than 50 patients. [pmid: 2166857].
2248 Kontessis PA, Bossinakou I, Sarika L, et al. Renal, metabolic, and hormonal responses to proteins of different origin in normotensive, nonproteinuric type I diabetic patients. Diabetes Care. 1995;18(9):1233. Follow-up less than 6 months. [pmid: 8612436].
2249 Kontessis PS, Jones SL, Barrow SE, et al. Effect of selective inhibition of thromboxane synthesis on renal function in diabetic nephropathy. Journal of Laboratory & Clinical Medicine. 1993;121(3):415-23. Sample size less than 50 patients. [pmid: 8445289].
2250 Kooienga L, Fried L, Scragg R, et al. The effect of combined calcium and vitamin D3 supplementation on serum intact parathyroid hormone in moderate CKD. American Journal of Kidney Diseases. 2009;53(3):408-16. Not CKD treatment. [pmid: 19185400].
2251 Kooman JP, Daemen MJ, Wijnen R, et al. Morphological changes of the venous system in uremic patients. A histopathologic study. Nephron. 1995;69(4):454-8. Sample size less than 50 patients. [pmid: 7777112].
2252 Koopmans PP, Thien T, Thomas CM, et al. The effects of sulindac and indomethacin on the anti-hypertensive and diuretic action of hydrochlorothiazide in patients with mild to moderate essential hypertension. British Journal of Clinical Pharmacology. 1986;21(4):417-23. Sample size less than 50 patients. [pmid: 3518773].
2253 Kopf D, Schmitz H, Beyer J, et al. A double-blind trial of perindopril and nitrendipine in incipient diabetic nephropathy. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2001;14(5):245-52. Sample size less than 50 patients.
2254 Koppert W, Frotsch K, Huzurudin N, et al. The effects of paracetamol and parecoxib on kidney function in elderly patients undergoing orthopedic surgery. Anesthesia & Analgesia. 2006;103(5):1170-6. Not early CKD. [pmid: 17056950].
2255 Kopple JD, Berg R, Houser H, et al. Nutritional status of patients with different levels of chronic renal insufficiency. Modification of Diet in Renal Disease (MDRD) Study Group. Kidney International - Supplement. 1989;27:S184-94. Not relevant to key questions. [pmid: 2636655].
2256 Kopple JD, Greene T, Chumlea WC, et al. Relationship between nutritional status and the glomerular filtration rate: results from the MDRD study. Kidney International. 2000;57(4):1688-703. Not early CKD. [pmid: 10760105].
2257 Kopple JD, Kalantar-Zadeh K, Mehrotra R. Risks of chronic metabolic acidosis in patients with chronic kidney disease. Kidney International - Supplement. 2005;(95):S21-7. Not relevant to key questions. [pmid: 15882309].
2258 Koretz RL. Does nutritional intervention in protein-energy malnutrition improve morbidity or mortality?. Journal of Renal Nutrition. 1999;9(3):119-21. Not RCT or controlled trial. [pmid: 10431028].
2259 Korkor AB, Bretzmann C. Effect of fish oil on vitamin D absorption. American Journal of Kidney Diseases. 2009;53(2):356. Not CKD treatment. [pmid: 19166803].
2260 Kossmann S, Magner-Krezel Z, Sobieraj R, et al. The assessment of nephrotoxic effect of organophosphorous pesticides based on the determination of the activity of some selected enzymes in urine. Przeglad Lekarski. 1997;54(10):707-11. Not RCT or controlled trial. [pmid: 9478090].
2261 Kostapanos MS, Milionis HJ, Saougos VG, et al. Dose-dependent effect of rosuvastatin treatment on urinary protein excretion. Journal of Cardiovascular Pharmacology & Therapeutics. 2007;12(4):292-7. Not CKD treatment. [pmid: 18172223].
2262 Kotlyar E, Keogh AM, Thavapalachandran S, et al. Prehydration alone is sufficient to prevent contrast-induced nephropathy after day-only angiography procedures--a randomised controlled trial. Heart, Lung & Circulation. 2005;14(4):245-51. Not relevant to key questions.
2263 Koufaki P, Mercer TH, Naish PF. Effects of exercise training on aerobic and functional capacity of end-stage renal disease patients. Clinical Physiology & Functional Imaging. 2002;22(2):115-24. Not early CKD. [pmid: 12005153].
2264 Kovesdy CP, Kalantar-Zadeh K. Why is protein-energy wasting associated with mortality in chronic kidney disease?. Seminars in Nephrology. 2009;29(1):3-14. Not CKD treatment. [pmid: 19121469].
2265 Kowey PR, Dickson TZ, Zhang Z, et al. Losartan and end-organ protection--lessons from the RENAAL study. Clinical Cardiology. 2005;28(3):136-42. Not relevant to key questions. [pmid: 15813620].
2266 Krairittichai U, Chaisuvannarat V. Effects of dual blockade of renin-angiotensin system in type 2 diabetes mellitus patients with diabetic nephropathy. Journal of the Medical Association of Thailand. 2009;92(5):611-7. Follow-up less than 6 months. [pmid: 19459520].
2267 Kramer BK, Preuner J, Ebenburger A, et al. Lack of renoprotective effect of theophylline during aortocoronary bypass surgery. Nephrology Dialysis Transplantation. 2002;17(5):910-5. Not early CKD.
2268 Kramer H. The National Kidney Foundation's Kidney Disease Outcomes Quality Initiative (KDOQI) Grant Initiative: moving clinical practice forward. American Journal of Kidney Diseases. Mar. 2010;55(3):411-4. Not RCT or controlled trial. [pmid: 20060632].
2269 Kramer HJ, Uhl W, Ladstetter B, et al. Influence of asimadoline, a new kappa-opioid receptor agonist, on tubular water absorption and vasopressin secretion in man. British Journal of Clinical Pharmacology. 2000;50(3):227-35. Not early CKD. [pmid: 10971307].
2270 Krantz SB. Review of patients' responses to epoetin alfa therapy. Pharmacotherapy. 1990;10(2 (Pt 2)):15S-21S. Not relevant to key questions. [pmid: 2189124].
2271 Krasuski RA, Beard BM, Geoghagan JD, et al. Optimal timing of hydration to erase contrast-associated nephropathy: the OTHER CAN study. Journal of Invasive Cardiology. 2003;15(12):699-702. Not CKD treatment. [pmid: 14660821].
2272 Krekels MM, Spiering W, Schaper NC, et al. Dissociation between the renal effects of angiotensin I and II in sodium-restricted normal subjects. Cardiovascular Research. 1998;38(1):215-20. Sample size less than 50 patients. [pmid: 9683924].
2273 Krempf M, Ranganathan S, Remy JP, et al. Effect of long-acting somatostatin analog (SMS 201-995) on high glomerular filtration rate in insulin dependent diabetic patients. International Journal of Clinical Pharmacology, Therapy, & Toxicology. 1990;28(7):309-11. Sample size less than 50 patients.
2274 Krespi PG, Makris TK, Hatzizacharias AN, et al. Moxonidine effect on microalbuminuria, thrombomodulin, and plasminogen activator inhibitor-1 levels in patients with essential hypertension. Cardiovascular Drugs & Therapy. 1998;12(5):463-7. Not RCT or controlled trial. [pmid: 9926277].
2275 Kresyn VI, Aryaev VL, Kostev FI. Litonit: evaluation of clinical effectiveness. Alcohol & Alcoholism. 1993;28(3):333-7. Not RCT or controlled trial. [pmid: 8352844].
2276 Kreutz R, Kruse HJ, Overlack A, et al. Effects of sympathetic inhibition on blood pressure and renal responses to central hypervolaemia in normal humans. Acta Physiologica Scandinavica. 1996;156(1):1-7. Sample size less than 50 patients. [pmid: 8866880].
2277 Krijnen P, van Jaarsveld BC, Man in 't Veld AJ, et al. Reproducibility and validity of quality of life measurements in hypertensive patients on stable medication. Netherlands Journal of Medicine. 1997;50(4):137-52. Not RCT or controlled trial. [pmid: 9130837].
2278 Krikken JA, Gansevoort RT, Dullaart RPF, et al. Lower HDL-C and apolipoprotein A-I are related to higher glomerular filtration rate in subjects without kidney disease. Journal of Lipid Research. Jul. 2010;51(7):1982-90. Not early CKD. [pmid: 20211930].
2279 Krikken JA, Waanders F, Dallinga-Thie GM, et al. Antiproteinuric therapy decreases LDL-cholesterol as well as HDL-cholesterol in non-diabetic proteinuric patients: relationships with cholesteryl ester transfer protein mass and adiponectin. Expert Opinion on Therapeutic Targets. 2009;13(5):497-504. Not CKD treatment. [pmid: 19397474].
2280 Krimholtz MJ, Karalliedde J, Thomas S, et al. Targeting albumin excretion rate in the treatment of the hypertensive diabetic patient with renal disease. Journal of the American Society of Nephrology. Suppl 1. 2005;16:S42-7. Not relevant to key questions. [pmid: 15938033].
2281 Krishna GG, Kapoor SC. Preservation of renal reserve in chronic renal disease. American Journal of Kidney Diseases. 1991;17(1):18-24. Sample size less than 50 patients. [pmid: 1986565].
2282 Krishna GG, Newell G, Miller E, et al. Protein-induced glomerular hyperfiltration: role of hormonal factors. Kidney International. 1988;33(2):578-83. Sample size less than 50 patients. [pmid: 2834601].
2283 Kristjansson A, Mansson W. Renal function in the setting of urinary diversion. World Journal of Urology. 2004;22(3):172-7. Not relevant to key questions. [pmid: 15340756].
2284 Kristjansson A, Wallin L, Mansson W. Renal function up to 16 years after conduit (refluxing or anti-reflux anastomosis) or continent urinary diversion. 1. Glomerular filtration rate and patency of uretero-intestinal anastomosis. [Erratum appears in Br Urol 1995 Dec; 76(6):815]. British Journal of Urology. 1995;76(5):539-45. Not CKD treatment. [pmid: 8535669].
2285 Kron BG, Sjostrom PA, Karlberg BE, et al. Acute tolerance to furosemide. Pretreatment with captopril or prazosin does not influence diuresis and natriuresis. Scandinavian Journal of Urology & Nephrology. 1994;28(4):337-44. Not CKD treatment. [pmid: 7886407].
2286 Kronenberg F, Kuen E, Ritz E, et al. Lipoprotein(a) serum concentrations and apolipoprotein(a) phenotypes in mild and moderate renal failure. Journal of the American Society of Nephrology. 2000;11(1):105-15. Not RCT or controlled trial. [pmid: 10616846].
2287 Kruger W, Sobottka I, Stockschlader M, et al. Fatal outcome of disseminated candidosis after allogeneic bone marrow transplantation under treatment with liposomal and conventional amphotericin-B. A report of 4 cases with determination of the Mic values. Scandinavian Journal of Infectious Diseases. 1996;28(3):313-6. Not CKD treatment. [pmid: 8863370].
2288 Krum H, Aw TJ, Liew D, et al. Blood pressure effects of COX-2 inhibitors. Journal of Cardiovascular Pharmacology. Suppl 1. 2006;47:S43-8. Not RCT or controlled trial. [pmid: 16785828].
2289 Krum H, Schlaich M, Whitbourn R, et al. Catheter-based renal sympathetic denervation for resistant hypertension: a multicentre safety and proof-of-principle cohort study. Lancet. 2009;373(9671):1275-81. Not RCT or controlled trial. [pmid: 19332353].
2290 Krusell LR, Christensen CK, Pedersen OL. Alpha-adrenoceptor blockade in patients with mild to moderate hypertension: long-term renal effects of doxazosin. Journal of Cardiovascular Pharmacology. 1992;20(3):440-4. Sample size less than 50 patients. [pmid: 1279290].
2291 Kshirsagar AV, Joy MS, Hogan SL, et al. Effect of ACE inhibitors in diabetic and nondiabetic chronic renal disease: a systematic overview of randomized placebo-controlled trials. American Journal of Kidney Diseases. 2000;35(4):695-707. Not relevant to key questions. [pmid: 10739792].
2292 Kshirsagar AV, Poole C, Mottl A, et al. N-acetylcysteine for the prevention of radiocontrast induced nephropathy: a meta-analysis of prospective controlled trials. Journal of the American Society of Nephrology. 2004;15(3):761-9. Sample size less than 50 patients. [pmid: 14978179].
2293 Kshirsagar AV, Shoham DA, Bang H, et al. The effect of cholesterol reduction with cholestyramine on renal function. American Journal of Kidney Diseases. 2005;46(5):812-9. Not RCT or controlled trial. [pmid: 16253720].
2294 Kuan Y, Surman J, Frystyk J, et al. Lack of effect of IGF-I on the glomerular filtration rate in non-diabetic patients with advanced chronic kidney disease. Growth Hormone & Igf Research. 2009;19(3):219-25. Not CKD treatment. [pmid: 19046909].
2295 Kuduvalli M, Grayson AD, Au J, et al. A multi-centre additive and logistic risk model for in-hospital mortality following aortic valve replacement. European Journal of Cardio-Thoracic Surgery. 2007;31(4):607-13. Not RCT or controlled trial. [pmid: 17287128].
2296 Kulik A, Ruel M. Statins and coronary artery bypass graft surgery: preoperative and postoperative efficacy and safety. Expert Opinion on Drug Safety. 2009;8(5):559-71. Not RCT or controlled trial. [pmid: 19673591].
2297 Kulka PJ, Tryba M, Zenz M. Preoperative alpha2-adrenergic receptor agonists prevent the deterioration of renal function after cardiac surgery: results of a randomized, controlled trial. Critical Care Medicine. 1996;24(6):947-52. Sample size less than 50 patients. [pmid: 8681596].
2298 Kult J, Hacker W, Glocke M. Comparison of efficacy and tolerance of different oral doses of torasemide and furosemide in patients with advanced chronic renal failure. Arzneimittel-Forschung. 1988;38(1A):212-4. Follow-up less than 6 months. [pmid: 3285837].
2299 Kumar A. Influence of radish consumption on urinary calcium oxalate excretion. Nepal Medical College Journal: NMCJ. 2004;6(1):41-4. Not relevant to key questions. [pmid: 15449653].
2300 Kumar NS, Singh AK, Mishra RN, et al. Comparative study of angiotensin converting enzyme inhibitor and calcium channel blocker in the treatment of steroid-resistant idiopathic nephrotic syndrome. Journal of the Association of Physicians of India. 2004;52:454-8. Not early CKD. [pmid: 15645954].
2301 Kumar R, Kapoor R, Mandhani A, et al. Optimum duration of splinting after endopyelotomy. Journal of Endourology. 1999;13(2):89-92. Not CKD treatment. [pmid: 10213101].
2302 Kumar S, Masood N, Shaikh AJ. Old disease, new targets--part-I, solid malignancies. JPMA - Journal of the Pakistan Medical Association. Jun. 2009;59(6):398-405. Not early CKD.
2303 Kunz R, Friedrich C, Wolbers M, et al. Meta-analysis: effect of monotherapy and combination therapy with inhibitors of the renin angiotensin system on proteinuria in renal disease. Annals of Internal Medicine. 2008;148(1):30-48. Not RCT or controlled trial. [pmid: 17984482].
2304 Kunz R, Wolbers M, Glass T, et al. The COOPERATE trial: a letter of concern. Lancet. 2008;371(9624):1575-6. Not CKD treatment. [pmid: 18468534].
2305 Kuriyama S, Tomonari H, Tokudome G, et al. Antiproteinuric effects of combined antihypertensive therapies in patients with overt type 2 diabetic nephropathy. Hypertension Research - Clinical & Experimental. 2002;25(6):849-55. Sample size less than 50 patients.
2306 Kuriyama S, Tomonari H, Yoshida H, et al. Reversal of anemia by erythropoietin therapy retards the progression of chronic renal failure, especially in nondiabetic patients. Nephron. 1997;77(2):176-85. Not early CKD. [pmid: 9346384].
2307 Kurman MR. Recent clinical trials with levamisole. Annals of the New York Academy of Sciences. 1993;685:269-77. Not RCT or controlled trial. [pmid: 8363230].
2308 Kurnik BR, Allgren RL, Genter FC, et al. Prospective study of atrial natriuretic peptide for the prevention of radiocontrast-induced nephropathy. American Journal of Kidney Diseases. 1998;31(4):674-80. Not CKD treatment. [pmid: 9531185].
2309 Kurnik BR, Weisberg LS, Askenase AD, et al. Mannitol stimulates atrial natriuretic peptide release in humans. American Journal of Kidney Diseases. 1991;17(1):62-8. Sample size less than 50 patients. [pmid: 1824736].
2310 Kurokawa K, Chan JCN, Cooper ME, et al. Renin angiotensin aldosterone system blockade and renal disease in patients with type 2 diabetes: a subanalysis of Japanese patients from the RENAAL study. Clinical & Experimental Nephrology. 2006;10(3):193-200. Sample size less than 50 patients. [pmid: 17009077].
2311 Kurth T, de Jong PE, Cook NR, et al. Kidney function and risk of cardiovascular disease and mortality in women: a prospective cohort study. [Erratum appears in BMJ 2009;339:b2769]. BMJ. 2009;338:b2392. Not RCT or controlled trial. [pmid: 19564178].
2312 Kurth T, de Jong PE, Cook NR, et al. Kidney function and risk of cardiovascular disease and mortality in women: a prospective cohort study. [Erratum appears in BMJ2009;339:b2769]. BMJ. 2009;338:b2392. Not RCT or controlled trial. [pmid: 19564178].
2313 Kusek JW, Coyne T, de Velasco A, et al. Recruitment experience in the full-scale phase of the Modification of Diet in Renal Disease Study. Controlled Clinical Trials. 1993;14(6):538-57. Not relevant to key questions. [pmid: 8119068].
2314 Kusek JW, Hirschman GH, Agodoa L, et al. Nephrology clinical trials supported by the kidney programs of the National Institutes of Health. Clinical Nephrology. Suppl 1. 1992;38:S61-3. Not CKD treatment. [pmid: 1295710].
2315 Kusek JW, Lee JY, Charleston J, et al. Participant satisfaction in the African American Study of Kidney Disease and Hypertension (AASK) Pilot Study. Controlled Clinical Trials. 1996;17(4 Suppl):47S-54S. Not RCT or controlled trial. [pmid: 8889354].
2316 Kusek JW, Lee JY, Smith DE, et al. Effect of blood pressure control and antihypertensive drug regimen on quality of life: the African American Study of Kidney Disease and Hypertension (AASK) Pilot Study. Controlled Clinical Trials. 1996;17(4 Suppl):40S-6S. Not relevant to key questions. [pmid: 8889353].
2317 Kutner N. Quality of life assessment in a recent haemoglobin trial in CKD (CHOIR). Nephrology Dialysis Transplantation. 2007;22(7):2099. Not CKD treatment.
2318 Kutner NG, Johansen KL, Kaysen GA, et al. The comprehensive dialysis study (CDS): a USRDS special study. Clinical Journal of The American Society of Nephrology: CJASN. 2009;4(3):645-50. Not early CKD. [pmid: 19261814].
2319 Kvetny J, Gregersen G, Pedersen RS. Randomized placebo-controlled trial of perindopril in normotensive, normoalbuminuric patients with type 1 diabetes mellitus. Qjm. 2001;94(2):89-94. Not early CKD. [pmid: 11181984].
2320 Kwong YTD, Stevens LA, Selvin E, et al. Imprecision of urinary iothalamate clearance as a gold-standard measure of GFR decreases the diagnostic accuracy of kidney function estimating equations. American Journal of Kidney Diseases. Jul. 2010;56(1):39-49. Not CKD treatment. [pmid: 20537455].
2321 Kyle RA, Gertz MA, Greipp PR, et al. A trial of three regimens for primary amyloidosis: colchicine alone, melphalan and prednisone, and melphalan, prednisone, and colchicine. New England Journal of Medicine. 1997;336(17):1202-7. Not CKD treatment. [pmid: 9110907].
2322 La Villa G, Barletta G, Pantaleo P, et al. Hemodynamic, renal, and endocrine effects of acute inhibition of nitric oxide synthase in compensated cirrhosis. Hepatology. 2001;34(1):19-27. Not early CKD. [pmid: 11431729].
2323 La Villa G, Fronzaroli C, Lazzeri C, et al. Cardiovascular and renal effects of low dose brain natriuretic peptide infusion in man. Journal of Clinical Endocrinology & Metabolism. 1994;78(5):1166-71. Not CKD treatment. [pmid: 8175974].
2324 La Villa G, Lazzeri C, Pascale A, et al. Cardiovascular and renal effects of low-dose atrial natriuretic peptide in compensated cirrhosis. American Journal of Gastroenterology. 1997;92(5):852-7. Not CKD treatment. [pmid: 9149200].
2325 La Villa G, Marra F, Laffi G, et al. Effects of rhein on renal arachidonic acid metabolism and renal function in patients with congestive heart failure. European Journal of Clinical Pharmacology. 1989;37(1):1-5. Sample size less than 50 patients. [pmid: 2512175].
2326 La Villa G, Stefani L, Lazzeri C, et al. Acute effects of physiological increments of brain natriuretic peptide in humans. Hypertension. 1995;26(4):628-33. Sample size less than 50 patients. [pmid: 7558223].
2327 Labrecque M, Dostaler LP, Rousselle R, et al. Efficacy of nonsteroidal anti-inflammatory drugs in the treatment of acute renal colic. A meta-analysis. Archives of Internal Medicine. 1994;154(12):1381-7. Not RCT or controlled trial. [pmid: 8002690].
2328 Lacourciere Y, Nadeau A, Poirier L, et al. Comparative effects of converting enzyme inhibition and conventional therapy in hypertensive non-insulin dependent diabetics with normal renal function. Clinical & Investigative Medicine - Medecine Clinique et Experimentale. 1991;14(6):652-60. Not early CKD. [pmid: 1794215].
2329 Laczy B, Cseh J, Mohas M, et al. Effects of pentoxifylline and pentosan polysulphate combination therapy on diabetic neuropathy in type 2 diabetes mellitus. Acta Diabetologica. 2009;46(2):105-11. Not CKD treatment. [pmid: 18839054].
2330 Laerum E, Ommundsen OE, Gronseth JE, et al. Intramuscular diclofenac versus intravenous indomethacin in the treatment of acute renal colic. European Urology. 1996;30(3):358-62. Not CKD treatment. [pmid: 8931970].
2331 Laffi G, Marra F, Carloni V, et al. Thromboxane-receptor blockade increases water diuresis in cirrhotic patients with ascites. Gastroenterology. 1992;103(3):1017-21. Not CKD treatment. [pmid: 1386823].
2332 Lainchbury JG, Richards AM, Nicholls MG, et al. The effects of pathophysiological increments in brain natriuretic peptide in left ventricular systolic dysfunction. Hypertension. 1997;30(3 Pt 1):398-404. Follow-up less than 6 months. [pmid: 9314423].
2333 Lainchbury JG, Troughton RW, Lewis LK, et al. Hemodynamic, hormonal, and renal effects of short-term adrenomedullin infusion in healthy volunteers. Journal of Clinical Endocrinology & Metabolism. 2000;85(3):1016-20. Not early CKD. [pmid: 10720032].
2334 Laine L, White WB, Rostom A, et al. COX-2 selective inhibitors in the treatment of osteoarthritis. Seminars in Arthritis & Rheumatism. 2008;38(3):165-87. Not CKD treatment. [pmid: 18177922].
2335 Laing C, Unwin RJ. Are calcium antagonists effective in preventing complications of hypertension and progression of renal disease?. Current Opinion in Nephrology & Hypertension. 2000;9(5):489-95. Not relevant to key questions. [pmid: 10990366].
2336 Laisalmi M, Teppo AM, Koivusalo AM, et al. The effect of ketorolac and sevoflurane anesthesia on renal glomerular and tubular function. Anesthesia & Analgesia. 2001;93(5):1210-3. Not early CKD. [pmid: 11682399].
2337 Laisalmi-Kokki M, Pesonen E, Kokki H, et al. Potentially detrimental effects of N-acetylcysteine on renal function in knee arthroplasty. Free Radical Research. 2009;43(7):691-6. Not CKD treatment. [pmid: 19526394].
2338 Lajer H, Daugaard G. Cisplatin and hypomagnesemia. Cancer Treatment Reviews. 1999;25(1):47-58. Not CKD treatment. [pmid: 10212589].
2339 Lalezari JP, Drew WL, Glutzer E, et al. (S)-1-[3-hydroxy-2-(phosphonylmethoxy)propyl]cytosine (cidofovir): results of a phase I/II study of a novel antiviral nucleotide analogue. Journal of Infectious Diseases. 1995;171(4):788-96. Sample size less than 50 patients. [pmid: 7706804].
2340 Lalezari JP, Holland GN, Kramer F, et al. Randomized, controlled study of the safety and efficacy of intravenous cidofovir for the treatment of relapsing cytomegalovirus retinitis in patients with AIDS. Journal of Acquired Immune Deficiency Syndromes & Human Retrovirology. 1998;17(4):339-44. Not CKD treatment. [pmid: 9525435].
2341 Laliberte MC, Normandeau M, Lord A, et al. Use of over-the-counter medications and natural products in patients with moderate and severe chronic renal insufficiency. American Journal of Kidney Diseases. 2007;49(2):245-56. Not RCT or controlled trial. [pmid: 17261427].
2342 Lalonde L, Normandeau M, Lamarre D, et al. Evaluation of a training and communication-network nephrology program for community pharmacists. Pharmacy World & Science. 2008;30(6):924-33. Not CKD treatment. [pmid: 18802782].
2343 Lam KS, Cheng IK, Janus ED, et al. Cholesterol-lowering therapy may retard the progression of diabetic nephropathy. Diabetologia. 1995;38(5):604-9. Sample size less than 50 patients. [pmid: 7489845].
2344 Lam YW, Boyd RA, Chin SK, et al. Effect of probenecid on the pharmacokinetics and pharmacodynamics of procainamide. Journal of Clinical Pharmacology. 1991;31(5):429-32. Not CKD treatment. [pmid: 2050827].
2345 Lamb EJ, Fluck RJ, Venton TR, et al. Effects of parathyroid hormone and 1,25(OH2)D3 on protein glycation in moderate uraemia. Nephron. 1996;74(2):295-300. Not RCT or controlled trial. [pmid: 8893144].
2346 Lambers Heerspink HJ, Agarwal R, Coyne DW, et al. The selective vitamin D receptor activator for albuminuria lowering (VITAL) study: study design and baseline characteristics. American Journal of Nephrology. 2009;30(3):280-6. Not early CKD. [pmid: 19521070].
2347 Lambers Heerspink HJ, Fowler MJ, Volgi J, et al. Rationale for and study design of the sulodexide trials in Type 2 diabetic, hypertensive patients with microalbuminuria or overt nephropathy. Diabetic Medicine. 2007;24(11):1290-5. Not RCT or controlled trial. [pmid: 17956455].
2348 Lambert KE. Recombinant human erythropoietin. Canadian Nurse. 1990;86(10):27-8. Not early CKD. [pmid: 2224810].
2349 Lameire N. Contrast-induced nephropathy in the critically-ill patient: focus on emergency screening and prevention. Acta Clinica Belgica - Supplementum. 2007;(2):346-52. Not CKD treatment. [pmid: 18283997].
2350 Landersdorfer CB, Kirkpatrick CMJ, Kinzig M, et al. Competitive inhibition of renal tubular secretion of gemifloxacin by probenecid. Antimicrobial Agents & Chemotherapy. 2009;53(9):3902-7. Sample size less than 50 patients. [pmid: 19564368].
2351 Landersdorfer CB, Kirkpatrick CMJ, Kinzig M, et al. Inhibition of flucloxacillin tubular renal secretion by piperacillin. British Journal of Clinical Pharmacology. 2008;66(5):648-59. Not RCT or controlled trial. [pmid: 19032173].
2352 Landmann R, Keilholz U, Scheibenbogen C, et al. Relationship between soluble tumor necrosis factor (TNF) receptors and TNF alpha during immunotherapy with interleukin-2 and/or interferon alpha. Cancer Immunology, Immunotherapy. 1994;38(2):113-8. Not CKD treatment.
2353 Landoni G, Bignami E, Gonfalini M, et al. Fenoldopam in cardiac surgery-associated acute kidney injury. International Journal of Artificial Organs. 2008;31(6):561. Not CKD treatment. [pmid: 18609509].
2354 Landoni G, Biondi-Zoccai GGL, Tumlin JA, et al. Beneficial impact of fenoldopam in critically ill patients with or at risk for acute renal failure: a meta-analysis of randomized clinical trials. American Journal of Kidney Diseases. 2007;49(1):56-68. Not RCT or controlled trial. [pmid: 17185146].
2355 Landray M, Baigent C, Leaper C, et al. The second United Kingdom Heart and Renal Protection (UK-HARP-II) Study: a randomized controlled study of the biochemical safety and efficacy of adding ezetimibe to simvastatin as initial therapy among patients with CKD. American Journal of Kidney Diseases. 2006;47(3):385-95. Not RCT or controlled trial. [pmid: 16490616].
2356 Lane C, Brown M, Dunsmuir W, et al. Can spot urine protein/creatinine ratio replace 24 h urine protein in usual clinical nephrology?. Nephrology. 2006;11(3):245-9. Follow-up less than 6 months. [pmid: 16756640].
2357 Lang CC, Choy AM, Balfour DJ, et al. Prazosin attenuates the natriuretic response to atrial natriuretic factor in man. Kidney International. 1992;42(2):433-41. Sample size less than 50 patients. [pmid: 1405327].
2358 Lang CC, Choy AM, Rahman AR, et al. Renal effects of low dose prazosin in patients with congestive heart failure. European Heart Journal. 1993;14(9):1245-52. Not CKD treatment. [pmid: 8223740].
2359 Lang CC, Rahman AR, Balfour DJ, et al. Effect of noradrenaline on renal sodium and water handling in euhydrated and overhydrated man. Clinical Science. 1993;85(4):487-94. Not RCT or controlled trial. [pmid: 8222516].
2360 Lang CC, Rahman AR, Balfour DJ, et al. Enalapril blunts the antinatriuretic effect of circulating noradrenaline in man. Journal of Hypertension. 1993;11(5):565-71. Sample size less than 50 patients. [pmid: 8390529].
2361 Lang CC, Rahman AR, Choy AM, et al. Renal interactions between the renin-angiotensin system and the sympathetic nervous system in man. Journal of Hypertension - Supplement. 1991;9(6):S206-7. Sample size less than 50 patients.
2362 Lang SM, Schiffl H. Losartan and anaemia of end-stage renal disease. Lancet. 1998;352(9141):1708. Not early CKD. [pmid: 9853467].
2363 Langer M, Junge W, Keysser R, et al. Renal and hepatic tolerance of nonionic and ionic contrast media in intravenous digital subtraction angiography. Fortschritte auf dem Gebiete der Rontgenstrahlen und der Nuklearmedizin - Erganzungsband. 1989;128:95-100. Not CKD treatment. [pmid: 2568817].
2364 Langer M, Langer R, Felix R, et al. Analysis of renal and hepatic impairment by ionic and nonionic contrast media. Investigative Radiology. Suppl 1. 1990;25:S125-6. Follow-up less than 6 months. [pmid: 2283230].
2365 Langer M, Langer R, Zwicker C, et al. Clinical and nephrologic tolerance of iopromide and iotrolan in computed tomography. Investigative Radiology. Suppl 1. 1991;26:S83-5. discussion S8-91. Sample size less than 50 patients. [pmid: 1808156].
2366 Langston RD, Presley R, Flanders WD, et al. Renal insufficiency and anemia are independent risk factors for death among patients with acute myocardial infarction. Kidney International. 2003;64(4):1398-405. Not CKD treatment. [pmid: 12969159].
2367 Langtry HD, Gillis JC, Davis R. Topiramate. A review of its pharmacodynamic and pharmacokinetic properties and clinical efficacy in the management of epilepsy. Drugs. 1997;54(5):752-73. Not CKD treatment. [pmid: 9360061].
2368 Larkin JMG, Kaye SB. Potential clinical applications of epothilones: a review of phase II studies. Annals of Oncology. Suppl 5. 2007;18:v28-34. Sample size less than 50 patients. [pmid: 17656559].
2369 Larochelle P, Cusson JR, du Souich P, et al. Renal effects of a nonhypotensive i.v. dose of felodipine. Journal of Clinical Pharmacology. 1993;33(8):732-7. Sample size less than 50 patients. [pmid: 8408734].
2370 Larsen M, Hommel E, Parving HH, et al. Protective effect of captopril on the blood-retina barrier in normotensive insulin-dependent diabetic patients with nephropathy and background retinopathy. Graefes Archive for Clinical & Experimental Ophthalmology. 1990;228(6):505-9. Sample size less than 50 patients.
2371 Lasaridis AN, Sarafidis PA. Diabetic nephropathy and antihypertensive treatment: what are the lessons from clinical trials?. American Journal of Hypertension. 2003;16(8):689-97. Not RCT or controlled trial. [pmid: 12878377].
2372 Lash JP, Wang X, Greene T, et al. Quality of life in the African American Study of Kidney Disease and Hypertension: effects of blood pressure management. American Journal of Kidney Diseases. 2006;47(6):956-64. Not CKD treatment. [pmid: 16731290].
2373 Lassnigg A, Donner E, Grubhofer G, et al. Lack of renoprotective effects of dopamine and furosemide during cardiac surgery. Journal of the American Society of Nephrology. 2000;11(1):97-104. Not CKD treatment. [pmid: 10616845].
2374 Lastra-Gonzalez G, Manrique CM, Govindarajan G, et al. Insights into the emerging cardiometabolic prevention and management of diabetes mellitus. Expert Opinion on Pharmacotherapy. 2005;6(13):2209-21. Not RCT or controlled trial. [pmid: 16218882].
2375 Laszlo J, Goldstein D, Vugrin D, et al. Does maintenance therapy with alpha interferon stabilize cancer growth? A pilot study. Journal of Biological Response Modifiers. 1986;5(4):294-9. Sample size less than 50 patients. [pmid: 3734845].
2376 Latinwo LM, Ikediobi CO, Singh NP, et al. Comparative studies of in vivo genotoxic effects of cadmium chloride in rat brain, kidney and liver cells. Cellular & Molecular Biology. 1997;43(2):203-10. Not human studies. [pmid: 9130604].
2377 Lau HS, Hyneck ML, Berardi RR, et al. Kinetics, dynamics, and bioavailability of bumetanide in healthy subjects and patients with chronic renal failure. Clinical Pharmacology & Therapeutics. 1986;39(6):635-45. Sample size less than 50 patients. [pmid: 3709028].
2378 Lau LL, Halliday MI, Smye MG, et al. Extraperitoneal approach reduces intestinal and renal dysfunction in elective abdominal aortic aneurysm repair. International Angiology. 2001;20(4):282-7. Not early CKD. [pmid: 11782693].
2379 Laufs U, Custodis F, Bohm M. Who does not need a statin: too late in end-stage renal disease or heart failure?. Heart. 2008;94(9):1138-40. Not CKD treatment. [pmid: 18703694].
2380 Laufs U, Custodis F, Bohm M. Who does not need a statin: too late in end-stage renal disease or heart failure?. Postgraduate Medical Journal. 2009;85(1002):187-9. Not RCT or controlled trial. [pmid: 19417167].
2381 Laurent S. Evidence for benefits of perindopril in hypertension and its complications. American Journal of Hypertension. 2005;18(9 Pt 2):155S-62S. Sample size less than 50 patients. [pmid: 16125052].
2382 Lauridsen TG, Vase H, Bech JN, et al. Direct effect of methylprednisolone on renal sodium and water transport via the principal cells in the kidney. European Journal of Endocrinology. May. 2010;162(5):961-9. Not early CKD. [pmid: 20203161].
2383 Lauridsen TG, Vase H, Starklint J, et al. Protein-enriched diet increases water absorption via the aquaporin-2 water channels in healthy humans. Nephrology Dialysis Transplantation. Aug. 2010;25(8):2502-10. Not early CKD.
2384 Lauschke A, Teichgraber UKM, Frei U, et al. ‘Low-dose’ dopamine worsens renal perfusion in patients with acute renal failure. Kidney International. 2006;69(9):1669-74. Sample size less than 50 patients. [pmid: 16572117].
2385 Laverman GD, Navis G, Henning RH, et al. Dual renin-angiotensin system blockade at optimal doses for proteinuria. Kidney International. 2002;62(3):1020-5. Sample size less than 50 patients. [pmid: 12164886].
2386 Laviades C, Varo N, Diez J. Transforming growth factor beta in hypertensives with cardiorenal damage. Hypertension. 2000;36(4):517-22. Sample size less than 50 patients. [pmid: 11040229].
2387 Laville M, Anaemia CiDt. New strategies in anaemia management: ACORD (Anaemia CORrection in Diabetes) trial. Acta Diabetologica. Suppl 1. 2004;41:S18-22. Not CKD treatment. [pmid: 15103544].
2388 Lavrijssen AT, Kroon AA, Fuss-Lejeune M, et al. Renal haemodynamics and sodium excretory capacity during urapidil treatment in patients with essential hypertension. Journal of Hypertension. 2000;18(7):963-9. Sample size less than 50 patients. [pmid: 10930195].
2389 Lawendy N, Krishnaswami S, Wang R, et al. Effect of CP-690,550, an orally active janus kinase inhibitor, on renal function in healthy adult volunteers. Journal of Clinical Pharmacology. 2009;49(4):423-9. Not early CKD. [pmid: 19318693].
2390 Lawlor DK, Moist L, DeRose G, et al. Prevention of contrast-induced nephropathy in vascular surgery patients. Annals of Vascular Surgery. 2007;21(5):593-7. Follow-up less than 6 months. [pmid: 17823041].
2391 Lazarus JM, Bourgoignie JJ, Buckalew VM, et al. Achievement and safety of a low blood pressure goal in chronic renal disease. The Modification of Diet in Renal Disease Study Group. Hypertension. 1997;29(2):641-50. Not relevant to key questions. [pmid: 9040451].
2392 Lazzeri C, Tosti Guerra C, Vecchiarino S, et al. C-type natriuretic peptide does not affect plasma and urinary adrenomedullin in man. Clinical Physiology. 1999;19(1):68-75. Sample size less than 50 patients. [pmid: 10068868].
2393 Lazzeri M, Barbanti G, Beneforti P, et al. Vesical-renal reflex: diuresis and natriuresis activated by intravesical capsaicin. Scandinavian Journal of Urology & Nephrology. 1995;29(1):39-43. Sample size less than 50 patients. [pmid: 7618049].
2394 Le Bricon T, Erlich D, Bengoufa D, et al. Sodium dodecyl sulfate-agarose gel electrophoresis of urinary proteins: application to multiple myeloma. Clinical Chemistry. 1998;44(6 Pt 1):1191-7. Not RCT or controlled trial. [pmid: 9625042].
2395 Lea J, Greene T, Hebert L, et al. The relationship between magnitude of proteinuria reduction and risk of end-stage renal disease: results of the African American study of kidney disease and hypertension. Archives of Internal Medicine. 2005;165(8):947-53. Not RCT or controlled trial. [pmid: 15851648].
2396 Leary WP. Renal excretory actions of antihypertensive agents. Effects of rilmenidine. American Journal of Medicine. 1989;87(3C):63S-6S. Not relevant to key questions. [pmid: 2571295].
2397 Leary WP, Reyes AJ, Wynne RD, et al. Renal excretory actions of furosemide, of hydrochlorothiazide and of the vasodilator flosequinan in healthy subjects. Journal of International Medical Research. 1990;18(2):120-41. Not CKD treatment. [pmid: 2340945].
2398 Leavey SF, Weitzel WF. Endocrine abnormalities in chronic renal failure. Endocrinology & Metabolism Clinics of North America. 2002;31(1):107-19. Not RCT or controlled trial. [pmid: 12055983].
2399 Leblond V, Sutton L, Jacquiaud C, et al. Evaluation of renal function in 60 long-term survivors of bone marrow transplantation. Journal of the American Society of Nephrology. 1995;6(6):1661-5. Not CKD treatment. [pmid: 8749695].
2400 Lebovitz HE, Wiegmann TB, Cnaan A, et al. Renal protective effects of enalapril in hypertensive NIDDM: role of baseline albuminuria. Kidney International - Supplement. 1994;45:S150-5. Not relevant to key questions. [pmid: 8158885].
2401 Lebrec D, Thabut D, Oberti F, et al. Pentoxifylline does not decrease short-term mortality but does reduce complications in patients with advanced cirrhosis. Gastroenterology. May. 2010;138(5):1755-62. Not early CKD. [pmid: 20102716].
2402 Lecomte JM, Baumer P, Lim C, et al. Stereoselective protection of exogenous and endogenous atrial natriuretic factor by enkephalinase inhibitors in mice and humans. European Journal of Pharmacology. 1990;179(1-2):65-73. Sample size less than 50 patients. [pmid: 2163851].
2403 Ledderhos C, Brauer H, Gens A, et al. Cardiorespiratory and renal responses to arterial chemoreceptor stimulation in early hypertension. International Journal of Clinical Pharmacology & Therapeutics. 1996;34(11):470-6. Sample size less than 50 patients. [pmid: 8937928].
2404 Lee A, Cooper MC, Craig JC, et al. Effects of nonsteroidal anti-inflammatory drugs on post-operative renal function in normal adults. Cochrane Database of Systematic Reviews. 2001;(2):CD002765. Not CKD treatment. [pmid: 11406042].
2405 Lee A, Cooper MC, Craig JC, et al. Effects of nonsteroidal anti-inflammatory drugs on postoperative renal function in adults with normal renal function. Cochrane Database of Systematic Reviews. 2004;(2):CD002765. Not CKD treatment. [pmid: 15106177].
2406 Lee A, Cooper MG, Craig JC, et al. The effects of nonsteroidal anti-inflammatory drugs (NSAIDs) on postoperative renal function: a meta-analysis. Anaesthesia & Intensive Care. 1999;27(6):574-80. Not RCT or controlled trial. [pmid: 10631409].
2407 Lee A, Cooper MG, Craig JC, et al. Effects of nonsteroidal anti-inflammatory drugs on post-operative renal function in adults. Cochrane Database of Systematic Reviews. 2000;(4):CD002765. Not early CKD. [pmid: 11034758].
2408 Lee A, Cooper MG, Craig JC, et al. Effects of nonsteroidal anti-inflammatory drugs on postoperative renal function in adults with normal renal function. Cochrane Database of Systematic Reviews. 2007;(2):CD002765. Not relevant to key questions. [pmid: 17443518].
2409 Lee C, Gnanasegaram D, Maloba M. Best evidence topic report. Rectal or intravenous non-steroidal anti-inflammatory drugs in acute renal colic. Emergency Medicine Journal. 2005;22(9):653-4. Not relevant to key questions. [pmid: 16113190].
2410 Lee CC, Sharp SJ, Wexler DJ, et al. Dietary intake of eicosapentaenoic and docosahexaenoic acid and diabetic nephropathy: cohort analysis of the diabetes control and complications trial. Diabetes Care. Jul. 2010;33(7):1454-6. Not CKD treatment. [pmid: 20357378].
2411 Lee CYW, Chen HH, Lisy O, et al. Pharmacodynamics of a novel designer natriuretic peptide, CD-NP, in a first-in-human clinical trial in healthy subjects. Journal of Clinical Pharmacology. 2009;49(6):668-73. Not CKD treatment. [pmid: 19395584].
2412 Lee D, Levin A, Roger SD, et al. Longitudinal analysis of performance of estimated glomerular filtration rate as renal function declines in chronic kidney disease. Nephrology Dialysis Transplantation. 2009;24(1):109-16. Not CKD treatment.
2413 Lee HC, Mitchell HC, Van Dreal P, et al. Hyperfiltration and conservation of renal function in hypertensive nephrosclerosis patients. American Journal of Kidney Diseases. 1993;21(4 Suppl 1):68-74. Not RCT or controlled trial. [pmid: 8465839].
2414 Lee HK, Kim YJ, Jeong JU, et al. Desmopressin improves platelet dysfunction measured by in vitro closure time in uremic patients. Nephron. 2010;114(4):c248-52. Sample size less than 50 patients. [pmid: 20090366].
2415 Lee JY, Greene PG, Douglas M, et al. Appointment attendance, pill counts, and achievement of goal blood pressure in the African American Study of Kidney Disease and Hypertension Pilot Study. Controlled Clinical Trials. 1996;17(4 Suppl):34S-9S. Follow-up less than 6 months. [pmid: 8889352].
2416 Lee JY, Kusek JW, Greene PG, et al. Assessing medication adherence by pill count and electronic monitoring in the African American Study of Kidney Disease and Hypertension (AASK) Pilot Study. American Journal of Hypertension. 1996;9(8):719-25. Follow-up less than 6 months. [pmid: 8862216].
2417 Lee M, Saver JL, Chang KH, et al. Impact of microalbuminuria on incident stroke: a meta-analysis. Stroke. Nov. 2010;41(11):2625-31. Not relevant to key questions. [pmid: 20930164].
2418 Lee M, Saver JL, Chang KH, et al. Low glomerular filtration rate and risk of stroke: meta-analysis. BMJ. 2010;341:c4249. Not CKD treatment. [pmid: 20884696].
2419 Lee RT, Lee TH, Poole WK, et al. Rate of disappearance of creatine kinase-MB after acute myocardial infarction: clinical determinants of variability. American Heart Journal. 1988;116(6 Pt 1):1493-9. Follow-up less than 6 months. [pmid: 3195433].
2420 Lee RWC, Di Giantomasso D, May C, et al. Vasoactive drugs and the kidney. Best Practice & Research. Clinical Anaesthesiology. 2004;18(1):53-74. Not CKD treatment.
2421 Lee TM, Chang NC. Effect of nicorandil on proteinuria in well controlled hypertensive patients. Journal of Hypertension. 2009;27(3):618-25. Not RCT or controlled trial. [pmid: 19262229].
2422 Lee TM, Lin MS, Tsai CH, et al. Add-on and withdrawal effect of pravastatin on proteinuria in hypertensive patients treated with AT receptor blockers. Kidney International. 2005;68(2):779-87. Not relevant to key questions. [pmid: 16014056].
2423 Lee TM, Su SF, Tsai CH. Effect of pravastatin on proteinuria in patients with well-controlled hypertension. Hypertension. 2002;40(1):67-73. Not relevant to key questions. [pmid: 12105140].
2424 Lee VS, Rusinek H, Bokacheva L, et al. Renal function measurements from MR renography and a simplified multicompartmental model. American Journal of Physiology - Renal Physiology. 2007;292(5):F1548-59. Not RCT or controlled trial. [pmid: 17213464].
2425 Lee WT, Padayachi K, Collins JF, et al. A comparison of oral and intravenous alfacalcidol in the treatment of uremic hyperparathyroidism. Journal of the American Society of Nephrology. 1994;5(6):1344-8. Not early CKD. [pmid: 7894000].
2426 Lee YH, Lee WC, Chen MT, et al. Acupuncture in the treatment of renal colic. Journal of Urology. 1992;147(1):16-8. Not CKD treatment. [pmid: 1729516].
2427 Leehey DJ, Braun BI, Tholl DA, et al. Can pharmacokinetic dosing decrease nephrotoxicity associated with aminoglycoside therapy. Journal of the American Society of Nephrology. 1993;4(1):81-90. Sample size less than 50 patients. [pmid: 8400072].
2428 Leehey DJ, Moinuddin I, Bast JP, et al. Aerobic exercise in obese diabetic patients with chronic kidney disease: a randomized and controlled pilot study. Cardiovascular Diabetology. 2009;8:62. Follow-up less than 6 months. [pmid: 20003224].
2429 Leehey DJ, Palubiak DJ, Chebrolu S, et al. Sodium ferric gluconate causes oxidative stress but not acute renal injury in patients with chronic kidney disease: a pilot study. Nephrology Dialysis Transplantation. 2005;20(1):135-40. Not relevant to key questions.
2430 Leeman M, van de Borne P, Collart F, et al. Bisoprolol and atenolol in essential hypertension: effects on systemic and renal hemodynamics and on ambulatory blood pressure. Journal of Cardiovascular Pharmacology. 1993;22(6):785-91. Sample size less than 50 patients. [pmid: 7509894].
2431 Leenen FH, Smith DL, Farkas RM, et al. Cardiovascular effects of indapamide in hypertensive patients with or without renal failure. A dose-response curve. American Journal of Medicine. 1988;84(1B):76-85. Sample size less than 50 patients. [pmid: 3341390].
2432 Leenen FHH, Coletta E, Davies RA. Prevention of renal dysfunction and hypertension by amlodipine after heart transplant. American Journal of Cardiology. 2007;100(3):531-5. Follow-up less than 6 months. [pmid: 17659942].
2433 Leenen FHH, Nwachuku CE, Black HR, et al. Clinical events in high-risk hypertensive patients randomly assigned to calcium channel blocker versus angiotensin-converting enzyme inhibitor in the antihypertensive and lipid-lowering treatment to prevent heart attack trial. Hypertension. 2006;48(3):374-84. Not RCT or controlled trial. [pmid: 16864749].
2434 Lefebvre P, Duh MS, Buteau S, et al. Medical costs of untreated anemia in elderly patients with predialysis chronic kidney disease. Journal of the American Society of Nephrology. 2006;17(12):3497-502. Sample size less than 50 patients. [pmid: 17082245].
2435 Lefebvre P, Vekeman F, Sarokhan B, et al. Relationship between hemoglobin level and quality of life in anemic patients with chronic kidney disease receiving epoetin alfa. Current Medical Research & Opinion. 2006;22(10):1929-37. Not RCT or controlled trial. [pmid: 17022852].
2436 Legault L, Ogilvie RI, Cardella CJ, et al. Calcium antagonists in heart transplant recipients: effects on cardiac and renal function and cyclosporine pharmacokinetics. Canadian Journal of Cardiology. 1993;9(5):398-404. Follow-up less than 6 months. [pmid: 8348391].
2437 Legroux-Crespel E, Cledes J, Misery L. A comparative study on the effects of naltrexone and loratadine on uremic pruritus. Dermatology. 2004;208(4):326-30. Sample size less than 50 patients. [pmid: 15178915].
2438 Lehmkuhl HB, Arizon J, Vigano M, et al. Everolimus with reduced cyclosporine versus MMF with standard cyclosporine in de novo heart transplant recipients. Transplantation. 2009;88(1):115-22. Not early CKD. [pmid: 19584690].
2439 Leitersdorf E, Muratti EN, Eliav O, et al. Efficacy and safety of triple therapy (fluvastatin-bezafibrate-cholestyramine) for severe familial hypercholesterolemia. American Journal of Cardiology. 1995;76(2):84A-8A. Follow-up less than 6 months.
2440 Lely AT, van der Kleij FGH, Kistemaker TJ, et al. Impact of the preintervention rate of renal function decline on outcome of renoprotective intervention. Clinical Journal of The American Society of Nephrology: CJASN. 2008;3(1):54-60. Not CKD treatment. [pmid: 18077786].
2441 Lema G, Urzua J, Jalil R, et al. Renal protection in patients undergoing cardiopulmonary bypass with preoperative abnormal renal function. Anesthesia & Analgesia. 1998;86(1):3-8. Sample size less than 50 patients. [pmid: 9428842].
2442 Lemaire SA, Jones MM, Conklin LD, et al. Randomized comparison of cold blood and cold crystalloid renal perfusion for renal protection during thoracoabdominal aortic aneurysm repair. Journal of Vascular Surgery. 2009;49(1):11-9. discussion 9. Not CKD treatment. [pmid: 19028052].
2443 Lemann J, Bidani AK, Bain RP, et al. Use of the serum creatinine to estimate glomerular filtration rate in health and early diabetic nephropathy. Collaborative Study Group of Angiotensin Converting Enzyme Inhibition in Diabetic Nephropathy. American Journal of Kidney Diseases. 1990;16(3):236-43. Not CKD treatment. [pmid: 2399915].
2444 Lemann J Jr., Pleuss JA, Hornick L, et al. Dietary NaCl-restriction prevents the calciuria of KCl-deprivation and blunts the calciuria of KHCO3-deprivation in healthy adults. Kidney International. 1995;47(3):899-906. Sample size less than 50 patients. [pmid: 7752590].
2445 Lemley KV, Abdullah I, Myers BD, et al. Evolution of incipient nephropathy in type 2 diabetes mellitus. [Erratum appears in Kidney Int 2000 Nov; 58(5):2257]. Kidney International. 2000;58(3):1228-37. Not RCT or controlled trial. [pmid: 10972685].
2446 Lemmer JH Jr., Stanford W, Bonney SL, et al. Aprotinin for coronary artery bypass grafting: effect on postoperative renal function. Annals of Thoracic Surgery. 1995;59(1):132-6. Not CKD treatment. [pmid: 7529484].
2447 Lemos PA, Arampatzis CA, Hoye A, et al. Impact of baseline renal function on mortality after percutaneous coronary intervention with sirolimus-eluting stents or bare metal stents. American Journal of Cardiology. 2005;95(2):167-72. Sample size less than 50 patients. [pmid: 15642546].
2448 Lenaerts A, Codden T, Henry JP, et al. Comparative pilot study of repeated large volume paracentesis vs the combination on clonidine-spironolactone in the treatment of cirrhosis-associated refractory ascites. Gastroenterologie Clinique et Biologique. 2005;29(11):1137-42. Sample size less than 50 patients. [pmid: 16505759].
2449 Lennert T, Luft FC. Kidneys on vacation: the notion of renal work and the introduction of nonpharmacological therapies. American Journal of Kidney Diseases. 1997;29(5):777-80. Not RCT or controlled trial. [pmid: 9159316].
2450 Leoncini G, Martinoli C, Viazzi F, et al. Changes in renal resistive index and urinary albumin excretion in hypertensive patients under long-term treatment with lisinopril or nifedipine GITS. Nephron. 2002;90(2):169-73. Sample size less than 50 patients. [pmid: 11818701].
2451 Leopold JA. Small-molecule glycoprotein IIb/IIIa antagonists and bleeding risk in women: too much of a good thing?. Circulation. 2006;114(13):1344-6. Not CKD treatment. [pmid: 17000918].
2452 Lepor NE. A review of contemporary prevention strategies for radiocontrast nephropathy: a focus on fenoldopam and N-acetylcysteine. Reviews in Cardiovascular Medicine. Suppl 1. 2003;4:S15-20. Not CKD treatment. [pmid: 12556733].
2453 Lerner SA, Schmitt BA, Seligsohn R, et al. Comparative study of ototoxicity and nephrotoxicity in patients randomly assigned to treatment with amikacin or gentamicin. American Journal of Medicine. 1986;80(6B):98-104. Not early CKD. [pmid: 3524221].
2454 Lernfelt B, Landahl S, Johansson P, et al. Haemodynamic and renal effects of felodipine in young and elderly subjects. European Journal of Clinical Pharmacology. 1998;54(8):595-601. Sample size less than 50 patients. [pmid: 9860145].
2455 Leung TK, Luk AOY, So WY, et al. Development and validation of equations estimating glomerular filtration rates in Chinese patients with type 2 diabetes. Kidney International. Apr. 2010;77(8):729-35. Not CKD treatment. [pmid: 20164828].
2456 Leung WYS, So WY, Tong PCY, et al. The renoprotective effects of structured care in a clinical trial setting in type 2 diabetic patients with nephropathy. Nephrology Dialysis Transplantation. 2004;19(10):2519-25. Not CKD treatment.
2457 Levey AS, Adler S, Caggiula AW, et al. Effects of dietary protein restriction on the progression of advanced renal disease in the Modification of Diet in Renal Disease Study. American Journal of Kidney Diseases. 1996;27(5):652-63. Not early CKD. [pmid: 8629624].
2458 Levey AS, Berg RL, Gassman JJ, et al. Creatinine filtration, secretion and excretion during progressive renal disease. Modification of Diet in Renal Disease (MDRD) Study Group. Kidney International - Supplement. 1989;27:S73-80. Not relevant to key questions. [pmid: 2636677].
2459 Levey AS, Bosch JP, Lewis JB, et al. A more accurate method to estimate glomerular filtration rate from serum creatinine: a new prediction equation. Modification of Diet in Renal Disease Study Group. Annals of Internal Medicine. 1999;130(6):461-70. Not RCT or controlled trial. [pmid: 10075613].
2460 Levey AS, Coresh J, Greene T, et al. Using standardized serum creatinine values in the modification of diet in renal disease study equation for estimating glomerular filtration rate. [Erratum appears in Ann Intern Med 2008 Oct 7; 149(7):519]. Annals of Internal Medicine. 2006;145(4):247-54. Not CKD treatment. [pmid: 16908915].
2461 Levey AS, Gassman JJ, Hall PM, et al. Assessing the progression of renal disease in clinical studies: effects of duration of follow-up and regression to the mean. Modification of Diet in Renal Disease (MDRD) Study Group. Journal of the American Society of Nephrology. 1991;1(9):1087-94. Not relevant to key questions. [pmid: 1912407].
2462 Levey AS, Greene T, Schluchter MD, et al. Glomerular filtration rate measurements in clinical trials. Modification of Diet in Renal Disease Study Group and the Diabetes Control and Complications Trial Research Group. Journal of the American Society of Nephrology. 1993;4(5):1159-71. Not CKD treatment. [pmid: 8305642].
2463 Levey AS, Mulrow CD. An editorial update: what level of blood pressure control in chronic kidney disease?. Annals of Internal Medicine. 2005;143(1):79-81. Not CKD treatment. [pmid: 15998758].
2464 Levin A. The treatment of anemia in chronic kidney disease: understandings in 2006. Current Opinion in Nephrology & Hypertension. 2007;16(3):267-71. Sample size less than 50 patients. [pmid: 17420672].
2465 Levin A. Understanding recent haemoglobin trials in CKD: methods and lesson learned from CREATE and CHOIR. [Erratum appears in Nephrol Dial Transplant. 2007 Mar; 22(3):977]. Nephrology Dialysis Transplantation. 2007;22(2):309-12. Not CKD treatment.
2466 Levin A, Duncan L, Djurdjev O, et al. A randomized placebo-controlled double-blind trial of lipid-lowering strategies in patients with renal insufficiency: diet modification with or without fenofibrate. Clinical Nephrology. 2000;53(2):140-6. Sample size less than 50 patients. [pmid: 10711416].
2467 Levine CB, Fahrbach KR, Frame D, et al. Effect of amlodipine on systolic blood pressure. Clinical Therapeutics. 2003;25(1):35-57. Not RCT or controlled trial. [pmid: 12637111].
2468 Levy B, Nace L, Bollaert PE, et al. Comparison of systemic and regional effects of dobutamine and dopexamine in norepinephrine-treated septic shock. Intensive Care Medicine. 1999;25(9):942-8. Sample size less than 50 patients. [pmid: 10501749].
2469 Levy EM. Angiotensin converting enzyme inhibitors: first line therapy in patients with diabetic hypertension?. Current Opinion in Nephrology & Hypertension. 1999;8(3):333-4. Not RCT or controlled trial. [pmid: 10456264].
2470 Levy PY, Corey R, Berger P, et al. Etiologic diagnosis of 204 pericardial effusions. Medicine. 2003;82(6):385-91. Not CKD treatment. [pmid: 14663288].
2471 Levy R, DellaValle A, Atav AS, et al. The relationship between glomerular filtration rate and survival in patients treated with an implantable cardioverter defibrillator. Clinical Cardiology. 2008;31(6):265-9. Not CKD treatment. [pmid: 18543307].
2472 Lewandowski B, Bernacka K, Kucharewicz B, et al. Assessment of beta-2-microglobulin concentration in serum and urine in rheumatoid arthritis. Roczniki Akademii Medycznej W Bialymstoku. 1996;41(2):482-91. Not CKD treatment. [pmid: 9020562].
2473 Lewerin C, Ljungman S, Nilsson-Ehle H. Glomerular filtration rate as measured by serum cystatin C is an important determinant of plasma homocysteine and serum methylmalonic acid in the elderly. Journal of Internal Medicine. 2007;261(1):65-73. Not relevant to key questions. [pmid: 17222169].
2474 Lewis D, Haynes R, Landray MJ. Lipids in chronic kidney disease. Journal of Renal Care. May. Suppl 1. 2010;36:27-33. Not RCT or controlled trial. [pmid: 20586897].
2475 Lewis EJ. Therapeutic interventions in the progression of diabetic nephropathy. American Journal of Hypertension. 1994;7(9 Pt 2):93S-5S. Not CKD treatment. [pmid: 7818842].
2476 Lewis EJ. The role of angiotensin II receptor blockers in preventing the progression of renal disease in patients with type 2 diabetes. American Journal of Hypertension. 2002;15(10 Pt 2):123S-8S. Not RCT or controlled trial. [pmid: 12383593].
2477 Lewis EJ, Hunsicker LG, Rodby RA, et al. A clinical trial in type 2 diabetic nephropathy. American Journal of Kidney Diseases. 2001;38(4 Suppl 1):S191-4. Not RCT or controlled trial. [pmid: 11576953].
2478 Lewis EJ, Lewis JB. Treatment of diabetic nephropathy with angiotensin II receptor antagonist. Clinical & Experimental Nephrology. 2003;7(1):1-8. Not CKD treatment. [pmid: 14586737].
2479 Lewis HM, Wilkins MR, Kendall MJ, et al. Carbidopa does not affect the renal response to atrial natriuretic factor in man. Clinical Science. 1989;77(3):281-5. Not CKD treatment. [pmid: 2553325].
2480 Lewis J, Agodoa L, Cheek D, et al. Comparison of cross-sectional renal function measurements in African Americans with hypertensive nephrosclerosis and of primary formulas to estimate glomerular filtration rate. [Erratum appears in Am J Kidney Dis 2002 Feb; 39(2):444]. American Journal of Kidney Diseases. 2001;38(4):744-53. Not RCT or controlled trial. [pmid: 11576877].
2481 Lewis J, Greene T, Appel L, et al. A comparison of iothalamate-GFR and serum creatinine-based outcomes: acceleration in the rate of GFR decline in the African American Study of Kidney Disease and Hypertension. Journal of the American Society of Nephrology. 2004;15(12):3175-83. Sample size less than 50 patients. [pmid: 15579521].
2482 Lewis NP, Ferguson DR. The effect of enalapril on the renal response to tilting in humans. British Journal of Clinical Pharmacology. 1989;27(2):191-7. Sample size less than 50 patients. [pmid: 2540785].
2483 Lherm T, Troche G, Rossignol M, et al. Renal effects of low-dose dopamine in patients with sepsis syndrome or septic shock treated with catecholamines. Intensive Care Medicine. 1996;22(3):213-9. Sample size less than 50 patients. [pmid: 8727434].
2484 Li G, Yin L, Liu T, et al. Role of probucol in preventing contrast-induced acute kidney injury after coronary interventional procedure. American Journal of Cardiology. 2009;103(4):512-4. Not CKD treatment. [pmid: 19195512].
2485 Li GS, Jiang WL, Yue XD, et al. Effect of astilbin on experimental diabetic nephropathy in vivo and in vitro. Planta Medica. Nov. 2009;75(14):1470-5. Not RCT or controlled trial. [pmid: 19644810].
2486 Li H, Liu Lt, Zhao Wm, et al. Effect of traditional and integrative regimens on quality of life and early renal impairment in elderly patients with isolated systolic hypertension. Chinese Journal of Integrative Medicine. Jun. 2010;16(3):216-21. Follow-up less than 6 months. [pmid: 20694775].
2487 Li J, Schluchter MD. Conditional mixed models adjusting for non-ignorable drop-out with administrative censoring in longitudinal studies. Statistics in Medicine. 2004;23(22):3489-503. Not RCT or controlled trial. [pmid: 15505888].
2488 Li J, Wu HM, Zhang L, et al. Heparin and related substances for preventing diabetic kidney disease. Cochrane Database of Systematic Reviews. 2010;(9):CD005631. Not CKD treatment. [pmid: 20824845].
2489 Li Kam, Wa TC, Freestone S, Samson RR, et al. A comparison of the renal and neuroendocrine effects of two 5-hydroxytryptamine renal prodrugs in normal man. Clinical Science. 1993;85(5):607-14. Follow-up less than 6 months. [pmid: 8287650].
2490 Li Kam, Wa TC, Freestone S, Samson RR, et al. The antinatriuretic action of gamma-L-glutamyl-5-hydroxy-L-tryptophan is dependent on its decarboxylation to 5-hydroxytryptamine in normal man. British Journal of Clinical Pharmacology. 1994;38(3):265-9. Sample size less than 50 patients. [pmid: 7826829].
2491 Li Kam, Wa TC, Freestone S, Samson RR, et al. Renal metabolism and effects of the glutamyl derivatives of L-dopa and 5-hydroxytryptophan in man. Clinical Science. 1996;91(2):177-85. Not CKD treatment. [pmid: 8795441].
2492 Li Q, Zhang CL, Fu ZL, et al. Development of formulae for accurate measurement of the glomerular filtration rate by renal dynamic imaging. Nuclear Medicine Communications. 2007;28(5):407-13. Not CKD treatment. [pmid: 17414891].
2493 Li X, Tian J, Wu J, et al. A comparison of a standard-dose prednisone regimen and mycophenolate mofetil combined with a lower prednisone dose in Chinese adults with idiopathic nephrotic syndrome who were carriers of hepatitis B surface antigen: a prospective cohort study. Clinical Therapeutics. 2009;31(4):741-50. Not RCT or controlled trial. [pmid: 19446147].
2494 Li XS, Zheng WY, Lou SX, et al. Effect of Ginkgo leaf extract on vascular endothelial function in patients with early stage diabetic nephropathy. Chinese Journal of Integrative Medicine. 2009;15(1):26-9. Not early CKD. [pmid: 19271166].
2495 Li XY, Xu M, Wang JG, et al. Serum C-reactive protein (CRP) and microalbuminuria in relation to fasting and 2-h postload plasma glucose in a Chinese population. Clinical Endocrinology. 2009;70(5):691-7. Not RCT or controlled trial. [pmid: 18691271].
2496 Li Y, Tang X, Zhang J, et al. Nutritional support for acute kidney injury. Cochrane Database of Systematic Reviews. 2010;(1):CD005426. Not early CKD. [pmid: 20091576].
2497 Libertino JA, Beckmann CF. Surgery and percutaneous angioplasty in the management of renovascular hypertension. Urologic Clinics of North America. 1994;21(2):235-43. Not RCT or controlled trial. [pmid: 8178391].
2498 Licata G, Scaglione R, Ganguzza A, et al. Effects of amlodipine on renal haemodynamics in mild to moderate hypertensive patients. A randomized controlled study versus placebo. European Journal of Clinical Pharmacology. 1993;45(4):307-11. Sample size less than 50 patients. [pmid: 8299661].
2499 Licata G, Scaglione R, Guillet C, et al. Double-blind controlled study of rilmenidine versus hydrochlorothiazide in mild hypertension: clinical and renal haemodynamic evaluation. Journal of Human Hypertension. 1993;7(2):153-7. Sample size less than 50 patients. [pmid: 8510088].
2500 Licker M, Bednarkiewicz M, Neidhart P, et al. Preoperative inhibition of angiotensin-converting enzyme improves systemic and renal haemodynamic changes during aortic abdominal surgery. British Journal of Anaesthesia. 1996;76(5):632-9. Sample size less than 50 patients. [pmid: 8688261].
2501 Lieberman SA, Holloway L, Marcus R, et al. Interactions of growth hormone and parathyroid hormone in renal phosphate, calcium, and calcitriol metabolism and bone remodeling in postmenopausal women. Journal of Bone & Mineral Research. 1994;9(11):1723-8. Sample size less than 50 patients. [pmid: 7863823].
2502 Lievre M, Marre M, Chatellier G, et al. The non-insulin-dependent diabetes, hypertension, microalbuminuria or proteinuria, cardiovascular events, and ramipril (DIABHYCAR) study: design, organization, and patient recruitment. DIABHYCAR Study Group. Controlled Clinical Trials. 2000;21(4):383-96. Not RCT or controlled trial. [pmid: 10913814].
2503 Ligtenberg G, Blankestijn PJ, Oey PL, et al. Reduction of sympathetic hyperactivity by enalapril in patients with chronic renal failure. New England Journal of Medicine. 1999;340(17):1321-8. Sample size less than 50 patients. [pmid: 10219067].
2504 Lim SC, Koh AFY, Goh SK, et al. Angiotensin receptor antagonist vs. angiotensin-converting enzyme inhibitor in Asian subjects with type 2 diabetes and albuminuria - a randomized crossover study. Diabetes, Obesity & Metabolism. 2007;9(4):477-82. Sample size less than 50 patients.
2505 Lim VS. Recombinant human erythropoietin in predialysis patients. American Journal of Kidney Diseases. 1991;18(4 Suppl 1):34-7. Not relevant to key questions. [pmid: 1928077].
2506 Lim VS, DeGowin RL, Zavala D, et al. Recombinant human erythropoietin treatment in pre-dialysis patients. A double-blind placebo-controlled trial. Annals of Internal Medicine. 1989;110(2):108-14. Follow-up less than 6 months. [pmid: 2909202].
2507 Lim VS, Wolfson M, Yarasheski KE, et al. Leucine turnover in patients with nephrotic syndrome: evidence suggesting body protein conservation. Journal of the American Society of Nephrology. 1998;9(6):1067-73. Not RCT or controlled trial. [pmid: 9621290].
2508 Lim VS, Zavala DC, Flanigan MJ, et al. Blunted peripheral tissue responsiveness to thyroid hormone in uremic patients. Kidney International. 1987;31(3):808-14. Sample size less than 50 patients. [pmid: 3573541].
2509 Lim W, Dentali F, Eikelboom JW, et al. Meta-analysis: low-molecular-weight heparin and bleeding in patients with severe renal insufficiency. Annals of Internal Medicine. 2006;144(9):673-84. Not RCT or controlled trial. [pmid: 16670137].
2510 Lin CC, Chuang FR, Lee CH, et al. The renal-sparing efficacy of basiliximab in adult living donor liver transplantation. Liver Transplantation. 2005;11(10):1258-64. Follow-up less than 6 months. [pmid: 16184544].
2511 Lin J, Bonventre JV. Prevention of radiocontrast nephropathy. Current Opinion in Nephrology & Hypertension. 2005;14(2):105-10. Not relevant to key questions. [pmid: 15687835].
2512 Lin JL, Ho HH, Yu CC. Chelation therapy for patients with elevated body lead burden and progressive renal insufficiency. A randomized, controlled trial. Annals of Internal Medicine. 1999;130(1):7-13. Sample size less than 50 patients. [pmid: 9890856].
2513 Lin JL, Lin-Tan DT, Yu CC, et al. Environmental exposure to lead and progressive diabetic nephropathy in patients with type II diabetes. Kidney International. 2006;69(11):2049-56. Not relevant to key questions. [pmid: 16641918].
2514 Lin JL, Tan DT, Hsu KH, et al. Environmental lead exposure and progressive renal insufficiency. Archives of Internal Medicine. 2001;161(2):264-71. Not CKD treatment. [pmid: 11176742].
2515 Lin JL, Yu CC, Lin-Tan DT, et al. Lead chelation therapy and urate excretion in patients with chronic renal diseases and gout. Kidney International. 2001;60(1):266-71. Sample size less than 50 patients. [pmid: 11422760].
2516 Lin JL, Lin-Tan DT, Hsu KH, et al. Environmental lead exposure and progression of chronic renal diseases in patients without diabetes. New England Journal of Medicine. 2003;348(4):277-86. Not CKD treatment. [pmid: 12540640].
2517 Lin JL, Lin-Tan DT, Li YJ, et al. Low-level environmental exposure to lead and progressive chronic kidney diseases. American Journal of Medicine. 2006;119(8):707.e1-9. Not relevant to key questions. [pmid: 16887418].
2518 Lin S. New research areas for keto acid/amino acid-supplemented protein diets. Journal of Renal Nutrition. 2009;19(5 Suppl):S30-2. Not RCT or controlled trial. [pmid: 19712875].
2519 Lin SL, Chen YM, Chiang WC, et al. Effect of pentoxifylline in addition to losartan on proteinuria and GFR in CKD: a 12-month randomized trial. American Journal of Kidney Diseases. 2008;52(3):464-74. Not RCT or controlled trial. [pmid: 18617301].
2520 Lind L, Wengle B, Sorensen OH, et al. Delayed hypersensitivity in primary and secondary hyperparathyroidism. Treatment with active vitamin D. Experimental & Clinical Endocrinology. 1990;95(2):271-4. Not CKD treatment. [pmid: 2365023].
2521 Lindeman RD, Romero L, Liang HC, et al. Prevalence of proteinuria/microalbuminuria in an elderly urban, biethnic community. Geriatric Nephrology & Urology. 1998;8(3):123-30. Not RCT or controlled trial. [pmid: 10221169].
2522 Lindenfeld J, Borer J, Armstrong PW. Losartan potassium (Cozaar). Circulation. 2002;105(16):e9100. Not relevant to key questions. [pmid: 11997294].
2523 Lindsay RM, Spanner E, Heidenheim AP, et al. A multicenter study of short hour dialysis using AN69S. Preliminary results. ASAIO Transactions. 1991;37(3):M465-7. Not CKD treatment. [pmid: 1751239].
2524 Lindsay RM, Spanner E, Heidenheim AP, et al. The influence of dialysis membrane upon protein catabolic rate. ASAIO Transactions. 1991;37(3):M134-5. Not CKD treatment. [pmid: 1751080].
2525 Linnebjerg H, Kothare PA, Park S, et al. Effect of renal impairment on the pharmacokinetics of exenatide. British Journal of Clinical Pharmacology. 2007;64(3):317-27. Sample size less than 50 patients. [pmid: 17425627].
2526 Lin-Tan DT, Lin JL, Yen TH, et al. Long-term outcome of repeated lead chelation therapy in progressive non-diabetic chronic kidney diseases. Nephrology Dialysis Transplantation. 2007;22(10):2924-31. Not RCT or controlled trial.
2527 Lintott CJ, Scott RS, Bremer JM, et al. Fluvastatin for dyslipoproteinemia, with or without concomitant chronic renal insufficiency. American Journal of Cardiology. 1995;76(2):97A-101A. Sample size less than 50 patients. [pmid: 7793418].
2528 Liou HH, Chiang SS, Wu SC, et al. Intravenous infusion or nebulization of salbutamol for treatment of hyperkalemia in patients with chronic renal failure. Chung Hua i Hsueh Tsa Chih - Chinese Medical Journal. 1994;53(5):276-81. Sample size less than 50 patients.
2529 Liou HH, Huang TP, Campese VM. Effect of long-term therapy with captopril on proteinuria and renal function in patients with non-insulin-dependent diabetes and with non-diabetic renal diseases. Nephron. 1995;69(1):41-8. Sample size less than 50 patients. [pmid: 7891796].
2530 Lipkin GW, Dawnay AB, Harwood SM, et al. Enhanced natriuretic response to neutral endopeptidase inhibition in patients with moderate chronic renal failure. Kidney International. 1997;52(3):792-801. Sample size less than 50 patients. [pmid: 9291201].
2531 Lips P, Wiersinga A, van Ginkel FC, et al. The effect of vitamin D supplementation on vitamin D status and parathyroid function in elderly subjects. Journal of Clinical Endocrinology & Metabolism. 1988;67(4):644-50. Not CKD treatment. [pmid: 3417845].
2532 Lipton A. The safety of zoledronic acid. Expert Opinion on Drug Safety. 2007;6(3):305-13. Sample size less than 50 patients. [pmid: 17480179].
2533 Lishner M, Lang R, Jutrin I, et al. Analgesic effect of ceruletide compared with pentazocine in biliary and renal colic: a prospective, controlled, double-blind study. Drug Intelligence & Clinical Pharmacy. 1985;19(6):433-6. Follow-up less than 6 months. [pmid: 3891284].
2534 Lissoni P, Malugani F, Malysheva O, et al. Neuroimmunotherapy of untreatable metastatic solid tumors with subcutaneous low-dose interleukin-2, melatonin and naltrexone: modulation of interleukin-2-induced antitumor immunity by blocking the opioid system. Neuroendocrinology Letters. 2002;23(4):341-4. Not CKD treatment. [pmid: 12195238].
2535 Lit YZ, Meyer T. Managing diabetic nephropathy: recent studies. Current Opinion in Nephrology & Hypertension. 2006;15(2):111-6. Not RCT or controlled trial. [pmid: 16481875].
2536 Littlewood KJ, Greiner W, Baum D, et al. Adjunctive treatment with moxonidine versus nitrendipine for hypertensive patients with advanced renal failure: a cost-effectiveness analysis. BMC Nephrology. 2007;8:9. Not RCT or controlled trial. [pmid: 17645811].
2537 Littlewood TJ, Alikhan R. The use of intravenous iron in patients with cancer-related anaemia. British Journal of Haematology. 2008;141(6):751-6. Sample size less than 50 patients. [pmid: 18410455].
2538 Litz RJ, Hubler M, Lorenz W, et al. Renal responses to desflurane and isoflurane in patients with renal insufficiency. Anesthesiology. 2002;97(5):1133-6. Not CKD treatment. [pmid: 12411797].
2539 Liu BC, Chen L, Sun J, et al. Connective tissue growth factor-mediated angiotensin II-induced hypertrophy of proximal tubular cells. Nephron. Experimental Nephrology. 2006;103(1):e16-26. Not RCT or controlled trial. [pmid: 16374037].
2540 Liu C, Chen H, Zhou C, et al. Potent potentiating diuretic effects of prednisone in congestive heart failure. Journal of Cardiovascular Pharmacology. 2006;48(4):173-6. Not CKD treatment. [pmid: 17086096].
2541 Liu C, Liu G, Zhou C, et al. Potent diuretic effects of prednisone in heart failure patients with refractory diuretic resistance. Canadian Journal of Cardiology. 2007;23(11):865-8. Not RCT or controlled trial. [pmid: 17876376].
2542 Liu Q, Garner P, Wang Y, et al. Drugs and herbs given to prevent hepatotoxicity of tuberculosis therapy: systematic review of ingredients and evaluation studies. BMC Public Health. 2008;8:365. Not CKD treatment. [pmid: 18939987].
2543 Liu R, Nair D, Ix J, et al. N-acetylcysteine for the prevention of contrast-induced nephropathy. A systematic review and meta-analysis. Journal of General Internal Medicine. 2005;20(2):193-200. Not RCT or controlled trial. [pmid: 15836554].
2544 Liu X, Du J, Cai J, et al. Clinical systematic observation of Kangxin capsule curing vascular dementia of senile kidney deficiency and blood stagnation type. Journal of Ethnopharmacology. 2007;112(2):350-5. Not RCT or controlled trial. [pmid: 17442512].
2545 Livio M, Mannucci PM, Vigano G, et al. Conjugated estrogens for the management of bleeding associated with renal failure. New England Journal of Medicine. 1986;315(12):731-5. Sample size less than 50 patients. [pmid: 3018561].
2546 Ljungman S, Wikstrand J, Hartford M, et al. Effects of long-term antihypertensive treatment and aging on renal function and albumin excretion in primary hypertension. American Journal of Hypertension. 1993;6(7 Pt 1):554-63. Sample size less than 50 patients. [pmid: 8397995].
2547 Ljutic D, Perkovic D, Rumboldt Z, et al. Comparison of ondansetron with metoclopramide in the symptomatic relief of uremia-induced nausea and vomiting. Kidney & Blood Pressure Research. 2002;25(1):61-4. Sample size less than 50 patients. [pmid: 11834879].
2548 Llanos A, Cieza J, Bernardo J, et al. Effect of salt supplementation on amphotericin B nephrotoxicity. Kidney International. 1991;40(2):302-8. Not CKD treatment. [pmid: 1942779].
2549 Lloret J, Vila A, Puig X, et al. Nifedipine in the treatment of renal colic. Methods & Findings in Experimental & Clinical Pharmacology. 1986;8(9):575-9. Sample size less than 50 patients. [pmid: 3773599].
2550 Lobo ED, Heathman M, Kuan HY, et al. Effects of varying degrees of renal impairment on the pharmacokinetics of duloxetine: analysis of a single-dose phase I study and pooled steady-state data from phase II/III trials. Clinical Pharmacokinetics. May. 1. 2010;49(5):311-21. Not RCT or controlled trial. [pmid: 20384393].
2551 Locatelli F. Controlled study of protein-restricted diet in chronic renal failure. Contributions to Nephrology. 1989;75:141-6. Not relevant to key questions. [pmid: 2697498].
2552 Locatelli F. Dietary compliance in patients with chronic renal failure: experience in a northern Italy trial. Contributions to Nephrology. 1990;81:102-6. Not CKD treatment. [pmid: 2093485].
2553 Locatelli F, Aljama P, Canaud B, et al. Target haemoglobin to aim for with erythropoiesis-stimulating agents: a position statement by ERBP following publication of the Trial to reduce cardiovascular events with Aranesp therapy (TREAT) study. Nephrology Dialysis Transplantation. Sep. 2010;25(9):2846-50. Not CKD treatment.
2554 Locatelli F, Canaud B, Eckardt KU, et al. Oxidative stress in end-stage renal disease: an emerging threat to patient outcome. Nephrology Dialysis Transplantation. 2003;18(7):1272-80. Not early CKD.
2555 Locatelli F, Carbarns IR, Maschio G, et al. Long-term progression of chronic renal insufficiency in the AIPRI Extension Study. The Angiotensin-Converting-Enzyme Inhibition in Progressive Renal Insufficiency Study Group. Kidney International - Supplement. 1997;63:S63-6. Not relevant to key questions. [pmid: 9407424].
2556 Locatelli F, Covic A, Macdougall IC, et al. ORAMA: a study to investigate EBPG impact on renal anaemia - design and baseline data. Journal of Nephrology. 2008;21(4):592-603. Not CKD treatment. [pmid: 18651551].
2557 Locatelli F, Del Vecchio L, Andrulli S, et al. The role of underlying nephropathy in the progression of renal disease. Kidney International - Supplement. 2000;75:S49-55. Not CKD treatment. [pmid: 10828762].
2558 Locatelli F, Del Vecchio L, Marai P, et al. The renoprotective effect of antihypertensive drugs. Journal of Nephrology. 1998;11(6):330-6. Not RCT or controlled trial. [pmid: 10048500].
2559 Locatelli F, Del Vecchio L, Pozzoni P. Clinical benefits of slowing the progression of renal failure. Kidney International - Supplement. 2005;(99):S152-6. Not relevant to key questions. [pmid: 16336569].
2560 Locatelli F, Del Vecchio L, Pozzoni P. Anemia and cardiovascular risk: the lesson of the CREATE Trial. Journal of the American Society of Nephrology. 2006;17(12 Suppl 3):S262-6. Not RCT or controlled trial. [pmid: 17130272].
2561 Locatelli F, Del Vecchio L, Pozzoni P. Treating anemia at different stages of renal disease. Journal of Nephrology. Suppl 12. 2007;20:S33-8. Not relevant to key questions. [pmid: 18050140].
2562 Locatelli F, Del Vecchio L, Pozzoni P, et al. Is it the agent or the blood pressure level that matters for renal and vascular protection in chronic nephropathies?. Kidney International - Supplement. 2005;(93):S15-9. Not RCT or controlled trial. [pmid: 15613061].
2563 Locatelli F, Manzoni C, Marcelli D. Factors affecting progression of renal insufficiency. Mineral & Electrolyte Metabolism. 1997;23(3-6):301-5. Not RCT or controlled trial. [pmid: 9387138].
2564 Locatelli F, Manzoni C, Marcelli D. Treatment of hypertension in chronic renal insufficiency. Journal of Nephrology. 1997;10(4):220-3. Not RCT or controlled trial. [pmid: 9377731].
2565 Locatelli F, Marcelli D, Comelli M, et al. Proteinuria and blood pressure as causal components of progression to end-stage renal failure. Northern Italian Cooperative Study Group. Nephrology Dialysis Transplantation. 1996;11(3):461-7. Not RCT or controlled trial.
2566 Locatelli F, Marcelli D, Tentori F, et al. Controlled trials on low-protein diet: effects on chronic renal insufficiency progression. Renal Failure. 1993;15(3):407-13. Not RCT or controlled trial. [pmid: 8516499].
2567 Locatelli F, Olivares J, Walker R, et al. Novel erythropoiesis stimulating protein for treatment of anemia in chronic renal insufficiency. Kidney International. 2001;60(2):741-7. Not CKD treatment. [pmid: 11473657].
2568 Locatelli F, Vecchio LD, Pozzoni P. The importance of early detection of chronic kidney disease. Nephrology Dialysis Transplantation. Suppl 11. 2002;17:2-7. Not relevant to key questions.
2569 Locatelli MC, D'Antona A, Labianca R, et al. A phase II study of combination chemotherapy in advanced ovarian carcinoma with cisplatin and cyclophosphamide plus reduced glutathione as potential protective agent against cisplatin toxicity. Tumori. 1993;79(1):37-9. Not CKD treatment. [pmid: 8497920].
2570 Lodise TP, Lomaestro B, Graves J, et al. Larger vancomycin doses (at least four grams per day) are associated with an increased incidence of nephrotoxicity. Antimicrobial Agents & Chemotherapy. 2008;52(4):1330-6. Not CKD treatment. [pmid: 18227177].
2571 Loeb M, Neupane B, Walter SD, et al. Environmental risk factors for community-acquired pneumonia hospitalization in older adults. Journal of the American Geriatrics Society. 2009;57(6):1036-40. Not CKD treatment. [pmid: 19467147].
2572 Loef BG, Epema AH, Navis G, et al. Off-pump coronary revascularization attenuates transient renal damage compared with on-pump coronary revascularization. Chest. 2002;121(4):1190-4. Not early CKD. [pmid: 11948052].
2573 Loef BG, Henning RH, Epema AH, et al. Effect of dexamethasone on perioperative renal function impairment during cardiac surgery with cardiopulmonary bypass. British Journal of Anaesthesia. 2004;93(6):793-8. Not relevant to key questions. [pmid: 15377582].
2574 Logan A. BENEDICT in the treatment of hypertension. Current Hypertension Reports. 2005;7(2):121-3. Not RCT or controlled trial. [pmid: 15748536].
2575 London GM. Efficacy of indapamide 1.5 mg, sustained release, in the lowering of systolic blood pressure. Journal of Human Hypertension. Suppl 2. 2004;18:S9-S14. Not RCT or controlled trial. [pmid: 15592572].
2576 London GM, Pannier B, Guerin AP, et al. Cardiac hypertrophy, aortic compliance, peripheral resistance, and wave reflection in end-stage renal disease. Comparative effects of ACE inhibition and calcium channel blockade. Circulation. 1994;90(6):2786-96. Not early CKD. [pmid: 7994822].
2577 Lopes NH, da Silva Paulitsch F, Pereira A, et al. Mild chronic kidney dysfunction and treatment strategies for stable coronary artery disease. Journal of Thoracic & Cardiovascular Surgery. 2009;137(6):1443-9. Not CKD treatment. [pmid: 19464462].
2578 Lopes T, Dias JS, Marcelino J, et al. An assessment of the clinical efficacy of intranasal desmopressin spray in the treatment of renal colic. BJU International. 2001;87(4):322-5. Not CKD treatment. [pmid: 11251523].
2579 Lopez LM, Santiago TM. Isradipine--another calcium-channel blocker for the treatment of hypertension and angina. Annals of Pharmacotherapy. 1992;26(6):789-99. Not relevant to key questions. [pmid: 1535246].
2580 Lopez MC, Belizan JM, Villar J, et al. The measurement of diastolic blood pressure during pregnancy: which Korotkoff phase should be used?. American Journal of Obstetrics & Gynecology. 1994;170(2):574-8. Not RCT or controlled trial. [pmid: 8116715].
2581 Lopez-Suarez A, Beltran-Robles M, Elvira-Gonzalez J, et al. Comparison of the MDRD and the CKD-EPI equations to estimate the glomerular filtration rate in the general population. Medicina Clinica. May. 15. 2010;134(14):617-23. Not early CKD. [pmid: 20226480].
2582 Lorenzano E, Badalamenti S, Scotti A, et al. Renal effects of imidazole-2-hydroxybenzoate in patients with compensated liver cirrhosis. International Journal of Clinical Pharmacology, Therapy, & Toxicology. 1992;30(7):225-9. Sample size less than 50 patients.
2583 Lottenberg R, Hassell KL. An evidence-based approach to the treatment of adults with sickle cell disease. Hematology. 2005:58-65. Not adult population.
2584 Loudon JAZ, Groom KM, Bennett PR. Prostaglandin inhibitors in preterm labour. Best Practice & Research in Clinical Obstetrics & Gynaecology. 2003;17(5):731-44. Not CKD treatment.
2585 Loup R, Favre L, Vallotton MB. Effect of noradrenaline, vasopressin and angiotensin II on renal prostaglandins in man. Clinical Science. 1986;70(4):371-7. Sample size less than 50 patients. [pmid: 3698513].
2586 Lovell HG. Angiotensin converting enzyme inhibitors in normotensive diabetic patients with microalbuminuria. Cochrane Database of Systematic Reviews. 2000;(2):CD002183. Not relevant to key questions. [pmid: 10796871].
2587 Lovell HG. Angiotensin converting enzyme inhibitors in normotensive diabetic patients with microalbuminuria. Cochrane Database of Systematic Reviews. 2001;(1):CD002183. Not relevant to key questions. [pmid: 11279757].
2588 Lovell HG. WITHDRAWN: Angiotensin converting enzyme inhibitors in normotensive diabetic patients with microalbuminuria. Cochrane Database of Systematic Reviews. 2006;(1):CD002183. Sample size less than 50 patients.
2589 Lu M, Cohen MH, Rieves D, et al. FDA report: Ferumoxytol for intravenous iron therapy in adult patients with chronic kidney disease. American Journal of Hematology. May. 2010;85(5):315-9. Follow-up less than 6 months. [pmid: 20201089].
2590 Lubrano R, Marandola M, Antonucci A, et al. Hypotensive anesthesia with propofol and remifentanil: protective effect of alpha-tocopherol on renal function. Journal of Clinical Anesthesia. 2008;20(3):164-9. Not CKD treatment. [pmid: 18502357].
2591 Lucarini AR, Arrighi P, Favilla S, et al. The influence of dopamine-1 receptor blockade on the humoral and renal effects of low-dose atrial natriuretic factor in human hypertensives. Journal of Hypertension - Supplement. 1989;7(6):S230-1. Sample size less than 50 patients.
2592 Lucarini AR, Salvetti A. Haemodynamic (systemic and renal) and humoral interactions between nicardipine and domperidone in hypertensives. Journal of Hypertension - Supplement. 1987;5(5):S571-4. Sample size less than 50 patients.
2593 Lucarini AR, Salvetti A. Systemic and renal hemodynamic effects of celiprolol in essential hypertensives. American Journal of Cardiology. 1988;61(5):45C-8C. Sample size less than 50 patients.
2594 Luchner A, Hengstenberg C, Lowel H, et al. Effect of compensated renal dysfunction on approved heart failure markers: direct comparison of brain natriuretic peptide (BNP) and N-terminal pro-BNP. Hypertension. 2005;46(1):118-23. Not RCT or controlled trial. [pmid: 15939804].
2595 Luchsinger A, Velasco M, Urbina A, et al. Comparative effects of dopaminergic agonists on cardiovascular, renal, and renin-angiotensin systems in hypertensive patients. Journal of Clinical Pharmacology. 1992;32(1):55-60. Sample size less than 50 patients. [pmid: 1346790].
2596 Lucker PW, Venitz J, Hey B, et al. Pharmacodynamic and pharmacokinetic correlation of muzolimine with and without aluminium hydroxide. Zeitschrift fur Kardiologie. Suppl 2. 1985;74:141-4. Sample size less than 50 patients. [pmid: 4002789].
2597 Ludlow M, Luxton G, Mathew T. Effects of fluoridation of community water supplies for people with chronic kidney disease. Nephrology Dialysis Transplantation. 2007;22(10):2763-7. Sample size less than 50 patients.
2598 Luft FC. STOPPING at the CAPPP of good HOPE. Nephrology Dialysis Transplantation. 2000;15(4):451-2. Not RCT or controlled trial.
2599 Luft FC. Hypertensive nephrosclerosis: update. Current Opinion in Nephrology & Hypertension. 2004;13(2):147-54. Not CKD treatment. [pmid: 15202608].
2600 Luik PT, Hoogenberg K, Van Der Kleij FGH, et al. Short-term moderate sodium restriction induces relative hyperfiltration in normotensive normoalbuminuric Type I diabetes mellitus. Diabetologia. 2002;45(4):535-41. Sample size less than 50 patients. [pmid: 12032630].
2601 Luippold G, Benohr P, Piesch C, et al. Urinary dopamine excretion in healthy volunteers: effect of sodium diet and acute water load. Pflugers Archiv - European Journal of Physiology. 2000;440(1):28-33. Not early CKD. [pmid: 10863994].
2602 Luippold G, Schneider S, Stefanescu A, et al. Dopamine D2-like receptors and amino acid-induced glomerular hyperfiltration in humans. British Journal of Clinical Pharmacology. 2001;51(5):415-21. Not early CKD. [pmid: 11421998].
2603 Luke DR, Sarnoski TP, Bell N, et al. Influence of pentoxifylline on renal function in HIV-seropositive patients. Renal Failure. 1993;15(2):181-8. Sample size less than 50 patients. [pmid: 8469785].
2604 Luke RG, Boyle JA. Renal effects of amphotericin B lipid complex. American Journal of Kidney Diseases. 1998;31(5):780-5. Not CKD treatment. [pmid: 9590187].
2605 Luksch A, Polak K, Matulla B, et al. Glucose and insulin exert additive ocular and renal vasodilator effects on healthy humans. Diabetologia. 2001;44(1):95-103. Not early CKD. [pmid: 11206417].
2606 Lumlertgul D, Keoplung M, Sitprija V, et al. Furosemide and dopamine in malarial acute renal failure. Nephron. 1989;52(1):40-4. Not CKD treatment. [pmid: 2651949].
2607 Lumlertgul D, Wongmekiat O, Sirivanichai C, et al. Intrarenal infusion of gallopamil in acute renal failure. A preliminary report. Drugs. Suppl 1. 1991;42:44-50. Not CKD treatment. [pmid: 1718694].
2608 Lund B, Hansen OP, Hansen HH, et al. Combination therapy with carboplatin/cisplatin/ifosfamide/etoposide in ovarian cancer. Seminars in Oncology. 1992;19(1 Suppl 1):26-9. Not CKD treatment. [pmid: 1411618].
2609 Lundby B, Berg KJ, Lien HH, et al. A double blind study to evaluate the tolerability of gadodiamide injection and its effect on renal function in patients undergoing cerebral magnetic resonance imaging. British Journal of Radiology. 1993;66(790):871-6. Not CKD treatment. [pmid: 8220968].
2610 Lungershausen YK, Howe PR, Clifton PM, et al. Evaluation of an omega-3 fatty acid supplement in diabetics with microalbuminuria. Annals of the New York Academy of Sciences. 1997;827:369-81. Follow-up less than 6 months. [pmid: 9329768].
2611 Luno J, Barrio V, Goicoechea MA, et al. Effects of dual blockade of the renin-angiotensin system in primary proteinuric nephropathies. Kidney International - Supplement. 2002;(82):S47-52. Sample size less than 50 patients. [pmid: 12410855].
2612 Luntz SP, Unnebrink K, Seibert-Grafe M, et al. HEGPOL: randomized, placebo controlled, multicenter, double-blind clinical trial to investigate hepatoprotective effects of glycine in the postoperative phase of liver transplantation. [ISRCTN69350312]. BMC Surgery. 2005;5:18. Not relevant to key questions. [pmid: 16105183].
2613 Luss H, Mitrovic V, Seferovic PM, et al. Renal effects of ularitide in patients with decompensated heart failure. American Heart Journal. 2008;155(6):1012.e1-8. Not CKD treatment. [pmid: 18513512].
2614 Luts L, Bergenfelz A, Alumets J, et al. Parathyroid function and histology in patients with parathyroid adenoma: correlation of clinical and morphologic findings. World Journal of Surgery. 1997;21(5):553-63. Not RCT or controlled trial. [pmid: 9204747].
2615 Lynch AI, Boerwinkle E, Davis BR, et al. Antihypertensive pharmacogenetic effect of fibrinogen-beta variant -455G>A on cardiovascular disease, end-stage renal disease, and mortality: the GenHAT study. Pharmacogenetics & Genomics. 2009;19(6):415-21. Not CKD treatment. [pmid: 19352213].
2616 Lyubimova NV, Topchieva SV, Averinova SG, et al. Modern methods for diagnosis and monitoring of nephrotoxicity during antitumor therapy with platinum derivatives. Bulletin of Experimental Biology & Medicine. 2000;130(9):886-91. Not early CKD. [pmid: 11177273].
2617 Ma WW, Jimeno A. Temsirolimus. Drugs of Today. 2007;43(10):659-69. Not RCT or controlled trial. [pmid: 17987219].
2618 Ma X. Clinical analysis for the acupuncture treatment in 42 cases of gouty renal damage. Journal of Traditional Chinese Medicine. 2004;24(3):185-7. Sample size less than 50 patients. [pmid: 15510795].
2619 Ma YC, Zuo L, Chen JH, et al. Improved GFR estimation by combined creatinine and cystatin C measurements. Kidney International. 2007;72(12):1535-42. Not RCT or controlled trial. [pmid: 17898698].
2620 Ma YC, Zuo L, Chen JH, et al. Modified glomerular filtration rate estimating equation for Chinese patients with chronic kidney disease. [Erratum appears in J Am Soc Nephrol. 2006 Dec;17(12):3540]. Journal of the American Society of Nephrology. 2006;17(10):2937-44. Not RCT or controlled trial. [pmid: 16988059].
2621 Maccariello ER, Genelhu de Abreu Fagundes V, Francischetti EA. The effects of isradipine and spirapril as monotherapy and combined therapy on blood pressure, renal hemodynamics, natriuresis, and urinary kallikrein in hypertensive nephropathy. American Journal of Hypertension. 1997;10(5 Pt 1):541-5. Follow-up less than 6 months. [pmid: 9160765].
2622 Maccubbin D, Tipping D, Kuznetsova O, et al. Hypophosphatemic effect of niacin in patients without renal failure: a randomized trial. Clinical Journal of The American Society of Nephrology: CJASN. Apr. 2010;5(4):582-9. Not CKD treatment. [pmid: 20299362].
2623 Macdonald JH, Marcora SM, Jibani MM, et al. Nandrolone decanoate as anabolic therapy in chronic kidney disease: a randomized phase II dose-finding study. Nephron. 2007;106(3):c125-35. Follow-up less than 6 months. [pmid: 17522475].
2624 MacDonald TM. Metoclopramide, domperidone and dopamine in man: actions and interactions. European Journal of Clinical Pharmacology. 1991;40(3):225-30. Sample size less than 50 patients. [pmid: 2060557].
2625 MacDonald TM, Jeffrey RF, Lee MR. The renal and haemodynamic effects of a 10 h infusion of glutamyl-L-dopa in normal man. British Journal of Clinical Pharmacology. 1989;27(6):811-22. Not CKD treatment. [pmid: 2527048].
2626 Macdougall IC. How to improve survival in pre-dialysis patients. Nephron. Suppl 1. 2000;85:15-22. Not RCT or controlled trial. [pmid: 10754423].
2627 Macdougall IC, Robson R, Opatrna S, et al. Pharmacokinetics and pharmacodynamics of intravenous and subcutaneous continuous erythropoietin receptor activator (C.E.R.A.) in patients with chronic kidney disease. Clinical Journal of The American Society of Nephrology: CJASN. 2006;1(6):1211-5. Not RCT or controlled trial. [pmid: 17699350].
2628 Macdougall IC. Steering Committee of the Ct, Group CS. CREATE: new strategies for early anaemia management in renal insufficiency. Nephrology Dialysis Transplantation. Suppl 2. 2003;18:ii13-6. Not early CKD.
2629 Macdougall IC, Walker R, Provenzano R, et al. C.E.R.A. corrects anemia in patients with chronic kidney disease not on dialysis: results of a randomized clinical trial. Clinical Journal of The American Society of Nephrology: CJASN. 2008;3(2):337-47. Not CKD treatment. [pmid: 18287255].
2630 Macedo E, Abdulkader R, Castro I, et al. Lack of protection of N-acetylcysteine (NAC) in acute renal failure related to elective aortic aneurysm repair-a randomized controlled trial. Nephrology Dialysis Transplantation. 2006;21(7):1863-9. Sample size less than 50 patients.
2631 MacGregor DA, Butterworth JFt, Zaloga CP, et al. Hemodynamic and renal effects of dopexamine and dobutamine in patients with reduced cardiac output following coronary artery bypass grafting. Chest. 1994;106(3):835-41. Sample size less than 50 patients. [pmid: 7915979].
2632 MacGregor GA. Blood pressure, angiotensin-converting enzyme (ACE) inhibitors, and the kidney. American Journal of Medicine. 1992;92(4B):20S-7S. Not relevant to key questions. [pmid: 1580276].
2633 MacGregor MS, Deighan CJ, Rodger RSC, et al. A prospective open-label randomised trial of quinapril and/or amlodipine in progressive non-diabetic renal failure. Nephron. 2005;101(3):c139-49. Sample size less than 50 patients. [pmid: 16015004].
2634 Macisaac RJ, Jerums G, Weekes AJ, et al. Patterns of glycaemic control in Australian primary care (NEFRON 8). [Erratum appears in Intern Med J. 2009 Dec; 39(12):862]. Internal Medicine Journal. Aug. 2009;39(8):512-8. Not CKD treatment. [pmid: 19220533].
2635 Mackay IG, Macnicol AM, Smith HJ, et al. Intrinsic sympathomimetic activity of cardioselective beta-adrenoceptor blockers and effects on renal function. British Journal of Clinical Pharmacology. 1985;20(3):197-203. Sample size less than 50 patients. [pmid: 2864052].
2636 MacKinnon M, Leenen FHH, Ruzicka M. Does ALLHAT change the management of hypertension in chronic kidney disease?. Current Hypertension Reports. 2005;7(6):474-83. Not RCT or controlled trial. [pmid: 16386205].
2637 MacKinnon M, Shurraw S, Akbari A, et al. Combination therapy with an angiotensin receptor blocker and an ACE inhibitor in proteinuric renal disease: a systematic review of the efficacy and safety data. American Journal of Kidney Diseases. 2006;48(1):8-20. Not relevant to key questions. [pmid: 16797382].
2638 MacLean CH, Mojica WA, Morton SC, et al. Effects of omega-3 fatty acids on lipids and glycemic control in type II diabetes and the metabolic syndrome and on inflammatory bowel disease, rheumatoid arthritis, renal disease, systemic lupus erythematosus, and osteoporosis. Evidence Report: Technology Assessment. 2004;(89):1-4. Follow-up less than 6 months. [pmid: 15133890].
2639 MacLeod MJ, McLay J. Drug treatment of hypertension complicating diabetes mellitus. Drugs. 1998;56(2):189-202. Not RCT or controlled trial. [pmid: 9711444].
2640 MacNeill BD, Harding SA, Bazari H, et al. Prophylaxis of contrast-induced nephropathy in patients undergoing coronary angiography. Catheterization & Cardiovascular Interventions. 2003;60(4):458-61. Not relevant to key questions. [pmid: 14624421].
2641 Madero M, Sarnak MJ, Wang X, et al. Uric acid and long-term outcomes in CKD. American Journal of Kidney Diseases. 2009;53(5):796-803. Follow-up less than 6 months. [pmid: 19303683].
2642 Madero M, Sarnak MJ, Wang X, et al. Body mass index and mortality in CKD. American Journal of Kidney Diseases. 2007;50(3):404-11. Sample size less than 50 patients. [pmid: 17720519].
2643 Madkour H, Gadallah M, Riveline B, et al. Comparison between the effects of indapamide and hydrochlorothiazide on creatinine clearance in patients with impaired renal function and hypertension. American Journal of Nephrology. 1995;15(3):251-5. Not relevant to key questions. [pmid: 7618651].
2644 Madkour H, Gadallah M, Riveline B, et al. Indapamide is superior to thiazide in the preservation of renal function in patients with renal insufficiency and systemic hypertension. American Journal of Cardiology. 1996;77(6):23B-5B. Not CKD treatment.
2645 Madore F, Lazarus JM, Brady HR. Therapeutic plasma exchange in renal diseases. Journal of the American Society of Nephrology. 1996;7(3):367-86. Not RCT or controlled trial. [pmid: 8704102].
2646 Madsen JK, Jensen JW, Sandermann J, et al. Effect of nitrendipine on renal function and on hormonal parameters after intravascular iopromide. Acta Radiologica. 1998;39(4):375-80. Sample size less than 50 patients. [pmid: 9685822].
2647 Madsen JK, Zachariae H, Pedersen EB. Effects of the calcium antagonist felodipine on renal haemodynamics, tubular sodium handling, and blood pressure in cyclosporin-treated dermatological patients. Nephrology Dialysis Transplantation. 1997;12(3):480-4. Not CKD treatment.
2648 Magee GM, Bilous RW, Cardwell CR, et al. Is hyperfiltration associated with the future risk of developing diabetic nephropathy? A meta-analysis. Diabetologia. 2009;52(4):691-7. Not relevant to key questions. [pmid: 19198800].
2649 Mahajan A, Simoni J, Sheather SJ, et al. Daily oral sodium bicarbonate preserves glomerular filtration rate by slowing its decline in early hypertensive nephropathy. Kidney International. Aug. 2010;78(3):303-9. Not CKD treatment. [pmid: 20445497].
2650 Mahajan SK, Sharma VK, Thakral S. Effect of enalapril on renal profile and right ventricular dimensions in chronic cor pulmonale. Journal of the Association of Physicians of India. 1996;44(5):323-4. Sample size less than 50 patients. [pmid: 9282581].
2651 Mahesh B, Yim B, Robson D, et al. Does furosemide prevent renal dysfunction in high-risk cardiac surgical patients? Results of a double-blinded prospective randomised trial. European Journal of Cardio-Thoracic Surgery. 2008;33(3):370-6. Sample size less than 50 patients. [pmid: 18243724].
2652 Mahmood A, Gosling P, Vohra RK. Randomized clinical trial comparing the effects on renal function of hydroxyethyl starch or gelatine during aortic aneurysm surgery. British Journal of Surgery. 2007;94(4):427-33. Not relevant to key questions. [pmid: 17380548].
2653 Mahmud N, O'Toole D, O'Hare N, et al. Evaluation of renal function following treatment with 5-aminosalicylic acid derivatives in patients with ulcerative colitis. Alimentary Pharmacology & Therapeutics. 2002;16(2):207-15. Not early CKD. [pmid: 11860403].
2654 Maillard M, Burnier M. Comparative cardiovascular safety of traditional nonsteroidal anti-inflammatory drugs. Expert Opinion on Drug Safety. 2006;5(1):83-94. Not relevant to key questions. [pmid: 16370958].
2655 Mainra R, Gallo K, Moist L. Effect of N-acetylcysteine on renal function in patients with chronic kidney disease. Nephrology. 2007;12(5):510-3. Sample size less than 50 patients. [pmid: 17803476].
2656 Maioli M, Toso A, Leoncini M, et al. Sodium bicarbonate versus saline for the prevention of contrast-induced nephropathy in patients with renal dysfunction undergoing coronary angiography or intervention. Journal of the American College of Cardiology. 2008;52(8):599-604. Not early CKD. [pmid: 18702961].
2657 Maione A, Nicolucci A, Craig JC, et al. Protocol of the Long-term Impact of RAS Inhibition on Cardiorenal Outcomes (LIRICO) randomized trial. Journal of Nephrology. 2007;20(6):646-55. Not CKD treatment. [pmid: 18046666].
2658 Maisch NM, Pezzillo KK. HMG-CoA reductase inhibitors for the prevention of nephropathy. Annals of Pharmacotherapy. 2004;38(2):342-5. Sample size less than 50 patients. [pmid: 14742776].
2659 Majumdar SR, Kjellstrand CM, Tymchak WJ, et al. Forced euvolemic diuresis with mannitol and furosemide for prevention of contrast-induced nephropathy in patients with CKD undergoing coronary angiography: a randomized controlled trial. American Journal of Kidney Diseases. 2009;54(4):602-9. Not CKD treatment. [pmid: 19535188].
2660 Mak RH, Cheung W. Therapeutic strategy for cachexia in chronic kidney disease. Current Opinion in Nephrology & Hypertension. 2007;16(6):542-6. Not CKD treatment. [pmid: 18089968].
2661 Maki DD, Ma JZ, Louis TA, et al. Long-term effects of antihypertensive agents on proteinuria and renal function. Archives of Internal Medicine. 1995;155(10):1073-80. Not relevant to key questions. [pmid: 7748051].
2662 Makino H, Haneda M, Babazono T, et al. The telmisartan renoprotective study from incipient nephropathy to overt nephropathy--rationale, study design, treatment plan and baseline characteristics of the incipient to overt: angiotensin II receptor blocker, telmisartan, Investigation on Type 2 Diabetic Nephropathy (INNOVATION) Study. Journal of International Medical Research. 2005;33(6):677-86. Not human studies. [pmid: 16372586].
2663 Makino H, Haneda M, Babazono T, et al. Microalbuminuria reduction with telmisartan in normotensive and hypertensive Japanese patients with type 2 diabetes: a post-hoc analysis of The Incipient to Overt: Angiotensin II Blocker, Telmisartan, Investigation on Type 2 Diabetic Nephropathy (INNOVATION) study. Hypertension Research - Clinical & Experimental. 2008;31(4):657-64. Not CKD treatment.
2664 Malaguarnera M, Vacante M, Russo C, et al. A single dose of rasburicase in elderly patients with hyperuricaemia reduces serum uric acid levels and improves renal function. Expert Opinion on Pharmacotherapy. 2009;10(5):737-42. Not RCT or controlled trial. [pmid: 19351224].
2665 Malandrino S, Angelini M, Baldini L, et al. Effects of suprofen on renal function in patients with rheumatoid arthritis. International Journal of Clinical Pharmacology Research. 1987;7(4):259-63. Follow-up less than 6 months. [pmid: 3474214].
2666 Malani AK, Ammar H, Yassin MH. Progression of chronic kidney disease: can it be prevented or arrested?. American Journal of Medicine. 2007;120(3):e29. author reply e31. Not RCT or controlled trial. [pmid: 17349429].
2667 Malhis M, Al-Bitar S, Al-Deen Zaiat K. The role of theophylline in prevention of radiocontrast media-induced nephropathy. Saudi Journal of Kidney Diseases & Transplantation. Mar. 2010;21(2):276-83. Not CKD treatment. [pmid: 20228513].
2668 Mallamaci F, Leonardis D, Bellizzi V, et al. Does high salt intake cause hyperfiltration in patients with essential hypertension?. Journal of Human Hypertension. 1996;10(3):157-61. Sample size less than 50 patients. [pmid: 8733032].
2669 Maller R, Ahrne H, Holmen C, et al. Once- versus twice-daily amikacin regimen: efficacy and safety in systemic gram-negative infections. Scandinavian Amikacin Once Daily Study Group. Journal of Antimicrobial Chemotherapy. 1993;31(6):939-48. Not CKD treatment. [pmid: 8360131].
2670 Maller R, Isaksson B, Nilsson L, et al. A study of amikacin given once versus twice daily in serious infections. Journal of Antimicrobial Chemotherapy. 1988;22(2):75-9. Sample size less than 50 patients. [pmid: 3170393].
2671 Malleson PN, Lockitch G, Mackinnon M, et al. Renal disease in chronic arthritis of childhood. A study of urinary N-acetyl-beta-glucosaminidase and beta 2-microglobulin excretion. Arthritis & Rheumatism. 1990;33(10):1560-6. Not CKD treatment. [pmid: 2222536].
2672 Mallett C, House AA, Spence JD, et al. Longitudinal ultrasound evaluation of carotid atherosclerosis in one, two and three dimensions. Ultrasound in Medicine & Biology. 2009;35(3):367-75. Sample size less than 50 patients. [pmid: 18996639].
2673 Mallick NP. Dietary protein and progression of chronic renal disease. BMJ. 1994;309(6962):1101-2. Not CKD treatment. [pmid: 7987095].
2674 Malmstrom H, Rasmussen S, Simonsen E. Intraperitoneal high-dose cisplatin and etoposide with systemic thiosulfate protection in second-line treatment of advanced ovarian cancer. Gynecologic Oncology. 1993;49(2):166-71. Not CKD treatment. [pmid: 8504983].
2675 Malnick SDH, Somin M. The VALIDD study. Lancet. 2007;370(9591):931. author reply -2. Sample size less than 50 patients. [pmid: 17869624].
2676 Malvy D, Maingourd C, Pengloan J, et al. Effects of severe protein restriction with ketoanalogues in advanced renal failure. Journal of the American College of Nutrition. 1999;18(5):481-6. Not early CKD. [pmid: 10511331].
2677 Man in't Veld AJ. Clinical overview of irbesartan: expanding the therapeutic window in hypertension. Journal of Hypertension - Supplement. 1997;15(7):S27-33. Not relevant to key questions.
2678 Manasia AR, Leibowitz AB, Miller CM, et al. Postoperative intravenous infusion of alprostadil (PGE1) does not improve renal function in hepatic transplant recipients. Journal of the American College of Surgeons. 1996;182(4):347-52. Sample size less than 50 patients. [pmid: 8605558].
2679 Manche A, Galea J, Busuttil W. Tolerance to ACE inhibitors after cardiac surgery. European Journal of Cardio-Thoracic Surgery. 1999;15(1):55-60. Not CKD treatment. [pmid: 10077374].
2680 Mancia G. ADVANCE: a new era in diabetes and hypertension. Introduction. Journal of Hypertension - Supplement. 2008;26(2):S1. Not RCT or controlled trial.
2681 Mandhani A, Kapoor R, Zaman W, et al. Is a 2-week duration sufficient for stenting in endopyelotomy?. Journal of Urology. 2003;169(3):886-9. Not CKD treatment. [pmid: 12576806].
2682 Manley HJ. Role of angiotensin-converting-enzyme inhibition in patients with renal disease. American Journal of Health-System Pharmacy. Suppl 1. 2000;57:S12-8. Not relevant to key questions. [pmid: 11030018].
2683 Manley KJ, Fraenkel MB, Mayall BC, et al. Probiotic treatment of vancomycin-resistant enterococci: a randomised controlled trial. Medical Journal of Australia. 2007;186(9):454-7. Follow-up less than 6 months. [pmid: 17484706].
2684 Manlucu J, Tonelli M, Ray JG, et al. Dose-reducing H2 receptor antagonists in the presence of low glomerular filtration rate: a systematic review of the evidence. Nephrology Dialysis Transplantation. 2005;20(11):2376-84. Follow-up less than 6 months.
2685 Mann JF. Ace inhibition in chronic renal failure: a step forward. Nephrology Dialysis Transplantation. 1996;11(6):932-3. Not RCT or controlled trial.
2686 Mann JF. What are the short-term and long-term consequences of anaemia in CRF patients?. Nephrology Dialysis Transplantation. Suppl 2. 1999;14:22-36. Not RCT or controlled trial.
2687 Mann JF. Valsartan and the kidney: present and future. Journal of Cardiovascular Pharmacology. Suppl 1. 1999;33:S37-40. discussion S1-3. Not RCT or controlled trial. [pmid: 10028953].
2688 Mann JF. Should the results of the HOPE study affect nephrological practice? For the HOPE investigators. Nephrology Dialysis Transplantation. 2000;15(4):453-4. Not relevant to key questions.
2689 Mann JF, Gerstein HC, Pogue J, et al. Renal insufficiency as a predictor of cardiovascular outcomes and the impact of ramipril: the HOPE randomized trial. Annals of Internal Medicine. 2001;134(8):629-36. Not relevant to key questions. [pmid: 11304102].
2690 Mann JF, Hilgers KF, Veelken R, et al. Effect of antihypertensive therapy on the progression of non-diabetic renal disease. Clinical Nephrology. Suppl 1. 1992;38:S74-7. Not relevant to key questions. [pmid: 1295712].
2691 Mann JF, Reisch C, Bergbreiter R, et al. Effects of WY 47987 (atrial natriuretic factor 102-126) in patients with renal insufficiency: a placebo-controlled, randomised study. Nephrology Dialysis Transplantation. 1989;4(9):776-81. Sample size less than 50 patients.
2692 Mann JFE. Cardiovascular risk in patients with mild renal insufficiency: implications for the use of ACE inhibitors. Presse Medicale. 2005;34(18):1303-8. Not relevant to key questions.
2693 Mann JFE, Gerstein HC, Yi QL, et al. Development of renal disease in people at high cardiovascular risk: results of the HOPE randomized study. Journal of the American Society of Nephrology. 2003;14(3):641-7. Not relevant to key questions. [pmid: 12595499].
2694 Mann JFE, Green D, Jamerson K, et al. Avosentan for overt diabetic nephropathy. Journal of the American Society of Nephrology. 2010;21(3):527-35. Not CKD treatment. [pmid: 20167702].
2695 Mann JFE, Lonn EM, Yi Q, et al. Effects of vitamin E on cardiovascular outcomes in people with mild-to-moderate renal insufficiency: results of the HOPE study. Kidney International. 2004;65(4):1375-80. Not CKD treatment. [pmid: 15086477].
2696 Manns B, Stevens L, Miskulin D, et al. A systematic review of sevelamer in ESRD and an analysis of its potential economic impact in Canada and the United States. Kidney International. 2004;66(3):1239-47. Not CKD treatment. [pmid: 15327423].
2697 Manske CL, Wang Y, Rector T, et al. Coronary revascularisation in insulin-dependent diabetic patients with chronic renal failure. Lancet. 1992;340(8826):998-1002. Not CKD treatment. [pmid: 1357450].
2698 Mansour G, Mansour J. Autoregulated glomerular filtration rate during candesartan treatment in hypertensive type 2 diabetic patients. Current Hypertension Reports. 2002;4(6):437-8. Not RCT or controlled trial. [pmid: 12419171].
2699 Mansson W, Ahlgren G, White T. Glomerular filtration rate up to 10 years after urinary diversion of different types. A comparative study of ileal and colonic conduit, refluxing and antirefluxing ureteral anastomosis and continent caecal reservoir. Scandinavian Journal of Urology & Nephrology. 1989;23(3):195-200. Not CKD treatment. [pmid: 2678427].
2700 Mansy H, Goodship TH, Tapson JS, et al. Effect of a high protein diet in patients with the nephrotic syndrome. Clinical Science. 1989;77(4):445-51. Sample size less than 50 patients. [pmid: 2805603].
2701 Marathias KP, Vassili M, Robola A, et al. Preoperative intravenous hydration confers renoprotection in patients with chronic kidney disease undergoing cardiac surgery. Artificial Organs. 2006;30(8):615-21. Follow-up less than 6 months. [pmid: 16911315].
2702 Marchais SJ, Boussac I, Guerin AP, et al. Arteriosclerosis and antihypertensive response to calcium antagonists in end-stage renal failure. Journal of Cardiovascular Pharmacology. Suppl 1. 1991;18:S74-8. Not early CKD. [pmid: 1723463].
2703 Marcus J, Sarnak MJ, Menon V. Homocysteine lowering and cardiovascular disease risk: lost in translation. Canadian Journal of Cardiology. 2007;23(9):707-10. Not RCT or controlled trial. [pmid: 17622392].
2704 Marcus LS, Hart D, Packer M, et al. Hemodynamic and renal excretory effects of human brain natriuretic peptide infusion in patients with congestive heart failure. A double-blind, placebo-controlled, randomized crossover trial. Circulation. 1996;94(12):3184-9. Not CKD treatment. [pmid: 8989127].
2705 Marcus R, Butterfield G, Holloway L, et al. Effects of short term administration of recombinant human growth hormone to elderly people. Journal of Clinical Endocrinology & Metabolism. 1990;70(2):519-27. Sample size less than 50 patients. [pmid: 2298863].
2706 Marenzi G, Assanelli E, Marana I, et al. N-acetylcysteine and contrast-induced nephropathy in primary angioplasty. New England Journal of Medicine. 2006;354(26):2773-82. Sample size less than 50 patients. [pmid: 16807414].
2707 Marier JF, Lee J, Kambhampati SRP, et al. Effect of repeated oral administrations of the oral adsorbent AST-120 on serum creatinine and other markers of renal function. A randomized controlled study in patients with chronic kidney disease. American Journal of Nephrology. 2006;26(2):136-41. Not RCT or controlled trial. [pmid: 16549905].
2708 Marik PE. Low-dose dopamine: a systematic review. Intensive Care Medicine. 2002;28(7):877-83. Not early CKD. [pmid: 12122525].
2709 Marik PE, Iglesias J. Low-dose dopamine does not prevent acute renal failure in patients with septic shock and oliguria. NORASEPT II Study Investigators. American Journal of Medicine. 1999;107(4):387-90. Follow-up less than 6 months. [pmid: 10527041].
2710 Marin R, Ruilope LM, Aljama P, et al. A random comparison of fosinopril and nifedipine GITS in patients with primary renal disease. Journal of Hypertension. 2001;19(10):1871-6. Not early CKD. [pmid: 11593109].
2711 Marincola FM, White DE, Wise AP, et al. Combination therapy with interferon alfa-2a and interleukin-2 for the treatment of metastatic cancer. Journal of Clinical Oncology. 1995;13(5):1110-22. Not RCT or controlled trial. [pmid: 7738617].
2712 Maroni BJ, Tom K, Masud T, et al. How is lean body mass conserved with the very-low protein diet regimen?. Mineral & Electrolyte Metabolism. 1996;22(1-3):54-7. Follow-up less than 6 months. [pmid: 8676825].
2713 Marre M. Microalbuminuria and ACE inhibition in non-hypertensive diabetics. Journal of Diabetic Complications. 1990;4(2):84-5. Sample size less than 50 patients. [pmid: 2145309].
2714 Marre M. Recent advance in the treatment of diabetic nephropathy: angiotensin I converting enzyme (ACE) inhibitors. Journal of Diabetic Complications. 1991;5(2-3). Sample size less than 50 patients.
2715 Marre M, Chatellier G, Leblanc H, et al. Prevention of diabetic nephropathy with enalapril in normotensive diabetics with microalbuminuria. BMJ. 1988;297(6656):1092-5. Sample size less than 50 patients. [pmid: 2848604].
2716 Marre M, Hallab M, Billiard A, et al. Small doses of ramipril to reduce microalbuminuria in diabetic patients with incipient nephropathy independently of blood pressure changes. Journal of Cardiovascular Pharmacology. Suppl 2. 1991;18:S165-8. Sample size less than 50 patients. [pmid: 1725033].
2717 Marre M, Leblanc H, Suarez L, et al. Converting enzyme inhibition and kidney function in normotensive diabetic patients with persistent microalbuminuria. British Medical Journal Clinical Research Ed. 1987;294(6585):1448-52. Sample size less than 50 patients. [pmid: 3038254].
2718 Marre M, Lievre M, Chatellier G, et al. ACE inhibitors and diabetics with albuminuria. The DIABHYCAR Study Group. Lancet. 1995;346(8990):1638. Not RCT or controlled trial. [pmid: 7500787].
2719 Marre M, Lievre M, Vasmant D, et al. Determinants of elevated urinary albumin in the 4,937 type 2 diabetic subjects recruited for the DIABHYCAR Study in Western Europe and North Africa. Diabetes Care. Suppl 2. 2000;23:B40-8. Not RCT or controlled trial. [pmid: 10860190].
2720 Marrocco-Trischitta MM, Melissano G, Kahlberg A, et al. Glomerular filtration rate after left renal vein division and reconstruction during infrarenal aortic aneurysm repair. Journal of Vascular Surgery. 2007;45(3):481-6. Not RCT or controlled trial. [pmid: 17257799].
2721 Marsell R, Grundberg E, Krajisnik T, et al. Fibroblast growth factor-23 is associated with parathyroid hormone and renal function in a population-based cohort of elderly men. European Journal of Endocrinology. 2008;158(1):125-9. Not CKD treatment. [pmid: 18166826].
2722 Marshall MR, Song Q, Ma TM, et al. Evolving connectionist system versus algebraic formulas for prediction of renal function from serum creatinine. Kidney International. 2005;67(5):1944-54. Not RCT or controlled trial. [pmid: 15840042].
2723 Marshall SM. Screening for microalbuminuria: which measurement?. Diabetic Medicine. 1991;8(8):706-11. Not CKD treatment. [pmid: 1838060].
2724 Marshall SM. HOPE for all people with diabetes? Heart Outcomes Prevention Evaluation. Diabetic Medicine. Suppl 2. 2000;17:9-10. Not relevant to key questions. [pmid: 11048826].
2725 Marshall SM, Shearing PA, Shelley JH, et al. The effect of bromhexine on albumin excretion in insulin dependent diabetes. Diabete et Metabolisme. 1991;17(3):332-6. Sample size less than 50 patients. [pmid: 1884876].
2726 Marso SP, Ellis SG, Tuzcu M, et al. The importance of proteinuria as a determinant of mortality following percutaneous coronary revascularization in diabetics. Journal of the American College of Cardiology. 1999;33(5):1269-77. Not RCT or controlled trial. [pmid: 10193727].
2727 Marti HP, Frey FJ. Nephrotoxicity of rapamycin: an emerging problem in clinical medicine. Nephrology Dialysis Transplantation. 2005;20(1):13-5. Not RCT or controlled trial.
2728 Martin KJ. The first human cell line-derived erythropoietin, epoetin-delta (Dynepo), in the management of anemia in patients with chronic kidney disease. Clinical Nephrology. 2007;68(1):26-31. Not RCT or controlled trial. [pmid: 17703832].
2729 Martin KJ, Gonzalez EA, Gellens ME, et al. Therapy of secondary hyperparathyroidism with 19-nor-1alpha,25-dihydroxyvitamin D2. American Journal of Kidney Diseases. 1998;32(2 Suppl 2):S61-6. Sample size less than 50 patients. [pmid: 9808145].
2730 Martin P, Tindall H, Rice P, et al. Effects of pimobendan (UDCG 115) on renal function in healthy volunteers. Journal of International Medical Research. 1992;20(3):267-72. Sample size less than 50 patients. [pmid: 1397671].
2731 Martinez I, Saracho R, Montenegro J, et al. The importance of dietary calcium and phosphorous in the secondary hyperparathyroidism of patients with early renal failure. American Journal of Kidney Diseases. 1997;29(4):496-502. Follow-up less than 6 months. [pmid: 9100037].
2732 Martinez Martin FJ. Manidipine in hypertensive patients with metabolic syndrome: the MARIMBA study. Expert Review of Cardiovascular Therapy. 2009;7(7):863-9. Follow-up less than 6 months. [pmid: 19589122].
2733 Martinez-de-Anda A, Valdivia AG, Jaramillo-Juarez F, et al. Effects of aflatoxin chronic intoxication in renal function of laying hens. Poultry Science. Aug. 2010;89(8):1622-8. Not human studies.
2734 Martinez-Martin FJ, Saiz-Satjes M. Add-on manidipine versus amlodipine in diabetic patients with hypertension and microalbuminuria: the AMANDHA study. Expert Review of Cardiovascular Therapy. 2008;6(10):1347-55. Not CKD treatment. [pmid: 19018688].
2735 Martino G, Frusciante V, Varraso A, et al. Efficacy of 51Cr-EDTA clearance to tailor a carboplatin therapeutic regimen in ovarian cancer patients. Anticancer Research. 1999;19(6C):5587-91. Sample size less than 50 patients. [pmid: 10697623].
2736 Martins D, Norris K. Combating diabetic nephropathy with drug therapy. Current Diabetes Reports. 2001;1(2):148-56. Not RCT or controlled trial. [pmid: 12643111].
2737 Masala A, Faedda R, Alagna S, et al. Use of testosterone to prevent cyclophosphamide-induced azoospermia. Annals of Internal Medicine. 1997;126(4):292-5. Sample size less than 50 patients. [pmid: 9036801].
2738 Maschio G, Alberti D, Locatelli F, et al. Angiotensin-converting enzyme inhibitors and kidney protection: the AIPRI trial. The ACE Inhibition in Progressive Renal Insufficiency (AIPRI) Study Group. Journal of Cardiovascular Pharmacology. Suppl 1. 1999;33:S16-20. discussion S41-3. Not relevant to key questions. [pmid: 10028949].
2739 Massarella JW, Nazareno LA, Passe S, et al. The effect of probenecid on the pharmacokinetics of zalcitabine in HIV-positive patients. Pharmaceutical Research. 1996;13(3):449-52. Sample size less than 50 patients. [pmid: 8692740].
2740 Massy ZA. Therapy of hyperhomocysteinemia in chronic kidney disease. Seminars in Nephrology. 2006;26(1):24-7. Follow-up less than 6 months. [pmid: 16412821].
2741 Masud T, Young VR, Chapman T, et al. Adaptive responses to very low protein diets: the first comparison of ketoacids to essential amino acids. Kidney International. 1994;45(4):1182-92. Sample size less than 50 patients. [pmid: 8007590].
2742 Masuda M, Yamada T, Mine T, et al. Comparison of usefulness of sodium bicarbonate versus sodium chloride to prevent contrast-induced nephropathy in patients undergoing an emergent coronary procedure. American Journal of Cardiology. 2007;100(5):781-6. Not early CKD. [pmid: 17719320].
2743 Masuda M, Yamada T, Okuyama Y, et al. Sodium bicarbonate improves long-term clinical outcomes compared with sodium chloride in patients with chronic kidney disease undergoing an emergent coronary procedure. Circulation Journal. 2008;72(10):1610-4. Not CKD treatment. [pmid: 18756037].
2744 Masuda Si, Tamura K, Wakui H, et al. Effects of angiotensin II type 1 receptor blocker on ambulatory blood pressure variability in hypertensive patients with overt diabetic nephropathy. Hypertension Research - Clinical & Experimental. 2009;32(11):950-5. Sample size less than 50 patients.
2745 Mathew A, Eliasziw M, Devereaux PJ, et al. Carotid endarterectomy benefits patients with CKD and symptomatic high-grade stenosis. Journal of the American Society of Nephrology. 2010;21(1):145-52. Not RCT or controlled trial. [pmid: 20007752].
2746 Mathew JT, Patni H, Chaudhary AN, et al. Aldosterone induces mesangial cell apoptosis both in vivo and in vitro. American Journal of Physiology - Renal Physiology. 2008;295(1):F73-81. Not CKD treatment. [pmid: 18463316].
2747 Mathiesen ER, Hommel E, Giese J, et al. Efficacy of captopril in postponing nephropathy in normotensive insulin dependent diabetic patients with microalbuminuria. BMJ. 1991;303(6794):81-7. Not relevant to key questions. [pmid: 1860008].
2748 Mathiesen ER, Hommel E, Hansen HP, et al. Randomised controlled trial of long term efficacy of captopril on preservation of kidney function in normotensive patients with insulin dependent diabetes and microalbuminuria. BMJ. 1999;319(7201):24-5. Sample size less than 50 patients. [pmid: 10390455].
2749 Mathiesen ER, Hommel E, Olsen UB, et al. Elevated urinary prostaglandin excretion and the effect of indomethacin on renal function in incipient diabetic nephropathy. Diabetic Medicine. 1988;5(2):145-9. Sample size less than 50 patients. [pmid: 2964980].
2750 Mathur RP, Dash SC, Gupta N, et al. Effects of correction of metabolic acidosis on blood urea and bone metabolism in patients with mild to moderate chronic kidney disease: a prospective randomized single blind controlled trial. Renal Failure. 2006;28(1):1-5. Not RCT or controlled trial. [pmid: 16526312].
2751 Mathur VS. Pathophysiology of radiocontrast nephropathy and use of fenoldopam for its prevention. Reviews in Cardiovascular Medicine. Suppl 1. 2001;2:S4-8. Not CKD treatment. [pmid: 12439361].
2752 Mathur VS. The role of the DA1 receptor agonist fenoldopam in the management of critically ill, transplant, and hypertensive patients. Reviews in Cardiovascular Medicine. Suppl 1. 2003;4:S35-40. Not CKD treatment. [pmid: 12556736].
2753 Mathur VS, Swan SK, Lambrecht LJ, et al. The effects of fenoldopam, a selective dopamine receptor agonist, on systemic and renal hemodynamics in normotensive subjects. Critical Care Medicine. 1999;27(9):1832-7. Follow-up less than 6 months. [pmid: 10507606].
2754 Matikainen N, Kahri J, Taskinen MR. Reviewing statin therapy in diabetes--towards the best practise. Primary care diabetes. Apr. 2010;4(1):9-15. Not CKD treatment. [pmid: 20171948].
2755 Matin SF. Laparoscopic approaches to urologic malignancies. Current Treatment Options in Oncology. 2003;4(5):373-83. Not CKD treatment. [pmid: 12941197].
2756 Matos JPS, de Lourdes Rodrigues M, Ismerim VL, et al. Effects of dual blockade of the renin angiotensin system in hypertensive type 2 diabetic patients with nephropathy. Clinical Nephrology. 2005;64(3):180-9. Not RCT or controlled trial. [pmid: 16175942].
2757 Matsuda H, Hayashi K, Homma K, et al. Differing anti-proteinuric action of candesartan and losartan in chronic renal disease. Hypertension Research - Clinical & Experimental. 2003;26(11):875-80. Follow-up less than 6 months.
2758 Matsuda H, Hayashi K, Saruta T. Distinct time courses of renal protective action of angiotensin receptor antagonists and ACE inhibitors in chronic renal disease. Journal of Human Hypertension. 2003;17(4):271-6. Not CKD treatment. [pmid: 12692572].
2759 Matsumoto H, Nakao T, Okada T, et al. Favorable outcome of low-dose cyclosporine after pulse methylprednisolone in Japanese adult minimal-change nephrotic syndrome. Internal Medicine. 2004;43(8):668-73. Not RCT or controlled trial. [pmid: 15468963].
2760 Matsumura C, Kemmotsu O, Kawano Y, et al. Serum and urine inorganic fluoride levels following prolonged low-dose sevoflurane anesthesia combined with epidural block. Journal of Clinical Anesthesia. 1994;6(5):419-24. Sample size less than 50 patients. [pmid: 7527229].
2761 Matthews DR, Stratton IM, Aldington SJ, et al. Risks of progression of retinopathy and vision loss related to tight blood pressure control in type 2 diabetes mellitus: UKPDS 69. Archives of Ophthalmology. 2004;122(11):1631-40. Not CKD treatment. [pmid: 15534123].
2762 Matuszkiewicz-Rowinska J. KDIGO clinical practice guidelines for the diagnosis, evaluation, prevention, and treatment of mineral and bone disorders in chronic kidney disease. Polskie Archiwum Medycyny Wewnetrznej. Jul. 2010;120(7-8):300-6. Not RCT or controlled trial. [pmid: 20693962].
2763 Matz GJ. Aminoglycoside ototoxicity. American Journal of Otolaryngology. 1986;7(2):117-9. Not relevant to key questions. [pmid: 3485932].
2764 Mauer M, Zinman B, Gardiner R, et al. ACE-I and ARBs in early diabetic nephropathy. Journal of the Renin-Angiotensin-Aldosterone System. 2002;3(4):262-9. Not early CKD. [pmid: 12584670].
2765 Mauer M, Zinman B, Gardiner R, et al. Renal and retinal effects of enalapril and losartan in type 1 diabetes. New England Journal of Medicine. 2009;361(1):40-51. Not relevant to key questions. [pmid: 19571282].
2766 Mauer M, Zinman B, Gardiner R, et al. Renal and retinal effects of enalapril and losartan in type 1 diabetes. New England Journal of Medicine. 2009;361(1):40-51. Not relevant to key questions. [pmid: 19571282].
2767 Mauri JM, Valles M. Effects of recombinant interleukin-2 and revaccination for hepatitis B in previously vaccinated, non-responder, chronic uraemic patients. Collaborative Group of Girona. Nephrology Dialysis Transplantation. 1997;12(4):729-32. Not CKD treatment.
2768 Mauro LS, Kuhl DA, Kirchhoff JR, et al. Impact of oral bases on aluminum absorption. American Journal of Therapeutics. 2001;8(1):21-5. Not early CKD. [pmid: 11304654].
2769 Mayer AF, Schroeder C, Heusser K, et al. Influences of norepinephrine transporter function on the distribution of sympathetic activity in humans. Hypertension. 2006;48(1):120-6. Not early CKD. [pmid: 16717144].
2770 Mayer SA, Solomon RA, Fink ME, et al. Effect of 5% albumin solution on sodium balance and blood volume after subarachnoid hemorrhage. Neurosurgery. 1998;42(4):759-67. discussion 67-8. Not CKD treatment. [pmid: 9574640].
2771 Mazze RS, Bergenstal R, Ginsberg B. Intensified diabetes management: lessons from the diabetes control and complications trial. International Journal of Clinical Pharmacology & Therapeutics. 1995;33(1):43-51. Not RCT or controlled trial. [pmid: 7711992].
2772 Mazzeo AT, Brophy GM, Gilman CB, et al. Safety and tolerability of cyclosporin a in severe traumatic brain injury patients: results from a prospective randomized trial. Journal of Neurotrauma. 2009;26(12):2195-206. Not CKD treatment. [pmid: 19621985].
2773 McAlister FA, Levine M, Zarnke KB, et al. The 2000 Canadian recommendations for the management of hypertension: Part one--therapy. Canadian Journal of Cardiology. 2001;17(5):543-59. Not early CKD. [pmid: 11381277].
2774 McAuliffe AV, Brooks BA, Fisher EJ, et al. Administration of ascorbic acid and an aldose reductase inhibitor (tolrestat) in diabetes: effect on urinary albumin excretion. Nephron. 1998;80(3):277-84. Sample size less than 50 patients. [pmid: 9807036].
2775 McBride WT, Allen S, Gormley SMC, et al. Methylprednisolone favourably alters plasma and urinary cytokine homeostasis and subclinical renal injury at cardiac surgery. Cytokine. 2004;27(2-3):81-9. Sample size less than 50 patients. [pmid: 15242697].
2776 McCance-Katz EF, Rainey PM, Jatlow P, et al. Methadone effects on zidovudine disposition (AIDS Clinical Trials Group 262). Journal of Acquired Immune Deficiency Syndromes & Human Retrovirology. 1998;18(5):435-43. Not CKD treatment. [pmid: 9715839].
2777 McCarthy ML, Stoukides CA. Estrogen therapy of uremic bleeding. Annals of Pharmacotherapy. 1994;28(1):60-2. Not relevant to key questions. [pmid: 8123965].
2778 McClean DR, Ikram H, Garlick AH, et al. The clinical, cardiac, renal, arterial and neurohormonal effects of omapatrilat, a vasopeptidase inhibitor, in patients with chronic heart failure. Journal of the American College of Cardiology. 2000;36(2):479-86. Not early CKD. [pmid: 10933361].
2779 McClellan WM, Knight DF, Karp H, et al. Early detection and treatment of renal disease in hospitalized diabetic and hypertensive patients: important differences between practice and published guidelines. American Journal of Kidney Diseases. 1997;29(3):368-75. Not RCT or controlled trial. [pmid: 9041212].
2780 McClellan WM, Langston RD, Presley R. Medicare patients with cardiovascular disease have a high prevalence of chronic kidney disease and a high rate of progression to end-stage renal disease. Journal of the American Society of Nephrology. 2004;15(7):1912-9. Not CKD treatment. [pmid: 15213281].
2781 McClellan WM, Ramirez SPB, Jurkovitz C. Screening for chronic kidney disease: unresolved issues. Journal of the American Society of Nephrology. 2003;14(7 Suppl 2):S81-7. Not CKD treatment. [pmid: 12819308].
2782 McConaghy JR. What is the best treatment for slowing the progression to end-stage renal disease (ESRD) in African Americans with hypertensive nephropathy?. Journal of Family Practice. 2001;50(9):744. Not RCT or controlled trial. [pmid: 11674903].
2783 McCormack PL, Wagstaff AJ. Lacidipine: a review of its use in the management of hypertension. Drugs. 2003;63(21):2327-56. Not RCT or controlled trial. [pmid: 14524737].
2784 McCormack PM, Cox JP, Marron J, et al. The antihypertensive efficacy of ketanserin in the elderly evaluated by ambulatory blood pressure measurement. Journal of Human Hypertension. 1990;4(5):565-70. Sample size less than 50 patients. [pmid: 2283647].
2785 McCormick BB, Sydor A, Akbari A, et al. The effect of pentoxifylline on proteinuria in diabetic kidney disease: a meta-analysis. American Journal of Kidney Diseases. 2008;52(3):454-63. Not CKD treatment. [pmid: 18433957].
2786 McCormick PA, Greenslade L, Kibbler CC, et al. A prospective randomized trial of ceftazidime versus netilmicin plus mezlocillin in the empirical therapy of presumed sepsis in cirrhotic patients. Hepatology. 1997;25(4):833-6. Not CKD treatment. [pmid: 9096584].
2787 McCullough PA. Evaluation and treatment of coronary artery disease in patients with end-stage renal disease. Kidney International - Supplement. 2005;(95):S51-8. Not RCT or controlled trial. [pmid: 15882314].
2788 McCullough PA. Multimodality prevention of contrast-induced acute kidney injury. American Journal of Kidney Diseases. 2008;51(2):169-72. Not CKD treatment. [pmid: 18215694].
2789 McCullough PA. Prevention of cardiorenal syndromes. Contributions to Nephrology. 2010;165:101-11. Not RCT or controlled trial. [pmid: 20427960].
2790 McCullough PA, Agrawal V, Danielewicz E, et al. Accelerated atherosclerotic calcification and Monckeberg's sclerosis: a continuum of advanced vascular pathology in chronic kidney disease. Clinical Journal of The American Society of Nephrology: CJASN. 2008;3(6):1585-98. Not CKD treatment. [pmid: 18667741].
2791 McCullough PA, Bertrand ME, Brinker JA, et al. A meta-analysis of the renal safety of isosmolar iodixanol compared with low-osmolar contrast media. Journal of the American College of Cardiology. 2006;48(4):692-9. Not relevant to key questions. [pmid: 16904536].
2792 McCullough PA, Franklin BA, Leifer E, et al. Impact of reduced kidney function on cardiopulmonary fitness in patients with systolic heart failure. American Journal of Nephrology. 2010;32(3):226-33. Not CKD treatment. [pmid: 20664198].
2793 McCullough PA, Li S, Jurkovitz CT, et al. CKD and cardiovascular disease in screened high-risk volunteer and general populations: the Kidney Early Evaluation Program (KEEP) and National Health and Nutrition Examination Survey (NHANES) 1999-2004. American Journal of Kidney Diseases. 2008;51(4 Suppl 2):S38-45. Not CKD treatment. [pmid: 18359407].
2794 McDiarmid SV, Colonna JO 2nd, Shaked A, et al. A comparison of renal function in cyclosporine- and FK-506-treated patients after primary orthotopic liver transplantation. Transplantation. 1993;56(4):847-53. Follow-up less than 6 months. [pmid: 7692636].
2795 McDonald V, Leandro M. Rituximab in non-haematological disorders of adults and its mode of action. British Journal of Haematology. 2009;146(3):233-46. Not CKD treatment. [pmid: 19466979].
2796 McGee WT, Mailloux P, Jodka P, et al. The pulmonary artery catheter in critical care. Seminars in Dialysis. 2006;19(6):480-91. Follow-up less than 6 months. [pmid: 17150048].
2797 McGill JB. Improving microvascular outcomes in patients with diabetes through management of hypertension. Postgraduate Medicine. 2009;121(2):89-101. Not RCT or controlled trial. [pmid: 19332966].
2798 McGowan T, Vaccaro NM, Beaver JS, et al. Pharmacokinetic and pharmacodynamic profiles of extended dosing of epoetin alfa in anemic patients who have chronic kidney disease and are not on dialysis. Clinical Journal of The American Society of Nephrology: CJASN. 2008;3(4):1006-14. Sample size less than 50 patients. [pmid: 18417741].
2799 McGregor DO, Dellow WJ, Robson RA, et al. Betaine supplementation decreases post-methionine hyperhomocysteinemia in chronic renal failure. Kidney International. 2002;61(3):1040-6. Sample size less than 50 patients. [pmid: 11849459].
2800 McInnes GT. Angiotensin II antagonism in clinical practice: experience with valsartan. Journal of Cardiovascular Pharmacology. Suppl 1. 1999;33:S29-32. discussion S41-3. Not RCT or controlled trial. [pmid: 10028951].
2801 McInnes GT. The expanding role of angiotensin receptor blockers in the management of the elderly hypertensive. Current Medical Research & Opinion. 2003;19(5):452-5. Not relevant to key questions. [pmid: 13678487].
2802 McKee MD, Cecco SA, Niemela JE, et al. Effects of interleukin 2 therapy on lymphocyte magnesium levels. Journal of Laboratory & Clinical Medicine. 2002;139(1):5-12. Not early CKD. [pmid: 11873239].
2803 McKenna F, Davison AM. Renin and beta-blockade: prorenin and aldosterone may explain the controversy. Clinical Nephrology. 1986;25(3):149-54. Sample size less than 50 patients. [pmid: 2869848].
2804 McKenna K, Smith D, Barrett P, et al. Angiotensin-converting enzyme inhibition by quinapril blocks the albuminuric effect of atrial natriuretic peptide in Type 1 diabetes and microalbuminuria. Diabetic Medicine. 2000;17(3):219-24. Sample size less than 50 patients. [pmid: 10784227].
2805 McKinnon PS, Paladino JA, Schentag JJ. Evaluation of area under the inhibitory curve (AUIC) and time above the minimum inhibitory concentration (T>MIC) as predictors of outcome for cefepime and ceftazidime in serious bacterial infections. International Journal of Antimicrobial Agents. 2008;31(4):345-51. Not early CKD. [pmid: 18313273].
2806 McLachlan SA, Cameron D, Murray R, et al. Safety of oral ibandronate in the treatment of bone metastases from breast cancer : long-term follow-up experience. Clinical Drug Investigation. 2006;26(1):43-8. Not CKD treatment. [pmid: 17163234].
2807 McMahon LP, Mason K, Skinner SL, et al. Effects of haemoglobin normalization on quality of life and cardiovascular parameters in end-stage renal failure. Nephrology Dialysis Transplantation. 2000;15(9):1425-30. Sample size less than 50 patients.
2808 McMurray J. Angiotensin receptor blockers and myocardial infarction: analysis of evidence is incomplete and inaccurate. BMJ. 2005;330(7502):1269. author reply 70-1. Not RCT or controlled trial. [pmid: 15920134].
2809 McMurray J, Seidelin PH, Struthers AD. Evidence for a proximal and distal nephron action of atrial natriuretic factor in man. Nephron. 1989;51(1):39-43. Not CKD treatment. [pmid: 2521696].
2810 McMurray J, Struthers AD. Effects of angiotensin II and atrial natriuretic peptide alone and in combination on urinary water and electrolyte excretion in man. Clinical Science. 1988;74(4):419-25. Not RCT or controlled trial. [pmid: 2965633].
2811 McMurray JJ, Seidelin PH, Brown RA, et al. Noradrenaline attenuates the natriuretic effect of atrial natriuretic factor in man. British Journal of Clinical Pharmacology. 1989;27(1):7-12. Not CKD treatment. [pmid: 2523228].
2812 McNabb WR, Noormohamed FH, Lant AF. The effects of enalapril on blood pressure and the kidney in normotensive subjects under altered sodium balance. Journal of Hypertension. 1986;4(1):39-47. Sample size less than 50 patients. [pmid: 3007604].
2813 McParland P, Pearce JM, Chamberlain GV. Doppler ultrasound and aspirin in recognition and prevention of pregnancy-induced hypertension. Lancet. 1990;335(8705):1552-5. Not early CKD. [pmid: 1972487].
2814 McQueen MJ, Lonn E, Gerstein HC, et al. The HOPE (Heart Outcomes Prevention Evaluation) Study and its consequences. Scandinavian Journal of Clinical and Laboratory Investigation Supplement. 2005;240:143-56. Not RCT or controlled trial. [pmid: 16112972].
2815 Mechl Z, Kerpel-Fronius S, Decker A, et al. Comparative evaluation of two administration schedules of cis-dichlorodiammineplatinum (DDP) in ovarian and head and neck cancers: a CMEA chemotherapy group study. Neoplasma. 1987;34(1):37-43. Follow-up less than 6 months. [pmid: 3561604].
2816 Medina HJ, Galvin EM, Dirckx M, et al. Remifentanil as a single drug for extracorporeal shock wave lithotripsy: a comparison of infusion doses in terms of analgesic potency and side effects. Anesthesia & Analgesia. 2005;101(2):365-70. Follow-up less than 6 months. [pmid: 16037145].
2817 Meeme A, Kasozi H. Effect of glycaemic control on glomerular filtration rate in diabetes mellitus patients. African Health Sciences. Aug. 1. Suppl 1. 2009;9:S23-6. Not RCT or controlled trial. [pmid: 20589157].
2818 Mehdi U, Toto RD. Anemia, diabetes, and chronic kidney disease. Diabetes Care. 2009;32(7):1320-6. Not RCT or controlled trial. [pmid: 19564475].
2819 Mehdi UF, Adams-Huet B, Raskin P, et al. Addition of angiotensin receptor blockade or mineralocorticoid antagonism to maximal angiotensin-converting enzyme inhibition in diabetic nephropathy. Journal of the American Society of Nephrology. 2009;20(12):2641-50. Duplicate listings. [pmid: 19926893].
2820 Mehls O, Haas S. Effects of recombinant human growth hormone in catabolic adults with chronic renal failure. Growth Hormone & Igf Research. Suppl B. 2000;10:S31-7. Not relevant to key questions. [pmid: 10984251].
2821 Mehls O, Knoller N, Oh J, et al. Daily but not pulse calcitriol therapy improves growth in experimental uremia. Pediatric Nephrology. 2000;14(7):658-63. Not human studies. [pmid: 10912538].
2822 Mehran R, Ashby DT. Radiocontrast-induced acute renal failure: allocations and outcomes. Reviews in Cardiovascular Medicine. Suppl 1. 2001;2:S9-13. Not CKD treatment. [pmid: 12439362].
2823 Mehran R, Nikolsky E, Kirtane AJ, et al. Ionic low-osmolar versus nonionic iso-osmolar contrast media to obviate worsening nephropathy after angioplasty in chronic renal failure patients: the ICON (Ionic versus non-ionic Contrast to Obviate worsening Nephropathy after angioplasty in chronic renal failure patients) study. Jacc: Cardiovascular Interventions. May. 2009;2(5):415-21. Not CKD treatment. [pmid: 19463464].
2824 Mehran R, Nikolsky E, Lansky AJ, et al. Impact of chronic kidney disease on early (30-day) and late (1-year) outcomes of patients with acute coronary syndromes treated with alternative antithrombotic treatment strategies: an ACUITY (Acute Catheterization and Urgent Intervention Triage strategY) substudy. Jacc: Cardiovascular Interventions. 2009;2(8):748-57. Not CKD treatment. [pmid: 19695543].
2825 Mehrotra R, De Gaudio R, Palazzo M. Antibiotic pharmacokinetic and pharmacodynamic considerations in critical illness. Intensive Care Medicine. 2004;30(12):2145-56. Not RCT or controlled trial. [pmid: 15536528].
2826 Mehrotra R, Kermah DA, Salusky IB, et al. Chronic kidney disease, hypovitaminosis D, and mortality in the United States. Kidney International. 2009;76(9):977-83. Not RCT or controlled trial. [pmid: 19657329].
2827 Mehta RL. Timed and targeted therapy for acute kidney injury: a glimpse of the future. Kidney International. Jun. 2010;77(11):947-9. Not early CKD. [pmid: 20467432].
2828 Mehta RL, Pascual MT, Soroko S, et al. Diuretics, mortality, and nonrecovery of renal function in acute renal failure. JAMA. 2002;288(20):2547-53. Not CKD treatment. [pmid: 12444861].
2829 Meier P, Ko DT, Tamura A, et al. Sodium bicarbonate-based hydration prevents contrast-induced nephropathy: a meta-analysis. BMC Medicine. 2009;7:23. Not early CKD. [pmid: 19439062].
2830 Meisinger E, Strauch M. Controlled trial of two keto acid supplements on renal function, nutritional status, and bone metabolism in uremic patients. Kidney International - Supplement. 1987;22:S170-3. Not RCT or controlled trial. [pmid: 3323611].
2831 Melin B, Jimenez C, Koulmann N, et al. Hyperhydration induced by glycerol ingestion: hormonal and renal responses. Canadian Journal of Physiology & Pharmacology. 2002;80(6):526-32. Not early CKD. [pmid: 12117301].
2832 Melis D, Parenti G, Gatti R, et al. Efficacy of ACE-inhibitor therapy on renal disease in glycogen storage disease type 1: a multicentre retrospective study. Clinical Endocrinology. 2005;63(1):19-25. Sample size less than 50 patients. [pmid: 15963056].
2833 Mellor JA, Kingdom J, Cafferkey M, et al. Vancomycin toxicity: a prospective study. Journal of Antimicrobial Chemotherapy. 1985;15(6):773-80. Sample size less than 50 patients. [pmid: 4030539].
2834 Meloni C, Morosetti M, Suraci C, et al. Severe dietary protein restriction in overt diabetic nephropathy: benefits or risks?. Journal of Renal Nutrition. 2002;12(2):96-101. Not relevant to key questions. [pmid: 11953922].
2835 Meloni C, Tatangelo P, Cipriani S, et al. Adequate protein dietary restriction in diabetic and nondiabetic patients with chronic renal failure. Journal of Renal Nutrition. 2004;14(4):208-13. Not relevant to key questions. [pmid: 15483780].
2836 Mena AC, Pulido EG, Guillen-Ponce C. Understanding the molecular-based mechanism of action of the tyrosine kinase inhibitor: sunitinib. Anti-Cancer Drugs. Suppl 1. 2010;21:S3-11. Not CKD treatment. [pmid: 20110785].
2837 Mendelssohn DC, Muirhead N, Manns BJ. Managing anemia. What do we do now? Views from Canada. Nephrology News & Issues. 2007;21(7):55-7. Follow-up less than 6 months. [pmid: 17623988].
2838 Menon V, Greene T, Pereira AA, et al. Glycosylated hemoglobin and mortality in patients with nondiabetic chronic kidney disease. Journal of the American Society of Nephrology. 2005;16(11):3411-7. Follow-up less than 6 months. [pmid: 16207824].
2839 Menon V, Greene T, Pereira AA, et al. Relationship of phosphorus and calcium-phosphorus product with mortality in CKD. American Journal of Kidney Diseases. 2005;46(3):455-63. Follow-up less than 6 months. [pmid: 16129207].
2840 Menon V, Greene T, Wang X, et al. C-reactive protein and albumin as predictors of all-cause and cardiovascular mortality in chronic kidney disease. Kidney International. 2005;68(2):766-72. Not relevant to key questions. [pmid: 16014054].
2841 Menon V, Kopple JD, Wang X, et al. Effect of a very low-protein diet on outcomes: long-term follow-up of the Modification of Diet in Renal Disease (MDRD) Study. American Journal of Kidney Diseases. 2009;53(2):208-17. Not CKD treatment. [pmid: 18950911].
2842 Menon V, Li L, Wang X, et al. Adiponectin and mortality in patients with chronic kidney disease. Journal of the American Society of Nephrology. 2006;17(9):2599-606. Sample size less than 50 patients. [pmid: 16885405].
2843 Menon V, Sarnak MJ, Greene T, et al. Relationship between homocysteine and mortality in chronic kidney disease. Circulation. 2006;113(12):1572-7. Sample size less than 50 patients. [pmid: 16549639].
2844 Menon V, Shlipak MG, Wang X, et al. Cystatin C as a risk factor for outcomes in chronic kidney disease. Annals of Internal Medicine. 2007;147(1):19-27. Follow-up less than 6 months. [pmid: 17606957].
2845 Menon V, Tighiouart H, Vaughn NS, et al. Serum bicarbonate and long-term outcomes in CKD. American Journal of Kidney Diseases. Nov. 2010;56(5):907-14. Not RCT or controlled trial. [pmid: 20605301].
2846 Menon V, Wang X, Greene T, et al. Relationship between C-reactive protein, albumin, and cardiovascular disease in patients with chronic kidney disease. American Journal of Kidney Diseases. 2003;42(1):44-52. Not CKD treatment. [pmid: 12830455].
2847 Menon V, Wang X, Greene T, et al. Homocysteine in chronic kidney disease: Effect of low protein diet and repletion with B vitamins. Kidney International. 2005;67(4):1539-46. Not relevant to key questions. [pmid: 15780109].
2848 Menon V, Wang X, Sarnak MJ, et al. Long-term outcomes in nondiabetic chronic kidney disease. Kidney International. 2008;73(11):1310-5. Not CKD treatment. [pmid: 18337713].
2849 Mercieri M, Mercieri A, Tritapepe L, et al. High-dose aprotinin with gentamicin-vancomycin antibiotic prophylaxis increases blood concentrations of creatinine and cystatin C in patients undergoing coronary artery bypass grafting. British Journal of Anaesthesia. 1999;82(4):531-6. Follow-up less than 6 months. [pmid: 10472217].
2850 Meredith PA, Elliott HL, Pasanisi F, et al. Verapamil pharmacokinetics and apparent hepatic and renal blood flow. British Journal of Clinical Pharmacology. 1985;20(2):101-6. Sample size less than 50 patients. [pmid: 4041329].
2851 Meredith PA, Pasanisi F, Elliott HL, et al. The effect of nisoldipine on apparent liver blood flow and effective renal plasma flow. British Journal of Clinical Pharmacology. 1985;20(3):235-7. Sample size less than 50 patients. [pmid: 4041344].
2852 Merion RM. Prostaglandins in liver transplantation. Advances in Experimental Medicine & Biology. 1997;433:13-8. Not CKD treatment. [pmid: 9561096].
2853 Merkel C, Gatta A, Donada C, et al. Long-term effect of nadolol or nadolol plus isosorbide-5-mononitrate on renal function and ascites formation in patients with cirrhosis. GTIP Gruppo Triveneto per l'Ipertensione Portale. Hepatology. 1995;22(3):808-13. Not CKD treatment. [pmid: 7657286].
2854 Merten GJ, Burgess WP, Gray LV, et al. Prevention of contrast-induced nephropathy with sodium bicarbonate: a randomized controlled trial. JAMA. 2004;291(19):2328-34. Not relevant to key questions. [pmid: 15150204].
2855 Mesotten D, Swinnen JV, Vanderhoydonc F, et al. Contribution of circulating lipids to the improved outcome of critical illness by glycemic control with intensive insulin therapy. Journal of Clinical Endocrinology & Metabolism. 2004;89(1):219-26. Not relevant to key questions. [pmid: 14715853].
2856 Messa P, Macario F, Yaqoob M, et al. The OPTIMA study: assessing a new cinacalcet (Sensipar/Mimpara) treatment algorithm for secondary hyperparathyroidism. Clinical Journal of The American Society of Nephrology: CJASN. 2008;3(1):36-45. Not CKD treatment. [pmid: 18178780].
2857 Messerli FH. Combinations in the treatment of hypertension: ACE inhibitors and calcium antagonists. American Journal of Hypertension. 1999;12(8 Pt 2):86S-90S. Not RCT or controlled trial. [pmid: 10478702].
2858 Metra M, Dei Cas L. Clinical efficacy of ibopamine in patients with chronic heart failure. Clinical Cardiology. 1995;18(3 Suppl I):I22-31. Not CKD treatment. [pmid: 7743695].
2859 Metz U, Graben N, Maruhn D, et al. Urinary enzyme excretion after a single dose of phenacetin and paracetamol (acetaminophen) during antidiuresis and during water diuresis. Clinica Chimica Acta. 1986;160(2):151-5. Sample size less than 50 patients.
2860 Meyer M, Pfarr E, Schirmer G, et al. Therapeutic use of the natriuretic peptide ularitide in acute renal failure. Renal Failure. 1999;21(1):85-100. Not CKD treatment. [pmid: 10048120].
2861 Meyer M, Wiebe K, Wahlers T, et al. Urodilatin (INN:ularitide) as a new drug for the therapy of acute renal failure following cardiac surgery. Clinical & Experimental Pharmacology & Physiology. 1997;24(5):374-6. Not CKD treatment. [pmid: 9143791].
2862 Meyer RD. Risk factors and comparisons of clinical nephrotoxicity of aminoglycosides. American Journal of Medicine. 1986;80(6B):119-25. Not relevant to key questions. [pmid: 3524214].
2863 Meyrier A, Dratwa M, Sennesael J, et al. Fixed low-dose perindopril-indapamide combination in hypertensive patients with chronic renal failure. American Journal of Hypertension. 1998;11(9):1087-92. Sample size less than 50 patients. [pmid: 9752894].
2864 Mezzano D, Tagle R, Pais E, et al. Endothelial cell markers in chronic uremia: relationship with hemostatic defects and severity of renal failure. Thrombosis Research. 1997;88(6):465-72. Not RCT or controlled trial. [pmid: 9610957].
2865 Miao L, Sun J, Yuan H, et al. Combined therapy of low-dose tacrolimus and prednisone in nephrotic syndrome with slight mesangial proliferation. Nephrology. 2006;11(5):449-54. Not RCT or controlled trial. [pmid: 17014560].
2866 Miao XH, Wang CG, Hu BQ, et al. TGF-beta1 immunohistochemistry and promoter methylation in chronic renal failure rats treated with Uremic Clearance Granules. Folia Histochemica et Cytobiologica. Jan. 2010;48(2):284-91. Not human studies. [pmid: 20675287].
2867 Miceli JJ, Wilner KD, Swan SK, et al. Pharmacokinetics, safety, and tolerability of intramuscular ziprasidone in healthy volunteers. Journal of Clinical Pharmacology. 2005;45(6):620-30. Not relevant to key questions. [pmid: 15901743].
2868 Michael M, Elliott EJ, Craig JC, et al. Interventions for hemolytic uremic syndrome and thrombotic thrombocytopenic purpura: a systematic review of randomized controlled trials. American Journal of Kidney Diseases. 2009;53(2):259-72. Not CKD treatment. [pmid: 18950913].
2869 Michael M, Elliott EJ, Ridley GF, et al. Interventions for haemolytic uraemic syndrome and thrombotic thrombocytopenic purpura. Cochrane Database of Systematic Reviews. 2009;(1):CD003595. Not early CKD. [pmid: 19160220].
2870 Michalopoulos A, Geroulanos S, Rosmarakis ES, et al. Frequency, characteristics, and predictors of microbiologically documented nosocomial infections after cardiac surgery. European Journal of Cardio-Thoracic Surgery. 2006;29(4):456-60. Not relevant to key questions. [pmid: 16481186].
2871 Mielniczuk LM, Pfeffer MA, Lewis EF, et al. Acute decline in renal function, inflammation, and cardiovascular risk after an acute coronary syndrome. Clinical Journal of The American Society of Nephrology: CJASN. 2009;4(11):1811-7. Not CKD treatment. [pmid: 19820133].
2872 Mielniczuk LM, Pfeffer MA, Lewis EF, et al. Estimated glomerular filtration rate, inflammation, and cardiovascular events after an acute coronary syndrome. American Heart Journal. 2008;155(4):725-31. Not CKD treatment. [pmid: 18371483].
2873 Mihatsch MJ, Helmchen U, Casanova P, et al. Kidney biopsy findings in cyclosporine-treated patients with insulin-dependent diabetes mellitus. Klinische Wochenschrift. 1991;69(8):354-9. Not CKD treatment. [pmid: 1909398].
2874 Mihmanli I, Besirli K, Kurugoglu S, et al. Cephalic vein and hemodialysis fistula: surgeon's observation versus color Doppler ultrasonographic findings. Journal of Ultrasound in Medicine. 2001;20(3):217-22. Not early CKD. [pmid: 11270525].
2875 Milas NC, Nowalk MP, Akpele L, et al. Factors associated with adherence to the dietary protein intervention in the Modification of Diet in Renal Disease Study. Journal of the American Dietetic Association. 1995;95(11):1295-300. Not CKD treatment. [pmid: 7594126].
2876 Miller CC 3rd, Grimm JC, Estrera AL, et al. Postoperative renal function preservation with nonischemic femoral arterial cannulation for thoracoabdominal aortic repair. Journal of Vascular Surgery. 2010;51(1):38-42. Not RCT or controlled trial. [pmid: 19853401].
2877 Miller ER 3rd, Juraschek SP, Appel LJ, et al. The effect of n-3 long-chain polyunsaturated fatty acid supplementation on urine protein excretion and kidney function: meta-analysis of clinical trials. American Journal of Clinical Nutrition. 2009;89(6):1937-45. Not CKD treatment. [pmid: 19403630].
2878 Miller HI, Dascalu A, Rassin TA, et al. Effects of an acute dose of L-arginine during coronary angiography in patients with chronic renal failure: a randomized, parallel, double-blind clinical trial. American Journal of Nephrology. 2003;23(2):91-5. Follow-up less than 6 months. [pmid: 12481147].
2879 Miller JA. Impact of hyperglycemia on the renin angiotensin system in early human type 1 diabetes mellitus. Journal of the American Society of Nephrology. 1999;10(8):1778-85. Sample size less than 50 patients. [pmid: 10446946].
2880 Miller MA, Texter M, Gmerek A, et al. Quinapril hydrochloride effects on renal function in patients with renal dysfunction and hypertension: a drug-withdrawal study. Cardiovascular Drugs & Therapy. 1994;8(2):271-5. Sample size less than 50 patients. [pmid: 7918140].
2881 Miller PD, Roux C, Boonen S, et al. Safety and efficacy of risedronate in patients with age-related reduced renal function as estimated by the Cockcroft and Gault method: a pooled analysis of nine clinical trials. Journal of Bone & Mineral Research. 2005;20(12):2105-15. Not RCT or controlled trial. [pmid: 16294264].
2882 Miller PD, Schwartz EN, Chen P, et al. Teriparatide in postmenopausal women with osteoporosis and mild or moderate renal impairment. Osteoporosis International. 2007;18(1):59-68. Not relevant to key questions. [pmid: 17013567].
2883 Miller SB, Moulton M, O'Shea M, et al. Effects of IGF-I on renal function in end-stage chronic renal failure. Kidney International. 1994;46(1):201-7. Not early CKD. [pmid: 7933838].
2884 Millis JM, McDiarmid SV, Hiatt JR, et al. Randomized prospective trial of OKT3 for early prophylaxis of rejection after liver transplantation. Transplantation. 1989;47(1):82-8. Not CKD treatment. [pmid: 2521409].
2885 Millward SF, Burbridge BE, Hartman NG, et al. Nephrotoxicity of ioxaglate and ioversol assessed by glomerular filtration rate: a pilot study. Canadian Association of Radiologists Journal. 1996;47(1):24-9. Sample size less than 50 patients. [pmid: 8548465].
2886 Mimran A, Alfaro V. Candesartan: nephroprotective effects and treatment of diabetic nephropathy. Drugs of Today. 2003;39(6):439-50. Not RCT or controlled trial. [pmid: 12944996].
2887 Mimran A, Insua A, Ribstein J, et al. Comparative effect of captopril and nifedipine in normotensive patients with incipient diabetic nephropathy. Diabetes Care. 1988;11(10):850-3. Follow-up less than 6 months. [pmid: 3073076].
2888 Mimran A, Insua A, Ribstein J, et al. Contrasting effects of captopril and nifedipine in normotensive patients with incipient diabetic nephropathy. Journal of Hypertension. 1988;6(11):919-23. Follow-up less than 6 months. [pmid: 3069935].
2889 Mimran A, Ribstein J, DuCailar G. Angiotensin II receptor antagonists and hypertension. Clinical & Experimental Hypertension. 1999;21(5-6):847-58. Not RCT or controlled trial. [pmid: 10423107].
2890 Mimura T, Takenaka T, Kanno Y, et al. Vascular compliance is secured under angiotensin inhibition in non-diabetic chronic kidney diseases. Journal of Human Hypertension. 2008;22(1):38-47. Not RCT or controlled trial. [pmid: 17653243].
2891 Miner SES, Dzavik V, Nguyen-Ho P, et al. N-acetylcysteine reduces contrast-associated nephropathy but not clinical events during long-term follow-up. American Heart Journal. 2004;148(4):690-5. Not RCT or controlled trial. [pmid: 15459602].
2892 Mineshita S, Toyoshima A, Yazaki T. Influence of phenacetin and its metabolites on renal function. Nippon Jinzo Gakkai Shi. Japanese Journal of Nephrology. 1989;31(6):629-33. Sample size less than 50 patients. [pmid: 2795991].
2893 Minetti EE, Cozzi MG, Guidi E. Long- versus short-term effects of two different ACE inhibitors on renal haemodynamics: preliminary results from an ongoing trial. Nephrology Dialysis Transplantation. Suppl 6. 1995;10:18-21. Sample size less than 50 patients.
2894 Minutolo R, Andreucci M, Balletta MM, et al. Effect of posture on sodium excretion and diuretic efficacy in nephrotic patients. American Journal of Kidney Diseases. 2000;36(4):719-27. Not RCT or controlled trial. [pmid: 11007673].
2895 Miralles R, Cami J, Gutierrez J, et al. Diclofenac versus dipyrone in acute renal colic: a double-blind controlled trial. European Journal of Clinical Pharmacology. 1987;33(5):527-8. Not CKD treatment. [pmid: 3322848].
2896 Miranda ME. The influence of allopurinol on renal deterioration in familial nepropathy associated with hyperuricemia (FNAH). The Spanish Group for the Study of FNAH. Advances in Experimental Medicine & Biology. 1994;370:61-4. Not CKD treatment. [pmid: 7660979].
2897 Mircescu G, Garneata L, Stancu SH, et al. Effects of a supplemented hypoproteic diet in chronic kidney disease. Journal of Renal Nutrition. 2007;17(3):179-88. Not RCT or controlled trial. [pmid: 17462550].
2898 Misra D, Leibowitz K, Gowda RM, et al. Role of N-acetylcysteine in prevention of contrast-induced nephropathy after cardiovascular procedures: a meta-analysis. Clinical Cardiology. 2004;27(11):607-10. Not relevant to key questions. [pmid: 15562929].
2899 Mitaka C, Kudo T, Jibiki M, et al. Effects of human atrial natriuretic peptide on renal function in patients undergoing abdominal aortic aneurysm repair. Critical Care Medicine. 2008;36(3):745-51. Not RCT or controlled trial. [pmid: 18431264].
2900 Mitchell HC, Smith RD, Cutler RE, et al. Racial differences in the renal response to blood pressure lowering during chronic angiotensin-converting enzyme inhibition: a prospective double-blind randomized comparison of fosinopril and lisinopril in older hypertensive patients with chronic renal insufficiency. American Journal of Kidney Diseases. 1997;29(6):897-906. Sample size less than 50 patients. [pmid: 9186076].
2901 Mitrovic V, Seferovic P, Dodic S, et al. Cardio-renal effects of the A1 adenosine receptor antagonist SLV320 in patients with heart failure. Circulation: Heart Failure. 2009;2(6):523-31. Not CKD treatment. [pmid: 19919976].
2902 Mittleman KD. Influence of angiotensin II blockade during exercise in the heat. European Journal of Applied Physiology & Occupational Physiology. 1996;72(5-6):542-7. Not CKD treatment. [pmid: 8925829].
2903 Mix TCH, Brenner RM, Cooper ME, et al. Rationale--Trial to Reduce Cardiovascular Events with Aranesp Therapy (TREAT): evolving the management of cardiovascular risk in patients with chronic kidney disease. [Erratum appears in Am Heart J. 2005 Jul;150(1):53]. American Heart Journal. 2005;149(3):408-13. Not relevant to key questions. [pmid: 15864229].
2904 Miyagawa K, Dohi Y, Nakazawa A, et al. Renoprotective effect of calcium channel blockers in combination with an angiotensin receptor blocker in elderly patients with hypertension. A randomized crossover trial between benidipine and amlodipine. Clinical & Experimental Hypertension. Jan. 2010;32(1):1-7. Not CKD treatment. [pmid: 20144066].
2905 Miyazaki Y, Cersosimo E, Triplitt C, et al. Rosiglitazone decreases albuminuria in type 2 diabetic patients. Kidney International. 2007;72(11):1367-73. Follow-up less than 6 months. [pmid: 17805239].
2906 Miyoshi H, Ohshiba S, Matsumoto A, et al. Haptoglobin prevents renal dysfunction associated with intravariceal infusion of ethanolamine oleate. American Journal of Gastroenterology. 1991;86(11):1638-41. Not CKD treatment. [pmid: 1951242].
2907 Mocan MZ, Mocan H, Gacar MN, et al. Effect of essential amino acid supplementation in acute renal failure. International Urology & Nephrology. 1995;27(4):503-10. Not CKD treatment. [pmid: 8586527].
2908 Mocroft A, Wyatt C, Szczech L, et al. Interruption of antiretroviral therapy is associated with increased plasma cystatin C. AIDS. 2009;23(1):71-82. Not CKD treatment. [pmid: 19050388].
2909 Mocroft A, Wyatt C, Szczech L, et al. Interruption of antiretroviral therapy is associated with increased plasma cystatin C. AIDS. 2009;23(1):71-82. Not CKD treatment. [pmid: 19050388].
2910 Modesti PA, Vanni S, Morabito M, et al. Role of endothelin-1 in exposure to high altitude: Acute Mountain Sickness and Endothelin-1 (ACME-1) study. Circulation. 2006;114(13):1410-6. Sample size less than 50 patients. [pmid: 16982943].
2911 Modi GK. The death knell for dopamine?. National Medical Journal of India. 2001;14(2):88-9. Not CKD treatment. [pmid: 11396325].
2912 Modi NB, Novotny W, Reimann JD, et al. Pharmacokinetics and pharmacodynamics of sibrafiban, an orally administered IIb/IIIa antagonist, in patients with acute coronary syndrome. Journal of Clinical Pharmacology. 1999;39(7):675-84. Not CKD treatment. [pmid: 10392322].
2913 Moe SM, Cunningham J, Bommer J, et al. Long-term treatment of secondary hyperparathyroidism with the calcimimetic cinacalcet HCl. Nephrology Dialysis Transplantation. 2005;20(10):2186-93. Follow-up less than 6 months.
2914 Moe SM, Saifullah A, LaClair RE, et al. A randomized trial of cholecalciferol versus doxercalciferol for lowering parathyroid hormone in chronic kidney disease. Clinical Journal of The American Society of Nephrology: CJASN. Feb. 2010;5(2):299-306. Follow-up less than 6 months. [pmid: 20056760].
2915 Mogensen CE. The reno-protective role of AT(1)-receptor blockers. Journal of Human Hypertension. Suppl 3. 2002;16:S52-8. Not relevant to key questions. [pmid: 12140729].
2916 Mogensen CE, Neldam S, Tikkanen I, et al. Randomised controlled trial of dual blockade of renin-angiotensin system in patients with hypertension, microalbuminuria, and non-insulin dependent diabetes: the candesartan and lisinopril microalbuminuria (CALM) study. BMJ. 2000;321(7274):1440-4. Follow-up less than 6 months. [pmid: 11110735].
2917 Mohammed SF, Korinek J, Chen HH, et al. Nesiritide in acute decompensated heart failure: current status and future perspectives. Reviews in Cardiovascular Medicine. 2008;9(3):151-8. Not CKD treatment. [pmid: 18953274].
2918 Mohanram A, Zhang Z, Shahinfar S, et al. Anemia and end-stage renal disease in patients with type 2 diabetes and nephropathy. Kidney International. 2004;66(3):1131-8. Not CKD treatment. [pmid: 15327408].
2919 Mohanram A, Zhang Z, Shahinfar S, et al. The effect of losartan on hemoglobin concentration and renal outcome in diabetic nephropathy of type 2 diabetes. Kidney International. 2008;73(5):630-6. Not CKD treatment. [pmid: 18094675].
2920 Mohideen P, Bornemann M, Sugihara J, et al. The metabolic effects of troglitazone in patients with diabetes and end-stage renal disease. Endocrine. 2005;28(2):181-6. Not relevant to key questions. [pmid: 16388091].
2921 Mohrke W, Knauf H, Mutschler E. Pharmacokinetics and pharmacodynamics of triamterene and hydrochlorothiazide and their combination in healthy volunteers. International Journal of Clinical Pharmacology & Therapeutics. 1997;35(10):447-52. Not CKD treatment. [pmid: 9352394].
2922 Moist L, Nesrallah G, Kortas C, et al. Plasma exchange in rapidly progressive renal failure due to multiple myeloma. A retrospective case series. American Journal of Nephrology. 1999;19(1):45-50. Not RCT or controlled trial. [pmid: 10085449].
2923 Moist L, Sontrop JM, Gallo K, et al. Effect of N-acetylcysteine on serum creatinine and kidney function: results of a randomized controlled trial. American Journal of Kidney Diseases. Oct. 2010;56(4):643-50. Follow-up less than 6 months. [pmid: 20541301].
2924 Molenaar IQ, Begliomini B, Grazi GL, et al. The effect of aprotinin on renal function in orthotopic liver transplantation. Transplantation. 2001;71(2):247-52. Not CKD treatment. [pmid: 11213068].
2925 Molina CR, Fowler MB, McCrory S, et al. Hemodynamic, renal and endocrine effects of atrial natriuretic peptide infusion in severe heart failure. Journal of the American College of Cardiology. 1988;12(1):175-86. Sample size less than 50 patients. [pmid: 2967855].
2926 Molitch ME, Steffes M, Sun W, et al. Development and progression of renal insufficiency with and without albuminuria in adults with type 1 diabetes in the diabetes control and complications trial and the epidemiology of diabetes interventions and complications study. Diabetes Care. Jul. 2010;33(7):1536-43. Not relevant to key questions. [pmid: 20413518].
2927 Molitch ME, Steffes MW, Cleary PA, et al. Baseline analysis of renal function in the Diabetes Control and Complications Trial. The Diabetes Control and Complications Trial Research Group [corrected]. [Erratum appears in Kidney Int 1993 May;43(5):1196]. Kidney International. 1993;43(3):668-74. Not RCT or controlled trial. [pmid: 8455366].
2928 Mollee PN, Wechalekar AD, Pereira DL, et al. Autologous stem cell transplantation in primary systemic amyloidosis: the impact of selection criteria on outcome. Bone Marrow Transplantation. 2004;33(3):271-7. Not CKD treatment. [pmid: 14647248].
2929 Molnar Z, Szakmany T, Koszegi T. Prophylactic N-acetylcysteine decreases serum CRP but not PCT levels and microalbuminuria following major abdominal surgery. A prospective, randomised, double-blinded, placebo-controlled clinical trial. Intensive Care Medicine. 2003;29(5):749-55. Not CKD treatment. [pmid: 12682719].
2930 Molyneaux LM, Willey KA, Yue DK. Indapamide is as effective as captopril in the control of microalbuminuria in diabetes. Journal of Cardiovascular Pharmacology. 1996;27(3):424-7. Sample size less than 50 patients. [pmid: 8907805].
2931 Molzahn AE, Hibbert MP, Gaudet D, et al. Managing chronic kidney disease in a nurse-run, physician-monitored clinic: the CanPREVENT experience. Canadian Journal of Nursing Research. 2008;40(3):96-112. Not RCT or controlled trial. [pmid: 18947094].
2932 Momeni A, Shahidi S, Seirafian S, et al. Effect of allopurinol in decreasing proteinuria in type 2 diabetic patients. Iranian journal of Kidney Diseases. Apr. 2010;4(2):128-32. Sample size less than 50 patients. [pmid: 20404423].
2933 Monaco M, Di Tommaso L, Mottola M, et al. Clinical outcome for on-pump myocardial revascularization in patients with mild renal dysfunction. Thoracic & Cardiovascular Surgeon. 2005;53(1):46-51. Not relevant to key questions. [pmid: 15692919].
2934 Mondorf A, Mondorf W, Banzer S. A multiple-center comparative study of the kidney tolerance of ceftazidime versus cefotaxime and tobramycin. Chemioterapia. 1987;6(2 Suppl):331-2. Follow-up less than 6 months. [pmid: 2908241].
2935 Mondorf AW, Bonsiepe C, Mondorf W. Randomized multi center study comparing nephrotoxicity of ceftazidime versus the combination of piperacillin and netilmicin with and without furosemide. Advances in Experimental Medicine & Biology. 1989;252:307-12. Not early CKD. [pmid: 2675557].
2936 Monier-Faugere MC, Malluche HH. Calcitriol pulse therapy in patients with end-stage renal failure. Current Opinion in Nephrology & Hypertension. 1994;3(6):615-9. Not early CKD. [pmid: 7881985].
2937 Montanari A, Carra N, Perinotto P, et al. Renal hemodynamic control by endothelin and nitric oxide under angiotensin II blockade in man. Hypertension. 2002;39(2 Pt 2):715-20. Not early CKD. [pmid: 11882637].
2938 Montanari A, Tateo E, Fasoli E, et al. Angiotensin II blockade does not prevent renal effects of L-NAME in sodium-repleted humans. Hypertension. 1997;30(3 Pt 2):557-62. Sample size less than 50 patients. [pmid: 9322981].
2939 Montori VM. Should patients with type 2 diabetes focus on glycemic control to reduce their cardiovascular risk?. Polskie Archiwum Medycyny Wewnetrznej. 2008;118(9):502-7. Not CKD treatment. [pmid: 18846985].
2940 Moore AEB, Hain SF, Blake GM, et al. Validation of ultrafiltration as a method of measuring free 99mTc-MDP. Journal of Nuclear Medicine. 2003;44(6):891-7. Not CKD treatment. [pmid: 12791815].
2941 Moore KB, McKenna K, Tormey WP, et al. The albuminuric action of atrial natriuretic peptide is not modified by ACE-inhibition with perindopril in Type 2 diabetes. Diabetic Medicine. 2003;20(9):713-6. Sample size less than 50 patients. [pmid: 12925049].
2942 Moore MJ, O'Sullivan B, Tannock IF. Are treatment strategies of urologic oncologists influenced by the opinions of their colleagues?. British Journal of Cancer. 1990;62(6):988-91. Not CKD treatment. [pmid: 2257231].
2943 Moore NN, Lapsley M, Norden AG, et al. Does N-acetylcysteine prevent contrast-induced nephropathy during endovascular AAA repair? A randomized controlled pilot study. Journal of Endovascular Therapy: Official Journal of the International Society of Endovascular Specialists. 2006;13(5):660-6. Sample size less than 50 patients.
2944 Moore RD, Lerner SA, Levine DP. Nephrotoxicity and ototoxicity of aztreonam versus aminoglycoside therapy in seriously ill nonneutropenic patients. Journal of Infectious Diseases. 1992;165(4):683-8. Not CKD treatment. [pmid: 1552197].
2945 Moore RD, Smith CR, Holloway JJ, et al. Cefotaxime vs nafcillin and tobramycin for the treatment of serious infection. Comparative cost-effectiveness. Archives of Internal Medicine. 1986;146(6):1153-7. Not CKD treatment. [pmid: 3087307].
2946 Moore RD, Steinberg EP, Powe NR, et al. Nephrotoxicity of high-osmolality versus low-osmolality contrast media: randomized clinical trial. Radiology. 1992;182(3):649-55. Not CKD treatment. [pmid: 1535876].
2947 Moore WV, Donaldson DL, Chonko AM, et al. Ambulatory blood pressure in type I diabetes mellitus. Comparison to presence of incipient nephropathy in adolescents and young adults. Diabetes. 1992;41(9):1035-41. Not RCT or controlled trial. [pmid: 1499855].
2948 Mor E, Patel T, Glabman S, et al. Comparison of short and long-term renal function in liver transplant patients receiving cyclosporin or FK 506. Transplant International. Suppl 1. 1994;7:S77-80. Not RCT or controlled trial. [pmid: 11271340].
2949 Mora C, Macia M, Navarro JF. Renal failure, anaemia, cytokines and inflammation. Nephrology Dialysis Transplantation. 2001;16(7):1524-5. Not RCT or controlled trial.
2950 Morales E, Valero MA, Leon M, et al. Beneficial effects of weight loss in overweight patients with chronic proteinuric nephropathies. American Journal of Kidney Diseases. 2003;41(2):319-27. Sample size less than 50 patients. [pmid: 12552492].
2951 Morales JM, Grinyo JM, Campistol JM, et al. Improved renal function, with similar proteinuria, after two years of early tacrolimus withdrawal from a regimen of sirolimus plus tacrolimus. Transplantation. 2008;86(4):620-2. Not CKD treatment. [pmid: 18724234].
2952 Morariu AM, Loef BG, Aarts LPHJ, et al. Dexamethasone: benefit and prejudice for patients undergoing on-pump coronary artery bypass grafting: a study on myocardial, pulmonary, renal, intestinal, and hepatic injury. Chest. 2005;128(4):2677-87. Not RCT or controlled trial. [pmid: 16236942].
2953 Morcos M, Borcea V, Isermann B, et al. Effect of alpha-lipoic acid on the progression of endothelial cell damage and albuminuria in patients with diabetes mellitus: an exploratory study. Diabetes Research & Clinical Practice. 2001;52(3):175-83. Sample size less than 50 patients. [pmid: 11323087].
2954 Moreau ME, Garbacki N, Molinaro G, et al. The kallikrein-kinin system: current and future pharmacological targets. Journal of Pharmacological Sciences. 2005;99(1):6-38. Not RCT or controlled trial. [pmid: 16177542].
2955 Moreau P, Milpied N, Fayette N, et al. Reduced renal toxicity and improved clinical tolerance of amphotericin B mixed with intralipid compared with conventional amphotericin B in neutropenic patients. Journal of Antimicrobial Chemotherapy. 1992;30(4):535-41. Sample size less than 50 patients. [pmid: 1490923].
2956 Moreau R, Lebrec D. Acute kidney injury: new concepts. Hepatorenal syndrome: the role of vasopressors. Nephron. Physiology. 2008;109(4):73-9. Not CKD treatment.
2957 Moreira RO, Trujillo FR, Meirelles RM, et al. Use of optical coherence tomography (OCT) and indirect ophthalmoscopy in the diagnosis of macular edema in diabetic patients. International Ophthalmology. 2001;24(6):331-6. Not CKD treatment. [pmid: 14750570].
2958 Morelli A, Ricci Z, Bellomo R, et al. Prophylactic fenoldopam for renal protection in sepsis: a randomized, double-blind, placebo-controlled pilot trial. Critical Care Medicine. 2005;33(11):2451-6. Not relevant to key questions. [pmid: 16276165].
2959 Morgan T, Anderson A, Bertram D, et al. Effect of candesartan and lisinopril alone and in combination on blood pressure and microalbuminuria. Journal of the Renin-Angiotensin-Aldosterone System. 2004;5(2):64-71. Not CKD treatment. [pmid: 15295717].
2960 Morganti A. Randomized clinical trials on surrogate end points: are they useful for evaluating cardiovascular and renal disease protection in hypertension? The case for yes. Journal of the American Society of Nephrology. 2006;17(4 Suppl 2):S141-4. Not relevant to key questions. [pmid: 16565239].
2961 Morgera S, Woydt R, Kern H, et al. Low-dose prostacyclin preserves renal function in high-risk patients after coronary bypass surgery. Critical Care Medicine. 2002;30(1):107-12. Not early CKD. [pmid: 11902251].
2962 Mori TA, Burke V, Puddey I, et al. The effects of [omega]3 fatty acids and coenzyme Q10 on blood pressure and heart rate in chronic kidney disease: a randomized controlled trial. Journal of Hypertension. 2009;27(9):1863-72. Follow-up less than 6 months. [pmid: 19705518].
2963 Morikawa S, Sone T, Tsuboi H, et al. Renal protective effects and the prevention of contrast-induced nephropathy by atrial natriuretic peptide. [Erratum appears in J Am Coll Cardiol. 2009 Sep 15;54(12):1122]. Journal of the American College of Cardiology. 2009;53(12):1040-6. Not RCT or controlled trial. [pmid: 19298916].
2964 Morillas RM, Planas R, Cabre E, et al. Propranolol plus isosorbide-5-mononitrate for portal hypertension in cirrhosis: long-term hemodynamic and renal effects. Hepatology. 1994;20(6):1502-8. Not CKD treatment. [pmid: 7982651].
2965 Morimoto S, Yano Y, Maki K, et al. Renal and vascular protective effects of cilnidipine in patients with essential hypertension. Journal of Hypertension. 2007;25(10):2178-83. Not RCT or controlled trial. [pmid: 17885563].
2966 Morimoto S, Yano Y, Maki K, et al. Renal and vascular protective effects of telmisartan in patients with essential hypertension. Hypertension Research - Clinical & Experimental. 2006;29(8):567-72. Not RCT or controlled trial.
2967 Morita S, Fukuhara S, Akizawa T, et al. Study design and methods for a clinical trial of an oral carbonaceous adsorbent used to prevent the progression of chronic kidney disease (CAP-KD). Clinical & Experimental Nephrology. 2005;9(3):219-27. Not CKD treatment. [pmid: 16189630].
2968 Morris ST, McMurray JJ, Rodger RS, et al. Impaired endothelium-dependent vasodilatation in uraemia. Nephrology Dialysis Transplantation. 2000;15(8):1194-200. Sample size less than 50 patients.
2969 Mortelmans LJM, Desruelles D, Baert JA, et al. Use of tramadol drip in controlling renal colic pain. Journal of Endourology. 2006;20(12):1010-5. Not RCT or controlled trial. [pmid: 17206893].
2970 Mortensen BM, Aarseth HP. Ganss R, et al. 24,25-dihydroxy vitamin D3 treatment inhibits parathyroid-stimulated adenylate cyclase in iliac crest biopsies from uremic patients. Bone. 1993;14(2):125-31. Sample size less than 50 patients. [pmid: 8334029].
2971 Mosconi L, Ruggenenti P, Perna A, et al. Nitrendipine and enalapril improve albuminuria and glomerular filtration rate in non-insulin dependent diabetes. Kidney International - Supplement. 1996;55:S91-3. Sample size less than 50 patients. [pmid: 8743521].
2972 Motovska Z, Widimsky P, Petr R, et al. Factors influencing clopidogrel efficacy in patients with stable coronary artery disease undergoing elective percutaneous coronary intervention: statin's advantage and the smoking “paradox”. Journal of Cardiovascular Pharmacology. 2009;53(5):368-72. Not CKD treatment. [pmid: 19247187].
2973 Motwani JG, Fenwick MK, McAlpine HM, et al. Effectiveness of captopril in reversing renal vasoconstriction after Q-wave acute myocardial infarction. American Journal of Cardiology. 1993;71(4):281-6. Sample size less than 50 patients. [pmid: 8427168].
2974 Motwani JG, Fenwick MK, Morton JJ, et al. Furosemide-induced natriuresis is augmented by ultra-low-dose captopril but not by standard doses of captopril in chronic heart failure. Circulation. 1992;86(2):439-45. Sample size less than 50 patients. [pmid: 1638713].
2975 Motwani JG, Fenwick MK, Morton JJ, et al. Determinants of the initial effects of captopril on blood pressure, glomerular filtration rate, and natriuresis in mild-to-moderate chronic congestive heart failure secondary to coronary artery disease. American Journal of Cardiology. 1994;73(16):1191-6. Sample size less than 50 patients. [pmid: 8203337].
2976 Motwani JG, Fenwick MK, Struthers AD. Comparison of three methods of glomerular filtration rate measurement with and without captopril pretreatment in groups of patients with left ventricular dysfunction. European Heart Journal. 1992;13(9):1195-200. Not CKD treatment. [pmid: 1396829].
2977 Motwani JG, Lang CC, Cramb G, et al. Natriuretic response to neutral endopeptidase inhibition is blunted by enalapril in healthy men. Hypertension. 1995;25(4 Pt 1):637-42. Sample size less than 50 patients. [pmid: 7721409].
2978 Motwani JG, Struthers AD. Interactive effects of indomethacin, angiotensin II and frusemide on renal haemodynamics and natriuresis in man. British Journal of Clinical Pharmacology. 1994;37(4):355-61. Not CKD treatment. [pmid: 8018457].
2979 Moudgal VV, Sobel JD. Selecting antifungal agents for the treatment of invasive fungal infections in patients with renal failure. Current Opinion in Investigational Drugs. 2004;5(8):873-8. Follow-up less than 6 months. [pmid: 15600244].
2980 Moulder JE, Fish BL, Cohen EP. ACE inhibitors and AII receptor antagonists in the treatment and prevention of bone marrow transplant nephropathy. Current Pharmaceutical Design. 2003;9(9):737-49. Not relevant to key questions. [pmid: 12570791].
2981 Moulin B, Fillastre JP, Godin M, et al. Renal hemodynamics and sodium excretion after acute and chronic administration of cicletanine in normotensive and hypertensive subjects. Journal of Cardiovascular Pharmacology. 1995;25(2):292-9. Sample size less than 50 patients. [pmid: 7752655].
2982 Mourad G, Haecker W, Mion C. Dose-dependent salidiuretic efficacy of torasemide in comparison to furosemide and placebo in advanced renal failure. Arzneimittel-Forschung. 1988;38(1A):205-8. Sample size less than 50 patients. [pmid: 3285835].
2983 Mourad JJ, Le Jeune S. Evaluation of high dose of perindopril/indapamide fixed combination in reducing blood pressure and improving end-organ protection in hypertensive patients. Current Medical Research & Opinion. 2009;25(9):2271-80. Not RCT or controlled trial. [pmid: 19627177].
2984 Moyses C, Higgins TJ. Safety of long-term use of lisinopril for congestive heart failure. American Journal of Cardiology. 1992;70(10):91C-7C. Not CKD treatment. [pmid: 1615876].
2985 Mueck AO, Seeger H, Petersen G, et al. Effect of two oral contraceptives with different ethinyl estradiol and levonorgestrel concentrations on the urinary excretion of biochemical vasoactive markers. Contraception. 2001;64(6):357-62. Not early CKD. [pmid: 11834234].
2986 Mueller AR, Platz KP, Blumhardt G, et al. The optimal immunosuppressant after liver transplantation according to diagnosis: cyclosporine A or FK506?. Clinical Transplantation. 1995;9(3 Pt 1):176-84. Not CKD treatment. [pmid: 7549057].
2987 Mueller C. Prevention of contrast-induced nephropathy with volume supplementation. Kidney International - Supplement. 2006;(100):S16-9. Not RCT or controlled trial. [pmid: 16612395].
2988 Mueller C, Buerkle G, Buettner HJ, et al. Prevention of contrast media-associated nephropathy: randomized comparison of 2 hydration regimens in 1620 patients undergoing coronary angioplasty. Archives of Internal Medicine. 2002;162(3):329-36. Not early CKD. [pmid: 11822926].
2989 Mueller C, Buerkle G, Perruchoud AP, et al. Female sex and risk of contrast nephropathy after percutaneous coronary intervention. Canadian Journal of Cardiology. 2004;20(5):505-9. Not relevant to key questions. [pmid: 15100752].
2990 Mueller C, Laule-Kilian K, Scholer A, et al. B-type natriuretic peptide for acute dyspnea in patients with kidney disease: insights from a randomized comparison. Kidney International. 2005;67(1):278-84. Not CKD treatment. [pmid: 15610252].
2991 Mueller C, Seidensticker P, Buettner HJ, et al. Incidence of contrast nephropathy in patients receiving comprehensive intravenous and oral hydration. Swiss Medical Weekly. 2005;135(19-20):286-90. Follow-up less than 6 months. [pmid: 15986266].
2992 Muir A, Davidson R, Silverstone T, et al. Two regimens of lithium prophylaxis and renal function. Acta Psychiatrica Scandinavica. 1989;80(6):579-83. Sample size less than 50 patients. [pmid: 2515753].
2993 Muirhead N. A rationale for an individualized haemoglobin target. Nephrology Dialysis Transplantation. Suppl 6. 2002;17:2-7. Not RCT or controlled trial.
2994 Mukhopadhyay S, Singh M, Cater JI, et al. Nebulised antipseudomonal antibiotic therapy in cystic fibrosis: a meta-analysis of benefits and risks. Thorax. 1996;51(4):364-8. Not RCT or controlled trial. [pmid: 8733486].
2995 Mulec H, Johnsen SA, Bjorck S. Long-term enalapril treatment in diabetic nephropathy. Kidney International - Supplement. 1994;45:S141-4. Not relevant to key questions. [pmid: 8158883].
2996 Mulec H, Johnson SA, Bjorck S. Relation between serum cholesterol and diabetic nephropathy. Lancet. 1990;335(8704):1537-8. Not RCT or controlled trial. [pmid: 1972477].
2997 Mulhauser I, Prange K, Sawicki PT, et al. Effects of dietary sodium on blood pressure in IDDM patients with nephropathy. Diabetologia. 1996;39(2):212-9. Sample size less than 50 patients. [pmid: 8635674].
2998 Munger MA, Gardner SF, Ateshkadi A, et al. Misoprostol effects on diclofenac-induced cardiorenal changes in salt-sensitive patients with hypertension: the MEDIC Study. Pharmacotherapy. 2008;28(7):834-42. Not CKD treatment. [pmid: 18576898].
2999 Munkhaugen J, Lydersen S, Romundstad PR, et al. Kidney function and future risk for adverse pregnancy outcomes: a population-based study from HUNT II, Norway. Nephrology Dialysis Transplantation. 2009;24(12):3744-50. Not RCT or controlled trial.
3000 Munoz M, Breymann C, Garcia-Erce JA, et al. Efficacy and safety of intravenous iron therapy as an alternative/adjunct to allogeneic blood transfusion. Vox Sanguinis. 2008;94(3):172-83. Not RCT or controlled trial. [pmid: 18069918].
3001 Munoz-Garcia B, Moreno JA, Lopez-Franco O, et al. Tumor necrosis factor-like weak inducer of apoptosis (TWEAK) enhances vascular and renal damage induced by hyperlipidemic diet in ApoE-knockout mice. Arteriosclerosis, Thrombosis & Vascular Biology. 2009;29(12):2061-8. Follow-up less than 6 months.
3002 Murakami R, Tajima H, Kumazaki T. Effect of iomeprol on renal function immediately after abdominal angiography. Acta Radiologica. 1996;37(6):962-5. Sample size less than 50 patients. [pmid: 8995474].
3003 Murakami R, Tajima H, Kumazaki T, et al. Effect of iodixanol on renal function immediately after abdominal angiography. Clinical comparison with iomeprol and ioxaglate. Acta Radiologica. 1998;39(4):368-71. Sample size less than 50 patients. [pmid: 9685820].
3004 Murayama S, Hirano T, Sakaue T, et al. Low-dose candesartan cilexetil prevents early kidney damage in type 2 diabetic patients with mildly elevated blood pressure. Hypertension Research - Clinical & Experimental. 2003;26(6):453-8. Not RCT or controlled trial.
3005 Murdoch D, Sager J. Will targeted therapy hold its promise? An evidence-based review. Current Opinion in Oncology. 2008;20(1):104-11. Follow-up less than 6 months. [pmid: 18043264].
3006 Murgia MG, Jordan S, Kahan BD. The side effect profile of sirolimus: a phase I study in quiescent cyclosporine-prednisone-treated renal transplant patients. Kidney International. 1996;49(1):209-16. Not early CKD. [pmid: 8770969].
3007 Muriel C, Ortiz P. Efficacy of two different intramuscular doses of dipyrone in acute renal colic. Cooperative Study Group. Methods & Findings in Experimental & Clinical Pharmacology. 1993;15(7):465-9. Not CKD treatment. [pmid: 8255126].
3008 Muriel-Villoria C, Zungri-Telo E, Diaz-Curiel M, et al. Comparison of the onset and duration of the analgesic effect of dipyrone, 1 or 2 g, by the intramuscular or intravenous route, in acute renal colic. European Journal of Clinical Pharmacology. 1995;48(2):103-7. Follow-up less than 6 months. [pmid: 7589022].
3009 Murphy PT, Casey MC, Walker F, et al. The role of plasmapheresis in myeloma patients with renal failure. Clinical & Laboratory Haematology. 1994;16(4):407. Not CKD treatment. [pmid: 7736718].
3010 Murray MD, Black PK, Kuzmik DD, et al. Acute and chronic effects of nonsteroidal antiinflammatory drugs on glomerular filtration rate in elderly patients. American Journal of the Medical Sciences. 1995;310(5):188-97. Sample size less than 50 patients. [pmid: 7485222].
3011 Murray MD, Greene PK, Brater DC, et al. Effects of flurbiprofen on renal function in patients with moderate renal insufficiency. British Journal of Clinical Pharmacology. 1992;33(4):385-93. Sample size less than 50 patients. [pmid: 1576067].
3012 Muscheites J, Wigger M, Drueckler E, et al. Cinacalcet for secondary hyperparathyroidism in children with end-stage renal disease. Pediatric Nephrology. 2008;23(10):1823-9. Not CKD treatment. [pmid: 18504621].
3013 Musleh GS, Patel NC, Grayson AD, et al. Off-pump coronary artery bypass surgery does not reduce gastrointestinal complications. European Journal of Cardio-Thoracic Surgery. 2003;23(2):170-4. Not CKD treatment. [pmid: 12559338].
3014 Musso P, Cox I, Vidano E, et al. Cardiac troponin elevations in chronic renal failure: prevalence and clinical significance. Clinical Biochemistry. 1999;32(2):125-30. Not CKD treatment. [pmid: 10211629].
3015 Myint L, Tin Nu S, Myint Aye M, et al. Heparin therapy in Russell's viper bite victims with impending dic (a controlled trial). Southeast Asian Journal of Tropical Medicine & Public Health. 1989;20(2):271-7. Sample size less than 50 patients. [pmid: 2532790].
3016 Myles PS, Buckland MR, Schenk NJ, et al. Effect of “renal-dose” dopamine on renal function following cardiac surgery. Anaesthesia & Intensive Care. 1993;21(1):56-61. Not RCT or controlled trial. [pmid: 8447608].
3017 Myrup B, Hansen PM, Jensen T, et al. Effect of low-dose heparin on urinary albumin excretion in insulin-dependent diabetes mellitus. Lancet. 1995;345(8947):421-2. Sample size less than 50 patients. [pmid: 7853952].
3018 Na KY, Han JS, Kim YS, et al. Does albumin preinfusion potentiate diuretic action of furosemide in patients with nephrotic syndrome?. Journal of Korean Medical Science. 2001;16(4):448-54. Sample size less than 50 patients. [pmid: 11511790].
3019 Naeije R, Degaute JP. Redistribution of cardiac output to the kidneys by tertatolol does not involve prostaglandins. American Journal of Hypertension. 1989;2(11 Pt 2):241S-4S. Sample size less than 50 patients. [pmid: 2573371].
3020 Naeije R, Fiasse A, Carlier E, et al. Systemic and renal haemodynamic effects of angiotensin converting enzyme inhibition by zabicipril in young and in old normal men. European Journal of Clinical Pharmacology. 1993;44(1):35-9. Sample size less than 50 patients. [pmid: 8436152].
3021 Nagai T. The effect of pancreatic elastase on diabetic nephropathy. Diabetes Research & Clinical Practice. 1994;24(3):161-5. Not RCT or controlled trial. [pmid: 7988347].
3022 Nagaya N, Miyatake K, Uematsu M, et al. Hemodynamic, renal, and hormonal effects of ghrelin infusion in patients with chronic heart failure. Journal of Clinical Endocrinology & Metabolism. 2001;86(12):5854-9. Sample size less than 50 patients. [pmid: 11739451].
3023 Nagaya N, Satoh T, Nishikimi T, et al. Hemodynamic, renal, and hormonal effects of adrenomedullin infusion in patients with congestive heart failure. Circulation. 2000;101(5):498-503. Sample size less than 50 patients. [pmid: 10662746].
3024 Nagler A, Ackerstein A, Ben-Shahar M, et al. Continuous interleukin-2 infusion combined with cyclophosphamide- based combination chemotherapy in the treatment of hemato-oncological malignancies. Results of a phase I-II study. Acta Haematologica. 1998;100(2):63-8. Sample size less than 50 patients. [pmid: 9792934].
3025 Nair KS, Pabico RC, Truglia JA, et al. Mechanism of glomerular hyperfiltration after a protein meal in humans. Role of hormones and amino acids. Diabetes Care. 1994;17(7):711-5. Not CKD treatment. [pmid: 7924782].
3026 Nakamura K, Okamura T, Hayakawa T, et al. Chronic kidney disease is a risk factor for cardiovascular death in a community-based population in Japan: NIPPON DATA90. Circulation Journal. 2006;70(8):954-9. Follow-up less than 6 months. [pmid: 16864924].
3027 Nakamura M, Arakawa N, Kato M. Renal, hormonal, and hemodynamic effects of low-dose infusion of atrial natriuretic factor in acute myocardial infarction. American Heart Journal. 1990;120(5):1078-85. Not CKD treatment. [pmid: 2146863].
3028 Nakamura T, Fujiwara N, Kawagoe Y, et al. Effects of telmisartan and enalapril on renoprotection in patients with mild to moderate chronic kidney disease. European Journal of Clinical Investigation. Sep. 2010;40(9):790-6. Sample size less than 50 patients. [pmid: 20584070].
3029 Nakamura T, Fujiwara N, Sugaya T, et al. Effect of red wine on urinary protein, 8-hydroxydeoxyguanosine, and liver-type fatty acid-binding protein excretion in patients with diabetic nephropathy. Metabolism: Clinical & Experimental. 2009;58(8):1185-90. Sample size less than 50 patients. [pmid: 19481229].
3030 Nakamura T, Inoue T, Fujiwara N, et al. Additional renoprotective effects of azelnidipine combined with angiotensin receptor blockers in patients with diabetic nephropathy. Clinical Nephrology. 2008;70(5):385-92. Not RCT or controlled trial. [pmid: 19000538].
3031 Nakamura T, Inoue T, Sugaya T, et al. Renoprotective effect of telmisartan in patients with chronic kidney disease. Clinical & Experimental Hypertension. 2008;30(7):662-72. Sample size less than 50 patients. [pmid: 18855269].
3032 Nakamura T, Kanno Y, Takenaka T, et al. An angiotensin receptor blocker reduces the risk of congestive heart failure in elderly hypertensive patients with renal insufficiency. Hypertension Research - Clinical & Experimental. 2005;28(5):415-23. Not relevant to key questions.
3033 Nakamura T, Kawagoe Y, Matsuda T, et al. Oral ADSORBENT AST-120 decreases carotid intima-media thickness and arterial stiffness in patients with chronic renal failure. Kidney & Blood Pressure Research. 2004;27(2):121-6. Not relevant to key questions. [pmid: 15051932].
3034 Nakamura T, Matsuda T, Kawagoe Y, et al. Effect of pioglitazone on carotid intima-media thickness and arterial stiffness in type 2 diabetic nephropathy patients. Metabolism: Clinical & Experimental. 2004;53(10):1382-6. Follow-up less than 6 months. [pmid: 15375799].
3035 Nakamura T, Sato E, Fujiwara N, et al. Comparative effects of benidipine and amlodipine on proteinuria, urinary 8-OHdG, urinary L-FABP, and inflammatory and atherosclerosis markers in early-stage chronic kidney disease. American Journal of the Medical Sciences. 2010;339(2):157-63. Sample size less than 50 patients. [pmid: 20145433].
3036 Nakamura T, Sato E, Fujiwara N, et al. Co-administration of ezetimibe enhances proteinuria-lowering effects of pitavastatin in chronic kidney disease patients partly via a cholesterol-independent manner. Pharmacological Research. Jan. 2010;61(1):58-61. Sample size less than 50 patients. [pmid: 19666118].
3037 Nakamura T, Sugaya T, Kawagoe Y, et al. Effect of pitavastatin on urinary liver-type fatty-acid-binding protein in patients with nondiabetic mild chronic kidney disease. American Journal of Nephrology. 2006;26(1):82-6. Not RCT or controlled trial. [pmid: 16534182].
3038 Nakamura T, Sugaya T, Kawagoe Y, et al. Effect of erythropoietin on urinary liver-type fatty-acid-binding protein in patients with chronic renal failure and anemia. American Journal of Nephrology. 2006;26(3):276-80. Sample size less than 50 patients. [pmid: 16772708].
3039 Nakamura T, Sugaya T, Kawagoe Y, et al. Azelnidipine reduces urinary protein excretion and urinary liver-type fatty acid binding protein in patients with hypertensive chronic kidney disease. American Journal of the Medical Sciences. 2007;333(6):321-6. Follow-up less than 6 months. [pmid: 17570983].
3040 Nakamura T, Sugaya T, Kawagoe Y, et al. Effect of pitavastatin on urinary liver-type fatty acid-binding protein levels in patients with early diabetic nephropathy. Diabetes Care. 2005;28(11):2728-32. Sample size less than 50 patients. [pmid: 16249547].
3041 Nakamura T, Ushiyama C, Hirokawa K, et al. Effect of cerivastatin on urinary albumin excretion and plasma endothelin-1 concentrations in type 2 diabetes patients with microalbuminuria and dyslipidemia. American Journal of Nephrology. 2001;21(6):449-54. Not relevant to key questions. [pmid: 11799261].
3042 Nakamura T, Ushiyama C, Osada S, et al. Pioglitazone reduces urinary podocyte excretion in type 2 diabetes patients with microalbuminuria. Metabolism: Clinical & Experimental. 2001;50(10):1193-6. Sample size less than 50 patients. [pmid: 11586492].
3043 Nakamura T, Ushiyama C, Shimada N, et al. Effect of the antiplatelet drug dilazep dihydrochloride on urinary podocytes in patients in the early stage of diabetic nephropathy. Diabetes Care. 2000;23(8):1168-71. Not RCT or controlled trial. [pmid: 10937516].
3044 Nakamura T, Ushiyama C, Suzuki S, et al. Comparison between the angiotensin II receptor antagonist candesartan cilexetil and the angiotensin-converting enzyme inhibitor trandolapril in microalbuminuria of patients with early diabetic nephropathy. Nephron. 2000;86(2):247. Follow-up less than 6 months. [pmid: 11015024].
3045 Nakamura T, Ushiyama C, Suzuki Y, et al. Hemoperfusion with polymyxin B immobilized fibers for urinary albumin excretion in septic patients with trauma. ASAIO Journal. 2002;48(3):244-8. Not early CKD. [pmid: 12058997].
3046 Nakano S, Takekoshi H, Nakano M. Chlorella pyrenoidosa supplementation reduces the risk of anemia, proteinuria and edema in pregnant women. Plant Foods for Human Nutrition. Mar. 2010;65(1):25-30. Not early CKD. [pmid: 20013055].
3047 Nakano T, Ninomiya T, Sumiyoshi S, et al. Association of kidney function with coronary atherosclerosis and calcification in autopsy samples from Japanese elders: the Hisayama study. American Journal of Kidney Diseases. 2010;55(1):21-30. Not RCT or controlled trial. [pmid: 19765871].
3048 Nakao N, Seno H, Kasuga H, et al. Effects of combination treatment with losartan and trandolapril on office and ambulatory blood pressures in non-diabetic renal disease: a COOPERATE-ABP substudy. American Journal of Nephrology. 2004;24(5):543-8. Not RCT or controlled trial. [pmid: 15528874].
3049 Nakao N, Yoshimura A, Morita H, et al. Combination treatment of angiotensin-II receptor blocker and angiotensin-converting-enzyme inhibitor in non-diabetic renal disease (COOPERATE): a randomised controlled trial. [Erratum appears in Lancet. 2003 Apr 5;361(9364):1230].[Retraction in Lancet. 2009 Oct 10;374(9697):1226; PMID:19819378]. Lancet. 2003;361(9352):117-24. Not CKD treatment. [pmid: 12531578].
3050 Nakao N, Yoshimura A, Morita H, et al. Combination treatment of angiotensin-II receptor blocker and angiotensin-converting-enzyme inhibitor in non-diabetic renal disease (COOPERATE): a randomised controlled trial. [Erratum appears in Lancet. 2003 Apr 5;361(9364):1230].[Retraction in Lancet. 2009 Oct 10;374(9697):1226; PMID:19819378]. Lancet. 2003;361(9352):117-24. Not CKD treatment. [pmid: 12531578].
3051 Nakao T, Yoshino M, Matsumoto H, et al. Low-density lipoprotein apheresis retards the progression of hyperlipidemic overt diabetic nephropathy. Kidney International - Supplement. 1999;71:S206-9. Sample size less than 50 patients. [pmid: 10412777].
3052 Nakayama Y, Nonoguchi H, Kohda Y, et al. Different Mechanisms for the Progression of CKD with ACE Gene Polymorphisms. Nephron. 2009;111(4):c240-6. Not RCT or controlled trial. [pmid: 19293592].
3053 Nallamothu BK, Shojania KG, Saint S, et al. Is acetylcysteine effective in preventing contrast-related nephropathy? A meta-analysis. American Journal of Medicine. 2004;117(12):938-47. Not relevant to key questions. [pmid: 15629733].
3054 Nalysnyk L, Fahrbach K, Reynolds MW, et al. Adverse events in coronary artery bypass graft (CABG) trials: a systematic review and analysis. Heart. 2003;89(7):767-72. Not CKD treatment. [pmid: 12807853].
3055 Nanayakkara PWB, Kiefte-de Jong JC, Stehouwer CDA, et al. Association between global leukocyte DNA methylation, renal function, carotid intima-media thickness and plasma homocysteine in patients with stage 2-4 chronic kidney disease. Nephrology Dialysis Transplantation. 2008;23(8):2586-92. Not CKD treatment.
3056 Nanayakkara PWB, Kiefte-de Jong JC, ter Wee PM, et al. Randomized placebo-controlled trial assessing a treatment strategy consisting of pravastatin, vitamin E, and homocysteine lowering on plasma asymmetric dimethylarginine concentration in mild to moderate CKD. American Journal of Kidney Diseases. 2009;53(1):41-50. Not CKD treatment. [pmid: 18786751].
3057 Nanayakkara PWB, Teerlink T, Stehouwer CDA, et al. Plasma asymmetric dimethylarginine (ADMA) concentration is independently associated with carotid intima-media thickness and plasma soluble vascular cell adhesion molecule-1 (sVCAM-1) concentration in patients with mild-to-moderate renal failure. Kidney International. 2005;68(5):2230-6. Sample size less than 50 patients. [pmid: 16221223].
3058 Nanayakkara PWB, van Guldener C, ter Wee PM, et al. Effect of a treatment strategy consisting of pravastatin, vitamin E, and homocysteine lowering on carotid intima-media thickness, endothelial function, and renal function in patients with mild to moderate chronic kidney disease: results from the Anti-Oxidant Therapy in Chronic Renal Insufficiency (ATIC) Study. Archives of Internal Medicine. 2007;167(12):1262-70. Not RCT or controlled trial. [pmid: 17592099].
3059 Nangaku M, Fliser D. Erythropoiesis-stimulating agents: past and future. Kidney International - Supplement. 2007;(107):S1-3. Not RCT or controlled trial. [pmid: 17943137].
3060 Nankervis A, Nicholls K, Kilmartin G, et al. Effects of perindopril on renal histomorphometry in diabetic subjects with microalbuminuria: a 3-year placebo-controlled biopsy study. Metabolism: Clinical & Experimental. 1998;47(12 Suppl 1):12-5. Sample size less than 50 patients. [pmid: 9867064].
3061 Nash RA, Etzioni R, Storb R, et al. Tacrolimus (FK506) alone or in combination with methotrexate or methylprednisolone for the prevention of acute graft-versus-host disease after marrow transplantation from HLA-matched siblings: a single-center study. Blood. 1995;85(12):3746-53. Sample size less than 50 patients. [pmid: 7540071].
3062 Natov S, Hannedouche T, Schmitt F, et al. Are the renal haemodynamic and natriuretic effects of calcium antagonists and angiotensin converting inhibitors additive?. Journal of Hypertension - Supplement. 1991;9(6):S392-3. Sample size less than 50 patients.
3063 Naughton F, Wijeysundera D, Karkouti K, et al. N-acetylcysteine to reduce renal failure after cardiac surgery: a systematic review and meta-analysis. Canadian Journal of Anaesthesia. 2008;55(12):827-35. Not CKD treatment. [pmid: 19050086].
3064 Navaneethan SD, Nigwekar SU, Sehgal AR, et al. Aldosterone antagonists for preventing the progression of chronic kidney disease. Cochrane Database of Systematic Reviews. 2009;3:CD007004. Not RCT or controlled trial. [pmid: 19588415].
3065 Navaneethan SD, Nigwekar SU, Sehgal AR, et al. Aldosterone antagonists for preventing the progression of chronic kidney disease: a systematic review and meta-analysis. Clinical Journal of The American Society of Nephrology: CJASN. 2009;4(3):542-51. Follow-up less than 6 months. [pmid: 19261819].
3066 Navaneethan SD, Pansini F, Strippoli GFM. Statins in patients with chronic kidney disease: evidence from systematic reviews and randomized clinical trials. PLoS Medicine / Public Library of Science. 2006;3(5):e123. Not relevant to key questions.
3067 Navaneethan SD, Singh S, Appasamy S, et al. Sodium bicarbonate therapy for prevention of contrast-induced nephropathy: a systematic review and meta-analysis. American Journal of Kidney Diseases. 2009;53(4):617-27. Not CKD treatment. [pmid: 19027212].
3068 Navarro JF, Mora C, Muros M, et al. Additive antiproteinuric effect of pentoxifylline in patients with type 2 diabetes under angiotensin II receptor blockade: a short-term, randomized, controlled trial. Journal of the American Society of Nephrology. 2005;16(7):2119-26. Follow-up less than 6 months. [pmid: 15917336].
3069 Navarro JF, Mora C, Muros M, et al. Effects of pentoxifylline administration on urinary N-acetyl-beta-glucosaminidase excretion in type 2 diabetic patients: a short-term, prospective, randomized study. American Journal of Kidney Diseases. 2003;42(2):264-70. Sample size less than 50 patients. [pmid: 12900807].
3070 Navarro JF, Mora C, Rivero A, et al. Urinary protein excretion and serum tumor necrosis factor in diabetic patients with advanced renal failure: effects of pentoxifylline administration. American Journal of Kidney Diseases. 1999;33(3):458-63. Sample size less than 50 patients. [pmid: 10070909].
3071 Naviglio S, Pirozzi F. Renin-Angiotensin system blockade for diabetic nephropathy prevention. American Journal of Cardiology. May. 15. 2010;105(10):1505. Not RCT or controlled trial. [pmid: 20451706].
3072 Navis G, de Jong PE, Donker AJ, et al. Moderate sodium restriction in hypertensive subjects: renal effects of ACE-inhibition. Kidney International. 1987;31(3):815-9. Follow-up less than 6 months. [pmid: 3033389].
3073 Naylor CD, Detsky AS, O'Rourke K, et al. Does treatment with essential amino acids and hypertonic glucose improve survival in acute renal failure?: A meta-analysis. Renal Failure. 1987;10(3-4):141-52. Not relevant to key questions. [pmid: 3141988].
3074 Nazir FS, Overell JR, Bolster A, et al. Effect of perindopril on cerebral and renal perfusion on normotensives in mild early ischaemic stroke: a randomized controlled trial. Cerebrovascular Diseases. 2005;19(2):77-83. Follow-up less than 6 months. [pmid: 15608430].
3075 Nazir FS, Overell JR, Bolster A, et al. The effect of losartan on global and focal cerebral perfusion and on renal function in hypertensives in mild early ischaemic stroke. Journal of Hypertension. 2004;22(5):989-95. Not CKD treatment. [pmid: 15097240].
3076 Negri AL. Prevention of progressive fibrosis in chronic renal diseases: antifibrotic agents. Journal of Nephrology. 2004;17(4):496-503. Not relevant to key questions. [pmid: 15372410].
3077 Negrier S, Perol D, Ravaud A, et al. Randomized study of intravenous versus subcutaneous interleukin-2, and IFNalpha in patients with good prognosis metastatic renal cancer. Clinical Cancer Research. 2008;14(18):5907-12. Not CKD treatment. [pmid: 18794104].
3078 Nellemann B, Gormsen LC, Dollerup J, et al. Simvastatin reduces plasma osteoprotegerin in type 2 diabetic patients with microalbuminuria. Diabetes Care. 2007;30(12):3122-4. Not RCT or controlled trial. [pmid: 17804683].
3079 Nelson CE, Nylander C, Olsson AM, et al. Rectal v. intravenous administration of indomethacin in the treatment of renal colic. Acta Chirurgica Scandinavica. 1988;154(4):253-5. Not relevant to key questions. [pmid: 3287813].
3080 Nergelius G, Vinge E, Bengtsson HI, et al. No effect of diclofenac on the pharmacokinetics of cloxacillin. Pharmacology & Toxicology. 1997;81(1):26-30. Not CKD treatment. [pmid: 9258981].
3081 Neri S, Bruno CM, Leotta C, et al. Early endothelial alterations in non-insulin-dependent diabetes mellitus. International Journal of Clinical & Laboratory Research. 1998;28(2):100-3. Not CKD treatment. [pmid: 9689551].
3082 Nesher G, Sonnenblick M, Dwolatzky T. Protective effect of misoprostol on indomethacin induced renal dysfunction in elderly patients. Journal of Rheumatology. 1995;22(4):713-6. Sample size less than 50 patients. [pmid: 7791169].
3083 Netelenbos JC, Asscheman H, Lips P, et al. Absence of effect of 24,25-dihydroxyvitamin D3 in primary hyperparathyroidism. Journal of Clinical Endocrinology & Metabolism. 1986;63(1):246-8. Sample size less than 50 patients. [pmid: 3486877].
3084 Neuberger JM, Mamelok RD, Neuhaus P, et al. Delayed introduction of reduced-dose tacrolimus, and renal function in liver transplantation: the ‘ReSpECT’study. American Journal of Transplantation. 2009;9(2):327-36. Not RCT or controlled trial. [pmid: 19120077].
3085 Neuhaus PJ. Optimised first-line FK506-based protocols in liver transplantation: experience from the University Hospital Rudolf Virchow, Berlin. Transplantation Proceedings. 1994;26(6):3264-6. Not RCT or controlled trial. [pmid: 7527961].
3086 Neuhofer W, Pittrow D. Endothelin receptor selectivity in chronic kidney disease: rationale and review of recent evidence. European Journal of Clinical Investigation. Suppl 2. 2009;39:50-67. Not early CKD. [pmid: 19335747].
3087 Neumann DR, Esselstyn CB Jr., Madera A, et al. Parathyroid detection in secondary hyperparathyroidism with 123I/99mTc-sestamibi subtraction single photon emission computed tomography. Journal of Clinical Endocrinology & Metabolism. 1998;83(11):3867-71. Not CKD treatment. [pmid: 9814460].
3088 Neumayer HH, Gellert J, Luft FC. Calcium antagonists and renal protection. Renal Failure. 1993;15(3):353-8. Not RCT or controlled trial. [pmid: 8516490].
3089 Neumayer HH, Junge W, Kufner A, et al. Prevention of radiocontrast-media-induced nephrotoxicity by the calcium channel blocker nitrendipine: a prospective randomised clinical trial. Nephrology Dialysis Transplantation. 1989;4(12):1030-6. Not CKD treatment.
3090 Neumayer HH, Kunzendorf U. Renal protection with the calcium antagonists. Journal of Cardiovascular Pharmacology. Suppl 1. 1991;18:S11-8. Not relevant to key questions. [pmid: 1723449].
3091 Neuringer JR, Levey AS. Strategies to slow the progression of renal disease. Seminars in Nephrology. 1994;14(3):261-73. Not RCT or controlled trial. [pmid: 8036361].
3092 New JP, Marshall SM, Bilous RW. Renal autoregulation is normal in newly diagnosed, normotensive, NIDDM patients. Diabetologia. 1998;41(2):206-11. Sample size less than 50 patients. [pmid: 9498655].
3093 Newell DR, Eeles RA, Gumbrell LA, et al. Carboplatin and etoposide pharmacokinetics in patients with testicular teratoma. Cancer Chemotherapy & Pharmacology. 1989;23(6):367-72. Not CKD treatment. [pmid: 2469544].
3094 Newman PJ, Quinn AC, Hall GM, et al. Circulating fluoride changes and hepatorenal function following sevoflurane anaesthesia. Anaesthesia. 1994;49(11):936-9. Not CKD treatment. [pmid: 7802235].
3095 Newman TJ, Dreslinski GR, Tadros SS. Safety profile of aztreonam in clinical trials. Reviews of Infectious Diseases. Suppl 4. 1985;7:S648-55. Not RCT or controlled trial. [pmid: 2934785].
3096 Ng TMH, Shurmur SW, Silver M, et al. Comparison of N-acetylcysteine and fenoldopam for preventing contrast-induced nephropathy (CAFCIN). International Journal of Cardiology. 2006;109(3):322-8. Follow-up less than 6 months. [pmid: 16039733].
3097 Ngan HY, Choo YC, Cheung M, et al. A randomized study of high-dose versus low-dose cis-platinum combined with cyclophosphamide in the treatment of advanced ovarian cancer. Hong Kong Ovarian Carcinoma Study Group. Chemotherapy. 1989;35(3):221-7. Not CKD treatment. [pmid: 2766862].
3098 Ngugi NN, McLigeyo SO, Kayima JK. Treatment of hyperkalaemia by altering the transcellular gradient in patients with renal failure: effect of various therapeutic approaches. East African Medical Journal. 1997;74(8):503-9. Follow-up less than 6 months. [pmid: 9487416].
3099 Nguyen M, Chung EP. Telithromycin: the first ketolide antimicrobial. Clinical Therapeutics. 2005;27(8):1144-63. Not CKD treatment. [pmid: 16199242].
3100 Nguyen SA, Suranyi P, Ravenel JG, et al. Iso-osmolality versus low-osmolality iodinated contrast medium at intravenous contrast-enhanced CT: effect on kidney function. Radiology. 2008;248(1):97-105. Not RCT or controlled trial. [pmid: 18483232].
3101 Nguyen TC, Stegmayr B, Busund R, et al. Plasma therapies in thrombotic syndromes. International Journal of Artificial Organs. 2005;28(5):459-65. Follow-up less than 6 months. [pmid: 15883960].
3102 Niccoli L, Bellino S, Cantini F. Renal tolerability of three commonly employed non-steroidal anti-inflammatory drugs in elderly patients with osteoarthritis. Clinical & Experimental Rheumatology. 2002;20(2):201-7. Not early CKD. [pmid: 12051399].
3103 Nicholls MG, Arakawa K. Angiotensin-converting enzyme inhibitors in congestive heart failure. Journal of Cardiovascular Pharmacology. Suppl 3. 1987;9:S19-21. Not relevant to key questions. [pmid: 2442546].
3104 Nicholls SJ, Tuzcu EM, Hsu A, et al. Comparison of coronary atherosclerotic volume in patients with glomerular filtration rates < or = 60 versus > 60 ml/min/1.73 m(2): a meta-analysis of intravascular ultrasound studies. American Journal of Cardiology. 2007;99(6):813-6. Not relevant to key questions. [pmid: 17350372].
3105 Nichols GA, Arondekar B, Herman WH. Complications of dysglycemia and medical costs associated with nondiabetic hyperglycemia. American Journal of Managed Care. 2008;14(12):791-8. Not CKD treatment. [pmid: 19067496].
3106 Nicholson ML, Baker DM, Hopkinson BR, et al. Randomized controlled trial of the effect of mannitol on renal reperfusion injury during aortic aneurysm surgery. British Journal of Surgery. 1996;83(9):1230-3. Sample size less than 50 patients. [pmid: 8983613].
3107 Nieburg I, Kahan T. Cardiovascular risk factors are not treated to target in hypertensive patients in primary care. Blood Pressure. Jun. 2010;19(3):176-81. Not CKD treatment. [pmid: 20429693].
3108 Nielsen CB, Bech JN, Pedersen EB. Effects of prostacyclin on renal haemodynamics, renal tubular function and vasoactive hormones in healthy humans. A placebo-controlled dose-response study. British Journal of Clinical Pharmacology. 1997;44(5):471-6. Sample size less than 50 patients. [pmid: 9384464].
3109 Nielsen CB, Eiskjaer H, Pedersen EB. Enhanced renal production of cyclic GMP and reduced free water clearance during sodium nitroprusside infusion in healthy man. European Journal of Clinical Investigation. 1993;23(6):375-81. Sample size less than 50 patients. [pmid: 8393795].
3110 Nielsen CB, Pedersen EB. Effect of pinacidil on renal haemodynamics, tubular function and plasma levels of angiotensin II, aldosterone and atrial natriuretic peptide in healthy man. European Journal of Clinical Pharmacology. 1993;45(1):29-35. Sample size less than 50 patients. [pmid: 8405026].
3111 Nielsen CB, Pedersen EB. Abnormal distal tubular sodium reabsorption during dopamine infusion in patients with essential hypertension evaluated by the lithium clearance methods. Clinical Nephrology. 1997;47(5):304-9. Sample size less than 50 patients. [pmid: 9181277].
3112 Nielsen FS. Diabetic nephropathy in non-insulin dependent diabetes mellitus. Cardiovascular risk factors and antihypertensive treatment. Danish Medical Bulletin. 2000;47(4):249-70. Not relevant to key questions. [pmid: 11064829].
3113 Nielsen FS, Gaede P, Vedel P, et al. White coat hypertension in NIDDM patients with and without incipient and overt diabetic nephropathy. Diabetes Care. 1997;20(5):859-63. Follow-up less than 6 months. [pmid: 9135956].
3114 Nielsen FS, Rossing P, Gall MA, et al. Impact of lisinopril and atenolol on kidney function in hypertensive NIDDM subjects with diabetic nephropathy. Diabetes. 1994;43(9):1108-13. Sample size less than 50 patients. [pmid: 8070610].
3115 Nielsen FS, Rossing P, Gall MA, et al. Long-term effect of lisinopril and atenolol on kidney function in hypertensive NIDDM subjects with diabetic nephropathy. Diabetes. 1997;46(7):1182-8. Sample size less than 50 patients. [pmid: 9200654].
3116 Nielsen FS, Rossing P, Gall MA, et al. Lisinopril improves endothelial dysfunction in hypertensive NIDDM subjects with diabetic nephropathy. Scandinavian Journal of Clinical & Laboratory Investigation. 1997;57(5):427-34. Sample size less than 50 patients. [pmid: 9279969].
3117 Nielsen HK, Krusell L, Baelum J, et al. Renal effects of acute exposure to toluene. A controlled clinical trial. Acta Medica Scandinavica. 1985;218(3):317-21. Sample size less than 50 patients. [pmid: 3907288].
3118 Nielsen HK, Thomsen K, Eriksen EF, et al. The effects of high-dose glucocorticoid administration on serum bone gamma carboxyglutamic acid-containing protein, serum alkaline phosphatase and vitamin D metabolites in normal subjects. Bone & Mineral. 1988;4(1):105-13. Follow-up less than 6 months. [pmid: 3263890].
3119 Nielsen OM, Engell HC. Effects of maintaining normal plasma colloid osmotic pressure on renal function and excretion of sodium and water after major surgery. A randomized study. Danish Medical Bulletin. 1985;32(3):182-5. Sample size less than 50 patients. [pmid: 4017661].
3120 Nielsen S, Dollerup J, Nielsen B, et al. Losartan reduces albuminuria in patients with essential hypertension. An enalapril controlled 3 months study. Nephrology Dialysis Transplantation. Suppl 2. 1997;12:19-23. Sample size less than 50 patients.
3121 Nielsen S, Dollerup J, Nielsen B, et al. Combination of enalapril and low-dose thiazide reduces normoalbuminuria in essential hypertension. Journal of Hypertension. 1998;16(10):1539-44. Follow-up less than 6 months. [pmid: 9814627].
3122 Nielsen S, Hove KY, Dollerup J, et al. Losartan modifies glomerular hyperfiltration and insulin sensitivity in type 1 diabetes. Diabetes, Obesity & Metabolism. 2001;3(6):463-71. Sample size less than 50 patients.
3123 Nielsen S, Schmitz A, Bacher T, et al. Transcapillary escape rate and albuminuria in Type II diabetes. Effects of short-term treatment with low-molecular weight heparin. Diabetologia. 1999;42(1):60-7. Not RCT or controlled trial. [pmid: 10027580].
3124 Nielsen S, Schmitz O, Moller N, et al. Renal function and insulin sensitivity during simvastatin treatment in type 2 (non-insulin-dependent) diabetic patients with microalbuminuria. Diabetologia. 1993;36(10):1079-86. Sample size less than 50 patients. [pmid: 8243858].
3125 Nielsen SE, Sugaya T, Tarnow L, et al. Tubular and glomerular injury in diabetes and the impact of ACE inhibition. Diabetes Care. 2009;32(9):1684-8. Not RCT or controlled trial. [pmid: 19502542].
3126 Niemczyk S, Sikorska H, Wiecek A, et al. A super-agonist of growth hormone-releasing hormone causes rapid improvement of nutritional status in patients with chronic kidney disease. Kidney International. Mar. 2010;77(5):450-8. Not early CKD. [pmid: 20016461].
3127 Nigwekar SU, Kandula P, Hix JK, et al. Off-pump coronary artery bypass surgery and acute kidney injury: a meta-analysis of randomized and observational studies. American Journal of Kidney Diseases. 2009;54(3):413-23. Not RCT or controlled trial. [pmid: 19406542].
3128 Nigwekar SU, Navaneethan SD, Parikh CR, et al. Atrial natriuretic peptide for preventing and treating acute kidney injury. Cochrane Database of Systematic Reviews. 2009;(4):CD006028. Not RCT or controlled trial. [pmid: 19821351].
3129 Nigwekar SU, Navaneethan SD, Parikh CR, et al. Atrial natriuretic peptide for management of acute kidney injury: a systematic review and meta-analysis. Clinical Journal of The American Society of Nephrology: CJASN. 2009;4(2):261-72. Not CKD treatment. [pmid: 19073785].
3130 Nigwekar SU, Navaneethan SD, Parikh CR, et al. Atrial natriuretic peptide for management of acute kidney injury: a systematic review and meta-analysis. Clinical Journal of The American Society of Nephrology: CJASN. 2009;4(2):261-72. Not CKD treatment. [pmid: 19073785].
3131 Nikolov IG, Mozar A, Drueke TB, et al. Impact of disturbances of calcium and phosphate metabolism on vascular calcification and clinical outcomes in patients with chronic kidney disease. Blood Purification. 2009;27(4):350-9. Not CKD treatment. [pmid: 19295198].
3132 Nikolsky E, Mehran R, Dangas G, et al. Development and validation of a prognostic risk score for major bleeding in patients undergoing percutaneous coronary intervention via the femoral approach. European Heart Journal. 2007;28(16):1936-45. Follow-up less than 6 months. [pmid: 17575270].
3133 Nilsen L, Djoseland O, Rootwelt K, et al. Effects of short-term treatment with naproxen on kidney function in insulin-dependent diabetic patients with microalbuminuria. Scandinavian Journal of Clinical & Laboratory Investigation. 1991;51(7):591-7. Sample size less than 50 patients. [pmid: 1810019].
3134 Nilsen OG, Sellevold OF, Romfo OS, et al. Pharmacokinetics and effects on renal function following cilazapril and hydrochlorothiazide alone and in combination in healthy subjects and hypertensive patients. British Journal of Clinical Pharmacology. Suppl 2. 1989;27:323S-8S. Not relevant to key questions. [pmid: 2527546].
3135 Ninomiya T, Perkovic V, de Galan BE, et al. Albuminuria and kidney function independently predict cardiovascular and renal outcomes in diabetes. Journal of the American Society of Nephrology. 2009;20(8):1813-21. Not early CKD. [pmid: 19443635].
3136 Ninomiya T, Perkovic V, Gallagher M, et al. Lower blood pressure and risk of recurrent stroke in patients with chronic kidney disease: PROGRESS trial. Kidney International. 2008;73(8):963-70. Not CKD treatment. [pmid: 18272959].
3137 Ninomiya Y, Arakawa M. Renal effects of prostaglandin E1 in type 2 (non-insulin-dependent) diabetic patients with subclinical nephropathy. Diabetes Research. 1989;10(3):129-34. Follow-up less than 6 months. [pmid: 2680226].
3138 Nishimura M, Sasaki T, Ohishi A, et al. Angiotensin-converting enzyme inhibitors and probucol suppress the time-dependent increase in urinary Type IV collagen excretion of Type II diabetes mellitus patients with early diabetic nephropathy. Clinical Nephrology. 2001;56(2):96-103. Not early CKD. [pmid: 11522101].
3139 Nishizawa Y, Shoji T. Does paricalcitol reduce proteinuria in patients with chronic kidney disease?. Nature Clinical Practice Nephrology. 2006;2(7):352-3. Not RCT or controlled trial.
3140 Nissel R, Fischer DC, Puhlmann A, et al. Short-term growth hormone treatment and microcirculation: effects in patients with chronic kidney disease. Microvascular Research. 2009;78(2):246-52. Not RCT or controlled trial. [pmid: 19500600].
3141 Nitsch D, Felber Dietrich D, von Eckardstein A, et al. Prevalence of renal impairment and its association with cardiovascular risk factors in a general population: results of the Swiss SAPALDIA study. Nephrology Dialysis Transplantation. 2006;21(4):935-44. Not adult population.
3142 Nitsch D, Lawlor DA, Patel R, et al. The association of renal impairment with all-cause and cardiovascular disease mortality. Nephrology Dialysis Transplantation. Apr. 2010;25(4):1191-9. Not CKD treatment.
3143 Nix DE, Thomas JK, Symonds WT, et al. Assessment of the enzymuria resulting from gentamicin alone and combinations of gentamicin with various beta-lactam antibiotics. Annals of Pharmacotherapy. 1997;31(6):696-703. Not CKD treatment. [pmid: 9184707].
3144 Nohria A, Hasselblad V, Stebbins A, et al. Cardiorenal interactions: insights from the ESCAPE trial. Journal of the American College of Cardiology. 2008;51(13):1268-74. Not CKD treatment. [pmid: 18371557].
3145 Nolan CR, Califano JR, Butzin CA. Influence of calcium acetate or calcium citrate on intestinal aluminum absorption. Kidney International. 1990;38(5):937-41. Not CKD treatment. [pmid: 2266679].
3146 Nolasco F, Cameron JS, Heywood EF, et al. Adult-onset minimal change nephrotic syndrome: a long-term follow-up. Kidney International. 1986;29(6):1215-23. Follow-up less than 6 months. [pmid: 3747335].
3147 Nolin TD, Ouseph R, Himmelfarb J, et al. Multiple-dose pharmacokinetics and pharmacodynamics of N-acetylcysteine in patients with end-stage renal disease. Clinical Journal of The American Society of Nephrology: CJASN. Sep. 2010;5(9):1588-94. Follow-up less than 6 months. [pmid: 20538838].
3148 Noone M, Pomeroy L, Sage R, et al. Prospective study of amikacin versus netilmicin in the treatment of severe infection in hospitalized patients. American Journal of Medicine. 1989;86(6 Pt 2):809-13. Not CKD treatment. [pmid: 2658582].
3149 Noormohamed FH, Fuller GN, Lant AF. Effect of salt balance on the renal and hemodynamic actions of benazepril in normal men. Journal of Clinical Pharmacology. 1989;29(10):928-37. Sample size less than 50 patients. [pmid: 2687336].
3150 Noormohamed FH, Lant AF. Renal handling of lithium and the effects of mannitol and arginine vasopressin in man. Clinical Science. 1995;89(1):27-36. Sample size less than 50 patients. [pmid: 7671564].
3151 Nordal KP, Dahl E. Low dose calcitriol versus placebo in patients with predialysis chronic renal failure. Journal of Clinical Endocrinology & Metabolism. 1988;67(5):929-36. Sample size less than 50 patients. [pmid: 3182964].
3152 Nordenstrom E, Westerdahl J, Bergenfelz A. Effect on bone density of postoperative calcium and vitamin-D supplementation in patients with primary hyperparathyroidism: A retrospective study. Langenbecks Archives of Surgery. 2009;394(3):461-7. Not CKD treatment.
3153 Norgaard K, Feldt-Rasmussen B. Sodium retention and insulin treatment in insulin-dependent diabetes mellitus. Acta Diabetologica. 1994;31(1):19-25. Sample size less than 50 patients. [pmid: 8043892].
3154 Norgaard K, Jensen T, Christensen P, et al. A comparison of spirapril and isradipine in patients with diabetic nephropathy and hypertension. Blood Pressure. 1993;2(4):301-8. Sample size less than 50 patients. [pmid: 8173700].
3155 Norgaard K, Jensen T, Skott P, et al. Effects of insulin on renal haemodynamics and sodium handling in normal subjects. Scandinavian Journal of Clinical & Laboratory Investigation. 1991;51(4):367-76. Sample size less than 50 patients. [pmid: 1947721].
3156 Norlund L, Fex G, Lanke J, et al. Reference intervals for the glomerular filtration rate and cell-proliferation markers: serum cystatin C and serum beta 2-microglobulin/cystatin C-ratio. Scandinavian Journal of Clinical & Laboratory Investigation. 1997;57(6):463-70. Not RCT or controlled trial. [pmid: 9350064].
3157 Norman RW, Butler GJ, MacDiarmid SA, et al. 111Indium-oxine-labeled leukocytes and 67gallium-citrate as indicators of renal injury following extracorporeal shock wave lithotripsy. Journal of Urology. 1992;148(3 Pt 2):1022-4. Sample size less than 50 patients. [pmid: 1507320].
3158 Norris K, Vaughn C. The role of renin-angiotensin-aldosterone system inhibition in chronic kidney disease. Expert Review of Cardiovascular Therapy. 2003;1(1):51-63. Not early CKD. [pmid: 15030297].
3159 Norris KC, Greene T, Kopple J, et al. Baseline predictors of renal disease progression in the African American Study of Hypertension and Kidney Disease. Journal of the American Society of Nephrology. 2006;17(10):2928-36. Not RCT or controlled trial. [pmid: 16959828].
3160 North RA, Taylor RS, Schellenberg JC. Evaluation of a definition of pre-eclampsia. British Journal of Obstetrics & Gynaecology. 1999;106(8):767-73. Not RCT or controlled trial. [pmid: 10453825].
3161 Northridge DB, Jardine AG, Findlay IN, et al. Inhibition of the metabolism of atrial natriuretic factor causes diuresis and natriuresis in chronic heart failure. American Journal of Hypertension. 1990;3(9):682-7. Not CKD treatment. [pmid: 2145874].
3162 Nosrati SM, Khwaja S, el-Shahawy M, et al. Effect of angiotensin converting enzyme inhibition by perindopril on proteinuria of primary renal diseases. American Journal of Nephrology. 1997;17(6):511-7. Sample size less than 50 patients. [pmid: 9426847].
3163 Nossen JO, Jakobsen JA, Kjaersgaard P, et al. Elimination of the non-ionic X-ray contrast media iodixanol and iohexol in patients with severely impaired renal function. Scandinavian Journal of Clinical & Laboratory Investigation. 1995;55(4):341-50. Sample size less than 50 patients. [pmid: 7569737].
3164 Notghi A, Fiskerstrand CE, Burnet ME, et al. Effect of nifedipine and mefruside on renal function and platelet function in hypertensive patients. Current Medical Research & Opinion. 1987;10(7):441-9. Sample size less than 50 patients. [pmid: 3621989].
3165 Nouri-Majalan N, Ardakani EF, Forouzannia K, et al. Effects of allopurinol and vitamin E on renal function in patients with cardiac coronary artery bypass grafts. Vascular Health & Risk Management. 2009;5(2):489-94. Follow-up less than 6 months. [pmid: 19554089].
3166 Nowack R, Fliser D, Richter J, et al. Effects of angiotensin-converting enzyme inhibition on renal sodium handling after furosemide injection. Clinical Investigator. 1993;71(8):622-7. Sample size less than 50 patients. [pmid: 8219659].
3167 Nyberg G, Blohme G, Norden G. Impact of metabolic control in progression of clinical diabetic nephropathy. Diabetologia. 1987;30(2):82-6. Sample size less than 50 patients. [pmid: 3106126].
3168 Nyman U, Almen T, Aspelin P, et al. Contrast-medium-Induced nephropathy correlated to the ratio between dose in gram iodine and estimated GFR in ml/min. Acta Radiologica. 2005;46(8):830-42. Not RCT or controlled trial. [pmid: 16392608].
3169 Nyman U, Elmstahl B, Leander P, et al. Are gadolinium-based contrast media really safer than iodinated media for digital subtraction angiography in patients with azotemia?. Radiology. 2002;223(2):311-8. discussion 28-9. Not early CKD. [pmid: 11997530].
3170 Obasaju CK, Johnson SW, Rogatko A, et al. Evaluation of carboplatin pharmacokinetics in the absence and presence of paclitaxel. Clinical Cancer Research. 1996;2(3):549-52. Sample size less than 50 patients. [pmid: 9816202].
3171 Obata R, Bito H, Ohmura M, et al. The effects of prolonged low-flow sevoflurane anesthesia on renal and hepatic function. Anesthesia & Analgesia. 2000;91(5):1262-8. Not early CKD. [pmid: 11049919].
3172 Ochoa A, Pellizzon G, Addala S, et al. Abbreviated dosing of N-acetylcysteine prevents contrast-induced nephropathy after elective and urgent coronary angiography and intervention. Journal of Interventional Cardiology. 2004;17(3):159-65. Not early CKD. [pmid: 15209578].
3173 O'Connell DP, Ragsdale NV, Boyd DG, et al. Differential human renal tubular responses to dopamine type 1 receptor stimulation are determined by blood pressure status. Hypertension. 1997;29(1 Pt 1):115-22. Sample size less than 50 patients. [pmid: 9039090].
3174 O'Connell JE, Jardine AG, Davies DL, et al. Renal and hormonal effects of chronic inhibition of neutral endopeptidase (EC 3.4.24.11) in normal man. Clinical Science. 1993;85(1):19-26. Follow-up less than 6 months. [pmid: 8149689].
3175 O'Connor PJ, Spann SJ, Woolf SH. Care of adults with type 2 diabetes mellitus. A review of the evidence. Journal of Family Practice. 1998;47(5 Suppl):S13-22. Not RCT or controlled trial. [pmid: 9834750].
3176 Odabas AR, Cetinkaya R, Selcuk Y, et al. Effect of losartan treatment on the proteinuria in normotensive patients having proteinuria due to secondary amyloidosis. Upsala Journal of Medical Sciences. 2001;106(3):183-8. Sample size less than 50 patients. [pmid: 12166510].
3177 Oddoze C, Morange S, Portugal H, et al. Cystatin C is not more sensitive than creatinine for detecting early renal impairment in patients with diabetes. American Journal of Kidney Diseases. 2001;38(2):310-6. Not RCT or controlled trial. [pmid: 11479157].
3178 O'Doherty DP, Gertz BJ, Tindale W, et al. Effects of five daily 1 h infusions of alendronate in Paget's disease of bone. Journal of Bone & Mineral Research. 1992;7(1):81-7. Not CKD treatment. [pmid: 1549961].
3179 O'Doherty DP, McCloskey EV, Vasikaran S, et al. The effects of intravenous alendronate in Paget's disease of bone. Journal of Bone & Mineral Research. 1995;10(7):1094-100. Sample size less than 50 patients. [pmid: 7484285].
3180 O'Donnell MJ, Rowe BR, Lawson N, et al. Comparison of the effects of an angiotensin converting enzyme inhibitor and a calcium antagonist in hypertensive, macroproteinuric diabetic patients: a randomised double-blind study. Journal of Human Hypertension. 1993;7(4):333-9. Sample size less than 50 patients. [pmid: 8410924].
3181 O'Donnell MJ, Rowe BR, Lawson N, et al. Placebo-controlled trial of lisinopril in normotensive diabetic patients with incipient nephropathy. Journal of Human Hypertension. 1993;7(4):327-32. Sample size less than 50 patients. [pmid: 8410923].
3182 Odvina CV, Mason RP, Pak CYC. Prevention of thiazide-induced hypokalemia without magnesium depletion by potassium-magnesium-citrate. American Journal of Therapeutics. 2006;13(2):101-8. Not RCT or controlled trial. [pmid: 16645424].
3183 Ogawa O, Hayashi C, Nakaniwa T, et al. Arterial stiffness is associated with diabetic retinopathy in type 2 diabetes. Diabetes Research & Clinical Practice. 2005;68(2):162-6. Not relevant to key questions. [pmid: 15860245].
3184 Ogawa S, Mori T, Nako K, et al. Reduced albuminuria with sarpogrelate is accompanied by a decrease in monocyte chemoattractant protein-1 levels in type 2 diabetes. Clinical Journal of The American Society of Nephrology: CJASN. 2008;3(2):362-8. Not RCT or controlled trial. [pmid: 18235151].
3185 Ogawa S, Mori T, Nako K, et al. Combination therapy with renin-angiotensin system inhibitors and the calcium channel blocker azelnidipine decreases plasma inflammatory markers and urinary oxidative stress markers in patients with diabetic nephropathy. Hypertension Research - Clinical & Experimental. 2008;31(6):1147-55. Sample size less than 50 patients.
3186 Ogawa S, Mori T, Nako K, et al. Angiotensin II type 1 receptor blockers reduce urinary oxidative stress markers in hypertensive diabetic nephropathy. Hypertension. 2006;47(4):699-705. Follow-up less than 6 months. [pmid: 16505207].
3187 Ogawa S, Takeuchi K, Mori T, et al. Spironolactone further reduces urinary albumin excretion and plasma B-type natriuretic peptide levels in hypertensive type II diabetes treated with angiotensin-converting enzyme inhibitor. Clinical & Experimental Pharmacology & Physiology. 2006;33(5-6):477-9. Not RCT or controlled trial. [pmid: 16700881].
3188 Ogawa Y, Haneda T, Hirayama T, et al. Effects of lisinopril and nitrendipine on urinary albumin excretion and renal function in patients with mild to moderate essential hypertension. Hypertension Research - Clinical & Experimental. 2000;23(6):607-12. Sample size less than 50 patients.
3189 Ogihara T, Kaneko Y, Ikeda M, et al. Clinical evaluation of delapril in Japan. Report from the Japan Study Group on Delapril. American Journal of Hypertension. 1991;4(1 Pt 2):42S-5S. Not CKD treatment. [pmid: 2009147].
3190 O'Hanlon JJ, Beers H, Huss BK, et al. A comparison of the effect of intramuscular diclofenac, ketorolac or piroxicam on post-operative pain following laparoscopy. European Journal of Anaesthesiology. 1996;13(4):404-7. Not CKD treatment. [pmid: 8842665].
3191 O'Hara JF Jr., Hsu THS, Sprung J, et al. The effect of dopamine on renal function in solitary partial nephrectomy surgery. [Erratum appears in J Urol 2002 Mar;167(3):1408]. Journal of Urology. 2002;167(1):24-8. Not early CKD. [pmid: 11743267].
3192 O'Hare AM, Kaufman JS, Covinsky KE, et al. Current guidelines for using angiotensin-converting enzyme inhibitors and angiotensin II-receptor antagonists in chronic kidney disease: is the evidence base relevant to older adults?. Annals of Internal Medicine. 2009;150(10):717-24. Not RCT or controlled trial. [pmid: 19451579].
3193 O'Hare AM, Vittinghoff E, Hsia J, et al. Renal insufficiency and the risk of lower extremity peripheral arterial disease: results from the Heart and Estrogen/Progestin Replacement Study (HERS). Journal of the American Society of Nephrology. 2004;15(4):1046-51. Not CKD treatment. [pmid: 15034108].
3194 Ohkubo Y, Kishikawa H, Araki E, et al. Intensive insulin therapy prevents the progression of diabetic microvascular complications in Japanese patients with non-insulin-dependent diabetes mellitus: a randomized prospective 6-year study. Diabetes Research & Clinical Practice. 1995;28(2):103-17. Not CKD treatment. [pmid: 7587918].
3195 Ohls RK, Dai A. Long-acting erythropoietin: clinical studies and potential uses in neonates. Clinics in Perinatology. 2004;31(1):77-89. Sample size less than 50 patients. [pmid: 15183658].
3196 Ohmit SE, Flack JM, Peters RM, et al. Longitudinal Study of the National Kidney Foundation's (NKF) Kidney Early Evaluation Program (KEEP). Journal of the American Society of Nephrology. 2003;14(7 Suppl 2):S117-21. Not CKD treatment. [pmid: 12819315].
3197 Ohnmacht GA, Phan GQ, Mavroukakis SA, et al. A prospective, randomized, double-blind, placebo-controlled trial evaluating the effect of nystatin on the development of oral irritation in patients receiving high-dose intravenous interleukin-2. Journal of Immunotherapy. 2001;24(2):188-92. Not CKD treatment.
3198 Okamoto H, Nagatomo A, Kunitoh H, et al. Prediction of carboplatin clearance calculated by patient characteristics or 24-hour creatinine clearance: a comparison of the performance of three formulae. Cancer Chemotherapy & Pharmacology. 1998;42(4):307-12. Not CKD treatment. [pmid: 9744776].
3199 O'Keefe JH, Bybee KA, Lavie CJ. Intensive lipid intervention in the post-ENHANCE era. Mayo Clinic Proceedings. 2008;83(8):867-9. Not CKD treatment. [pmid: 18674470].
3200 Oksa A, Spustova V, Krivosikova Z, et al. Effects of long-term cholecalciferol supplementation on mineral metabolism and calciotropic hormones in chronic kidney disease. Kidney & Blood Pressure Research. 2008;31(5):322-9. Not CKD treatment. [pmid: 18802363].
3201 Olbricht CJ, Wanner C, Thiery J, et al. Simvastatin in nephrotic syndrome. Simvastatin in Nephrotic Syndrome Study Group. Kidney International - Supplement. 1999;(71):S113-6. Not CKD treatment. [pmid: 10412752].
3202 Oldemeyer JB, Biddle WP, Wurdeman RL, et al. Acetylcysteine in the prevention of contrast-induced nephropathy after coronary angiography. American Heart Journal. 2003;146(6):E23. Not RCT or controlled trial. [pmid: 14661012].
3203 Olencki T, Finke J, Tubbs R, et al. Immunomodulatory effects of interleukin-2 and interleukin-4 in patients with malignancy. Journal of Immunotherapy with Emphasis on Tumor Immunology. 1996;19(1):69-80. Not CKD treatment. [pmid: 8859726].
3204 Olgaard K, Lewin E. Reply to Dr S.C. Palmer and co-workers. Nephrology Dialysis Transplantation. 2008;23(8):2709-10. Not CKD treatment.
3205 Olgaard K, Storm T, van Wowern N, et al. Glucocorticoid-induced osteoporosis in the lumbar spine, forearm, and mandible of nephrotic patients: a double-blind study on the high-dose, long-term effects of prednisone versus deflazacort. Calcified Tissue International. 1992;50(6):490-7. Sample size less than 50 patients. [pmid: 1525702].
3206 Oliveira RB, Cancela ALE, Graciolli FG, et al. Early control of PTH and FGF23 in normophosphatemic CKD patients: a new target in CKD-MBD therapy?. Clinical Journal of The American Society of Nephrology: CJASN. Feb. 2010;5(2):286-91. Follow-up less than 6 months. [pmid: 19965540].
3207 Oliver WC Jr., Nuttall GA, Cherry KJ, et al. A comparison of fenoldopam with dopamine and sodium nitroprusside in patients undergoing cross-clamping of the abdominal aorta. Anesthesia & Analgesia. 2006;103(4):833-40. Not CKD treatment. [pmid: 17000789].
3208 Olsen KM, Rudis MI, Rebuck JA, et al. Effect of once-daily dosing vs. multiple daily dosing of tobramycin on enzyme markers of nephrotoxicity. Critical Care Medicine. 2004;32(8):1678-82. Not CKD treatment. [pmid: 15286543].
3209 Olsen ME, Thomsen T, Hassager C, et al. Hemodynamic and renal effects of indomethacin in losartan-treated hypertensive individuals. American Journal of Hypertension. 1999;12(2 Pt 1):209-16. Sample size less than 50 patients. [pmid: 10090350].
3210 Olsen MH, Wachtell K, Bella JN, et al. Albuminuria predicts cardiovascular events independently of left ventricular mass in hypertension: a LIFE substudy. Journal of Human Hypertension. 2004;18(6):453-9. Not CKD treatment. [pmid: 15085167].
3211 Olsen MH, Wachtell K, Borch-Johnsen K, et al. A blood pressure independent association between glomerular albumin leakage and electrocardiographic left ventricular hypertrophy. The LIFE Study. Losartan Intervention For Endpoint reduction. Journal of Human Hypertension. 2002;16(8):591-5. Not relevant to key questions. [pmid: 12149666].
3212 Olsen MH, Wachtell K, Ibsen H, et al. Reductions in albuminuria and in electrocardiographic left ventricular hypertrophy independently improve prognosis in hypertension: the LIFE study. Journal of Hypertension. 2006;24(4):775-81. Sample size less than 50 patients. [pmid: 16531808].
3213 Olsen NV, Fogh-Andersen N, Strandgaard S, et al. Endogenous versus exogenous lithium clearance for evaluation of dopamine-induced changes in renal tubular function. Clinical Science. 1996;90(6):511-5. Sample size less than 50 patients. [pmid: 8697722].
3214 Olsen NV, Jensen NG, Hansen JM, et al. Non-steroidal anti-inflammatory drugs and renal response to exercise: a comparison of indomethacin and nabumetone. Clinical Science. 1999;97(4):457-65. Sample size less than 50 patients. [pmid: 10491346].
3215 Olsen NV, Lang-Jensen T, Hansen JM, et al. Effects of acute beta-adrenoceptor blockade with metoprolol on the renal response to dopamine in normal humans. British Journal of Clinical Pharmacology. 1994;37(4):347-53. Not CKD treatment. [pmid: 8018456].
3216 Olsen NV, Olsen MH, Bonde J, et al. Dopamine natriuresis in salt-repleted, water-loaded humans: a dose-response study. British Journal of Clinical Pharmacology. 1997;43(5):509-20. Sample size less than 50 patients. [pmid: 9159566].
3217 Olsen NV, Olsen MH, Fogh-Andersen N, et al. Lithium clearance method and the renal response to low-dose dopamine in man: a randomized, controlled study. Clinical Science. 1993;84(2):237-42. Sample size less than 50 patients. [pmid: 8382588].
3218 Olthof MR, Brink EJ, Katan MB, et al. Choline supplemented as phosphatidylcholine decreases fasting and postmethionine-loading plasma homocysteine concentrations in healthy men. American Journal of Clinical Nutrition. 2005;82(1):111-7. Sample size less than 50 patients. [pmid: 16002808].
3219 Omar MA, Motala AA, Seedat MA, et al. Effects of captopril and prazosin on renal function in diabetes. South African Medical Journal. Suid-Afrikaanse Tydskrif Vir Geneeskunde. 1993;83(5):365. Not RCT or controlled trial. [pmid: 8211440].
3220 Omari BO, Nelson RJ, Robertson JM. Effect of right atrial appendectomy on the release of atrial natriuretic hormone. Journal of Thoracic & Cardiovascular Surgery. 1991;102(2):272-9. Not CKD treatment. [pmid: 1830916].
3221 O'Meara E, Clayton T, McEntegart MB, et al. Clinical correlates and consequences of anemia in a broad spectrum of patients with heart failure: results of the Candesartan in Heart Failure: Assessment of Reduction in Mortality and Morbidity (CHARM) Program. Circulation. 2006;113(7):986-94. Not RCT or controlled trial. [pmid: 16476847].
3222 Onat A, Hergenc G, Uyarel H, et al. Association between mild renal dysfunction and insulin resistance or metabolic syndrome in a random nondiabetic population sample. Kidney & Blood Pressure Research. 2007;30(2):88-96. Not relevant to key questions. [pmid: 17347575].
3223 Onbasili AO, Yeniceriglu Y, Agaoglu P, et al. Trimetazidine in the prevention of contrast-induced nephropathy after coronary procedures. Heart. 2007;93(6):698-702. Not CKD treatment. [pmid: 17065180].
3224 O'Neill JO, Taylor DO, Starling RC. Immunosuppression for cardiac transplantation--the past, present and future. Transplantation Proceedings. 2004;36(2 Suppl):309S-13S. Sample size less than 50 patients. [pmid: 15041359].
3225 Ong-Ajyooth L, Vareesangthip K, Khonputsa P, et al. Prevalence of chronic kidney disease in Thai adults: a national health survey. BMC Nephrology. 2009:10-35. Not CKD treatment.
3226 Onorati F, Presta P, Fuiano G, et al. A randomized trial of pulsatile perfusion using an intra-aortic balloon pump versus nonpulsatile perfusion on short-term changes in kidney function during cardiopulmonary bypass during myocardial reperfusion. American Journal of Kidney Diseases. 2007;50(2):229-38. Not relevant to key questions. [pmid: 17660024].
3227 Onuigbo MAC. Does concurrent renin-angiotensin-aldosterone blockade in (older) chronic kidney disease patients play a role in the acute renal failure epidemic in US hospitalized patients?--Three cases of severe acute renal failure encountered in a northwestern Wisconsin Nephrology practice. Hemodialysis International. Suppl 1. 2009;13:S24-9. Not CKD treatment. [pmid: 19775421].
3228 Onuigbo MAC. Reno-prevention vs. reno-protection: a critical re-appraisal of the evidence-base from the large RAAS blockade trials after ONTARGET--a call for more circumspection. Qjm. 2009;102(3):155-67. Not CKD treatment. [pmid: 19098074].
3229 Onwude JL, Lilford RJ, Hjartardottir H, et al. A randomised double blind placebo controlled trial of fish oil in high risk pregnancy. British Journal of Obstetrics & Gynaecology. 1995;102(2):95-100. Not CKD treatment. [pmid: 7756226].
3230 Ooi JSM, Ramzisham ARM, Zamrin MD. Is 6% hydroxyethyl starch 130/0.4 safe in coronary artery bypass graft surgery?. Asian Cardiovascular & Thoracic Annals. 2009;17(4):368-72. Not CKD treatment. [pmid: 19713332].
3231 Oosterlinck W, Philp NH, Charig C, et al. A double-blind single dose comparison of intramuscular ketorolac tromethamine and pethidine in the treatment of renal colic. Journal of Clinical Pharmacology. 1990;30(4):336-41. Not CKD treatment. [pmid: 2341581].
3232 Ordonez JD, Hiatt RA, Killebrew EJ, et al. The increased risk of coronary heart disease associated with nephrotic syndrome. Kidney International. 1993;44(3):638-42. Not RCT or controlled trial. [pmid: 8231039].
3233 O'Reilly PH, Brooman PJ, Martin PJ, et al. Accuracy and reproducibility of a new contrast clearance method for the determination of glomerular filtration rate. British Medical Journal Clinical Research Ed. 1986;293(6541):234-6. Follow-up less than 6 months. [pmid: 3089467].
3234 Oriana S, Bohm S, Spatti G, et al. A preliminary clinical experience with reduced glutathione as protector against cisplatin-toxicity. Tumori. 1987;73(4):337-40. Sample size less than 50 patients. [pmid: 3660470].
3235 O'Riordan E, Foley RN. Effects of anaemia on cardiovascular status. Nephrology Dialysis Transplantation. Suppl 3. 2000;15:19-22. Not early CKD.
3236 Orita Y, Okada M, Harada S, et al. Skim soy protein enhances GFR as much as beefsteak protein in healthy human subjects. Clinical & Experimental Nephrology. 2004;8(2):103-8. Not CKD treatment. [pmid: 15235926].
3237 Ortapamuk H, Naldoken S, Tekdogan UY, et al. Differential renal function in the prediction of recovery in adult obstructed kidneys after pyeloplasty. Annals of Nuclear Medicine. 2003;17(8):663-8. Not CKD treatment. [pmid: 14971608].
3238 Orth SR, Hallan SI. Smoking: a risk factor for progression of chronic kidney disease and for cardiovascular morbidity and mortality in renal patients--absence of evidence or evidence of absence?. Clinical Journal of The American Society of Nephrology: CJASN. 2008;3(1):226-36. Not RCT or controlled trial. [pmid: 18003763].
3239 Ortiz A, Oliveira JP, Wanner C, et al. Recommendations and guidelines for the diagnosis and treatment of Fabry nephropathy in adults. Nature Clinical Practice Nephrology. 2008;4(6):327-36. Not CKD treatment.
3240 Ortiz MA, De Prado A, Donate T, et al. Angiotensin-converting enzyme polymorphism gene and evolution of nephropathy to end-stage renal disease. Nephrology. 2003;8(4):171-6. Sample size less than 50 patients. [pmid: 15012717].
3241 Os I, Gudmundsdottir H, Kjeldsen SE, et al. Treatment of isolated systolic hypertension in diabetes mellitus type 2. Diabetes, Obesity & Metabolism. 2006;8(4):381-7. Not RCT or controlled trial.
3242 Osei SY, Price DA, Laffel LM, et al. Effect of angiotensin II antagonist eprosartan on hyperglycemia-induced activation of intrarenal renin-angiotensin system in healthy humans. Hypertension. 2000;36(1):122-6. Not early CKD. [pmid: 10904023].
3243 Oster HS, Hoffman M, Prutchi-Sagiv S, et al. Erythropoietin in clinical practice: current use, effect on survival, and future directions. Israel Medical Association Journal: Imaj. 2006;8(10):703-6. Not CKD treatment.
3244 Ostermann M, Alvarez G, Sharpe MD, et al. Frusemide administration in critically ill patients by continuous compared to bolus therapy. Nephron. 2007;107(2):c70-6. Sample size less than 50 patients. [pmid: 17890871].
3245 Osterziel KJ, Dietz R, Harder K, et al. Comparison of captopril with enalapril in the treatment of heart failure: influence on hemodynamics and measures of renal function. Cardiovascular Drugs & Therapy. 1992;6(2):173-80. Sample size less than 50 patients. [pmid: 1390330].
3246 Osterziel KJ, Dietz R, Lemmer B. Circadian rhythm of blood pressure in congestive heart failure and effects of ACE inhibitors. Chronobiology International. 1991;8(5):420-31. Sample size less than 50 patients. [pmid: 1818790].
3247 O'Toole L, Stewart M, Padfield P, et al. Effect of the insertion/deletion polymorphism of the angiotensin-converting enzyme gene on response to angiotensin-converting enzyme inhibitors in patients with heart failure. Journal of Cardiovascular Pharmacology. 1998;32(6):988-94. Sample size less than 50 patients. [pmid: 9869506].
3248 Ott C, Ritt M, Titze SI, et al. Rosuvastatin does not affect intrarenal hemodynamics in patients with hypercholesterolemia. Journal of Nephrology. 2009;22(5):675-81. Sample size less than 50 patients. [pmid: 19810001].
3249 Ottesen LH, Aagaard NK, Kiszka-Kanowitz M, et al. Effects of a long-acting formulation of octreotide on renal function and renal sodium handling in cirrhotic patients with portal hypertension: a randomized, double-blind, controlled trial. Hepatology. 2001;34(3):471-7. Not early CKD. [pmid: 11526531].
3250 Oudemans-van Straaten HM. Strategies to prevent contrast nephropathy. Minerva Cardioangiologica. 2005;53(5):445-63. Sample size less than 50 patients. [pmid: 16179886].
3251 Oudit GY, Liu GC, Zhong J, et al. Human recombinant ACE2 reduces the progression of diabetic nephropathy. Diabetes. 2010;59(2):529-38. Not human studies. [pmid: 19934006].
3252 Ovartlarnporn M, Jongjaroenprasert W. Advancing age and renal impairment as important predisposing factors of gatifloxacin-induced hyperglycemia in non-diabetes patients. Journal of the Medical Association of Thailand. 2007;90(3):569-73. Not relevant to key questions. [pmid: 17427537].
3253 Overbosch D, van Gulpen C, Mattie H. Renal clearance of temocillin in volunteers. Drugs. Suppl 5. 1985;29:128-34. Sample size less than 50 patients. [pmid: 4029016].
3254 Overman GP, Teter CJ, Guthrie SK. Acamprosate for the adjunctive treatment of alcohol dependence. Annals of Pharmacotherapy. 2003;37(7-8):1090-9. Not CKD treatment. [pmid: 12841823].
3255 Owada A, Nakao M, Koike J, et al. Effects of oral adsorbent AST-120 on the progression of chronic renal failure: a randomized controlled study. Kidney International - Supplement. 1997;63:S188-90. Sample size less than 50 patients. [pmid: 9407455].
3256 Owada A, Suda S, Hata T. Effect of long-term administration of prostaglandin I(2) in incipient diabetic nephropathy. Nephron. 2002;92(4):788-96. Sample size less than 50 patients. [pmid: 12399622].
3257 Owada A, Suda S, Hata T. Antiproteinuric effect of niceritrol, a nicotinic acid derivative, in chronic renal disease with hyperlipidemia: a randomized trial. American Journal of Medicine. 2003;114(5):347-53. Sample size less than 50 patients. [pmid: 12714122].
3258 Owan TE, Chen HH, Frantz RP, et al. The effects of nesiritide on renal function and diuretic responsiveness in acutely decompensated heart failure patients with renal dysfunction. Journal of Cardiac Failure. 2008;14(4):267-75. Not CKD treatment. [pmid: 18474338].
3259 Ozcan EE, Guneri S, Akdeniz B, et al. Sodium bicarbonate, N-acetylcysteine, and saline for prevention of radiocontrast-induced nephropathy. A comparison of 3 regimens for protecting contrast-induced nephropathy in patients undergoing coronary procedures. A single-center prospective controlled trial. American Heart Journal. 2007;154(3):539-44. Follow-up less than 6 months. [pmid: 17719303].
3260 Ozcan S, Yilmaz E, Buyukkocak U, et al. Comparison of three analgesics for extracorporeal shock wave lithotripsy. Scandinavian Journal of Urology & Nephrology. 2002;36(4):281-5. Not CKD treatment. [pmid: 12201921].
3261 Ozdal OL, Ozden C, Benli K, et al. Effect of short-term finasteride therapy on peroperative bleeding in patients who were candidates for transurethral resection of the prostate (TUR-P): a randomized controlled study. Prostate Cancer & Prostatic Diseases. 2005;8(3):215-8. Not RCT or controlled trial. [pmid: 15999118].
3262 Ozdener F, Ozdemir V. Fasidotril Eli Lilly. Current Opinion in Investigational Drugs. 2003;4(9):1113-9. Not CKD treatment. [pmid: 14582457].
3263 Ozhan H, Erden I, Ordu S, et al. Efficacy of short-term high-dose atorvastatin for prevention of contrast-induced nephropathy in patients undergoing coronary angiography. Angiology. Oct. 2010;61(7):711-4. Not CKD treatment. [pmid: 20395226].
3264 Pacher R, Stanek B, Globits S, et al. Effects of two different enalapril dosages on clinical, haemodynamic and neurohumoral response of patients with severe congestive heart failure. European Heart Journal. 1996;17(8):1223-32. Not early CKD. [pmid: 8869864].
3265 Pacher R, Stanek B, Hulsmann M, et al. Effect of prostaglandin E1 infusion in severe chronic heart failure. Prostaglandins. 1997;53(4):221-35. Not CKD treatment. [pmid: 9167210].
3266 Packard DP, Milton JE, Shuler LA, et al. Implications of chronic kidney disease for dietary treatment in cardiovascular disease. Journal of Renal Nutrition. 2006;16(3):259-68. Follow-up less than 6 months. [pmid: 16825032].
3267 Padillo FJ, Briceno J, Cruz A, et al. Randomized clinical trial of the effect of intravenous fluid administration on hormonal and renal dysfunction in patients with obstructive jaundice undergoing endoscopic drainage. British Journal of Surgery. 2005;92(1):39-43. Sample size less than 50 patients. [pmid: 15521079].
3268 Pageaux GP, Rostaing L, Calmus Y, et al. Mycophenolate mofetil in combination with reduction of calcineurin inhibitors for chronic renal dysfunction after liver transplantation. Liver Transplantation. 2006;12(12):1755-60. Sample size less than 50 patients. [pmid: 17133564].
3269 Pagliaro LC, Sharma P. Review of metastatic bladder cancer. Minerva Urologica e Nefrologica. 2006;58(1):53-71. Not relevant to key questions. [pmid: 16760884].
3270 Pain JA, Cahill CJ, Gilbert JM, et al. Prevention of postoperative renal dysfunction in patients with obstructive jaundice: a multicentre study of bile salts and lactulose. British Journal of Surgery. 1991;78(4):467-9. Not CKD treatment. [pmid: 2032107].
3271 Pais RC, Abdel-Mageed A, Ghim TT, et al. Phase I study of recombinant human interleukin-2 for pediatric malignancies: feasibility of outpatient therapy. A Pediatric Oncology Group Study. Journal of Immunotherapy. 1992;12(2):138-46. Not adult population. [pmid: 1504055].
3272 Palazzuoli A, Gallotta M, Iovine F, et al. Anaemia in heart failure: a common interaction with renal insufficiency called the cardio-renal anaemia syndrome. International Journal of Clinical Practice. 2008;62(2):281-6. Not CKD treatment. [pmid: 18081797].
3273 Palazzuoli A, Silverberg D, Iovine F, et al. Erythropoietin improves anemia exercise tolerance and renal function and reduces B-type natriuretic peptide and hospitalization in patients with heart failure and anemia. American Heart Journal. 2006;152(6):1096.e9-15. Not CKD treatment. [pmid: 17161060].
3274 Palla R, Marchitiello M, Tuoni M, et al. Enzymuria in aminoglycoside-induced kidney damage. Comparative study of gentamicin, amikacin, sisomicin and netilmicin. International Journal of Clinical Pharmacology Research. 1985;5(5):351-5. Sample size less than 50 patients. [pmid: 2866167].
3275 Palla R, Parrini M, Panichi V, et al. Acute effects of calcitonin gene related peptide on renal haemodynamics and renin and angiotensin II secretion in patients with renal disease. International Journal of Tissue Reactions. 1995;17(1):43-9. Sample size less than 50 patients. [pmid: 7499063].
3276 Palmas W, Moran A, Pickering T, et al. Ambulatory pulse pressure and progression of urinary albumin excretion in older patients with type 2 diabetes mellitus. Hypertension. 2006;48(2):301-8. Sample size less than 50 patients. [pmid: 16818800].
3277 Palmer AJ, Annemans L, Roze S, et al. An economic evaluation of the Irbesartan in Diabetic Nephropathy Trial (IDNT) in a UK setting. Journal of Human Hypertension. 2004;18(10):733-8. Not CKD treatment. [pmid: 15116142].
3278 Palmer AJ, Valentine WJ, Chen R, et al. A health economic analysis of screening and optimal treatment of nephropathy in patients with type 2 diabetes and hypertension in the USA. Nephrology Dialysis Transplantation. 2008;23(4):1216-23. Sample size less than 50 patients.
3279 Palmer AJ, Valentine WJ, Ray JA. Irbesartan treatment of patients with type 2 diabetes, hypertension and renal disease: a UK health economics analysis. International Journal of Clinical Practice. 2007;61(10):1626-33. Not RCT or controlled trial. [pmid: 17877649].
3280 Palmer SC, McGregor DO, Macaskill P, et al. Meta-analysis: vitamin D compounds in chronic kidney disease. Annals of Internal Medicine. 2007;147(12):840-53. Not relevant to key questions. [pmid: 18087055].
3281 Palmer SC, Nand K, Strippoli GF. Interventions for minimal change disease in adults with nephrotic syndrome. Cochrane Database of Systematic Reviews. 2008;(1):CD001537. Not relevant to key questions. [pmid: 18253993].
3282 Palmer SC, Navaneethan SD, Craig JC, et al. Meta-analysis: erythropoiesis-stimulating agents in patients with chronic kidney disease. Annals of Internal Medicine. Jul. 6. 2010;153(1):23-33. Not CKD treatment. [pmid: 20439566].
3283 Palumbo A, Gay F. How to treat elderly patients with multiple myeloma: combination of therapy or sequencing. Hematology. 2009:566-77. Not RCT or controlled trial.
3284 Pan Y, Guo LL, Jin HM. Low-protein diet for diabetic nephropathy: a meta-analysis of randomized controlled trials. American Journal of Clinical Nutrition. 2008;88(3):660-6. Not CKD treatment. [pmid: 18779281].
3285 Panetta CJ, Herzog CA, Henry TD. Acute coronary syndromes in patients with renal disease: what are the issues?. Current Cardiology Reports. 2006;8(4):296-300. Sample size less than 50 patients. [pmid: 16822365].
3286 Paniagua JA, Lopez-Miranda J, Perez-Martinez P, et al. Oxidized-LDL levels are changed during short-term serum glucose variations and lowered with statin treatment in early Type 2 diabetes: a study of endothelial function and microalbuminuria. Diabetic Medicine. 2005;22(12):1647-56. Sample size less than 50 patients. [pmid: 16401307].
3287 Paniagua R, Claure R, Amato D, et al. Effects of oral administration of zinc and diiodohydroxyquinolein on plasma zinc levels of uremic patients. Nephron. 1995;69(2):147-50. Sample size less than 50 patients. [pmid: 7723896].
3288 Panichi V, Andreini B, De Pietro S, et al. Calcitriol oral therapy for the prevention of secondary hyperparathyroidism in patients with predialytic renal failure. Clinical Nephrology. 1998;49(4):245-50. Sample size less than 50 patients. [pmid: 9582556].
3289 Panichi V, Paoletti S, Mantuano E, et al. In vivo and in vitro effects of simvastatin on inflammatory markers in pre-dialysis patients. Nephrology Dialysis Transplantation. 2006;21(2):337-44. Not CKD treatment.
3290 Pannu N, Manns B, Lee H, et al. Systematic review of the impact of N-acetylcysteine on contrast nephropathy. Kidney International. 2004;65(4):1366-74. Not relevant to key questions. [pmid: 15086476].
3291 Pannu N, Tonelli M. Strategies to reduce the risk of contrast nephropathy: an evidence-based approach. Current Opinion in Nephrology & Hypertension. 2006;15(3):285-90. Follow-up less than 6 months. [pmid: 16609296].
3292 Pannu N, Wiebe N, Tonelli M, et al. Prophylaxis strategies for contrast-induced nephropathy. JAMA. 2006;295(23):2765-79. Not relevant to key questions. [pmid: 16788132].
3293 Panos GZ, Betsi GI, Falagas ME. Systematic review: are antibiotics detrimental or beneficial for the treatment of patients with Escherichia coli O157:H7 infection?. Alimentary Pharmacology & Therapeutics. 2006;24(5):731-42. Not RCT or controlled trial. [pmid: 16918877].
3294 Pantaleo P, Marra F, Vizzutti F, et al. Effects of dietary supplementation with arachidonic acid on platelet and renal function in patients with cirrhosis. Clinical Science. 2004;106(1):27-34. Not CKD treatment. [pmid: 12877651].
3295 Paoletti E, Cannella G. Update on erythropoietin treatment: should hemoglobin be normalized in patients with chronic kidney disease?. Journal of the American Society of Nephrology. 2006;17(4 Suppl 2):S74-7. Not relevant to key questions. [pmid: 16565252].
3296 Papaioannou GI, Seip RL, Grey NJ, et al. Brachial artery reactivity in asymptomatic patients with type 2 diabetes mellitus and microalbuminuria (from the Detection of Ischemia in Asymptomatic Diabetics-brachial artery reactivity study). American Journal of Cardiology. 2004;94(3):294-9. Not CKD treatment. [pmid: 15276091].
3297 Papavasiliou EC, Gouva C, Siamopoulos KC, et al. Erythrocyte PAF-acetylhydrolase activity in various stages of chronic kidney disease: effect of long-term therapy with erythropoietin. Kidney International. 2005;68(1):246-55. Sample size less than 50 patients. [pmid: 15954914].
3298 Papavasiliou EC, Gouva C, Siamopoulos KC, et al. PAF-acetylhydrolase activity in plasma of patients with chronic kidney disease. Effect of long-term therapy with erythropoietin. Nephrology Dialysis Transplantation. 2006;21(5):1270-7. Not RCT or controlled trial.
3299 Pappas KD, Gouva CD, Katopodis KP, et al. Correction of anemia with erythropoietin in chronic kidney disease (stage 3 or 4): effects on cardiac performance. Cardiovascular Drugs & Therapy. 2008;22(1):37-44. Not RCT or controlled trial. [pmid: 18095148].
3300 Paran H, Neufeld D, Mayo A, et al. Preliminary report of a prospective randomized study of octreotide in the treatment of severe acute pancreatitis. Journal of the American College of Surgeons. 1995;181(2):121-4. Not CKD treatment. [pmid: 7627383].
3301 Paredes J, Hong WK, Felder TB, et al. Prospective randomized trial of high-dose cisplatin and fluorouracil infusion with or without sodium diethyldithiocarbamate in recurrent and/or metastatic squamous cell carcinoma of the head and neck. Journal of Clinical Oncology. 1988;6(6):955-62. Not CKD treatment. [pmid: 2836565].
3302 Parfrey P. Anaemia in chronic renal disease: lessons learned since Seville 1994. Nephrology Dialysis Transplantation. Suppl 7. 2001;16:41-5. Not RCT or controlled trial.
3303 Parfrey PS, Harnett JD. The management of cardiac disease in chronic uremia. Current Opinion in Nephrology & Hypertension. 1994;3(2):145-54. Not CKD treatment. [pmid: 7842264].
3304 Parikh CR, McSweeney P, Schrier RW. Acute renal failure independently predicts mortality after myeloablative allogeneic hematopoietic cell transplant. Kidney International. 2005;67(5):1999-2005. Not CKD treatment. [pmid: 15840050].
3305 Parissis JT, Rafouli-Stergiou P, Paraskevaidis I, et al. Levosimendan: from basic science to clinical practice. Heart Failure Reviews. 2009;14(4):265-75. Not CKD treatment. [pmid: 19101796].
3306 Park GD, Goldberg MJ, Spector R, et al. The effects of activated charcoal on digoxin and digitoxin clearance. Drug Intelligence & Clinical Pharmacy. 1985;19(12):937-41. Sample size less than 50 patients. [pmid: 4085353].
3307 Park JS, Kim SB. C-reactive protein as a cardiovascular risk factor and its therapeutic implications in end-stage renal disease patients. Nephrology. 2003;8(Suppl):S40-4. Not CKD treatment. [pmid: 15012690].
3308 Park M, Coca SG, Nigwekar SU, et al. Prevention and treatment of acute kidney injury in patients undergoing cardiac surgery: a systematic review. American Journal of Nephrology. 2010;31(5):408-18. Not CKD treatment. [pmid: 20375494].
3309 Parkash R, Stevenson WG, Epstein LM, et al. Predicting early mortality after implantable defibrillator implantation: a clinical risk score for optimal patient selection. American Heart Journal. 2006;151(2):397-403. Not RCT or controlled trial. [pmid: 16442906].
3310 Parker MR, Willatts SM. A pilot study to investigate the effects of an infusion of aminophylline on renal function following major abdominal surgery. Anaesthesia. 2001;56(7):670-5. Not RCT or controlled trial. [pmid: 11437769].
3311 Parks RW, Diamond T, McCrory DC, et al. Prospective study of postoperative renal function in obstructive jaundice and the effect of perioperative dopamine. British Journal of Surgery. 1994;81(3):437-9. Not CKD treatment. [pmid: 8173923].
3312 Parrinello G, Paterna S, Torres D, et al. One-year renal and cardiac effects of bisoprolol versus losartan in recently diagnosed hypertensive patients: a randomized, double-blind study. Clinical Drug Investigation. 2009;29(9):591-600. Not CKD treatment. [pmid: 19663521].
3313 Parsons DS, Harris DC. A review of quality of life in chronic renal failure. Pharmacoeconomics. 1997;12(2 Pt 1):140-60. Not RCT or controlled trial. [pmid: 10169667].
3314 Parvanova A, Chiurchiu C, Ruggenenti P, et al. Inhibition of the renin-angiotensin system and cardio-renal protection: focus on losartan and angiotensin receptor blockade. Expert Opinion on Pharmacotherapy. 2005;6(11):1931-42. Not relevant to key questions. [pmid: 16144512].
3315 Parvez Z, Ramamurthy S, Patel NB, et al. Enzyme markers of contrast media-induced renal failure. Investigative Radiology. Suppl 1. 1990;25:S133-4. Sample size less than 50 patients. [pmid: 2283232].
3316 Parving HH. Protein restriction and renal failure in diabetes mellitus. New England Journal of Medicine. 1991;324(24):1743-4. Not RCT or controlled trial. [pmid: 2034255].
3317 Parving HH. Is antihypertensive treatment the same for NIDDM and IDDM patients?. Diabetes Research & Clinical Practice. 1998;39(Suppl):S43-7. Not RCT or controlled trial. [pmid: 9649959].
3318 Parving HH. Benefits and cost of antihypertensive treatment in incipient and overt diabetic nephropathy. Journal of Hypertension - Supplement. 1998;16(1):S99-101. Not RCT or controlled trial.
3319 Parving HH. Diabetic hypertensive patients. Is this a group in need of particular care and attention?. Diabetes Care. Suppl 2. 1999;22:B76-9. Not RCT or controlled trial. [pmid: 10097904].
3320 Parving HH. Blockade of the renin-angiotensin-aldosterone system and renal protection in diabetes mellitus. Journal of the Renin-Angiotensin-Aldosterone System. 2000;1(1):30-1. Not RCT or controlled trial. [pmid: 11967794].
3321 Parving HH, Hommel E, Damkjaer Nielsen M, et al. Effect of captopril on blood pressure and kidney function in normotensive insulin dependent diabetics with nephropathy. BMJ. 1989;299(6698):533-6. Sample size less than 50 patients. [pmid: 2507061].
3322 Parving HH, Hommel E, Jensen BR, et al. Long-term beneficial effect of ACE inhibition on diabetic nephropathy in normotensive type 1 diabetic patients. Kidney International. 2001;60(1):228-34. Sample size less than 50 patients. [pmid: 11422755].
3323 Parving HH, Hommel E, Smidt UM. Protection of kidney function and decrease in albuminuria by captopril in insulin dependent diabetics with nephropathy. BMJ. 1988;297(6656):1086-91. Sample size less than 50 patients. [pmid: 3143437].
3324 Parving HH, Mogensen CE, Thomas MC, et al. Poor prognosis in proteinuric type 2 diabetic patients with retinopathy: insights from the RENAAL study. Qjm. 2005;98(2):119-26. Not early CKD. [pmid: 15655096].
3325 Parving HH, Rossing P. The use of antihypertensive agents in prevention and treatment of diabetic nephropathy. Current Opinion in Nephrology & Hypertension. 1994;3(3):292-300. Not RCT or controlled trial. [pmid: 7922255].
3326 Parving HH, Tarnow L, Nielsen FS, et al. Cyclosporine nephrotoxicity in type 1 diabetic patients. A 7-year follow-up study. Diabetes Care. 1999;22(3):478-83. Sample size less than 50 patients. [pmid: 10097932].
3327 Parving HH, Tarnow L, Rossing P. Renal protection in diabetes: an emerging role for calcium antagonists. Journal of Hypertension - Supplement. 1996;14(4):S21-5. Not RCT or controlled trial.
3328 Parving HH, Tarnow L, Rossing P. Renal protection in diabetes--an emerging role for calcium antagonists. Cardiology. Suppl 3. 1997;88:56-62. Not RCT or controlled trial. [pmid: 9397296].
3329 Parving HH, Andersen S, Jacobsen P, et al. Angiotensin receptor blockers in diabetic nephropathy: renal and cardiovascular end points. Seminars in Nephrology. 2004;24(2):147-57. Not CKD treatment. [pmid: 15017527].
3330 Parving HH, Brenner BM, McMurray JJV, et al. Aliskiren Trial in Type 2 Diabetes Using Cardio-Renal Endpoints (ALTITUDE): rationale and study design. Nephrology Dialysis Transplantation. 2009;24(5):1663-71. Not CKD treatment.
3331 Parving HH, de Zeeuw D, Cooper ME, et al. ACE gene polymorphism and losartan treatment in type 2 diabetic patients with nephropathy. Journal of the American Society of Nephrology. 2008;19(4):771-9. Not CKD treatment. [pmid: 18199798].
3332 Parving HH, Persson F, Lewis JB, et al. Aliskiren combined with losartan in type 2 diabetes and nephropathy. [Reprint in Ugeskr Laeger. 2009 Mar 9;171(11):881-4; PMID:19291865]. New England Journal of Medicine. 2008;358(23):2433-46. Follow-up less than 6 months. [pmid: 18525041].
3333 Pasquali S, Cagnoli L, Rovinetti C, et al. Plasma exchange therapy in rapidly progressive renal failure due to multiple myeloma. International Journal of Artificial Organs. Suppl 2. 1985;8:27-30. Sample size less than 50 patients. [pmid: 4055108].
3334 Passa P, Chatellier G. The DIAB-HYCAR Study. Diabetologia. 1996;39(12):1662-7. Not RCT or controlled trial. [pmid: 9081852].
3335 Passa P, Leblanc H, Chevrel A, et al. Discontinuing ACE inhibition in patients with diabetic nephropathy. BMJ. 1991;302(6777):658. Not RCT or controlled trial. [pmid: 2012888].
3336 Passariello N, Sepe J, Marrazzo G, et al. Effect of aldose reductase inhibitor (tolrestat) on urinary albumin excretion rate and glomerular filtration rate in IDDM subjects with nephropathy. Diabetes Care. 1993;16(5):789-95. Sample size less than 50 patients. [pmid: 8495620].
3337 Passfall J, Pai J, Spies KP, et al. Effect of water and bicarbonate loading in patients with chronic renal failure. Clinical Nephrology. 1997;47(2):92-8. Sample size less than 50 patients. [pmid: 9049456].
3338 Passmore AP, Copeland S, Johnston GD. The effects of ibuprofen and indomethacin on renal function in the presence and absence of frusemide in healthy volunteers on a restricted sodium diet. British Journal of Clinical Pharmacology. 1990;29(3):311-9. Not CKD treatment. [pmid: 2178660].
3339 Passmore AP, Kondowe GB, Johnston GD. Renal and cardiovascular effects of caffeine: a dose-response study. Clinical Science. 1987;72(6):749-56. Sample size less than 50 patients. [pmid: 3297472].
3340 Pasternack A, Vanttinen T, Solakivi T, et al. Normalization of lipoprotein lipase and hepatic lipase by gemfibrozil results in correction of lipoprotein abnormalities in chronic renal failure. Clinical Nephrology. 1987;27(4):163-8. Sample size less than 50 patients. [pmid: 3555908].
3341 Pastors JG, Franz MJ, Warshaw H, et al. How effective is medical nutrition therapy in diabetes care?. Journal of the American Dietetic Association. 2003;103(7):827-31. Not RCT or controlled trial. [pmid: 12830019].
3342 Patel A. Acute renal failure from contrast medium: … and remember simple and cheap measures. BMJ. 2006;333(7569):653-4. Not RCT or controlled trial. [pmid: 16990331].
3343 Patel UD, Greiner MA, Fonarow GC, et al. Associations between worsening renal function and 30-day outcomes among Medicare beneficiaries hospitalized with heart failure. American Heart Journal. Jul. 2010;160(1):132-8.e1. Not CKD treatment. [pmid: 20598983].
3344 Patel Z, Bhattacharjee LI, Shah BV. The role of dietary protein restriction in Indian patients with chronic renal failure. Journal of the Association of Physicians of India. 2000;48(11):1078-81. Sample size less than 50 patients. [pmid: 11310385].
3345 Paterna S, Parrinello G, Scaglione R, et al. Effect of long-term losartan administration on renal haemodynamics and function in hypertensive patients. Cardiovascular Drugs & Therapy. 2000;14(5):529-32. Sample size less than 50 patients. [pmid: 11101201].
3346 Patil AJ, Bhagwat VR, Patil JA, et al. Occupational lead exposure in battery manufacturing workers, silver jewelry workers, and spray painters in western Maharashtra (India): effect on liver and kidney function. Journal of Basic & Clinical Physiology & Pharmacology. 2007;18(2):87-100. Not RCT or controlled trial. [pmid: 17715565].
3347 Patrono C, Davi G. Antiplatelet agents in the prevention of diabetic vascular complications. Diabetes-Metabolism Reviews. 1993;9(3):177-88. Not RCT or controlled trial. [pmid: 8187606].
3348 Pattou FN, Pellissier LC, Noel C, et al. Supernumerary parathyroid glands: frequency and surgical significance in treatment of renal hyperparathyroidism. World Journal of Surgery. 2000;24(11):1330-4. Not early CKD. [pmid: 11038202].
3349 Paulsen L, Holm C, Bech JN, et al. Effects of statins on renal sodium and water handling: acute and short-term effects of atorvastatin on renal haemodynamics, tubular function, vasoactive hormones, blood pressure and pulse rate in healthy, normocholesterolemic humans. Nephrology Dialysis Transplantation. 2008;23(5):1556-61. Follow-up less than 6 months.
3350 Paulsen L, Holst LM, Bech JN, et al. Glomerular filtration rate and blood pressure are unchanged by increased sodium intake in atorvastatin-treated healthy men. Scandinavian Journal of Clinical & Laboratory Investigation. 2009;69(3):323-9. Sample size less than 50 patients. [pmid: 19051099].
3351 Paulsen L, Matthesen SK, Bech JN, et al. Acute effects of atorvastatin on glomerular filtration rate, tubular function, blood pressure, and vasoactive hormones in patients with type 2 diabetes. Journal of Clinical Pharmacology. Jul. 2010;50(7):816-22. Not CKD treatment. [pmid: 20056802].
3352 Pavlik I, Suchy J, Pacik D, et al. Comparison of cizolirtine citrate and metamizol sodium in the treatment of adult acute renal colic: a randomized, double-blind, clinical pilot study. Clinical Therapeutics. 2004;26(7):1061-72. Sample size less than 50 patients. [pmid: 15336471].
3353 Pechere-Bertschi A, Maillard M, Stalder H, et al. Renal hemodynamic and tubular responses to salt in women using oral contraceptives. Kidney International. 2003;64(4):1374-80. Sample size less than 50 patients. [pmid: 12969156].
3354 Pecis M, Azevedo MJ, Gross JL. Glomerular hyperfiltration is associated with blood pressure abnormalities in normotensive normoalbuminuric IDDM patients. Diabetes Care. 1997;20(8):1329-33. Follow-up less than 6 months. [pmid: 9250464].
3355 Pecis M, de Azevedo MJ, Gross JL. Chicken and fish diet reduces glomerular hyperfiltration in IDDM patients. Diabetes Care. 1994;17(7):665-72. Sample size less than 50 patients. [pmid: 7924775].
3356 Pedersen EB, Madsen JK, Sorensen SS, et al. Improvement in renal function by felodipine during cyclosporine treatment in acute and short-term studies. Kidney International - Supplement. 1996;55:S94-6. Not early CKD. [pmid: 8743522].
3357 Pedersen EB, Thomsen IM, Fjordside LS. Effect of BQ-123, an endothelin antagonist, on renal hemodynamics, tubular function, vasoactive hormones, and blood pressure in healthy humans: a dose response study. American Journal of Hypertension. 2005;18(12 Pt 1):1578-85. Not relevant to key questions. [pmid: 16364829].
3358 Pedersen LM, Milman N. Microalbuminuria in patients with lung cancer. European Journal of Cancer. 1998;34(1):76-80. Not CKD treatment. [pmid: 9624241].
3359 Pedersen MM, Christiansen JS, Mogensen CE. Reduction of glomerular hyperfiltration in normoalbuminuric IDDM patients by 6 mo of aldose reductase inhibition. Diabetes. 1991;40(5):527-31. Sample size less than 50 patients. [pmid: 1902426].
3360 Pedersen MM, Hansen KW, Schmitz A, et al. Effects of ACE inhibition supplementary to beta blockers and diuretics in early diabetic nephropathy. Kidney International. 1992;41(4):883-90. Sample size less than 50 patients. [pmid: 1355149].
3361 Pedersen MM, Mogensen CE, Jorgensen FS, et al. Renal effects from limitation of high dietary protein in normoalbuminuric diabetic patients. Kidney International - Supplement. 1989;27:S115-21. Sample size less than 50 patients. [pmid: 2636645].
3362 Pedersen MM, Schmitz A, Pedersen EB, et al. Acute and long-term renal effects of angiotensin converting enzyme inhibition in normotensive, normoalbuminuric insulin-dependent diabetic patients. Diabetic Medicine. 1988;5(6):562-9. Sample size less than 50 patients. [pmid: 2850132].
3363 Pedersen RS, Bentzen H, Bech JN, et al. Effect of an acute oral ibuprofen intake on urinary aquaporin-2 excretion in healthy humans. Scandinavian Journal of Clinical & Laboratory Investigation. 2001;61(8):631-40. Not early CKD. [pmid: 11768323].
3364 Pedrinelli R, Dell'Omo G, Giampietro O, et al. Dissociation between albuminuria and insulinaemia in hypertensive and atherosclerotic men. Journal of Human Hypertension. 1999;13(2):129-34. Not CKD treatment. [pmid: 10100062].
3365 Pedrinelli R, Ebel M, Catapano G, et al. Pressor, renal and endocrine effects of L-arginine in essential hypertensives. European Journal of Clinical Pharmacology. 1995;48(3-4):195-201. Sample size less than 50 patients. [pmid: 7589041].
3366 Pedrinelli R, Panarace G, Spessot M, et al. Low dose atrial natriuretic factor in primary aldosteronism: renal, hemodynamic, and vascular effects. Hypertension. 1989;14(2):156-63. Not CKD treatment. [pmid: 2527199].
3367 Pedrini MT, Levey AS, Lau J, et al. The effect of dietary protein restriction on the progression of diabetic and nondiabetic renal diseases: a meta-analysis. Annals of Internal Medicine. 1996;124(7):627-32. Not RCT or controlled trial. [pmid: 8607590].
3368 Peixoto AJ, Orias M. Is there a role for direct renin inhibitors in chronic kidney disease?. Current Opinion in Nephrology & Hypertension. 2009;18(5):397-403. Not RCT or controlled trial. [pmid: 19584722].
3369 Peloquin CA, Berning SE, Nitta AT, et al. Aminoglycoside toxicity: daily versus thrice-weekly dosing for treatment of mycobacterial diseases. Clinical Infectious Diseases. 2004;38(11):1538-44. Not CKD treatment. [pmid: 15156439].
3370 Peng T, Hu Z, Xia Q, et al. A comparative study of the renoprotective effects of benidipine and valsartan in primary hypertensive patients with proteinuria. Arzneimittel-Forschung. 2009;59(12):647-50. Not relevant to key questions. [pmid: 20108651].
3371 Penno G, Chaturvedi N, Talmud PJ, et al. Effect of angiotensin-converting enzyme (ACE) gene polymorphism on progression of renal disease and the influence of ACE inhibition in IDDM patients: findings from the EUCLID Randomized Controlled Trial. EURODIAB Controlled Trial of Lisinopril in IDDM. Diabetes. 1998;47(9):1507-11. Not CKD treatment. [pmid: 9726242].
3372 Pentheroudakis G, Twelves C. Capecitabine (Xeloda): from the laboratory to the patient's home. Clinical Colorectal Cancer. 2002;2(1):16-23. Not CKD treatment. [pmid: 12453332].
3373 Percheron C, Colette C, Astre C, et al. Effects of moderate changes in protein intake on urinary albumin excretion in type I diabetic patients. Nutrition. 1995;11(4):345-9. Sample size less than 50 patients. [pmid: 8580574].
3374 Pereira CN, Machado FR, Guimaraes HP, et al. Hemodynamics and renal function during administration of low-dose dopamine in severely ill patients. Sao Paulo Medical Journal = Revista Paulista de Medicina. 2004;122(4):141-6. Not RCT or controlled trial. [pmid: 15543367].
3375 Perez J, Taura P, Rueda J, et al. Role of dopamine in renal dysfunction during laparoscopic surgery. Surgical Endoscopy. 2002;16(9):1297-301. Not early CKD. [pmid: 12000983].
3376 Perez N, Spizzirri F, Rahman R, et al. Steroids in the hemolytic uremic syndrome. Pediatric Nephrology. 1998;12(2):101-4. Not CKD treatment. [pmid: 9543364].
3377 Perez-Maraver M, Carrera MJ, Micalo T, et al. Renoprotective effect of diltiazem in hypertensive type 2 diabetic patients with persistent microalbuminuria despite ACE inhibitor treatment. Diabetes Research & Clinical Practice. 2005;70(1):13-9. Sample size less than 50 patients. [pmid: 16126118].
3378 Perez-Valdivieso JR, Bes-Rastrollo M, Monedero P, et al. Prognosis and serum creatinine levels in acute renal failure at the time of nephrology consultation: an observational cohort study. BMC Nephrology. 2007:8-14. Not early CKD.
3379 Pergola PE, Gartenberg G, Fu M, et al. A randomized controlled study comparing once-weekly to every-2-week and every-4-week dosing of epoetin alfa in CKD patients with anemia. Clinical Journal of The American Society of Nephrology: CJASN. Apr. 2010;5(4):598-606. Not CKD treatment. [pmid: 20185602].
3380 Perinotto P, Biggi A, Carra N, et al. Angiotensin II and prostaglandin interactions on systemic and renal effects of L-NAME in humans. Journal of the American Society of Nephrology. 2001;12(8):1706-12. Not early CKD. [pmid: 11461943].
3381 Perkins RM, Aboudara MC, Uy AL, et al. Effect of pentoxifylline on GFR decline in CKD: a pilot, double-blind, randomized, placebo-controlled trial. American Journal of Kidney Diseases. 2009;53(4):606-16. Not CKD treatment. [pmid: 19216016].
3382 Perkovic V, Verdon C, Ninomiya T, et al. The relationship between proteinuria and coronary risk: a systematic review and meta-analysis. PLoS Medicine / Public Library of Science. 2008;5(10):e207. Not CKD treatment.
3383 Perna A, Ruggenenti P, Testa A, et al. ACE genotype and ACE inhibitors induced renoprotection in chronic proteinuric nephropathies1. Kidney International. 2000;57(1):274-81. Not CKD treatment. [pmid: 10620209].
3384 Perneger TV, Klag MJ, Whelton PK. Cause of death in patients with end-stage renal disease: death certificates vs registry reports. American Journal of Public Health. 1993;83(12):1735-8. Not early CKD. [pmid: 8259805].
3385 Perrin NESS, Jaremko GA, Berg UB. The effects of candesartan on diabetes glomerulopathy: a double-blind, placebo-controlled trial. Pediatric Nephrology. 2008;23(6):947-54. Sample size less than 50 patients. [pmid: 18270751].
3386 Persson B, Andersson OK, Wysocki M, et al. Renal and hemodynamic effects of isradipine in essential hypertension. American Journal of Medicine. 1989;86(4A):60-4. Sample size less than 50 patients. [pmid: 2523657].
3387 Persson B, Andersson OK, Wysocki M, et al. Calcium antagonism in essential hypertension: effect on renal haemodynamics and microalbuminuria. Journal of Internal Medicine. 1992;231(3):247-52. Sample size less than 50 patients. [pmid: 1532613].
3388 Persson B, Granerus G, Wysocki M, et al. Acute systemic and renal haemodynamic effects and long-term antihypertensive action of cadralazine in patients pretreated with beta-blockers and diuretics. European Journal of Clinical Pharmacology. 1987;31(5):513-8. Sample size less than 50 patients. [pmid: 2881788].
3389 Persson F, Rossing P, Hovind P, et al. Endothelial dysfunction and inflammation predict development of diabetic nephropathy in the Irbesartan in Patients with Type 2 Diabetes and Microalbuminuria (IRMA 2) study. Scandinavian Journal of Clinical & Laboratory Investigation. 2008;68(8):731-8. Not CKD treatment. [pmid: 18609080].
3390 Persson F, Rossing P, Reinhard H, et al. Renal effects of aliskiren compared with and in combination with irbesartan in patients with type 2 diabetes, hypertension, and albuminuria. Diabetes Care. 2009;32(10):1873-9. Sample size less than 50 patients. [pmid: 19587362].
3391 Persson F, Rossing P, Reinhard H, et al. Optimal antiproteinuric dose of aliskiren in type 2 diabetes mellitus: a randomised crossover trial. Diabetologia. Aug. 2010;53(8):1576-80. Follow-up less than 6 months. [pmid: 20480132].
3392 Persson NH, Bergqvist D, Melander A, et al. Comparison of a narcotic (oxicone) and a non-narcotic anti-inflammatory analgesic (indoprofen) in the treatment of renal colic. Acta Chirurgica Scandinavica. 1985;151(2):105-8. Follow-up less than 6 months. [pmid: 3890435].
3393 Perttunen K, Kalso E, Heinonen J, et al. IV diclofenac in post-thoracotomy pain. British Journal of Anaesthesia. 1992;68(5):474-80. Not CKD treatment. [pmid: 1642935].
3394 Perttunen K, Nilsson E, Kalso E. I.v. diclofenac and ketorolac for pain after thoracoscopic surgery. British Journal of Anaesthesia. 1999;82(2):221-7. Not CKD treatment. [pmid: 10364998].
3395 Perumal K, Fischer MJ, Mrtek R. Efficacy of furosemide in ARF. American Journal of Kidney Diseases. 2005;45(4):786. author reply -7. Follow-up less than 6 months. [pmid: 15806485].
3396 Petchey WG, Hickman IJ, Duncan E, et al. The role of 25-hydroxyvitamin D deficiency in promoting insulin resistance and inflammation in patients with chronic kidney disease: a randomised controlled trial. BMC Nephrology. 2009:10-41. Not RCT or controlled trial.
3397 Peters PJ, Moore DM, Mermin J, et al. Antiretroviral therapy improves renal function among HIV-infected Ugandans. Kidney International. 2008;74(7):925-9. Not early CKD. [pmid: 18614998].
3398 Peters RM, Flack JM. Salt sensitivity and hypertension in African Americans: implications for cardiovascular nurses. Progress in Cardiovascular Nursing. 2000;15(4):138-44. Not RCT or controlled trial. [pmid: 11098526].
3399 Petersen LJ, Petersen JR, Talleruphuus U, et al. A randomized and double-blind comparison of isradipine and spirapril as monotherapy and in combination on the decline in renal function in patients with chronic renal failure and hypertension. Clinical Nephrology. 2001;55(5):375-83. Sample size less than 50 patients. [pmid: 11393383].
3400 Peterson GE, de Backer T, Gabriel A, et al. Prevalence and correlates of left ventricular hypertrophy in the African American Study of Kidney Disease Cohort Study. Hypertension. 2007;50(6):1033-9. Sample size less than 50 patients. [pmid: 17968003].
3401 Peterson K. ACE inhibitors and renoprotection. Journal of Family Practice. 1996;42(5):453. Not RCT or controlled trial. [pmid: 8642355].
3402 Petrica L, Petrica M, Vlad A, et al. Nephro- and neuroprotective effects of rosiglitazone versus glimepiride in normoalbuminuric patients with type 2 diabetes mellitus: a randomized controlled trial. Wiener Klinische Wochenschrift. 2009;121(23-24):765-75. Sample size less than 50 patients. [pmid: 20047115].
3403 Petrovich Z, Yu C, Giannotta SL, et al. Survival and pattern of failure in brain metastasis treated with stereotactic gamma knife radiosurgery. Journal of Neurosurgery. 2002;97(5 Suppl):499-506. Not CKD treatment. [pmid: 12507085].
3404 Petry A, Wulf H, Baumgartel M. The influence of ketanserin or urapidil on haemodynamics, stress response and kidney function during operations for myocardial revascularisation. Anaesthesia. 1995;50(4):312-6. Sample size less than 50 patients. [pmid: 7747847].
3405 Pettinger WA, Lee HC, Reisch J, et al. Long-term improvement in renal function after short-term strict blood pressure control in hypertensive nephrosclerosis. Hypertension. 1989;13(6 Pt 2):766-72. Not relevant to key questions. [pmid: 2544523].
3406 Peuckmann V, Elsner F, Krumm N, et al. Pharmacological treatments for fatigue associated with palliative care. Cochrane Database of Systematic Reviews. 2010;11:CD006788. Not CKD treatment. [pmid: 21069692].
3407 Pfaller W, Thorwartl U, Nevinny-Stickel M, et al. Clinical value of fructose 1,6 bisphosphatase in monitoring renal proximal tubular injury. Kidney International - Supplement. 1994;47:S68-75. Not CKD treatment. [pmid: 7532742].
3408 Pfeffer MA, Burdmann EA, Chen CY, et al. A trial of darbepoetin alfa in type 2 diabetes and chronic kidney disease. New England Journal of Medicine. 2009;361(21):2019-32. Not CKD treatment. [pmid: 19880844].
3409 Pfeffer MA, Burdmann EA, Chen CY, et al. A trial of darbepoetin alfa in type 2 diabetes and chronic kidney disease. New England Journal of Medicine. 2009;361(21):2019-32. Not CKD treatment. [pmid: 19880844].
3410 Pfeffer MA, Burdmann EA, Chen CY, et al. Baseline characteristics in the Trial to Reduce Cardiovascular Events With Aranesp Therapy (TREAT). American Journal of Kidney Diseases. 2009;54(1):59-69. Not CKD treatment. [pmid: 19501439].
3411 Pfeffer MA, Committee TE. An ongoing study of anemia correction in chronic kidney disease. New England Journal of Medicine. 2007;356(9):959-61. Not relevant to key questions. [pmid: 17329707].
3412 Pfeffer MA, Solomon SD, Singh AK, et al. Uncertainty in the treatment of anemia in chronic kidney disease. Reviews in Cardiovascular Medicine. Suppl 3. 2005;6:S35-41. Not human studies. [pmid: 16340937].
3413 Pham PTT, Pham PCT, Wilkinson AH. Management of renal dysfunction in the liver transplant recipient. Current Opinion in Organ Transplantation. 2009;14(3):231-9. Not CKD treatment. [pmid: 19395967].
3414 Phillips E, Hinck B, Pedro R, et al. Celecoxib in the management of acute renal colic: a randomized controlled clinical trial. Urology. 2009;74(5):994-9. Follow-up less than 6 months. [pmid: 19589565].
3415 Phillips PJ, Phillipou G, Bowen KM, et al. Diabetic microalbuminuria and cilazapril. American Journal of Medicine. 1993;94(4A):58S-60S. Sample size less than 50 patients. [pmid: 8488862].
3416 Phillips RA, Faulkner M, Gassman J, et al. Recruitment of African Americans with chronic renal insufficiency into a multicenter clinical trial: the african american study of kidney disease and hypertension. Journal of Clinical Hypertension. 2004;6(8):430-6. Not CKD treatment. [pmid: 15308881].
3417 Phrommintikul A, Haas SJ, Elsik M, et al. Mortality and target haemoglobin concentrations in anaemic patients with chronic kidney disease treated with erythropoietin: a meta-analysis. Lancet. 2007;369(9559):381-8. Sample size less than 50 patients. [pmid: 17276778].
3418 Piccoli A. Elementary clinical decision analysis in evidence-based nephrology. Journal of Nephrology. 2000;13(6):419-32. Not RCT or controlled trial. [pmid: 11132758].
3419 Pichler J, Risch L, Hefti U, et al. Glomerular filtration rate estimates decrease during high altitude expedition but increase with Lake Louise acute mountain sickness scores. Acta Physiologica. 2008;192(3):443-50. Not RCT or controlled trial. [pmid: 17970827].
3420 Pichler RH, de Boer IH. Dual renin-angiotensin-aldosterone system blockade for diabetic kidney disease. Current Diabetes Reports. Aug. 2010;10(4):297-305. Not relevant to key questions. [pmid: 20532701].
3421 Pickering JW, Endre ZH. Back-calculating baseline creatinine with MDRD misclassifies acute kidney injury in the intensive care unit. Clinical Journal of The American Society of Nephrology: CJASN. Jul. 2010;5(7):1165-73. Not CKD treatment. [pmid: 20498242].
3422 Pickering TG. Cardiorenal protection in diabetes. Heart Disease. 2000;2(2):S18-22. Not RCT or controlled trial. [pmid: 11728259].
3423 Pickles CJ, Broughton Pipkin F, Symonds EM. A randomised placebo controlled trial of labetalol in the treatment of mild to moderate pregnancy induced hypertension. British Journal of Obstetrics & Gynaecology. 1992;99(12):964-8. Not CKD treatment. [pmid: 1477017].
3424 Pickup JC, Collins AC, Walker JD, et al. Patterns of hyperinsulinaemia in type 1 diabetic patients with and without nephropathy. Diabetic Medicine. 1989;6(8):685-91. Sample size less than 50 patients. [pmid: 2532102].
3425 Pidgeon GB, Richards AM, Nicholls MG, et al. Acute effects of intravenous ouabain in healthy volunteers. Clinical Science. 1994;86(4):391-7. Not CKD treatment. [pmid: 8168332].
3426 Piecha G, Adamczak M, Chudek J, et al. Indapamide decreases plasma adiponectin concentration in patients with essential hypertension. Kidney & Blood Pressure Research. 2007;30(3):187-94. Sample size less than 50 patients. [pmid: 17536226].
3427 Pierce HL, Stevermer JJ. Does losartan (Cozaar) slow the progression of renal disease in patients with type 2 diabetes and nephropathy?. Journal of Family Practice. 2001;50(12):1083. Not RCT or controlled trial. [pmid: 11742614].
3428 Pieta J, Millar T, Zacharias J, et al. Effect of pergolide on restless legs and leg movements in sleep in uremic patients. Sleep. 1998;21(6):617-22. Not early CKD. [pmid: 9779521].
3429 Pijls LTJ, de Vries H, van Eijk JTM, et al. Protein restriction, glomerular filtration rate and albuminuria in patients with type 2 diabetes mellitus: a randomized trial. European Journal of Clinical Nutrition. 2002;56(12):1200-7. Sample size less than 50 patients. [pmid: 12494305].
3430 Pimenta E, Oparil S. Role of aliskiren in cardio-renal protection and use in hypertensives with multiple risk factors. Vascular Health & Risk Management. 2009;5(1):453-63. Not RCT or controlled trial. [pmid: 19475781].
3431 Pines A, Fisman EZ. ACE Inhibition with moexipril: a review of potential effects beyond blood pressure control. American Journal of Cardiovascular Drugs. 2003;3(5):351-60. Follow-up less than 6 months. [pmid: 14728069].
3432 Pinkau T, Ndrepepa G, Kastrati A, et al. Glycoprotein IIb/IIIa receptor inhibition with abciximab during percutaneous coronary interventions increases the risk of bleeding in patients with impaired renal function. Cardiology. 2008;111(4):247-53. Follow-up less than 6 months. [pmid: 18434733].
3433 Pinol C, Cobos A, Cases A, et al. Nitrendipine and enalapril in the treatment of diabetic hypertensive patients with microalbuminuria. Kidney International - Supplement. 1996;55:S85-7. Sample size less than 50 patients. [pmid: 8743519].
3434 Pinto JR, Bending JJ, Dodds RA, et al. Effect of low protein diet on the renal response to meat ingestion in diabetic nephropathy. European Journal of Clinical Investigation. 1991;21(2):175-83. Sample size less than 50 patients. [pmid: 1905630].
3435 Piozzi R, Ribeiro DA, Padovan LEM, et al. Genotoxicity and cytotoxicity in multiple organs induced by titanium miniplates in Wistar rats. Journal of Biomedical Materials Research. Part A. 2009;88(2):342-7. Not early CKD. [pmid: 18286617].
3436 Piper SN, Kumle B, Maleck WH, et al. Diltiazem may preserve renal tubular integrity after cardiac surgery. Canadian Journal of Anaesthesia. 2003;50(3):285-92. Not CKD treatment. [pmid: 12620953].
3437 Piquard F, Richard R, Charloux A, et al. Hormonal, renal, hemodynamic responses to acute neutral endopeptidase inhibition in heart transplant patients. Journal of Applied Physiology. 2002;93(2):569-75. Not early CKD. [pmid: 12133866].
3438 Pisoni R, Ruggenenti P, Remuzzi G. Drug-induced thrombotic microangiopathy: incidence, prevention and management. Drug Safety. 2001;24(7):491-501. Not early CKD. [pmid: 11444722].
3439 Pistrosch F, Herbrig K, Kindel B, et al. Rosiglitazone improves glomerular hyperfiltration, renal endothelial dysfunction, and microalbuminuria of incipient diabetic nephropathy in patients. Diabetes. 2005;54(7):2206-11. Sample size less than 50 patients. [pmid: 15983223].
3440 Pitt B. Revascularization in patients with chronic kidney disease: the state of the ARTS. European Heart Journal. 2005;26(15):1456-7. Follow-up less than 6 months. [pmid: 15917278].
3441 Pitt B, Segal R, Martinez FA, et al. Randomised trial of losartan versus captopril in patients over 65 with heart failure (Evaluation of Losartan in the Elderly Study, ELITE). Lancet. 1997;349(9054):747-52. Not early CKD. [pmid: 9074572].
3442 Pivalizza EG, Abramson DC, Harvey A. Perioperative hypercoagulability in uremic patients: a viscoelastic study. Journal of Clinical Anesthesia. 1997;9(6):442-5. Sample size less than 50 patients. [pmid: 9278828].
3443 Platz KP, Mueller AR, Jonas S, et al. Toxicity versus rejection--or why conversions between cyclosporine A and FK506 were performed after liver transplantation. Clinical Transplantation. 1995;9(3 Pt 1):146-54. Not RCT or controlled trial. [pmid: 7549052].
3444 Plosker GL, Sorkin EM. Quinapril. A reappraisal of its pharmacology and therapeutic efficacy in cardiovascular disorders. Drugs. 1994;48(2):227-52. Not CKD treatment. [pmid: 7527326].
3445 Plum J, Bunten B, Nemeth R, et al. Effects of the angiotensin II antagonist valsartan on blood pressure, proteinuria, and renal hemodynamics in patients with chronic renal failure and hypertension. Journal of the American Society of Nephrology. 1998;9(12):2223-34. Sample size less than 50 patients. [pmid: 9848776].
3446 Plum J, Bunten B, Nemeth R, et al. Treatment with the angiotensin II antagonist valsartan in patients with chronic renal failure and hypertension. Nephrology Dialysis Transplantation. Suppl 4. 1999;14:25-7. Sample size less than 50 patients.
3447 Plusa SM, Clark NW. Prevention of postoperative renal dysfunction in patients with obstructive jaundice: a comparison of mannitol-induced diuresis and oral sodium taurocholate. Journal of the Royal College of Surgeons of Edinburgh. 1991;36(5):303-5. Not CKD treatment. [pmid: 1757907].
3448 Pohl MA. Changing the course of diabetic nephropathy: angiotensin-converting enzyme inhibition in type I diabetic renal disease. Cleveland Clinic Journal of Medicine. 1994;61(1):38-42. Not RCT or controlled trial. [pmid: 8124846].
3449 Pohl MA, Blumenthal S, Cordonnier DJ, et al. Independent and additive impact of blood pressure control and angiotensin II receptor blockade on renal outcomes in the irbesartan diabetic nephropathy trial: clinical implications and limitations. Journal of the American Society of Nephrology. 2005;16(10):3027-37. Not RCT or controlled trial. [pmid: 16120823].
3450 Poirier SJ. Reducing complications in type 2 diabetes. American Family Physician. 1998;57(6):1238-9. Not RCT or controlled trial. [pmid: 9531907].
3451 Poletti PA, Saudan P, Platon A, et al. I.v. N-acetylcysteine and emergency CT: use of serum creatinine and cystatin C as markers of radiocontrast nephrotoxicity. AJR. American Journal of Roentgenology. 2007;189(3):687-92. Not CKD treatment. [pmid: 17715118].
3452 Polonia J, Boaventura I, Gama G, et al. Influence of non-steroidal anti-inflammatory drugs on renal function and 24h ambulatory blood pressure-reducing effects of enalapril and nifedipine gastrointestinal therapeutic system in hypertensive patients. Journal of Hypertension. 1995;13(8):925-31. Follow-up less than 6 months. [pmid: 8557971].
3453 Pomerleau J, Verdy M, Garrel DR, et al. Effect of protein intake on glycaemic control and renal function in type 2 (non-insulin-dependent) diabetes mellitus. Diabetologia. 1993;36(9):829-34. Sample size less than 50 patients. [pmid: 8405754].
3454 Ponticelli C, Edefonti A, Ghio L, et al. Cyclosporin versus cyclophosphamide for patients with steroid-dependent and frequently relapsing idiopathic nephrotic syndrome: a multicentre randomized controlled trial. Nephrology Dialysis Transplantation. 1993;8(12):1326-32. Not early CKD.
3455 Ponticelli C, Rizzoni G, Edefonti A, et al. A randomized trial of cyclosporine in steroid-resistant idiopathic nephrotic syndrome. Kidney International. 1993;43(6):1377-84. Sample size less than 50 patients. [pmid: 8315953].
3456 Pool JL. Is it time to move to multidrug combinations?. American Journal of Hypertension. 2003;16(11 Pt 2):36S-40S. Not CKD treatment.
3457 Poortmans JR, Auquier H, Renaut V, et al. Effect of short-term creatine supplementation on renal responses in men. European Journal of Applied Physiology & Occupational Physiology. 1997;76(6):566-7. Sample size less than 50 patients. [pmid: 9404870].
3458 Porayko MK, Gonwa TA, Klintmalm GB, et al. Comparing nephrotoxicity of FK 506 and cyclosporine regimens after liver transplantation: preliminary results from US Multicenter trial. U.S. Multicenter Liver Study Group. Transplantation Proceedings. 1995;27(1):1114-6. Not early CKD. [pmid: 7533358].
3459 Porayko MK, Textor SC, Krom RA, et al. Nephrotoxic effects of primary immunosuppression with FK-506 and cyclosporine regimens after liver transplantation. Mayo Clinic Proceedings. 1994;69(2):105-11. Sample size less than 50 patients. [pmid: 7508536].
3460 Porayko MK, Textor SC, Krom RA, et al. Nephrotoxicity of FK 506 and cyclosporine when used as primary immunosuppression in liver transplant recipients. Transplantation Proceedings. 1993;25(1 Pt 1):665-8. Not RCT or controlled trial. [pmid: 7679835].
3461 Pordy R, Woittiez A. Steady-state trough plasma mibefradil concentrations and correlation to blood pressure response in hypertensive patients with chronic renal disease. International Journal of Clinical Pharmacology Research. 1998;18(3):105-8. Not RCT or controlled trial. [pmid: 9825266].
3462 Portaluppi F, Vergnani L, Manfredini R, et al. Time-dependent effect of isradipine on the nocturnal hypertension in chronic renal failure. American Journal of Hypertension. 1995;8(7):719-26. Sample size less than 50 patients. [pmid: 7546498].
3463 Porter GA. Contrast-associated nephropathy: presentation, pathophysiology and management. Mineral & Electrolyte Metabolism. 1994;20(4):232-43. Not CKD treatment. [pmid: 7845325].
3464 Porter GA, Norton TL, Legg V. Using urinary biomarkers to evaluate renal effects of a Cox-2 NSAID in volunteers. Renal Failure. 1999;21(3-4):311-7. Sample size less than 50 patients. [pmid: 10416208].
3465 Porzano AM, Baldoncini R, De Siati L, et al. Effects of short-time insulin suppression on renal sodium excretion in type II diabetic hypertensives. Diabetes Research. 1993;22(1):3-10. Sample size less than 50 patients. [pmid: 8200182].
3466 Poschel KA, Bucha E, Esslinger HU, et al. Pharmacodynamics and pharmacokinetics of polyethylene glycol-hirudin in patients with chronic renal failure. Kidney International. 2000;58(6):2478-84. Not RCT or controlled trial. [pmid: 11115081].
3467 Posen S, Clifton-Bligh P, Reeve TS, et al. Is parathyroidectomy of benefit in primary hyperparathyroidism?. Quarterly Journal of Medicine. 1985;54(215):241-51. Not CKD treatment. [pmid: 3991879].
3468 Post FA, Moyle GJ, Stellbrink HJ, et al. Randomized comparison of renal effects, efficacy, and safety with once-daily abacavir/lamivudine versus tenofovir/emtricitabine, administered with efavirenz, in antiretroviral-naive, HIV-1-infected adults: 48-week results from the ASSERT study. Journal of Acquired Immune Deficiency Syndromes: JAIDS. Sep. 1. 2010;55(1):49-57. Not early CKD.
3469 Postma MJ, Kruidhof H, de Jong-van den Berg LTW, et al. Pharmacoeconomic aspects of losartan treatment to delay progression of renal disease in patients with Type 2 diabetes. Expert Opinion on Pharmacotherapy. 2003;4(9):1543-50. Not relevant to key questions. [pmid: 12943484].
3470 Potena L, Bianchi IG, Magnani G, et al. Cyclosporine lowering with everolimus or mycophenolate to preserve renal function in heart recipients: a randomized study. Transplantation. 2010;89(2):263-5. Sample size less than 50 patients. [pmid: 20098293].
3471 Potter K, Hankey GJ, Green DJ, et al. Homocysteine or renal impairment: which is the real cardiovascular risk factor?. Arteriosclerosis, Thrombosis & Vascular Biology. 2008;28(6):1158-64. Not human studies.
3472 Pouleur H. Neurohormonal and hemodynamic effects of ibopamine. Clinical Cardiology. 1995;18(3 Suppl I):I17-21. Not CKD treatment. [pmid: 7743694].
3473 Poulsen PL. ACE inhibitor intervention in Type 1 diabetes with low grade microalbuminuria. Journal of the Renin-Angiotensin-Aldosterone System. 2003;4(1):17-26. Sample size less than 50 patients. [pmid: 12692749].
3474 Poulsen PL, Ebbehoj E, Mogensen CE. Lisinopril reduces albuminuria during exercise in low grade microalbuminuric type 1 diabetic patients: a double blind randomized study. Journal of Internal Medicine. 2001;249(5):433-40. Sample size less than 50 patients. [pmid: 11350567].
3475 Poulsen PL, Ebbehoj E, Nosadini R, et al. Early ACE-i intervention in microalbuminuric patients with type 1 diabetes: effects on albumin excretion, 24 h ambulatory blood pressure, and renal function. Diabetes & Metabolism. 2001;27(2 Pt 1):123-8. Sample size less than 50 patients. [pmid: 11353877].
3476 Powe NR. Measuring effectiveness and outcomes of interventions for renal disease. Current Opinion in Nephrology & Hypertension. 1996;5(3):230-5. Not RCT or controlled trial. [pmid: 8737858].
3477 Powe NR, Moore RD, Steinberg EP. Adverse reactions to contrast media: factors that determine the cost of treatment. AJR. American Journal of Roentgenology. 1993;161(5):1089-95. Not CKD treatment. [pmid: 8273616].
3478 Power DA, Duggan J, Brady HR. Renal-dose (low-dose) dopamine for the treatment of sepsis-related and other forms of acute renal failure: ineffective and probably dangerous. Clinical & Experimental Pharmacology & Physiology - Supplement. 1999;26:S23-8. Not RCT or controlled trial. [pmid: 10386250].
3479 Power I, Cumming AD, Pugh GC. Effect of diclofenac on renal function and prostacyclin generation after surgery. British Journal of Anaesthesia. 1992;69(5):451-6. Sample size less than 50 patients. [pmid: 1467074].
3480 Praga M, Andrade CF, Luno J, et al. Antiproteinuric efficacy of losartan in comparison with amlodipine in non-diabetic proteinuric renal diseases: a double-blind, randomized clinical trial. Nephrology Dialysis Transplantation. 2003;18(9):1806-13. Follow-up less than 6 months.
3481 Praga M, Hernandez E, Andres A, et al. Effects of body-weight loss and captopril treatment on proteinuria associated with obesity. Nephron. 1995;70(1):35-41. Sample size less than 50 patients. [pmid: 7617115].
3482 Prakash S, Pande DP, Sharma S, et al. Randomized, double-blind, placebo-controlled trial to evaluate efficacy of ketodiet in predialytic chronic renal failure. Journal of Renal Nutrition. 2004;14(2):89-96. Not CKD treatment. [pmid: 15060873].
3483 Pratley RE, Rosenstock J, Pi-Sunyer FX, et al. Management of type 2 diabetes in treatment-naive elderly patients: benefits and risks of vildagliptin monotherapy. Diabetes Care. 2007;30(12):3017-22. Not relevant to key questions. [pmid: 17878242].
3484 Predel HG, Kuklinski P, Kramer HJ. Intranasal application of atrial natriuretic peptide and 1-deamino-d-arginine vasopressin in healthy volunteers. Hemodynamic, hormonal, and renal excretory effects. American Journal of Hypertension. 1992;5(9):657-60. Sample size less than 50 patients. [pmid: 1329853].
3485 Preiss DJ, Godber IM, Lamb EJ, et al. The influence of a cooked-meat meal on estimated glomerular filtration rate. Annals of Clinical Biochemistry. 2007;44(Pt 1):35-42. Not RCT or controlled trial. [pmid: 17270090].
3486 Prescott LF, Freestone S, McAuslane JA. Reassessment of the single intravenous injection method with inulin for measurement of the glomerular filtration rate in man. Clinical Science. 1991;80(2):167-76. Sample size less than 50 patients. [pmid: 1848170].
3487 Prescott LF, Mattison P, Menzies DG, et al. The comparative effects of paracetamol and indomethacin on renal function in healthy female volunteers. British Journal of Clinical Pharmacology. 1990;29(4):403-12. Not CKD treatment. [pmid: 2183866].
3488 Presta P, Onorati F, Fuiano L, et al. Can pulsatile cardiopulmonary bypass prevent perioperative renal dysfunction during myocardial revascularization in elderly patients?. Nephron. 2009;111(4):c229-35. Not CKD treatment. [pmid: 19287182].
3489 Preston RA, Afshartous D, Alonso AB. Effects of selective vs. nonselective cyclooxygenase inhibition on dynamic renal potassium excretion: a randomized trial. Clinical Pharmacology & Therapeutics. 2008;84(2):208-11. Not CKD treatment. [pmid: 18288080].
3490 Preston RA, Afshartous D, Garg D, et al. Mechanisms of impaired potassium handling with dual renin-angiotensin-aldosterone blockade in chronic kidney disease. Hypertension. 2009;53(5):754-60. Not CKD treatment. [pmid: 19307466].
3491 Preston RA, Materson BJ, Reda DJ, et al. Proteinuria in mild to moderate hypertension: results of the VA cooperative study of six antihypertensive agents and placebo. Department of Veterans Affairs Cooperative Study Group on Antihypertensive Agents. Clinical Nephrology. 1997;47(5):310-5. Not early CKD. [pmid: 9181278].
3492 Price DA, Fisher NDL, Lansang MC, et al. Renal perfusion in blacks: alterations caused by insuppressibility of intrarenal renin with salt. Hypertension. 2002;40(2):186-9. Not CKD treatment. [pmid: 12154111].
3493 Price DA, Hollenberg NK. Angiotensin receptor blockers in diabetic nephropathy. Current Diabetes Reports. 2001;1(3):267-74. Not RCT or controlled trial. [pmid: 12643209].
3494 Pridjian AK, Bove EL, Beekman RH 3rd, et al. Comparison of a low osmolarity nonionic radiographic contrast agent with a standard medium on renal function in cyanotic and normal dogs. Catheterization & Cardiovascular Diagnosis. 1994;31(1):90-3. Sample size less than 50 patients. [pmid: 8118866].
3495 Prins JM, Buller HR, Kuijper EJ, et al. Once versus thrice daily gentamicin in patients with serious infections. Lancet. 1993;341(8841):335-9. Not CKD treatment. [pmid: 8094114].
3496 Prisant LM. Diabetes mellitus and hypertension: a mandate for intense treatment according to new guidelines. American Journal of Therapeutics. 2003;10(5):363-9. Not RCT or controlled trial. [pmid: 12975721].
3497 Prisant LM, Louard RJ. Controversies surrounding the treatment of the hypertensive patient with diabetes. Current Hypertension Reports. 1999;1(6):512-20. Not RCT or controlled trial. [pmid: 10981115].
3498 Pritchard G, Lyons D, Webster J, et al. Do trandolapril and indomethacin influence renal function and renal functional reserve in hypertensive patients?. British Journal of Clinical Pharmacology. 1997;44(2):145-9. Follow-up less than 6 months. [pmid: 9278199].
3499 Prodjosudjadi W, Suhardjono, Suwitra K, et al. Detection and prevention of chronic kidney disease in Indonesia: initial community screening. Nephrology. 2009;14(7):669-74. Not RCT or controlled trial. [pmid: 19796026].
3500 Pronovost PH, Brady HR, Gunning ME, et al. Clinical features, predictors of disease progression and results of renal transplantation in fibrillary/immunotactoid glomerulopathy. Nephrology Dialysis Transplantation. 1996;11(5):837-42. Not RCT or controlled trial.
3501 Provenzano R, Bhaduri S, Singh AK, et al. Extended epoetin alfa dosing as maintenance treatment for the anemia of chronic kidney disease: the PROMPT study. Clinical Nephrology. 2005;64(2):113-23. Not CKD treatment. [pmid: 16114787].
3502 Provenzano R, Garcia-Mayol L, Suchinda P, et al. Once-weekly epoetin alfa for treating the anemia of chronic kidney disease. Clinical Nephrology. 2004;61(6):392-405. Sample size less than 50 patients. [pmid: 15224803].
3503 Prowle JR, Echeverri JE, Ligabo EV, et al. Fluid balance and acute kidney injury. Nature Reviews Nephrology. Feb. 2010;6(2):107-15. Not early CKD.
3504 Puig JG, Marre M, Kokot F, et al. Efficacy of indapamide SR compared with enalapril in elderly hypertensive patients with type 2 diabetes. American Journal of Hypertension. 2007;20(1):90-7. Not RCT or controlled trial. [pmid: 17198918].
3505 Puig JG, Mateos FA, Ramos TH, et al. Albumin excretion rate and metabolic modifications in patients with essential hypertension. Effects of two angiotensin converting enzyme inhibitors. American Journal of Hypertension. 1994;7(1):46-51. Sample size less than 50 patients. [pmid: 8136110].
3506 Puigmule M, Lopez-Hellin J, Sune G, et al. Differential proteomic analysis of cyclosporine A-induced toxicity in renal proximal tubule cells. Nephrology Dialysis Transplantation. 2009;24(9):2672-86. Not CKD treatment.
3507 Pull ter Gunne AJ, Bruining HA, Obertop H. Haemodynamics and ‘optimal’ hydration in aortic cross clamping. Netherlands Journal of Surgery. 1990;42(4):113-7. Not CKD treatment. [pmid: 2216006].
3508 Puolakka PAE, Rintala S, Yli-Hankala A, et al. The effect of parecoxib on kidney function at laparoscopic hysterectomy. Renal Failure. 2009;31(4):284-9. Sample size less than 50 patients. [pmid: 19462277].
3509 Puscas I, Coltau M, Baican M, et al. Omeprazole has a dual mechanism of action: it inhibits both H(+)K(+)ATPase and gastric mucosa carbonic anhydrase enzyme in humans (in vitro and in vivo experiments). Journal of Pharmacology & Experimental Therapeutics. 1999;290(2):530-4. Not CKD treatment. [pmid: 10411559].
3510 Pylypchuk G, Beaubien E. Diabetic nephropathy. Prevention and early referral. Canadian Family Physician. 2000;46:636-42. Not RCT or controlled trial. [pmid: 10752002].
3511 Qiu Z, Chen X, Xu M, et al. Evaluation of preoperative intra-aortic balloon pump in coronary patients with severe left ventricular dysfunction undergoing OPCAB surgery: early and mid-term outcomes. Journal Of Cardiothoracic Surgery. 2009;4:39. Not CKD treatment. [pmid: 19635155].
3512 Quan DJ, McQueen KD. dDAVP in enuresis. DICP. 1990;24(12):1179-80. Not RCT or controlled trial. [pmid: 2089827].
3513 Qureshi F, Tahir M, Sami W. Protective role of vitamin C and E against sodium arsenate induced changes in developing kidney of albino mice. Journal of Ayub Medical College, Abbottabad: JAMC. Oct-Dec. 2009;21(4):63-9. Not human studies.
3514 Raab C, Weidmann E, Schmidt A, et al. The effects of interleukin-2 treatment on endothelin and the activation of the hypothalamic-pituitary-adrenal axis. Clinical Endocrinology. 1999;50(1):37-44. Not CKD treatment. [pmid: 10341854].
3515 Raal FJ, Kalk WJ, Lawson M, et al. Effect of moderate dietary protein restriction on the progression of overt diabetic nephropathy: a 6-mo prospective study. American Journal of Clinical Nutrition. 1994;60(4):579-85. Sample size less than 50 patients. [pmid: 8092094].
3516 Rab A, Dallinger S, Polak K, et al. Specific endothelin ET(A) receptor antagonism does not modulate insulin-induced hemodynamic effects in the human kidney, eye, or forearm. Journal of Pharmacology & Experimental Therapeutics. 2004;309(2):692-6. Not CKD treatment. [pmid: 14757848].
3517 Rabbani N, Alam SS, Riaz S, et al. High-dose thiamine therapy for patients with type 2 diabetes and microalbuminuria: a randomised, double-blind placebo-controlled pilot study. Diabetologia. 2009;52(2):208-12. Not CKD treatment. [pmid: 19057893].
3518 Rabelink AJ, Hene RJ, Erkelens DW, et al. Effects of simvastatin and cholestyramine on lipoprotein profile in hyperlipidaemia of nephrotic syndrome. Lancet. 1988;2(8624):1335-8. Sample size less than 50 patients. [pmid: 2904053].
3519 Rabelink TJ, Kaasjager KA, Boer P, et al. Effects of endothelin-1 on renal function in humans: implications for physiology and pathophysiology. Kidney International. 1994;46(2):376-81. Not RCT or controlled trial. [pmid: 7967349].
3520 Rabelink TJ, Koomans HA, van de Stolpe A, et al. Effects of atrial natriuretic peptide on distal tubule function in humans. Kidney International. 1990;37(3):996-1001. Not CKD treatment. [pmid: 2138237].
3521 Rachmani R, Levi Z, Slavachevski I, et al. Teaching patients to monitor their risk factors retards the progression of vascular complications in high-risk patients with Type 2 diabetes mellitus--a randomized prospective study. Diabetic Medicine. 2002;19(5):385-92. Not early CKD. [pmid: 12027926].
3522 Rachmani R, Levi Z, Slavachevsky I, et al. Effect of an alpha-adrenergic blocker, and ACE inhibitor and hydrochlorothiazide on blood pressure and on renal function in type 2 diabetic patients with hypertension and albuminuria. A randomized cross-over study. Nephron. 1998;80(2):175-82. Follow-up less than 6 months. [pmid: 9736816].
3523 Rachmani R, Ravid M. Risk factors for nephropathy in type 2 diabetes mellitus. Comprehensive Therapy. 1999;25(6-7):366-9. Not RCT or controlled trial. [pmid: 10470521].
3524 Rachmani R, Slavachevski I, Berla M, et al. Teaching and motivating patients to control their risk factors retards progression of cardiovascular as well as microvascular sequelae of Type 2 diabetes mellitus- a randomized prospective 8 years follow-up study. Diabetic Medicine. 2005;22(4):410-4. Not early CKD. [pmid: 15787665].
3525 Rachmani R, Slavachevsky I, Amit M, et al. The effect of spironolactone, cilazapril and their combination on albuminuria in patients with hypertension and diabetic nephropathy is independent of blood pressure reduction: a randomized controlled study. [Retraction in Diabet Med. 2006 Jul;23(7):818; PMID:16842490]. Diabetic Medicine. 2004;21(5):471-5. Sample size less than 50 patients. [pmid: 15089793].
3526 Radermacher J, Koch KM. Treatment of renal anemia by erythropoietin substitution. The effects on the cardiovascular system. Clinical Nephrology. Suppl 1. 1995;44:S56-60. Not early CKD. [pmid: 8608665].
3527 Radovancevic B, Frazier OH. Treatment of moderate heart allograft rejection with cyclosporine. Journal of Heart Transplantation. 1986;5(4):307-11. Sample size less than 50 patients. [pmid: 3114444].
3528 Ragsdale NV, Lynd M, Chevalier RL, et al. Selective peripheral dopamine-1 receptor stimulation. Differential responses to sodium loading and depletion in humans. Hypertension. 1990;15(6 Pt 2):914-21. Not CKD treatment. [pmid: 1972140].
3529 Rahman AR, Motwani JG, Lang CC, et al. Circulating angiotensin II and renal sodium handling in man: a dose-response study. Clinical Science. 1993;85(2):147-56. Sample size less than 50 patients. [pmid: 8403783].
3530 Rahman IA, Mascaro JG, Steeds RP, et al. Remote ischemic preconditioning in human coronary artery bypass surgery: from promise to disappointment. Circulation. Sep. 14. 2010;122(11 Suppl):S53-9. Not CKD treatment. [pmid: 20837926].
3531 Rahman M. Initial findings of the AASK: African Americans with hypertensive kidney disease benefit from an ACE inhibitor. Cleveland Clinic Journal of Medicine. 2003;70(4):304-5. Not relevant to key questions. [pmid: 12701984].
3532 Rahman M, El-Meanawy A, Romanello J. The African American Study of Kidney Disease: do these results indicate that 140/90 mm hg is good enough?. Current Hypertension Reports. 2005;7(5):363-6. Not relevant to key questions. [pmid: 16157080].
3533 Raimondo ML, Dagher L, Papatheodoridis GV, et al. Long-term mycophenolate mofetil monotherapy in combination with calcineurin inhibitors for chronic renal dysfunction after liver transplantation. Transplantation. 2003;75(2):186-90. Sample size less than 50 patients. [pmid: 12548120].
3534 Ralph CJ, Tanser SJ, Macnaughton PD, et al. A randomised controlled trial investigating the effects of dopexamine on gastrointestinal function and organ dysfunction in the critically ill. [Erratum appears in Intensive Care Med 2002 Jul;28(7):1001]. Intensive Care Medicine. 2002;28(7):884-90. Not CKD treatment. [pmid: 12122526].
3535 Ram CV. Ketanserin in essential hypertension. Effects of blood pressure on renal hemodynamics. American Journal of Hypertension. 1988;1(3 Pt 3):309S-11S. Follow-up less than 6 months. [pmid: 3046633].
3536 Raman GV, Campbell SK, Farrer A, et al. Modifying effects of amlodipine on cyclosporin A-induced changes in renal function in patients with psoriasis. Journal of Hypertension - Supplement. 1998;16(4):S39-41. Sample size less than 50 patients.
3537 Ramel A, Jonsson PV, Bjornsson S, et al. Differences in the glomerular filtration rate calculated by two creatinine-based and three cystatin-C-based formulae in hospitalized elderly patients. Nephron. 2008;108(1):c16-22. Not relevant to key questions. [pmid: 18075276].
3538 Ramin SM, Vidaeff AC, Yeomans ER, et al. Chronic renal disease in pregnancy. Obstetrics & Gynecology. 2006;108(6):1531-9. Not relevant to key questions. [pmid: 17138789].
3539 Ramires JA, Tsanaclis A, Gimenez HC, et al. Acute effects of dobutamine and dopamine on renal and respiratory functions in patients on prolonged mechanical ventilation. Brazilian Journal of Medical & Biological Research. 1991;24(1):35-42. Sample size less than 50 patients. [pmid: 1823215].
3540 Rammohan C, Fintel D. Dosing considerations and monitoring of low molecular weight heparins and glycoprotein IIb/IIIa antagonists in patients with renal insufficiency. Current Cardiology Reports. 2003;5(4):303-9. Not CKD treatment. [pmid: 12801450].
3541 Randell TT, Hockerstedt KA. Triiodothyronine treatment in brain-dead multiorgan donors--a controlled study. Transplantation. 1992;54(4):736-8. Sample size less than 50 patients. [pmid: 1412767].
3542 Ranganathan N, Friedman EA, Tam P, et al. Probiotic dietary supplementation in patients with stage 3 and 4 chronic kidney disease: a 6-month pilot scale trial in Canada. Current Medical Research & Opinion. 2009;25(8):1919-30. Sample size less than 50 patients. [pmid: 19558344].
3543 Ranganathan S, Krempf M, Feraille E, et al. Short term effect of an aldose reductase inhibitor on urinary albumin excretion rate (UAER) and glomerular filtration rate (GFR) in type 1 diabetic patients with incipient nephropathy. Diabete et Metabolisme. 1993;19(2):257-61. Sample size less than 50 patients. [pmid: 8339858].
3544 Rangemark C, Lind H, Lindholm L, et al. Lisinopril reduces postexercise albuminuria more effectively than atenolol in primary hypertension. European Journal of Clinical Pharmacology. 1996;49(4):267-71. Follow-up less than 6 months. [pmid: 8857071].
3545 Ranich T, Bhathena SJ, Velasquez MT. Protective effects of dietary phytoestrogens in chronic renal disease. Journal of Renal Nutrition. 2001;11(4):183-93. Not CKD treatment. [pmid: 11679998].
3546 Ranieri G, Andriani A, Lamontanara G, et al. Effects of lisinopril and amlodipine on microalbuminuria and renal function in patients with hypertension. Clinical Pharmacology & Therapeutics. 1994;56(3):323-30. Sample size less than 50 patients. [pmid: 7924128].
3547 Ranpura V, Hapani S, Chuang J, et al. Risk of cardiac ischemia and arterial thromboembolic events with the angiogenesis inhibitor bevacizumab in cancer patients: a meta-analysis of randomized controlled trials. Acta Oncologica. Apr. 2010;49(3):287-97. Not CKD treatment. [pmid: 20156114].
3548 Ranucci M, Soro G, Barzaghi N, et al. Fenoldopam prophylaxis of postoperative acute renal failure in high-risk cardiac surgery patients. Annals of Thoracic Surgery. 2004;78(4):1332-7. discussion 7-8. Not RCT or controlled trial. [pmid: 15464494].
3549 Rapini RP, Herbert AA, Drucker CR. Acquired perforating dermatosis. Evidence for combined transepidermal elimination of both collagen and elastic fibers. Archives of Dermatology. 1989;125(8):1074-8. Sample size less than 50 patients. [pmid: 2757403].
3550 Rappelli A, Dessi-Fulgheri P, Madeddu P, et al. Studies on the natriuretic effect of nifedipine in hypertensive patients: increase in levels of plasma atrial natriuretic factor without participation of the renal kallikrein-kinin system. Journal of Hypertension - Supplement. 1987;5(4):S61-5. Sample size less than 50 patients.
3551 Rasaratnam B, Kaye D, Jennings G, et al. The effect of selective intestinal decontamination on the hyperdynamic circulatory state in cirrhosis. A randomized trial. Annals of Internal Medicine. 2003;139(3):186-93. Not CKD treatment. [pmid: 12899586].
3552 Rashid ST, Salman M, Myint F, et al. Prevention of contrast-induced nephropathy in vascular patients undergoing angiography: a randomized controlled trial of intravenous N-acetylcysteine. Journal of Vascular Surgery. 2004;40(6):1136-41. Not relevant to key questions. [pmid: 15622367].
3553 Rasmussen A, Jespersen L. Reduced tubular reabsorption of phosphate during post-operative glucose infusions in humans. European Journal of Clinical Investigation. 1985;15(3):157-60. Sample size less than 50 patients. [pmid: 3926511].
3554 Rasmussen A, Kimose HH, Hessov I. Severity of postoperative hypophosphatemia in relation to glucose administration and renal handling of phosphate. Acta Chirurgica Scandinavica. 1988;154(11-12):617-21. Follow-up less than 6 months. [pmid: 3232477].
3555 Rasmussen S, Leth A, Ibsen H, et al. Converting enzyme inhibition in mild and moderate essential hypertension. II. Acta Medica Scandinavica. 1986;219(1):29-36. Sample size less than 50 patients. [pmid: 3006449].
3556 Rathod A, Badheka A, Kizilbash M, et al. Renal disease and cardiac mortality in survivors of sudden cardiac death. Acta Cardiologica. Jun. 2010;65(3):323-8. Not CKD treatment. [pmid: 20666271].
3557 Ratner RE. Diabetes control and complications. Where do we go from here?. Online Journal of Current Clinical Trials. 1993. Doc No 68:[996 words; 6 paragraphs]. Not RCT or controlled trial.
3558 Ravera M, Ratto E, Vettoretti S, et al. Prevention and treatment of diabetic nephropathy: the program for irbesartan mortality and morbidity evaluation. Journal of the American Society of Nephrology. Suppl 1. 2005;16:S48-52. Not relevant to key questions. [pmid: 15938034].
3559 Ravid M, Brosh D, Levi Z, et al. Use of enalapril to attenuate decline in renal function in normotensive, normoalbuminuric patients with type 2 diabetes mellitus. A randomized, controlled trial. Annals of Internal Medicine. 1998;128(12 Pt 1):982-8. Not relevant to key questions. [pmid: 9625684].
3560 Ravid M, Lang R, Rachmani R, et al. Long-term renoprotective effect of angiotensin-converting enzyme inhibition in non-insulin-dependent diabetes mellitus. A 7-year follow-up study. Archives of Internal Medicine. 1996;156(3):286-9. Not relevant to key questions. [pmid: 8572838].
3561 Ravid M, Neumann L, Lishner M. Plasma lipids and the progression of nephropathy in diabetes mellitus type II: effect of ACE inhibitors. Kidney International. 1995;47(3):907-10. Not CKD treatment. [pmid: 7752591].
3562 Ravid M, Savin H, Jutrin I, et al. Long-term effect of ACE inhibition on development of nephropathy in diabetes mellitus type II. Kidney International - Supplement. 1994;45:S161-4. Not relevant to key questions. [pmid: 8158887].
3563 Ravva P, Gastonguay MR, Tensfeldt TG, et al. Population pharmacokinetic analysis of varenicline in adult smokers. British Journal of Clinical Pharmacology. Nov. 2009;68(5):669-81. Not CKD treatment. [pmid: 19916991].
3564 Rayner B. Advances in the treatment of diabetic renal disease: focus on losartan. Current Medical Research & Opinion. 2004;20(3):333-40. Not RCT or controlled trial. [pmid: 15025842].
3565 Rayner BL, Trinder YA, Baines D, et al. Effect of losartan versus candesartan on uric acid, renal function, and fibrinogen in patients with hypertension and hyperuricemia associated with diuretics. American Journal of Hypertension. 2006;19(2):208-13. Follow-up less than 6 months. [pmid: 16448895].
3566 Reams G, Villarreal D, Wu Z, et al. Urinary angiotensin II: a marker of renal tissue activity?. Nephron. 1994;67(4):450-8. Not RCT or controlled trial. [pmid: 7969680].
3567 Reams GP, Bauer JH. Enalapril versus triple-drug therapy in the treatment of renovascular hypertension. Drugs. Suppl 1. 1985;30:59-69. Sample size less than 50 patients. [pmid: 2994988].
3568 Reams GP, Lau A, Bauer JH. Short-term and long-term renal response to nifedipine monotherapy. American Journal of Hypertension. 1989;2(3 Pt 1):188-90. Not CKD treatment. [pmid: 2645918].
3569 Reams GP, Lau A, Hamory A, et al. Amlodipine therapy corrects renal abnormalities encountered in the hypertensive state. American Journal of Kidney Diseases. 1987;10(6):446-51. Sample size less than 50 patients. [pmid: 2961256].
3570 Reddan D, Laville M, Garovic VD. Contrast-induced nephropathy and its prevention: What do we really know from evidence-based findings?. Journal of Nephrology. 2009;22(3):333-51. Not RCT or controlled trial. [pmid: 19557710].
3571 Reddan DN, Frankenfield DL, Klassen PS, et al. Regional variability in anaemia management and haemoglobin in the US. Nephrology Dialysis Transplantation. 2003;18(1):147-52. Not early CKD.
3572 Reddan DN, O'Shea JC, Sarembock IJ, et al. Treatment effects of eptifibatide in planned coronary stent implantation in patients with chronic kidney disease (ESPRIT Trial). American Journal of Cardiology. 2003;91(1):17-21. Follow-up less than 6 months. [pmid: 12505565].
3573 Redman BG, Flaherty L, Martino S, et al. Effect of calcium replacement on the hemodynamic changes associated with high dose interleukin-2 therapy. American Journal of Clinical Oncology. 1992;15(4):340-3. Not CKD treatment. [pmid: 1514532].
3574 Regamey F, Maillard M, Nussberger J, et al. Renal hemodynamic and natriuretic effects of concomitant Angiotensin-converting enzyme and neutral endopeptidase inhibition in men. Hypertension. 2002;40(3):266-72. Sample size less than 50 patients. [pmid: 12215465].
3575 Regazzi MB, Rinaldi M, Molinaro M, et al. Clinical pharmacokinetics of tacrolimus in heart transplant recipients. Therapeutic Drug Monitoring. 1999;21(1):2-7. Not CKD treatment. [pmid: 10051048].
3576 Reich DJ, Clavien PA, Hodge EE, et al. Mycophenolate mofetil for renal dysfunction in liver transplant recipients on cyclosporine or tacrolimus: randomized, prospective, multicenter pilot study results. Transplantation. 2005;80(1):18-25. Follow-up less than 6 months. [pmid: 16003228].
3577 Reichard P, Nilsson BY, Rosenqvist U. The effect of long-term intensified insulin treatment on the development of microvascular complications of diabetes mellitus. New England Journal of Medicine. 1993;329(5):304-9. Not early CKD. [pmid: 8147960].
3578 Reichard P, Pihl M, Rosenqvist U, et al. Complications in IDDM are caused by elevated blood glucose level: the Stockholm Diabetes Intervention Study (SDIS) at 10-year follow up. Diabetologia. 1996;39(12):1483-8. Sample size less than 50 patients. [pmid: 8960830].
3579 Reichard P, Rosenqvist U. Nephropathy is delayed by intensified insulin treatment in patients with insulin-dependent diabetes mellitus and retinopathy. Journal of Internal Medicine. 1989;226(2):81-7. Not relevant to key questions. [pmid: 2671247].
3580 Reichel H, Grussinger A, Knehans A, et al. Long-term therapy with cyclosporin A does not influence serum concentrations of vitamin D metabolites in patients with multiple sclerosis. Clinical Investigator. 1992;70(7):595-9. Not CKD treatment. [pmid: 1392429].
3581 Reichert LJ, Koene RA, Wetzels JF. Acute haemodynamic and proteinuric effects of prednisolone in patients with a nephrotic syndrome. Nephrology Dialysis Transplantation. 1999;14(1):91-7. Sample size less than 50 patients.
3582 Reid A, Stohr W, Walker AS, et al. Severe renal dysfunction and risk factors associated with renal impairment in HIV-infected adults in Africa initiating antiretroviral therapy. Clinical Infectious Diseases. 2008;46(8):1271-81. Not CKD treatment. [pmid: 18444867].
3583 Reimann IW, Golbs E, Fischer C, et al. Influence of intravenous acetylsalicylic acid and sodium salicylate on human renal function and lithium clearance. European Journal of Clinical Pharmacology. 1985;29(4):435-41. Sample size less than 50 patients. [pmid: 3912188].
3584 Reisler RB, Han C, Burman WJ, et al. Grade 4 events are as important as AIDS events in the era of HAART. Journal of Acquired Immune Deficiency Syndromes: JAIDS. 2003;34(4):379-86. Not relevant to key questions.
3585 Remuzzi G, Macia M, Ruggenenti P. Prevention and treatment of diabetic renal disease in type 2 diabetes: the BENEDICT study. Journal of the American Society of Nephrology. 2006;17(4 Suppl 2):S90-7. Sample size less than 50 patients. [pmid: 16565256].
3586 Remuzzi G, Ruggenenti P, Perna A, et al. Continuum of renoprotection with losartan at all stages of type 2 diabetic nephropathy: a post hoc analysis of the RENAAL trial results. Journal of the American Society of Nephrology. 2004;15(12):3117-25. Not relevant to key questions. [pmid: 15579515].
3587 Renke M, Knap N, Tylicki L, et al. Atorvastatin attenuates oxidative stress in patients with chronic kidney disease. Medical Science Monitor. Feb. 26. 2010;16(3):LE3. Not relevant to key questions. [pmid: 20190691].
3588 Renke M, Rutkowski P, Tylicki L, et al. Combination treatment and renal function in patients with chronic kidney disease. Journal of the Renin-Angiotensin-Aldosterone System. Jun. 2010;11(2):146-7. Not relevant to key questions. [pmid: 20223790].
3589 Renke M, Tylicki L, Knap N, et al. Spironolactone attenuates oxidative stress in patients with chronic kidney disease. Hypertension. 2008;52(5):e132-3. author reply e4. Not CKD treatment. [pmid: 18824658].
3590 Renke M, Tylicki L, Knap N, et al. High-dose angiotensin-converting enzyme inhibitor attenuates oxidative stress in patients with chronic kidney disease. Nephrology Dialysis Transplantation. 2009;24(2):689-90. Sample size less than 50 patients.
3591 Renke M, Tylicki L, Rutkowski P, et al. Effect of pentoxifylline on proteinuria, markers of tubular injury and oxidative stress in non-diabetic patients with chronic kidney disease - placebo controlled, randomized, cross-over study. Acta Biochimica Polonica. 2010;57(1):119-23. Sample size less than 50 patients. [pmid: 20309434].
3592 Renke M, Tylicki L, Rutkowski P, et al. The effect of N-acetylcysteine on proteinuria and markers of tubular injury in non-diabetic patients with chronic kidney disease. A placebo-controlled, randomized, open, cross-over study. Kidney & Blood Pressure Research. 2008;31(6):404-10. Sample size less than 50 patients. [pmid: 19092257].
3593 Renke M, Tylicki L, Rutkowski P, et al. The effect of N-acetylcysteine on blood pressure and markers of cardiovascular risk in non-diabetic patients with chronic kidney disease: a placebo-controlled, randomized, cross-over study. Medical Science Monitor. 2010;16(7):PI13-8. Sample size less than 50 patients. [pmid: 20581787].
3594 Renke M, Tylicki L, Rutkowski P, et al. Low-dose dual blockade of the renin-angiotensin system improves tubular status in non-diabetic proteinuric patients. Scandinavian Journal of Urology & Nephrology. 2005;39(6):511-7. Not CKD treatment. [pmid: 16303729].
3595 Reriani M, Raichlin E, Prasad A, et al. Long-term administration of endothelin receptor antagonist improves coronary endothelial function in patients with early atherosclerosis. Circulation. Sep. 7. 2010;122(10):958-66. Not CKD treatment. [pmid: 20733096].
3596 Resnick B, Sabol V, Galik E, et al. The impact of anemia on nursing home residents. Clinical Nursing Research. May. 2010;19(2):113-30. Not CKD treatment. [pmid: 20185805].
3597 Reuse C, Leeman M, Degaute JP, et al. Preserved renal perfusion during beta blockade by tertatolol with and without cyclooxygenase inhibition in normal humans. Journal of Clinical Pharmacology. 1988;28(4):312-6. Sample size less than 50 patients. [pmid: 3134468].
3598 Revicki DA. Relationship between health utility and psychometric health status measures. Medical Care. 1992;30(5 Suppl):MS274-82. Not CKD treatment. [pmid: 1583939].
3599 Revicki DA, Brown RE, Feeny DH, et al. Health-related quality of life associated with recombinant human erythropoietin therapy for predialysis chronic renal disease patients. American Journal of Kidney Diseases. 1995;25(4):548-54. Not CKD treatment. [pmid: 7702049].
3600 Rexrode KM, Buring JE, Glynn RJ, et al. Analgesic use and renal function in men. JAMA. 2001;286(3):315-21. Not RCT or controlled trial. [pmid: 11466097].
3601 Reyes AJ. Effects of diuretics on renal excretory function. European Heart Journal. Suppl G. 1992;13:15-21. Follow-up less than 6 months. [pmid: 1486900].
3602 Ribeiro AB. Angiotensin II antagonists--therapeutic benefits spanning the cardiovascular disease continuum from hypertension to heart failure and diabetic nephropathy. Current Medical Research & Opinion. 2006;22(1):1-16. Sample size less than 50 patients. [pmid: 16393425].
3603 Ribeiro AB, Gavras H. Angiotensin II antagonists: clinical experience in the treatment of hypertension, prevention of cardiovascular outcomes and renal protection in diabetic nephropathy and proteinuria. Arquivos Brasileiros de Endocrinologia e Metabologia. 2006;50(2):327-33. Sample size less than 50 patients. [pmid: 16767299].
3604 Riben PD, Horsman GB, Rayner E, et al. Emergence of tobramycin-resistant S. epidermidis possessing aminoglycoside modifying enzymes and bacteremic superinfection during empiric therapy of febrile neutropenic episodes. Clinical & Investigative Medicine - Medecine Clinique et Experimentale. 1985;8(4):272-85. Sample size less than 50 patients. [pmid: 3907919].
3605 Ribstein J, Codis P, duCailar G, et al. Effects of captopril and nitrendipine on the response to acute volume expansion in essential hypertension. Journal of Hypertension - Supplement. 1988;6(4):S473-5. Sample size less than 50 patients.
3606 Ribstein J, Du Cailar G, Brouard R, et al. Comparative renal and cardiac effects of tertatolol and enalapril in essential hypertension. Cardiology. Suppl 1. 1993;83:57-63. Follow-up less than 6 months. [pmid: 7903217].
3607 Ricci Z, Ronco C. ‘Renal-dose’ fenoldopam for early-stage renal dysfunction in critically ill patients. Nature Clinical Practice Nephrology. 2006;2(10):548-9. Not CKD treatment.
3608 Richards AM, Crozier IG, Espiner EA, et al. Acute inhibition of endopeptidase 24.11 in essential hypertension: SCH 34826 enhances atrial natriuretic peptide and natriuresis without lowering blood pressure. Journal of Cardiovascular Pharmacology. 1992;20(5):735-41. Sample size less than 50 patients. [pmid: 1280735].
3609 Richards AM, Espiner EA, Ikram H, et al. Atrial natriuretic factor in hypertension: bioactivity at normal plasma levels. Hypertension. 1989;14(3):261-8. Sample size less than 50 patients. [pmid: 2527819].
3610 Richards AM, Nicholls MG, Espiner EA, et al. Effects of alpha-human atrial natriuretic peptide in essential hypertension. Hypertension. 1985;7(5):812-7. Sample size less than 50 patients. [pmid: 3161825].
3611 Richards AM, Tonolo G, Montorsi P, et al. Low dose infusions of 26- and 28-amino acid human atrial natriuretic peptides in normal man. Journal of Clinical Endocrinology & Metabolism. 1988;66(3):465-72. Sample size less than 50 patients. [pmid: 2965159].
3612 Richards AM, Wittert G, Espiner EA, et al. Prolonged inhibition of endopeptidase 24.11 in normal man: renal, endocrine and haemodynamic effects. Journal of Hypertension. 1991;9(10):955-62. Not CKD treatment. [pmid: 1658138].
3613 Richards AM, Wittert GA, Crozier IG, et al. Chronic inhibition of endopeptidase 24.11 in essential hypertension: evidence for enhanced atrial natriuretic peptide and angiotensin II. Journal of Hypertension. 1993;11(4):407-16. Follow-up less than 6 months. [pmid: 8390508].
3614 Richards M, Espiner E, Frampton C, et al. Inhibition of endopeptidase EC 24.11 in humans. Renal and endocrine effects. Hypertension. 1990;16(3):269-76. Sample size less than 50 patients. [pmid: 2144260].
3615 Richer M, Robert S, Lebel M. Renal hemodynamics during norepinephrine and low-dose dopamine infusions in man. Critical Care Medicine. 1996;24(7):1150-6. Sample size less than 50 patients. [pmid: 8674327].
3616 Richmond H, Zwerner J, Kim Y, et al. Nephrogenic systemic fibrosis: relationship to gadolinium and response to photopheresis. [Erratum appears in Arch Dermatol. 2007 Dec;143(12):1565]. Archives of Dermatology. 2007;143(8):1025-30. Follow-up less than 6 months. [pmid: 17709661].
3617 Riechers G, Futerova M, Hanisch M, et al. Effects of muzolimine and of a combination of hydrochlorothiazide/triamterene in healthy subjects and in nephrotic patients. Zeitschrift fur Kardiologie. Suppl 2. 1985;74:103-8. Follow-up less than 6 months. [pmid: 4002782].
3618 Riedl M, Hass M, Oberbauer R, et al. The effects of prolonged substitution of recombinant human growth hormone on renal functional reserve in growth hormone-deficient adults. Journal of the American Society of Nephrology. 1995;6(5):1434-8. Not CKD treatment. [pmid: 8589319].
3619 Riegger GA, Kahles HW, Elsner D, et al. Effects of acetylsalicylic acid on renal function in patients with chronic heart failure. American Journal of Medicine. 1991;90(5):571-5. Not CKD treatment. [pmid: 2029014].
3620 Righetti M. Hopeful for a second HOPE-2 post hoc analysis. Nephrology Dialysis Transplantation. 2008;23(7):2428-9. author reply 9-30. Not relevant to key questions.
3621 Righetti M. Protective effect of vitamin B therapy on bone and cardiovascular disease. Recent Patents on Cardiovascular Drug Discovery. 2009;4(1):37-44. Not human studies. [pmid: 19149705].
3622 Rigler R, Pramanik A, Jonasson P, et al. Specific binding of proinsulin C-peptide to human cell membranes. Proceedings of the National Academy of Sciences of the United States of America. 1999;96(23):13318-23. Not CKD treatment. [pmid: 10557318].
3623 Rinaldi M, Pellegrini C, Martinelli L, et al. FK506 effectiveness in reducing acute rejection after heart transplantation: a prospective randomized study. Journal of Heart & Lung Transplantation. 1997;16(10):1001-10. Sample size less than 50 patients. [pmid: 9361242].
3624 Rinaldi S, Adembri C, Grechi S, et al. Low-dose hydrocortisone during severe sepsis: effects on microalbuminuria. Critical Care Medicine. 2006;34(9):2334-9. Not CKD treatment. [pmid: 16850006].
3625 Ring-Larsen H, Henriksen JH, Wilken C, et al. Diuretic treatment in decompensated cirrhosis and congestive heart failure: effect of posture. British Medical Journal Clinical Research Ed. 1986;292(6532):1351-3. Sample size less than 50 patients. [pmid: 3085844].
3626 Ripley E. Complementary effects of angiotensin-converting enzyme inhibitors and angiotensin receptor blockers in slowing the progression of chronic kidney disease. American Heart Journal. 2009;157(6 Suppl):S7-S16. Not early CKD. [pmid: 19450722].
3627 Rippin J, Bain SC, Barnett AH, et al. Rationale and design of diabetics exposed to telmisartan and enalapril (DETAIL) study. Journal of Diabetes & its Complications. 2002;16(3):195-200. Not RCT or controlled trial. [pmid: 12015188].
3628 Ristikankare A, Kuitunen T, Kuitunen A, et al. Lack of renoprotective effect of i.v. N-acetylcysteine in patients with chronic renal failure undergoing cardiac surgery. British Journal of Anaesthesia. 2006;97(5):611-6. Not CKD treatment. [pmid: 16914459].
3629 Ritchie C, Ekundayo OJ, Muchimba M, et al. Effects of diabetes mellitus in patients with heart failure and chronic kidney disease: a propensity-matched study of multimorbidity in chronic heart failure. International Journal of Cardiology. 2009;134(3):330-5. Not RCT or controlled trial. [pmid: 19178965].
3630 Ritchie C, Ekundayo OJ, Muchimba M, et al. Effects of diabetes mellitus in patients with heart failure and chronic kidney disease: a propensity-matched study of multimorbidity in chronic heart failure. [Erratum appears in Int J Cardiol. 2010 Jan 7;138(1):106]. International Journal of Cardiology. 2009;134(3):330-5. Not CKD treatment. [pmid: 19178965].
3631 Ritter JM, Ludgin JR, Scharschmidt LA, et al. Effects of a stable prostaglandin analogue, L-644,122, in healthy and hypertensive men. European Journal of Clinical Pharmacology. 1985;28(6):685-8. Sample size less than 50 patients. [pmid: 4065193].
3632 Ritz E. Should all patients with chronic kidney disease take a statin? A commentary to a meta-analysis of randomized control trials. Polskie Archiwum Medycyny Wewnetrznej. 2008;118(10):541-2. Not CKD treatment. [pmid: 19112813].
3633 Ritz E, Kuster S, Schmidt-Gayk H, et al. Low-dose calcitriol prevents the rise in 1,84-iPTH without affecting serum calcium and phosphate in patients with moderate renal failure (prospective placebo-controlled multicentre trial). Nephrology Dialysis Transplantation. 1995;10(12):2228-34. Sample size less than 50 patients.
3634 Ritz E, Laville M, Bilous RW, et al. Target level for hemoglobin correction in patients with diabetes and CKD: primary results of the Anemia Correction in Diabetes (ACORD) Study. [Erratum appears in Am J Kidney Dis. 2007 Apr;49(4):562]. American Journal of Kidney Diseases. 2007;49(2):194-207. Not RCT or controlled trial. [pmid: 17261422].
3635 Ritz E, Rychlik I, Miltenberger-Miltenyi G. Optimizing antihypertensive therapy in patients with diabetic nephropathy. Journal of Hypertension - Supplement. 1998;16(7):S17-22. Not RCT or controlled trial.
3636 Ritz E, Rychlik I, Schomig M, et al. Blood pressure in diabetic nephropathy--current controversies. Journal of Internal Medicine. 2001;249(3):215-23. Not relevant to key questions. [pmid: 11293432].
3637 Ritz E, Schmieder RE, Pollock CA. Renal protection in diabetes: lessons from ONTARGET. Cardiovascular Diabetology. 2010;9:60. Not RCT or controlled trial. [pmid: 20920303].
3638 Ritz E, Viberti GC, Ruilope LM, et al. Determinants of urinary albumin excretion within the normal range in patients with type 2 diabetes: the Randomised Olmesartan and Diabetes Microalbuminuria Prevention (ROADMAP) study. Diabetologia. Jan. 2010;53(1):49-57. Not CKD treatment. [pmid: 19876613].
3639 Rius F, Pizarro E, Castells I, et al. Renal function changes in hypertensive patients with non-insulin- dependent diabetes mellitus. Kidney International - Supplement. 1996;55:S88-90. Not RCT or controlled trial. [pmid: 8743520].
3640 Rix M, Eskildsen P, Olgaard K. Effect of 18 months of treatment with alfacalcidol on bone in patients with mild to moderate chronic renal failure. Nephrology Dialysis Transplantation. 2004;19(4):870-6. Not CKD treatment.
3641 Rizos CV, Elisaf MS, Liberopoulos EN. Are the pleiotropic effects of telmisartan clinically relevant?. Current Pharmaceutical Design. 2009;15(24):2815-32. Not RCT or controlled trial. [pmid: 19689352].
3642 Rizos E, Bairaktari E, Ganotakis E, et al. Effect of ciprofibrate on lipoproteins, fibrinogen, renal function, and hepatic enzymes. Journal of Cardiovascular Pharmacology & Therapeutics. 2002;7(4):219-26. Not CKD treatment. [pmid: 12490967].
3643 Rizzoni D, Porteri E, Boari GEM, et al. Prognostic significance of small-artery structure in hypertension. Circulation. 2003;108(18):2230-5. Not CKD treatment. [pmid: 14557363].
3644 Roberto AJ, Krieger JL, Beam MA. Enhancing web-based kidney disease prevention messages for Hispanics using targeting and tailoring. Journal of Health Communication. 2009;14(6):525-40. Not RCT or controlled trial. [pmid: 19731125].
3645 Roberts DG, Gerber JG, Barnes JS, et al. Sulindac is not renal sparing in man. Clinical Pharmacology & Therapeutics. 1985;38(3):258-65. Sample size less than 50 patients. [pmid: 4028619].
3646 Roberts JT. Chemotherapy for metastatic bladder cancer. Clinical Oncology. 2005;17(7):514-23. Not CKD treatment. [pmid: 16238139].
3647 Roberts JT, Ali HH, Shorten GD. Using the bubble inclinometer to measure laryngeal tilt and predict difficulty of laryngoscopy. Journal of Clinical Anesthesia. 1993;5(4):306-9. Not CKD treatment. [pmid: 8373609].
3648 Roberts JT, Ali HH, Shorten GD. Using the laryngeal indices caliper to predict difficulty of laryngoscopy with a Macintosh #3 laryngoscope. Journal of Clinical Anesthesia. 1993;5(4):302-5. Not CKD treatment. [pmid: 8373608].
3649 Roberts MA, Hare DL. JUPITER “moderate CKD” subgroup is not truly “moderate” chronic kidney disease. Journal of the American College of Cardiology. Aug. 3. 2010;56(6):528. author reply 30. Not RCT or controlled trial. [pmid: 20670769].
3650 Roberts WL, Calcote CB, Cook CB, et al. Comparison of four commercial urinary albumin (microalbumin) methods: implications for detecting diabetic nephropathy using random urine specimens. Clinica Chimica Acta. 1998;273(1):21-33. Not RCT or controlled trial.
3651 Robertson L, Waugh N, Robertson A. Protein restriction for diabetic renal disease. Cochrane Database of Systematic Reviews. 2007;(4):CD002181. Not early CKD. [pmid: 17943769].
3652 Robiner WN, Yozwiak JA, Bearman DL, et al. Barriers to clinical research participation in a diabetes randomized clinical trial. Social Science & Medicine. 2009;68(6):1069-74. Follow-up less than 6 months. [pmid: 19167143].
3653 Robinson T, Gariballa S, Fancourt G, et al. The acute effects of a single dopamine infusion in elderly patients with congestive cardiac failure. British Journal of Clinical Pharmacology. 1994;37(3):261-3. Not CKD treatment. [pmid: 8198935].
3654 Robinson TM, Sewell DA, Casey A, et al. Dietary creatine supplementation does not affect some haematological indices, or indices of muscle damage and hepatic and renal function. British Journal of Sports Medicine. 2000;34(4):284-8. Sample size less than 50 patients. [pmid: 10953902].
3655 Robson R. The use of bivalirudin in patients with renal impairment. Journal of Invasive Cardiology. Suppl F. 2000;12:33F-6. Not RCT or controlled trial.
3656 Robson RA, Bridgman PG, Wells JE, et al. The effect of celiprolol on glomerular filtration rate and renal blood flow in patients with chronic renal impairment and healthy volunteers. British Journal of Clinical Pharmacology. 1992;33(4):454-7. Sample size less than 50 patients. [pmid: 1349496].
3657 Roca-Cusachs A, Triposkiadis F. Antihypertensive effect of manidipine. Drugs. Suppl 2. 2005;65:11-9. Not RCT or controlled trial. [pmid: 16398058].
3658 Rocco MV, Gassman JJ, Wang SR, et al. Cross-sectional study of quality of life and symptoms in chronic renal disease patients: the Modification of Diet in Renal Disease Study. American Journal of Kidney Diseases. 1997;29(6):888-96. Not RCT or controlled trial. [pmid: 9186075].
3659 Rocco S, Opocher G, Carpene G, et al. Atrial natriuretic peptide infusion in primary aldosteronism. Renal, hemodynamic and hormonal effects. American Journal of Hypertension. 1990;3(9):668-73. Not CKD treatment. [pmid: 2145872].
3660 Rocha R, Funder JW. The pathophysiology of aldosterone in the cardiovascular system. Annals of the New York Academy of Sciences. 2002;970:89-100. Not CKD treatment. [pmid: 12381544].
3661 Rock G, Shumak K, Kelton J, et al. Thrombotic thrombocytopenic purpura: outcome in 24 patients with renal impairment treated with plasma exchange. Canadian Apheresis Study Group. Transfusion. 1992;32(8):710-4. Not CKD treatment. [pmid: 1412677].
3662 Rockemann MG, Seeling W, Bischof C, et al. Prophylactic use of epidural mepivacaine/morphine, systemic diclofenac, and metamizole reduces postoperative morphine consumption after major abdominal surgery. Anesthesiology. 1996;84(5):1027-34. Not CKD treatment. [pmid: 8623995].
3663 Rodby RA, Ali A, Rohde RD, et al. Renal scanning 99mTc diethylene-triamine pentaacetic acid glomerular filtration rate (GFR) determination compared with iothalamate clearance GFR in diabetics. The Collaborative Study Group for The study of Angiotensin-Converting Enzyme Inhibition in Diabetic Nephropathy. American Journal of Kidney Diseases. 1992;20(6):569-73. Not CKD treatment. [pmid: 1462984].
3664 Rodby RA, Chiou CF, Borenstein J, et al. The cost-effectiveness of irbesartan in the treatment of hypertensive patients with type 2 diabetic nephropathy. Clinical Therapeutics. 2003;25(7):2102-19. Not relevant to key questions. [pmid: 12946554].
3665 Rodby RA, Firth LM, Lewis EJ. An economic analysis of captopril in the treatment of diabetic nephropathy. The Collaborative Study Group. Diabetes Care. 1996;19(10):1051-61. Not CKD treatment. [pmid: 8886549].
3666 Rodby RA, Rohde R, Evans J, et al. The study of the effect of intensity of blood pressure management on the progression of type 1 diabetic nephropathy: study design and baseline patient characteristics. Collaborative Study Group. Journal of the American Society of Nephrology. 1995;5(10):1775-81. Not relevant to key questions. [pmid: 7787145].
3667 Rodby RA, Rohde RD, Clarke WR, et al. The Irbesartan type II diabetic nephropathy trial: study design and baseline patient characteristics. For the Collaborative Study Group. Nephrology Dialysis Transplantation. 2000;15(4):487-97. Not RCT or controlled trial.
3668 Roderick PJ, Atkins RJ, Smeeth L, et al. Detecting chronic kidney disease in older people; what are the implications?. [Erratum appears in Age Ageing. 2009 Sep;38(5):638 Note: Flectcher, Astrid E [corrected to Fletcher, Astrid E]]. Age & Ageing. 2008;37(2):179-86. Follow-up less than 6 months. [pmid: 18083723].
3669 Rodicio JL. Does antihypertensive therapy protect the kidney in essential hypertension?. Journal of Hypertension - Supplement. 1996;14(2):S69-75. discussion S-6. Not RCT or controlled trial.
3670 Rodjer S, Alestig K, Bergmark J, et al. Treatment of septicaemia in immunocompromised patients with ceftazidime or with tobramycin and cefuroxime, with special reference to renal effects. Journal of Antimicrobial Chemotherapy. 1987;20(1):109-16. Not relevant to key questions. [pmid: 3305460].
3671 Rodondi LC, Flaherty JF, Schoenfeld P, et al. Influence of coadministration on the pharmacokinetics of mezlocillin and cefotaxime in healthy volunteers and in patients with renal failure. Clinical Pharmacology & Therapeutics. 1989;45(5):527-34. Sample size less than 50 patients. [pmid: 2721108].
3672 Rodondi N, Yerly P, Gabriel A, et al. Microalbuminuria, but not cystatin C, is associated with carotid atherosclerosis in middle-aged adults. Nephrology Dialysis Transplantation. 2007;22(4):1107-14. Follow-up less than 6 months.
3673 Rodriguez-Iturbe B, Herrera J, Garcia R. Relationship between glomerular filtration rate and renal blood flow at different levels of protein-induced hyperfiltration in man. Clinical Science. 1988;74(1):11-5. Sample size less than 50 patients. [pmid: 3338249].
3674 Rodriguez-Iturbe B, Herrera J, Gutkowska J, et al. Atrial natriuretic factor increases after a protein meal in man. Clinical Science. 1988;75(5):495-8. Sample size less than 50 patients. [pmid: 2978287].
3675 Rodriguez-Moran M, Gonzalez-Gonzalez G, Bermudez-Barba MV, et al. Effects of pentoxifylline on the urinary protein excretion profile of type 2 diabetic patients with microproteinuria: a double-blind, placebo-controlled randomized trial. Clinical Nephrology. 2006;66(1):3-10. Sample size less than 50 patients. [pmid: 16878429].
3676 Rodriguez-Moran M, Guerrero-Romero F. Pentoxifylline is as effective as captopril in the reduction of microalbuminuria in non-hypertensive type 2 diabetic patients--a randomized, equivalent trial. Clinical Nephrology. 2005;64(2):91-7. Not CKD treatment. [pmid: 16114784].
3677 Rodriquez A, Martin A, Oterino JA, et al. Renal function in compensated hepatic cirrhosis: effects of an amino acid infusion and relationship with nitric acid. Digestive Diseases. 1999;17(4):235-40. Not early CKD. [pmid: 10754364].
3678 Roehrborn CG. Acute relief or future prevention: is urology ready for preventive health care?. Urology. 2000;56(5 Suppl 1):12-9. Not early CKD. [pmid: 11074197].
3679 Roelen DL, Frolich M, Papapoulos SE. Renal responsiveness to synthetic human parathyroid hormone 1-38 in healthy subjects. European Journal of Clinical Investigation. 1989;19(3):311-5. Sample size less than 50 patients. [pmid: 2553425].
3680 Roger SD, Levin A. Epoetin trials: randomised controlled trials don't always mimic observational data. Nephrology Dialysis Transplantation. 2007;22(3):684-6. Follow-up less than 6 months.
3681 Roger SD, McMahon LP, Clarkson A, et al. Effects of early and late intervention with epoetin alpha on left ventricular mass among patients with chronic kidney disease (stage 3 or 4): results of a randomized clinical trial. Journal of the American Society of Nephrology. 2004;15(1):148-56. Not CKD treatment. [pmid: 14694167].
3682 Roger SD, Suranyi MG, Walker RG, et al. A randomised, cross-over study comparing injection site pain with subcutaneous epoetin beta and subcutaneous darbepoetin alfa in patients with chronic kidney disease. Current Medical Research & Opinion. 2008;24(8):2181-7. Not CKD treatment. [pmid: 18565240].
3683 Rogers NM, Coates PTH. Calcific uraemic arteriolopathy: an update. Current Opinion in Nephrology & Hypertension. 2008;17(6):629-34. Not CKD treatment. [pmid: 18941358].
3684 Roglic G, Colhoun HM, Stevens LK, et al. Parental history of hypertension and parental history of diabetes and microvascular complications in insulin-dependent diabetes mellitus: the EURODIAB IDDM Complications Study. Diabetic Medicine. 1998;15(5):418-26. Not RCT or controlled trial. [pmid: 9609365].
3685 Rohrer JE. Outcomes research in nephrology. Seminars in Nephrology. 2003;23(3):250-4. Not CKD treatment. [pmid: 12838493].
3686 Rojanasthien N, Kumsorn B, Atikachai B, et al. Protective effects of fosfomycin on cisplatin-induced nephrotoxicity in patients with lung cancer. International Journal of Clinical Pharmacology & Therapeutics. 2001;39(3):121-5. Not early CKD. [pmid: 11396752].
3687 Rokoss MJ, Teo KK. Ramipril in the treatment of vascular diseases. Expert Opinion on Pharmacotherapy. 2005;6(11):1911-9. Not relevant to key questions. [pmid: 16144510].
3688 Rolleman EJ, Valkema R, de Jong M, et al. Safe and effective inhibition of renal uptake of radiolabelled octreotide by a combination of lysine and arginine. European Journal of Nuclear Medicine & Molecular Imaging. 2003;30(1):9-15. Not CKD treatment. [pmid: 12483404].
3689 Romanelli G, Giustina A, Agabiti-Rosei E, et al. Short-term effect of captopril and nifedipine on micro-albuminuria induced by exercise in hypertensive diabetic patients. Journal of Hypertension - Supplement. 1989;7(6):S312-3. Sample size less than 50 patients.
3690 Romanelli G, Giustina A, Bossoni S, et al. Short-term administration of captopril and nifedipine and exercise-induced albuminuria in normotensive diabetic patients with early-stage nephropathy. Diabetes. 1990;39(11):1333-8. Follow-up less than 6 months. [pmid: 2227107].
3691 Romanelli G, Giustina A, Cimino A, et al. Short term effect of captopril on microalbuminuria induced by exercise in normotensive diabetics. BMJ. 1989;298(6669):284-8. Follow-up less than 6 months. [pmid: 2493897].
3692 Romanelli G, Giustina A, Cravarezza P, et al. Albuminuria induced by exercise in hypertensive type I and type II diabetic patients: a randomised, double-blind study on the effects of acute administration of captopril and nifedipine. Journal of Human Hypertension. 1991;5(3):167-73. Sample size less than 50 patients. [pmid: 1920340].
3693 Romero R, Salinas I, Lucas A, et al. Renal function changes in microalbuminuric normotensive type II diabetic patients treated with angiotensin-converting enzyme inhibitors. Diabetes Care. 1993;16(4):597-600. Sample size less than 50 patients. [pmid: 8462386].
3694 Romero R, Salinas I, Lucas A, et al. Comparative effects of captopril versus nifedipine on proteinuria and renal function of type 2 diabetic patients. Diabetes Research & Clinical Practice. 1992;17(3):191-8. Sample size less than 50 patients. [pmid: 1425158].
3695 Romundstad S, Holmen J, Hallan H, et al. Microalbuminuria, cardiovascular disease and risk factors in a nondiabetic/nonhypertensive population. The Nord-Trondelag Health Study (HUNT, 1995-97), Norway. Journal of Internal Medicine. 2002;252(2):164-72. Not CKD treatment. [pmid: 12190892].
3696 Romundstad S, Holmen J, Kvenild K, et al. Clinical relevance of microalbuminuria screening in self-reported non-diabetic/non-hypertensive persons identified in a large health screening--the Nord-Trondelag Health Study (HUNT), Norway. Clinical Nephrology. 2003;59(4):241-51. Not CKD treatment. [pmid: 12708563].
3697 Ronco C, Bellomo R. Prevention of acute renal failure in the critically ill. Nephron. 2003;93(1):C13-20. Not CKD treatment. [pmid: 12411754].
3698 Rooke GA, Ebert T, Muzi M, et al. The hemodynamic and renal effects of sevoflurane and isoflurane in patients with coronary artery disease and chronic hypertension. Sevoflurane Ischemia Study Group. Anesthesia & Analgesia. 1996;82(6):1159-65. Not CKD treatment. [pmid: 8638784].
3699 Roozbeh J, Banihashemi MA, Ghezlou M, et al. Captopril and combination therapy of captopril and pentoxifylline in reducing proteinuria in diabetic nephropathy. Renal Failure. Jan. 2010;32(2):172-8. Not relevant to key questions. [pmid: 20199178].
3700 Rosa EM, Viecceli C Jr. Interesting findings in the VALERIA trial. Journal of Hypertension. 2009;27(4):902. author reply -3. Not CKD treatment. [pmid: 19300116].
3701 Rose GW, Kanno Y, Ikebukuro H, et al. Cilnidipine is as effective as benazepril for control of blood pressure and proteinuria in hypertensive patients with benign nephrosclerosis. Hypertension Research - Clinical & Experimental. 2001;24(4):377-83. Sample size less than 50 patients.
3702 Rose PG. Amifostine cytoprotection with chemotherapy for advanced ovarian carcinoma. Seminars in Oncology. 1996;23(4 Suppl 8):83-9. Not CKD treatment. [pmid: 8783673].
3703 Rosei EA, Rizzoni D, Muiesan ML, et al. Effects of candesartan cilexetil and enalapril on inflammatory markers of atherosclerosis in hypertensive patients with non-insulin-dependent diabetes mellitus. Journal of Hypertension. 2005;23(2):435-44. Follow-up less than 6 months. [pmid: 15662233].
3704 Rosenberg ME, Hostetter TH. Comparative effects of antihypertensives on proteinuria: angiotensin-converting enzyme inhibitor versus alpha 1-antagonist. American Journal of Kidney Diseases. 1991;18(4):472-82. Sample size less than 50 patients. [pmid: 1656730].
3705 Rosenberg PH, Veering BT, Urmey WF. Maximum recommended doses of local anesthetics: a multifactorial concept. Regional Anesthesia & Pain Medicine. 2004;29(6):564-75. discussion 24. Not RCT or controlled trial. [pmid: 15635516].
3706 Rosenstock JL, Bruno R, Kim JK, et al. The effect of withdrawal of ACE inhibitors or angiotensin receptor blockers prior to coronary angiography on the incidence of contrast-induced nephropathy. International Urology & Nephrology. 2008;40(3):749-55. Not CKD treatment. [pmid: 18438718].
3707 Rosenthal JH. Therapeutic experience with cilazapril. Journal of Cardiovascular Pharmacology. Suppl 2. 1994;24:S65-9. Not RCT or controlled trial. [pmid: 7898097].
3708 Rosman JB, Donker-Willenborg MA. Dietary compliance and its assessment in the Groningen trial on protein restriction in renal failure. Contributions to Nephrology. 1990;81:95-101. Not RCT or controlled trial. [pmid: 2093518].
3709 Rosman JB, ter Wee PM, Piers-Becht GP, et al. Early protein restriction in chronic renal failure. Proceedings of the European Dialysis & Transplant Association - European Renal Association. 1985;21:567-73. Not CKD treatment. [pmid: 3887375].
3710 Rossat J, Maillard M, Nussberger J, et al. Renal effects of selective cyclooxygenase-2 inhibition in normotensive salt-depleted subjects. Clinical Pharmacology & Therapeutics. 1999;66(1):76-84. Sample size less than 50 patients. [pmid: 10430112].
3711 Rosseel PM, Santman FW, Bouter H, et al. Postcardiac surgery low cardiac output syndrome: dopexamine or dopamine?. Intensive Care Medicine. 1997;23(9):962-8. Not CKD treatment. [pmid: 9347368].
3712 Rossert J, Fouqueray B, Boffa JJ. Anemia management and the delay of chronic renal failure progression. Journal of the American Society of Nephrology. 2003;14(7 Suppl 2):S173-7. Not relevant to key questions. [pmid: 12819324].
3713 Rossert J, Froissart M. Role of anemia in progression of chronic kidney disease. Seminars in Nephrology. 2006;26(4):283-9. Not RCT or controlled trial. [pmid: 16949466].
3714 Rossert J, Froissart M, Jacquot C. Anemia management and chronic renal failure progression. Kidney International - Supplement. 2005;(99):S76-81. Not relevant to key questions. [pmid: 16336582].
3715 Rossert J, Gassmann-Mayer C, Frei D, et al. Prevalence and predictors of epoetin hyporesponsiveness in chronic kidney disease patients. Nephrology Dialysis Transplantation. 2007;22(3):794-800. Not RCT or controlled trial.
3716 Rossert J, Levin A, Roger SD, et al. Effect of early correction of anemia on the progression of CKD. American Journal of Kidney Diseases. 2006;47(5):738-50. Sample size less than 50 patients. [pmid: 16632012].
3717 Rossert JA, McClellan WM, Roger SD, et al. Contribution of anaemia to progression of renal disease: a debate. Nephrology Dialysis Transplantation. Suppl 1. 2002;17:60-6. Not RCT or controlled trial.
3718 Rossing K, Christensen PK, Andersen S, et al. Comparative effects of Irbesartan on ambulatory and office blood pressure: a substudy of ambulatory blood pressure from the Irbesartan in Patients with Type 2 Diabetes and Microalbuminuria study. Diabetes Care. 2003;26(3):569-74. Sample size less than 50 patients. [pmid: 12610003].
3719 Rossing K, Christensen PK, Hansen BV, et al. Optimal dose of candesartan for renoprotection in type 2 diabetic patients with nephropathy: a double-blind randomized cross-over study. Diabetes Care. 2003;26(1):150-5. Sample size less than 50 patients. [pmid: 12502672].
3720 Rossing K, Christensen PK, Jensen BR, et al. Dual blockade of the renin-angiotensin system in diabetic nephropathy: a randomized double-blind crossover study. Diabetes Care. 2002;25(1):95-100. Sample size less than 50 patients. [pmid: 11772908].
3721 Rossing K, Jacobsen P, Pietraszek L, et al. Renoprotective effects of adding angiotensin II receptor blocker to maximal recommended doses of ACE inhibitor in diabetic nephropathy: a randomized double-blind crossover trial. Diabetes Care. 2003;26(8):2268-74. Sample size less than 50 patients. [pmid: 12882847].
3722 Rossing K, Mischak H, Parving HH, et al. Impact of diabetic nephropathy and angiotensin II receptor blockade on urinary polypeptide patterns. Kidney International. 2005;68(1):193-205. Not relevant to key questions. [pmid: 15954909].
3723 Rossing K, Schjoedt KJ, Jensen BR, et al. Enhanced renoprotective effects of ultrahigh doses of irbesartan in patients with type 2 diabetes and microalbuminuria. Kidney International. 2005;68(3):1190-8. Follow-up less than 6 months. [pmid: 16105050].
3724 Rossing K, Schjoedt KJ, Smidt UM, et al. Beneficial effects of adding spironolactone to recommended antihypertensive treatment in diabetic nephropathy: a randomized, double-masked, cross-over study. Diabetes Care. 2005;28(9):2106-12. Follow-up less than 6 months. [pmid: 16123474].
3725 Rossing P, Hansen BV, Nielsen FS, et al. Fish oil in diabetic nephropathy. Diabetes Care. 1996;19(11):1214-9. Sample size less than 50 patients. [pmid: 8908382].
3726 Rossing P, Tarnow L, Boelskifte S, et al. Differences between nisoldipine and lisinopril on glomerular filtration rates and albuminuria in hypertensive IDDM patients with diabetic nephropathy during the first year of treatment. Diabetes. 1997;46(3):481-7. Not relevant to key questions. [pmid: 9032106].
3727 Roth D, Smith RD, Schulman G, et al. Effects of recombinant human erythropoietin on renal function in chronic renal failure predialysis patients. American Journal of Kidney Diseases. 1994;24(5):777-84. Not early CKD. [pmid: 7977319].
3728 Rothele E, Krumme B, Rump LC. Design of the prospective randomized study for the treatment of patients with thrombotic microangiopathy. PRODROMI Study Group. Therapeutic Apheresis. 2000;4(5):327-31. Not early CKD. [pmid: 11111812].
3729 Rother KI, Brown RJ, Morales MM, et al. Effect of ingested interferon-alpha on beta-cell function in children with new-onset type 1 diabetes. [Erratum appears in Diabetes Care. 2009 Sep;32(9):1751]. Diabetes Care. 2009;32(7):1250-5. Not CKD treatment. [pmid: 19564474].
3730 Rousso P, Buclin T, Nussberger J, et al. Effects of a dual inhibitor of angiotensin converting enzyme and neutral endopeptidase, MDL 100,240, on endocrine and renal functions in healthy volunteers. Journal of Hypertension. 1999;17(3):427-37. Follow-up less than 6 months. [pmid: 10100082].
3731 Rozen-Zvi B, Gafter-Gvili A, Paul M, et al. Intravenous versus oral iron supplementation for the treatment of anemia in CKD: systematic review and meta-analysis. American Journal of Kidney Diseases. 2008;52(5):897-906. Not CKD treatment. [pmid: 18845368].
3732 Ruben EC, Manuel VR, Agustin OR, et al. Ciprofloxacin utility as antifibrotic in the skin of patients with scleroderma. Journal of Dermatology. Apr. 2010;37(4):323-9. Not CKD treatment. [pmid: 20507401].
3733 Rubenstein MH, Harrell LC, Sheynberg BV, et al. Are patients with renal failure good candidates for percutaneous coronary revascularization in the new device era?. Circulation. 2000;102(24):2966-72. Not RCT or controlled trial. [pmid: 11113047].
3734 Rubin MR, Volek JS, Gomez AL, et al. Safety measures of L-carnitine L-tartrate supplementation in healthy men. Journal of Strength & Conditioning Research. 2001;15(4):486-90. Not early CKD. [pmid: 11726261].
3735 Rucinska EJ, Small R, Irvin J. High-risk patients treated with enalapril maleate: safety considerations. International Journal of Cardiology. 1989;22(2):249-59. Not RCT or controlled trial. [pmid: 2536644].
3736 Rucker D, Tonelli M, Coles MG, et al. Vitamin D insufficiency and treatment with oral vitamin D3 in northern-dwelling patients with chronic kidney disease. Journal of Nephrology. 2009;22(1):75-82. Sample size less than 50 patients. [pmid: 19229821].
3737 Rudberg S, Dahlquist G, Aperia A, et al. Reduction of protein intake decreases glomerular filtration rate in young type 1 (insulin-dependent) diabetic patients mainly in hyperfiltering patients. Diabetologia. 1988;31(12):878-83. Sample size less than 50 patients. [pmid: 3240842].
3738 Rudberg S, Osterby R, Bangstad HJ, et al. Effect of angiotensin converting enzyme inhibitor or beta blocker on glomerular structural changes in young microalbuminuric patients with Type I (insulin-dependent) diabetes mellitus. Diabetologia. 1999;42(5):589-95. Sample size less than 50 patients. [pmid: 10333052].
3739 Rudis MI, Zarowitz BJ. Low-dose dopamine in acute oliguric renal failure. American Journal of Medicine. 1997;102(3):320-2. Not early CKD. [pmid: 9217610].
3740 Rudnick MR, Davidson C, Laskey W, et al. Nephrotoxicity of iodixanol versus ioversol in patients with chronic kidney disease: the Visipaque Angiography/Interventions with Laboratory Outcomes in Renal Insufficiency (VALOR) Trial. American Heart Journal. 2008;156(4):776-82. Not RCT or controlled trial. [pmid: 18946896].
3741 Rudnick MR, Goldfarb S, Wexler L, et al. Nephrotoxicity of ionic and nonionic contrast media in 1196 patients: a randomized trial. The Iohexol Cooperative Study. Kidney International. 1995;47(1):254-61. Not RCT or controlled trial. [pmid: 7731155].
3742 Rudy DW, Voelker JR, Greene PK, et al. Loop diuretics for chronic renal insufficiency: a continuous infusion is more efficacious than bolus therapy. Annals of Internal Medicine. 1991;115(5):360-6. Not early CKD. [pmid: 1863026].
3743 Ruedin P, Rizzoli R, Slosman D, et al. Effects of oral calcitriol on bone mineral density in patients with end-stage renal failure. Kidney International. 1994;45(1):245-52. Not early CKD. [pmid: 8127015].
3744 Ruggenenti P, Fassi A, Ilieva AP, et al. Preventing microalbuminuria in type 2 diabetes. New England Journal of Medicine. 2004;351(19):1941-51. Not RCT or controlled trial. [pmid: 15516697].
3745 Ruggenenti P, Flores C, Aros C, et al. Renal and metabolic effects of insulin lispro in type 2 diabetic subjects with overt nephropathy. Diabetes Care. 2003;26(2):502-9. Sample size less than 50 patients. [pmid: 12547889].
3746 Ruggenenti P, Gaspari F, Perna A, et al. Cross sectional longitudinal study of spot morning urine protein:creatinine ratio, 24 hour urine protein excretion rate, glomerular filtration rate, and end stage renal failure in chronic renal disease in patients without diabetes. [Erratum appears in BMJ 1998 Nov 28;317(7171):1491]. BMJ. 1998;316(7130):504-9. Not RCT or controlled trial. [pmid: 9501711].
3747 Ruggenenti P, Iliev I, Costa GM, et al. Preventing left ventricular hypertrophy by ACE inhibition in hypertensive patients with type 2 diabetes: a prespecified analysis of the Bergamo Nephrologic Diabetes Complications Trial (BENEDICT). Diabetes Care. 2008;31(8):1629-34. Not CKD treatment. [pmid: 18443191].
3748 Ruggenenti P, Mise N, Pisoni R, et al. Diverse effects of increasing lisinopril doses on lipid abnormalities in chronic nephropathies. Circulation. 2003;107(4):586-92. Sample size less than 50 patients. [pmid: 12566371].
3749 Ruggenenti P, Mosconi L, Bianchi L, et al. Long-term treatment with either enalapril or nitrendipine stabilizes albuminuria and increases glomerular filtration rate in non-insulin-dependent diabetic patients. American Journal of Kidney Diseases. 1994;24(5):753-61. Sample size less than 50 patients. [pmid: 7977316].
3750 Ruggenenti P, Mosconi L, Sangalli F, et al. Glomerular size-selective dysfunction in NIDDM is not ameliorated by ACE inhibition or by calcium channel blockade. Kidney International. 1999;55(3):984-94. Sample size less than 50 patients. [pmid: 10027935].
3751 Ruggenenti P, Pagano E, Tammuzzo L, et al. Ramipril prolongs life and is cost effective in chronic proteinuric nephropathies. Kidney International. 2001;59(1):286-94. Not RCT or controlled trial. [pmid: 11135082].
3752 Ruggenenti P, Perna A, Benini R, et al. In chronic nephropathies prolonged ACE inhibition can induce remission: dynamics of time-dependent changes in GFR. Investigators of the GISEN Group. Gruppo Italiano Studi Epidemiologici in Nefrologia. Journal of the American Society of Nephrology. 1999;10(5):997-1006. Not relevant to key questions. [pmid: 10232685].
3753 Ruggenenti P, Perna A, Benini R, et al. Effects of dihydropyridine calcium channel blockers, angiotensin-converting enzyme inhibition, and blood pressure control on chronic, nondiabetic nephropathies. Gruppo Italiano di Studi Epidemiologici in Nefrologia (GISEN). Journal of the American Society of Nephrology. 1998;9(11):2096-101. Not relevant to key questions. [pmid: 9808096].
3754 Ruggenenti P, Perna A, Ganeva M, et al. Impact of blood pressure control and angiotensin-converting enzyme inhibitor therapy on new-onset microalbuminuria in type 2 diabetes: a post hoc analysis of the BENEDICT trial. Journal of the American Society of Nephrology. 2006;17(12):3472-81. Not early CKD. [pmid: 17082240].
3755 Ruggenenti P, Perna A, Gherardi G, et al. Chronic proteinuric nephropathies: outcomes and response to treatment in a prospective cohort of 352 patients with different patterns of renal injury. American Journal of Kidney Diseases. 2000;35(6):1155-65. Not RCT or controlled trial. [pmid: 10845831].
3756 Ruggenenti P, Perna A, Lesti M, et al. Pretreatment blood pressure reliably predicts progression of chronic nephropathies. GISEN Group. Kidney International. 2000;58(5):2093-101. Not RCT or controlled trial. [pmid: 11044230].
3757 Ruggenenti P, Perna A, Loriga G, et al. Blood-pressure control for renoprotection in patients with non-diabetic chronic renal disease (REIN-2): multicentre, randomised controlled trial. Lancet. 2005;365(9463):939-46. Not relevant to key questions. [pmid: 15766995].
3758 Ruggenenti P, Perna A, Mosconi L, et al. Proteinuria predicts end-stage renal failure in non-diabetic chronic nephropathies. The “Gruppo Italiano di Studi Epidemiologici in Nefrologia” (GISEN). Kidney International - Supplement. 1997;63:S54-7. Not RCT or controlled trial. [pmid: 9407422].
3759 Ruggenenti P, Perna A, Mosconi L, et al. Urinary protein excretion rate is the best independent predictor of ESRF in non-diabetic proteinuric chronic nephropathies. “Gruppo Italiano di Studi Epidemiologici in Nefrologia” (GISEN). Kidney International. 1998;53(5):1209-16. Not RCT or controlled trial. [pmid: 9573535].
3760 Ruggenenti P, Perna A, Remuzzi G, et al. Retarding progression of chronic renal disease: the neglected issue of residual proteinuria. Kidney International. 2003;63(6):2254-61. Not relevant to key questions. [pmid: 12753315].
3761 Ruggenenti P, Remuzzi G. Primary prevention of renal failure in diabetic patients: the Bergamo Nephrologic Diabetes Complication Trial. Journal of Hypertension - Supplement. 1998;16(1):S95-7. Not early CKD.
3762 Ruggenenti P, Remuzzi G. Proteinuria: Is the ONTARGET renal substudy actually off target?. Nature Reviews Nephrology. 2009;5(8):436-7. Not RCT or controlled trial.
3763 Rugiu C, Oldrizzi L, Maschio G. Effects of an oral protein load on glomerular filtration rate in patients with solitary kidneys. Kidney International - Supplement. 1987;22:S29-31. Sample size less than 50 patients. [pmid: 3480994].
3764 Ruhnau KJ, Meissner HP, Finn JR, et al. Effects of 3-week oral treatment with the antioxidant thioctic acid (alpha-lipoic acid) in symptomatic diabetic polyneuropathy. Diabetic Medicine. 1999;16(12):1040-3. Sample size less than 50 patients. [pmid: 10656234].
3765 Ruilope L. RAS blockade: new possibilities in the treatment of complications of diabetes. Heart. Suppl 1. 2000;84:i32-4. discussion i50. Not relevant to key questions. [pmid: 10956319].
3766 Ruilope LM. Renoprotection and renin-angiotensin system blockade in diabetes mellitus. American Journal of Hypertension. 1997;10(12 Pt 2):325S-31S. Not RCT or controlled trial. [pmid: 9438777].
3767 Ruilope LM. Lessons from trials in hypertensive type 2 diabetic patients. Current Hypertension Reports. 2003;5(4):322-8. Not RCT or controlled trial. [pmid: 12844467].
3768 Ruilope LM. New ADVANCEs in guidelines. Journal of Hypertension - Supplement. 2008;26(2):S16-8. Not CKD treatment.
3769 Ruilope LM. New ADVANCEs in guidelines. Journal of Hypertension. Suppl 2. 2008;26:S16-8. Not RCT or controlled trial. [pmid: 18979719].
3770 Ruilope LM. Angiotensin receptor blockers: RAAS blockade and renoprotection. Current Medical Research & Opinion. 2008;24(5):1285-93. Not CKD treatment. [pmid: 18366863].
3771 Ruilope LM, Alcazar JM, Hernandez E, et al. Long-term influences of antihypertensive therapy on microalbuminuria in essential hypertension. Kidney International - Supplement. 1994;45:S171-3. Sample size less than 50 patients. [pmid: 7908997].
3772 Ruilope LM, Aldigier JC, Ponticelli C, et al. Safety of the combination of valsartan and benazepril in patients with chronic renal disease. European Group for the Investigation of Valsartan in Chronic Renal Disease. Journal of Hypertension. 2000;18(1):89-95. Follow-up less than 6 months. [pmid: 10678548].
3773 Ruilope LM, Araque A, Lahera V, et al. Antihypertensive effect of nitrendipine in the hypertensive patient with renal impairment. Renal Failure. 1993;15(3):359-63. Not RCT or controlled trial. [pmid: 8516491].
3774 Ruilope LM, Casal MC, Guerrero L, et al. Sodium intake does not influence the effect of verapamil in hypertensive patients with mild renal insufficiency. Drugs. Suppl 1. 1992;44:94-8. Sample size less than 50 patients. [pmid: 1283591].
3775 Ruilope LM, Lahera V, Alcazar JM, et al. Randomly allocated study of the effects of standard therapy versus ACE inhibition on micro-albuminuria in essential hypertension. Journal of Hypertension - Supplement. 1994;12(4):S59-63. Sample size less than 50 patients.
3776 Ruilope LM, Miranda B, Garcia-Robles R, et al. Effects of nisoldipine on renal function in normal volunteers and essential hypertensive patients. Journal of Cardiovascular Pharmacology. 1989;13(1):90-3. Sample size less than 50 patients. [pmid: 2468941].
3777 Ruilope LM, Rodicio J, Garcia Robles R, et al. Influence of a low sodium diet on the renal response to amino acid infusions in humans. Kidney International. 1987;31(4):992-9. Follow-up less than 6 months. [pmid: 3295362].
3778 Ruilope LM, Schiffrin EL. Blood pressure control and benefits of antihypertensive therapy: does it make a difference which agents we use?. Hypertension. 2001;38(3 Pt 2):537-42. Not RCT or controlled trial. [pmid: 11566927].
3779 Ruilope LM, Zanchetti A, Julius S, et al. Prediction of cardiovascular outcome by estimated glomerular filtration rate and estimated creatinine clearance in the high-risk hypertension population of the VALUE trial. Journal of Hypertension. 2007;25(7):1473-9. Not RCT or controlled trial. [pmid: 17563571].
3780 Rule AD, Rodeheffer RJ, Larson TS, et al. Limitations of estimating glomerular filtration rate from serum creatinine in the general population. [Erratum appears in Mayo Clin Proc. 2006 Dec;81(12):1639]. Mayo Clinic Proceedings. 2006;81(11):1427-34. Not relevant to key questions. [pmid: 17120397].
3781 Ruml LA, Gonzalez G, Taylor R, et al. Effect of varying doses of potassium-magnesium citrate on thiazide-induced hypokalemia and magnesium loss. American Journal of Therapeutics. 1999;6(1):45-50. Sample size less than 50 patients. [pmid: 10423646].
3782 Rupoli L, Fruscio M, Gradnik R, et al. Cardiovascular and renal effects of single administration of three different doses of isradipine in hypertensive patients. Dose-response curves of the different effects. American Journal of Medicine. 1989;86(4A):65-6. Sample size less than 50 patients. [pmid: 2523658].
3783 Rusinek H, Lee VS, Johnson G. Optimal dose of Gd-DTPA in dynamic MR studies. Magnetic Resonance in Medicine. 2001;46(2):312-6. Not RCT or controlled trial. [pmid: 11477635].
3784 Russel JA. The current management of septic shock. Minerva Medica. 2008;99(5):431-58. Sample size less than 50 patients. [pmid: 18971911].
3785 Russell CD. Optimum sample times for single-injection, multisample renal clearance methods. Journal of Nuclear Medicine. 1993;34(10):1761-5. Not RCT or controlled trial. [pmid: 8410295].
3786 Russo D, Minutolo R, Cianciaruso B, et al. Early effects of contrast media on renal hemodynamics and tubular function in chronic renal failure. Journal of the American Society of Nephrology. 1995;6(5):1451-8. Not CKD treatment. [pmid: 8589322].
3787 Russo D, Testa A, Della Volpe L, et al. Randomised prospective study on renal effects of two different contrast media in humans: protective role of a calcium channel blocker. Nephron. 1990;55(3):254-7. Sample size less than 50 patients. [pmid: 2370924].
3788 Ruzicka M, Burns KD, Culleton B, et al. Treatment of hypertension in patients with nondiabetic chronic kidney disease. Canadian Journal of Cardiology. 2007;23(7):595-601. Follow-up less than 6 months. [pmid: 17534470].
3789 Rybak MJ, Abate BJ, Kang SL, et al. Prospective evaluation of the effect of an aminoglycoside dosing regimen on rates of observed nephrotoxicity and ototoxicity. Antimicrobial Agents & Chemotherapy. 1999;43(7):1549-55. Not CKD treatment. [pmid: 10390201].
3790 Ryckwaert F, Colson P, Ribstein J, et al. Haemodynamic and renal effects of intravenous enalaprilat during coronary artery bypass graft surgery in patients with ischaemic heart dysfunction. British Journal of Anaesthesia. 2001;86(2):169-75. Sample size less than 50 patients. [pmid: 11573655].
3791 Sa Carvalho M, Henderson R, Shimakura S, et al. Survival of hemodialysis patients: modeling differences in risk of dialysis centers. International Journal for Quality in Health Care. 2003;15(3):189-96. Not early CKD. [pmid: 12803346].
3792 Sackner-Bernstein JD, Skopicki HA, Aaronson KD. Risk of worsening renal function with nesiritide in patients with acutely decompensated heart failure. [Erratum appears in Circulation. 2005 May 3;111(17):2274]. Circulation. 2005;111(12):1487-91. Not relevant to key questions. [pmid: 15781736].
3793 Sadeghi HM, Stone GW, Grines CL, et al. Impact of renal insufficiency in patients undergoing primary angioplasty for acute myocardial infarction. Circulation. 2003;108(22):2769-75. Not RCT or controlled trial. [pmid: 14638545].
3794 Safdar B, Degutis LC, Landry K, et al. Intravenous morphine plus ketorolac is superior to either drug alone for treatment of acute renal colic. Annals of Emergency Medicine. 2006;48(2):173-81. Not early CKD. [pmid: 16953530].
3795 Sahani DV, Soulez G, Chen KM, et al. A comparison of the efficacy and safety of iopamidol-370 and iodixanol-320 in patients undergoing multidetector-row computed tomography. Investigative Radiology. 2007;42(12):856-61. Follow-up less than 6 months. [pmid: 18007158].
3796 Saikawa T, Sasaki J, Biro S, et al. Is the reno-protective effect of valsartan dose dependent? A comparative study of 80 and 160 mg day(-1). Hypertension Research - Clinical & Experimental. Sep. 2010;33(9):886-91. Not early CKD.
3797 Saito F, Fujita H, Takahashi A, et al. Renoprotective effect and cost-effectiveness of using benidipine, a calcium channel blocker, to lower the dose of angiotensin receptor blocker in hypertensive patients with albuminuria. Hypertension Research - Clinical & Experimental. 2007;30(1):39-47. Not RCT or controlled trial.
3798 Sakai H, Watanabe S, Inoue I, et al. Effect of urokinase on preservation of renal function in patients with diabetic nephropathy. Journal of Diabetic Complications. 1991;5(2-3):95-7. Sample size less than 50 patients. [pmid: 1770066].
3799 Saklayen MG, Gyebi LK, Tasosa J, et al. Effects of additive therapy with spironolactone on proteinuria in diabetic patients already on ACE inhibitor or ARB therapy: results of a randomized, placebo-controlled, double-blind, crossover trial. Journal of Investigative Medicine. 2008;56(4):714-9. Not RCT or controlled trial. [pmid: 18382267].
3800 Salako BL, Finomo FO, Kadiri S, et al. Comparative effect of lisinopril and lacidipine on urinary albumin excretion in patients with type 11 diabetic nephropathy. African Journal of Medicine & Medical Sciences. 2002;31(1):53-7. Sample size less than 50 patients. [pmid: 12518931].
3801 Salazar MR, Carbajal HA, Marillet AG, et al. Glomerular filtration rate, cardiovascular risk factors and insulin resistance. Medicina. 2009;69(5):541-6. Not CKD treatment. [pmid: 19897440].
3802 Salerno F, Lorenzano E, Maggi A, et al. Effects of imidazole-salicylate on renal function and the diuretic action of furosemide in cirrhotic patients with ascites. Journal of Hepatology. 1993;19(2):279-84. Not CKD treatment. [pmid: 8301062].
3803 Salerno M, Di Salvo M, Furnari R, et al. Comparison of muzolimine and furosemide in heart failure. Zeitschrift fur Kardiologie. Suppl 2. 1985;74:32-3. Sample size less than 50 patients. [pmid: 4002801].
3804 Salvetti A, Leonetti G, Bernini GP, et al. Antihypertensive and renal effects of tertatolol, a new beta-blocking agent, in hypertensive patients. American Journal of Nephrology. Suppl 2. 1986;6:45-9. Sample size less than 50 patients. [pmid: 2879473].
3805 Sambhi MP. Saluretic and diuretic effects of antihypertensive nitrendipine monotherapy in man. Angiology. 1988;39(1 Pt 2):106-12. Sample size less than 50 patients. [pmid: 3341609].
3806 Sampath S, Moran JL, Graham PL, et al. The efficacy of loop diuretics in acute renal failure: assessment using Bayesian evidence synthesis techniques. Critical Care Medicine. 2007;35(11):2516-24. Not RCT or controlled trial. [pmid: 18084840].
3807 Samuelsson O, Attman PO, Knight-Gibson C, et al. Fluvastatin improves lipid abnormalities in patients with moderate to advanced chronic renal insufficiency. American Journal of Kidney Diseases. 2002;39(1):67-75. Sample size less than 50 patients. [pmid: 11774104].
3808 Samuelsson O, Hedner T, Ljungman S, et al. A comparative study of lisinopril and atenolol on low degree urinary albumin excretion, renal function and haemodynamics in uncomplicated, primary hypertension. European Journal of Clinical Pharmacology. 1992;43(5):469-75. Follow-up less than 6 months. [pmid: 1336463].
3809 Samy AK, Murray G, MacBain G. Glasgow aneurysm score. Cardiovascular Surgery. 1994;2(1):41-4. Not RCT or controlled trial. [pmid: 8049922].
3810 San Miguel JF, Blade Creixenti J, Garcia-Sanz R. Treatment of multiple myeloma. Haematologica. 1999;84(1):36-58. Not CKD treatment. [pmid: 10091392].
3811 Sanahuja J, Corbera G, Garau J, et al. Intramuscular diclofenac sodium versus intravenous Baralgin in the treatment of renal colic. DICP. 1990;24(4):361-4. Not CKD treatment. [pmid: 2183488].
3812 Sanchez EQ, Martin AP, Ikegami T, et al. Sirolimus conversion after liver transplantation: improvement in measured glomerular filtration rate after 2 years. [Erratum appears in Transplant Proc. 2006 Jan-Feb;38(1):342 Note: Klintmaim, GB [corrected to Klintmalm, GB]]. Transplantation Proceedings. 2005;37(10):4416-23. Sample size less than 50 patients. [pmid: 16387135].
3813 Sanchez Garcia M, Alvarez Gonzaez M, Velo Plaza M. Dopamine dose and renal damage. Lancet. 2001;357(9269):1707-8. Not early CKD. [pmid: 11729836].
3814 Sanchez RA, Marco E, Gilbert HB, et al. Natriuretic effect and changes in renal haemodynamics induced by enalapril in essential hypertension. Drugs. Suppl 1. 1985;30:49-58. Sample size less than 50 patients. [pmid: 2994987].
3815 Sanchez RA, Migliorini M, Giannone C, et al. Plasma renin activity levels influence the effect of converting enzyme inhibitors in preserving renal function in hypertension. Journal of Hypertension. 1996;14(8):1025-31. Sample size less than 50 patients. [pmid: 8884559].
3816 Sanchez RA, Traballi CA, Gilbert BH, et al. Effect of cilazapril in hypertensive patients with renal impairment. Journal of Cardiovascular Pharmacology. 1991;17(2):222-7. Sample size less than 50 patients. [pmid: 1709226].
3817 Sanchez-Alcaraz A, Vargas A, Quintana MB, et al. Therapeutic drug monitoring of tobramycin: once-daily versus twice-daily dosage schedules. Journal of Clinical Pharmacy & Therapeutics. 1998;23(5):367-73. Sample size less than 50 patients. [pmid: 9875685].
3818 Sanchez-Carpena J, Dominguez-Hervella F, Garcia I, et al. Comparison of intravenous dexketoprofen and dipyrone in acute renal colic. European Journal of Clinical Pharmacology. 2007;63(8):751-60. Not early CKD. [pmid: 17571256].
3819 Sanchorawala V, Wright DG, Seldin DC, et al. High-dose intravenous melphalan and autologous stem cell transplantation as initial therapy or following two cycles of oral chemotherapy for the treatment of AL amyloidosis: results of a prospective randomized trial. Bone Marrow Transplantation. 2004;33(4):381-8. Not relevant to key questions. [pmid: 14676787].
3820 Sandage B, Sabounjian L, Shipley J, et al. Predictive power of an in vitro system to assess drug interactions of an antimuscarinic medication: a comparison of in vitro and in vivo drug-drug interaction studies of trospium chloride with digoxin. Journal of Clinical Pharmacology. 2006;46(7):776-84. Not RCT or controlled trial. [pmid: 16809803].
3821 Sanders PW. Management of paraproteinemic renal disease. Current Opinion in Nephrology & Hypertension. 2005;14(2):97-103. Not RCT or controlled trial. [pmid: 15687834].
3822 Sandhu C, Belli AM, Oliveira DB. The role of N-acetylcysteine in the prevention of contrast-induced nephrotoxicity. Cardiovascular & Interventional Radiology. 2006;29(3):344-7. Not RCT or controlled trial. [pmid: 16502177].
3823 Sandhu DP, Iacovou JW, Fletcher MS, et al. A comparison of intramuscular ketorolac and pethidine in the alleviation of renal colic. British Journal of Urology. 1994;74(6):690-3. Sample size less than 50 patients. [pmid: 7827834].
3824 Sandhu S, Wiebe N, Fried LF, et al. Statins for improving renal outcomes: a meta-analysis. Journal of the American Society of Nephrology. 2006;17(7):2006-16. Not relevant to key questions. [pmid: 16762986].
3825 Sanjay S, Annigeri RA, Seshadri R, et al. The comparison of the diuretic and natriuretic efficacy of continuous and bolus intravenous furosemide in patients with chronic kidney disease. Nephrology. 2008;13(3):247-50. Not early CKD. [pmid: 18315706].
3826 San-Miguel JF, Richardson PG, Sonneveld P, et al. Efficacy and safety of bortezomib in patients with renal impairment: results from the APEX phase 3 study. Leukemia. 2008;22(4):842-9. Not CKD treatment. [pmid: 18200040].
3827 Sano T, Hotta N, Kawamura T, et al. Effects of long-term enalapril treatment on persistent microalbuminuria in normotensive type 2 diabetic patients: results of a 4-year, prospective, randomized study. Diabetic Medicine. 1996;13(2):120-4. Not relevant to key questions. [pmid: 8641115].
3828 Santoso JT, Lucci JA 3rd, Coleman RL, et al. Saline, mannitol, and furosemide hydration in acute cisplatin nephrotoxicity: a randomized trial. Cancer Chemotherapy & Pharmacology. 2003;52(1):13-8. Not CKD treatment. [pmid: 12719883].
3829 Sar F, Saler T, Ecebay A, et al. The efficacy of n-acetylcysteine in preventing contrast-induced nephropathy in type 2 diabetic patients without nephropathy. Journal of Nephrology. Jul-Aug. 2010;23(4):478-82. Not CKD treatment. [pmid: 20383874].
3830 Sarafidis PA, Bakris GL. Protection of the kidney by thiazolidinediones: an assessment from bench to bedside. Kidney International. 2006;70(7):1223-33. Not relevant to key questions. [pmid: 16883325].
3831 Sarafidis PA, Bakris GL. Renin-angiotensin blockade and kidney disease. Lancet. 2008;372(9638):511-2. Not relevant to key questions. [pmid: 18707969].
3832 Sarafidis PA, Lasaridis AN. Diabetic nephropathy: Endothelin antagonism for diabetic nephropathy. Nature Reviews Nephrology. Aug. 2010;6(8):447-9. Not relevant to key questions.
3833 Sarafidis PA, Stafylas PC, Georgianos PI, et al. Effect of thiazolidinediones on albuminuria and proteinuria in diabetes: a meta-analysis. American Journal of Kidney Diseases. May. 2010;55(5):835-47. Not relevant to key questions. [pmid: 20110146].
3834 Sarafidis PA, Stafylas PC, Kanaki AI, et al. Effects of renin-angiotensin system blockers on renal outcomes and all-cause mortality in patients with diabetic nephropathy: an updated meta-analysis. American Journal of Hypertension. 2008;21(8):922-9. Not relevant to key questions. [pmid: 18535536].
3835 Saran R, Novak JE, Desai A, et al. Impact of vitamin E on plasma asymmetric dimethylarginine (ADMA) in chronic kidney disease (CKD): a pilot study. Nephrology Dialysis Transplantation. 2003;18(11):2415-20. Sample size less than 50 patients.
3836 Sarapa N, Wickremasingha P, Ge N, et al. Lack of effect of DX-619, a novel des-fluoro(6)-quinolone, on glomerular filtration rate measured by serum clearance of cold iohexol. Antimicrobial Agents & Chemotherapy. 2007;51(6):1912-7. Sample size less than 50 patients. [pmid: 17371829].
3837 Sarnak MJ, Coronado BE, Greene T, et al. Cardiovascular disease risk factors in chronic renal insufficiency. Clinical Nephrology. 2002;57(5):327-35. Not RCT or controlled trial. [pmid: 12036190].
3838 Sarnak MJ, Greene T, Wang X, et al. The effect of a lower target blood pressure on the progression of kidney disease: long-term follow-up of the modification of diet in renal disease study. Annals of Internal Medicine. 2005;142(5):342-51. Not relevant to key questions. [pmid: 15738453].
3839 Sarnak MJ, Wang SR, Beck GJ, et al. Homocysteine, cysteine, and B vitamins as predictors of kidney disease progression. American Journal of Kidney Diseases. 2002;40(5):932-9. Not CKD treatment. [pmid: 12407637].
3840 Sarraf M, Masoumi A, Schrier RW. Cardiorenal syndrome in acute decompensated heart failure. Clinical Journal of The American Society of Nephrology: CJASN. 2009;4(12):2013-26. Not CKD treatment. [pmid: 19965544].
3841 Saruta T, Hayashi K, Ogihara T, et al. Effects of candesartan and amlodipine on cardiovascular events in hypertensive patients with chronic kidney disease: subanalysis of the CASE-J Study. [Erratum appears in Hypertens Res. 2009 Dec;32(12):1157]. Hypertension Research - Clinical & Experimental. 2009;32(6):505-12. Duplicate listings.
3842 Sasaki H, Saiki A, Endo K, et al. Protective effects of efonidipine, a T- and L-type calcium channel blocker, on renal function and arterial stiffness in type 2 diabetic patients with hypertension and nephropathy. Journal of Atherosclerosis & Thrombosis. 2009;16(5):568-75. Sample size less than 50 patients. [pmid: 19749494].
3843 Sassard J, Geoffroy J, Ferry N, et al. Compared effects of isoxicam and indomethacin on the urinary excretion of prostaglandins in degenerative articular diseases. Prostaglandins Leukotrienes & Essential Fatty Acids. 1989;38(2):107-11. Sample size less than 50 patients.
3844 Sasso FC, Carbonara O, Persico M, et al. Irbesartan reduces the albumin excretion rate in microalbuminuric type 2 diabetic patients independently of hypertension: a randomized double-blind placebo-controlled crossover study. Diabetes Care. 2002;25(11):1909-13. Not relevant to key questions. [pmid: 12401731].
3845 Sato A, Hayashi K, Naruse M, et al. Effectiveness of aldosterone blockade in patients with diabetic nephropathy. Hypertension. 2003;41(1):64-8. Sample size less than 50 patients. [pmid: 12511531].
3846 Sato A, Hayashi K, Saruta T. Antiproteinuric effects of mineralocorticoid receptor blockade in patients with chronic renal disease. American Journal of Hypertension. 2005;18(1):44-9. Not relevant to key questions. [pmid: 15691616].
3847 Sato A, Tabata M, Hayashi K, et al. Effects of the angiotensin II type 1 receptor antagonist candesartan, compared with angiotensin-converting enzyme inhibitors, on the urinary excretion of albumin and type IV collagen in patients with diabetic nephropathy. Clinical & Experimental Nephrology. 2003;7(3):215-20. Not relevant to key questions. [pmid: 14586718].
3848 Satoh N, Kimoto S, Hiraki Y. Studies of an aspect of renal function with the aid of dynamic CT and renogram. Acta Medica Okayama. 1991;45(3):187-93. Not CKD treatment. [pmid: 1891978].
3849 Sav T, Tokgoz B, Sipahioglu MH, et al. Is there a difference between the allergic potencies of the iron sucrose and low molecular weight iron dextran?. Renal Failure. 2007;29(4):423-6. Not CKD treatment. [pmid: 17497463].
3850 Savage S, Nagel NJ, Estacio RO, et al. Clinical factors associated with urinary albumin excretion in type II diabetes. American Journal of Kidney Diseases. 1995;25(6):836-44. Not CKD treatment. [pmid: 7771479].
3851 Savage S, Schrier RW. Progressive renal insufficiency: the role of angiotensin converting enzyme inhibitors. Advances in Internal Medicine. 1992;37:85-101. Not relevant to key questions. [pmid: 1558007].
3852 Savolainen H. Studies on urinary proteoglycan excretion in occupational cadmium exposure. Pharmacology & Toxicology. 1994;75(2):113-4. Not RCT or controlled trial. [pmid: 7971739].
3853 Sawara Y, Takei T, Uchida K, et al. Effects of lipid-lowering therapy with rosuvastatin on atherosclerotic burden in patients with chronic kidney disease. Internal Medicine. 2008;47(17):1505-10. Not CKD treatment. [pmid: 18758125].
3854 Sawicki PT. Stabilization of glomerular filtration rate over 2 years in patients with diabetic nephropathy under intensified therapy regimens. Diabetes Treatment and Teaching Programmes Working Group. Nephrology Dialysis Transplantation. 1997;12(9):1890-9. Sample size less than 50 patients.
3855 Sawicki PT, Muhlhauser I, Bender R, et al. Effects of smoking on blood pressure and proteinuria in patients with diabetic nephropathy. Journal of Internal Medicine. 1996;239(4):345-52. Sample size less than 50 patients. [pmid: 8774389].
3856 Sawicki PT, Muhlhauser I, Didjurgeit U, et al. Intensified antihypertensive therapy is associated with improved survival in type 1 diabetic patients with nephropathy. Journal of Hypertension. 1995;13(8):933-8. Not RCT or controlled trial. [pmid: 8557972].
3857 Sawicki PT, Muhlhauser I, Didjurgeit U, et al. Effects of intensification of antihypertensive care in diabetic nephropathy. Journal of Diabetes & its Complications. 1995;9(4):315-7. Not RCT or controlled trial. [pmid: 8573755].
3858 Sax PE, Gallant JE, Klotman PE. Renal safety of tenofovir disoproxil fumarate. AIDS Reader. 2007;17(2):90-2. Sample size less than 50 patients. [pmid: 17323508].
3859 Saxenhofer H, Raselli A, Weidmann P, et al. Urodilatin, a natriuretic factor from kidneys, can modify renal and cardiovascular function in men. American Journal of Physiology. 1990;259(5 Pt 2):F832-8. Not CKD treatment. [pmid: 2146885].
3860 Scaglione R, Argano C, Corrao S, et al. Transforming growth factor beta1 and additional renoprotective effect of combination ACE inhibitor and angiotensin II receptor blocker in hypertensive subjects with minor renal abnormalities: a 24-week randomized controlled trial. Journal of Hypertension. 2005;23(3):657-64. Sample size less than 50 patients. [pmid: 15716710].
3861 Scaglione R, Ganguzza A, Corrao S, et al. Effects of cilazapril on renal haemodynamics and function in hypertensive patients: a randomised controlled study versus hydrochlorothiazide. Blood Pressure. 1995;4(6):363-8. Sample size less than 50 patients. [pmid: 8746604].
3862 Scaglione R, Indovina A, Parrinello G, et al. Antihypertensive efficacy and effects of nitrendipine on cardiac and renal hemodynamics in mild to moderate hypertensive patients: randomized controlled trial versus hydrochlorothiazide. Cardiovascular Drugs & Therapy. 1992;6(2):141-6. Follow-up less than 6 months. [pmid: 1390326].
3863 Scanferla F, Toffoletto PP, Roncali D, et al. Associated effect of hepatic hydroxymethylglutaryl coenzyme A reductase + angiotensin converting enzyme inhibitors on the progression of renal failure in hypertensive subjects. American Journal of Hypertension. 1991;4(10 Pt 1):868. Sample size less than 50 patients. [pmid: 1747221].
3864 Scarsi KK, Bjornson DC. The use of ACE inhibitors as renoprotective agents in Medicaid patients with diabetes. Annals of Pharmacotherapy. 2000;34(9):1002-6. Not RCT or controlled trial. [pmid: 10981244].
3865 Schachinger V, Zeiher AM. Stem cells and cardiovascular and renal disease: today and tomorrow. Journal of the American Society of Nephrology. Suppl 1. 2005;16:S2-6. Sample size less than 50 patients. [pmid: 15938024].
3866 Schaefer K, Scheer J, Asmus G, et al. The treatment of uraemic hyperphosphataemia with calcium acetate and calcium carbonate: a comparative study. Nephrology Dialysis Transplantation. 1991;6(3):170-5. Not early CKD.
3867 Schaefer RM, Schaefer L, Heidland A. Recombinant human erythropoietin for anaemia associated with chronic renal failure in predialysis patients. Przeglad Lekarski. 1992;49(1-2):41-2. Not early CKD. [pmid: 1455005].
3868 Schaeffner ES, Kurth T, Bowman TS, et al. Blood pressure measures and risk of chronic kidney disease in men. Nephrology Dialysis Transplantation. 2008;23(4):1246-51. Not RCT or controlled trial.
3869 Schaeffner ES, van der Giet M, Gaedeke J, et al. The Berlin initiative study: the methodology of exploring kidney function in the elderly by combining a longitudinal and cross-sectional approach. European Journal of Epidemiology. Mar. 2010;25(3):203-10. Not CKD treatment. [pmid: 20094758].
3870 Schefer T, Wolber T, Binggeli C, et al. Long-term predictors of mortality in ICD patients with non-ischaemic cardiac disease: impact of renal function. Europace. 2008;10(9):1052-9. Not CKD treatment. [pmid: 18687703].
3871 Scheid DC, McCarthy LH, Lawler FH, et al. Screening for microalbuminuria to prevent nephropathy in patients with diabetes: a systematic review of the evidence. Journal of Family Practice. 2001;50(8):661-8. Not relevant to key questions. [pmid: 11509158].
3872 Scherberich JE, Fischer A, Rautschka E, et al. Nephrotoxicity of high and low osmolar contrast media: case control studies following digital subtraction angiography in potential risk patients. Fortschritte auf dem Gebiete der Rontgenstrahlen und der Nuklearmedizin - Erganzungsband. 1989;128:91-4. Not CKD treatment. [pmid: 2568816].
3873 Scherberich JE, Mondorf WA. Nephrotoxic potential of antiinfective drugs as assessed by tissue-specific proteinuria of renal antigens. International Journal of Clinical Pharmacology & Therapeutics. 1998;36(3):152-8. Not CKD treatment. [pmid: 9562231].
3874 Schetz M. Diuretics in acute renal failure?. Contributions to Nephrology. 2004;144:166-81. Not CKD treatment. [pmid: 15264406].
3875 Schetz M, Bove T, Morelli A, et al. Prevention of cardiac surgery-associated acute kidney injury. International Journal of Artificial Organs. 2008;31(2):179-89. Not CKD treatment. [pmid: 18311734].
3876 Schetz M, Vanhorebeek I, Wouters PJ, et al. Tight blood glucose control is renoprotective in critically ill patients. Journal of the American Society of Nephrology. 2008;19(3):571-8. Sample size less than 50 patients. [pmid: 18235100].
3877 Schiffl H, Schollmeyer P. Metabolic consequences of long-term thiazide-based antihypertensive treatment of renal hypertension. Cardiology. Suppl 1. 1985;72:54-6. Not CKD treatment. [pmid: 4053132].
3878 Schiffl H, Sitter T, Lang S, et al. Bioincompatible membranes place patients with acute renal failure at increased risk of infection. ASAIO Journal. 1995;41(3):M709-12. Not CKD treatment. [pmid: 8573898].
3879 Schiffmann R, Ries M, Timmons M, et al. Long-term therapy with agalsidase alfa for Fabry disease: safety and effects on renal function in a home infusion setting. Nephrology Dialysis Transplantation. 2006;21(2):345-54. Not relevant to key questions.
3880 Schindler C. ACE-inhibitor, AT1-receptor-antagonist, or both? A clinical pharmacologist's perspective after publication of the results of ONTARGET. Therapeutic Advances in Cardiovascular Disease. 2008;2(4):233-48. Not relevant to key questions. [pmid: 19124424].
3881 Schjoedt KJ, Andersen S, Rossing P, et al. Aldosterone escape during blockade of the renin-angiotensin-aldosterone system in diabetic nephropathy is associated with enhanced decline in glomerular filtration rate. Diabetologia. 2004;47(11):1936-9. Not early CKD. [pmid: 15551047].
3882 Schjoedt KJ, Astrup AS, Persson F, et al. Optimal dose of lisinopril for renoprotection in type 1 diabetic patients with diabetic nephropathy: a randomised crossover trial. Diabetologia. 2009;52(1):46-9. Not RCT or controlled trial. [pmid: 18974967].
3883 Schjoedt KJ, Christensen PK, Jorsal A, et al. Autoregulation of glomerular filtration rate during spironolactone treatment in hypertensive patients with type 1 diabetes: a randomized crossover trial. Nephrology Dialysis Transplantation. 2009;24(11):3343-9. Sample size less than 50 patients.
3884 Schjoedt KJ, Hansen HP, Tarnow L, et al. Long-term prevention of diabetic nephropathy: an audit. Diabetologia. 2008;51(6):956-61. Follow-up less than 6 months. [pmid: 18385971].
3885 Schjoedt KJ, Jacobsen P, Rossing K, et al. Dual blockade of the renin-angiotensin-aldosterone system in diabetic nephropathy: the role of aldosterone. Hormone & Metabolic Research. Suppl 1. 2005;37:4-8. Not relevant to key questions. [pmid: 15918104].
3886 Schjoedt KJ, Rossing K, Juhl TR, et al. Beneficial impact of spironolactone in diabetic nephropathy. Kidney International. 2005;68(6):2829-36. Follow-up less than 6 months. [pmid: 16316360].
3887 Schjoedt KJ, Rossing K, Juhl TR, et al. Beneficial impact of spironolactone on nephrotic range albuminuria in diabetic nephropathy. Kidney International. 2006;70(3):536-42. Not RCT or controlled trial. [pmid: 16775595].
3888 Schlaich MP, Jacobi J, John S, et al. Is l-arginine infusion an adequate tool to assess endothelium-dependent vasodilation of the human renal vasculature?. Clinical Science. 2000;99(4):293-302. Not early CKD. [pmid: 10995594].
3889 Schlaich MP, Sobotka PA, Krum H, et al. Renal denervation as a therapeutic approach for hypertension: novel implications for an old concept. Hypertension. 2009;54(6):1195-201. Not RCT or controlled trial. [pmid: 19822798].
3890 Schlieper G, Brandenburg V, Ketteler M, et al. Sodium thiosulfate in the treatment of calcific uremic arteriolopathy. Nature Reviews Nephrology. 2009;5(9):539-43. Not CKD treatment.
3891 Schluchter MD. Estimating correlation between alternative measures of disease progression in a longitudinal study. Modification of Diet in Renal Disease Study. Statistics in Medicine. 1990;9(10):1175-88. Not CKD treatment. [pmid: 2247718].
3892 Schluchter MD, Greene T, Beck GJ. Analysis of change in the presence of informative censoring: application to a longitudinal clinical trial of progressive renal disease. Statistics in Medicine. 2001;20(7):989-1007. Not RCT or controlled trial. [pmid: 11276031].
3893 Schlueter W, Keilani T, Batlle DC. Metabolic effects of converting enzyme inhibitors: focus on the reduction of cholesterol and lipoprotein(a) by fosinopril. American Journal of Cardiology. 1993;72(20):37H-44H. Sample size less than 50 patients.
3894 Schmetterer L, Dallinger S, Bobr B, et al. Systemic and renal effects of an ET(A) receptor subtype-specific antagonist in healthy subjects. British Journal of Pharmacology. 1998;124(5):930-4. Sample size less than 50 patients. [pmid: 9692778].
3895 Schmid CH, Landa M, Jafar TH, et al. Constructing a database of individual clinical trials for longitudinal analysis. Controlled Clinical Trials. 2003;24(3):324-40. Not RCT or controlled trial. [pmid: 12757997].
3896 Schmid CH, Stark PC, Berlin JA, et al. Meta-regression detected associations between heterogeneous treatment effects and study-level, but not patient-level, factors. Journal of Clinical Epidemiology. 2004;57(7):683-97. Not RCT or controlled trial. [pmid: 15358396].
3897 Schmidt A, Bayerle-Eder M, Pleiner H, et al. The renal and systemic hemodynamic effects of a nitric oxide-synthase inhibitor are reversed by a selective endothelin(a) receptor antagonist in men. Nitric Oxide. 2001;5(4):370-6. Not early CKD. [pmid: 11485375].
3898 Schmidt A, Pleiner J, Schaller G, et al. Renal hemodynamic effects of somatostatin are not related to inhibition of endogenous insulin release. Kidney International. 2002;61(5):1788-93. Not early CKD. [pmid: 11967028].
3899 Schmidt BMW, Sammer U, Fleischmann I, et al. Rapid nongenomic effects of aldosterone on the renal vasculature in humans. Hypertension. 2006;47(4):650-5. Not RCT or controlled trial. [pmid: 16520409].
3900 Schmidt P, Pang D, Nykamp D, et al. N-acetylcysteine and sodium bicarbonate versus N-acetylcysteine and standard hydration for the prevention of radiocontrast-induced nephropathy following coronary angiography. Annals of Pharmacotherapy. 2007;41(1):46-50. Sample size less than 50 patients. [pmid: 17190844].
3901 Schmieder RE. Nephroprotection by antihypertensive agents. Journal of Cardiovascular Pharmacology. Suppl 2. 1994;24:S55-64. Not RCT or controlled trial. [pmid: 7898095].
3902 Schmieder RE. Optimizing therapeutic strategies to achieve renal and cardiovascular risk reduction in diabetic patients with angiotensin receptor blockers. Journal of Hypertension. 2005;23(5):905-11. Sample size less than 50 patients. [pmid: 15834271].
3903 Schmieder RE, Gatzka C, Schobel H, et al. Renal hemodynamic response to stress is influenced by ACE-inhibitors. Clinical Nephrology. 1994;42(6):381-8. Sample size less than 50 patients. [pmid: 7882602].
3904 Schmieder RE, Klingbeil AU, Fleischmann EH, et al. Additional antiproteinuric effect of ultrahigh dose candesartan: a double-blind, randomized, prospective study. Journal of the American Society of Nephrology. 2005;16(10):3038-45. Sample size less than 50 patients. [pmid: 16120821].
3905 Schmieder RE, Ruddel H, Schlebusch H, et al. Impact of antihypertensive therapy with isradipine and metoprolol on early markers of hypertensive nephropathy. American Journal of Hypertension. 1992;5(5 Pt 1):318-21. Sample size less than 50 patients. [pmid: 1533771].
3906 Schmieder RE, Schobel HP, Gatzka CE, et al. Effects of angiotensin converting enzyme inhibitor on renal haemodynamics during mental stress. Journal of Hypertension. 1996;14(10):1201-7. Sample size less than 50 patients. [pmid: 8906519].
3907 Schmieder RE, Veelken R, Schobel H, et al. Glomerular hyperfiltration during sympathetic nervous system activation in early essential hypertension. Journal of the American Society of Nephrology. 1997;8(6):893-900. Sample size less than 50 patients. [pmid: 9189855].
3908 Schmitt F, Martinez F, Brillet G, et al. Acute renal effects of AT1-receptor blockade after exogenous angiotensin II infusion in healthy subjects. Journal of Cardiovascular Pharmacology. 1998;31(2):314-21. Follow-up less than 6 months. [pmid: 9475275].
3909 Schmitt F, Natov S, Martinez F, et al. Renal effects of angiotensin I-receptor blockade and angiotensin convertase inhibition in man. Clinical Science. 1996;90(3):205-13. Not RCT or controlled trial. [pmid: 8777826].
3910 Schmitt R, Coca S, Kanbay M, et al. Recovery of kidney function after acute kidney injury in the elderly: a systematic review and meta-analysis. American Journal of Kidney Diseases. 2008;52(2):262-71. Not RCT or controlled trial. [pmid: 18511164].
3911 Schmitz A, Pedersen MM, Mogensen CE. Effects of felodipine on urinary albumin excretion and metabolic control in hypertensive non-insulin-dependent diabetics. American Journal of Hypertension. 1990;3(8 Pt 1):611-7. Sample size less than 50 patients. [pmid: 2222952].
3912 Schmitz A, Pedersen MM, Moller A, et al. Some aspects of antihypertensive and diuretic treatment in noninsulin-dependent diabetic patients. Journal of Diabetic Complications. 1990;4(2):79-81. Sample size less than 50 patients. [pmid: 2145307].
3913 Schmoelz M, Schelling G, Dunker M, et al. Comparison of systemic and renal effects of dopexamine and dopamine in norepinephrine-treated septic shock. Journal of Cardiothoracic & Vascular Anesthesia. 2006;20(2):173-8. Not RCT or controlled trial. [pmid: 16616656].
3914 Schnack C, Capek M, Banyai M, et al. Long-term treatment with nifedipine reduces urinary albumin excretion and glomerular filtration rate in normotensive type 1 diabetic patients with microalbuminuria. Acta Diabetologica. 1994;31(1):14-8. Sample size less than 50 patients. [pmid: 8043891].
3915 Schnack C, Hoffmann W, Hopmeier P, et al. Renal and metabolic effects of 1-year treatment with ramipril or atenolol in NIDDM patients with microalbuminuria. Diabetologia. 1996;39(12):1611-6. Not relevant to key questions. [pmid: 8960851].
3916 Schnapp P. Acute natriuretic effect of nifedipine in elderly males with essential hypertension. International Journal of Clinical Pharmacology, Therapy, & Toxicology. 1989;27(9):442-4. Sample size less than 50 patients.
3917 Schneider CA, Ferrannini E, Defronzo R, et al. Effect of pioglitazone on cardiovascular outcome in diabetes and chronic kidney disease. Journal of the American Society of Nephrology. 2008;19(1):182-7. Follow-up less than 6 months. [pmid: 18057215].
3918 Schneider LM, Roubin GS. Minimal contrast use in carotid stenting: avoiding contrast pitfalls. Journal of Invasive Cardiology. 2007;19(1):37-8. Sample size less than 50 patients. [pmid: 17297184].
3919 Schneider MP, Klingbeil AU, Schlaich MP, et al. Impaired sodium excretion during mental stress in mild essential hypertension. Hypertension. 2001;37(3):923-7. Not early CKD. [pmid: 11244019].
3920 Schohn DC, Jahn HA, Maareck M. Long term effects of sustained release verapamil on the renal and systemic haemodynamic parameters in hypertensive patients with mild to severe chronic renal failure. Drugs. Suppl 2. 1993;46:113-9. discussion 9-20. Sample size less than 50 patients. [pmid: 7512464].
3921 Schorr U, Distler A, Sharma AM. Effect of sodium chloride- and sodium bicarbonate-rich mineral water on blood pressure and metabolic parameters in elderly normotensive individuals: a randomized double-blind crossover trial. Journal of Hypertension. 1996;14(1):131-5. Not early CKD. [pmid: 12013486].
3922 Schou M, Gabrielsen A, Bruun NE, et al. Angiotensin II attenuates the natriuresis of water immersion in humans. American Journal of Physiology - Regulatory Integrative & Comparative Physiology. 2002;283(1):R187-96. Not CKD treatment.
3923 Schouten LMT, Niessen LW, van de Pas JWAM, et al. Cost-effectiveness of a quality improvement collaborative focusing on patients with diabetes. Medical Care. Oct. 2010;48(10):884-91. Not CKD treatment. [pmid: 20808258].
3924 Schram MT, van Ittersum FJ, Spoelstra-de Man A, et al. Aggressive antihypertensive therapy based on hydrochlorothiazide, candesartan or lisinopril as initial choice in hypertensive type II diabetic individuals: effects on albumin excretion, endothelial function and inflammation in a double-blind, randomized clinical trial. Journal of Human Hypertension. 2005;19(6):429-37. Not RCT or controlled trial. [pmid: 15647778].
3925 Schrier RW. Treating high-risk diabetic hypertensive patients with comorbid conditions. American Journal of Kidney Diseases. 2000;36(3 Suppl 1):S10-7. Not RCT or controlled trial. [pmid: 10986154].
3926 Schrier RW. Aggressively preventing diabetes. Nature Reviews Nephrology. Jun. 2010;6(6):313. Not CKD treatment.
3927 Schrier RW. Fluid administration in critically ill patients with acute kidney injury. Clinical Journal of The American Society of Nephrology: CJASN. Apr. 2010;5(4):733-9. Not CKD treatment. [pmid: 20167687].
3928 Schrier RW, Burke TJ. Role of calcium-channel blockers in preventing acute and chronic renal injury. Journal of Cardiovascular Pharmacology. Suppl 6. 1991;18:S38-43. Not relevant to key questions. [pmid: 1725916].
3929 Schrier RW, Estacio RO. The effect of angiotensin-converting enzyme inhibitors on the progression of nondiabetic renal disease: a pooled analysis of individual-patient data from 11 randomized, controlled trials. Annals of Internal Medicine. 2001;135(2):138-9. Not RCT or controlled trial. [pmid: 11453714].
3930 Schrier RW, Estacio RO, Esler A, et al. Effects of aggressive blood pressure control in normotensive type 2 diabetic patients on albuminuria, retinopathy and strokes. Kidney International. 2002;61(3):1086-97. Not relevant to key questions. [pmid: 11849464].
3931 Schrier RW, Estacio RO, Jeffers B. Appropriate Blood Pressure Control in NIDDM (ABCD) Trial. Diabetologia. 1996;39(12):1646-54. Not RCT or controlled trial. [pmid: 8960857].
3932 Schroth RJ, Hitchon CA, Uhanova J, et al. Hepatitis B vaccination for patients with chronic renal failure. Cochrane Database of Systematic Reviews. 2004;(3):CD003775. Not CKD treatment. [pmid: 15266500].
3933 Schucker JJ, Ward KE. Hyperphosphatemia and phosphate binders. American Journal of Health-System Pharmacy. 2005;62(22):2355-61. Follow-up less than 6 months. [pmid: 16278327].
3934 Schulman G. A nexus of progression of chronic kidney disease: charcoal, tryptophan and profibrotic cytokines. Blood Purification. 2006;24(1):143-8. Sample size less than 50 patients. [pmid: 16361855].
3935 Schulman G, Agarwal R, Acharya M, et al. A multicenter, randomized, double-blind, placebo-controlled, dose-ranging study of AST-120 (Kremezin) in patients with moderate to severe CKD. American Journal of Kidney Diseases. 2006;47(4):565-77. Not relevant to key questions. [pmid: 16564934].
3936 Schultz MJ, Baas MC, van der Sluijs HP, et al. N-acetylcysteine and other preventive measures for contrast-induced nephropathy in the intensive care unit. Current Medicinal Chemistry. 2006;13(21):2565-70. Not RCT or controlled trial. [pmid: 17017911].
3937 Schutzer KM, Svensson MK, Zetterstrand S, et al. Reversible elevations of serum creatinine levels but no effect on glomerular filtration during treatment with the direct thrombin inhibitor AZD0837. European Journal of Clinical Pharmacology. Sep. 2010;66(9):903-10. Not early CKD. [pmid: 20535457].
3938 Schwab SJ, Dunn FL, Feinglos MN. Screening for microalbuminuria. A comparison of single sample methods of collection and techniques of albumin analysis. Diabetes Care. 1992;15(11):1581-4. Not CKD treatment. [pmid: 1468288].
3939 Schwab SJ, Hlatky MA, Pieper KS, et al. Contrast nephrotoxicity: a randomized controlled trial of a nonionic and an ionic radiographic contrast agent. New England Journal of Medicine. 1989;320(3):149-53. Sample size less than 50 patients. [pmid: 2643042].
3940 Schwartz AB, Prior JE, Mintz GS, et al. Cardiovascular hemodynamic effects of correction of anemia of chronic renal failure with recombinant-human erythropoietin. Transplantation Proceedings. 1991;23(2):1827-30. Not relevant to key questions. [pmid: 2053168].
3941 Schwartz JI, Vandormael K, Malice MP, et al. Comparison of rofecoxib, celecoxib, and naproxen on renal function in elderly subjects receiving a normal-salt diet. Clinical Pharmacology & Therapeutics. 2002;72(1):50-61. Not CKD treatment. [pmid: 12152004].
3942 Schwartz MM, Lewis EJ, Leonard-Martin T, et al. Renal pathology patterns in type II diabetes mellitus: relationship with retinopathy. The Collaborative Study Group. Nephrology Dialysis Transplantation. 1998;13(10):2547-52. Sample size less than 50 patients.
3943 Schwartz RP. Recent advances in the management of diabetes mellitus. Indian Journal of Pediatrics. 1997;64(1):33-41. Not RCT or controlled trial. [pmid: 10771811].
3944 Schwartz Sorensen S, Eiskjaer H, Orskov H, et al. Effect of intravenous glucagon infusion on renal haemodynamics and renal tubular handling of sodium in healthy humans. Scandinavian Journal of Clinical & Laboratory Investigation. 1993;53(1):25-34. Sample size less than 50 patients. [pmid: 8451599].
3945 Schweizer A, Hohn L, Morel DR, et al. Aprotinin does not impair renal haemodynamics and function after cardiac surgery. British Journal of Anaesthesia. 2000;84(1):16-22. Not early CKD. [pmid: 10740541].
3946 Schwenk MH. Ferumoxytol: a new intravenous iron preparation for the treatment of iron deficiency anemia in patients with chronic kidney disease. Pharmacotherapy. Jan. 2010;30(1):70-9. Follow-up less than 6 months. [pmid: 20030475].
3947 Schwietzer GK, Hartmann A, Kober G, et al. Chronic angiotensin-converting enzyme inhibition may improve sodium excretion in cardiac transplant hypertension. Transplantation. 1995;59(7):999-1004. Sample size less than 50 patients. [pmid: 7709462].
3948 Scorza R, Rivolta R, Mascagni B, et al. Effect of iloprost infusion on the resistance index of renal vessels of patients with systemic sclerosis. Journal of Rheumatology. 1997;24(10):1944-8. Sample size less than 50 patients. [pmid: 9330936].
3949 Scott DA, Hore PJ, Cannata J, et al. A comparison of albumin, polygeline and crystalloid priming solutions for cardiopulmonary bypass in patients having coronary artery bypass graft surgery. Perfusion. 1995;10(6):415-24. Not CKD treatment. [pmid: 8747898].
3950 Sculier JP, Paesmans M, Thiriaux J, et al. A comparison of methods of calculation for estimating carboplatin AUC with a retrospective pharmacokinetic-pharmacodynamic analysis in patients with advanced non-small cell lung cancer. European Lung Cancer Working Party. European Journal of Cancer. 1999;35(9):1314-9. Not CKD treatment. [pmid: 10658520].
3951 Sear JW. Kidney dysfunction in the postoperative period. British Journal of Anaesthesia. 2005;95(1):20-32. Not RCT or controlled trial. [pmid: 15531622].
3952 Sebekova K, Ramuscak A, Boor P, et al. The selective TP receptor antagonist, S18886 (terutroban), attenuates renal damage in the double transgenic rat model of hypertension. American Journal of Nephrology. 2008;28(1):47-53. Follow-up less than 6 months. [pmid: 17890857].
3953 Seddon M, Curzen N. Coronary revascularisation in chronic kidney disease. Part II: acute coronary syndromes. Journal of Renal Care. May. Suppl 1. 2010;36:118-26. Not RCT or controlled trial. [pmid: 20586907].
3954 Sedlis SP, Jurkovitz CT, Hartigan PM, et al. Optimal medical therapy with or without percutaneous coronary intervention for patients with stable coronary artery disease and chronic kidney disease. American Journal of Cardiology. 2009;104(12):1647-53. Not CKD treatment. [pmid: 19962469].
3955 Sedrakyan A. Improving clinical outcomes in coronary artery bypass graft surgery. American Journal of Health-System Pharmacy. 2005;62(18 Suppl 4):S19-23. Not relevant to key questions. [pmid: 16227192].
3956 Segall L, Oprisiu R, Fournier A, et al. Antihypertensive treatment and stroke prevention in patients with and without chronic kidney disease: a review of controlled trials. Journal of Nephrology. 2008;21(3):374-83. Not CKD treatment. [pmid: 18587726].
3957 Segura J, Garcia-Donaire JA, Ruilope LM. Calcium channel blockers and renal protection: insights from the latest clinical trials. Journal of the American Society of Nephrology. Suppl 1. 2005;16:S64-6. Not relevant to key questions. [pmid: 15938037].
3958 Segura J, Praga M, Campo C, et al. Combination is better than monotherapy with ACE inhibitor or angiotensin receptor antagonist at recommended doses. Journal of the Renin-Angiotensin-Aldosterone System. 2003;4(1):43-7. Sample size less than 50 patients. [pmid: 12692753].
3959 Seidelin PH, McMurray JJ, Struthers AD. Mechanisms of the antinatriuretic action of physiological doses of angiotensin II in man. Clinical Science. 1989;76(6):653-8. Not CKD treatment. [pmid: 2736884].
3960 Seiler S. Anemia of chronic renal failure: new treatment alternative. Cannt Journal. 2000;10(3):35-9. Not CKD treatment. [pmid: 11799582].
3961 Sekkarie M, Cosma M, Mendelssohn D. Nonreferral and nonacceptance to dialysis by primary care physicians and nephrologists in Canada and the United States. American Journal of Kidney Diseases. 2001;38(1):36-41. Not CKD treatment. [pmid: 11431179].
3962 Selamet U, Kovaliv YB, Savage CO, et al. ANCA-associated vasculitis: new options beyond steroids and cytotoxic drugs. Expert Opinion on Investigational Drugs. 2007;16(5):689-703. Sample size less than 50 patients. [pmid: 17461741].
3963 Selvin E, Manzi J, Stevens LA, et al. Calibration of serum creatinine in the National Health and Nutrition Examination Surveys (NHANES) 1988-1994, 1999-2004. American Journal of Kidney Diseases. 2007;50(6):918-26. Sample size less than 50 patients. [pmid: 18037092].
3964 Semplicini A, Ceolotto G, Sartori M, et al. Regulation of glomerular filtration in essential hypertension: role of abnormal Na+ transport and atrial natriuretic peptide. Journal of Nephrology. 2002;15(5):489-96. Sample size less than 50 patients. [pmid: 12455714].
3965 Sener M, Torgay A, Akpek E, et al. The effect of anesthetic technique on early postoperative renal function after donor nephrectomy: a preliminary report. Transplantation Proceedings. 2005;37(5):2023-7. Not relevant to key questions. [pmid: 15964329].
3966 Seng WK, Hwang SJ, Han DC, et al. Losartan reduces the costs of diabetic end-stage renal disease: an Asian perspective. Nephrology. 2005;10(5):520-4. Sample size less than 50 patients. [pmid: 16221106].
3967 Serri O, Beauregard H, Brazeau P, et al. Somatostatin analogue, octreotide, reduces increased glomerular filtration rate and kidney size in insulin-dependent diabetes. JAMA. 1991;265(7):888-92. Not CKD treatment. [pmid: 1992187].
3968 Seth AK. Management of hepatitis C in HIV infected and other immunocompromised individuals. Tropical Gastroenterology. 2006;27(3):111-7. Sample size less than 50 patients. [pmid: 17310553].
3969 Seyon RA, Jensen LA, Ferguson IA, et al. Efficacy of N-acetylcysteine and hydration versus placebo and hydration in decreasing contrast-induced renal dysfunction in patients undergoing coronary angiography with or without concomitant percutaneous coronary intervention. Heart & Lung. 2007;36(3):195-204. Not RCT or controlled trial. [pmid: 17509426].
3970 Seyss C, Foote EF. Calcium-channel blockers for prophylaxis of radiocontrast-associated nephrotoxicity. Annals of Pharmacotherapy. 1995;29(2):187-8. Not CKD treatment. [pmid: 7756720].
3971 Sezai A, Hata M, Niino T, et al. Continuous low-dose infusion of human atrial natriuretic peptide in patients with left ventricular dysfunction undergoing coronary artery bypass grafting: the NU-HIT (Nihon University working group study of low-dose Human ANP Infusion Therapy during cardiac surgery) for left ventricular dysfunction. Journal of the American College of Cardiology. Apr. 27. 2010;55(17):1844-51. Not CKD treatment. [pmid: 20413036].
3972 Sezai A, Hata M, Niino T, et al. Influence of continuous infusion of low-dose human atrial natriuretic peptide on renal function during cardiac surgery: a randomized controlled study. Journal of the American College of Cardiology. 2009;54(12):1058-64. Not CKD treatment. [pmid: 19744614].
3973 Sgouros J, Maraveyas A. Excess premature (3-month) mortality in advanced pancreatic cancer could be related to fatal vascular thromboembolic events. A hypothesis based on a systematic review of phase III chemotherapy studies in advanced pancreatic cancer. Acta Oncologica. 2008;47(3):337-46. Sample size less than 50 patients. [pmid: 17957501].
3974 Shaefer MS. Current topics in immunotherapy and the role of the pharmacist on a solid organ transplant service. Pharmacotherapy. 1991;11(6):136S-41S. Not CKD treatment. [pmid: 1771138].
3975 Shafqat J, Juntti-Berggren L, Zhong Z, et al. Proinsulin C-peptide and its analogues induce intracellular Ca2+ increases in human renal tubular cells. Cellular & Molecular Life Sciences. 2002;59(7):1185-9. Not CKD treatment. [pmid: 12222964].
3976 Shah A, Lettieri J, Blum R, et al. Pharmacokinetics of intravenous ciprofloxacin in normal and renally impaired subjects. Journal of Antimicrobial Chemotherapy. 1996;38(1):103-16. Sample size less than 50 patients. [pmid: 8858462].
3977 Shah HN, Hegde SS, Shah JN, et al. Safety and efficacy of supracostal access in tubeless percutaneous nephrolithotomy. [Erratum appears in J Endourol. 2007 Jan;21(1):118 Note: Shah, Hemendra [corrected to Shah, Hemendra N]; Hegde, Sunil [corrected to Hegde, Sunil S]; Shah, Jignesh [corrected to Shah, Jignesh N]; Bansal, Manish [corrected to Bansal, Manish B]]. Journal of Endourology. 2006;20(12):1016-21. Not early CKD. [pmid: 17206894].
3978 Shah S, Paparello J, Danesh FR. Effects of statin therapy on the progression of chronic kidney disease. Advances in Chronic Kidney Disease. 2005;12(2):187-95. Follow-up less than 6 months. [pmid: 15822054].
3979 Shah SV. Progress toward novel treatments for chronic kidney disease. Journal of Renal Nutrition. Sep. 2010;20(5 Suppl):S122-6. Not relevant to key questions. [pmid: 20797560].
3980 Shaheen FA, Mansuri NA, al-Shaikh AM, et al. Reversible uremic deafness: is it correlated with the degree of anemia?. Annals of Otology, Rhinology & Laryngology. 1997;106(5):391-3. Not CKD treatment.
3981 Shahinfar S, Dickson TZ, Ahmed T, et al. Losartan in patients with type 2 diabetes and proteinuria: observations from the RENAAL Study. Kidney International - Supplement. 2002;(82):S64-7. Not RCT or controlled trial. [pmid: 12410858].
3982 Shahinfar S, Lyle PA, Zhang Z, et al. Losartan: lessons learned from the RENAAL study. Expert Opinion on Pharmacotherapy. 2006;7(5):623-30. Not relevant to key questions. [pmid: 16553578].
3983 Shand BI. Haemorheological effects of losartan and enalapril in patients with renal parenchymal disease and hypertension. Journal of Human Hypertension. 2000;14(5):305-9. Sample size less than 50 patients. [pmid: 10822316].
3984 Shara NM, Umans JG, Wang W, et al. Assessing the impact of different imputation methods on serial measures of renal function: the Strong Heart Study. Kidney International. 2007;71(7):701-5. Sample size less than 50 patients. [pmid: 17264875].
3985 Sharma AK, Arora M, Goyle A, et al. Lipid peroxide levels in chronic renal failure. Journal of the Association of Physicians of India. 1999;47(3):296-7. Not RCT or controlled trial. [pmid: 10999124].
3986 Sharma AM, Hollander A, Koster J, et al. Telmisartan in patients with mild/moderate hypertension and chronic kidney disease. Clinical Nephrology. 2005;63(4):250-7. Not RCT or controlled trial. [pmid: 15847251].
3987 Sharma K, Eltayeb BO, McGowan TA, et al. Captopril-induced reduction of serum levels of transforming growth factor-beta1 correlates with long-term renoprotection in insulin-dependent diabetic patients. [Erratum appears in Am J Kidney Dis 2000 Mar;35(3):572]. American Journal of Kidney Diseases. 1999;34(5):818-23. Sample size less than 50 patients. [pmid: 10561136].
3988 Sharma SK, Kini A. Effect of nonionic radiocontrast agents on the occurrence of contrast-induced nephropathy in patients with mild-moderate chronic renal insufficiency: pooled analysis of the randomized trials. Catheterization & Cardiovascular Interventions. 2005;65(3):386-93. Not relevant to key questions. [pmid: 15926184].
3989 Shehata N, Kouroukis C, Kelton JG. A review of randomized controlled trials using therapeutic apheresis. Transfusion Medicine Reviews. 2002;16(3):200-29. Not CKD treatment. [pmid: 12075559].
3990 Sheinfeld GR, Bakris GL. Benefits of combination angiotensin-converting enzyme inhibitor and calcium antagonist therapy for diabetic patients. American Journal of Hypertension. 1999;12(8 Pt 2):80S-5S. Not RCT or controlled trial. [pmid: 10478701].
3991 Shemin D, Bostom AG, Selhub J. Treatment of hyperhomocysteinemia in end-stage renal disease. American Journal of Kidney Diseases. 2001;38(4 Suppl 1):S91-4. Not early CKD. [pmid: 11576930].
3992 Shenker Y. Atrial natriuretic hormone effect on renal function and aldosterone secretion in sodium depletion. American Journal of Physiology. 1988;255(6 Pt 2):R867-73. Sample size less than 50 patients. [pmid: 2974252].
3993 Shepherd J, Hunninghake DB, Stein EA, et al. Safety of rosuvastatin. American Journal of Cardiology. 2004;94(7):882-8. Follow-up less than 6 months. [pmid: 15464670].
3994 Shepherd J, Kastelein JJP, Bittner V, et al. Effect of intensive lipid lowering with atorvastatin on renal function in patients with coronary heart disease: the Treating to New Targets (TNT) study. Clinical Journal of The American Society of Nephrology: CJASN. 2007;2(6):1131-9. Not CKD treatment. [pmid: 17942759].
3995 Shepherd J, Kastelein JP, Bittner VA, et al. Intensive lipid lowering with atorvastatin in patients with coronary artery disease, diabetes, and chronic kidney disease. Mayo Clinic Proceedings. 2008;83(8):870-9. Not relevant to key questions. [pmid: 18674471].
3996 Sheu BS, Huang JJ, Yang HB, et al. The selection of triple therapy for Helicobacter pylori eradication in chronic renal insufficiency. Alimentary Pharmacology & Therapeutics. 2003;17(10):1283-90. Not CKD treatment. [pmid: 12755841].
3997 Shiba T, Inoue M, Tada H, et al. Delapril versus manidipine in hypertensive therapy to halt the type-2-diabetes-mellitus-associated nephropathy. Diabetes Research & Clinical Practice. 2000;47(2):97-104. Sample size less than 50 patients. [pmid: 10670908].
3998 Shibasaki T, Nakano H, Matsuda H, et al. Pravastatin administration to hyperlipidemia in patients with nephrotic syndrome. Nippon Jinzo Gakkai Shi. Japanese Journal of Nephrology. 1993;35(11):1243-8. Not RCT or controlled trial. [pmid: 8139136].
3999 Shibasaki Y, Nishiue T, Masaki H, et al. Impact of the angiotensin II receptor antagonist, losartan, on myocardial fibrosis in patients with end-stage renal disease: assessment by ultrasonic integrated backscatter and biochemical markers. Hypertension Research - Clinical & Experimental. 2005;28(10):787-95. Not RCT or controlled trial.
4000 Shichiri M, Kishikawa H, Ohkubo Y, et al. Long-term results of the Kumamoto Study on optimal diabetes control in type 2 diabetic patients. Diabetes Care. Suppl 2. 2000;23:B21-9. Not early CKD. [pmid: 10860187].
4001 Shiga Microalbuminuria Reduction Trial G., Uzu T, Sawaguchi M, et al. Reduction of microalbuminuria in patients with type 2 diabetes: the Shiga Microalbuminuria Reduction Trial (SMART). Diabetes Care. 2007;30(6):1581-3. Not RCT or controlled trial. [pmid: 17363751].
4002 Shiga Microalbuminuria Reduction Trial G., Uzu T, Sawaguchi M, et al. Impact of renin-angiotensin system inhibition on microalbuminuria in type 2 diabetes: a post hoc analysis of the Shiga Microalbuminuria Reduction Trial (SMART). Hypertension Research - Clinical & Experimental. 2008;31(6):1171-6. Follow-up less than 6 months.
4003 Shiga T, Hashiguchi M, Urae A, et al. Effect of cimetidine and probenecid on pilsicainide renal clearance in humans. Clinical Pharmacology & Therapeutics. 2000;67(3):222-8. Not early CKD. [pmid: 10741624].
4004 Shigihara T, Sato A, Hayashi K, et al. Effect of combination therapy of angiotensin-converting enzyme inhibitor plus calcium channel blocker on urinary albumin excretion in hypertensive microalbuminuric patients with type II diabetes. Hypertension Research - Clinical & Experimental. 2000;23(3):219-26. Sample size less than 50 patients.
4005 Shih YC, Kauf TL. Reconciling decision models with the real world. An application to anaemia of renal failure. Pharmacoeconomics. 1999;15(5):481-93. Not CKD treatment. [pmid: 10537965].
4006 Shiigai T, Hattori K, Iwamoto H, et al. Long-term enalapril therapy in patients with chronic renal failure on a low-protein diet. A prospective randomized comparison with metoprolol. Nephron. 1998;79(2):148-53. Sample size less than 50 patients. [pmid: 9647493].
4007 Shik J, Parfrey PS. The clinical epidemiology of cardiovascular disease in chronic kidney disease. Current Opinion in Nephrology & Hypertension. 2005;14(6):550-7. Not relevant to key questions. [pmid: 16205474].
4008 Shilliday I, Allison ME. Diuretics in acute renal failure. Renal Failure. 1994;16(1):3-17. Not CKD treatment. [pmid: 8184144].
4009 Shilliday IR, Allison ME. Intraplatelet calcium levels in patients with acute renal failure before and after the administration of loop diuretics. [Erratum appears in Nephrol Dial Transplant 2001 Sep;16(9):1964]. Nephrology Dialysis Transplantation. 2001;16(3):552-5. Not early CKD.
4010 Shilliday IR, Quinn KJ, Allison ME. Loop diuretics in the management of acute renal failure: a prospective, double-blind, placebo-controlled, randomized study. Nephrology Dialysis Transplantation. 1997;12(12):2592-6. Not CKD treatment.
4011 Shimizu H, Ohtani K, Tanaka Y, et al. Increased plasma thrombin-antithrombin III complex levels in non-insulin dependent diabetic patients with albuminuria are reduced by ethyl icosapentatenoate. Thrombosis & Haemostasis. 1995;74(5):1231-4. Not CKD treatment. [pmid: 8607100].
4012 Shimizu H, Ohtani K, Tanaka Y, et al. Long-term effect of eicosapentaenoic acid ethyl (EPA-E) on albuminuria of non-insulin dependent diabetic patients. Diabetes Research & Clinical Practice. 1995;28(1):35-40. Not early CKD. [pmid: 7587910].
4013 Shionoiri H, Sugimoto K, Kosaka T, et al. Long-term therapy with an ACE inhibitor, temocapril, reduces microalbuminuria in essential hypertension. Hypertension Research - Clinical & Experimental. 1998;21(2):81-7. Not relevant to key questions.
4014 Shirley DG, Walter SJ, Noormohamed FH. Natriuretic effect of caffeine: assessment of segmental sodium reabsorption in humans. Clinical Science. 2002;103(5):461-6. Sample size less than 50 patients. [pmid: 12401118].
4015 Shirley DG, Walter SJ, Skinner J, et al. The natriuretic effect of lithium in man: is the proximal tubule involved?. Scandinavian Journal of Clinical & Laboratory Investigation. 1995;55(7):635-42. Not CKD treatment. [pmid: 8633188].
4016 Shlipak MG, Massie BM. The clinical challenge of cardiorenal syndrome. Circulation. 2004;110(12):1514-7. Not relevant to key questions. [pmid: 15381655].
4017 Shlipak MG, Smith GL, Rathore SS, et al. Renal function, digoxin therapy, and heart failure outcomes: evidence from the digoxin intervention group trial. Journal of the American Society of Nephrology. 2004;15(8):2195-203. Sample size less than 50 patients. [pmid: 15284305].
4018 Shlipak MG, Stehman-Breen C, Vittinghoff E, et al. Creatinine levels and cardiovascular events in women with heart disease: do small changes matter?. American Journal of Kidney Diseases. 2004;43(1):37-44. Not CKD treatment. [pmid: 14712425].
4019 Shobha TR, Prakash O. Glycosuria in organophosphate and carbamate poisoning. Journal of the Association of Physicians of India. 2000;48(12):1197-9. Not early CKD. [pmid: 11280228].
4020 Shoemaker WC, Appel PL, Kram HB. Oxygen transport measurements to evaluate tissue perfusion and titrate therapy: dobutamine and dopamine effects. Critical Care Medicine. 1991;19(5):672-88. Not CKD treatment. [pmid: 2026030].
4021 Shoji T, Wada A, Inoue K, et al. Prospective randomized study evaluating the efficacy of the spherical adsorptive carbon AST-120 in chronic kidney disease patients with moderate decrease in renal function. Nephron. 2007;105(3):c99-107. Not RCT or controlled trial. [pmid: 17179734].
4022 Shroff R, Knott C, Rees L. The virtues of vitamin D--but how much is too much?. Pediatric Nephrology. Sep. 2010;25(9):1607-20. Not RCT or controlled trial. [pmid: 20393752].
4023 Shurraw S, Tonelli M. Statins for treatment of dyslipidemia in chronic kidney disease. Peritoneal Dialysis International. 2006;26(5):523-39. Sample size less than 50 patients. [pmid: 16973506].
4024 Shy BD, Gupta A, Hoffman RS. Sodium bicarbonate vs sodium chloride in preventing contrast medium-induced nephropathy. JAMA. 2009;301(4):377-8. author reply 9-80. Not CKD treatment. [pmid: 19176435].
4025 Shyu KG, Cheng JJ, Kuan P. Acetylcysteine protects against acute renal damage in patients with abnormal renal function undergoing a coronary procedure. Journal of the American College of Cardiology. 2002;40(8):1383-8. Not CKD treatment. [pmid: 12392825].
4026 Sibai BM. Risk factors, pregnancy complications, and prevention of hypertensive disorders in women with pregravid diabetes mellitus. Journal of Maternal-Fetal Medicine. 2000;9(1):62-5. Not early CKD. [pmid: 10757438].
4027 Sibai BM. Imitators of severe preeclampsia. Obstetrics & Gynecology. 2007;109(4):956-66. Not RCT or controlled trial. [pmid: 17400860].
4028 Sica DA. ALLHAT: is the final answer in?. Heart Disease. 2003;5(3):171-5. Not RCT or controlled trial. [pmid: 12783629].
4029 Sidharta PN, Wagner FD, Bohnemeier H, et al. Pharmacodynamics and pharmacokinetics of the urotensin II receptor antagonist palosuran in macroalbuminuric, diabetic patients. Clinical Pharmacology & Therapeutics. 2006;80(3):246-56. Not RCT or controlled trial. [pmid: 16952491].
4030 Siebenhofer A, Plank J, Horvath K, et al. Angiotensin receptor blockers as anti-hypertensive treatment for patients with diabetes mellitus: meta-analysis of controlled double-blind randomized trials. Diabetic Medicine. 2004;21(1):18-25. Not CKD treatment. [pmid: 14706049].
4031 Siegel J, Jorgenson J, Johnson PE, et al. Use and prescribing patterns for erythropoiesis-stimulating agents in inpatient and outpatient hospital settings. American Journal of Health-System Pharmacy. 2008;65(18):1711-9. Not CKD treatment. [pmid: 18768997].
4032 Siegers CP, Andresen S, Keogh JP. Does cimetidine improve prospects for cancer patients?. A reappraisal of the evidence to date. Digestion. 1999;60(5):415-21. Not RCT or controlled trial. [pmid: 10473965].
4033 Siewert-Delle A, Ljungman S, Andersson OK, et al. Does treated primary hypertension lead to end-stage renal disease? A 20-year follow-up of the Primary Prevention Study in Goteborg, Sweden. Nephrology Dialysis Transplantation. 1998;13(12):3084-90. Not RCT or controlled trial.
4034 Siewert-Delle A, Ljungman S, Hartford M, et al. Effects of intensified blood-pressure reduction on renal function and albumin excretion in primary hypertension. Addition of felodipine or ramipril to long-term treatment with beta-blockade. American Journal of Hypertension. 1995;8(2):113-23. Sample size less than 50 patients. [pmid: 7755939].
4035 Siewert-Delle A, Ljungman S, Hartford M, et al. Effect of 14 years of antihypertensive treatment on renal function and urinary albumin excretion in primary hypertension. American Journal of Hypertension. 1996;9(9):841-9. Sample size less than 50 patients. [pmid: 8879339].
4036 Sikka R, Waters J, Moore W, et al. Renal assessment practices and the effect of nurse case management of health maintenance organization patients with diabetes. Diabetes Care. 1999;22(1):1-6. Not RCT or controlled trial. [pmid: 10333895].
4037 Sikole A, Efremov DG, Dimovski A, et al. Hemoglobin F levels in end-stage renal disease patients after correction of anemia with erythropoietin. Nephron. 1993;65(3):482-4. Sample size less than 50 patients. [pmid: 7507224].
4038 Silver MA, Yancy CW. Using homeostatic peptides in decompensated heart failure a reasonable paradigm but a flawed practice?. Journal of the American College of Cardiology. 2007;50(19):1841-3. Follow-up less than 6 months. [pmid: 17980249].
4039 Silverberg DS, Wexler D, Blum M, et al. The effect of correction of anaemia in diabetics and non-diabetics with severe resistant congestive heart failure and chronic renal failure by subcutaneous erythropoietin and intravenous iron. Nephrology Dialysis Transplantation. 2003;18(1):141-6. Not RCT or controlled trial.
4040 Silverberg DS, Wexler D, Iaina A, et al. The interaction between heart failure and other heart diseases, renal failure, and anemia. Seminars in Nephrology. 2006;26(4):296-306. Follow-up less than 6 months. [pmid: 16949468].
4041 Silverberg DS, Wexler D, Iaina A, et al. Anaemia management in cardio renal disease. Journal of Renal Care. May. Suppl 1. 2010;36:86-96. Not RCT or controlled trial. [pmid: 20586904].
4042 Sima AAF. Diabetic neuropathy in type 1 and type 2 diabetes and the effects of C-peptide. Journal of the Neurological Sciences. 2004;220(1-2):133-6. Not relevant to key questions. [pmid: 15140622].
4043 Simon AH, Lima PR, Almerinda M, et al. Renal haemodynamic responses to a chicken or beef meal in normal individuals. Nephrology Dialysis Transplantation. 1998;13(9):2261-4. Sample size less than 50 patients.
4044 Simon SR, Trinacty CM, Soumerai SB, et al. Improving diabetes care among patients overdue for recommended testing: a randomized controlled trial of automated telephone outreach. Diabetes Care. Jul. 2010;33(7):1452-3. Not CKD treatment. [pmid: 20357376].
4045 Sinert R, Doty CI. Evidence-based emergency medicine review. Prevention of contrast-induced nephropathy in the emergency department. Annals of Emergency Medicine. 2007;50(3):335-45. Not RCT or controlled trial. [pmid: 17512638].
4046 Singer DR, Markandu ND, Miller MA, et al. Potassium channel stimulation in normal subjects and in patients with essential hypertension: an acute study with cromakalim (BRL 34915). Journal of Hypertension - Supplement. 1989;7(6):S294-5. Sample size less than 50 patients.
4047 Singer DR, Shirley DG, Markandu ND, et al. How important are suppression of aldosterone and stimulation of atrial natriuretic peptide secretion in the natriuretic response to an acute sodium load in man?. Clinical Science. 1991;80(4):293-9. Sample size less than 50 patients. [pmid: 1851063].
4048 Singer I, Epstein M. Potential of dopamine A-1 agonists in the management of acute renal failure. American Journal of Kidney Diseases. 1998;31(5):743-55. Not CKD treatment. [pmid: 9590183].
4049 Singer P. High-dose amino acid infusion preserves diuresis and improves nitrogen balance in non-oliguric acute renal failure. Wiener Klinische Wochenschrift. 2007;119(7-8):218-22. Not early CKD. [pmid: 17492348].
4050 Singh A, Gupta U, Sagar S, et al. Comparative bioequivalence study of furosemide in patients with edema of renal origin. International Journal of Clinical Pharmacology, Therapy, & Toxicology. 1987;25(3):136-8. Sample size less than 50 patients.
4051 Singh A, Patel T, Hertel J, et al. Safety of ferumoxytol in patients with anemia and CKD. American Journal of Kidney Diseases. 2008;52(5):907-15. Not RCT or controlled trial. [pmid: 18824288].
4052 Singh AK. The target hemoglobin in patients with chronic kidney disease. Nephrology News & Issues. 2006;20(13):29-30. Sample size less than 50 patients. [pmid: 17168056].
4053 Singh AK. The controversy surrounding hemoglobin and erythropoiesis-stimulating agents: what should we do now?. American Journal of Kidney Diseases. 2008;52(6 Suppl):S5-13. Not early CKD. [pmid: 19010260].
4054 Singh AK. Does TREAT give the boot to ESAs in the treatment of CKD anemia?. Journal of the American Society of Nephrology. 2010;21(1):2-6. Not RCT or controlled trial. [pmid: 20035034].
4055 Singh AK. What is causing the mortality in treating the anemia of chronic kidney disease: erythropoietin dose or hemoglobin level?. Current Opinion in Nephrology & Hypertension. Sep. 2010;19(5):420-4. Not RCT or controlled trial. [pmid: 20689425].
4056 Singh AK. Diabetes, anemia and CKD: Why TREAT?. Current Diabetes Reports. Aug. 2010;10(4):291-6. Not RCT or controlled trial. [pmid: 20544312].
4057 Singh AK, Szczech L, Tang KL, et al. Anaemia of CKD--the CHOIR study revisited. Nephrology Dialysis Transplantation. 2007;22(7):1806-10. Not RCT or controlled trial.
4058 Singh AK, Szczech L, Tang KL, et al. Correction of anemia with epoetin alfa in chronic kidney disease. New England Journal of Medicine. 2006;355(20):2085-98. Not CKD treatment. [pmid: 17108343].
4059 Singh N, Limaye AP, Forrest G, et al. Combination of voriconazole and caspofungin as primary therapy for invasive aspergillosis in solid organ transplant recipients: a prospective, multicenter, observational study. Transplantation. 2006;81(3):320-6. Sample size less than 50 patients. [pmid: 16477215].
4060 Singh NP, Aggarwal L, Singh T, et al. Anaemia, iron studies and erythropoietin in patients of chronic renal failure. Journal of the Association of Physicians of India. 1999;47(3):284-90. Sample size less than 50 patients. [pmid: 10999121].
4061 Singh NP, Ingle GK, Saini VK, et al. Prevalence of low glomerular filtration rate, proteinuria and associated risk factors in North India using Cockcroft-Gault and Modification of Diet in Renal Disease equation: an observational, cross-sectional study. BMC Nephrology. 2009;10:4. Not RCT or controlled trial. [pmid: 19220921].
4062 Singh V, Deedwania P. Reducing morbidity and mortality in high risk patients with statins. Vascular Health & Risk Management. 2009;5(2):495-507. Not RCT or controlled trial. [pmid: 19554090].
4063 Singh-Franco D, Machado C, Tuteja S, et al. Trospium chloride for the treatment of overactive bladder with urge incontinence. Clinical Therapeutics. 2005;27(5):511-30. Follow-up less than 6 months. [pmid: 15978301].
4064 Sinsakul M, Sika M, Rodby R, et al. A randomized trial of a 6-week course of celecoxib on proteinuria in diabetic kidney disease. American Journal of Kidney Diseases. 2007;50(6):946-51. Not RCT or controlled trial. [pmid: 18037095].
4065 Siragy HM. Angiotensin receptor blockers: how important is selectivity?. American Journal of Hypertension. 2002;15(11):1006-14. Not relevant to key questions. [pmid: 12441224].
4066 Siragy HM. Comparing angiotensin II receptor blockers on benefits beyond blood pressure. Advances in Therapy. May. 2010;27(5):257-84. Not RCT or controlled trial. [pmid: 20524096].
4067 Sirivella S, Gielchinsky I, Parsonnet V. Mannitol, furosemide, and dopamine infusion in postoperative renal failure complicating cardiac surgery. Annals of Thoracic Surgery. 2000;69(2):501-6. Not early CKD. [pmid: 10735688].
4068 Sisillo E, Ceriani R, Bortone F, et al. N-acetylcysteine for prevention of acute renal failure in patients with chronic renal insufficiency undergoing cardiac surgery: a prospective, randomized, clinical trial. Critical Care Medicine. 2008;36(1):81-6. Not RCT or controlled trial. [pmid: 18090169].
4069 Sitprija V, Lumlertgul D. Angiotensin converting enzyme inhibitor and chronic renal failure. Journal of the Medical Association of Thailand. 1993;76(7):359-67. Sample size less than 50 patients. [pmid: 8089635].
4070 Sjoland JA, Pedersen RS, Jespersen J, et al. Intraperitoneal heparin ameliorates the systemic inflammatory response in PD patients. Nephron. 2005;100(4):c105-10. Not relevant to key questions. [pmid: 15849476].
4071 Sketch MH Jr., Whelton A, Schollmayer E, et al. Prevention of contrast media-induced renal dysfunction with prostaglandin E1: a randomized, double-blind, placebo-controlled study. American Journal of Therapeutics. 2001;8(3):155-62. Follow-up less than 6 months. [pmid: 11344383].
4072 Skott P, Hommel E, Bruun NE, et al. Effects of acetazolamide on kidney function in type 1 (insulin-dependent) diabetic patients with diabetic nephropathy. Diabetologia. 1988;31(11):806-10. Follow-up less than 6 months. [pmid: 3234635].
4073 Skov AR, Toubro S, Bulow J, et al. Changes in renal function during weight loss induced by high vs low-protein low-fat diets in overweight subjects. International Journal of Obesity & Related Metabolic Disorders: Journal of the International Association for the Study of Obesity. 1999;23(11):1170-7. Not early CKD. [pmid: 10578207].
4074 Skovgaard N, Holm J, Hemmingsen L, et al. Urinary protein excretion following intravenously administered ionic and non-ionic contrast media in man. Acta Radiologica. 1989;30(5):517-9. Sample size less than 50 patients. [pmid: 2692667].
4075 Skroeder NR, Jacobson SH, Lins LE, et al. Biocompatibility of dialysis membranes is of no importance for objective or subjective symptoms during or after hemodialysis. ASAIO Transactions. 1990;36(3):M637-9. Not CKD treatment. [pmid: 2252771].
4076 Slagman MCJ, Navis G, Laverman GD. Dual blockade of the renin-angiotensin-aldosterone system in cardiac and renal disease. Current Opinion in Nephrology & Hypertension. Mar. 2010;19(2):140-52. Not relevant to key questions. [pmid: 20051849].
4077 Slagman MCJ, Sinkeler SJ, Hemmelder MH, et al. Erythropoietin is reduced by combination of diuretic therapy and RAAS blockade in proteinuric renal patients with preserved renal function. Nephrology Dialysis Transplantation. Oct. 2010;25(10):3256-60. Follow-up less than 6 months.
4078 Slataper R, Vicknair N, Sadler R, et al. Comparative effects of different antihypertensive treatments on progression of diabetic renal disease. Archives of Internal Medicine. 1993;153(8):973-80. Sample size less than 50 patients. [pmid: 8386921].
4079 Slaven GM, Walker RJ, Zacharias M, et al. Tenoxicam does not alter renal function during anaesthesia in normal individuals. Australian & New Zealand Journal of Medicine. 1998;28(6):772-6. Not CKD treatment. [pmid: 9972405].
4080 Slotman GJ, Kerstein MD, Bone RC, et al. The effects of prostaglandin E1 on non-pulmonary organ function during clinical acute respiratory failure. The Prostaglandin E1 Study Group. Journal of Trauma-Injury Infection & Critical Care. 1992;32(4):480-8. discussion 8-9. Not CKD treatment.
4081 Slowik MM. Early education of patients with chronic renal insufficiency: the Healthy Start program. Case study of the anemic patient. Nephrology Nursing Journal: Journal of the American Nephrology Nurses' Association. 2001;28(6):643-6. Not relevant to key questions. [pmid: 12143474].
4082 Small EJ, Halabi S, Kantoff P, et al. Activities and accomplishments of the cancer and leukemia group B genitourinary committee. Clinical Cancer Research. 2006;12(11 Pt 2):3596s-600s. Follow-up less than 6 months. [pmid: 16740791].
4083 Smalley RV, Guaspari A, Haase-Statz S, et al. Allopurinol: intravenous use for prevention and treatment of hyperuricemia. [Erratum appears in J Clin Oncol 2000 May;18(10):2188]. Journal of Clinical Oncology. 2000;18(8):1758-63. Not early CKD. [pmid: 10764437].
4084 Smebye ML, Iversen EK, Hoieggen A, et al. Effect of hemoglobin levels on cardiovascular outcomes in patients with isolated systolic hypertension and left ventricular hypertrophy (from the LIFE study). American Journal of Cardiology. 2007;100(5):855-9. Not relevant to key questions. [pmid: 17719333].
4085 Smilde TDJ, Linssen GCM, Gallemann D, et al. Influence of renal dysfunction on the pharmacokinetics of the selective Na+/H+ exchange inhibitor EMD 87 580 in patients with chronic heart failure. International Journal of Clinical Pharmacology & Therapeutics. 2005;43(11):507-16. Sample size less than 50 patients. [pmid: 16300166].
4086 Smit AJ, Meijer S, Wesseling H, et al. Effect of metoclopramide on dopamine-induced changes in renal function in healthy controls and in patients with renal disease. Clinical Science. 1988;75(4):421-8. Sample size less than 50 patients. [pmid: 2904313].
4087 Smith AC, Toto R, Bakris GL. Differential effects of calcium channel blockers on size selectivity of proteinuria in diabetic glomerulopathy. Kidney International. 1998;54(3):889-96. Sample size less than 50 patients. [pmid: 9734613].
4088 Smith DG, Nguyen AB, Peak CN, et al. Markov modeling analysis of health and economic outcomes of therapy with valsartan versus amlodipine in patients with type 2 diabetes and microalbuminuria. Journal of Managed Care Pharmacy. 2004;10(1):26-32. Not CKD treatment. [pmid: 14720103].
4089 Smith DH, Johnson ES, Thorp ML, et al. Outcomes predicted by phosphorous in chronic kidney disease: a retrospective CKD-inception cohort study. Nephrology Dialysis Transplantation. 2010;25(1):166-74. Not RCT or controlled trial.
4090 Smith DHG. Treatment of hypertension with an angiotensin II-receptor antagonist compared with an angiotensin-converting enzyme inhibitor: a review of clinical studies of telmisartan and enalapril. Clinical Therapeutics. 2002;24(10):1484-501. Not relevant to key questions. [pmid: 12462282].
4091 Smith HJ, Levorstad K, Berg KJ, et al. High dose urography in patients with renal failure. A double blind investigation of iohexol and metrizoate. Acta Radiologica: Diagnosis. 1985;26(2):213-20. Sample size less than 50 patients. [pmid: 3993426].
4092 Smith MC, Austen JL, Carey JT, et al. Prednisone improves renal function and proteinuria in human immunodeficiency virus-associated nephropathy. American Journal of Medicine. 1996;101(1):41-8. Sample size less than 50 patients. [pmid: 8686713].
4093 Smith MNA, Best D, Sheppard SV, et al. The effect of mannitol on renal function after cardiopulmonary bypass in patients with established renal dysfunction. Anaesthesia. 2008;63(7):701-4. Not early CKD. [pmid: 18582254].
4094 Smith SR, Coffman TM, Svetkey LP. Effect of low-dose aspirin on thromboxane production and the antihypertensive effect of captopril. Journal of the American Society of Nephrology. 1993;4(5):1133-9. Follow-up less than 6 months. [pmid: 8305640].
4095 Smolander J, Vogt B, Maillard M, et al. Dose-dependent acute and sustained renal effects of the endothelin receptor antagonist avosentan in healthy subjects. Clinical Pharmacology & Therapeutics. 2009;85(6):628-34. Not CKD treatment. [pmid: 19279566].
4096 Snetselaar L. MDRD study enters clinical phases … as the recruitment of patients begins. Modification of Diet and Renal Disease. Nephrology News & Issues. 1990;4(3):14-5. Not RCT or controlled trial. [pmid: 2181323].
4097 Snir N, Moskovitz B, Nativ O, et al. Papaverine hydrochloride for the treatment of renal colic: an old drug revisited. A prospective, randomized study. Journal of Urology. 2008;179(4):1411-4. Not CKD treatment. [pmid: 18289563].
4098 Sobh MA, Moustafa FE, Sally SM, et al. A prospective, randomized therapeutic trial for schistosomal specific nephropathy. Kidney International. 1989;36(5):904-7. Sample size less than 50 patients. [pmid: 2515342].
4099 Sobue S, Tan K, Layton G, et al. The effects of renal impairment on the pharmacokinetics and safety of fosfluconazole and fluconazole following a single intravenous bolus injection of fosfluconazole. British Journal of Clinical Pharmacology. 2004;57(6):773-84. Not relevant to key questions. [pmid: 15151523].
4100 Sochman J. N-acetylcysteine somewhere between Scylla and Charybdis. Journal of the American College of Cardiology. Sep. 21. 2010;56(13):1067. author reply -8. Not RCT or controlled trial. [pmid: 20846610].
4101 Sola-Vera J, Minana J, Ricart E, et al. Randomized trial comparing albumin and saline in the prevention of paracentesis-induced circulatory dysfunction in cirrhotic patients with ascites. Hepatology. 2003;37(5):1147-53. Not CKD treatment. [pmid: 12717396].
4102 Solerte SB, Fioravanti M, Bozzetti A, et al. Pentoxifylline, albumin excretion rate and proteinuria in type I and type II diabetic patients with microproteinuria. Results of a short-term randomized study. Acta Diabetologica Latina. 1986;23(2):171-7. Not relevant to key questions. [pmid: 3751450].
4103 Solerte SB, Fioravanti M, Patti AL, et al. Pentoxifylline, total urinary protein excretion rate and arterial blood pressure in long-term insulin-dependent diabetic patients with overt nephropathy. Acta Diabetologica Latina. 1987;24(3):229-39. Sample size less than 50 patients. [pmid: 3687315].
4104 Solini A, Vergnani L, Ricci F, et al. Glycosaminoglycans delay the progression of nephropathy in NIDDM. Diabetes Care. 1997;20(5):819-23. Follow-up less than 6 months. [pmid: 9135948].
4105 Solmazgul E, Uzun G, Cermik H, et al. Hyperbaric oxygen therapy attenuates renal ischemia/reperfusion injury in rats. Urologia Internationalis. 2007;78(1):82-5. Not early CKD. [pmid: 17192739].
4106 Solomon LR, Atherton JC, Bobinski H, et al. Effect of a meal containing protein on lithium clearance and plasma immunoreactive atrial natriuretic peptide in man. Clinical Science. 1988;75(2):151-7. Not RCT or controlled trial. [pmid: 2970361].
4107 Solomon LR, Atherton JC, Bobinski H, et al. Effect of low dose infusion of atrial natriuretic peptide on renal function in man. Clinical Science. 1988;75(4):403-10. Sample size less than 50 patients. [pmid: 2973849].
4108 Solomon LR, Hendler ED. Prospective controlled study of androgen therapy in the anemia of chronic renal disease: effects on iron kinetics. Acta Haematologica. 1988;79(1):12-9. Follow-up less than 6 months. [pmid: 3124456].
4109 Solomon R, Werner C, Mann D, et al. Effects of saline, mannitol, and furosemide to prevent acute decreases in renal function induced by radiocontrast agents. New England Journal of Medicine. 1994;331(21):1416-20. Not CKD treatment. [pmid: 7969280].
4110 Solomon RJ, Mehran R, Natarajan MK, et al. Contrast-induced nephropathy and long-term adverse events: cause and effect?. Clinical Journal of The American Society of Nephrology: CJASN. 2009;4(7):1162-9. Not CKD treatment. [pmid: 19556381].
4111 Solomon RJ, Natarajan MK, Doucet S, et al. Cardiac Angiography in Renally Impaired Patients (CARE) study: a randomized double-blind trial of contrast-induced nephropathy in patients with chronic kidney disease. Circulation. 2007;115(25):3189-96. Not RCT or controlled trial. [pmid: 17562951].
4112 Solomon SD, Lin J, Solomon CG, et al. Influence of albuminuria on cardiovascular risk in patients with stable coronary artery disease. Circulation. 2007;116(23):2687-93. Sample size less than 50 patients. [pmid: 18025537].
4113 Solomon SD, Rice MM, A Jablonski K, et al. Renal function and effectiveness of angiotensin-converting enzyme inhibitor therapy in patients with chronic stable coronary disease in the Prevention of Events with ACE inhibition (PEACE) trial. Circulation. 2006;114(1):26-31. Follow-up less than 6 months. [pmid: 16801465].
4114 Solomon SD, Uno H, Lewis EF, et al. Erythropoietic response and outcomes in kidney disease and type 2 diabetes. New England Journal of Medicine. Sep. 16. 2010;363(12):1146-55. Follow-up less than 6 months. [pmid: 20843249].
4115 Soma J, Saito T, Taguma Y, et al. High prevalence and adverse effect of hepatitis C virus infection in type II diabetic-related nephropathy. Journal of the American Society of Nephrology. 2000;11(4):690-9. Not early CKD. [pmid: 10752528].
4116 Soma J, Sato K, Saito H, et al. Effect of tranilast in early-stage diabetic nephropathy. Nephrology Dialysis Transplantation. 2006;21(10):2795-9. Not CKD treatment.
4117 Somlo G, Doroshow JH, Lev-Ran A, et al. Effect of low-dose prophylactic dopamine on high-dose cisplatin-induced electrolyte wasting, ototoxicity, and epidermal growth factor excretion: a randomized, placebo-controlled, double-blind trial. Journal of Clinical Oncology. 1995;13(5):1231-7. Sample size less than 50 patients. [pmid: 7738626].
4118 Sommer P, Kromann-Andersen B, Lendorf A, et al. Analgesic effect and tolerance of Voltaren and Ketogan in acute renal or ureteric colic. British Journal of Urology. 1989;63(1):4-6. Not CKD treatment. [pmid: 2645969].
4119 Song H, Tasaki H, Yashiro A, et al. Chlamydia pneumoniae infection and accelerated development of coronary artery disease in patients with chronic renal failure. Clinical Nephrology. 2001;56(5):346-52. Not early CKD. [pmid: 11758004].
4120 Song JH, Cha SH, Lee HJ, et al. Effect of low-dose dual blockade of renin-angiotensin system on urinary TGF-beta in type 2 diabetic patients with advanced kidney disease. Nephrology Dialysis Transplantation. 2006;21(3):683-9. Not relevant to key questions.
4121 Song MK, Ward SE, Happ MB, et al. Randomized controlled trial of SPIRIT: an effective approach to preparing African-American dialysis patients and families for end of life. Research in Nursing & Health. 2009;32(3):260-73. Not CKD treatment. [pmid: 19205027].
4122 Song Tt, Jiang Yh, Lan Xz. Clinical observation on chemical damage of nephron and the preventive and therapeutic effects of Baoshen Mixture on it. Chinese Journal of Integrative Medicine. 2007;13(2):115-9. Sample size less than 50 patients. [pmid: 17609909].
4123 Song YR, Lee T, You SJ, et al. Prevention of acute kidney injury by erythropoietin in patients undergoing coronary artery bypass grafting: a pilot study. American Journal of Nephrology. 2009;30(3):253-60. Not CKD treatment. [pmid: 19494484].
4124 Sonkodi S, Mogyorosi A. Treatment of diabetic nephropathy with angiotensin II blockers. Nephrology Dialysis Transplantation. Suppl 5. 2003;18:v21-3. Not RCT or controlled trial.
4125 Sonpavde G, Hutson TE, Galsky MD, et al. Problems with the randomized discontinuation design. Journal of Clinical Oncology. 2006;24(28):4669-70. author reply 70-1. Not relevant to key questions. [pmid: 17008711].
4126 Soraas CL, Wachtell K, Okin PM, et al. Lack of regression of left ventricular hypertrophy is associated with higher incidence of revascularization in hypertension: The LIFE Study. Blood Pressure. Jun. 2010;19(3):145-51. Not CKD treatment. [pmid: 20429689].
4127 Sorensen SS, Jensen JD, Madsen JK, et al. Effect of isradipine on renal haemodynamics and systemic blood pressure changes induced by intravenous infusion of endothelin in healthy humans. Nephrology Dialysis Transplantation. 1995;10(8):1324-31. Sample size less than 50 patients.
4128 Sorensen SS, Lauridsen IN, Thomsen K, et al. Effect of two regimens of intravenous amino acid infusion on renal haemodynamics, renal tubular function and sodium and water homeostatic hormones in healthy humans. Nephrology Dialysis Transplantation. 1991;6(6):410-9. Not CKD treatment.
4129 Sorensen SS, Madsen JK, Pedersen EB. Systemic and renal effect of intravenous infusion of endothelin-1 in healthy human volunteers. American Journal of Physiology. 1994;266(3 Pt 2):F411-8. Sample size less than 50 patients. [pmid: 8160789].
4130 Sorensen SS, Thomsen OO, Danielsen H, et al. Effect of verapamil on renal plasma flow, glomerular filtration rate and plasma angiotensin II, aldosterone and arginine vasopressin in essential hypertension. European Journal of Clinical Pharmacology. 1985;29(3):257-61. Sample size less than 50 patients. [pmid: 4076325].
4131 Sorensen VB, Rossing P, Tarnow L, et al. Effects of nisoldipine and lisinopril on microvascular dysfunction in hypertensive Type I diabetes patients with nephropathy. Clinical Science. 1998;95(6):709-17. Sample size less than 50 patients. [pmid: 9831696].
4132 Sorger JI, Kirk PG, Ruhnke CJ, et al. Once daily, high dose versus divided, low dose gentamicin for open fractures. Clinical Orthopaedics & Related Research. 1999;(366):197-204. Not CKD treatment. [pmid: 10627736].
4133 Sorkine P, Nagar H, Weinbroum A, et al. Administration of amphotericin B in lipid emulsion decreases nephrotoxicity: results of a prospective, randomized, controlled study in critically ill patients. Critical Care Medicine. 1996;24(8):1311-5. Not CKD treatment. [pmid: 8706484].
4134 Sorof J, Berne C, Siewert-Delle A, et al. Effect of rosuvastatin or atorvastatin on urinary albumin excretion and renal function in type 2 diabetic patients. Diabetes Research & Clinical Practice. 2006;72(1):81-7. Not RCT or controlled trial. [pmid: 16246447].
4135 Sorrenti G, Grimaldi M, Canova N, et al. Glycosaminoglycans as a possible tool for micro- and macroalbuminuria in diabetic patients. A pilot study. Journal of International Medical Research. 1997;25(2):81-6. Sample size less than 50 patients. [pmid: 9100162].
4136 Sort P, Navasa M, Arroyo V, et al. Effect of intravenous albumin on renal impairment and mortality in patients with cirrhosis and spontaneous bacterial peritonitis. New England Journal of Medicine. 1999;341(6):403-9. Not CKD treatment. [pmid: 10432325].
4137 Sosman JA, Kohler PC, Hank JA, et al. Repetitive weekly cycles of interleukin-2 II Clinical and immunologic effects of dose, schedule, and addition of indomethacin. Journal of the National Cancer Institute. 1988;80(18):1451-61. Follow-up less than 6 months. [pmid: 3263508].
4138 Souchet T, Durand Zaleski I, Hannedouche T, et al. An economic evaluation of Losartan therapy in type 2 diabetic patients with nephropathy: an analysis of the RENAAL study adapted to France. Diabetes & Metabolism. 2003;29(1):29-35. Not relevant to key questions. [pmid: 12629445].
4139 Soupart A, Buisson L, Prospert F, et al. Indirect evidence to suggest that prolactin induces salt retention in cirrhosis. Journal of Hepatology. 1994;21(3):347-52. Sample size less than 50 patients. [pmid: 7836703].
4140 Spangberg-Viklund B, Berglund J, Nikonoff T, et al. Does prophylactic treatment with felodipine, a calcium antagonist, prevent low-osmolar contrast-induced renal dysfunction in hydrated diabetic and nondiabetic patients with normal or moderately reduced renal function?. Scandinavian Journal of Urology & Nephrology. 1996;30(1):63-8. Sample size less than 50 patients. [pmid: 8727868].
4141 Spapen HD, Diltoer MW, Nguyen DN, et al. Effects of N-acetylcysteine on microalbuminuria and organ failure in acute severe sepsis: results of a pilot study. Chest. 2005;127(4):1413-9. Not RCT or controlled trial. [pmid: 15821223].
4142 Spargias K, Adreanides E, Giamouzis G, et al. Iloprost for prevention of contrast-mediated nephropathy in high-risk patients undergoing a coronary procedure. Results of a randomized pilot study. European Journal of Clinical Pharmacology. 2006;62(8):589-95. Not relevant to key questions. [pmid: 16832680].
4143 Spargias K, Alexopoulos E, Kyrzopoulos S, et al. Ascorbic acid prevents contrast-mediated nephropathy in patients with renal dysfunction undergoing coronary angiography or intervention. [Erratum appears in Circulation. 2005 Jan 25;111(3):379 Note: Iacovis, Panagiotis [corrected to Iokovis,Panagiotis]]. Circulation. 2004;110(18):2837-42. Not relevant to key questions. [pmid: 15492300].
4144 Spasovski G, Massy Z, Vanholder R. Phosphate metabolism in chronic kidney disease: from pathophysiology to clinical management. Seminars in Dialysis. 2009;22(4):357-62. Not RCT or controlled trial. [pmid: 19708981].
4145 Spector R, Park GD. Regression to the mean: a potential source of error in clinical pharmacological studies. Drug Intelligence & Clinical Pharmacy. 1985;19(12):916-9. Not RCT or controlled trial. [pmid: 4085350].
4146 Spence JD. The arthritic patient with hypertension: selection of an NSAID. Scandinavian Journal of Rheumatology - Supplement. 1986;62:36-40. Not early CKD. [pmid: 3541167].
4147 Spence JD. Management of resistant hypertension in patients with carotid stenosis: high prevalence of renovascular hypertension. Cerebrovascular Diseases. 2000;10(4):249-54. Not early CKD. [pmid: 10878428].
4148 Spence JD. Treatment options for renovascular hypertension. Expert Opinion on Pharmacotherapy. 2002;3(4):411-6. Not early CKD. [pmid: 11934344].
4149 Spence JD, Bang H, Chambless LE, et al. Vitamin Intervention For Stroke Prevention trial: an efficacy analysis. Stroke. 2005;36(11):2404-9. Not early CKD. [pmid: 16239629].
4150 Spencer A, Roberts A, Kennedy N, et al. Renal safety of zoledronic acid with thalidomide in patients with myeloma: a pharmacokinetic and safety sub-study. BMC Clinical Pharmacology. 2008;8:2. Not CKD treatment. [pmid: 18377658].
4151 Spencer EM, Willatts SM, Prys-Roberts C. Plasma inorganic fluoride concentrations during and after prolonged (greater than 24 h) isoflurane sedation: effect on renal function. Anesthesia & Analgesia. 1991;73(6):731-7. Not CKD treatment. [pmid: 1952174].
4152 Spicer J, Quatan N, Plunkett T, et al. Cellular immunotherapy for cancer: current concepts and clinical perspectives Monitoring immune responses and clinical trials: part II. Clinical Oncology. 2004;16(6):395-404. Not RCT or controlled trial. [pmid: 15487131].
4153 Spieker LE, Noll G, Luscher TF. Therapeutic potential for endothelin receptor antagonists in cardiovascular disorders. American Journal of Cardiovascular Drugs. 2001;1(4):293-303. Not relevant to key questions. [pmid: 14728028].
4154 Spigt MG, Knottnerus JA, Westerterp KR, et al. The effects of 6 months of increased water intake on blood sodium, glomerular filtration rate, blood pressure, and quality of life in elderly (aged 55-75) men. Journal of the American Geriatrics Society. 2006;54(3):438-43. Not RCT or controlled trial. [pmid: 16551310].
4155 Spinazzi A, Pozzi Mucelli R. [Administration of iodinated contrast in patients with pre-existing renal failure: a review]. Radiologia Medica. 2004;107(1-2):88-97. Not CKD treatment. [pmid: 15031700].
4156 Spinler SA, Inverso SM, Cohen M, et al. Safety and efficacy of unfractionated heparin versus enoxaparin in patients who are obese and patients with severe renal impairment: analysis from the ESSENCE and TIMI 11B studies. American Heart Journal. 2003;146(1):33-41. Not CKD treatment. [pmid: 12851605].
4157 Spinowitz B, Germain M, Benz R, et al. A randomized study of extended dosing regimens for initiation of epoetin alfa treatment for anemia of chronic kidney disease. Clinical Journal of The American Society of Nephrology: CJASN. 2008;3(4):1015-21. Not RCT or controlled trial. [pmid: 18400964].
4158 Spinowitz BS, Kausz AT, Baptista J, et al. Ferumoxytol for treating iron deficiency anemia in CKD. Journal of the American Society of Nephrology. 2008;19(8):1599-605. Follow-up less than 6 months. [pmid: 18525001].
4159 Spinowitz BS, Pratt RD, Epoetin Delta Study G. Epoetin delta is effective for the management of anaemia associated with chronic kidney disease. Current Medical Research & Opinion. 2006;22(12):2507-13. Not relevant to key questions. [pmid: 17166333].
4160 Spitalewitz S, Porush JG, Cattran D, et al. Treatment of hyperlipidemia in the nephrotic syndrome: the effects of pravastatin therapy. American Journal of Kidney Diseases. 1993;22(1):143-50. Sample size less than 50 patients. [pmid: 8322777].
4161 Spitalewitz S, Weber MA, Reiser IW. Medical and non-medical approaches to renovascular hypertension. Cardiologia. 1997;42(3):237-43. Not RCT or controlled trial. [pmid: 9141238].
4162 Stabler SP, Estacio R, Jeffers BW, et al. Total homocysteine is associated with nephropathy in non-insulin-dependent diabetes mellitus. Metabolism: Clinical & Experimental. 1999;48(9):1096-101. Not RCT or controlled trial. [pmid: 10484047].
4163 Stachenfeld NS, DiPietro L, Palter SF, et al. Estrogen influences osmotic secretion of AVP and body water balance in postmenopausal women. American Journal of Physiology. 1998;274(1 Pt 2):R187-95. Sample size less than 50 patients. [pmid: 9458917].
4164 Stachenfeld NS, Silva C, Keefe DL, et al. Effects of oral contraceptives on body fluid regulation. Journal of Applied Physiology. 1999;87(3):1016-25. Follow-up less than 6 months. [pmid: 10484572].
4165 Stack AG. Coronary artery disease and peripheral vascular disease in chronic kidney disease: an epidemiological perspective. Cardiology Clinics. 2005;23(3):285-98. Not relevant to key questions. [pmid: 16084278].
4166 Stacul F, Carraro M, Magnaldi S, et al. Contrast agent nephrotoxicity: comparison of ionic and nonionic contrast agents. AJR. American Journal of Roentgenology. 1987;149(6):1287-9. Not RCT or controlled trial. [pmid: 2891285].
4167 Stacul F, Thomsen HS. Safety profile of new non-ionic contrast media: renal tolerance. European Journal of Radiology. Suppl 1. 1996;23:S6-9. Not RCT or controlled trial. [pmid: 9056157].
4168 Stadler DD, Chenard CA, Rebouche CJ. Effect of dietary macronutrient content on carnitine excretion and efficiency of carnitine reabsorption. American Journal of Clinical Nutrition. 1993;58(6):868-72. Sample size less than 50 patients. [pmid: 8249869].
4169 Staessen J. Low-level lead exposure, renal function and blood pressure. Verhandelingen - Koninklijke Academie voor Geneeskunde van Belgie. 1995;57(6):527-74. Not CKD treatment. [pmid: 8686371].
4170 Staessen J, Lauwerys R. Health effects of environmental exposure to cadmium in a population study. Journal of Human Hypertension. 1993;7(2):195-9. Not RCT or controlled trial. [pmid: 8510095].
4171 Staessen J, Yeoman WB, Fletcher AE, et al. Blood cadmium in London civil servants. International Journal of Epidemiology. 1990;19(2):362-6. Not CKD treatment. [pmid: 2376448].
4172 Staessen JA. Antiproteinuric effects of cilnidipine. Kidney International. 2008;73(9):1095. author reply -6. Sample size less than 50 patients. [pmid: 18414444].
4173 Staessen JA, Lauwerys RR, Buchet JP, et al. Impairment of renal function with increasing blood lead concentrations in the general population. The Cadmibel Study Group. New England Journal of Medicine. 1992;327(3):151-6. Not CKD treatment. [pmid: 1608406].
4174 Staessen JA, Lauwerys RR, Ide G, et al. Renal function and historical environmental cadmium pollution from zinc smelters. Lancet. 1994;343(8912):1523-7. Not RCT or controlled trial. [pmid: 7911869].
4175 Staessen JA, Li Y, Richart T. Oral renin inhibitors. Lancet. 2006;368(9545):1449-56. Not CKD treatment. [pmid: 17055947].
4176 Stafford-Smith M. Evidence-based renal protection in cardiac surgery. Seminars in Cardiothoracic & Vascular Anesthesia. 2005;9(1):65-76. Not CKD treatment. [pmid: 15735845].
4177 Stafford-Smith M, Shaw A, Swaminathan M. Cardiac surgery and acute kidney injury: emerging concepts. Current Opinion in Critical Care. 2009;15(6):498-502. Not RCT or controlled trial. [pmid: 19812485].
4178 Stafylas PC, Sarafidis PA, Lasaridis AN, et al. Cost-effectiveness of losartan in diabetic nephropathy: a Greek perspective. Journal of Nephrology. 2007;20(6):703-15. Sample size less than 50 patients. [pmid: 18046673].
4179 Staniloae CS, Doucet S, Sharma SK, et al. N-Acetylcysteine added to volume expansion with sodium bicarbonate does not further prevent contrast-induced nephropathy: results from the cardiac angiography in renally impaired patients study. Journal of Interventional Cardiology. Jun. 2009;22(3):261-5. Not CKD treatment. [pmid: 19490358].
4180 Stankov G, Schmieder G, Zerle G, et al. Double-blind study with dipyrone versus tramadol and butylscopolamine in acute renal colic pain. World Journal of Urology. 1994;12(3):155-61. Not CKD treatment. [pmid: 7951343].
4181 Stanton R. Intensive treatment of diabetic nephropathy. Current Diabetes Reports. 2004;4(6):433-4. Not CKD treatment. [pmid: 15539007].
4182 Starklint J, Bech JN, Nyvad O, et al. Increased urinary aquaporin-2 excretion in response to furosemide in patients with chronic heart failure. Scandinavian Journal of Clinical & Laboratory Investigation. 2006;66(1):55-66. Sample size less than 50 patients. [pmid: 16464787].
4183 Stefanidis I, Kytoudis K, Papathanasiou AA, et al. XbaI GLUT1 gene polymorphism and the risk of type 2 diabetes with nephropathy. Disease Markers. 2009;27(1):29-35. Not RCT or controlled trial. [pmid: 19822956].
4184 Stefoni S, Mosconi G, La Manna G, et al. Low-dosage ibopamine treatment in progressive renal failure: a long-term multicentre trial. American Journal of Nephrology. 1996;16(6):489-99. Not early CKD. [pmid: 8955760].
4185 Stegmayr BG, Brannstrom M, Bucht S, et al. Low-dose atorvastatin in severe chronic kidney disease patients: a randomized, controlled endpoint study. Scandinavian Journal of Urology & Nephrology. 2005;39(6):489-97. Not RCT or controlled trial. [pmid: 18161210].
4186 Stein A, Ben Dov D, Finkel B, et al. Single-dose intramuscular ketorolac versus diclofenac for pain management in renal colic. American Journal of Emergency Medicine. 1996;14(4):385-7. Not CKD treatment. [pmid: 8768161].
4187 Stein CM, Longmire AW, Minton TA, et al. Cyclosporine-induced alterations in renal function are not associated with lipid peroxidation. Transplantation. 1994;58(3):386-8. Sample size less than 50 patients. [pmid: 8053066].
4188 Stein EA, Amerena J, Ballantyne CM, et al. Long-term efficacy and safety of rosuvastatin 40 mg in patients with severe hypercholesterolemia. American Journal of Cardiology. 2007;100(9):1387-96. Not relevant to key questions. [pmid: 17950795].
4189 Stein G, Sierakowski B, Jansa U, et al. Spirapril in chronic renal failure. Blood Pressure Supplement. 1994;2:54-60. Sample size less than 50 patients. [pmid: 8061847].
4190 Steinberg EP, Moore RD, Brinker JA, et al. Nephrotoxicity of low osmolality contrast media versus high osmolality media. Investigative Radiology. Suppl 1. 1991;26:S86. discussion S8-91. Not RCT or controlled trial. [pmid: 1808157].
4191 Steinberg MH, McCarthy WF, Castro O, et al. The risks and benefits of long-term use of hydroxyurea in sickle cell anemia: A 17.5 year follow-up. American Journal of Hematology. Jun. 2010;85(6):403-8. Not CKD treatment. [pmid: 20513116].
4192 Steiner G. How can we improve the management of vascular risk in type 2 diabetes: insights from FIELD. Cardiovascular Drugs & Therapy. 2009;23(5):403-8. Not RCT or controlled trial. [pmid: 19757004].
4193 Steinmetz OM, Panzer U, Stahl RAK, et al. Statin therapy in patients with chronic kidney disease: to use or not to use. European Journal of Clinical Investigation. 2006;36(8):519-27. Not relevant to key questions. [pmid: 16893373].
4194 Stenlof K, Rossner S, Vercruysse F, et al. Topiramate in the treatment of obese subjects with drug-naive type 2 diabetes. Diabetes, Obesity & Metabolism. 2007;9(3):360-8. Not CKD treatment.
4195 Stenvinkel P. Chronic kidney disease: a public health priority and harbinger of premature cardiovascular disease. Journal of Internal Medicine. Nov. 2010;268(5):456-67. Not CKD treatment. [pmid: 20809922].
4196 Stenvinkel P, Carrero JJ, Axelsson J, et al. Emerging biomarkers for evaluating cardiovascular risk in the chronic kidney disease patient: how do new pieces fit into the uremic puzzle?. Clinical Journal of The American Society of Nephrology: CJASN. 2008;3(2):505-21. Not relevant to key questions. [pmid: 18184879].
4197 Stephenson JM, Kenny S, Stevens LK, et al. Proteinuria and mortality in diabetes: the WHO Multinational Study of Vascular Disease in Diabetes. Diabetic Medicine. 1995;12(2):149-55. Not CKD treatment. [pmid: 7743762].
4198 Stergiou GS, Nasothimiou EG. Does dosing antihypertensive drugs at night alter renal or cardiovascular outcome: do we have the evidence?. Current Opinion in Nephrology & Hypertension. 2008;17(5):464-9. Not CKD treatment. [pmid: 18695386].
4199 Stevens MA, McCullough PA, Tobin KJ, et al. A prospective randomized trial of prevention measures in patients at high risk for contrast nephropathy: results of the P.R.I.N.C.E. Study. Prevention of Radiocontrast Induced Nephropathy Clinical Evaluation. Journal of the American College of Cardiology. 1999;33(2):403-11. Not CKD treatment. [pmid: 9973020].
4200 Stevens PE. Blind Pew sends a black spot: the current haemoglobin controversy. Blood Purification. 2008;26(1):54-8. Not CKD treatment. [pmid: 18182797].
4201 Stewart CP, Christian P, Schulze KJ, et al. Antenatal micronutrient supplementation reduces metabolic syndrome in 6- to 8-year-old children in rural Nepal. Journal of Nutrition. 2009;139(8):1575-81. Not RCT or controlled trial. [pmid: 19549749].
4202 Stichtenoth DO, Marhauer V, Tsikas D, et al. Effects of specific COX-2-inhibition on renin release and renal and systemic prostanoid synthesis in healthy volunteers. Kidney International. 2005;68(5):2197-207. Not early CKD. [pmid: 16221219].
4203 Stieglmayr S, Khayyat AH, Bodlaj G, et al. Comparable outcomes in type 2 diabetic patients with diabetic or vascular nephropathy treated by hemodialysis. Nephron. 2010;114(2):c104-7. Not CKD treatment. [pmid: 19887830].
4204 Stier CT Jr., Chander PN, Rocha R. Aldosterone as a mediator in cardiovascular injury. Cardiology in Review. 2002;10(2):97-107. Not RCT or controlled trial. [pmid: 11895576].
4205 Stock JL, Coderre JA, Posillico JT. Effects of estrogen on mineral metabolism in postmenopausal women as evaluated by multiple assays measuring parathyrin bioactivity. Clinical Chemistry. 1989;35(1):18-22. Sample size less than 50 patients. [pmid: 2535973].
4206 Stock PG, Ascher NL, Osorio RW, et al. Standard sequential immunosuppression with Minnesota antilymphoblast globulin and cyclosporine vs FK 506: a comparison of early nephrotoxicity. Transplantation Proceedings. 1993;25(1 Pt 1):675-6. Not RCT or controlled trial. [pmid: 7679838].
4207 Stockwell MA, Scott A, Day A, et al. Colloid solutions in the critically ill. A randomised comparison of albumin and polygeline 2. Serum albumin concentration and incidences of pulmonary oedema and acute renal failure. Anaesthesia. 1992;47(1):7-9. Not CKD treatment. [pmid: 1536412].
4208 Stojiljkovic L, Behnia R. Role of renin angiotensin system inhibitors in cardiovascular and renal protection: a lesson from clinical trials. Current Pharmaceutical Design. 2007;13(13):1335-45. Sample size less than 50 patients. [pmid: 17506719].
4209 Stokes GS, Monaghan JC, Pillai DN. Comparison of the effects on urinary sodium excretion of indomethacin and of carbidopa in normal volunteers given an intravenous saline infusion. Clinical Science. 1997;92(4):409-14. Sample size less than 50 patients. [pmid: 9176041].
4210 Stoll DM, King LE Jr., McNeil L, et al. Human urinary epidermal growth factor excretion: age, sex, and race dependence. Journal of Clinical Endocrinology & Metabolism. 1988;67(2):361-7. Not RCT or controlled trial. [pmid: 3260600].
4211 Stone GW, McCullough PA, Tumlin JA, et al. Fenoldopam mesylate for the prevention of contrast-induced nephropathy: a randomized controlled trial. JAMA. 2003;290(17):2284-91. Not relevant to key questions. [pmid: 14600187].
4212 Stone GW, Tumlin JA, Madyoon H, et al. Design and rationale of CONTRAST--a prospective, randomized, placebo-controlled trial of fenoldopam mesylate for the prevention of radiocontrast nephropathy. Reviews in Cardiovascular Medicine. Suppl 1. 2001;2:S31-6. Not CKD treatment. [pmid: 12439366].
4213 Stone WJ, Graber SE, Krantz SB, et al. Treatment of the anemia of predialysis patients with recombinant human erythropoietin: a randomized, placebo-controlled trial. American Journal of the Medical Sciences. 1988;296(3):171-9. Sample size less than 50 patients. [pmid: 3177433].
4214 Stoof TJ, Korstanje MJ, Bilo HJ, et al. Does fish oil protect renal function in cyclosporin-treated psoriasis patients?. Journal of Internal Medicine. 1989;226(6):437-41. Sample size less than 50 patients. [pmid: 2489230].
4215 Stornello M, Valvo EV, Puglia N, et al. Angiotensin converting enzyme inhibition with a low dose of enalapril in normotensive diabetics with persistent proteinuria. Journal of Hypertension - Supplement. 1988;6(4):S464-6. Sample size less than 50 patients.
4216 Stornello M, Valvo EV, Scapellato L. Angiotensin converting enzyme inhibition in normotensive type II diabetics with persistent mild proteinuria. Journal of Hypertension - Supplement. 1989;7(6):S314-5. Sample size less than 50 patients.
4217 Stornello M, Valvo EV, Scapellato L. Hemodynamic, renal, and humoral effects of the calcium entry blocker nicardipine and converting enzyme inhibitor captopril in hypertensive type II diabetic patients with nephropathy. Journal of Cardiovascular Pharmacology. 1989;14(6):851-5. Sample size less than 50 patients. [pmid: 2481772].
4218 Stornello M, Valvo EV, Scapellato L. Comparative effects of enalapril, atenolol and chlorthalidone on blood pressure and kidney function of diabetic patients affected by arterial hypertension and persistent proteinuria. Nephron. 1991;58(1):52-7. Sample size less than 50 patients. [pmid: 1857482].
4219 Stornello M, Valvo EV, Scapellato L. Persistent albuminuria in normotensive non-insulin-dependent (type II) diabetic patients: comparative effects of angiotensin-converting enzyme inhibitors and beta-adrenoceptor blockers. Clinical Science. 1992;82(1):19-23. Sample size less than 50 patients. [pmid: 1310913].
4220 Stornello M, Valvo EV, Vasques E, et al. Systemic and renal effects of chronic angiotensin converting enzyme inhibition with captopril in hypertensive diabetic patients. Journal of Hypertension - Supplement. 1989;7(7):S65-7. Sample size less than 50 patients.
4221 Story DA, Tosolini A, Bellomo R, et al. Plasma acid-base changes in chronic renal failure: a Stewart analysis. International Journal of Artificial Organs. 2005;28(10):961-5. Not relevant to key questions. [pmid: 16288433].
4222 Stouthard JM, Levi M, Hack CE, et al. Interleukin-6 stimulates coagulation, not fibrinolysis, in humans. Thrombosis & Haemostasis. 1996;76(5):738-42. Not CKD treatment. [pmid: 8950783].
4223 Stouthard JM, van der Poll T, Endert E, et al. Effects of acute and chronic interleukin-6 administration on thyroid hormone metabolism in humans. Journal of Clinical Endocrinology & Metabolism. 1994;79(5):1342-6. Not CKD treatment. [pmid: 7962327].
4224 Stoves J, Inglis H, Newstead CG. A randomized study of oral vs intravenous iron supplementation in patients with progressive renal insufficiency treated with erythropoietin. Nephrology Dialysis Transplantation. 2001;16(5):967-74. Not CKD treatment.
4225 Strasser T, Schiffl H. Generation of leukotriene B4 by hemodialyzer membranes: a novel index of biocompatibility. Klinische Wochenschrift. 1991;69(17):808-12. Not CKD treatment. [pmid: 1662325].
4226 Strazzullo P, Cappuccio FP, Trevisan M, et al. Erythrocyte sodium/lithium countertransport and renal lithium clearance in a random sample of untreated middle-aged men. Clinical Science. 1989;77(3):337-42. Not relevant to key questions. [pmid: 2805596].
4227 Stricker K, Yu S, Krammer G. A 6-week, multicentre, randomised, double-blind, double-dummy, active-controlled, clinical safety study of lumiracoxib and rofecoxib in osteoarthritis patients. BMC Musculoskeletal Disorders. 2008;9:118. Not early CKD. [pmid: 18778469].
4228 Strippoli GFM, Bonifati C, Craig M, et al. Angiotensin converting enzyme inhibitors and angiotensin II receptor antagonists for preventing the progression of diabetic kidney disease. Cochrane Database of Systematic Reviews. 2006;(4):CD006257. Not RCT or controlled trial. [pmid: 17054288].
4229 Strippoli GFM, Craig JC. Hypothesis versus association: the optimal hemoglobin target debate. American Journal of Kidney Diseases. 2005;46(5):970-3. Not early CKD. [pmid: 16253741].
4230 Strippoli GFM, Craig JC, Manno C, et al. Hemoglobin targets for the anemia of chronic kidney disease: a meta-analysis of randomized, controlled trials. Journal of the American Society of Nephrology. 2004;15(12):3154-65. Not relevant to key questions. [pmid: 15579519].
4231 Strippoli GFM, Craig M, Craig JC. Antihypertensive agents for preventing diabetic kidney disease. Cochrane Database of Systematic Reviews. 2005;(4):CD004136. Sample size less than 50 patients. [pmid: 16235351].
4232 Strippoli GFM, Craig M, Deeks JJ, et al. Effects of angiotensin converting enzyme inhibitors and angiotensin II receptor antagonists on mortality and renal outcomes in diabetic nephropathy: systematic review. BMJ. 2004;329(7470):828. Not RCT or controlled trial. [pmid: 15459003].
4233 Strippoli GFM, Craig M, Schena FP, et al. Antihypertensive agents for primary prevention of diabetic nephropathy. Journal of the American Society of Nephrology. 2005;16(10):3081-91. Not RCT or controlled trial. [pmid: 16135776].
4234 Strippoli GFM, Craig MC, Schena FP, et al. Role of blood pressure targets and specific antihypertensive agents used to prevent diabetic nephropathy and delay its progression. Journal of the American Society of Nephrology. 2006;17(4 Suppl 2):S153-5. Not relevant to key questions. [pmid: 16565242].
4235 Strippoli GFM, Navaneethan SD, Johnson DW, et al. Effects of statins in patients with chronic kidney disease: meta-analysis and meta-regression of randomised controlled trials. BMJ. 2008;336(7645):645-51. Follow-up less than 6 months. [pmid: 18299289].
4236 Strippoli GFM, Palmer S, Tong A, et al. Meta-analysis of biochemical and patient-level effects of calcimimetic therapy. American Journal of Kidney Diseases. 2006;47(5):715-26. Not relevant to key questions. [pmid: 16632010].
4237 Strippoli GFM, Tognoni G, Navaneethan SD, et al. Haemoglobin targets: we were wrong, time to move on. Lancet. 2007;369(9559):346-50. Not RCT or controlled trial. [pmid: 17276756].
4238 Strohmaier WL, Bichler KH, Koch J, et al. Protective effect of verapamil on shock wave induced renal tubular dysfunction. Journal of Urology. 1993;150(1):27-9. Sample size less than 50 patients. [pmid: 7685425].
4239 Strohmaier WL, Koch J, Balk N, et al. Limitation of shock-wave-induced renal tubular dysfunction by nifedipine. European Urology. 1994;25(2):99-104. Sample size less than 50 patients. [pmid: 7511106].
4240 Strojek K, Grzeszczak W, Gorska J, et al. Lowering of microalbuminuria in diabetic patients by a sympathicoplegic agent: novel approach to prevent progression of diabetic nephropathy?. Journal of the American Society of Nephrology. 2001;12(3):602-5. Sample size less than 50 patients. [pmid: 11181810].
4241 Strumberg D. Preclinical and clinical development of the oral multikinase inhibitor sorafenib in cancer treatment. Drugs of Today. 2005;41(12):773-84. Not RCT or controlled trial. [pmid: 16474853].
4242 Studies of Ocular Complications of ARGTACTG. The ganciclovir implant plus oral ganciclovir versus parenteral cidofovir for the treatment of cytomegalovirus retinitis in patients with acquired immunodeficiency syndrome: The Ganciclovir Cidofovir Cytomegalovirus Retinitis Trial. American Journal of Ophthalmology. 2001;131(4):457-67. Not early CKD. [pmid: 11292409].
4243 Stumpe KO, Overlack A. A new trial of the efficacy, tolerability, and safety of angiotensin-converting enzyme inhibition in mild systemic hypertension with concomitant diseases and therapies. Perindopril Therapeutic Safety Study Group (PUTS). American Journal of Cardiology. 1993;71(17):32E-7E. Follow-up less than 6 months.
4244 Sturgiss SN, Wilkinson R, Davison JM. Renal reserve during human pregnancy. American Journal of Physiology. 1996;271(1 Pt 2):F16-20. Sample size less than 50 patients. [pmid: 8760238].
4245 Sturrock ND, Lang CC, Baylis PH, et al. Sequential effects of cyclosporine therapy on blood pressure, renal function and neurohormones. Kidney International. 1994;45(4):1203-10. Not RCT or controlled trial. [pmid: 8007592].
4246 Sturrock ND, Lang CC, Clark G, et al. Acute haemodynamic and renal effects of cyclosporin and indomethacin in man. Nephrology Dialysis Transplantation. 1994;9(8):1149-56. Follow-up less than 6 months.
4247 Sturrock ND, Lang CC, MacFarlane LJ, et al. Serial changes in blood pressure, renal function, endothelin and lipoprotein (a) during the first 9 days of cyclosporin therapy in males. Journal of Hypertension. 1995;13(6):667-73. Follow-up less than 6 months. [pmid: 7594425].
4248 Sturrock ND, Lang CC, Struthers AD. Cyclosporin-induced hypertension precedes renal dysfunction and sodium retention in man. Journal of Hypertension. 1993;11(11):1209-16. Sample size less than 50 patients. [pmid: 8301102].
4249 Sturrock ND, Lang CC, Struthers AD. Indomethacin and cyclosporin together produce marked renal vasoconstriction in humans. Journal of Hypertension. 1994;12(8):919-24. Sample size less than 50 patients. [pmid: 7814851].
4250 Subira M, Martino R, Gomez L, et al. Low-dose amphotericin B lipid complex vs. conventional amphotericin B for empirical antifungal therapy of neutropenic fever in patients with hematologic malignancies--a randomized, controlled trial. European Journal of Haematology. 2004;72(5):342-7. Not early CKD. [pmid: 15059069].
4251 Subira M, Martino R, Sureda A, et al. Safety and efficacy of low-dose amphotericin B lipid complex for empirical antifungal therapy of neutropenic fever in patients with hematologic malignancies. Methods & Findings in Experimental & Clinical Pharmacology. 2001;23(9):505-10. Not early CKD. [pmid: 11876025].
4252 Sulikowska B, Olejniczak H, Muszynska M, et al. Effect of sulodexide on albuminuria, NAG excretion and glomerular filtration response to dopamine in diabetic patients. American Journal of Nephrology. 2006;26(6):621-8. Not adult population. [pmid: 17191008].
4253 Suliman ME, Lindholm B, Barany P, et al. Homocysteine-lowering is not a primary target for cardiovascular disease prevention in chronic kidney disease patients. Seminars in Dialysis. 2007;20(6):523-9. Not RCT or controlled trial. [pmid: 17991198].
4254 Sullivan DH, Walls RC. The risk of life-threatening complications in a select population of geriatric patients: the impact of nutritional status. Journal of the American College of Nutrition. 1995;14(1):29-36. Not RCT or controlled trial. [pmid: 7706607].
4255 Sumaili EK, Krzesinski JM, Zinga CV, et al. Prevalence of chronic kidney disease in Kinshasa: results of a pilot study from the Democratic Republic of Congo. Nephrology Dialysis Transplantation. 2009;24(1):117-22. Sample size less than 50 patients.
4256 Sumeray M, Robertson C, Lapsley M, et al. Low dose dopamine infusion reduces renal tubular injury following cardiopulmonary bypass surgery. Journal of Nephrology. 2001;14(5):397-402. Sample size less than 50 patients. [pmid: 11730274].
4257 Summers MJ, Oliver KR, Coombes JS, et al. Effect of atorvastatin on cognitive function in patients from the Lipid Lowering and Onset of Renal Disease (LORD) trial. Pharmacotherapy. 2007;27(2):183-90. Sample size less than 50 patients. [pmid: 17253908].
4258 Sundar S, Gupta LB, Makharia MK, et al. Oral treatment of visceral leishmaniasis with miltefosine. Annals of Tropical Medicine & Parasitology. 1999;93(6):589-97. Not early CKD. [pmid: 10707104].
4259 Sunder-Plassmann G, Horl WH. Importance of iron supply for erythropoietin therapy. Nephrology Dialysis Transplantation. 1995;10(11):2070-6. Not early CKD.
4260 Sunderrajan S, Reams G, Bauer JH. Renal effects of diltiazem in primary hypertension. Hypertension. 1986;8(3):238-42. Sample size less than 50 patients. [pmid: 3949375].
4261 Supervia A, Pedro-Botet J, Nogues X, et al. Piroxicam fast-dissolving dosage form vs diclofenac sodium in the treatment of acute renal colic: a double-blind controlled trial. British Journal of Urology. 1998;81(1):27-30. Not CKD treatment. [pmid: 9467472].
4262 Sutherland DE. The case for pancreas transplantation. Diabetes & Metabolism. 1996;22(2):132-8. Not RCT or controlled trial. [pmid: 8792093].
4263 Sutters M, Duncan R, Peart WS. Effect of dietary salt restriction on renal sensitivity to vasopressin in man. Clinical Science. 1995;89(1):37-43. Not RCT or controlled trial. [pmid: 7671566].
4264 Sutton L, Sayer GP, Bajuk B, et al. Do very sick neonates born at term have antenatal risks? 1. Infants ventilated primarily for problems of adaptation to extra-uterine life. Acta Obstetricia et Gynecologica Scandinavica. 2001;80(10):905-16. Not RCT or controlled trial. [pmid: 11580735].
4265 Suzuki H, Kanno Y, Ikeda N, et al. Selection of the dose of angiotensin converting enzyme inhibitor for patients with diabetic nephropathy depends on the presence or absence of left ventricular hypertrophy. Hypertension Research - Clinical & Experimental. 2002;25(6):865-73. Not relevant to key questions.
4266 Suzuki H, Moriwaki K, Kanno Y, et al. Comparison of the effects of an ACE inhibitor and alphabeta blocker on the progression of renal failure with left ventricular hypertrophy: preliminary report. Hypertension Research - Clinical & Experimental. 2001;24(2):153-8. Not RCT or controlled trial.
4267 Suzuki H, Moriwaki K, Nakamoto H, et al. Blood pressure reduction in the morning yields beneficial effects on progression of chronic renal insufficiency with regression of left ventricular hypertrophy. Clinical & Experimental Hypertension. 2002;24(1-2):51-63. Sample size less than 50 patients. [pmid: 11848169].
4268 Suzuki M, Hirasawa Y, Hirashima K, et al. Dose-finding, double-blind, clinical trial of recombinant human erythropoietin (Chugai) in Japanese patients with end-stage renal disease. Research Group for Clinical Assessment of rhEPO. Contributions to Nephrology. 1989;76:179-92. discussion 212-8. Not early CKD. [pmid: 2684520].
4269 Suzuki S, Hinokio Y, Ohtomo M, et al. The effects of coenzyme Q10 treatment on maternally inherited diabetes mellitus and deafness, and mitochondrial DNA 3243 (A to G) mutation. Diabetologia. 1998;41(5):584-8. Sample size less than 50 patients. [pmid: 9628277].
4270 Svarstad E, Helland S, Morken T, et al. Renal effects of maintenance low-dose cyclosporin A treatment in psoriasis. Nephrology Dialysis Transplantation. 1994;9(10):1462-7. Sample size less than 50 patients.
4271 Svendsen KB, Bech JN, Sorensen TB, et al. A comparison of the effects of etodolac and ibuprofen on renal haemodynamics, tubular function, renin, vasopressin and urinary excretion of albumin and alpha-glutathione-S-transferase in healthy subjects: a placebo-controlled cross-over study. European Journal of Clinical Pharmacology. 2000;56(5):383-8. Not early CKD. [pmid: 11009046].
4272 Svensson M, Christensen JH, Solling J, et al. The effect of n-3 fatty acids on plasma lipids and lipoproteins and blood pressure in patients with CRF. American Journal of Kidney Diseases. 2004;44(1):77-83. Follow-up less than 6 months. [pmid: 15211441].
4273 Swan SK, Hursting MJ. The pharmacokinetics and pharmacodynamics of argatroban: effects of age, gender, and hepatic or renal dysfunction. Pharmacotherapy. 2000;20(3):318-29. Not CKD treatment. [pmid: 10730687].
4274 Swan SK, Rudy DW, Lasseter KC, et al. Effect of cyclooxygenase-2 inhibition on renal function in elderly persons receiving a low-salt diet. A randomized, controlled trial. Annals of Internal Medicine. 2000;133(1):1-9. Not early CKD. [pmid: 10877734].
4275 Sward K, Valsson F, Odencrants P, et al. Recombinant human atrial natriuretic peptide in ischemic acute renal failure: a randomized placebo-controlled trial. [Erratum appears in Crit Care Med. 2006 Jun;34(6):1862]. Critical Care Medicine. 2004;32(6):1310-5. Not relevant to key questions. [pmid: 15187512].
4276 Swedberg K. Effect of ACE-inhibition on renal function in severe congestive heart failure. Zeitschrift fur Kardiologie. Suppl 2. 1991;80:50-4. Not relevant to key questions. [pmid: 2024543].
4277 Swenson J, Olgun S, Radjavi A, et al. Clinical efficacy of buprenorphine to minimize distress in MRL/lpr mice. European Journal of Pharmacology. 2007;567(1-2):67-76. Sample size less than 50 patients. [pmid: 17490635].
4278 Swift PA, MacGregor GA. Renoprotection in Type 2 diabetes: blockade of the renin-angiotensin system with angiotensin II receptor blockers. Journal of the Renin-Angiotensin-Aldosterone System. 2001;2(3):170-3. Not RCT or controlled trial. [pmid: 11881118].
4279 Swygert TH, Roberts LC, Valek TR, et al. Effect of intraoperative low-dose dopamine on renal function in liver transplant recipients. Anesthesiology. 1991;75(4):571-6. Not CKD treatment. [pmid: 1928766].
4280 Szczech LA, Barnhart HX, Inrig JK, et al. Secondary analysis of the CHOIR trial epoetin-alpha dose and achieved hemoglobin outcomes. Kidney International. 2008;74(6):791-8. Not adult population. [pmid: 18596733].
4281 Szczech LA, Barnhart HX, Sapp S, et al. A secondary analysis of the CHOIR trial shows that comorbid conditions differentially affect outcomes during anemia treatment. Kidney International. Feb. 2010;77(3):239-46. Not CKD treatment. [pmid: 19890274].
4282 Szczech LA, Best PJ, Crowley E, et al. Outcomes of patients with chronic renal insufficiency in the bypass angioplasty revascularization investigation. Circulation. 2002;105(19):2253-8. Not relevant to key questions. [pmid: 12010906].
4283 Szepietowski JC, Bielicka E, Wasik F, et al. Microalbuminuria as a subclinical marker of renal impairment in subjects with psoriasis vulgaris. Journal of the European Academy of Dermatology & Venereology. 2000;14(6):513-4. Not CKD treatment. [pmid: 11444279].
4284 Szucs TD, Sandoz MS, Keusch GW. The cost-effectiveness of losartan in type 2 diabetics with nephropathy in Switzerland--an analysis of the RENAAL study. Swiss Medical Weekly. 2004;134(31-32):440-7. Follow-up less than 6 months. [pmid: 15389347].
4285 Taal MW, Brenner BM. Renoprotective benefits of RAS inhibition: from ACEI to angiotensin II antagonists. Kidney International. 2000;57(5):1803-17. Not RCT or controlled trial. [pmid: 10792600].
4286 Tadros GM, Malik JA, Manske CL, et al. Iso-osmolar radio contrast iodixanol in patients with chronic kidney disease. Journal of Invasive Cardiology. 2005;17(4):211-5. Not RCT or controlled trial. [pmid: 15831975].
4287 Tagliaferri F, Sirovich I, Stipa F, et al. Systemic specific active immunotherapy for solid tumors. An overview about cancer vaccinetherapy. Recenti Progressi in Medicina. 1994;85(12):591-6. Not RCT or controlled trial. [pmid: 7899685].
4288 Tahir H, Jackson LL, Warnock DG. Antiproteinuric therapy and fabry nephropathy: sustained reduction of proteinuria in patients receiving enzyme replacement therapy with agalsidase-beta. Journal of the American Society of Nephrology. 2007;18(9):2609-17. Sample size less than 50 patients. [pmid: 17656478].
4289 Takabatake T, Ohta H, Sasaki T, et al. Renal effects of manidipine hydrochloride. A new calcium antagonist in hypertensive patients. European Journal of Clinical Pharmacology. 1993;45(4):321-5. Sample size less than 50 patients. [pmid: 8299663].
4290 Takahashi A, Shiga T, Shoda M, et al. Impact of renal dysfunction on appropriate therapy in implantable cardioverter defibrillator patients with non-ischaemic dilated cardiomyopathy. Europace. 2009;11(11):1476-82. Not CKD treatment. [pmid: 19661116].
4291 Takahashi T, Reed SD, Schulman KA. Cost-effectiveness of the oral adsorbent AST-120 versus placebo for chronic kidney disease. Nephrology. 2008;13(5):419-27. Not CKD treatment. [pmid: 18518936].
4292 Takahashi T, Yano M, Minami J, et al. Sarpogrelate hydrochloride, a serotonin2A receptor antagonist, reduces albuminuria in diabetic patients with early-stage diabetic nephropathy. Diabetes Research & Clinical Practice. 2002;58(2):123-9. Not CKD treatment. [pmid: 12213354].
4293 Takebayashi K, Matsumoto S, Aso Y, et al. Aldosterone blockade attenuates urinary monocyte chemoattractant protein-1 and oxidative stress in patients with type 2 diabetes complicated by diabetic nephropathy. Journal of Clinical Endocrinology & Metabolism. 2006;91(6):2214-7. Sample size less than 50 patients. [pmid: 16569732].
4294 Takeda H, Ohta K, Hagiwara M, et al. Genetic predisposing factors in non-insulin dependent diabetes with persistent albuminuria. Tokai Journal of Experimental & Clinical Medicine. 1992;17(5-6):199-203. Not CKD treatment. [pmid: 1343428].
4295 Takeuchi K, Abe K, Yasujima M, et al. No adverse effect of non-steroidal anti-inflammatory drugs, sulindac and diclofenac sodium, on blood pressure control with a calcium antagonist, nifedipine, in elderly hypertensive patients. Tohoku Journal of Experimental Medicine. 1991;165(3):201-8. Sample size less than 50 patients. [pmid: 1807007].
4296 Takimoto CH, Remick SC, Sharma S, et al. Dose-escalating and pharmacological study of oxaliplatin in adult cancer patients with impaired renal function: a National Cancer Institute Organ Dysfunction Working Group Study. Journal of Clinical Oncology. 2003;21(14):2664-72. Sample size less than 50 patients. [pmid: 12860942].
4297 Taliercio CP, Vlietstra RE, Ilstrup DM, et al. A randomized comparison of the nephrotoxicity of iopamidol and diatrizoate in high risk patients undergoing cardiac angiography. Journal of the American College of Cardiology. 1991;17(2):384-90. Not CKD treatment. [pmid: 1991894].
4298 Tam SC, Tang LS, Lai CK, et al. Role of atrial natriuretic peptide in the increase in glomerular filtration rate induced by a protein meal. Clinical Science. 1990;78(5):481-5. Not relevant to key questions. [pmid: 2162274].
4299 Tammara V, Mahmood I, Yu DK, et al. A limited sampling method for the estimation of vigabatrin maximum plasma concentration and area under the curve. Therapeutic Drug Monitoring. 1997;19(1):79-82. Sample size less than 50 patients. [pmid: 9029752].
4300 Tamsma JT, Beverdam FH, Leuven JA, et al. Decreased interstitial apolipoprotein A-I levels in IDDM patients with diabetic nephropathy. Diabetes. 1995;44(5):501-5. Sample size less than 50 patients. [pmid: 7729606].
4301 Tamsma JT, van der Woude FJ, Lemkes HH. Effect of sulphated glycosaminoglycans on albuminuria in patients with overt diabetic (type 1) nephropathy. Nephrology Dialysis Transplantation. 1996;11(1):182-5. Follow-up less than 6 months.
4302 Tamura A, Goto Y, Miyamoto K, et al. Efficacy of single-bolus administration of sodium bicarbonate to prevent contrast-induced nephropathy in patients with mild renal insufficiency undergoing an elective coronary procedure. American Journal of Cardiology. 2009;104(7):921-5. Not CKD treatment. [pmid: 19766757].
4303 Tamura Y, Ikeda O, Nakasone Y, et al. Effect of sodium thiosulfate on cisplatin removal after intra-arterial embolization with a lipiodol-platinum suspension for hepatocellular carcinoma. Acta Radiologica. May. 2010;51(4):383-8. Not CKD treatment. [pmid: 20192896].
4304 Tamura Y, Kosuga M, Yamashita M, et al. Renoprotective effects of angiotensin II receptor blocker, candesartan cilexetil, in patients with stage 4-5 chronic kidney disease. Clinical & Experimental Nephrology. 2008;12(4):256-63. Not CKD treatment. [pmid: 18317875].
4305 Tan F, Mukherjee JJ, Lee KO, et al. Dual blockade of the renin-angiotensin-aldosterone system is safe and effective in reducing albuminuria in Asian type 2 diabetic patients with nephropathy. Singapore Medical Journal. Feb. 2010;51(2):151-6. Follow-up less than 6 months. [pmid: 20358155].
4306 Tan JK, Haberman HF, Coldman AJ. Identifying effective treatments for uremic pruritus. Journal of the American Academy of Dermatology. 1991;25(5 Pt 1):811-8. Not CKD treatment. [pmid: 1839393].
4307 Tan K, Chow WS, Wong Y, et al. Effect of losartan on plasma C-reactive protein in type 2 diabetic patients with microabluminuria. Diabetes Care. 2002;25(7):1254-5. Not relevant to key questions. [pmid: 12087039].
4308 Tan KCB, Chow WS, Ai VHG, et al. Effects of angiotensin II receptor antagonist on endothelial vasomotor function and urinary albumin excretion in type 2 diabetic patients with microalbuminuria. Diabetes/Metabolism Research Reviews. 2002;18(1):71-6. Not relevant to key questions.
4309 Tang AT, El-Gamel A, Keevil B, et al. The effect of ‘renal-dose’ dopamine on renal tubular function following cardiac surgery: assessed by measuring retinol binding protein (RBP). European Journal of Cardio-Thoracic Surgery. 1999;15(5):717-21. discussion 21-2. Not CKD treatment. [pmid: 10386423].
4310 Tang ATM, Knott J, Nanson J, et al. A prospective randomized study to evaluate the renoprotective action of beating heart coronary surgery in low risk patients. European Journal of Cardio-Thoracic Surgery. 2002;22(1):118-23. Not CKD treatment. [pmid: 12103384].
4311 Tang IY, Murray PT. Prevention of perioperative acute renal failure: what works?. Best Practice & Research. Clinical Anaesthesiology. 2004;18(1):91-111. Not relevant to key questions.
4312 Tang J, Wingerchuk DM, Crum BA, et al. Alpha-lipoic acid may improve symptomatic diabetic polyneuropathy. Neurologist. 2007;13(3):164-7. Follow-up less than 6 months. [pmid: 17495764].
4313 Tanihara S, Hayakawa T, Oki I, et al. Proteinuria is a prognostic marker for cardiovascular mortality: NIPPON DATA 80, 1980-1999. Journal of Epidemiology. 2005;15(4):146-53. Not RCT or controlled trial. [pmid: 16141633].
4314 Taniwaki H, Ishimura E, Kawagishi T, et al. Intrarenal hemodynamic changes after captopril test in patients with type 2 diabetes: a duplex Doppler sonography study. Diabetes Care. 2003;26(1):132-7. Follow-up less than 6 months. [pmid: 12502669].
4315 Tannehill SP, Mehta MP, Larson M, et al. Effect of amifostine on toxicities associated with sequential chemotherapy and radiation therapy for unresectable non-small-cell lung cancer: results of a phase II trial. Journal of Clinical Oncology. 1997;15(8):2850-7. Sample size less than 50 patients. [pmid: 9256128].
4316 Tannenbaum H, Davis P, Russell AS, et al. An evidence-based approach to prescribing NSAIDs in musculoskeletal disease: a Canadian consensus. Canadian NSAID Consensus Participants. CMAJ Canadian Medical Association Journal. 1996;155(1):77-88. Not CKD treatment.
4317 Tapp RJ, Zimmet PZ, Harper CA, et al. Diagnostic thresholds for diabetes: the association of retinopathy and albuminuria with glycaemia. Diabetes Research & Clinical Practice. 2006;73(3):315-21. Follow-up less than 6 months. [pmid: 16644057].
4318 Tarnow L, Rossing P, Jensen C, et al. Long-term renoprotective effect of nisoldipine and lisinopril in type 1 diabetic patients with diabetic nephropathy. Diabetes Care. 2000;23(12):1725-30. Sample size less than 50 patients. [pmid: 11128341].
4319 Tarnow L, Sato A, Ali S, et al. Effects of nisoldipine and lisinopril on left ventricular mass and function in diabetic nephropathy. Diabetes Care. 1999;22(3):491-4. Not CKD treatment. [pmid: 10097934].
4320 Tasanarong A, Piyayotai D, Thitiarchakul S. Protection of radiocontrast induced nephropathy by vitamin E (alpha tocopherol): a randomized controlled pilot study. Journal of the Medical Association of Thailand. 2009;92(10):1273-81. Not CKD treatment. [pmid: 19845233].
4321 Taskin F, Akdilli A, Karaman C, et al. Mammographically detected breast arterial calcifications: indicators for arteriosclerotic diseases?. European Journal of Radiology. 2006;60(2):250-5. Not RCT or controlled trial. [pmid: 16890393].
4322 Tassies D, Reverter JC, Cases A, et al. Effect of recombinant human erythropoietin treatment on circulating reticulated platelets in uremic patients: association with early improvement in platelet function. American Journal of Hematology. 1998;59(2):105-9. Not early CKD. [pmid: 9766793].
4323 Tataranni G, Malacarne F, Farinelli R, et al. Beneficial effects of verapamil in renal-risk surgical patients. Renal Failure. 1994;16(3):383-90. Sample size less than 50 patients. [pmid: 8059021].
4324 Tauxe WN, Mochizuki T, McCauley J, et al. A comparison of the renal effects (ERPF, GFR, and FF) of FK 506 and cyclosporine in patients with liver transplantation. Transplantation Proceedings. 1991;23(6):3146-7. Not CKD treatment. [pmid: 1721386].
4325 Tauzin-Fin P, Delort-Laval S, Krol-Houdek MC, et al. Effect of balanced analgesia with buprenorphine on pain response and general anaesthesia requirement during lithotripsy procedures. European Journal of Anaesthesiology. 1998;15(2):147-52. Not CKD treatment. [pmid: 9587719].
4326 Taverner D, Mackay IG, Craig K, et al. The effects of selective beta-adrenoceptor antagonists and partial agonist activity on renal function during exercise in normal subjects and those with moderate renal impairment. British Journal of Clinical Pharmacology. 1991;32(3):387-91. Sample size less than 50 patients. [pmid: 1685667].
4327 Taylor A Jr., Manatunga A, Morton K, et al. Multicenter trial validation of a camera-based method to measure Tc-99m mercaptoacetyltriglycine, or Tc-99m MAG3, clearance. Radiology. 1997;204(1):47-54. Sample size less than 50 patients. [pmid: 9205222].
4328 Team DT, Mugyenyi P, Walker AS, et al. Routine versus clinically driven laboratory monitoring of HIV antiretroviral therapy in Africa (DART): a randomised non-inferiority trial. Lancet. 2010;375(9709):123-31. Not CKD treatment. [pmid: 20004464].
4329 Tefekli A, Altunrende F, Tepeler K, et al. Tubeless percutaneous nephrolithotomy in selected patients: a prospective randomized comparison. International Urology & Nephrology. 2007;39(1):57-63. Sample size less than 50 patients. [pmid: 17171416].
4330 Teirstein PS, Price MJ, Mathur VS, et al. Differential effects between intravenous and targeted renal delivery of fenoldopam on renal function and blood pressure in patients undergoing cardiac catheterization. American Journal of Cardiology. 2006;97(7):1076-81. Sample size less than 50 patients. [pmid: 16563920].
4331 Teixeira SR, Tappenden KA, Carson L, et al. Isolated soy protein consumption reduces urinary albumin excretion and improves the serum lipid profile in men with type 2 diabetes mellitus and nephropathy. Journal of Nutrition. 2004;134(8):1874-80. Not RCT or controlled trial. [pmid: 15284369].
4332 Tejani A. Cyclosporine therapy for nephrotic syndrome. Nephron. 1997;77(4):488. Not RCT or controlled trial. [pmid: 9434078].
4333 Tejedor A, Torres AM, Castilla M, et al. Cilastatin protection against cyclosporin A-induced nephrotoxicity: clinical evidence. Current Medical Research & Opinion. 2007;23(3):505-13. Not relevant to key questions. [pmid: 17355732].
4334 Telishevka M, Chenett L, McKee M. Towards an understanding of the high death rate among young people with diabetes in Ukraine. Diabetic Medicine. 2001;18(1):3-9. Not RCT or controlled trial. [pmid: 11168334].
4335 ten Dam MA, Zwiers A, Crusius JB, et al. Tubular reabsorption of pepsinogen isozymogens in man studied by the inhibition of tubular protein reabsorption with dibasic amino acids. Clinical Science. 1991;80(2):161-6. Sample size less than 50 patients. [pmid: 1848169].
4336 Tepel M, van der Giet M, Schwarzfeld C, et al. Prevention of radiographic-contrast-agent-induced reductions in renal function by acetylcysteine. New England Journal of Medicine. 2000;343(3):180-4. Not early CKD. [pmid: 10900277].
4337 Tepel M, Zidek W. Acetylcysteine for radiocontrast nephropathy. Current Opinion in Critical Care. 2001;7(6):390-2. Not early CKD. [pmid: 11805540].
4338 Tepel M, Zidek W. Acetylcysteine and contrast media nephropathy. Current Opinion in Nephrology & Hypertension. 2002;11(5):503-6. Not CKD treatment. [pmid: 12187314].
4339 Tepel M, Zidek W. N-Acetylcysteine in nephrology; contrast nephropathy and beyond. Current Opinion in Nephrology & Hypertension. 2004;13(6):649-54. Not relevant to key questions. [pmid: 15483456].
4340 Teplan V, Schuck O, Knotek A, et al. Enhanced metabolic effect of erythropoietin and keto acids in CRF patients on low-protein diet: Czech multicenter study. American Journal of Kidney Diseases. 2003;41(3 Suppl 1):S26-30. Not early CKD. [pmid: 12612947].
4341 Teplan V, Schuck O, Knotek A, et al. Effects of low-protein diet supplemented with ketoacids and erythropoietin in chronic renal failure: a long-term metabolic study. Annals of Transplantation. 2001;6(1):47-53. Not relevant to key questions. [pmid: 11803607].
4342 Teplan V, Schuck O, Racek J, et al. Reduction of plasma asymmetric dimethylarginine in obese patients with chronic kidney disease after three years of a low-protein diet supplemented with keto-amino acids: a randomized controlled trial. Wiener Klinische Wochenschrift. 2008;120(15-16):478-85. Not CKD treatment. [pmid: 18820852].
4343 Teplan V, Schuck O, Votruba M, et al. Metabolic effects of keto acid--amino acid supplementation in patients with chronic renal insufficiency receiving a low-protein diet and recombinant human erythropoietin--a randomized controlled trial. Wiener Klinische Wochenschrift. 2001;113(17-18):661-9. Sample size less than 50 patients. [pmid: 11603100].
4344 Ter Maaten JC, Voorburg A, Heine RJ, et al. Renal handling of urate and sodium during acute physiological hyperinsulinaemia in healthy subjects. Clinical Science. 1997;92(1):51-8. Sample size less than 50 patients. [pmid: 9038591].
4345 ter Wee PM, Donker AJ. Clinical strategies for arresting progression of renal disease. Kidney International - Supplement. 1992;38:S114-20. Not relevant to key questions. [pmid: 1405361].
4346 Terrell KM, Perkins AJ, Hui SL, et al. Computerized decision support for medication dosing in renal insufficiency: a randomized, controlled trial. Annals of Emergency Medicine. Dec. 2010;56(6):623-9. Not CKD treatment. [pmid: 20452703].
4347 Tershakovec AM, Keane WF, Zhang Z, et al. Effect of LDL cholesterol and treatment with losartan on end-stage renal disease in the RENAAL study. Diabetes Care. 2008;31(3):445-7. Not RCT or controlled trial. [pmid: 18070995].
4348 Teschan PE, Beck GJ, Dwyer JT, et al. Effect of a ketoacid-aminoacid-supplemented very low protein diet on the progression of advanced renal disease: a reanalysis of the MDRD feasibility study. Clinical Nephrology. 1998;50(5):273-83. Not early CKD. [pmid: 9840314].
4349 Testani JM, Chen J, McCauley BD, et al. Potential effects of aggressive decongestion during the treatment of decompensated heart failure on renal function and survival. Circulation. Jul. 20. 2010;122(3):265-72. Not CKD treatment. [pmid: 20606118].
4350 Thakur V, Cook ME, Wallin JD. Antihypertensive effect of the combination of fosinopril and HCTZ is resistant to interference by nonsteroidal antiinflammatory drugs. American Journal of Hypertension. 1999;12(9 Pt 1):925-8. Sample size less than 50 patients. [pmid: 10509552].
4351 Thall PF, Wooten LH, Tannir NM. Monitoring event times in early phase clinical trials: some practical issues. Clinical Trials. 2005;2(6):467-78. Follow-up less than 6 months. [pmid: 16422307].
4352 Thiele H, Hildebrand L, Schirdewahn C, et al. Impact of high-dose N-acetylcysteine versus placebo on contrast-induced nephropathy and myocardial reperfusion injury in unselected patients with ST-segment elevation myocardial infarction undergoing primary percutaneous coronary intervention. The LIPSIA-N-ACC (Prospective, Single-Blind, Placebo-Controlled, Randomized Leipzig Immediate PercutaneouS Coronary Intervention Acute Myocardial Infarction N-ACC) Trial. Journal of the American College of Cardiology. May. 18. 2010;55(20):2201-9. Not CKD treatment. [pmid: 20466200].
4353 Thiesson HC, Jensen BL, Jespersen B, et al. Inhibition of cGMP-specific phosphodiesterase type 5 reduces sodium excretion and arterial blood pressure in patients with NaCl retention and ascites. American Journal of Physiology - Renal Physiology. 2005;288(5):F1044-52. Sample size less than 50 patients. [pmid: 15613622].
4354 Thijs A, Nanayakkara PWB, Ter Wee PM, et al. Mild-to-moderate renal impairment is associated with platelet activation: a cross-sectional study. Clinical Nephrology. 2008;70(4):325-31. Not CKD treatment. [pmid: 18826858].
4355 Thomas G, Rojas MC, Epstein SK, et al. Insulin therapy and acute kidney injury in critically ill patients a systematic review. Nephrology Dialysis Transplantation. 2007;22(10):2849-55. Not relevant to key questions.
4356 Thomas MC. Anemia in diabetes: marker or mediator of microvascular disease?. Nature Clinical Practice Nephrology. 2007;3(1):20-30. Not RCT or controlled trial.
4357 Thomas MC. The assessment and management of albuminuria in primary care. Diabetes Research & Clinical Practice. 2008;80(1):83-8. Not RCT or controlled trial. [pmid: 18093680].
4358 Thomas MC, Cooper ME, Rossing K, et al. Anaemia in diabetes: Is there a rationale to TREAT?. Diabetologia. 2006;49(6):1151-7. Follow-up less than 6 months. [pmid: 16586069].
4359 Thomas MC, Jerums G, Tsalamandris C, et al. Increased tubular organic ion clearance following chronic ACE inhibition in patients with type 1 diabetes. Kidney International. 2005;67(6):2494-9. Not RCT or controlled trial. [pmid: 15882297].
4360 Thomas MC, Weekes AJ, Broadley OJ, et al. The burden of chronic kidney disease in Australian patients with type 2 diabetes (the NEFRON study). [Erratum appears in Med J Aust. 2006 Oct 2;185(7):408]. Medical Journal of Australia. 2006;185(3):140-4. Not RCT or controlled trial. [pmid: 16893353].
4361 Thomas ME, Harris KP, Ramaswamy C, et al. Simvastatin therapy for hypercholesterolemic patients with nephrotic syndrome or significant proteinuria. Kidney International. 1993;44(5):1124-9. Sample size less than 50 patients. [pmid: 8264145].
4362 Thompson JF, Pike JM, Chumas PD, et al. Rectal diclofenac compared with pethidine injection in acute renal colic. BMJ. 1989;299(6708):1140-1. Not early CKD. [pmid: 2513026].
4363 Thomsen HS. Contrast-medium-induced nephrotoxicity: are all answers in for acetylcysteine?. European Radiology. 2001;11(12):2351-3. Not early CKD. [pmid: 11734930].
4364 Thomsen HS, Morcos SK. Risk of contrast-medium-induced nephropathy in high-risk patients undergoing MDCT--a pooled analysis of two randomized trials. European Radiology. Apr. 2009;19(4):891-7. Not CKD treatment. [pmid: 19002467].
4365 Thomsen HS, Morcos SK, Barrett BJ. Contrast-induced nephropathy: the wheel has turned 360 degrees. Acta Radiologica. 2008;49(6):646-57. Not CKD treatment. [pmid: 18568557].
4366 Thomsen HS, Sos TA, Nielsen SL. Renovascular hypertension. Diagnosis and intervention. Acta Radiologica. 1989;30(2):113-20. Not relevant to key questions. [pmid: 2522309].
4367 Thomsen OO, Danielsen H, Sorensen SS, et al. Effect of captopril on renal haemodynamics and the renin-angiotensin-aldosterone and osmoregulatory systems in essential hypertension. European Journal of Clinical Pharmacology. 1986;30(1):1-6. Sample size less than 50 patients. [pmid: 3519238].
4368 Thornalley PJ, Rabbani N. Therapy: Vitamin B6, B9 and B12 in diabetic nephropathy--beware. Nature Reviews Endocrinology. Sep. 2010;6(9):477-8. Not RCT or controlled trial.
4369 Thornley-Brown D, Wang X, Wright JT Jr., et al. Differing effects of antihypertensive drugs on the incidence of diabetes mellitus among patients with hypertensive kidney disease. Archives of Internal Medicine. 2006;166(7):797-805. Not relevant to key questions. [pmid: 16606818].
4370 Thyrum PT, Wong YW, Yeh C. Single-dose pharmacokinetics of quetiapine in subjects with renal or hepatic impairment. Progress in Neuro-Psychopharmacology & Biological Psychiatry. 2000;24(4):521-33. Not early CKD. [pmid: 10958148].
4371 Tillman J. Heparin versus citrate for anticoagulation in critically ill patients treated with continuous renal replacement therapy. Nursing in Critical Care. 2009;14(4):191-9. Not RCT or controlled trial. [pmid: 19531037].
4372 Tincani E, Mannucci C, Casolari B, et al. Safety of dalteparin for the prophylaxis of venous thromboembolism in elderly medical patients with renal insufficiency: a pilot study. Haematologica. 2006;91(7):976-9. Not CKD treatment. [pmid: 16757417].
4373 Tisdale JE, Rudis MI, Padhi ID, et al. Inhibition of N-acetylation of procainamide and renal clearance of N-acetylprocainamide by para-aminobenzoic acid in humans. Journal of Clinical Pharmacology. 1995;35(9):902-10. Not CKD treatment. [pmid: 8786250].
4374 Tiseo M, Martelli O, Mancuso A, et al. Short hydration regimen and nephrotoxicity of intermediate to high-dose cisplatin-based chemotherapy for outpatient treatment in lung cancer and mesothelioma. Tumori. 2007;93(2):138-44. Not relevant to key questions. [pmid: 17557559].
4375 Tleyjeh IM, Kashour T, Hakim FA, et al. Statins for the prevention and treatment of infections: a systematic review and meta-analysis. Archives of Internal Medicine. 2009;169(18):1658-67. Not RCT or controlled trial. [pmid: 19822822].
4376 Tobe S, Epstein M. The use of calcium antagonists in the treatment of hypertensive persons with kidney disease. Current Hypertension Reports. 2002;4(3):191-4. Not RCT or controlled trial. [pmid: 12003700].
4377 Toblli JE, Lombrana A, Duarte P, et al. Intravenous iron reduces NT-pro-brain natriuretic peptide in anemic patients with chronic heart failure and renal insufficiency. Journal of the American College of Cardiology. 2007;50(17):1657-65. Not RCT or controlled trial. [pmid: 17950147].
4378 Tod M, Minozzi C, Beaucaire G, et al. Isepamicin in intensive care unit patients with nosocomial pneumonia: population pharmacokinetic-pharmacodynamic study. Journal of Antimicrobial Chemotherapy. 1999;44(1):99-108. Not RCT or controlled trial. [pmid: 10459816].
4379 Todd PA, Goa KL. Enalapril. A reappraisal of its pharmacology and therapeutic use in hypertension. Drugs. 1992;43(3):346-81. Not relevant to key questions. [pmid: 1374319].
4380 Toivonen J, Kaukinen S, Oikkonen M, et al. Effects of deliberate hypotension induced by labetalol on renal function. European Journal of Anaesthesiology. 1991;8(1):13-20. Sample size less than 50 patients. [pmid: 1874198].
4381 Tokmakova MP, Skali H, Kenchaiah S, et al. Chronic kidney disease, cardiovascular risk, and response to angiotensin-converting enzyme inhibition after myocardial infarction: the Survival And Ventricular Enlargement (SAVE) study. Circulation. 2004;110(24):3667-73. Not RCT or controlled trial. [pmid: 15569840].
4382 Tolman C, Richardson D, Bartlett C, et al. Structured conversion from thrice weekly to weekly erythropoietic regimens using a computerized decision-support system: a randomized clinical study. Journal of the American Society of Nephrology. 2005;16(5):1463-70. Not RCT or controlled trial. [pmid: 15788469].
4383 Tomai F, Petrolini A, De Luca L, et al. Rationale and design of the Randomized comparison of XiEnce V and Multilink VisioN coronary stents in the sAme muLtivessel patient with chronic kiDnEy disease (RENAL-DES) study. Journal of Cardiovascular Medicine. Apr. 2010;11(4):310-7. Not CKD treatment. [pmid: 19924001].
4384 Tombach B, Bremer C, Reimer P, et al. Renal tolerance of a neutral gadolinium chelate (gadobutrol) in patients with chronic renal failure: results of a randomized study. Radiology. 2001;218(3):651-7. Sample size less than 50 patients. [pmid: 11230635].
4385 Tominaga Y, Kohara S, Namii Y, et al. Clonal analysis of nodular parathyroid hyperplasia in renal hyperparathyroidism. World Journal of Surgery. 1996;20(7):744-50. discussion 50-2. Not RCT or controlled trial. [pmid: 8678945].
4386 Tomita K, Marumo F. Effect of long-term carvedilol therapy on renal function in essential hypertension. Journal of Cardiovascular Pharmacology. Suppl 1. 1992;19:S97-101. Sample size less than 50 patients. [pmid: 1378158].
4387 Tomiyama H, Nishikawa E, Watanabe G, et al. Hormonal and cardiorenal responses to acute saline loading in mild congestive heart failure--the effect of angiotensin converting enzyme inhibition. Japanese Circulation Journal. 1998;62(1):29-35. Sample size less than 50 patients. [pmid: 9559415].
4388 Tomiyama H, Watanabe G, Abe M, et al. Systemic and renal effects of atrial natriuretic peptide in patients with heart failure treated with angiotensin-converting enzyme inhibitor or in acute saline solution loading. American Heart Journal. 2001;141(3):422-7. Not early CKD. [pmid: 11231440].
4389 Tomoda F, Takata M, Oh-Hashi S, et al. Altered renal response to enhanced endogenous 5-hydroxytryptamine after tryptophan administration in essential hypertension. Clinical Science. 1992;82(5):551-7. Sample size less than 50 patients. [pmid: 1317765].
4390 Tomson CRV, Foley RN, Li Q, et al. Race and end-stage renal disease in the United States Medicare population: the disparity persists. Nephrology. 2008;13(7):651-6. Not RCT or controlled trial. [pmid: 18808388].
4391 Tonelli M. The effect of statins on preservation of kidney function in patients with coronary artery disease. Current Opinion in Cardiology. 2006;21(6):608-12. Not relevant to key questions. [pmid: 17053412].
4392 Tonelli M, Collins D, Robins S, et al. Effect of gemfibrozil on change in renal function in men with moderate chronic renal insufficiency and coronary disease. American Journal of Kidney Diseases. 2004;44(5):832-9. Sample size less than 50 patients. [pmid: 15492949].
4393 Tonelli M, Collins D, Robins S, et al. Gemfibrozil for secondary prevention of cardiovascular events in mild to moderate chronic renal insufficiency. Kidney International. 2004;66(3):1123-30. Not CKD treatment. [pmid: 15327407].
4394 Tonelli M, Gill J, Pandeya S, et al. Barriers to blood pressure control and angiotensin enzyme inhibitor use in Canadian patients with chronic renal insufficiency. Nephrology Dialysis Transplantation. 2002;17(8):1426-33. Not relevant to key questions.
4395 Tonelli M, Isles C, Craven T, et al. Effect of pravastatin on rate of kidney function loss in people with or at risk for coronary disease. Circulation. 2005;112(2):171-8. Sample size less than 50 patients. [pmid: 15998677].
4396 Tonelli M, Jose P, Curhan G, et al. Proteinuria, impaired kidney function, and adverse outcomes in people with coronary disease: analysis of a previously conducted randomised trial. BMJ. 2006;332(7555):1426. Follow-up less than 6 months. [pmid: 16714328].
4397 Tonelli M, Keech A, Shepherd J, et al. Effect of pravastatin in people with diabetes and chronic kidney disease. Journal of the American Society of Nephrology. 2005;16(12):3748-54. Not RCT or controlled trial. [pmid: 16251235].
4398 Tonelli M, Manns B, Feller-Kopman D. Acute renal failure in the intensive care unit: a systematic review of the impact of dialytic modality on mortality and renal recovery. American Journal of Kidney Diseases. 2002;40(5):875-85. Not CKD treatment. [pmid: 12407631].
4399 Tonelli M, Moye L, Sacks FM, et al. Effect of pravastatin on loss of renal function in people with moderate chronic renal insufficiency and cardiovascular disease. Journal of the American Society of Nephrology. 2003;14(6):1605-13. Not relevant to key questions. [pmid: 12761262].
4400 Tonelli M, Sacks F, Pfeffer M, et al. Biomarkers of inflammation and progression of chronic kidney disease. Kidney International. 2005;68(1):237-45. Not RCT or controlled trial. [pmid: 15954913].
4401 Tonelli M, Wiebe N, Culleton B, et al. Chronic kidney disease and mortality risk: a systematic review. Journal of the American Society of Nephrology. 2006;17(7):2034-47. Not CKD treatment. [pmid: 16738019].
4402 Tong GD, Zhou DQ, He JS, et al. Clinical research on navel application of Shehuang Paste combined with Chinese herbal colon dialysis in treatment of refractory cirrhotic ascites complicated with azotemia. World Journal of Gastroenterology. 2006;12(48):7798-804. Not relevant to key questions. [pmid: 17203523].
4403 Tong PCY, Ko GTC, Chan WB, et al. The efficacy and tolerability of fosinopril in Chinese type 2 diabetic patients with moderate renal insufficiency. Diabetes, Obesity & Metabolism. 2006;8(3):342-7. Not relevant to key questions.
4404 Tonolo G, Ciccarese M, Brizzi P, et al. Reduction of albumin excretion rate in normotensive microalbuminuric type 2 diabetic patients during long-term simvastatin treatment. Diabetes Care. 1997;20(12):1891-5. Sample size less than 50 patients. [pmid: 9405913].
4405 Toppozada M, Darwish EA, Osman YF, et al. Low dose acetyl salicylic acid in severe preeclampsia. International Journal of Gynaecology & Obstetrics. 1991;35(4):311-7. Not CKD treatment. [pmid: 1682177].
4406 Torner A, Odar-Cederlof I, Kallner A, et al. Renal function in community-dwelling frail elderly. Comparison between measured and predicted glomerular filtration rate in the elderly and proposal for a new cystatin C-based prediction equation. Aging-Clinical & Experimental Research. 2008;20(3):216-25. Not RCT or controlled trial. [pmid: 18594189].
4407 Toso A, Maioli M, Leoncini M, et al. Usefulness of atorvastatin (80 mg) in prevention of contrast-induced nephropathy in patients with chronic renal disease. American Journal of Cardiology. 2010;105(3):288-92. Not CKD treatment. [pmid: 20102936].
4408 Toto R, Shultz P, Raij L, et al. Efficacy and tolerability of losartan in hypertensive patients with renal impairment. Collaborative Group. Hypertension. 1998;31(2):684-91. Follow-up less than 6 months. [pmid: 9461241].
4409 Toto RD. Management of hypertensive chronic kidney disease: role of calcium channel blockers. Journal of Clinical Hypertension. 2005;7(4 Suppl 1):15-20. Not early CKD. [pmid: 15858398].
4410 Toto RD. Lessons from the African-American Study of Kidney Disease and Hypertension: an update. Current Hypertension Reports. 2006;8(5):409-12. Not RCT or controlled trial. [pmid: 16965728].
4411 Toto RD, Adams-Huet B, Fenves AZ, et al. Effect of ramipril on blood pressure and protein excretion rate in normotensive nondiabetic patients with proteinuria. American Journal of Kidney Diseases. 1996;28(6):832-40. Sample size less than 50 patients. [pmid: 8957034].
4412 Toto RD, Anderson SA, Brown-Cartwright D, et al. Effects of acute and chronic dosing of NSAIDs in patients with renal insufficiency. Kidney International. 1986;30(5):760-8. Not relevant to key questions. [pmid: 3784306].
4413 Toto RD, Greene T, Hebert LA, et al. Relationship between body mass index and proteinuria in hypertensive nephrosclerosis: results from the African American Study of Kidney Disease and Hypertension (AASK) cohort. American Journal of Kidney Diseases. Nov. 2010;56(5):896-906. Not relevant to key questions. [pmid: 20801567].
4414 Toto RD, Grundy SM, Vega GL. Pravastatin treatment of very low density, intermediate density and low density lipoproteins in hypercholesterolemia and combined hyperlipidemia secondary to the nephrotic syndrome. American Journal of Nephrology. 2000;20(1):12-7. Sample size less than 50 patients. [pmid: 10644862].
4415 Toto RD, Mitchell HC, Lee HC, et al. Reversible renal insufficiency due to angiotensin converting enzyme inhibitors in hypertensive nephrosclerosis. Annals of Internal Medicine. 1991;115(7):513-9. Not relevant to key questions. [pmid: 1883120].
4416 Toto RD, Mitchell HC, Pettinger WA. Treatment of hypertension in nondiabetic renal disease. Current Opinion in Nephrology & Hypertension. 1994;3(3):279-85. Not RCT or controlled trial. [pmid: 7922253].
4417 Toto RD, Tian M, Fakouhi K, et al. Effects of calcium channel blockers on proteinuria in patients with diabetic nephropathy. Journal of Clinical Hypertension. 2008;10(10):761-9. Sample size less than 50 patients. [pmid: 19090877].
4418 Toussaint ND, Lau KK, Strauss BJ, et al. Using vertebral bone densitometry to determine aortic calcification in patients with chronic kidney disease. Nephrology. Aug. 2010;15(5):575-83. Not CKD treatment. [pmid: 20649879].
4419 Toussaint ND, Lau KK, Strauss BJ, et al. Effect of alendronate on vascular calcification in CKD stages 3 and 4: a pilot randomized controlled trial. American Journal of Kidney Diseases. Jul. 2010;56(1):57-68. Not CKD treatment. [pmid: 20347511].
4420 Townend JN, Doran J, Lote CJ, et al. Peripheral haemodynamic effects of inhibition of prostaglandin synthesis in congestive heart failure and interactions with captopril. British Heart Journal. 1995;73(5):434-41. Not CKD treatment. [pmid: 7786658].
4421 Townsend RR, Cohen DL, Katholi R, et al. Safety of intravenous gadolinium (Gd-BOPTA) infusion in patients with renal insufficiency. American Journal of Kidney Diseases. 2000;36(6):1207-12. Sample size less than 50 patients. [pmid: 11096046].
4422 Tozija L, Antova Z, Cakalaroski K, et al. Infection as a risk factor in the outcome of patients with acute renal failure assessed by SOFA score. Makedonska Akademija na Naukite i Umetnostite Oddelenie Za Bioloshki i Meditsinski Nauki Prilozi. 2006;27(1):17-27. Not relevant to key questions.
4423 Tozun N, Berkman K, Tankurt E, et al. Effect of diltiazem on renal function in patients with liver cirrhosis. International Journal of Clinical Pharmacology, Therapy, & Toxicology. 1991;29(5):198-203. Sample size less than 50 patients.
4424 Tramer MR, Williams JE, Carroll D, et al. Comparing analgesic efficacy of non-steroidal anti-inflammatory drugs given by different routes in acute and chronic pain: a qualitative systematic review. Acta Anaesthesiologica Scandinavica. 1998;42(1):71-9. Not RCT or controlled trial. [pmid: 9527748].
4425 Tramonti G, Donadio C, Silvestri L, et al. Renal effects of prolonged antihypertensive treatment with diltiazem. Kidney International - Supplement. 1996;55:S78-80. Sample size less than 50 patients. [pmid: 8743517].
4426 Trenkwalder C, Stiasny K, Pollmacher T, et al. L-dopa therapy of uremic and idiopathic restless legs syndrome: a double-blind, crossover trial. Sleep. 1995;18(8):681-8. Sample size less than 50 patients. [pmid: 8560135].
4427 Trewhella M, Dawson P, Forsling M, et al. Vasopressin release in response to intravenously injected contrast media. British Journal of Radiology. 1990;63(746):97-100. Not CKD treatment. [pmid: 2310915].
4428 Triposkiadis F, Parissis JT, Starling RC, et al. Current drugs and medical treatment algorithms in the management of acute decompensated heart failure. Expert Opinion on Investigational Drugs. 2009;18(6):695-707. Not CKD treatment. [pmid: 19426120].
4429 Tritrakarn T, Lertakyamanee J, Koompong P, et al. Both EMLA and placebo cream reduced pain during extracorporeal piezoelectric shock wave lithotripsy with the Piezolith 2300. Anesthesiology. 2000;92(4):1049-54. Not early CKD. [pmid: 10754625].
4430 Trivedi H, Daram S, Szabo A, et al. High-dose N-acetylcysteine for the prevention of contrast-induced nephropathy. American Journal of Medicine. 2009;122(9):874.e9-15. Not CKD treatment. [pmid: 19699385].
4431 Trivedi H, Lu N, Andresen BT, et al. Slower decline of renal function after initiation of rosiglitazone in diabetics -- a pilot study. Clinical Nephrology. 2009;72(3):181-5. Not CKD treatment. [pmid: 19761722].
4432 Trivedi HS, Moore H, Nasr S, et al. A randomized prospective trial to assess the role of saline hydration on the development of contrast nephrotoxicity. Nephron. 2003;93(1):C29-34. Not CKD treatment. [pmid: 12411756].
4433 Trocha AK, Schmidtke C, Didjurgeit U, et al. Effects of intensified antihypertensive treatment in diabetic nephropathy: mortality and morbidity results of a prospective controlled 10-year study. Journal of Hypertension. 1999;17(10):1497-503. Not RCT or controlled trial. [pmid: 10526912].
4434 Troiano M, Corsa P, Raguso A, et al. Radiation therapy in urinary cancer: state of the art and perspective. Radiologia Medica. 2009;114(1):70-82. Not CKD treatment. [pmid: 19082788].
4435 Trollfors B, Norrby R, Bergmark J, et al. Comparative toxicity of gentamicin and cefotetan. Scandinavian Journal of Infectious Diseases. 1986;18(2):139-46. Follow-up less than 6 months. [pmid: 3518049].
4436 Tsai CF, Wang SJ, Fuh JL. Moderate chronic kidney disease is associated with reduced cognitive performance in midlife women. Kidney International. Sep. 2010;78(6):605-10. Not CKD treatment. [pmid: 20571474].
4437 Tsai JC, Chen SC, Hwang SJ, et al. Prevalence and risk factors for CKD in spouses and relatives of hemodialysis patients. American Journal of Kidney Diseases. May. 2010;55(5):856-66. Not CKD treatment. [pmid: 20153917].
4438 Tsai JJ, Yeun JY, Kumar VA, et al. Comparison and interpretation of urinalysis performed by a nephrologist versus a hospital-based clinical laboratory. American Journal of Kidney Diseases. 2005;46(5):820-9. Not relevant to key questions. [pmid: 16253721].
4439 Tsai SY, Tseng HF, Tan HF, et al. End-stage renal disease in Taiwan: a case-control study. Journal of Epidemiology. 2009;19(4):169-76. Not RCT or controlled trial. [pmid: 19542686].
4440 Tsai YT, Lin HC, Lee FY, et al. Effects of captopril on renal functions, renal and portal hemodynamics in patients with cirrhosis. Proceedings of the National Science Council, Republic of China - Part B, Life Sciences. 1996;20(2):44-50. Not CKD treatment.
4441 Tsang GM, Allen S, Pagano D, et al. Pentoxifylline preloading reduces endothelial injury and permeability in cardiopulmonary bypass. ASAIO Journal. 1996;42(5):M429-34. Not CKD treatment. [pmid: 9063959].
4442 Tsao C, Greene P, Odlind B, et al. Pharmacokinetics of recombinant human superoxide dismutase in healthy volunteers. Clinical Pharmacology & Therapeutics. 1991;50(6):713-20. Not CKD treatment. [pmid: 1752116].
4443 Tschuppert Y, Buclin T, Rothuizen LE, et al. Effect of dronedarone on renal function in healthy subjects. British Journal of Clinical Pharmacology. 2007;64(6):785-91. Not RCT or controlled trial. [pmid: 17662087].
4444 Tsuboi M, Shiraki M, Hamada M, et al. Effects of phosphorus-containing calcium preparation (bone meal powder) and calcium carbonate on serum calcium and phosphorus in young and old healthy volunteers: a double-blinded crossover study. Journal of Bone & Mineral Metabolism. 2000;18(6):321-7. Not early CKD. [pmid: 11052464].
4445 Tsunoda K, Abe K, Omata K, et al. Effects of cicletanine on the urinary excretion of prostanoids and kallikrein, and on renal function in man. Cardiovascular Drugs & Therapy. 1993;7(2):253-6. Sample size less than 50 patients. [pmid: 8357779].
4446 Tsuruoka K, Yasuda T, Koitabashi K, et al. Evaluation of renal microcirculation by contrast-enhanced ultrasound with Sonazoid as a contrast agent. International Heart Journal. May. 2010;51(3):176-82. Not CKD treatment. [pmid: 20558907].
4447 Tsuruoka S, Ioka T, Wakaumi M, et al. Severe arrhythmia as a result of the interaction of cetirizine and pilsicainide in a patient with renal insufficiency: first case presentation showing competition for excretion via renal multidrug resistance protein 1 and organic cation transporter 2. [Erratum appears in Clin Pharmacol Ther. 2006 Dec;80(6):645]. Clinical Pharmacology & Therapeutics. 2006;79(4):389-96. Sample size less than 50 patients. [pmid: 16580907].
4448 Tugwell P, Ludwin D, Gent M, et al. Interaction between cyclosporin A and nonsteroidal antiinflammatory drugs. Journal of Rheumatology. 1997;24(6):1122-5. Not CKD treatment. [pmid: 9195520].
4449 Tumlin JA, Wang A, Murray PT, et al. Fenoldopam mesylate blocks reductions in renal plasma flow after radiocontrast dye infusion: a pilot trial in the prevention of contrast nephropathy. American Heart Journal. 2002;143(5):894-903. Not early CKD. [pmid: 12040355].
4450 Tuominen JA, Ebeling P, Koivisto VA. Long-term lisinopril therapy reduces exercise-induced albuminuria in normoalbuminuric normotensive IDDM patients. Diabetes Care. 1998;21(8):1345-8. Sample size less than 50 patients. [pmid: 9702445].
4451 Turakhia MP, Varosy PD, Lee K, et al. Impact of renal function on survival in patients with implantable cardioverter-defibrillators. Pacing & Clinical Electrophysiology. 2007;30(3):377-84. Not RCT or controlled trial. [pmid: 17367357].
4452 Turk S, Yeksan M, Tamer N, et al. Effect of 1,25 (OH)2D3 treatment on glucose intolerance in uraemia. Nephrology Dialysis Transplantation. 1992;7(12):1207-12. Not early CKD.
4453 Turker H, Donmez A, Zeyneloglu P, et al. Effects of enalaprilat infusion on hemodynamics and renal function in patients undergoing cardiac surgery. Anadolu Kardiyoloji Dergisi. 2004;4(4):296-300. Follow-up less than 6 months. [pmid: 15590356].
4454 Turnbull DA, Wilkinson C, Griffith EC, et al. The psychosocial outcomes of antenatal day care for three medical complications of pregnancy: a randomised controlled trial of 395 women. Australian & New Zealand Journal of Obstetrics & Gynaecology. 2006;46(6):510-6. Not RCT or controlled trial. [pmid: 17116056].
4455 Turner R. Hepatic and renal tolerability of long-term naproxen treatment in patients with rheumatoid arthritis. Seminars in Arthritis & Rheumatism. 1988;17(3 Suppl 2):29-35. Not RCT or controlled trial. [pmid: 3334108].
4456 Turner S, Derham C, Orsi NM, et al. Randomized clinical trial of the effects of methylprednisolone on renal function after major vascular surgery. British Journal of Surgery. 2008;95(1):50-6. Not CKD treatment. [pmid: 18027383].
4457 Turner S, Dhamarajah S, Bosomworth M, et al. Effect of perioperative steroids on renal function after liver transplantation. Anaesthesia. 2006;61(3):253-9. Not early CKD. [pmid: 16480350].
4458 Tuttle KR. Albuminuria reduction: the holy grail for kidney protection. Kidney International. 2007;72(7):785-6. Not CKD treatment. [pmid: 17882241].
4459 Tuttle KR, Bakris GL, Toto RD, et al. The effect of ruboxistaurin on nephropathy in type 2 diabetes. Diabetes Care. 2005;28(11):2686-90. Not RCT or controlled trial. [pmid: 16249540].
4460 Tuttle KR, McGill JB, Haney DJ, et al. Kidney outcomes in long-term studies of ruboxistaurin for diabetic eye disease. Clinical Journal of The American Society of Nephrology: CJASN. 2007;2(4):631-6. Not CKD treatment. [pmid: 17699475].
4461 Tuttle KR, Puhlman ME, Cooney SK, et al. Effects of amino acids and glucagon on renal hemodynamics in type 1 diabetes. American Journal of Physiology - Renal Physiology. 2002;282(1):F103-12. Sample size less than 50 patients. [pmid: 11739118].
4462 Tutuncu NB, Gurlek A, Gedik O. Efficacy of ACE inhibitors and ATII receptor blockers in patients with microalbuminuria: a prospective study. Acta Diabetologica. 2001;38(4):157-61. Sample size less than 50 patients. [pmid: 11855793].
4463 Twigg SM, Cao Z, McLennan SV, et al. Renal connective tissue growth factor induction in experimental diabetes is prevented by aminoguanidine. Endocrinology. 2002;143(12):4907-15. Not human studies. [pmid: 12446618].
4464 Tylicki L, Renke M, Rutkowski P, et al. Dual blockade of the renin-angiotensin-aldosterone system with high-dose angiotensin-converting enzyme inhibitor for nephroprotection: an open, controlled, randomized study. Scandinavian Journal of Urology & Nephrology. 2008;42(4):381-8. Not RCT or controlled trial. [pmid: 19230172].
4465 Tylicki L, Renke M, Rutkowski P, et al. Effects of N-acetylcysteine on angiotensin-converting enzyme plasma activity in patients with chronic kidney diseases. Blood Purification. 2008;26(4):354. Not RCT or controlled trial. [pmid: 18487879].
4466 Tylicki L, Rutkowski P, Renke M, et al. Triple pharmacological blockade of the renin-angiotensin-aldosterone system in nondiabetic CKD: an open-label crossover randomized controlled trial. American Journal of Kidney Diseases. 2008;52(3):486-93. Not CKD treatment. [pmid: 18423812].
4467 Tzakis AG, Tryphonopoulos P, Kato T, et al. Preliminary experience with alemtuzumab (Campath-1H) and low-dose tacrolimus immunosuppression in adult liver transplantation. [Erratum appears in Transplantation. 2004 Aug 15;78(3):489]. Transplantation. 2004;77(8):1209-14. Not relevant to key questions. [pmid: 15114087].
4468 Uchino S, Doig GS, Bellomo R, et al. Diuretics and mortality in acute renal failure. Critical Care Medicine. 2004;32(8):1669-77. Not CKD treatment. [pmid: 15286542].
4469 Udelson JE, Smith WB, Hendrix GH, et al. Acute hemodynamic effects of conivaptan, a dual V(1A) and V(2) vasopressin receptor antagonist, in patients with advanced heart failure. Circulation. 2001;104(20):2417-23. Not early CKD. [pmid: 11705818].
4470 Ueda S. New approaches to blockade of the renin-angiotensin-aldosterone system: evidence from randomized controlled trials (RCTs) of angiotensin-converting enzyme inhibitors and angiotensin II-receptor blockers--questions remain unsolved. Journal of Pharmacological Sciences. 2010;113(4):292-5. Not relevant to key questions. [pmid: 20675956].
4471 Uehlinger DE, Gotch FA, Sheiner LB. A pharmacodynamic model of erythropoietin therapy for uremic anemia. Clinical Pharmacology & Therapeutics. 1992;51(1):76-89. Not early CKD. [pmid: 1732079].
4472 Uehlinger DE, Weidmann P, Gnaedinger MP. Cardiovascular regulation and lipoprotein profile during administration of co-dergocrine in essential hypertension. European Journal of Clinical Pharmacology. 1989;36(2):119-25. Not CKD treatment. [pmid: 2721537].
4473 Uhlig K, Wang SR, Beck GJ, et al. Factors associated with lipoprotein(a) in chronic kidney disease. American Journal of Kidney Diseases. 2005;45(1):28-38. Not relevant to key questions. [pmid: 15696441].
4474 Ujhelyi MR, Bottorff MB, Schur M, et al. Aging effects on the organic base transporter and stereoselective renal clearance. Clinical Pharmacology & Therapeutics. 1997;62(2):117-28. Sample size less than 50 patients. [pmid: 9284847].
4475 Umeki S, Tsukiyama K, Okimoto N, et al. Urinastatin (Kunitz-type proteinase inhibitor) reducing cisplatin nephrotoxicity. American Journal of the Medical Sciences. 1989;298(4):221-6. Not CKD treatment. [pmid: 2552802].
4476 Umscheid CA, Kohl BA, Williams K. Antifibrinolytic use in adult cardiac surgery. Current Opinion in Hematology. 2007;14(5):455-67. Follow-up less than 6 months. [pmid: 17934352].
4477 Ungar A, Fumagalli S, Marini M, et al. Renal, but not systemic, hemodynamic effects of dopamine are influenced by the severity of congestive heart failure. Critical Care Medicine. 2004;32(5):1125-9. Sample size less than 50 patients. [pmid: 15190961].
4478 Uozumi J, Koikawa Y, Yasumasu T, et al. The protective effect of methylprednisolone against cisplatin-induced nephrotoxicity in patients with urothelial tumors. International Journal of Urology. 1996;3(5):343-7. Not CKD treatment. [pmid: 8886909].
4479 Upadhyay L, Tripathi K, Kulkarni KS. A study of prostane in the treatment of benign prostatic hyperplasia. Phytotherapy Research. 2001;15(5):411-5. Not early CKD. [pmid: 11507733].
4480 Upton A, McCune JS, Kirby KA, et al. Fluconazole coadministration concurrent with cyclophosphamide conditioning may reduce regimen-related toxicity postmyeloablative hematopoietic cell transplantation. Biology of Blood & Marrow Transplantation. 2007;13(7):760-4. Follow-up less than 6 months. [pmid: 17580253].
4481 Usui I, Fujisaka S, Yamazaki K, et al. Telmisartan reduced blood pressure and HOMA-IR with increasing plasma leptin level in hypertensive and type 2 diabetic patients. Diabetes Research & Clinical Practice. 2007;77(2):210-4. Not RCT or controlled trial. [pmid: 17240472].
4482 Utsunomiya Y, Hara Y, Ito H, et al. Effects of probenecid on the pharmacokinetics of mizoribine and co-administration of the two drugs in patients with nephrotic syndrome. International Journal of Clinical Pharmacology & Therapeutics. Nov. 2010;48(11):751-5. Sample size less than 50 patients. [pmid: 20979934].
4483 Uzan S, Beaufils M, Breart G, et al. Prevention of fetal growth retardation with low-dose aspirin: findings of the EPREDA trial. Lancet. 1991;337(8755):1427-31. Not adult population. [pmid: 1675315].
4484 Uzu T, Fujii T, Nishimura M, et al. Determinants of circadian blood pressure rhythm in essential hypertension. American Journal of Hypertension. 1999;12(1 Pt 1):35-9. Not CKD treatment. [pmid: 10075382].
4485 Vahabi S, Heidari M, Kazemi AH, et al. Assessment of clonidine effect as premedicative drug on kidney function. JPMA - Journal of the Pakistan Medical Association. Jul. 2010;60(7):570-2. Not CKD treatment.
4486 Vaitkus PT, Brar C. N-acetylcysteine in the prevention of contrast-induced nephropathy: publication bias perpetuated by meta-analyses. American Heart Journal. 2007;153(2):275-80. Not early CKD. [pmid: 17239689].
4487 Valantine H, Keogh A, McIntosh N, et al. Cost containment: coadministration of diltiazem with cyclosporine after heart transplantation. Journal of Heart & Lung Transplantation. 1992;11(1 Pt 1):1-7. discussion -8. Not CKD treatment. [pmid: 1540597].
4488 Valeri A, Gelfand J, Blum C, et al. Treatment of the hyperlipidemia of the nephrotic syndrome: a controlled trial. American Journal of Kidney Diseases. 1986;8(6):388-96. Sample size less than 50 patients. [pmid: 3544820].
4489 Valvo E, Casagrande P, Bedogna V, et al. Systemic and renal effects of a new angiotensin converting enzyme inhibitor, benazepril, in essential hypertension. Journal of Hypertension. 1990;8(11):991-5. Sample size less than 50 patients. [pmid: 1963190].
4490 van Acker BA, Prummel MF, Weber JA, et al. Effect of prednisone on renal function in man. Nephron. 1993;65(2):254-9. Follow-up less than 6 months. [pmid: 8247189].
4491 van Berge-Landry H, James GD. Serum electrolyte, serum protein, serum fat and renal responses to a dietary sodium challenge: allostasis and allostatic load. Annals of Human Biology. 2004;31(4):477-87. Not CKD treatment. [pmid: 15513697].
4492 Van Biesen W, De Bacquer D, Verbeke F, et al. The glomerular filtration rate in an apparently healthy population and its relation with cardiovascular mortality during 10 years. European Heart Journal. 2007;28(4):478-83. Not relevant to key questions. [pmid: 17223665].
4493 Van Buren D, Payne J, Geevarghese S, et al. Renal function in primary liver transplant recipients receiving neoral (cyclosporine) versus prograf (tacrolimus). Transplantation Proceedings. 1998;30(4):1401-2. Not CKD treatment. [pmid: 9636566].
4494 van de Wal RMA, Gansevoort RT, van der Harst P, et al. Predictors of angiotensin-converting enzyme inhibitor-induced reduction of urinary albumin excretion in nondiabetic patients. Hypertension. 2006;48(5):870-6. Not relevant to key questions. [pmid: 17000930].
4495 van de Wal RMA, van der Harst P, Gerritsen WBM, et al. Plasma matrix metalloproteinase-9 and ACE-inhibitor-induced improvement of urinary albumin excretion in non-diabetic, microalbuminuric subjects. Journal of the Renin-Angiotensin-Aldosterone System. 2007;8(4):177-80. Not CKD treatment. [pmid: 18205096].
4496 van den Bergh JP, Kaufmann BG, van Riet GJ, et al. Comparison of three formulations of calcium acetate tablets to evaluate tolerance and control of hyperphosphatemia in patients with chronic renal failure. Nephron. 1994;68(4):505-6. Sample size less than 50 patients. [pmid: 7870237].
4497 Van den Berghe G, Wilmer A, Hermans G, et al. Intensive insulin therapy in the medical ICU. New England Journal of Medicine. 2006;354(5):449-61. Not RCT or controlled trial. [pmid: 16452557].
4498 van den Meiracker AH, van der Linde NAJ, Broere A, et al. Effects of L-arginine and L-NAME on the renal function in hypertensive and normotensive subjects. Nephron. 2002;91(3):444-51. Not CKD treatment. [pmid: 12119475].
4499 van der Jagt RH, Pari G, McDiarmid SA, et al. Effect of pentoxifylline on regimen related toxicity in patients undergoing allogeneic or autologous bone marrow transplantation. Bone Marrow Transplantation. 1994;13(2):203-7. Not RCT or controlled trial. [pmid: 8205090].
4500 van der Kleij FGH, de Jong PE, Henning RH, et al. Enhanced responses of blood pressure, renal function, and aldosterone to angiotensin I in the DD genotype are blunted by low sodium intake. Journal of the American Society of Nephrology. 2002;13(4):1025-33. Not early CKD. [pmid: 11912262].
4501 van der Linde NA, Boomsma F, van den Meiracker AH. Potentiation of L-NAME-induced systemic and renal vasoconstrictor responses by alpha1-adrenoceptor antagonism. Journal of Hypertension. 2005;23(5):1017-24. Not relevant to key questions. [pmid: 15834288].
4502 van der Linde NA, van den Meiracker AH, Boomsma F. Role of angiotensin II in L-NAME-induced systemic and renal hemodynamic effects in hydrochlorothiazide-pretreated hypertensive subjects. Journal of Hypertension. 2003;21(2):345-51. Sample size less than 50 patients. [pmid: 12569265].
4503 van der Meulen J, Reijn E, Heidendal GA, et al. Comparison of the effects of penbutolol and propranolol on glomerular filtration rate in hypertensive patients with impaired renal function. British Journal of Clinical Pharmacology. 1986;22(4):469-74. Sample size less than 50 patients. [pmid: 3533129].
4504 van der Pijl JW, Lemkes HH, Frolich M, et al. Effect of danaparoid sodium on proteinuria, von Willebrand factor, and hard exudates in patients with diabetes mellitus type 2. Journal of the American Society of Nephrology. 1999;10(6):1331-6. Sample size less than 50 patients. [pmid: 10361873].
4505 van der Pijl JW, van der Woude FJ, Geelhoed-Duijvestijn PH, et al. Danaparoid sodium lowers proteinuria in diabetic nephropathy. Journal of the American Society of Nephrology. 1997;8(3):456-62. Follow-up less than 6 months. [pmid: 9071714].
4506 van der Putten K, Jie KE, van den Broek D, et al. Hepcidin-25 is a marker of the response rather than resistance to exogenous erythropoietin in chronic kidney disease/chronic heart failure patients. European Journal of Heart Failure. Sep. 2010;12(9):943-50. Sample size less than 50 patients. [pmid: 20601671].
4507 van der Zander K, Houben AJHM, Webb DJ, et al. Selective endothelin B receptor blockade does not influence BNP-induced natriuresis in man. Kidney International. 2006;69(5):864-8. Follow-up less than 6 months. [pmid: 16518347].
4508 van der Zee S, Baber U, Elmariah S, et al. Cardiovascular risk factors in patients with chronic kidney disease. Nature Reviews Cardiology. 2009;6(9):580-9. Not RCT or controlled trial.
4509 van Essen GG, Rensma PL, de Zeeuw D, et al. Association between angiotensin-converting-enzyme gene polymorphism and failure of renoprotective therapy. Lancet. 1996;347(8994):94-5. Not RCT or controlled trial. [pmid: 8538349].
4510 van Hamersvelt HW, Sluiter HE, Wetzels JF, et al. Is natriuresis on felodipine due to reversal of the renal effects of angiotensin II?. Kidney International - Supplement. 1992;36:S73-7. Not CKD treatment. [pmid: 1535400].
4511 Van Hamersvelt HW, Wetzels JF, Kloke HJ, et al. Exogenous aldosterone antagonizes distal tubular effects of calcium entry blocker felodipine. American Journal of Physiology. 1994;266(6 Pt 2):F843-9. Sample size less than 50 patients. [pmid: 8023964].
4512 van Hamersvelt HW, Wetzels JF, Koene RA, et al. Metoclopramide stimulates kaliuresis during felodipine without affecting its natriuresis. Hypertension. 1994;24(5):633-9. Not CKD treatment. [pmid: 7960025].
4513 van Paassen P, de Zeeuw D, de Jong PE. Renal and systemic effects of the renin inhibitor remikiren in patients with essential hypertension. Journal of Cardiovascular Pharmacology. 1995;26(1):39-45. Sample size less than 50 patients. [pmid: 7564363].
4514 van Paassen P, Navis GJ, De Jong PE, et al. Pretreatment renal vascular tone predicts the effect of specific renin inhibition on natriuresis in essential hypertension. European Journal of Clinical Investigation. 1999;29(12):1019-26. Sample size less than 50 patients. [pmid: 10583449].
4515 Van Praet JT, De Vriese AS. Prevention of contrast-induced nephropathy: a critical review. Current Opinion in Nephrology & Hypertension. 2007;16(4):336-47. Not RCT or controlled trial. [pmid: 17565276].
4516 van Rijthoven AW, Dijkmans BA, Goei The HS, et al. Longterm cyclosporine therapy in rheumatoid arthritis. Journal of Rheumatology. 1991;18(1):19-23. Not CKD treatment. [pmid: 2023194].
4517 van Rossum LK, Mathot RAA, Cransberg K, et al. Optimal sampling strategies to assess inulin clearance in children by the inulin single-injection method. Clinical Chemistry. 2003;49(7):1170-9. Not CKD treatment. [pmid: 12816915].
4518 van Stralen KJ, Jager KJ, Zoccali C, et al. Agreement between methods. Kidney International. 2008;74(9):1116-20. Not CKD treatment. [pmid: 18596728].
4519 Van Tilborg KA, Rabelink TJ, Koomans HA. Naloxone inhibits renal hemodynamic effect of head-out water immersion in humans. Kidney International. 1995;48(3):860-5. Sample size less than 50 patients. [pmid: 7474676].
4520 Van Wyck DB, Roppolo M, Martinez CO, et al. A randomized, controlled trial comparing IV iron sucrose to oral iron in anemic patients with nondialysis-dependent CKD. Kidney International. 2005;68(6):2846-56. Sample size less than 50 patients. [pmid: 16316362].
4521 Van Zuilen AD, Wetzels JFM, Blankestijn PJ, et al. Rationale and design of the MASTERPLAN study: Multifactorial approach and superior treatment efficacy in renal patients with the aid of nurse practitioners. Journal of Nephrology. 2005;18(1):30-4. Not RCT or controlled trial. [pmid: 15772920].
4522 Van Zuilen AD, Wetzels JFM, Bots ML, et al. MASTERPLAN: study of the role of nurse practitioners in a multifactorial intervention to reduce cardiovascular risk in chronic kidney disease patients. Journal of Nephrology. 2008;21(3):261-7. Not CKD treatment. [pmid: 18587712].
4523 van Zyl A, Jennings AA, Byrne MJ, et al. Effects of therapy on renal impairment in essential hypertension. South African Medical Journal. Suid-Afrikaanse Tydskrif Vir Geneeskunde. 1992;82(6):407-10. Sample size less than 50 patients. [pmid: 1465689].
4524 Vanholder R, Lameire N. Does biocompatibility of dialysis membranes affect recovery of renal function and survival?. Lancet. 1999;354(9187):1316-8. Not RCT or controlled trial. [pmid: 10533855].
4525 Vanholder R, Lameire N. Does biocompatibility of dialysis membranes affect recovery of renal function and survival?. Lancet. 1999;354(9187):1316-8. Not RCT or controlled trial. [pmid: 10533855].
4526 Vanholder R, Lamiere N, Ringoir S. Therapeutic effect and complication profile of clonidine-beta-blocker combinations. Kidney International - Supplement. 1988;25:S181-3. Not early CKD. [pmid: 2903267].
4527 Vanni S, Polidori G, Cecioni I, et al. ET(B) receptor in renal medulla is enhanced by local sodium during low salt intake. Hypertension. 2002;40(2):179-85. Sample size less than 50 patients. [pmid: 12154110].
4528 Varghese SA, Powell TB, Janech MG, et al. Identification of diagnostic urinary biomarkers for acute kidney injury. Journal of Investigative Medicine. Apr. 2010;58(4):612-20. Not CKD treatment. [pmid: 20224435].
4529 Vargo DL, Brater DC, Rudy DW, et al. Dopamine does not enhance furosemide-induced natriuresis in patients with congestive heart failure. Journal of the American Society of Nephrology. 1996;7(7):1032-7. Sample size less than 50 patients. [pmid: 8829118].
4530 Varriale P, Mossavi A. The benefit of low-dose dopamine during vigorous diuresis for congestive heart failure associated with renal insufficiency: does it protect renal function?. Clinical Cardiology. 1997;20(7):627-30. Not CKD treatment. [pmid: 9220179].
4531 Vasavada N, Agarwal R. Role of excess volume in the pathophysiology of hypertension in chronic kidney disease. Kidney International. 2003;64(5):1772-9. Follow-up less than 6 months. [pmid: 14531810].
4532 Vasavada N, Saha C, Agarwal R. A double-blind randomized crossover trial of two loop diuretics in chronic kidney disease. Kidney International. 2003;64(2):632-40. Sample size less than 50 patients. [pmid: 12846760].
4533 Vase H, Lauridsen TG, Bech JN, et al. Eprosartan modulates the reflex activation of the sympathetic nervous system in sodium restricted healthy humans. British Journal of Clinical Pharmacology. 2008;65(6):822-32. Not CKD treatment. [pmid: 18341678].
4534 Vase H, Lauridsen TG, Bech JN, et al. Effects of dihydralazine on renal water and aquaporin-2 excretion in humans. Scandinavian Journal of Clinical & Laboratory Investigation. 2009;69(1):45-51. Not RCT or controlled trial. [pmid: 18728933].
4535 Vasheghani-Farahani A, Sadigh G, Kassaian SE, et al. Sodium bicarbonate in preventing contrast nephropathy in patients at risk for volume overload: a randomized controlled trial. Journal of Nephrology. Mar-Apr. 2010;23(2):216-23. Not CKD treatment. [pmid: 20175053].
4536 Vasheghani-Farahani A, Sadigh G, Kassaian SE, et al. Sodium bicarbonate plus isotonic saline versus saline for prevention of contrast-induced nephropathy in patients undergoing coronary angiography: a randomized controlled trial. American Journal of Kidney Diseases. 2009;54(4):610-8. Not CKD treatment. [pmid: 19619921].
4537 Vaur L, Gueret P, Lievre M, et al. Development of congestive heart failure in type 2 diabetic patients with microalbuminuria or proteinuria: observations from the DIABHYCAR (type 2 DIABetes, Hypertension, CArdiovascular Events and Ramipril) study. [Erratum appears in Diabetes Care. 2003 Aug;26(8):2489]. Diabetes Care. 2003;26(3):855-60. Not relevant to key questions. [pmid: 12610049].
4538 Vecchio M, Navaneethan SD, Johnson DW, et al. Treatment options for sexual dysfunction in patients with chronic kidney disease: a systematic review of randomized controlled trials. Clinical Journal of The American Society of Nephrology: CJASN. Jun. 2010;5(6):985-95. Not CKD treatment. [pmid: 20498250].
4539 Vedder AC, Linthorst GE, Houge G, et al. Treatment of Fabry disease: outcome of a comparative trial with agalsidase alfa or beta at a dose of 0.2 mg/kg. PLoS ONE [Electronic Resource]. 2007;2(7):e598. Sample size less than 50 patients.
4540 Vedovato M, Lepore G, Coracina A, et al. Effect of sodium intake on blood pressure and albuminuria in Type 2 diabetic patients: the role of insulin resistance. Diabetologia. 2004;47(2):300-3. Not relevant to key questions. [pmid: 14704836].
4541 Veelken R, Delles C, Hilgers KF, et al. Outcome survey in unselected hypertensive patients with type 2 diabetes mellitus: effects of ACE inhibition. American Journal of Hypertension. 2001;14(7 Pt 1):672-8. Not RCT or controlled trial. [pmid: 11465652].
4542 Velussi M, Brocco E, Frigato F, et al. Effects of cilazapril and amlodipine on kidney function in hypertensive NIDDM patients. Diabetes. 1996;45(2):216-22. Sample size less than 50 patients. [pmid: 8549868].
4543 Venkateswaran RV, Charman SC, Goddard M, et al. Lethal mesenteric ischaemia after cardiopulmonary bypass: a common complication?. European Journal of Cardio-Thoracic Surgery. 2002;22(4):534-8. Not CKD treatment. [pmid: 12297168].
4544 Ventura P, Panini R, Verlato C, et al. Hyperhomocysteinemia and related factors in 600 hospitalized elderly subjects. Metabolism: Clinical & Experimental. 2001;50(12):1466-71. Not CKD treatment. [pmid: 11735095].
4545 Venugopal V, Laing CM, Ludman A, et al. Effect of remote ischemic preconditioning on acute kidney injury in nondiabetic patients undergoing coronary artery bypass graft surgery: a secondary analysis of 2 small randomized trials. American Journal of Kidney Diseases. Dec. 2010;56(6):1043-9. Not CKD treatment. [pmid: 20974511].
4546 Vercauteren SB, Bosmans JL, Elseviers MM, et al. A meta-analysis and morphological review of cyclosporine-induced nephrotoxicity in auto-immune diseases. Kidney International. 1998;54(2):536-45. Not CKD treatment. [pmid: 9690221].
4547 Verho M, Malerczyk V, Grotsch H, et al. Absence of crystalluria and estimation of renal parameters after oral and intravenous ofloxacin as compared to placebo in healthy volunteers. Drugs Under Experimental & Clinical Research. 1988;14(8):539-45. Sample size less than 50 patients. [pmid: 2907877].
4548 Verma A, Anavekar NS, Meris A, et al. The relationship between renal function and cardiac structure, function, and prognosis after myocardial infarction: the VALIANT Echo Study. Journal of the American College of Cardiology. 2007;50(13):1238-45. Follow-up less than 6 months. [pmid: 17888840].
4549 Verma A, Ranganna KM, Reddy RS, et al. Effect of rosuvastatin on C-reactive protein and renal function in patients with chronic kidney disease. American Journal of Cardiology. 2005;96(9):1290-2. Follow-up less than 6 months. [pmid: 16253600].
4550 Vessal G, Sagheb MM, Shilian S, et al. Effect of oral cromolyn sodium on CKD-associated pruritus and serum tryptase level: a double-blind placebo-controlled study. Nephrology Dialysis Transplantation. May. 2010;25(5):1541-7. Follow-up less than 6 months.
4551 Vestbo E, Damsgaard EM, Froland A, et al. Urinary albumin excretion in a population based cohort. Diabetic Medicine. 1995;12(6):488-93. Follow-up less than 6 months. [pmid: 7648821].
4552 Vexler AM, Mou X, Gabizon AA, et al. Reduction of the systemic toxicity of cisplatin by intra-arterial hepatic route administration for liver malignancies. International Journal of Cancer. 1995;60(5):611-5. Sample size less than 50 patients.
4553 Veyrat-Follet C, Vivier N, Trellu M, et al. The pharmacokinetics of idraparinux, a long-acting indirect factor Xa inhibitor: population pharmacokinetic analysis from Phase III clinical trials. Journal of Thrombosis & Haemostasis. 2009;7(4):559-65. Not CKD treatment. [pmid: 19187079].
4554 Vezyroglou G, Mitropoulos A, Antoniadis C. A metabolic syndrome in diffuse idiopathic skeletal hyperostosis. A controlled study. [Erratum appears in J Rheumatol 1997 Aug;24(8):1665]. Journal of Rheumatology. 1996;23(4):672-6. Not CKD treatment. [pmid: 8730125].
4555 Viallet NR, Blakley BW, Begleiter A, et al. Effect of sodium thiosulphate and cis-diamminedichloroplatinum on FADU tumour cells in nude mice. Journal of Otolaryngology. 2005;34(6):371-3. Not RCT or controlled trial. [pmid: 16343395].
4556 Viberti G. Regression of albuminuria: latest evidence for a new approach. Journal of Hypertension - Supplement. 2003;21(3):S24-8. Not RCT or controlled trial.
4557 Viberti G, Mogensen CE, Groop LC, et al. Effect of captopril on progression to clinical proteinuria in patients with insulin-dependent diabetes mellitus and microalbuminuria. European Microalbuminuria Captopril Study Group. JAMA. 1994;271(4):275-9. Not relevant to key questions. [pmid: 8295285].
4558 Viberti G, Slama G, Pozza G, et al. Early closure of European Pimagedine trial. Steering Committee. Safety Committee. Lancet. 1997;350(9072):214-5. Not RCT or controlled trial. [pmid: 9250200].
4559 Viberti G, Wheeldon NM, MicroAlbuminuria Reduction With VSI. Microalbuminuria reduction with valsartan in patients with type 2 diabetes mellitus: a blood pressure-independent effect. Circulation. 2002;106(6):672-8. Follow-up less than 6 months. [pmid: 12163426].
4560 Vidt DG. Clinical trials report. The effect of Ramipril versus Amlodipine on renal outcomes in hypertension nephrosclerosis. Current Hypertension Reports. 2001;3(5):379-80. Not RCT or controlled trial. [pmid: 11551370].
4561 Vidt DG, Cressman MD, Harris S, et al. Rosuvastatin-induced arrest in progression of renal disease. Cardiology. 2004;102(1):52-60. Not RCT or controlled trial. [pmid: 15073451].
4562 Vidt DG, Harris S, McTaggart F, et al. Effect of short-term rosuvastatin treatment on estimated glomerular filtration rate. American Journal of Cardiology. 2006;97(11):1602-6. Not relevant to key questions. [pmid: 16728222].
4563 Viele MK, Weiskopf RB, Fisher D. Recombinant human hemoglobin does not affect renal function in humans: analysis of safety and pharmacokinetics. Anesthesiology. 1997;86(4):848-58. Sample size less than 50 patients. [pmid: 9105229].
4564 Vigano G, Benigni A, Mendogni D, et al. Recombinant human erythropoietin to correct uremic bleeding. American Journal of Kidney Diseases. 1991;18(1):44-9. Sample size less than 50 patients. [pmid: 2063854].
4565 Vigano GL, Mannucci PM, Lattuada A, et al. Subcutaneous desmopressin (DDAVP) shortens the bleeding time in uremia. American Journal of Hematology. 1989;31(1):32-5. Not CKD treatment. [pmid: 2705441].
4566 Vigneau C, Ardiet C, Bret M, et al. Intermediate-dose (25mg/m2) IV melphalan for multiple myeloma with renal failure. Journal of Nephrology. 2002;15(6):684-9. Not CKD treatment. [pmid: 12495285].
4567 Vijan S, Stevens DL, Herman WH, et al. Screening, prevention, counseling, and treatment for the complications of type II diabetes mellitus. Putting evidence into practice. Journal of General Internal Medicine. 1997;12(9):567-80. Not RCT or controlled trial. [pmid: 9294791].
4568 Vijay SK, Mishra M, Kumar H, et al. Effect of pioglitazone and rosiglitazone on mediators of endothelial dysfunction, markers of angiogenesis and inflammatory cytokines in type-2 diabetes. Acta Diabetologica. 2009;46(1):27-33. Not CKD treatment. [pmid: 18758684].
4569 Vijayan A, Franklin SC, Behrend T, et al. Insulin-like growth factor I improves renal function in patients with end-stage chronic renal failure. American Journal of Physiology. 1999;276(4 Pt 2):R929-34. Follow-up less than 6 months. [pmid: 10198369].
4570 Vilarrasa N, Soler J, Montanya E. Regression of microalbuminuria in type 1 diabetic patients: results of a sequential intervention with improved metabolic control and ACE inhibitors. Acta Diabetologica. 2005;42(2):87-94. Follow-up less than 6 months. [pmid: 15944842].
4571 Vilayur E, Harris DCH. Emerging therapies for chronic kidney disease: what is their role?. Nature Reviews Nephrology. 2009;5(7):375-83. Not RCT or controlled trial.
4572 Vimalachandra D, Craig JC, Cowell CT, et al. Growth hormone treatment in children with chronic renal failure: a meta-analysis of randomized controlled trials. Journal of Pediatrics. 2001;139(4):560-7. Not adult population. [pmid: 11598604].
4573 Vincent JL. Evidence-based medicine in the ICU: important advances and limitations. Chest. 2004;126(2):592-600. Not relevant to key questions. [pmid: 15302748].
4574 Vincent JL. Do we need a dopaminergic agent in the management of the critically ill?. Journal of Autonomic Pharmacology. Suppl 1. 1990;10:s123-7. Not CKD treatment. [pmid: 1983006].
4575 Vincent JL, Biston P, Devriendt J, et al. Dopamine versus norepinephrine: is one better?. Minerva Anestesiologica. 2009;75(5):333-7. Not early CKD. [pmid: 19412154].
4576 Vinik AI, Bril V, Kempler P, et al. Treatment of symptomatic diabetic peripheral neuropathy with the protein kinase C beta-inhibitor ruboxistaurin mesylate during a 1-year, randomized, placebo-controlled, double-blind clinical trial. Clinical Therapeutics. 2005;27(8):1164-80. Not CKD treatment. [pmid: 16199243].
4577 Virani SA. Management of acute decompensated heart failure: renal implications. Blood Purification. 2008;26(1):18-22. Not CKD treatment. [pmid: 18182790].
4578 Virani SA, Khosla A, Levin A. Chronic kidney disease, heart failure and anemia. Canadian Journal of Cardiology. Suppl B. 2008;24:22B-4B. Not RCT or controlled trial.
4579 Virani SA, Khosla A, Levin A. Chronic kidney disease, heart failure and anemia. Canadian Journal of Cardiology. Suppl B. 2008;24:22B-4B. Not CKD treatment.
4580 Visser FW, Boonstra AH, Titia Lely A, et al. Renal response to angiotensin II is blunted in sodium-sensitive normotensive men. American Journal of Hypertension. 2008;21(3):323-8. Not RCT or controlled trial. [pmid: 18219299].
4581 Vita E, Schroeder DJ. Intralipid in prophylaxis of amphotericin B nephrotoxicity. Annals of Pharmacotherapy. 1994;28(10):1182-3. Not CKD treatment. [pmid: 7841575].
4582 Vivian EM, Rubinstein GB. Pharmacologic management of diabetic nephropathy. Clinical Therapeutics. 2002;24(11):1741-56. discussion 19. Not relevant to key questions. [pmid: 12501871].
4583 Vlachogiannakos J, Tang AK, Patch D, et al. Angiotensin converting enzyme inhibitors and angiotensin II antagonists as therapy in chronic liver disease. Gut. 2001;49(2):303-8. Not RCT or controlled trial. [pmid: 11454810].
4584 Vlagopoulos PT, Sarnak MJ. Traditional and nontraditional cardiovascular risk factors in chronic kidney disease. Medical Clinics of North America. 2005;89(3):587-611. Not RCT or controlled trial. [pmid: 15755469].
4585 Voelker JR, Cartwright-Brown D, Anderson S, et al. Comparison of loop diuretics in patients with chronic renal insufficiency. Kidney International. 1987;32(4):572-8. Not relevant to key questions. [pmid: 3430953].
4586 Vogt L, Chiurchiu C, Chadha-Boreham H, et al. Effect of the urotensin receptor antagonist palosuran in hypertensive patients with type 2 diabetic nephropathy. Hypertension. May. 2010;55(5):1206-9. Follow-up less than 6 months. [pmid: 20231521].
4587 Vogt L, de Zeeuw D, Woittiez AJJ, et al. Selective cyclooxygenase-2 (COX-2) inhibition reduces proteinuria in renal patients. Nephrology Dialysis Transplantation. 2009;24(4):1182-9. Not RCT or controlled trial.
4588 Vogt L, Kocks MJA, Laverman GD, et al. Renoprotection by blockade of the renin-angiotensin-aldosterone system in diabetic and non-diabetic chronic kidney disease. Specific involvement of intra-renal angiotensin-converting enzyme activity in therapy resistance?. Minerva Medica. 2004;95(5):395-409. Sample size less than 50 patients. [pmid: 15467515].
4589 Vogt L, Navis G, Koster J, et al. The angiotensin II receptor antagonist telmisartan reduces urinary albumin excretion in patients with isolated systolic hypertension: results of a randomized, double-blind, placebo-controlled trial. Journal of Hypertension. 2005;23(11):2055-61. Follow-up less than 6 months. [pmid: 16208149].
4590 Vogt L, Waanders F, Boomsma F, et al. Effects of dietary sodium and hydrochlorothiazide on the antiproteinuric efficacy of losartan. Journal of the American Society of Nephrology. 2008;19(5):999-1007. Not CKD treatment. [pmid: 18272844].
4591 von Baeyer H. Plasmapheresis in thrombotic microangiopathy-associated syndromes: review of outcome data derived from clinical trials and open studies. Therapeutic Apheresis. 2002;6(4):320-8. Not CKD treatment. [pmid: 12164804].
4592 Vonend O, Marsalek P, Russ H, et al. Moxonidine treatment of hypertensive patients with advanced renal failure. Journal of Hypertension. 2003;21(9):1709-17. Not early CKD. [pmid: 12923404].
4593 Vonesh EF, Greene T, Schluchter MD. Shared parameter models for the joint analysis of longitudinal data and event times. Statistics in Medicine. 2006;25(1):143-63. Not relevant to key questions. [pmid: 16025541].
4594 Vongterapak S, Dahlan W, Nakasatien S, et al. Impediment of the progressions of microalbuminuria and hyperlipidemia in normotensive type 2 diabetes by low-dose ramipril. Journal of the Medical Association of Thailand. 1998;81(9):671-81. Sample size less than 50 patients. [pmid: 9737124].
4595 Vora JP, Hendre TJ, Atiea J, et al. Renal haemodynamics during short-term angiotensin converting enzyme inhibition in normotensive normoalbuminuric insulin dependent diabetics. Diabetes Research. 1989;11(1):9-12. Sample size less than 50 patients. [pmid: 2695280].
4596 Vora JP, Leese GP, Peters JR, et al. Longitudinal evaluation of renal function in non-insulin-dependent diabetic patients with early nephropathy: effects of angiotensin-converting enzyme inhibition. Journal of Diabetes & its Complications. 1996;10(2):88-93. Not RCT or controlled trial. [pmid: 8777336].
4597 Vora JP, Owens DR, Ryder R, et al. Effect of somatostatin on renal function. British Medical Journal Clinical Research Ed. 1986;292(6537):1701-2. Sample size less than 50 patients. [pmid: 2873863].
4598 Vorobioff J, Picabea E, Gamen M, et al. Propranolol compared with propranolol plus isosorbide dinitrate in portal-hypertensive patients: long-term hemodynamic and renal effects. Hepatology. 1993;18(3):477-84. Sample size less than 50 patients. [pmid: 8359793].
4599 Voyaki SM, Staessen JA, Thijs L, et al. Follow-up of renal function in treated and untreated older patients with isolated systolic hypertension. Systolic Hypertension in Europe (Syst-Eur) Trial Investigators. Journal of Hypertension. 2001;19(3):511-9. Not early CKD. [pmid: 11288822].
4600 Vriesendorp R, Donker AJ, de Zeeuw D, et al. Antiproteinuric effect of naproxen and indomethacin. A double-blind crossover study. American Journal of Nephrology. 1985;5(4):236-42. Sample size less than 50 patients. [pmid: 3901756].
4601 Vuong AD, Annis LG. Ramipril for the prevention and treatment of cardiovascular disease. Annals of Pharmacotherapy. 2003;37(3):412-9. Not RCT or controlled trial. [pmid: 12639174].
4602 Vuurmans JLT, Boer P, Koomans HA. Effects of endothelin-1 and endothelin-1-receptor blockade on renal function in humans. Nephrology Dialysis Transplantation. 2004;19(11):2742-6. Not CKD treatment.
4603 Waanders F, Vaidya VS, van Goor H, et al. Effect of renin-angiotensin-aldosterone system inhibition, dietary sodium restriction, and/or diuretics on urinary kidney injury molecule 1 excretion in nondiabetic proteinuric kidney disease: a post hoc analysis of a randomized controlled trial. American Journal of Kidney Diseases. 2009;53(1):16-25. Not CKD treatment. [pmid: 18823687].
4604 Wada L, Don BR, Schambelan M. Hormonal mediators of amino acid-induced glomerular hyperfiltration in humans. American Journal of Physiology. 1991;260(6 Pt 2):F787-92. Not CKD treatment. [pmid: 1647685].
4605 Wade VL, Gleason BL. Dual blockade of the renin-angiotensin system in diabetic nephropathy. Annals of Pharmacotherapy. 2004;38(7-8):1278-82. Not CKD treatment. [pmid: 15187210].
4606 Waeber B, Burnier M, Nussberger J, et al. Experience with angiotensin II antagonists in hypertensive patients. Clinical & Experimental Pharmacology & Physiology - Supplement. 1996;3:S142-6. Not RCT or controlled trial. [pmid: 8993854].
4607 Waeber B, de la Sierra A, Ruilope LM. The ADVANCE trial: clarifying the role of perindopril/indapamide fixed-dose combination in the reduction of cardiovascular and renal events in patients with diabetes mellitus. American Journal of Cardiovascular Drugs. 2009;9(5):283-91. Not RCT or controlled trial. [pmid: 19791837].
4608 Wagner EA, Falciglia GA, Amlal H, et al. Short-term exposure to a high-protein diet differentially affects glomerular filtration rate but not Acid-base balance in older compared to younger adults. Journal of the American Dietetic Association. 2007;107(8):1404-8. Sample size less than 50 patients. [pmid: 17659909].
4609 Wagner F, Yeter R, Bisson S, et al. Beneficial hemodynamic and renal effects of intravenous enalaprilat following coronary artery bypass surgery complicated by left ventricular dysfunction. Critical Care Medicine. 2003;31(5):1421-8. Sample size less than 50 patients. [pmid: 12771613].
4610 Wahbah AM, el-Hefny MO, Wafa EM, et al. Perioperative renal protection in patients with obstructive jaundice using drug combinations. Hepato-Gastroenterology. 2000;47(36):1691-4. Sample size less than 50 patients. [pmid: 11149033].
4611 Wahbha MM, Wilson J, Hainsworth R. Cardiovascular responses to upright tilting in hypertensive patients, with and without renal impairment and before and following nisoldipine treatment. British Journal of Clinical Pharmacology. 1990;29(6):733-9. Not relevant to key questions. [pmid: 2136529].
4612 Wahlers T, Kotzerke B, Wagenbreth I, et al. Preventive treatment of renal impairment and graft rejection in cardiac transplantation using cyclosporine with an oral prostaglandin analog. Transplantation Proceedings. 1994;26(5):2743-4. Sample size less than 50 patients. [pmid: 7940861].
4613 Wake N, Hisashige A, Katayama T, et al. Cost-effectiveness of intensive insulin therapy for type 2 diabetes: a 10-year follow-up of the Kumamoto study. Diabetes Research & Clinical Practice. 2000;48(3):201-10. Not CKD treatment. [pmid: 10802159].
4614 Walker BJ, Evans PA, Forsling ML, et al. Somatostatin and water excretion in man: an intrarenal action. Clinical Endocrinology. 1985;23(2):169-74. Sample size less than 50 patients. [pmid: 2865021].
4615 Walker BR, Connacher AA, Webb DJ, et al. Glucocorticoids and blood pressure: a role for the cortisol/cortisone shuttle in the control of vascular tone in man. Clinical Science. 1992;83(2):171-8. Not CKD treatment. [pmid: 1327632].
4616 Walker PD, Brokering KL, Theobald JC. Fenoldopam and N-acetylcysteine for the prevention of radiographic contrast material-induced nephropathy: a review. Pharmacotherapy. 2003;23(12):1617-26. Sample size less than 50 patients. [pmid: 14695041].
4617 Walker RG, Strippoli GFM. A pegylated epoetin in anaemia of renal disease: non-inferiority for an unvalidated surrogate. Lancet. 2007;370(9596):1395-6. Follow-up less than 6 months. [pmid: 17950848].
4618 Walker SL, Fine A, Kryger MH. L-DOPA/carbidopa for nocturnal movement disorders in uremia. Sleep. 1996;19(3):214-8. Not CKD treatment. [pmid: 8723378].
4619 Walker WG, Neaton JD, Cutler JA, et al. Renal function change in hypertensive members of the Multiple Risk Factor Intervention Trial. Racial and treatment effects. The MRFIT Research Group. JAMA. 1992;268(21):3085-91. Not CKD treatment. [pmid: 1433739].
4620 Wall BM, Hardison RM, Molitch ME, et al. High prevalence and diversity of kidney dysfunction in patients with type 2 diabetes mellitus and coronary artery disease: the BARI 2D baseline data. American Journal of the Medical Sciences. May. 2010;339(5):401-10. Not RCT or controlled trial. [pmid: 20375690].
4621 Waller DG, Ramsay B, Fleming JS, et al. Longitudinal assessment of glomerular filtration rate by gamma camera and portable external detector. European Journal of Nuclear Medicine. 1987;13(8):402-3. Sample size less than 50 patients. [pmid: 3325291].
4622 Wallin JD, Frishman WH. Dilevalol: a selective beta-2 adrenergic agonist vasodilator with beta adrenergic blocking activity. Journal of Clinical Pharmacology. 1989;29(12):1057-68. Not relevant to key questions. [pmid: 2693499].
4623 Wallis PJ, Lodwick R, Sinha SK, et al. Effect of naproxen on renal haemodynamics in elderly patients with arthritis. Age & Ageing. 1989;18(1):26-30. Sample size less than 50 patients. [pmid: 2711919].
4624 Walrand S, Short KR, Bigelow ML, et al. Functional impact of high protein intake on healthy elderly people. American Journal of Physiology - Endocrinology & Metabolism. 2008;295(4):E921-8. Not CKD treatment. [pmid: 18697911].
4625 Walser M, Hill SB, Ward L, et al. A crossover comparison of progression of chronic renal failure: ketoacids versus amino acids. Kidney International. 1993;43(4):933-9. Follow-up less than 6 months. [pmid: 8479131].
4626 Walsh SR, Boyle JR, Tang TY, et al. Remote ischemic preconditioning for renal and cardiac protection during endovascular aneurysm repair: a randomized controlled trial. Journal of Endovascular Therapy: Official Journal of the International Society of Endovascular Specialists. 2009;16(6):680-9. Sample size less than 50 patients.
4627 Walsh TJ, Finberg RW, Arndt C, et al. Liposomal amphotericin B for empirical therapy in patients with persistent fever and neutropenia. National Institute of Allergy and Infectious Diseases Mycoses Study Group. New England Journal of Medicine. 1999;340(10):764-71. Not CKD treatment. [pmid: 10072411].
4628 Walters MR, Bolster A, Dyker AG, et al. Effect of perindopril on cerebral and renal perfusion in stroke patients with carotid disease. Stroke. 2001;32(2):473-8. Not CKD treatment. [pmid: 11157185].
4629 Wang A, Holcslaw T, Bashore TM, et al. Exacerbation of radiocontrast nephrotoxicity by endothelin receptor antagonism. Kidney International. 2000;57(4):1675-80. Not early CKD. [pmid: 10760103].
4630 Wang DJ, Dowling TC, Meadows D, et al. Nesiritide does not improve renal function in patients with chronic heart failure and worsening serum creatinine. Circulation. 2004;110(12):1620-5. Not CKD treatment. [pmid: 15337695].
4631 Wang F, Lu F, Xu L. Effects of Houttuynia cordata thumb on expression of BMP-7 and TGF-beta1 in the renal tissues of diabetic rats. Journal of Traditional Chinese Medicine. 2007;27(3):220-5. Not RCT or controlled trial. [pmid: 17955662].
4632 Wang G, Lai FMM, Lai KB, et al. Urinary messenger RNA expression of podocyte-associated molecules in patients with diabetic nephropathy treated by angiotensin-converting enzyme inhibitor and angiotensin receptor blocker. European Journal of Endocrinology. 2008;158(3):317-22. Not RCT or controlled trial. [pmid: 18299464].
4633 Wang H, Deng JL, Yue J, et al. Prostaglandin E1 for preventing the progression of diabetic kidney disease. Cochrane Database of Systematic Reviews. 2010;(5):CD006872. Not CKD treatment. [pmid: 20464745].
4634 Wang JG, Li Y, Franklin SS, et al. Prevention of stroke and myocardial infarction by amlodipine and Angiotensin receptor blockers: a quantitative overview. Hypertension. 2007;50(1):181-8. Not adult population. [pmid: 17502490].
4635 Wang PH, Lau J, Chalmers TC. Metaanalysis of the effects of intensive glycemic control on late complications of type I diabetes mellitus. Online Journal of Current Clinical Trials. 1993. Doc No 60:[5023 words; 37 paragraphs]. Not CKD treatment.
4636 Wang QL, Yuan JL, Tao YY, et al. Fuzheng Huayu recipe and vitamin E reverse renal interstitial fibrosis through counteracting TGF-beta1-induced epithelial-to-mesenchymal transition. Journal of Ethnopharmacology. Feb. 17. 2010;127(3):631-40. Not human studies. [pmid: 20015471].
4637 Wang SL, Head J, Stevens L, et al. Excess mortality and its relation to hypertension and proteinuria in diabetic patients. The world health organization multinational study of vascular disease in diabetes. Diabetes Care. 1996;19(4):305-12. Not RCT or controlled trial. [pmid: 8729151].
4638 Wang X, Lewis J, Appel L, et al. Validation of creatinine-based estimates of GFR when evaluating risk factors in longitudinal studies of kidney disease. Journal of the American Society of Nephrology. 2006;17(10):2900-9. Not relevant to key questions. [pmid: 16988064].
4639 Wang X, Xie Z. A clinical study on the effect of reinforcement of kidney on senile brain functions. Journal of Traditional Chinese Medicine. 1997;17(2):92-5. Not RCT or controlled trial. [pmid: 10437173].
4640 Wanner C. Prevention of cardiovascular disease in chronic kidney disease patients. Seminars in Nephrology. 2009;29(1):24-9. Not RCT or controlled trial. [pmid: 19121471].
4641 Ward RA, Buscaroli A, Schmidt B, et al. A comparison of dialysers with low-flux membranes: significant differences in spite of many similarities. Nephrology Dialysis Transplantation. 1997;12(5):965-72. Not CKD treatment.
4642 Wardle EN. Soyprotein diet therapy in renal disease. Nephron. 1998;78(3):328-31. Not RCT or controlled trial. [pmid: 9546695].
4643 Warrell RP Jr., Skelos A, Alcock NW, et al. Gallium nitrate for acute treatment of cancer-related hypercalcemia: clinicopharmacological and dose response analysis. Cancer Research. 1986;46(8):4208-12. Follow-up less than 6 months. [pmid: 3731088].
4644 Warren MM, Boyce WH, Evans JW, et al. A double-blind comparison of dezocine and morphine in patients with acute renal and ureteral colic. Journal of Urology. 1985;134(3):457-9. Not RCT or controlled trial. [pmid: 2863392].
4645 Warrington SJ, Lewis Y, Dawnay A, et al. Renal and gastrointestinal tolerability of lornoxicam, and effects on haemostasis and hepatic microsomal oxidation. Postgraduate Medical Journal. Suppl 4. 1990;66:S35-40. Not CKD treatment. [pmid: 2284219].
4646 Warrington SJ, Ravic M, Dawnay A. Renal and general tolerability of repeated doses of nimesulide in normal subjects. Drugs. Suppl 1. 1993;46:263-9. Sample size less than 50 patients. [pmid: 7506187].
4647 Waser M, Maggiorini M, Binswanger U, et al. Irreversibility of cyclosporine-induced renal function impairment in heart transplant recipients. Journal of Heart & Lung Transplantation. 1993;12(5):846-50. Sample size less than 50 patients. [pmid: 8241226].
4648 Waslen TA, McCauley FA, Wilson TW. Sulindac does not spare renal prostaglandins. Clinical & Investigative Medicine - Medecine Clinique et Experimentale. 1989;12(2):77-81. Sample size less than 50 patients. [pmid: 2650941].
4649 Watanabe G, Tomiyama H, Doba N. Effects of oral administration of L-arginine on renal function in patients with heart failure. Journal of Hypertension. 2000;18(2):229-34. Sample size less than 50 patients. [pmid: 10694193].
4650 Waters DD. Clinical insights from the Treating to New Targets trial. Progress in Cardiovascular Diseases. 2009;51(6):487-502. Not CKD treatment. [pmid: 19410683].
4651 Watson AJ, Gimenez LF, Cotton S, et al. Treatment of the anemia of chronic renal failure with subcutaneous recombinant human erythropoietin. American Journal of Medicine. 1990;89(4):432-5. Sample size less than 50 patients. [pmid: 2220877].
4652 Watson CJE, Gimson AES, Alexander GJ, et al. A randomized controlled trial of late conversion from calcineurin inhibitor (CNI)-based to sirolimus-based immunosuppression in liver transplant recipients with impaired renal function. Liver Transplantation. 2007;13(12):1694-702. Not RCT or controlled trial. [pmid: 18044728].
4653 Watson WA, Freer JP, Katz RS, et al. Kidney function during naproxen therapy in patients at risk for renal insufficiency. Seminars in Arthritis & Rheumatism. 1988;17(3 Suppl 2):12-6. Sample size less than 50 patients. [pmid: 3508327].
4654 Watson WJ. Screening for glycosuria during pregnancy. Southern Medical Journal. 1990;83(2):156-8. Not CKD treatment. [pmid: 2305295].
4655 Waugh NR, Robertson AM. Protein restriction for diabetic renal disease. Cochrane Database of Systematic Reviews. 2000;(2):CD002181. Not relevant to key questions. [pmid: 10796869].
4656 Weathers LW, Ziada KM. Drug-eluting stents in patients with end-stage renal disease. Minerva Cardioangiologica. 2008;56(1):117-25. Not early CKD. [pmid: 18432174].
4657 Webb JG, Pate GE, Humphries KH, et al. A randomized controlled trial of intravenous N-acetylcysteine for the prevention of contrast-induced nephropathy after cardiac catheterization: lack of effect. American Heart Journal. 2004;148(3):422-9. Not CKD treatment. [pmid: 15389228].
4658 Weber M. Clinical safety and tolerability of losartan. Clinical Therapeutics. 1997;19(4):604-16. discussion 3. Not relevant to key questions. [pmid: 9377606].
4659 Weber MA. Clinical implications of aldosterone blockade. American Heart Journal. 2002;144(5 Suppl):S12-8. Not relevant to key questions. [pmid: 12422136].
4660 Weber MA. New opportunities in cardiovascular patient management: a survey of clinical data on the combination of angiotensin-converting enzyme inhibitors and angiotensin receptor blockers. American Journal of Cardiology. 2007;100(3A):45J-52J. Follow-up less than 6 months. [pmid: 17599439].
4661 Weekers L, Bouhanick B, Hadjadj S, et al. Modulation of the renal response to ACE inhibition by ACE insertion/deletion polymorphism during hyperglycemia in normotensive, normoalbuminuric type 1 diabetic patients. Diabetes. 2005;54(10):2961-7. Not CKD treatment. [pmid: 16186399].
4662 Weidmann P. Metabolic profile of indapamide sustained-release in patients with hypertension: data from three randomised double-blind studies. Drug Safety. 2001;24(15):1155-65. Not RCT or controlled trial. [pmid: 11772148].
4663 Weidmann P, Gnadinger MP, Schohn D, et al. Antihypertensive and hypouricaemic effects of nitrendipine in chronic renal failure. European Journal of Clinical Pharmacology. 1989;36(3):223-7. Sample size less than 50 patients. [pmid: 2744062].
4664 Weidmann P, Schohn D, Gnadinger MP, et al. Hypertensive dysregulation and its modification by calcium channel blockade in nonoliguric renal failure. American Journal of Nephrology. 1989;9(4):269-78. Sample size less than 50 patients. [pmid: 2683789].
4665 Weinberg JM, Appel LJ, Bakris G, et al. Risk of hyperkalemia in nondiabetic patients with chronic kidney disease receiving antihypertensive therapy. Archives of Internal Medicine. 2009;169(17):1587-94. Not CKD treatment. [pmid: 19786678].
4666 Weinblatt ME, Germain BF, Kremer JM, et al. Lack of a renal-protective effect of misoprostol in rheumatoid arthritis patients receiving cyclosporin A. Results of a randomized, placebo-controlled trial. Arthritis & Rheumatism. 1994;37(9):1321-5. Not CKD treatment. [pmid: 7945495].
4667 Weiner DE, Rifkin DE. Kidney function and the risk of cardiovascular disease. BMJ. 2009;338:b1307. Not RCT or controlled trial. [pmid: 19564177].
4668 Weiner DE, Sarnak MJ. Managing dyslipidemia in chronic kidney disease. Journal of General Internal Medicine. 2004;19(10):1045-52. Not RCT or controlled trial. [pmid: 15482558].
4669 Weinhandl H, Pachler C, Mader JK, et al. Physiological hyperinsulinemia has no detectable effect on access of macromolecules to insulin-sensitive tissues in healthy humans. Diabetes. 2007;56(9):2213-7. Not RCT or controlled trial. [pmid: 17601990].
4670 Weinrauch LA, Burger AJ, Aepfelbacher F, et al. A pilot study to test the effect of pulsatile insulin infusion on cardiovascular mechanisms that might contribute to attenuation of renal compromise in type 1 diabetes mellitus patients with proteinuria. Metabolism: Clinical & Experimental. 2007;56(11):1453-7. Follow-up less than 6 months. [pmid: 17950093].
4671 Weinrauch LA, Kennedy FJ, Burger A, et al. Prospective evaluation of autonomic dysfunction in aggressive management of diabetic microangiopathy. American Journal of Hypertension. 1999;12(11 Pt 1):1135-9. Sample size less than 50 patients. [pmid: 10604492].
4672 Weinrauch LA, Sun J, Gleason RE, et al. Pulsatile intermittent intravenous insulin therapy for attenuation of retinopathy and nephropathy in type 1 diabetes mellitus. Metabolism: Clinical & Experimental. Oct. 2010;59(10):1429-34. Not relevant to key questions. [pmid: 20189608].
4673 Weinstein JM, Heyman S, Brezis M. Potential deleterious effect of furosemide in radiocontrast nephropathy. Nephron. 1992;62(4):413-5. Sample size less than 50 patients. [pmid: 1300436].
4674 Weir MR. The role of combination antihypertensive therapy in the prevention and treatment of chronic kidney disease. American Journal of Hypertension. 2005;18(4 Pt 2):100S-5S. Sample size less than 50 patients. [pmid: 15837552].
4675 Weir MR. Effects of renin-angiotensin system inhibition on end-organ protection: can we do better?. Clinical Therapeutics. 2007;29(9):1803-24. Not relevant to key questions. [pmid: 18035185].
4676 Weir MR. The renoprotective effects of RAS inhibition: focus on prevention and treatment of chronic kidney disease. Postgraduate Medicine. 2009;121(1):96-103. Not CKD treatment. [pmid: 19179817].
4677 Weir MR, Dengel DR, Behrens MT, et al. Salt-induced increases in systolic blood pressure affect renal hemodynamics and proteinuria. Hypertension. 1995;25(6):1339-44. Sample size less than 50 patients. [pmid: 7768584].
4678 Weir MR, Hollenberg NK, Zappe DH, et al. Antihypertensive effects of double the maximum dose of valsartan in African-American patients with type 2 diabetes mellitus and albuminuria. Journal of Hypertension. 2010;28(1):186-93. Not CKD treatment. [pmid: 19809363].
4679 Weir MR, Klassen DK, Hall PS, et al. Minimization of indomethacin-induced reduction in renal function by misoprostol. Journal of Clinical Pharmacology. 1991;31(8):729-35. Sample size less than 50 patients. [pmid: 1908864].
4680 Weisberg LS, Kurnik PB, Kurnik BR. Dopamine and renal blood flow in radiocontrast-induced nephropathy in humans. Renal Failure. 1993;15(1):61-8. Not CKD treatment. [pmid: 8441838].
4681 Weisberg LS, Kurnik PB, Kurnik BR. Risk of radiocontrast nephropathy in patients with and without diabetes mellitus. Kidney International. 1994;45(1):259-65. Not CKD treatment. [pmid: 8127017].
4682 Weisbord SD, Bruns FJ, Saul MI, et al. Provider use of preventive strategies for radiocontrast nephropathy in high-risk patients. Nephron. 2004;96(2):c56-62. Not relevant to key questions. [pmid: 14988599].
4683 Weisbord SD, Palevsky PM. Radiocontrast-induced acute renal failure. Journal of Intensive Care Medicine. 2005;20(2):63-75. Not RCT or controlled trial. [pmid: 15855219].
4684 Weiss JW, Johnson ES, Petrik A, et al. Systolic blood pressure and mortality among older community-dwelling adults with CKD. American Journal of Kidney Diseases. Dec. 2010;56(6):1062-71. Not CKD treatment. [pmid: 20961677].
4685 Weiss MF, Rodby RA, Justice AC, et al. Free pentosidine and neopterin as markers of progression rate in diabetic nephropathy. Collaborative Study Group. Kidney International. 1998;54(1):193-202. Not RCT or controlled trial. [pmid: 9648079].
4686 Welch M, Newstead CG, Smyth JV, et al. Evaluation of dopexamine hydrochloride as a renoprotective agent during aortic surgery. Annals of Vascular Surgery. 1995;9(5):488-92. Not CKD treatment. [pmid: 8541200].
4687 Wellenius GA, Mukamal KJ, Winkelmayer WC, et al. Renal dysfunction increases the risk of saphenous vein graft occlusion: results from the Post-CABG trial. Atherosclerosis. 2007;193(2):414-20. Not early CKD. [pmid: 16905139].
4688 Wellington K, Goa KL. Zoledronic acid: a review of its use in the management of bone metastases and hypercalcaemia of malignancy. Drugs. 2003;63(4):417-37. Not CKD treatment. [pmid: 12558465].
4689 Welz S, Hehr T, Kollmannsberger C, et al. Renal toxicity of adjuvant chemoradiotherapy with cisplatin in gastric cancer. International Journal of Radiation Oncology, Biology, Physics. 2007;69(5):1429-35. Not RCT or controlled trial.
4690 Wenger NK. Lipid metabolism, physical activity, and postmenopausal hormone therapy. American Journal of Kidney Diseases. 1998;32(5 Suppl 3):S80-8. Not RCT or controlled trial. [pmid: 9820467].
4691 Wennberg A, Hyltander A, Sjoberg A, et al. Prevalence of carnitine depletion in critically ill patients with undernutrition. Metabolism: Clinical & Experimental. 1992;41(2):165-71. Not CKD treatment. [pmid: 1736038].
4692 Wenzel RR. Renal protection in hypertensive patients: selection of antihypertensive therapy. Drugs. Suppl 2. 2005;65:29-39. Not RCT or controlled trial. [pmid: 16398060].
4693 Wenzel RR, Littke T, Kuranoff S, et al. Avosentan reduces albumin excretion in diabetics with macroalbuminuria. Journal of the American Society of Nephrology. 2009;20(3):655-64. Follow-up less than 6 months. [pmid: 19144760].
4694 West SL, Swan VJD, Jamal SA. Effects of calcium on cardiovascular events in patients with kidney disease and in a healthy population. Clinical Journal of The American Society of Nephrology: CJASN. Jan. Suppl 1. 2010;5:S41-7. Not RCT or controlled trial. [pmid: 20089502].
4695 Westberg G, Tarkowski A. Effect of MaxEPA in patients with SLE. A double-blind, crossover study. Scandinavian Journal of Rheumatology. 1990;19(2):137-43. Not CKD treatment. [pmid: 2186476].
4696 Westermann D, Savvatis K, Schultheiss HP, et al. Rational of the use of aliskiren in hypertension and beyond. Minerva Cardioangiologica. Dec. 2009;57(6):761-72. Not RCT or controlled trial. [pmid: 20019651].
4697 Westhuyzen J, Endre ZH, Reece G, et al. Measurement of tubular enzymuria facilitates early detection of acute renal impairment in the intensive care unit. Nephrology Dialysis Transplantation. 2003;18(3):543-51. Not CKD treatment.
4698 Wetzels JF, van Bergeijk JD, Hoitsma AJ, et al. Triamterene increases lithium excretion in healthy subjects: evidence for lithium transport in the cortical collecting tubule. Nephrology Dialysis Transplantation. 1989;4(11):939-42. Not CKD treatment.
4699 Wetzels JFM. Letter by Wetzels regarding article, “Renal Insufficiency Following Contrast Media Administration Trial (REMEDIAL): a randomized comparison of 3 preventive strategies”. Circulation. 2007;116(8):e310. author reply e1. Sample size less than 50 patients. [pmid: 17709647].
4700 Wetzels JFM, Kiemeney LALM, Swinkels DW, et al. Age- and gender-specific reference values of estimated GFR in Caucasians: the Nijmegen Biomedical Study. Kidney International. 2007;72(5):632-7. Not relevant to key questions. [pmid: 17568781].
4701 Wexler D, Silverberg D, Blum M, et al. Anaemia as a contributor to morbidity and mortality in congestive heart failure. Nephrology Dialysis Transplantation. Suppl 7. 2005;20:vii11-5. Not RCT or controlled trial.
4702 Wheeler ML, Fineberg SE, Fineberg NS, et al. Animal versus plant protein meals in individuals with type 2 diabetes and microalbuminuria: effects on renal, glycemic, and lipid parameters. Diabetes Care. 2002;25(8):1277-82. Sample size less than 50 patients. [pmid: 12145221].
4703 Whelton A, Fort JG, Puma JA, et al. Cyclooxygenase-2--specific inhibitors and cardiorenal function: a randomized, controlled trial of celecoxib and rofecoxib in older hypertensive osteoarthritis patients. [Erratum appears in Am J Ther 2001 May-Jun;8(3):220]. American Journal of Therapeutics. 2001;8(2):85-95. Not early CKD. [pmid: 11304662].
4704 Whelton A, Lefkowith JL, West CR, et al. Cardiorenal effects of celecoxib as compared with the nonsteroidal anti-inflammatory drugs diclofenac and ibuprofen. Kidney International. 2006;70(8):1495-502. Not RCT or controlled trial. [pmid: 16941030].
4705 Whelton A, Maurath CJ, Verburg KM, et al. Renal safety and tolerability of celecoxib, a novel cyclooxygenase-2 inhibitor. American Journal of Therapeutics. 2000;7(3):159-75. Not CKD treatment. [pmid: 11317165].
4706 Whelton A, Schulman G, Wallemark C, et al. Effects of celecoxib and naproxen on renal function in the elderly. Archives of Internal Medicine. 2000;160(10):1465-70. Not early CKD. [pmid: 10826459].
4707 Whelton A, Stout RL, Spilman PS, et al. Renal effects of ibuprofen, piroxicam, and sulindac in patients with asymptomatic renal failure. A prospective, randomized, crossover comparison. Annals of Internal Medicine. 1990;112(8):568-76. Sample size less than 50 patients. [pmid: 2183665].
4708 Whelton PK, Klag MJ. Hypertension as a risk factor for renal disease. Review of clinical and epidemiological evidence. Hypertension. 1989;13(5 Suppl):I19-27. Not relevant to key questions. [pmid: 2490824].
4709 Whelton PK, Lee JY, Kusek JW, et al. Recruitment experience in the African American Study of Kidney Disease and Hypertension (AASK) Pilot Study. Controlled Clinical Trials. 1996;17(4 Suppl):17S-33S. Not RCT or controlled trial. [pmid: 8889351].
4710 Whitcup SM, Salvo EC Jr., Nussenblatt RB. Combined cyclosporine and corticosteroid therapy for sight-threatening uveitis in Behcet's disease. American Journal of Ophthalmology. 1994;118(1):39-45. Not CKD treatment. [pmid: 8023874].
4711 White CM. Pharmacologic, pharmacokinetic, and therapeutic differences among ACE inhibitors. Pharmacotherapy. 1998;18(3):588-99. Not RCT or controlled trial. [pmid: 9620109].
4712 White CT, Macpherson CF, Hurley RM, et al. Antiproteinuric effects of enalapril and losartan: a pilot study. Pediatric Nephrology. 2003;18(10):1038-43. Sample size less than 50 patients. [pmid: 12920631].
4713 White HD, Gallo R, Cohen M, et al. The use of intravenous enoxaparin in elective percutaneous coronary intervention in patients with renal impairment: results from the SafeTy and Efficacy of Enoxaparin in PCI patients, an internationaL randomized Evaluation (STEEPLE) trial. American Heart Journal. 2009;157(1):125-31. Not CKD treatment. [pmid: 19081408].
4714 White IR, Royston P. Imputing missing covariate values for the Cox model. Statistics in Medicine. 2009;28(15):1982-98. Not RCT or controlled trial. [pmid: 19452569].
4715 White KE, Bilous RW, Marshall SM, et al. Podocyte number in normotensive type 1 diabetic patients with albuminuria. Diabetes. 2002;51(10):3083-9. Not CKD treatment. [pmid: 12351451].
4716 White KE, Pinel N, Cordonnier DJ, et al. Does ACE inhibition slow progression of glomerulopathy in patients with Type 2 diabetes mellitus?. Diabetic Medicine. 2001;18(11):933-6. Sample size less than 50 patients. [pmid: 11703440].
4717 White SL, Polkinghorne KR, Atkins RC, et al. Comparison of the prevalence and mortality risk of CKD in Australia using the CKD Epidemiology Collaboration (CKD-EPI) and Modification of Diet in Renal Disease (MDRD) Study GFR estimating equations: the AusDiab (Australian Diabetes, Obesity and Lifestyle) Study. American Journal of Kidney Diseases. Apr. 2010;55(4):660-70. Not relevant to key questions. [pmid: 20138414].
4718 White WB, Halley SE. Comparative renal effects of intravenous administration of fenoldopam mesylate and sodium nitroprusside in patients with severe hypertension. Archives of Internal Medicine. 1989;149(4):870-4. Sample size less than 50 patients. [pmid: 2565105].
4719 Whitworth JA, Gordon D, Harpley R, et al. Acute hormonal and renal effects of oral dilevalol in normal men. Clinical & Experimental Pharmacology & Physiology. 1989;16(1):59-63. Not CKD treatment. [pmid: 2523264].
4720 Whitworth JA, Ihle BU, Becker GJ, et al. Preservation of renal function in chronic renal failure. Tohoku Journal of Experimental Medicine. 1992;166(1):165-83. Not RCT or controlled trial. [pmid: 1412442].
4721 Whitworth JA, Williamson PM, Brown MA, et al. Haemodynamic and metabolic effects of carbenoxolone in normal subjects and patients with renal impairment. Clinical & Experimental Hypertension. 1994;16(4):431-50. Sample size less than 50 patients. [pmid: 7920454].
4722 Wiecek A. Anemia: To TREAT or not to TREAT--that is the question. Nature Reviews Nephrology. May. 2010;6(5):254-5. Not RCT or controlled trial.
4723 Wiecek A, Covic A, Locatelli F, et al. Renal anemia: comparing current Eastern and Western European management practice (ORAMA). Renal Failure. 2008;30(3):267-76. Sample size less than 50 patients. [pmid: 18350446].
4724 Wiecek A, Fliser D, Nowicki M, et al. Effect of moxonidine on urinary electrolyte excretion and renal haemodynamics in man. European Journal of Clinical Pharmacology. 1995;48(3-4):203-8. Follow-up less than 6 months. [pmid: 7589042].
4725 Wiedermann CJ. Hydroxyethyl starch--can the safety problems be ignored?. Wiener Klinische Wochenschrift. 2004;116(17-18):583-94. Not relevant to key questions. [pmid: 15515874].
4726 Wiegmann TB, Herron KG, Chonko AM, et al. Effect of angiotensin-converting enzyme inhibition on renal function and albuminuria in normotensive type I diabetic patients. Diabetes. 1992;41(1):62-7. Sample size less than 50 patients. [pmid: 1727741].
4727 Wiersbitzky M, Landgraf R, Gruska S, et al. Hormonal and renal responses to arterial chemoreceptor stimulation by almitrine in healthy and normotensive men. Biomedica Biochimica Acta. 1990;49(11):1155-63. Not CKD treatment. [pmid: 2094221].
4728 Wijeysundera DN, Beattie WS, Djaiani G, et al. Off-pump coronary artery surgery for reducing mortality and morbidity: meta-analysis of randomized and observational studies. Journal of the American College of Cardiology. 2005;46(5):872-82. Not RCT or controlled trial. [pmid: 16139139].
4729 Wijeysundera DN, Beattie WS, Rao V, et al. N-acetylcysteine for preventing acute kidney injury in cardiac surgery patients with pre-existing moderate renal insufficiency. Canadian Journal of Anaesthesia. 2007;54(11):872-81. Follow-up less than 6 months. [pmid: 17975231].
4730 Wijnen MHWA, Vader HL, Van Den Wall Bake AWL, et al. Can renal dysfunction after infra-renal aortic aneurysm repair be modified by multi-antioxidant supplementation?. Journal of Cardiovascular Surgery. 2002;43(4):483-8. Not CKD treatment. [pmid: 12124559].
4731 Wiland P, Szechcinski J. Proximal tubule damage in patients treated with gentamicin or amikacin. Polish Journal of Pharmacology. 2003;55(4):631-7. Follow-up less than 6 months. [pmid: 14581723].
4732 Wiland P, Szechinski J. N-acetyl-beta-D-glucosaminidase urinary excretion as an early indicator of kidney damage in rheumatoid arthritis patients starting on parenteral gold and Depo-Medrone/placebo injections. Clinical Rheumatology. 1999;18(2):106-13. Not CKD treatment. [pmid: 10357114].
4733 Wilkins MR, Lewis HM, West MJ, et al. Captopril reduces the renal response to intravenous atrial natriuretic peptide in normotensives. Journal of Human Hypertension. 1987;1(1):47-51. Sample size less than 50 patients. [pmid: 2977404].
4734 Willemsen JM, Rabelink TJ, Boer P, et al. Disparate systemic and renal blocking properties of angiotensin II antagonists during exogenous angiotensin II administration: implications for treatment. Journal of Human Hypertension. 2004;18(12):857-63. Follow-up less than 6 months. [pmid: 15361886].
4735 William J, Saad N, Salib M, et al. The acute effect of intravenously administered recombinant human erythropoietin on the immune response of uremic patients maintained on regular hemodialysis. Artificial Organs. 1998;22(3):192-6. Sample size less than 50 patients. [pmid: 9527278].
4736 Williams AF, Manias E, Walker RG. The devil is in the detail - a multifactorial intervention to reduce blood pressure in co-existing diabetes and chronic kidney disease: a single blind, randomized controlled trial. BMC Family Practice. 2010;11:3. Not RCT or controlled trial. [pmid: 20064272].
4737 Williams CD, Linch DC. Interferon alfa-2a. British Journal of Hospital Medicine. 1997;57(9):436-9. Not CKD treatment. [pmid: 9274677].
4738 Williams GH, Burgess E, Kolloch RE, et al. Efficacy of eplerenone versus enalapril as monotherapy in systemic hypertension. American Journal of Cardiology. 2004;93(8):990-6. Not CKD treatment. [pmid: 15081441].
4739 Williams ME, Bolton WK, Khalifah RG, et al. Effects of pyridoxamine in combined phase 2 studies of patients with type 1 and type 2 diabetes and overt nephropathy. American Journal of Nephrology. 2007;27(6):605-14. Not human studies. [pmid: 17823506].
4740 Williams R. Intensive insulin treatment after acute myocardial infarction in diabetes mellitus Evidence exists from study of non-insulin dependent diabetes in Japan. BMJ. 1997;315(7107):544. Not RCT or controlled trial. [pmid: 9329313].
4741 Williams RM, Yuen K, White D, et al. Short-term suppression of elevated growth hormone concentrations following insulin-like growth factor 1 administration in young adults with type 1 diabetes does not alter glomerular filtration or albumin excretion rates. Clinical Endocrinology. 2006;65(4):439-45. Not RCT or controlled trial. [pmid: 16984235].
4742 Willox JC, McAllister EJ, Sangster G, et al. Effects of magnesium supplementation in testicular cancer patients receiving cis-platin: a randomised trial. British Journal of Cancer. 1986;54(1):19-23. Not CKD treatment. [pmid: 3524645].
4743 Wilmer WA, Hebert LA, Lewis EJ, et al. Remission of nephrotic syndrome in type 1 diabetes: long-term follow-up of patients in the Captopril Study. American Journal of Kidney Diseases. 1999;34(2):308-14. Sample size less than 50 patients. [pmid: 10430979].
4744 Wilmer WA, Rovin BH, Hebert CJ, et al. Management of glomerular proteinuria: a commentary. Journal of the American Society of Nephrology. 2003;14(12):3217-32. Follow-up less than 6 months. [pmid: 14638920].
4745 Wilson DM, Bergert JH, Larson TS, et al. GFR determined by nonradiolabeled iothalamate using capillary electrophoresis. American Journal of Kidney Diseases. 1997;30(5):646-52. Not RCT or controlled trial. [pmid: 9370179].
4746 Wilson J, Orchard MA, Spencer AA, et al. Anti-hypertensive drugs non-specifically reduce “spontaneous” activation of blood platelets. Thrombosis & Haemostasis. 1989;62(2):776-80. Sample size less than 50 patients. [pmid: 2535678].
4747 Wilson J, Wahbha MM, Martin PG, et al. The effect of nisoldipine on renal function in the long-term treatment of hypertension in patients with and without renal impairment. European Journal of Clinical Pharmacology. 1989;37(5):437-41. Not relevant to key questions. [pmid: 2689184].
4748 Wilson R, Godwin M, Seguin R, et al. End-stage renal disease: factors affecting referral decisions by family physicians in Canada, the United States, and Britain. American Journal of Kidney Diseases. 2001;38(1):42-8. Not early CKD. [pmid: 11431180].
4749 Wilson RA, Norman DJ, Barry JM, et al. Noninvasive cardiac testing in the end-stage renal disease patient. Blood Purification. 1994;12(1):78-83. Not RCT or controlled trial. [pmid: 7986481].
4750 Wilson TW. The antihypertensive action of hydrochlorothiazide and renal prostacyclin. Clinical Pharmacology & Therapeutics. 1986;39(1):94-101. Sample size less than 50 patients. [pmid: 3510798].
4751 Wimmer A, Stanek B, Kubecova L, et al. Effects of prostaglandin E1, dobutamine and placebo on hemodynamic, renal and neurohumoral variables in patients with advanced heart failure. Japanese Heart Journal. 1999;40(3):321-34. Sample size less than 50 patients. [pmid: 10506854].
4752 Wing AJ. The social responsibility of physicians as agents of public health services. Renal Failure. 1996;18(3):425-31. Not RCT or controlled trial. [pmid: 8827988].
4753 Winkelmayer WC, Glynn RJ, Levin R, et al. Hydroxyethyl starch and change in renal function in patients undergoing coronary artery bypass graft surgery. Kidney International. 2003;64(3):1046-9. Not CKD treatment. [pmid: 12911555].
4754 Winkelmayer WC, Zhang Z, Shahinfar S, et al. Efficacy and safety of angiotensin II receptor blockade in elderly patients with diabetes. Diabetes Care. 2006;29(10):2210-7. Not CKD treatment. [pmid: 17003295].
4755 Winkle RA, Smith NA, Ruder MA, et al. Pharmacodynamics of enoximone during intravenous infusion. International Journal of Cardiology. Suppl 1. 1990;28:S1-2. Not CKD treatment. [pmid: 2145232].
4756 Wintermeyer SM, Nahata MC. Rimantadine: a clinical perspective. Annals of Pharmacotherapy. 1995;29(3):299-310. Not RCT or controlled trial. [pmid: 7606077].
4757 Wirta OR, Pasternack AI, Mustonen JT, et al. Urinary albumin excretion rate and its determinants after 6 years in non-insulin-dependent diabetic patients. Nephrology Dialysis Transplantation. 1996;11(3):449-56. Not RCT or controlled trial.
4758 Wirta OR, Pasternack AI, Mustonen JT, et al. Urinary albumin excretion rate is independently related to autonomic neuropathy in type 2 diabetes mellitus. Journal of Internal Medicine. 1999;245(4):329-35. Not RCT or controlled trial. [pmid: 10356594].
4759 Wiseman MJ, Saunders AJ, Keen H, et al. Effect of blood glucose control on increased glomerular filtration rate and kidney size in insulin-dependent diabetes. New England Journal of Medicine. 1985;312(10):617-21. Sample size less than 50 patients. [pmid: 3883162].
4760 Witasp A, Nordfors L, Lindholm B, et al. Use of single-nucleotide polymorphisms in the search for genetic modifiers of the uremic phenotype. Journal of Renal Nutrition. 2007;17(1):17-22. Sample size less than 50 patients. [pmid: 17198927].
4761 Witteles RM, Kao D, Christopherson D, et al. Impact of nesiritide on renal function in patients with acute decompensated heart failure and pre-existing renal dysfunction a randomized, double-blind, placebo-controlled clinical trial. Journal of the American College of Cardiology. 2007;50(19):1835-40. Not CKD treatment. [pmid: 17980248].
4762 Wittenberg C, Erman A, Shohat J, et al. Concomitant administration of isradipine and spirapril prevents reduction of renal function induced by acute administration of spirapril in patients with reduced renal function. Blood Pressure Supplement. 1994;1:48-9. Not CKD treatment. [pmid: 8205299].
4763 Wittenberg C, Rosenfeld JB. Acute antihypertensive and renal effects of isradipine in hypertensive patients with normal and reduced renal function. American Journal of Hypertension. 1991;4(2 Pt 2):191S-3S. Sample size less than 50 patients. [pmid: 1827019].
4764 Witting M, Kuo D. Screening with blood urea nitrogen before intravenous contrast. American Journal of Emergency Medicine. 2003;21(6):494-6. Not CKD treatment. [pmid: 14574660].
4765 Wittstock A, Burkert M, Zidek W, et al. N-acetylcysteine improves arterial vascular reactivity in patients with chronic kidney disease. Nephron. 2009;112(3):c184-9. Not early CKD. [pmid: 19439989].
4766 Woittiez AJ, Huysmans FT, Bailey R, et al. A comparison of the safety and efficacy of mibefradil and nifedipine SR in patients with renal disease and hypertension. Clinical Nephrology. 1998;49(3):160-6. Follow-up less than 6 months. [pmid: 9543597].
4767 Wolf DL, Jungbluth GL, Metzler CM, et al. Acute effects of increasing doses of nicorandil on renal function in man. International Journal of Clinical Pharmacology & Therapeutics. 1994;32(5):246-53. Sample size less than 50 patients. [pmid: 7921519].
4768 Wolf DL, Rodriguez CA, Mucci M, et al. Pharmacokinetics and renal effects of cidofovir with a reduced dose of probenecid in HIV-infected patients with cytomegalovirus retinitis. Journal of Clinical Pharmacology. 2003;43(1):43-51. Not CKD treatment. [pmid: 12520627].
4769 Wolf G. Zenon's paradox or how much to lower blood pressure for optimal renoprotection. Nephrology Dialysis Transplantation. 2005;20(11):2304-7. Not CKD treatment.
4770 Wolfe RA. The United States Renal Data System: a source of national norms for ESRD patient outcome and process of care. Advances in Renal Replacement Therapy. 1995;2(2):95-100. Not RCT or controlled trial. [pmid: 7614354].
4771 Woll PJ, Pettengell R. Interferons in oncology. [Erratum appears in Br J Clin Pract 1997 Apr-May;51(3):146]. British Journal of Clinical Practice. 1997;51(2):111-5. Not RCT or controlled trial. [pmid: 9158255].
4772 Wolpert C, Schimpf R, Giustetto C, et al. Further insights into the effect of quinidine in short QT syndrome caused by a mutation in HERG. Journal of Cardiovascular Electrophysiology. 2005;16(1):54-8. Not relevant to key questions. [pmid: 15673388].
4773 Wong F, Massie D, Hsu P, et al. The dose-dependent effect of misoprostol on indomethacin-induced renal dysfunction in well compensated cirrhosis. American Journal of Gastroenterology. 1995;90(9):1465-70. Sample size less than 50 patients. [pmid: 7661171].
4774 Wong JA, Goodman SG, Yan RT, et al. Temporal management patterns and outcomes of non-ST elevation acute coronary syndromes in patients with kidney dysfunction. European Heart Journal. 2009;30(5):549-57. Not CKD treatment. [pmid: 19201761].
4775 Wong SL, Awni WM, Cavanaugh JH, et al. The pharmacokinetics of single oral doses of zileuton 200 to 800mg, its enantiomers, and its metabolites, in normal healthy volunteers. Clinical Pharmacokinetics. Suppl 2. 1995;29:9-21. Sample size less than 50 patients. [pmid: 8620676].
4776 Wong T, Foote EF, Lefavour GS, et al. Physician knowledge and practice patterns relating to diabetic nephropathy. Journal of the American Pharmaceutical Association. 1999;39(6):785-90. Not RCT or controlled trial. [pmid: 10609443].
4777 Woo EBC, Tang ATM, el-Gamel A, et al. Dopamine therapy for patients at risk of renal dysfunction following cardiac surgery: science or fiction?. European Journal of Cardio-Thoracic Surgery. 2002;22(1):106-11. Not CKD treatment. [pmid: 12103382].
4778 Woo KT, Lau YK, Chan CM, et al. ATRA therapy restores normal renal function and renal reserve and prevents renal failure. Annals of the Academy of Medicine, Singapore. 2005;34(1):52-9. Not RCT or controlled trial.
4779 Woo KT, Lau YK, Wong KS, et al. ACE inhibitor use and the long-term risk of renal failure in diabetics. Kidney International. 2006;70(7):1376-7. author reply 8. Not RCT or controlled trial. [pmid: 16988741].
4780 Wood PJ, Ioannides-Demos LL, Li SC, et al. Minimisation of aminoglycoside toxicity in patients with cystic fibrosis. Thorax. 1996;51(4):369-73. Not CKD treatment. [pmid: 8733487].
4781 Woodman RJ, Mori TA, Burke V, et al. Docosahexaenoic acid but not eicosapentaenoic acid increases LDL particle size in treated hypertensive type 2 diabetic patients. Diabetes Care. 2003;26(1):253. Not CKD treatment. [pmid: 12502701].
4782 Woolf AS, Mansell MA, Hoffbrand BI, et al. The effects of low dose intravenous 99-126 atrial natriuretic factor infusion in patients with chronic renal failure. Postgraduate Medical Journal. 1989;65(764):362-6. Not early CKD. [pmid: 2532741].
4783 Woolfrey SG, Hegbrant J, Thysell H, et al. Dose regimen adjustment for milrinone in congestive heart failure patients with moderate and severe renal failure. Journal of Pharmacy & Pharmacology. 1995;47(8):651-5. Not CKD treatment. [pmid: 8583366].
4784 Woolfson RG, Neild GH. Cyclosporin nephrotoxicity following cardiac transplantation. Nephrology Dialysis Transplantation. 1997;12(10):2054-6. Not CKD treatment.
4785 Worth DP, Harvey JN, Brown J, et al. gamma-L-Glutamyl-L-dopa is a dopamine pro-drug, relatively specific for the kidney in normal subjects. Clinical Science. 1985;69(2):207-14. Sample size less than 50 patients. [pmid: 3933890].
4786 Wotherspoon F, Laight DW, Turner C, et al. The effect of oral folic acid upon plasma homocysteine, endothelial function and oxidative stress in patients with type 1 diabetes and microalbuminuria. International Journal of Clinical Practice. 2008;62(4):569-74. Sample size less than 50 patients. [pmid: 18248393].
4787 Wright JG, Boddy AV, Highley M, et al. Estimation of glomerular filtration rate in cancer patients. British Journal of Cancer. 2001;84(4):452-9. Not early CKD. [pmid: 11207037].
4788 Wright JT Jr., Agodoa L, Contreras G, et al. Successful blood pressure control in the African American Study of Kidney Disease and Hypertension. Archives of Internal Medicine. 2002;162(14):1636-43. Not CKD treatment. [pmid: 12123409].
4789 Wright JT Jr., Probstfield JL, Cushman WC, et al. ALLHAT findings revisited in the context of subsequent analyses, other trials, and meta-analyses. Archives of Internal Medicine. 2009;169(9):832-42. Not relevant to key questions. [pmid: 19433694].
4790 Wright JT Jr., Probstfield JL, Cushman WC, et al. ALLHAT findings revisited in the context of subsequent analyses, other trials, and meta-analyses. Archives of Internal Medicine. 2009;169(9):832-42. Not RCT or controlled trial. [pmid: 19433694].
4791 Wright S, Bogan A, Chokshi A. DaVita program advocates self-management of CKD. Nephrology News & Issues. 2009;23(13):28-9. Not RCT or controlled trial. [pmid: 20050436].
4792 Writing Team for the Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications Research G. Effect of intensive therapy on the microvascular complications of type 1 diabetes mellitus. JAMA. 2002;287(19):2563-9. Not CKD treatment. [pmid: 12020338].
4793 Wrobel W, Sinkiewicz W, Gordon M, et al. Oral versus intravenous hydration and renal function in diabetic patients undergoing percutaneous coronary interventions. Kardiologia Polska. Sep. 2010;68(9):1015-20. Not CKD treatment. [pmid: 20859892].
4794 Wrone EM, Hornberger JM, Zehnder JL, et al. Randomized trial of folic acid for prevention of cardiovascular events in end-stage renal disease. Journal of the American Society of Nephrology. 2004;15(2):420-6. Not relevant to key questions. [pmid: 14747389].
4795 Wu AYT, Low LP. Managing vascular risk in hypertension with a focus on microalbuminuria: attitude and practices. Singapore Medical Journal. 2009;50(10):976-81. Not RCT or controlled trial. [pmid: 19907888].
4796 Wu S, Han Y, Li J. Treatment of incipient diabetic nephropathy by clearing away the stomach-heat, purging the heart fire, strengthening the spleen and tonifying the kidney. Journal of Traditional Chinese Medicine. 2000;20(3):172-5. Sample size less than 50 patients. [pmid: 11038976].
4797 Wu SW, Chang HR, Lian JD. The effect of low-dose cidofovir on the long-term outcome of polyomavirus-associated nephropathy in renal transplant recipients. Nephrology Dialysis Transplantation. 2009;24(3):1034-8. Not CKD treatment.
4798 Wuerzner G, Burnier M. Effects of selective angiotensin II and beta1-receptor blockade on renal haemodynamics and sodium handling during orthostatic stress in healthy individuals. Journal of Hypertension - Supplement. 2006;24(1):S89-93. Not relevant to key questions.
4799 Wuerzner G, Chiolero A, Maillard M, et al. Angiotensin II receptor blockade prevents acute renal sodium retention induced by low levels of orthostatic stress. [Erratum appears in Kidney Int. 2004 Mar;65(3):1131 Note: Chiclero, Arnaud [corrected to Chiolero, Arnaud]]. Kidney International. 2004;65(1):238-44. Not CKD treatment. [pmid: 14675055].
4800 Wuerzner G, Chiolero A, Maillard M, et al. Metoprolol prevents sodium retention induced by lower body negative pressure in healthy men. Kidney International. 2005;68(2):688-94. Not relevant to key questions. [pmid: 16014046].
4801 Wuhl E, Schaefer F. Effects of growth hormone in patients with chronic renal failure: experience in children and adults. Hormone Research. Suppl 3. 2002;58:35-8. Not CKD treatment. [pmid: 12435895].
4802 Wu-Wong JR. Endothelial dysfunction and chronic kidney disease: treatment options. Current Opinion in Investigational Drugs. 2008;9(9):970-82. Not CKD treatment. [pmid: 18729004].
4803 Wyllie BF, Garg AX, Macnab J, et al. Thrombotic thrombocytopenic purpura/haemolytic uraemic syndrome: a new index predicting response to plasma exchange. British Journal of Haematology. 2006;132(2):204-9. Sample size less than 50 patients. [pmid: 16398654].
4804 Wysocki M, Andersson OK, Persson B, et al. Vasoconstriction during acute hypervolemic hemodilution in hypertensive patients is not prevented by calcium blockade. Angiology. 1998;49(1):41-8. Sample size less than 50 patients. [pmid: 9456163].
4805 Xiao HW. An approach to the appropriate dosage of essential amino acids in the treatment of chronic renal failure. Journal of Tongji Medical University. 1991;11(4):240-3. Not CKD treatment. [pmid: 1819034].
4806 Xinwei J, Xianghua F, Jing Z, et al. Comparison of usefulness of simvastatin 20 mg versus 80 mg in preventing contrast-induced nephropathy in patients with acute coronary syndrome undergoing percutaneous coronary intervention. American Journal of Cardiology. 2009;104(4):519-24. Not CKD treatment. [pmid: 19660605].
4807 Xu G, Tu W, Jiang D, et al. Tripterygium wilfordii Hook F treatment for idiopathic refractory nephrotic syndrome in adults: a meta-analysis. Nephron. 2009;111(4):c223-8. Not CKD treatment. [pmid: 19287181].
4808 Xu L, Shao J. Estimation in longitudinal or panel data models with random-effect-based missing responses. Biometrics. 2009;65(4):1175-83. Not CKD treatment. [pmid: 19432782].
4809 Xu X, Ling Q, Gao F, et al. Hepatoprotective effects of marine and kuhuang in liver transplant recipients. American Journal of Chinese Medicine. 2009;37(1):27-34. Not CKD treatment. [pmid: 19222109].
4810 Yallop KG, Sheppard SV, Smith DC. The effect of mannitol on renal function following cardio-pulmonary bypass in patients with normal pre-operative creatinine. Anaesthesia. 2008;63(6):576-82. Not CKD treatment. [pmid: 18477268].
4811 Yamagishi Si, Fukami K, Ueda S, et al. Molecular mechanisms of diabetic nephropathy and its therapeutic intervention. Current Drug Targets. 2007;8(8):952-9. Sample size less than 50 patients. [pmid: 17691932].
4812 Yamamoto T, Moriwaki Y, Takahashi S, et al. Effects of pyrazinamide, probenecid, and benzbromarone on renal excretion of oxypurinol. Annals of the Rheumatic Diseases. 1991;50(9):631-3. Not CKD treatment. [pmid: 1929586].
4813 Yamazaki M, Ito S, Usami A, et al. Urinary excretion rate of ceruloplasmin in non-insulin-dependent diabetic patients with different stages of nephropathy. European Journal of Endocrinology. 1995;132(6):681-7. Follow-up less than 6 months. [pmid: 7788006].
4814 Yanagawa T, Araki A, Sasamoto K, et al. Effect of antidiabetic medications on microalbuminuria in patients with type 2 diabetes. Metabolism: Clinical & Experimental. 2004;53(3):353-7. Not CKD treatment. [pmid: 15015149].
4815 Yancy CW, Singh A. Potential applications of outpatient nesiritide infusions in patients with advanced heart failure and concomitant renal insufficiency (from the Follow-Up Serial Infusions of Nesiritide [FUSION I] trial). American Journal of Cardiology. 2006;98(2):226-9. Sample size less than 50 patients. [pmid: 16828598].
4816 Yang QW, Mou L, Lv FL, et al. Novel TLR4-antagonizing peptides inhibit LPS-induced release of inflammatory mediators by monocytes. Biochemical & Biophysical Research Communications. 2005;329(3):846-54. Not CKD treatment. [pmid: 15752733].
4817 Yang W, Israni RK, Brunelli SM, et al. Hemoglobin variability and mortality in ESRD. Journal of the American Society of Nephrology. 2007;18(12):3164-70. Not CKD treatment. [pmid: 18003781].
4818 Yang X, So WY, Kong APS, et al. Development and validation of a total coronary heart disease risk score in type 2 diabetes mellitus. American Journal of Cardiology. 2008;101(5):596-601. Not CKD treatment. [pmid: 18308005].
4819 Yang XL, So WY, Kong APS, et al. End-stage renal disease risk equations for Hong Kong Chinese patients with type 2 diabetes: Hong Kong Diabetes Registry. Diabetologia. 2006;49(10):2299-308. Not RCT or controlled trial. [pmid: 16944095].
4820 Yanik B, Bavbek N, Yanik T, et al. The effect of alendronate, risedronate, and raloxifene on renal functions, based on the Cockcroft and Gault method, in postmenopausal women. Renal Failure. 2007;29(4):471-6. Sample size less than 50 patients. [pmid: 17497471].
4821 Yano Y, Hoshide S, Ishikawa J, et al. The differential effects of angiotensin II type 1 receptor blockers on microalbuminuria in relation to low-grade inflammation in metabolic hypertensive patients. American Journal of Hypertension. 2007;20(5):565-72. Not RCT or controlled trial. [pmid: 17485023].
4822 Yaqoob MM. Acidosis and progression of chronic kidney disease. Current Opinion in Nephrology & Hypertension. Sep. 2010;19(5):489-92. Not CKD treatment. [pmid: 20539229].
4823 Yasuda G, Ando D, Hirawa N, et al. Effects of atorvastatin versus probucol on low-density lipoprotein subtype distribution and renal function in hyperlipidemic patients with nondiabetic nephropathy. Renal Failure. Jul. 2010;32(6):680-6. Follow-up less than 6 months. [pmid: 20540635].
4824 Yasuda G, Umemura S, Ishii M. Characterization of bunazosin-sensitive alpha1-adrenoceptors in human renal medulla. Journal of Cardiovascular Pharmacology. 1997;30(2):163-8. Sample size less than 50 patients. [pmid: 9269942].
4825 Yasue H, Yoshimura M. Natriuretic peptides in the treatment of heart failure. Journal of Cardiac Failure. 1996;2(4 Suppl):S277-85. Not CKD treatment. [pmid: 8951590].
4826 Yavuz S, Ayabakan N, Dilek K, et al. Renal dose dopamine in open heart surgery. Does it protect renal tubular function?. Journal of Cardiovascular Surgery. 2002;43(1):25-30. Not early CKD. [pmid: 11803323].
4827 Yavuz S, Ayabakan N, Goncu MT, et al. Effect of combined dopamine and diltiazem on renal function after cardiac surgery. Medical Science Monitor. 2002;8(5):PI45-50. Not early CKD. [pmid: 12011785].
4828 Ye DQ, Yang SG, Li XP, et al. Polymorphisms in the promoter region of RANTES in Han Chinese and their relationship with systemic lupus erythematosus. Archives of Dermatological Research. 2005;297(3):108-13. Not relevant to key questions. [pmid: 16032408].
4829 Ye S, Zheng M, Hu Y, et al. Hydrochloride pioglitazone decreases urinary monocyte chemoattractant protein-1 excretion in type 2 diabetics. Diabetes Research & Clinical Practice. Jun. 2010;88(3):247-51. Not CKD treatment. [pmid: 20371128].
4830 Yildiz A, Hursit M, Celik AV, et al. Doxazosin, but not amlodipine decreases insulin resistance in patients with chronic renal failure: a prospective, randomized-controlled study. Clinical Nephrology. 2002;58(6):405-10. Sample size less than 50 patients. [pmid: 12508961].
4831 Yilmaz E. Re: Takmaz SA, et al. Analgesic effect of 8- and 16-mg lornoxicam administered before shock wave lithotripsy: a randomized, double-blind, controlled study (Urology 2008;72:282-285). Urology. 2009;73(1):211-2. Not CKD treatment. [pmid: 19111738].
4832 Yilmaz E, Batislam E, Deniz T, et al. Histamine 1 receptor antagonist in symptomatic treatment of renal colic accompanied by nausea: two birds with one stone?. Urology. 2009;73(1):32-6. Not CKD treatment. [pmid: 18849063].
4833 Yilmaz MB, Yalta K, Yontar C, et al. Levosimendan improves renal function in patients with acute decompensated heart failure: comparison with dobutamine. Cardiovascular Drugs & Therapy. 2007;21(6):431-5. Not human studies. [pmid: 17952581].
4834 Yilmaz MI, Axelsson J, Sonmez A, et al. Effect of renin angiotensin system blockade on pentraxin 3 levels in type-2 diabetic patients with proteinuria. Clinical Journal of The American Society of Nephrology: CJASN. 2009;4(3):535-41. Sample size less than 50 patients. [pmid: 19211665].
4835 Yilmaz MI, Carrero JJ, Martin-Ventura JL, et al. Combined therapy with renin-angiotensin system and calcium channel blockers in type 2 diabetic hypertensive patients with proteinuria: effects on soluble TWEAK, PTX3, and flow-mediated dilation. Clinical Journal of The American Society of Nephrology: CJASN. Jul. 2010;5(7):1174-81. Follow-up less than 6 months. [pmid: 20430947].
4836 Yilmaz MI, Saglam M, Sonmez A, et al. Improving proteinuria, endothelial functions and asymmetric dimethylarginine levels in chronic kidney disease: ramipril versus valsartan. Blood Purification. 2007;25(4):327-35. Follow-up less than 6 months. [pmid: 17709915].
4837 Yilmaz MI, Sonmez A, Caglar K, et al. Peroxisome proliferator-activated receptor gamma (PPAR-gamma) agonist increases plasma adiponectin levels in type 2 diabetic patients with proteinuria. Endocrine. 2004;25(3):207-14. Sample size less than 50 patients. [pmid: 15758247].
4838 Ylitalo P, Pitkajarvi T, Pyykonen ML, et al. Inhibition of prostaglandin synthesis by indomethacin interacts with the antihypertensive effect of atenolol. Clinical Pharmacology & Therapeutics. 1985;38(4):443-9. Sample size less than 50 patients. [pmid: 3899459].
4839 Yokoyama H, Kannno S, Ishimura I, et al. Miglitol increases the adiponectin level and decreases urinary albumin excretion in patients with type 2 diabetes mellitus. Metabolism: Clinical & Experimental. 2007;56(11):1458-63. Sample size less than 50 patients. [pmid: 17950094].
4840 Yokoyama M, Torita M, Yoshizawa M, et al. Indication of vitamin E on microalbuminuria in patients with incipient diabetic nephropathy. Diabetes & Metabolism. 2001;27(5 Pt 1):611-2. Not CKD treatment. [pmid: 11694862].
4841 Yorioka N, Kiribayashi K, Naito T, et al. An oral adsorbent, AST-120, combined with a low-protein diet and RAS blocker, for chronic kidney disease. Journal of Nephrology. 2008;21(2):213-20. Sample size less than 50 patients. [pmid: 18446716].
4842 Yosefy C, Magen E, Kiselevich A, et al. Rosiglitazone improves, while Glibenclamide worsens blood pressure control in treated hypertensive diabetic and dyslipidemic subjects via modulation of insulin resistance and sympathetic activity. Journal of Cardiovascular Pharmacology. 2004;44(2):215-22. Not relevant to key questions. [pmid: 15243303].
4843 Yoshida EM, Marotta PJ, Greig PD, et al. Evaluation of renal function in liver transplant recipients receiving daclizumab (Zenapax), mycophenolate mofetil, and a delayed, low-dose tacrolimus regimen vs. a standard-dose tacrolimus and mycophenolate mofetil regimen: a multicenter randomized clinical trial. Liver Transplantation. 2005;11(9):1064-72. Not RCT or controlled trial. [pmid: 16123958].
4844 Yoshida K, Kohzuki M, Xu HL, et al. Effects of troglitazone and temocapril in spontaneously hypertensive rats with chronic renal failure. Journal of Hypertension. 2001;19(3):503-10. Not human studies. [pmid: 11288821].
4845 Yoshikawa K, Davies A. Safety of ProHance in special populations. European Radiology. Suppl 5. 1997;7:246-50. Not RCT or controlled trial. [pmid: 9370552].
4846 Yoshioka K, Imanishi M, Konishi Y, et al. Glomerular charge and size selectivity assessed by changes in salt intake in type 2 diabetic patients. Diabetes Care. 1998;21(4):482-6. Sample size less than 50 patients. [pmid: 9571328].
4847 Yoshioka K, Ohashi Y, Sakai T, et al. A multicenter trial of mizoribine compared with placebo in children with frequently relapsing nephrotic syndrome. Kidney International. 2000;58(1):317-24. Not adult population. [pmid: 10886577].
4848 Younes H, Egret N, Hadj-Abdelkader M, et al. Fermentable carbohydrate supplementation alters nitrogen excretion in chronic renal failure. Journal of Renal Nutrition. 2006;16(1):67-74. Not RCT or controlled trial. [pmid: 16414445].
4849 Young EW, Ellis CN, Messana JM, et al. A prospective study of renal structure and function in psoriasis patients treated with cyclosporin. Kidney International. 1994;46(4):1216-22. Sample size less than 50 patients. [pmid: 7861719].
4850 Young J, Anwar A. Strong diabetes. British Journal of Sports Medicine. 2007;41(5):335-6. discussion 6. Not relevant to key questions. [pmid: 17324962].
4851 Young JM, Terrin N, Wang X, et al. Asymmetric dimethylarginine and mortality in stages 3 to 4 chronic kidney disease. Clinical Journal of The American Society of Nephrology: CJASN. 2009;4(6):1115-20. Not CKD treatment. [pmid: 19389824].
4852 Yuan W, Wang J, Wu T. Chinese herbal medicine Huangqi type formulations for nephrotic syndrome. Cochrane Database of Systematic Reviews. 2008;(2):CD006335. Not CKD treatment. [pmid: 18425948].
4853 Yukawa S, Mune M, Yamada Y, et al. Ongoing clinical trials of lipid reduction therapy in patients with renal disease. Kidney International - Supplement. 1999;71:S141-3. Not RCT or controlled trial. [pmid: 10412759].
4854 Yusuf S. Preventing vascular events due to elevated blood pressure. Circulation. 2006;113(18):2166-8. Follow-up less than 6 months. [pmid: 16684871].
4855 Yusuf S, Lonn E, Bosch J, et al. Summary of randomized trials of angiotensin converting enzyme inhibitors. Clinical & Experimental Hypertension. 1999;21(5-6):835-45. Not RCT or controlled trial. [pmid: 10423106].
4856 Yusuff KB, Balogun OB. Pattern of drug utilization among hypertensives in a Nigerian teaching hospital. Pharmacoepidemiology & Drug Safety. 2005;14(1):69-74. Follow-up less than 6 months. [pmid: 15508134].
4857 Yuyun MF, Khaw KT, Luben R, et al. Microalbuminuria and stroke in a British population: the European Prospective Investigation into Cancer in Norfolk (EPIC-Norfolk) population study. Journal of Internal Medicine. 2004;255(2):247-56. Not early CKD. [pmid: 14746562].
4858 Yuyun MF, Khaw KT, Luben R, et al. Microalbuminuria independently predicts all-cause and cardiovascular mortality in a British population: The European Prospective Investigation into Cancer in Norfolk (EPIC-Norfolk) population study. International Journal of Epidemiology. 2004;33(1):189-98. Not relevant to key questions. [pmid: 15075168].
4859 Zachariae H, Abrams B, Bleehen SS, et al. Conversion of psoriasis patients from the conventional formulation of cyclosporin A to a new microemulsion formulation: a randomized, open, multicentre assessment of safety and tolerability. Dermatology. 1998;196(2):231-6. Sample size less than 50 patients. [pmid: 9568413].
4860 Zacharias M, Conlon NP, Herbison GP, et al. Interventions for protecting renal function in the perioperative period. Cochrane Database of Systematic Reviews. 2008;(4):CD003590. Not CKD treatment. [pmid: 18843647].
4861 Zacharias M, Gilmore ICS, Herbison GP, et al. Interventions for protecting renal function in the perioperative period. Cochrane Database of Systematic Reviews. 2005;(3):CD003590. Not CKD treatment. [pmid: 16034904].
4862 Zager P, Nikolic J, Raj DS, et al. Hypertension in end-stage renal disease patients. Current Opinion in Nephrology & Hypertension. 2000;9(3):279-83. Not RCT or controlled trial. [pmid: 10847330].
4863 Zagler A, Azadpour M, Mercado C, et al. N-acetylcysteine and contrast-induced nephropathy: a meta-analysis of 13 randomized trials. American Heart Journal. 2006;151(1):140-5. Not RCT or controlled trial. [pmid: 16368307].
4864 Zaleski L, Abello D, Gold MI. Desflurane versus isoflurane in patients with chronic hepatic and renal disease. Anesthesia & Analgesia. 1993;76(2):353-6. Not RCT or controlled trial. [pmid: 8424515].
4865 Zaltzman JS. A comparison of short-term exposure of once-daily extended release tacrolimus and twice-daily cyclosporine on renal function in healthy volunteers. Transplantation. Dec. 15. 2010;90(11):1185-91. Not CKD treatment. [pmid: 21166111].
4866 Zalunardo N, Levin A. Anemia and the heart in chronic kidney disease. Seminars in Nephrology. 2006;26(4):290-5. Not RCT or controlled trial. [pmid: 16949467].
4867 Zambraski EJ, Dodelson R, Guidotti SM, et al. Renal prostaglandin E2 and F2 alpha synthesis during exercise: effects of indomethacin and sulindac. Medicine & Science in Sports & Exercise. 1986;18(6):678-84. Sample size less than 50 patients. [pmid: 3537627].
4868 Zanardo G, Michielon P, Rosi P, et al. Effects of a continuous diltiazem infusion on renal function during cardiac surgery. Journal of Cardiothoracic & Vascular Anesthesia. 1993;7(6):711-6. Sample size less than 50 patients. [pmid: 8305662].
4869 Zanchetti A, Hansson L, Leonetti G, et al. Low-dose aspirin does not interfere with the blood pressure-lowering effects of antihypertensive therapy. Journal of Hypertension. 2002;20(5):1015-22. Not CKD treatment. [pmid: 12011664].
4870 Zandbergen AAM, Baggen MGA, Lamberts SWJ, et al. Effect of losartan on microalbuminuria in normotensive patients with type 2 diabetes mellitus. A randomized clinical trial. Annals of Internal Medicine. 2003;139(2):90-6. Follow-up less than 6 months. [pmid: 12859158].
4871 Zandbergen AAM, Lamberts SWJ, Baggen MGA, et al. The IGF-I system and the renal and haemodynamic effects of losartan in normotensive patients with type 2 diabetes mellitus: a randomized clinical trial. Clinical Endocrinology. 2006;64(2):203-8. Sample size less than 50 patients. [pmid: 16430721].
4872 Zannikos PN, Rohatagi S, Jensen BK, et al. Pharmacokinetics, pharmacodynamics, and safety of a platelet GPIIb/IIIa antagonist, RGD891, following intravenous administration in healthy male volunteers. Journal of Clinical Pharmacology. 2000;40(11):1245-56. Not early CKD. [pmid: 11075310].
4873 Zarazaga A, Garcia-De-Lorenzo L, Garcia-Luna PP, et al. Nutritional support in chronic renal failure: systematic review. Clinical Nutrition. 2001;20(4):291-9. Not relevant to key questions. [pmid: 11478825].
4874 Zawada ET Jr. Renal hemodynamic changes after beta-blocker-diuretic combination therapy in azotemic hypertensive patients. International Journal of Artificial Organs. 1986;9(6):405-12. Sample size less than 50 patients. [pmid: 2880810].
4875 Zawada ET Jr., Williams L, McClung DE, et al. Renal-metabolic consequences of antihypertensive therapy with diltiazem versus hydrochlorothiazide. Mineral & Electrolyte Metabolism. 1987;13(2):72-7. Sample size less than 50 patients. [pmid: 3320720].
4876 Zeller A, Sigle JP, Battegay E, et al. Value of a standard urinary dipstick test for detecting microalbuminuria in patients with newly diagnosed hypertension. Swiss Medical Weekly. 2005;135(3-4):57-61. Not RCT or controlled trial. [pmid: 15729608].
4877 Zeller K, Whittaker E, Sullivan L, et al. Effect of restricting dietary protein on the progression of renal failure in patients with insulin-dependent diabetes mellitus. New England Journal of Medicine. 1991;324(2):78-84. Sample size less than 50 patients. [pmid: 1984187].
4878 Zelmanovitz T, Gross JL, Oliveira J, et al. Proteinuria is still useful for the screening and diagnosis of overt diabetic nephropathy. Diabetes Care. 1998;21(7):1076-9. Not RCT or controlled trial. [pmid: 9653598].
4879 Zelmanovitz T, Gross JL, Oliveira JR, et al. The receiver operating characteristics curve in the evaluation of a random urine specimen as a screening test for diabetic nephropathy. Diabetes Care. 1997;20(4):516-9. Not RCT or controlled trial. [pmid: 9096972].
4880 Zeman M, Zak A, Vecka M, et al. N-3 fatty acid supplementation decreases plasma homocysteine in diabetic dyslipidemia treated with statin-fibrate combination. Journal of Nutritional Biochemistry. 2006;17(6):379-84. Not RCT or controlled trial. [pmid: 16214329].
4881 Zemmel MH. The role of COX-2 inhibitors in the perioperative setting: efficacy and safety--a systematic review. AANA Journal. 2006;74(1):49-60. Not relevant to key questions. [pmid: 16483069].
4882 Zerem E, Imamovic G, Omerovic S. Symptomatic simple renal cyst: comparison of continuous negative-pressure catheter drainage and single-session alcohol sclerotherapy. AJR. American Journal of Roentgenology. 2008;190(5):1193-7. Not CKD treatment. [pmid: 18430831].
4883 Zhang J, Fu X, Jia X, et al. B-type natriuretic peptide for prevention of contrast-induced nephropathy in patients with heart failure undergoing primary percutaneous coronary intervention. Acta Radiologica. Jul. 2010;51(6):641-8. Not CKD treatment. [pmid: 20438292].
4884 Zhang JH, Li LS, Zhang M. Clinical effects of rheum and captopril on preventing progression of chronic renal failure. Chinese Medical Journal. 1990;103(10):788-93. Sample size less than 50 patients. [pmid: 2125252].
4885 Zhang M, Zhang D, Zhang W, et al. Treatment of chronic renal failure by supplementing the kidney and invigorating blood flow. Journal of Traditional Chinese Medicine. 2004;24(4):247-51. Not CKD treatment. [pmid: 15688687].
4886 Zhang Z, Shahinfar S, Keane WF, et al. Importance of baseline distribution of proteinuria in renal outcomes trials: lessons from the reduction of endpoints in NIDDM with the angiotensin II antagonist losartan (RENAAL) study. Journal of the American Society of Nephrology. 2005;16(6):1775-80. Follow-up less than 6 months. [pmid: 15872078].
4887 Zhao Q, Wu TG, Lin Y, et al. Low-dose nesiritide improves renal function in heart failure patients following acute myocardial infarction. Heart & Vessels. Mar. 2010;25(2):97-103. Not CKD treatment. [pmid: 20339970].
4888 Zhou X, Liu JX, Shi R, et al. Compound ion salt, a novel low-sodium salt substitute: from animal study to community-based population trial. American Journal of Hypertension. 2009;22(9):934-42. Follow-up less than 6 months. [pmid: 19661926].
4889 Zhou XJ, Vaziri ND. Defective calcium signalling in uraemic platelets and its amelioration with long-term erythropoietin therapy. Nephrology Dialysis Transplantation. 2002;17(6):992-7. Not human studies.
4890 Zhu S, Liu Y, Wang L, et al. Transforming growth factor-beta1 is associated with kidney damage in patients with essential hypertension: renoprotective effect of ACE inhibitor and/or angiotensin II receptor blocker. Nephrology Dialysis Transplantation. 2008;23(9):2841-6. Not CKD treatment.
4891 Zhu X, Stergiopoulos K, Wu S. Risk of hypertension and renal dysfunction with an angiogenesis inhibitor sunitinib: systematic review and meta-analysis. Acta Oncologica. 2009;48(1):9-17. Not CKD treatment. [pmid: 18752081].
4892 Ziakka S, Ursu M, Poulikakos D, et al. Predictive factors and therapeutic approach of renovascular disease: four years' follow-up. Renal Failure. 2008;30(10):965-70. Not CKD treatment. [pmid: 19016147].
4893 Zierer A, Voeller RK, Melby SJ, et al. Potential renal protective benefits of intra-operative BNP infusion during cardiac transplantation. Transplantation Proceedings. 2006;38(10):3680-4. Not relevant to key questions. [pmid: 17175366].
4894 Zietse R, Derkx FH, Weimar W, et al. Effect of atrial natriuretic peptide on renal and vascular permeability in diabetes mellitus. Journal of the American Society of Nephrology. 1995;5(12):2057-66. Sample size less than 50 patients. [pmid: 7579054].
4895 Zietse R, Schalekamp MA. Effect of synthetic human atrial natriuretic peptide (102-126) in nephrotic syndrome. Kidney International. 1988;34(5):717-24. Sample size less than 50 patients. [pmid: 2974095].
4896 Zijlstra JG, Tulleken JE, Ligtenberg JJM, et al. p38-MAPK inhibition and endotoxin induced tubular dysfunction in men. Journal of Endotoxin Research. 2004;10(6):402-5. Sample size less than 50 patients. [pmid: 15588422].
4897 Zimmerman TW, Schenker S. A comparative evaluation of cimetidine and ranitidine. Rational Drug Therapy. 1985;19(4):1-7. Not CKD treatment. [pmid: 2932770].
4898 Zipser RD. Effects of selective inhibition of thromboxane synthesis on renal function in humans. American Journal of Physiology. 1985;248(6 Pt 2):F753-6. Sample size less than 50 patients. [pmid: 3839111].
4899 Zitta S, Stoschitzky K, Zweiker R, et al. Dynamic renal function testing by compartmental analysis: assessment of renal functional reserve in essential hypertension. Nephrology Dialysis Transplantation. 2000;15(8):1162-9. Not early CKD.
4900 Zoccali C, Ciccarelli M, Mallamaci F, et al. Effect of naloxone on the defective autonomic control of heart rate in uraemic patients. Clinical Science. 1985;69(1):81-6. Sample size less than 50 patients. [pmid: 4064558].
4901 Zoccali C, Leonardis D, Enia G, et al. The MAURO study: multiple intervention and audit in renal diseases to optimize care. Journal of Nephrology. 2008;21(1):20-2. Not CKD treatment. [pmid: 18264932].
4902 Zoccali C, Mallamaci F. Salt intake and hyperfiltration. Hypertension. 1996;28(6):1100-2. Not CKD treatment. [pmid: 8952604].
4903 Zoungas S, Branley P, Kerr PG, et al. Atherosclerosis and folic acid supplementation trial in chronic renal failure: baseline results. Nephrology. 2004;9(3):130-41. Not relevant to key questions. [pmid: 15189174].
4904 Zoungas S, Cameron JD, Kerr PG, et al. Association of carotid intima-medial thickness and indices of arterial stiffness with cardiovascular disease outcomes in CKD. American Journal of Kidney Diseases. 2007;50(4):622-30. Follow-up less than 6 months. [pmid: 17900462].
4905 Zoungas S, McGrath BP, Branley P, et al. Cardiovascular morbidity and mortality in the Atherosclerosis and Folic Acid Supplementation Trial (ASFAST) in chronic renal failure: a multicenter, randomized, controlled trial. Journal of the American College of Cardiology. 2006;47(6):1108-16. Follow-up less than 6 months. [pmid: 16545638].
4906 Zucchelli P, Ponticelli C, Cagnoli L, et al. Prognostic value of T lymphocyte subset ratio in idiopathic membranous nephropathy. American Journal of Nephrology. 1988;8(1):15-20. Sample size less than 50 patients. [pmid: 2967032].
4907 Zucchelli P, Zuccala A. Blood pressure control effects on the progression of chronic renal failure. Renal Failure. 1993;15(3):339-42. Not RCT or controlled trial. [pmid: 8516487].
4908 Zucchelli P, Zuccala A. Pharmacological treatment of renal parenchymal hypertension. Contributions to Nephrology. 1994;106:198-201. Not RCT or controlled trial. [pmid: 8174372].
4909 Zucchelli P, Zuccala A, Borghi M, et al. Comparison of calcium channel blocker and ACE inhibitor therapy on the progression of renal insufficiency. Contributions to Nephrology. 1990;81:255-63. Not CKD treatment. [pmid: 2093506].
4910 Zucchelli P, Zuccala A, Sturani A. Glomerular dysfunction in diabetic nephropathy. Postgraduate Medical Journal. Suppl 3. 1988;64:22-30. discussion 48-9. Follow-up less than 6 months. [pmid: 3074295].
4911 Zuckermann A, Birsan T, Thaghavi S, et al. Benefit of mycophenolate mofetil in patients with cyclosporine A-induced nephropathy after lung transplantation. Transplantation Proceedings. 1999;31(1-2):1160-1. Not RCT or controlled trial. [pmid: 10083518].
4912 Zuliani E, Zwahlen H, Gilliet F, et al. Vancomycin-induced hypersensitivity reaction with acute renal failure: resolution following cyclosporine treatment. Clinical Nephrology. 2005;64(2):155-8. Sample size less than 50 patients. [pmid: 16114793].