# Search Strings

## Screening (KQ1, KQ2)

Database: Ovid MEDLINE(R)

Search Strategy:

--------------------------------------------------------------------------------

1. exp mass screening/ or screening.tw. or exp early diagnosis/
2. (expression screening or throughput screening or molecular screening or pharmaceutical screening or mutation screening or genetic screening).tw. or exp genetic screening/ or cancer screening.tw. or compound screening.tw. or drug screening.tw. or exp drug evaluation, preclinical/
3. 1 not 2
4. (randomized controlled trial or controlled clinical trial).pt. or random*.ti,ab. or placebo.ab. or exp Double-Blind Method/
5. exp albuminuria/ or exp proteinuria/ or exp glomerular filtration rate/ or exp creatinine/ or exp kidney function tests/ or exp cystatins/ or exp kidney diseases/ or kidney$.ti. or nephr$.ti. or renal.ti. or exp kidney/
6. 3 and 4 and 5
7. exp animals/ not humans.sh.
8. 6 not 7
9. limit 8 to english language
10. limit 9 to yr=“1985 -Current”
11. 11limit 10 to “all child (0 to 18 years)”
12. limit 10 to “all adult (19 plus years)”
13. 11 not 12
14. 10 not 13

## Monitoring (KQ3, KQ4)

Database: Ovid MEDLINE(R)

Search Strategy:

--------------------------------------------------------------------------------

1. monitoring.tw. or exp disease progression/
2. cardiac monitoring.tw. or exp drug monitoring/ or exp environmental monitoring/ or drug monitoring.tw. or exp blood glucose self-monitoring/ or exp blood gas monitoring, transcutaneous/ or exp clinical trials data monitoring committees/ or exp esophageal pH monitoring/ or exp monitoring, immunologic/ or exp uterine monitoring/ or exp monitoring, intraoperative/ or exp radiation monitoring/ or exp monitoring, physiologic/
3. 1 not 2
4. (randomized controlled trial or controlled clinical trial).pt. or random*.ti,ab. or placebo.ab. or exp Double-Blind Method/
5. exp albuminuria/ or exp proteinuria/ or exp glomerular filtration rate/ or exp creatinine/ or exp kidney function tests/ or exp cystatins/ or exp kidney diseases/ or kidney$.ti. or nephr$.ti. or renal.ti. or exp kidney/
6. 3 and 4 and 5
7. exp animals/ not humans.sh.
8. 6 not 7
9. limit 8 to english language
10. limit 9 to yr=“1985 -Current”
11. limit 10 to “all child (0 to 18 years)”
12. limit 10 to “all adult (19 plus years)”
13. 11 not 12
14. 10 not 13

## Treatment (KQ5, KQ6)

Database: Ovid MEDLINE(R)

Search Strategy:

--------------------------------------------------------------------------------

1. exp albuminuria/co, de, dh, dt, mo, pc, th or exp proteinuria/co, de, dh, dt, mo, pc, th or exp glomerular filtration rate/ or exp kidney diseases/co, de, dh, dt, mo, pc, th or exp kidney/co, de, dh, dt, mo, pc, th or exp diabetic nephropathies/co, de, dh, dt, mo, pc, th or exp kidney failure, chronic/co, de, dh, dt, mo, pc, th or exp chronic renal insufficiency/co, de, dh, dt, mo, pc, th or exp renal insufficiency/co, de, dh, dt, mo, pc, th or exp renal insufficiency, chronic/co, de, dh, dt, mo, pc, th
2. exp *renal replacement therapy/ or exp renal dialysis/ or exp *kidney neoplasms/ or *nephritis/ or exp *urinary tract infections/ or exp *urolithiasis/ or exp anuria/ or exp diabetes insipidus/ or exp fanconi syndrome/ or exp hepatorenal syndrome/ or exp hydronephrosis/ or exp kidney cortex necrosis/ or exp Kidney Diseases, Cystic/ or kidney papillary necrosis/ or exp nephritis/ or exp renal artery obstruction/ or exp Renal Tubular Transport, Inborn Errors/ or exp Tuberculosis, Renal/ or exp Zellweger syndrome/ or exp AIDS-Associated Nephropathy/ or exp Hyperoxaluria/ or exp Nephrocalcinosis/ or exp Perinephritis/ or exp Renal Osteodystrophy/
3. 1 not 2
4. (randomized controlled trial or controlled clinical trial).pt. or random*.ti,ab. or placebo.ab. or exp Double-Blind Method/ or randomized controlled trials as topic/
5. 3 and 4
6. exp animals/ not humans.sh.
7. 5 not 6
8. limit 7 to english language
9. limit 8 to yr=“1985 -Current”
10. limit 9 to “all child (0 to 18 years)”
11. limit 9 to “all adult (19 plus years)”
12. 10 not 11
13. 9 not 12