# Appendixes

Appendix A Search Strings

Appendix B Excluded Studies

Appendix C Evidence Tables and Other Supporting Tables and Figures