# Acronyms and Abbreviations

ACEI: Angiotensin converting enzyme inhibitors
AKI: Acute kidney injury
ARB: Angiotensin receptor blocker
ADA: American Diabetes Association
AHRQ: Agency for Healthcare Research and Quality
ALLHAT: Antihypertensive Lipid Lowering Treatment to Prevent Heart Attack
BB: Beta blocker
CCB: Calcium channel blocker
CCT: Controlled clinical trial
CHF: Congestive heart failure
CI: Confidence interval
CKD: Chronic kidney disease
CKD-EPI: Chronic Kidney Disease Epidemiology Collaboration
DBP: Diastolic blood pressure
eGFR: Estimated glomerular filtration rate
ESRD: End-stage renal disease
GFR: Glomerular filtration rate
HbA_1c_: Hemoglobin A_1c_
HCTZ: Hydrochlorothiazide
JNC7: Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure
KDIGO: Kidney Disease: Inspiring Global Outcomes
KDOQI: Kidney Disease Outcomes Quality Initiative
KEEP: Kidney Early Evaluation Program
LDL: Low density lipoprotein
MAP: Mean arterial blood pressure
MDRD: Modification of Diet in Renal Disease
MI: Myocardial infarction
NHANES: National Health and Nutrition Examination Survey
NHS: National Health Service
NICE: National Institute for Health and Clinical Excellence
RCT: Randomized controlled trial
ROADMAP: Randomized Olmesartan and Diabetes Microalbuminuria Prevention
RR: Relative risk
TEP: Technical expert panel
UACR: Urinary albumin-creatinine ratio
UAER: Urinary albumin excretion rate
UPER: Urine protein excretion rate
USRDS: U.S. Renal Data System