# Acknowledgments

We would like to thank Marilyn Eells for outstanding editing support. We also would like to thank James Tacklind and Indulis Rutks for their literature searching expertise, database management, extracting skills, and all-around general support. Finally, we would like to thank Nino Alapishvili, M.D., Milind Junghare, M.D., and Wei Yen Kong, M.D., for their assistance with abstract triaging and data extraction.