# References

1 Abrams P. Incontinence: 4th International Consultation on Incontinence. Paris. July 5–8, 2008. 4th ed. [Paris]. Health Publications Ltd. 2009. Committee 1 Epidemiology of Urinary (UI) and Fecal (FI) Incontinence and Pelvic Organ Prolapse (POP).
2 Carls C. The prevalence of stress urinary incontinence in high school and college-age female athletes in the midwest: implications for education and prevention. Urol Nurs. Feb. 2007;27(1):21-4. 39. [pmid: 17390923].
3 Kinchen KS, Lee J, Fireman B, et al. The prevalence, burden, and treatment of urinary incontinence among women in a managed care plan. J Womens Health (Larchmt). Apr. 2007;16(3):415-22. [pmid: 17439386].
4 Sampselle CM, Harlow SD, Skurnick J, et al. Urinary incontinence predictors and life impact in ethnically diverse perimenopausal women. Obstet Gynecol. Dec. 2002;100(6):1230-8. [pmid: 12468167].
5 Boyington JE, Howard DL, Carter-Edwards L, et al. Differences in resident characteristics and prevalence of urinary incontinence in nursing homes in the southeastern United States. Nurs Res. 2007;56:97-107. [pmid: 17356440].
6 Morrison A, Levy R. Fraction of nursing home admissions attributable to urinary incontinence. Value Health. Jul-Aug. 2006;9(4):272-4. [pmid: 16903997].
7 Anger JT, Saigal CS, Madison R, et al. Increasing costs of urinary incontinence among female Medicare beneficiaries. J Urol. Jul. 2006;176(1):247-51. discussion 51. [pmid: 16753411].
8 Hu TW, Wagner TH, Bentkover JD, et al. Costs of urinary incontinence and overactive bladder in the United States: a comparative study. Urology. Mar. 2004;63(3):461-5. [pmid: 15028438].
9 Shamliyan T, Wyman J, Bliss DZ, et al. Prevention of urinary and fecal incontinence in adults. Evid Rep Technol Assess (Full Rep). Dec. 2007;(161):1-379. [pmid: 18457475].
10 Haylen BT, de Ridder D, Freeman RM, et al. An International Urogynecological Association (IUGA)/International Continence Society (ICS) joint report on the terminology for female pelvic floor dysfunction. Neurourol Urodyn. 2010;29(1):4-20. [pmid: 19941278].
11 Samuelsson E, Victor A, Tibblin G. A population study of urinary incontinence and nocturia among women aged 20–59 years. Prevalence, well-being and wish for treatment. Acta Obstet Gynecol Scand. Jan. 1997;76(1):74-80. [pmid: 9033249].
12 Foldspang A, Mommsen S, Djurhuus JC. Prevalent urinary incontinence as a correlate of pregnancy, vaginal childbirth, and obstetric techniques. Am J Public Health. Feb. 1999;89(2):209-12. [pmid: 9949751].
13 Hannestad YS, Rortveit G, Sandvik H, et al. A community-based epidemiological survey of female urinary incontinence: the Norwegian EPINCONT study. Epidemiology of Incontinence in the County of Nord-Trondelag. J Clin Epidemiol. Nov. 2000;53(11):1150-7. [pmid: 11106889].
14 Peyrat L, Haillot O, Bruyere F, et al. Prevalence and risk factors of urinary incontinence in young and middle-aged women. BJU Int. Jan. 2002;89(1):61-6. [pmid: 11849162].
15 van der Vaart CH, de Leeuw JR, Roovers JP, et al. The effect of urinary incontinence and overactive bladder symptoms on quality of life in young women. BJU Int. Oct. 2002;90(6):544-9. [pmid: 12230614].
16 Chen GD, Lin TL, Hu SW, et al. Prevalence and correlation of urinary incontinence and overactive bladder in Taiwanese women. Neurourol Urodyn. 2003;22(2):109-17. [pmid: 12579627].
17 Rortveit G, Daltveit AK, Hannestad YS, et al. Urinary incontinence after vaginal delivery or cesarean section. N Engl J Med. Mar. 6. 2003;348(10):900-7. [pmid: 12621134].
18 Miller YD, Brown WJ, Russell A, et al. Urinary incontinence across the lifespan. Neurourol Urodyn. 2003;22(6):550-7. [pmid: 12951662].
19 Parazzini F, Chiaffarino F, Lavezzari M, et al. Risk factors for stress, urge or mixed urinary incontinence in Italy. Bjog. Oct. 2003;110(10):927-33. [pmid: 14550363].
20 Mawajdeh SM, Al-Qutob R, Schmidt A. Measuring reproductive morbidity: a community-based approach, Jordan. Health Care Women Int. Aug. 2003;24(7):635-49. [pmid: 14627210].
21 Andersson G, Johansson JE, Garpenholt O, et al. Urinary incontinence--prevalence, impact on daily living and desire for treatment: a population-based study. Scand J Urol Nephrol. 2004;38:125-30. [pmid: 15204395].
22 Nygaard I, Girts T, Fultz NH, et al. Is urinary incontinence a barrier to exercise in women?. Obstet Gynecol. Aug. 2005;106(2):307-14. [pmid: 16055580].
23 Rohr G, Stovring H, Christensen K, et al. Characteristics of middle-aged and elderly women with urinary incontinence. Scand J Prim Health Care. Dec. 2005;23(4):203-8. [pmid: 16272067].
24 Irwin DE, Milsom I, Hunskaar S, et al. Population-based survey of urinary incontinence, overactive bladder, and other lower urinary tract symptoms in five countries: results of the EPIC study. Eur Urol. Dec. 2006;50(6):1306-14. discussion 14–5. [pmid: 17049716].
25 Burgio KL, Burgio LD, McCormick KA, et al. Assessing toileting skills and habits in an adult day care center. J Gerontol Nurs. Dec. 1991;17(12):32-5. [pmid: 1761819].
26 Mommsen S, Foldspang A. Body mass index and adult female urinary incontinence. World J Urol. 1994;12(6):319-22. [pmid: 7881469].
27 Bogren MA, Hvarfwen E, Fridlund B. Urinary incontinence among a 65-year old Swedish population: medical history and psychosocial consequences. Vard Nord Utveckl Forsk. Winter. 1997;17(4):14-7. [pmid: 9464154].
28 Kuh D, Cardozo L, Hardy R. Urinary incontinence in middle aged women: childhood enuresis and other lifetime risk factors in a British prospective cohort. J Epidemiol Community Health. Aug. 1999;53(8):453-8. [pmid: 10562862].
29 Moller LA, Lose G, Jorgensen T. The prevalence and bothersomeness of lower urinary tract symptoms in women 40–60 years of age. Acta Obstet Gynecol Scand. Apr. 2000;79(4):298-305. [pmid: 10746846].
30 Ueda T, Tamaki M, Kageyama S, et al. Urinary incontinence among community-dwelling people aged 40 years or older in Japan: prevalence, risk factors, knowledge and self-perception. Int J Urol. Mar. 2000;7(3):95-103. [pmid: 10750888].
31 Temml C, Haidinger G, Schmidbauer J, et al. Urinary incontinence in both sexes: prevalence rates and impact on quality of life and sexual life. Neurourol Urodyn. 2000;19(3):259-71. [pmid: 10797583].
32 Swithinbank LV, Donovan JL, du Heaume JC, et al. Urinary symptoms and incontinence in women: relationships between occurrence, age, and perceived impact. Br J Gen Pract. Nov. 1999;49(448):897-900. [pmid: 10818656].
33 Alling Moller L, Lose G, Jorgensen T. Risk factors for lower urinary tract symptoms in women 40 to 60 years of age. Obstet Gynecol. Sep. 2000;96(3):446-51. [pmid: 10960640].
34 Muscatello DJ, Rissel C, Szonyi G. Urinary symptoms and incontinence in an urban community: prevalence and associated factors in older men and women. Intern Med J. Apr. 2001;31(3):151-60. [pmid: 11478344].
35 van der Vaart CH, van der Bom JG, de Leeuw JR, et al. The contribution of hysterectomy to the occurrence of urge and stress urinary incontinence symptoms. BJOG. Feb. 2002;109(2):149-54. [pmid: 11911100].
36 Sze EH, Jones WP, Ferguson JL, et al. Prevalence of urinary incontinence symptoms among black, white, and Hispanic women. Obstet Gynecol. Apr. 2002;99(4):572-5. [pmid: 12039113].
37 McGrother CW, Donaldson MM, Shaw C, et al. Storage symptoms of the bladder: prevalence, incidence and need for services in the UK. BJU Int. Apr. 2004;93(6):763-9. [pmid: 15049987].
38 Ozerdogan N, Beji NK, Yalcin O. Urinary incontinence: its prevalence, risk factors and effects on the quality of life of women living in a region of Turkey. Gynecol Obstet Invest. 2004;58(3):145-50. [pmid: 15237249].
39 Corcos J, Schick E. Prevalence of overactive bladder and incontinence in Canada. Can J Urol. Jun. 2004;11(3):2278-84. [pmid: 15287994].
40 Vandoninck V, Bemelmans BL, Mazzetta C, et al. The prevalence of urinary incontinence in community-dwelling married women: a matter of definition. BJU Int. Dec. 2004;94(9):1291-5. [pmid: 15610108].
41 Melville JL, Katon W, Delaney K, et al. Urinary incontinence in US women: a population-based study. Arch Intern Med. Mar. 14. 2005;165(5):537-42. [pmid: 15767530].
42 Kocak I, Okyay P, Dundar M, et al. Female urinary incontinence in the west of Turkey: prevalence, risk factors and impact on quality of life. Eur Urol. Oct. 2005;48(4):634-41. [pmid: 15963633].
43 Tegerstedt G, Maehle-Schmidt M, Nyren O, et al. Prevalence of symptomatic pelvic organ prolapse in a Swedish population. Int Urogynecol J Pelvic Floor Dysfunct. Nov–Dec. 2005;16(6):497-503. [pmid: 15986100].
44 Teleman P, Lidfeldt J, Nerbrand C, et al. Lower urinary tract symptoms in middle-aged women--prevalence and attitude towards mild urinary incontinence: a community-based population study. Acta Obstet Gynecol Scand. Nov. 2005;84(11):1108-12. [pmid: 16232181].
45 Fritel X, Ringa V, Varnoux N, et al. Mode of delivery and severe stress incontinence. a cross-sectional study among 2,625 perimenopausal women. Bjog. Dec. 2005;112(12):1646-51. [pmid: 16305569].
46 Goldberg RP, Abramov Y, Botros S, et al. Delivery mode is a major environmental determinant of stress urinary incontinence: results of the Evanston-Northwestern Twin Sisters Study. Am J Obstet Gynecol. Dec. 2005;193(6):2149-53. [pmid: 16325632].
47 Thom DH, van den Eeden SK, Ragins AI, et al. Differences in prevalence of urinary incontinence by race/ethnicity. J Urol. Jan. 2006;175(1):259-64. [pmid: 16406923].
48 Lukacz ES, Lawrence JM, Contreras R, et al. Parity, mode of delivery, and pelvic floor disorders. Obstet Gynecol. Jun. 2006;107(6):1253-60. [pmid: 16738149].
49 Waetjen LE, Liao S, Johnson WO, et al. Factors associated with prevalent and incident urinary incontinence in a cohort of midlife women: a longitudinal analysis of data: study of women’s health across the nation. Am J Epidemiol. Feb. 1. 2007;165(3):309-18. [pmid: 17132698].
50 Chen YC, Chen GD, Hu SW, et al. Is the occurrence of storage and voiding dysfunction affected by menopausal transition or associated with the normal aging process?. Menopause. May–Jun. 2003;10(3):203-8. [pmid: 12792290].
51 Nygaard IE, Lemke JH. Urinary incontinence in rural older women: prevalence, incidence and remission. J Am Geriatr Soc. Sep. 1996;44(9):1049-54. [pmid: 8790229].
52 Thom DH, van den Eeden SK, Brown JS. Evaluation of parturition and other reproductive variables as risk factors for urinary incontinence in later life. Obstet Gynecol. Dec. 1997;90(6):983-9. [pmid: 9397116].
53 Koyama W, Koyanagi A, Mihara S, et al. Prevalence and conditions of urinary incontinence among the elderly. Methods Inf Med. Jun. 1998;37(2):151-5. [pmid: 9656656].
54 Damiaan J, Martin-Moreno JM, Lobo F, et al. Prevalence of urinary incontinence among Spanish older people living at home. Eur Urol. 1998;34:333-8. [pmid: 9748681].
55 Brown JS, Grady D, Ouslander JG, et al. Prevalence of urinary incontinence and associated risk factors in postmenopausal women. Heart & Estrogen/Progestin Replacement Study (HERS) Research Group. Obstet Gynecol. Jul. 1999;94(1):66-70. [pmid: 10389720].
56 Stenberg A, Heimer G, Holmberg L, et al. Prevalence of postmenopausal symptoms in two age groups of elderly women in relation to oestrogen replacement therapy. Maturitas. Dec. 15. 1999;33(3):229-37. [pmid: 10656501].
57 Bortolotti A, Bernardini B, Colli E, et al. Prevalence and risk factors for urinary incontinence in Italy. Eur Urol. Jan. 2000;37(1):30-5. [pmid: 10671782].
58 Buchsbaum GM, Chin M, Glantz C, et al. Prevalence of urinary incontinence and associated risk factors in a cohort of nuns. Obstet Gynecol. Aug. 2002;100(2):226-9. [pmid: 12151141].
59 Nuotio M, Jylha M, Luukkaala T, et al. Urinary incontinence in a Finnish population aged 70 and over. Prevalence of types, associated factors and self-reported treatments. Scand J Prim Health Care. Sep. 2003;21(3):182-7. [pmid: 14531512].
60 Espino DV, Palmer RF, Miles TP, et al. Prevalence and severity of urinary incontinence in elderly Mexican-American women. J Am Geriatr Soc. Nov. 2003;51(11):1580-6. [pmid: 14687387].
61 Jackson RA, Vittinghoff E, Kanaya AM, et al. Urinary incontinence in elderly women: findings from the Health, Aging, and Body Composition Study. Obstet Gynecol. Aug. 2004;104(2):301-7. [pmid: 15292003].
62 Adelmann PK. Prevalence and detection of urinary incontinence among older Medicaid recipients. J Health Care Poor Underserved. 2004;15:99-112. [pmid: 15359977].
63 Oskay UY, Beji NK, Yalcin O. A study on urogenital complaints of postmenopausal women aged 50 and over. Acta Obstet Gynecol Scand. Jan. 2005;84(1):72-8. [pmid: 15603571].
64 Jackson SL, Boyko EJ, Scholes D, et al. Predictors of urinary tract infection after menopause: a prospective study. Am J Med. Dec. 15. 2004;117(12):903-11. [pmid: 15629728].
65 Bradley CS, Kennedy CM, Nygaard IE. Pelvic floor symptoms and lifestyle factors in older women. J Womens Health (Larchmt). Mar. 2005;14(2):128-36. [pmid: 15775730].
66 Jackson SL, Scholes D, Boyko EJ, et al. Urinary incontinence and diabetes in postmenopausal women. Diabetes Care. Jul. 2005;28(7):1730-8. [pmid: 15983327].
67 Tannenbaum C, Corcos J, Assalian P. The relationship between sexual activity and urinary incontinence in older women. J Am Geriatr Soc. Aug. 2006;54(8):1220-4. [pmid: 16913988].
68 Swanson JG, Kaczorowski J, Skelly J, et al. Urinary incontinence: common problem among women over 45. Can Fam Physician. Jan. 2005;51:84-5. [pmid: 16926957].
69 Abrams P. Incontinence: 4th International Consultation on Incontinence. Paris. July 5–8, 2008. 4th ed. [Paris]. Health Publications Ltd. 2009.
70 Thom DH, Nygaard IE, Calhoun EA. Urologic diseases in America project: urinary incontinence in women-national trends in hospitalizations, office visits, treatment and economic impact. J Urol. Apr. 2005;173(4):1295-301. [pmid: 15758785].
71 Wyman JF. Management of urinary incontinence in adult ambulatory care populations. Annu Rev Nurs Res. 2000;18:171-94. [pmid: 10918936].
72 Holroyd-Leduc JM, Tannenbaum C, Thorpe KE, et al. What type of urinary incontinence does this woman have?. Jama. Mar. 26. 2008;299(12):1446-56. [pmid: 18364487].
73 Martin JL, Williams KS, Abrams KR, et al. Systematic review and evaluation of methods of assessing urinary incontinence. Health Technol Assess. Feb. 2006;10(6):1-132. iii. iv. [pmid: 16487456].
74 Goepel M, Hoffmann JA, Piro M, et al. Prevalence and physician awareness of symptoms of urinary bladder dysfunction. Eur Urol. Mar. 2002;41(3):234-9. [pmid: 12180221].
75 Davila GW, Ghoniem GM, Kapoor DS, et al. Pelvic floor dysfunction management practice patterns: a survey of members of the International Urogynecological Association. Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(5):319-25. [pmid: 12355293].
76 Teunissen D, van den Bosch W, van Weel C, et al. Urinary incontinence in the elderly: attitudes and experiences of general practitioners. A focus group study. Scand J Prim Health Care. Mar. 2006;24(1):56-61. [pmid: 16464816].
77 Wagg A, Das Gupta R, Assassa P, et al. Secondary-care treatment patterns in the UK for women with urinary incontinence. BJU Int. 2005;96:839-42. [pmid: 16153213].
78 Abrams P. Incontinence: 4th International Consultation on Incontinence. Paris. July 5–8, 2008. Health Publications Ltd. 2009. Committee 12. Adult Conservative Management.
79 Fantl JA, Newman DK, Colling J, et al. Managing acute and chronic urinary incontinence. Clinical Practice Guideline. Quick Reference Guide for Clinicians, No. 2, 1996 Update Agency for Health Care Policy and Research. January. 1996. AHCPR Publication No. 96-0686. Available at http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=hsarchive&part=A32554#A32573. Washington, DC.
80 United States Agency for Health Care Policy and Research Urinary Incontinence Guideline Panel. Urinary incontinence in adults: clinical practice guideline. Rockville, MD. US Department of Health and Human Services. 1992.
81 Thomas LH, Barrett J, Cross S, et al. Prevention and treatment of urinary incontinence after stroke in adults. Cochrane Database Syst Rev. 2005;(3):CD004462. [pmid: 16034933].
82 Shaikh S, Ong EK, Glavind K, et al. Mechanical devices for urinary incontinence in women. Cochrane Database Syst Rev. 2006;3(CD001756). [pmid: 16855977].
83 Roe B, Williams K, Palmer M. Bladder training for urinary incontinence in adults. Cochrane Database Syst Rev. 2000;(2):CD001308. [pmid: 10796768].
84 Pickard R, Reaper J, Wyness L, et al. Periurethral injection therapy for urinary incontinence in women. Cochrane Database Syst Rev. 2003;(2):CD003881. [pmid: 12804494].
85 Ostaszkiewicz J, Johnston L, Roe B. Timed voiding for the management of urinary incontinence in adults. Cochrane Database Syst Rev. 2004;(1):CD002802. [pmid: 14973993].
86 Ostaszkiewicz J, Johnston L, Roe B. Habit retraining for the management of urinary incontinence in adults. Cochrane Database Syst Rev. 2004;(2):CD002801. [pmid: 15106179].
87 Appell RA. Clinical efficacy and safety of tolterodine in the treatment of overactive bladder: a pooled analysis. Urology. Dec. 1997;50(6A Suppl):90-6. discussion 7–9. [pmid: 9426760].
88 Sand PK, Morrow JD, Bavendam T, et al. Efficacy and tolerability of fesoterodine in women with overactive bladder. Int Urogynecol J Pelvic Floor Dysfunct. Jul. 2009;20(7):827-35. [pmid: 19495545].
89 Moehrer B, Ellis G, Carey M, et al. Laparoscopic colposuspension for urinary incontinence in women. Cochrane Database Syst Rev. 2002;(1):CD002239. [pmid: 11869634].
90 Maher C, Baessler K, Glazener CM, et al. Surgical management of pelvic organ prolapse in women. Cochrane Database Syst Rev. 2004;(4):CD004014. [pmid: 15495076].
91 Lapitan MC, Cody DJ, Grant AM. Open retropubic colposuspension for urinary incontinence in women. Cochrane Database Syst Rev. 2005;(3):CD002912. [pmid: 16034879].
92 Lappin MS, Lawrie FW, Richards TL, et al. Effects of a pulsed electromagnetic therapy on multiple sclerosis fatigue and quality of life: a double-blind, placebo controlled trial. Altern Ther Health Med. Jul–Aug. 2003;9(4):38-48. [pmid: 12868251].
93 Wyman JF, Fantl JA, McClish DK, et al. Comparative efficacy of behavioral interventions in the management of female urinary incontinence. Continence Program for Women Research Group. Am J Obstet Gynecol. Oct. 1998;179(4):999-1007. [pmid: 9790388].
94 Herbison P, Plevnik S, Mantle J. Weighted vaginal cones for urinary incontinence. Cochrane Database Syst Rev. 2002;(1):CD002114. [pmid: 11869623].
95 Herbison P, Plevnik S, Mantle J. Weighted vaginal cones for urinary incontinence. Cochrane Database Syst Rev. 2000;(2):CD002114. [pmid: 10796862].
96 Hay-Smith EJ, Dumoulin C. Pelvic floor muscle training versus no treatment, or inactive control treatments, for urinary incontinence in women. Cochrane Database Syst Rev. 2006;(1):CD005654. [pmid: 16437536].
97 Hay-Smith EJ, Bo Berghmans LC, Hendriks HJ, et al. Pelvic floor muscle training for urinary incontinence in women. Cochrane Database Syst Rev. 2001;(1):CD001407. [pmid: 11279716].
98 Glazener CM, Lapitan MC. Urodynamic investigations for management of urinary incontinence in adults. Cochrane Database Syst Rev. 2002;(3):CD003195. [pmid: 12137680].
99 Glazener CM, Cooper K. Bladder neck needle suspension for urinary incontinence in women. Cochrane Database Syst Rev. 2004;(2):CD003636. [pmid: 15106209].
100 Glazener CM, Cooper K. Bladder neck needle suspension for urinary incontinence in women. Cochrane Database Syst Rev. 2002;(2):CD003636. [pmid: 12076494].
101 Glazener CM, Cooper K. Anterior vaginal repair for urinary incontinence in women. Cochrane Database Syst Rev. 2001;(1):CD001755. [pmid: 11279728].
102 Glazener CM, Cooper K. Anterior vaginal repair for urinary incontinence in women. Cochrane Database Syst Rev. 2000;(3):CD001755. [pmid: 10908510].
103 Eustice S, Roe B, Paterson J. Prompted voiding for the management of urinary incontinence in adults. Cochrane Database Syst Rev. 2000;(2):CD002113. [pmid: 10796861].
104 Dean NM, Ellis G, Wilson PD, et al. Laparoscopic colposuspension for urinary incontinence in women. Cochrane Database Syst Rev. 2006;3:CD002239. [pmid: 16855989].
105 Bezerra CA, Bruschini H, Cody DJ. Traditional suburethral sling operations for urinary incontinence in women. Cochrane Database Syst Rev. 2005;(3):CD001754. [pmid: 16034866].
106 Bezerra CA, Bruschini H. Suburethral sling operations for urinary incontinence in women. Cochrane Database Syst Rev. 2001;(3):CD001754. [pmid: 11686996].
107 Bezerra CA, Bruschini H. Suburethral sling operations for urinary incontinence in women. Cochrane Database Syst Rev. 2000;(3):CD001754. [pmid: 10908509].
108 U.S. Department of Health and Human Services, Food and Drug Administration, Center for Devices and Radiological Health, et al. Draft Guidance for Industry and FDA Staff - Clinical Investigations of Devices Indicated for the Treatment of Urinary Incontinence. Rockville, MD 20852. Food and Drug Administration. 2008. Available: http://www.fda.gov/MedicalDevices/DeviceRegulationandGuidance/GuidanceDocuments/ucm070852.htm. Accessed August 2009.
109 Coyne KS, Sexton CC, Kopp ZS, et al. The impact of overactive bladder on mental health, work productivity and health-related quality of life in the UK and Sweden: results from EpiLUTS. BJU Int. 2011. Mar. 3. [pmid: 21371240].
110 Tennstedt SL, Fitzgerald MP, Nager CW, et al. Quality of life in women with stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. May. 2007;18(5):543-9. [pmid: 17036169].
111 Coyne KS, Zhou Z, Thompson C, et al. The impact on health-related quality of life of stress, urge and mixed urinary incontinence. BJU Int. Nov. 2003;92(7):731-5. [pmid: 14616456].
112 Hartmann KE, McPheeters ML, Biller DH, et al. Treatment of overactive bladder in women. Evid Rep Technol Assess (Full Rep). Aug. 2009;(187):1-120. v. [pmid: 19947666].
113 Shamliyan TA, Kane RL, Wyman J, et al. Systematic review: randomized, controlled trials of nonsurgical treatments for urinary incontinence in women. Ann Intern Med. Mar. 18. 2008;148(6):459-73. [pmid: 18268288].
114 Pharmaceutical Research and Manufacturers of America. Solifenacin in a flexible dose regimen with tolterodine as an active comparator in a double-blind, double-dummy, randomized overactive bladder symptom trial (STAR). Available at: http://www.clinicalstudyresults.org/documents/company-study_8350_0.pdf. Accessed June 25, 2010.
115 U.S. Food and Drug Administration, Center for Drug Evaluation and Research, et al. Medical Review for Ditropan XL ( Oxybutinin Chloride) Tablets. 1998. Available at: http://www.accessdata.fda.gov/drugsatfda_docs/nda/98/20897.cfm. Accessed June 25, 2010.
116 Moehrer B, Hextall A, Jackson S. Oestrogens for urinary incontinence in women. Cochrane Database Syst Rev. 2003;(2):CD001405. [pmid: 12804406].
117 Moehrer B, Carey M, Wilson D. Laparoscopic colposuspension: a systematic review. BJOG. Mar. 2003;110(3):230-5. [pmid: 12628259].
118 National Collaborating Centre for Women’s and Children’s Health. Urinary incontinence: The management of urinary incontinence in women Commissioned by the National Institute for Health and Clinical Excellence. October. 2006. Available at: http://www.nice.org.uk/nicemedia/pdf/CG40NICEguideline.pdf.
119 Shih YC, Hartzema AG, Tolleson-Rinehart S. Labor costs associated with incontinence in long-term care facilities. Urology. Sep. 2003;62(3):442-6. [pmid: 12946743].
120 Engstrom G, Henningsohn L, Steineck G, et al. Self-assessed health, sadness and happiness in relation to the total burden of symptoms from the lower urinary tract. BJU Int. 2005;95:810-5. [pmid: 15794788].
121 Brittain KR, Shaw C. The social consequences of living with and dealing with incontinence--a carers perspective. Soc Sci Med. Sep. 2007;65(6):1274-83. [pmid: 17509743].
122 Ismail SI, Bain C, Hagen S. Oestrogens for treatment or prevention of pelvic organ prolapse in postmenopausal women. Cochrane Database Syst Rev. 2010;(9):CD007063. [pmid: 20824855].
123 Albertazzi P, Sharma S. Urogenital effects of selective estrogen receptor modulators: a systematic review. Climacteric. Sep. 2005;8(3):214-20. [pmid: 16390753].
124 Abrams P, Andersson KE. Muscarinic receptor antagonists for overactive bladder. BJU Int. Nov. 2007;100(5):987-1006. [pmid: 17922784].
125 Andersson KE. Drug therapy for urinary incontinence. Baillieres Best Pract Res Clin Obstet Gynaecol. Apr. 2000;14(2):291-313. [pmid: 10897323].
126 Chapple CR. Muscarinic receptor antagonists in the treatment of overactive bladder. Urology. May. 2000;55(5A Suppl):33-46. discussion 50. [pmid: 10767450].
127 Abramov Y, Sand PK. Oxybutynin for treatment of urge urinary incontinence and overactive bladder: an updated review. Expert Opin Pharmacother. Nov. 2004;5(11):2351-9. [pmid: 15500382].
128 Appell RA. The newer antimuscarinic drugs: bladder control with less dry mouth. Cleve Clin J Med. Oct. 5. 2002;69(10):761-6. 8. 9. [pmid: 12371799].
129 Garely AD, Burrows L. Benefit-risk assessment of tolterodine in the treatment of overactive bladder in adults. Drug Saf. 2004;27(13):1043-57. [pmid: 15471509].
130 Cartwright R, Cardozo L. Transdermal oxybutynin: sticking to the facts. Eur Urol. Apr. 2007;51(4):907-14. discussion 14. [pmid: 17157979].
131 Crandall C. Tolterodine: a clinical review. J Womens Health Gend Based Med. Oct. 2001;10(8):735-43. [pmid: 11703885].
132 Croom KF, Keating GM. Darifenacin: in the treatment of overactive bladder. Drugs Aging. 2004;21(13):885-92. discussion 93–4. [pmid: 15493952].
133 Davila GW. Transdermal oxybutynin: a new treatment for overactive bladder. Expert Opin Pharmacother. Dec. 2003;4(12):2315-24. [pmid: 14640930].
134 Robinson D, Cardozo L. Solifenacin in the management of the overactive bladder syndrome. Int J Clin Pract. Oct. 2005;59(10):1229-36. [pmid: 16178992].
135 Rovner ES. Trospium chloride in the management of overactive bladder. Drugs. 2004;64(21):2433-46. [pmid: 15482001].
136 Simpson D, Wagstaff AJ. Solifenacin in overactive bladder syndrome. Drugs Aging. 2005;22(12):1061-9. [pmid: 16363887].
137 Zinner NR. Trospium chloride: an anticholinergic quaternary ammonium compound for the treatment of overactive bladder. Expert Opin Pharmacother. Jul. 2005;6(8):1409-20. [pmid: 16013990].
138 Subak LL, Brown JS, Kraus SR, et al. The “costs” of urinary incontinence for women. Obstet Gynecol. Apr. 2006;107(4):908-16. [pmid: 16582131].
139 Papanicolaou S, Pons ME, Hampel C, et al. Medical resource utilisation and cost of care for women seeking treatment for urinary incontinence in an outpatient setting. Examples from three countries participating in the PURE study. Maturitas. Nov. 30. 2005;52(Suppl 2):S35-47. [pmid: 16297577].
140 Darkow T, Fontes CL, Williamson TE. Costs associated with the management of overactive bladder and related comorbidities. Pharmacotherapy. Apr. 2005;25(4):511-9. [pmid: 15977912].
141 Abrams P, Cardozo L, Fall M, et al. for the Standardisation Sub-Committee of the International Continence Society. The standardisation of terminology in lower urinary tract function: report from the standardisation sub-committee of the International Continence Society. Urology. 2003;61:37-49. [pmid: 12559262].
142 Schorge JO, Schaffer JI, Halvorson LM, et al. Chapter 23. Urinary Incontinence. Schorge JO, Schaffer JI, Halvorson LM, Hoffman BL, Bradshaw KD, Cunningham FG, et al., editors. Gynecology. Available at: www.accessmedicine.com/content.aspx?alD=3150435.
143 Tarnay CM, Bhatia Narender N. Chapter 45. Urinary Incontinence. DeCherney AH, Nathan L, editors. Current Diagnosis & Treatment Obstetrics & Gynecology. 10e. Available at: www.accessmedicine.com/content.aspx?aID=2390665.
144 Haylen BT, Freeman RM, Swift SE, et al. An International Urogynecological Association (IUGA)/International Continence Society (ICS) joint terminology and classification of the complications related directly to the insertion of prostheses (meshes, implants, tapes) and grafts in female pelvic floor surgery. Neurourol Urodyn. Jan. 2011;30(1):2-12. [pmid: 21181958].
145 AHCPR Urinary Incontinence in Adults Guideline Update Panel. Managing acute and chronic urinary incontinence. Am Fam Physician. 1996;54:1661-72. [pmid: 8857788].
146 Resnick NM. Urinary incontinence. Beers MH, Jones TV, Berkwits M, Kaplan JL, Rahman MI, editors. Merck Research Laboratories. The Merck manual of geriatrics [online]. Whitehouse Station, NJ. Merck & Co Inc. 2010. Available at www.merck.com/mkgr/mmg/home.jsp.
147 Higgins J, Green S. Cochrane Collaboration. Cochrane handbook for systematic reviews of interventions. Chichester, West Sussex. Hoboken NJ. John Wiley & Sons. 2008.
148 Norris S, Atkins D, Bruening W, et al. Selecting observational studies for comparing medical interventions. Agency for Healthcare Research and Quality Methods Guide for Comparative Effectiveness Reviews. 2010.
149 Agency for Healthcare Research and Quality (AHRQ). Methods Guide for Comparative Effectiveness Reviews. 2007. http://www.effectivehealthcare.ahrq.gov/healthInfo.cfm?infotype=rr&ProcessID=60. Accessed on August 2009.
150 Chou R, Aronson N, Atkins D, et al. Assessing harms when comparing medical interventions: AHRQ and the Effective Health-Care Program. J Clin Epidemiol. 2008. Sep. 25. [pmid: 18823754].
151 Whiting PF, Weswood ME, Rutjes AW, et al. Evaluation of QUADAS, a tool for the quality assessment of diagnostic accuracy studies. BMC Med Res Methodol. 2006;6:9. [pmid: 16519814].
152 Bruns DE. The STARD initiative and the reporting of studies of diagnostic accuracy. Clin Chem. Jan. 2003;49(1):19-20. [pmid: 12507955].
153 Bossuyt PM, Reitsma JB, Bruns DE, et al. Towards complete and accurate reporting of studies of diagnostic accuracy: The STARD Initiative. Ann Intern Med. Jan. 7. 2003;138(1):40-4. [pmid: 12513043].
154 Bossuyt PM, Reitsma JB. The STARD initiative. Lancet. Jan. 4. 2003;361(9351):71. [pmid: 12517476].
155 Jones R. Reporting studies of diagnostic accuracy: the STARD initiative. Fam Pract. Feb. 2004;21(1):3. [pmid: 14760035].
156 Bossuyt PM, Reitsma JB, Bruns DE, et al. Towards complete and accurate reporting of studies of diagnostic accuracy: the STARD initiative. Fam Pract. Feb. 2004;21(1):4-10. [pmid: 14760036].
157 Owens DK, Lohr KN, Atkins D, et al. Grading the strength of a body of evidence when comparing medical interventions-Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. 2009. Jul. 10. [pmid: 19595577].
158 Aschengrau A, Seage GR. Essentials of Epidemiology in Public Health. Sudbury, Mass. Jones and Bartlett. 2003.
159 Egger M, Smith GD. Bias in location and selection of studies. BMJ. Jan. 3. 1998;316(7124):61-6. [pmid: 9451274].
160 Dickersin K, Min YI. NIH clinical trials and publication bias. Online J Curr Clin Trials. 1993. Apr. 28. Doc No 50:[4967 words; 53 paragraphs]. [pmid: 8306005].
161 Higgins J, Green S. The Cochrane Collaboration. The Cochrane handbook for systematic reviews of interventions. Chichester, UK. John Wiley & Sons, Ltd. Cochrane Collaboration. 2005. Avaiable at: http://www.cochrane.org/resources/handbook/handbook.pdf2006.
162 Thornton A, Lee P. Publication bias in meta-analysis: its causes and consequences. J Clin Epidemiol. Feb. 2000;53(2):207-16. [pmid: 10729693].
163 Deeks JJ, Altman DG. Diagnostic tests 4: likelihood ratios. BMJ. Jul. 17. 2004;329(7458):168-9. [pmid: 15258077].
164 Bland JM, Altman DG. Statistical methods for assessing agreement between two methods of clinical measurement. Lancet. Feb. 8. 1986;1(8476):307-10. [pmid: 2868172].
165 Altman DG, Bland JM. Diagnostic tests 3: receiver operating characteristic plots. BMJ. Jul. 16. 1994;309(6948):188. [pmid: 8044101].
166 Methods Guide for Medical Test Reviews. Methods Guide for Medical Test Reviews. Rockville, MD. Agency for Healthcare Research and Quality. 2010.
167 Altman DG, Bland JM. Diagnostic tests 2: Predictive values. BMJ. Jul. 9. 1994;309(6947):102. [pmid: 8038641].
168 Wallace BC, Schmid CH, Lau J, et al. Meta-Analyst: software for meta-analysis of binary, continuous and diagnostic data. BMC Med Res Methodol. 2009;9:80. [pmid: 19961608].
169 Deville WL, Buntinx F, Bouter LM, et al. Conducting systematic reviews of diagnostic studies: didactic guidelines. BMC Med Res Methodol. Jul. 3. 2002;2:9. [pmid: 12097142].
170 Deeks JJ. Systematic reviews in health care: Systematic reviews of evaluations of diagnostic and screening tests. BMJ. Jul. 21. 2001;323(7305):157-62. [pmid: 11463691].
171 Whitehead A. Meta-analysis of controlled clinical trials. Chichester, New York. John Wiley & Sons. 2002.
172 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. Sep. 1986;7(3):177-88. [pmid: 3802833].
173 Fu R, Gartlehner G, Grant M, et al. Conducting Quantitative Synthesis When Comparing Medical Interventions: AHRQ and the Effective Health Care Program, Methods Guide for Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. 2010.
174 Egger M, Smith GD, Altman DG. Systematic Reviews in Health Care. London. NetLibrary, Inc. BMJ Books. 2001.
175 Ebrahim S. The use of numbers needed to treat derived from systematic reviews and meta-analysis. Caveats and pitfalls. Eval Health Prof. Jun. 2001;24(2):152-64. [pmid: 11523384].
176 Altman DG. Confidence intervals for the number needed to treat. Bmj. Nov. 7. 1998;317(7168):1309-12. [pmid: 9804726].
177 Fu R, Gartlehner G, Grant M, et al. Conducting quantitative synthesis when comparing medical interventions: AHRQ and the effective health care program. J Clin Epidemiol. 2011. Apr. 6. [pmid: 21477993].
178 Bradburn MJ, Deeks JJ, Berlin JA, et al. Much ado about nothing: a comparison of the performance of meta-analytical methods with rare events. Stat Med. Jan. 15. 2007;26(1):53-77. [pmid: 16596572].
179 Sweeting MJ, Sutton AJ, Lambert PC. What to add to nothing? Use and avoidance of continuity corrections in meta-analysis of sparse data. Stat Med. May. 15. 2004;23(9):1351-75. [pmid: 15116347].
180 Stijnen T, Hamza TH, Ozdemir P. Random effects meta-analysis of event outcome in the framework of the generalized linear mixed model with applications in sparse data. Stat Med. Dec. 20. 2010;29(29):3046-67. [pmid: 20827667].
181 Rucker G, Schwarzer G, Carpenter J, et al. Why add anything to nothing? The arcsine difference as a measure of treatment effect in meta-analysis with zero cells. Stat Med. Feb. 28. 2009;28(5):721-38. [pmid: 19072749].
182 Viechtbauer W. Confidence intervals for the amount of heterogeneity in meta-analysis. Stat Med. 2006. Feb. 6. [pmid: 16463355].
183 Knapp G, Biggerstaff BJ, Hartung J. Assessing the amount of heterogeneity in random-effects meta-analysis. Biom J. Apr. 2006;48(2):271-85. [pmid: 16708778].
184 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. Sep. 6. 2003;327(7414):557-60. [pmid: 12958120].
185 Herbison P, Hay-Smith J, Gillespie WJ. Adjustment of meta-analyses on the basis of quality scores should be abandoned. J Clin Epidemiol. Dec. 2006;59(12):1249-56. [pmid: 17098567].
186 Eastwood HD. Urodynamic studies in the management of urinary incontinence in the elderly. Age Ageing. Feb. 1979;8(1):41-8. [pmid: 443110].
187 Drutz HP, Mandel F. Urodynamic analysis of urinary incontinence symptoms in women. Am J Obstet Gynecol. Aug. 1. 1979;134(7):789-92. [pmid: 463981].
188 Farrar DJ, Whiteside CG, Osborne JL, et al. A urosynamic analysis of micturition symptoms in the female. Surg Gynecol Obstet. Dec. 1975;141(6):875-81. [pmid: 1188564].
189 Niecestro RM, Wheeler JS Jr, Nanninga J, et al. Use of stresscath for diagnosing stress incontinence. Urology. Mar. 1992;39(3):266-9. [pmid: 1546422].
190 Rosenzweig BA, Pushkin S, Blumenfeld D, et al. Prevalence of abnormal urodynamic test results in continent women with severe genitourinary prolapse. Obstet Gynecol. Apr. 1992;79(4):539-42. [pmid: 1553172].
191 De Muylder X, Claes H, Neven P, et al. Usefulness of urodynamic investigations in female incontinence. Eur J Obstet Gynecol Reprod Biol. May. 13. 1992;44(3):205-8. [pmid: 1607060].
192 Versi E, Cardozo L, Anand D, et al. Symptoms analysis for the diagnosis of genuine stress incontinence. Br J Obstet Gynaecol. Aug. 1991;98(8):815-9. [pmid: 1911591].
193 Bergman A, Bader K. Reliability of the patient’s history in the diagnosis of urinary incontinence. Int J Gynaecol Obstet. Jul. 1990;32(3):255-9. [pmid: 1972118].
194 Sand PK, Brubaker LT, Novak T. Simple standing incremental cystometry as a screening method for detrusor instability. Obstet Gynecol. Mar. 1991;77(3):453-7. [pmid: 1992416].
195 Lagro-Janssen AL, Debruyne FM, van Weel C. Value of the patient’s case history in diagnosing urinary incontinence in general practice. Br J Urol. Jun. 1991;67(6):569-72. [pmid: 2070199].
196 Lagro-Janssen TL, Smits AJ, Van Weel C. Women with urinary incontinence: self-perceived worries and general practitioners’ knowledge of problem. Br J Gen Pract. Aug. 1990;40(337):331-4. [pmid: 2121179].
197 Diokno AC, Normolle DP, Brown MB, et al. Urodynamic tests for female geriatric urinary incontinence. Urology. Nov. 1990;36(5):431-9. [pmid: 2238302].
198 Hastie KJ, Moisey CU. Are urodynamics necessary in female patients presenting with stress incontinence?. Br J Urol. Feb. 1989;63(2):155-6. [pmid: 2702401].
199 Haylen BT, Sutherst JR, Frazer MI. Is the investigation of most stress incontinence really necessary?. Br J Urol. Aug. 1989;64(2):147-9. [pmid: 2765780].
200 Sand PK, Hill RC, Ostergard DR. Incontinence history as a predictor of detrusor stability. Obstet Gynecol. Feb. 1988;71(2):257-60. [pmid: 3336562].
201 Wyman JF, Choi SC, Harkins SW, et al. The urinary diary in evaluation of incontinent women: a test-retest analysis. Obstet Gynecol. Jun. 1988;71(6 Pt 1):812-7. [pmid: 3368165].
202 Walters MD, Shields LE. The diagnostic value of history, physical examination, and the Q-tip cotton swab test in women with urinary incontinence. Am J Obstet Gynecol. Jul. 1988;159(1):145-9. [pmid: 3394734].
203 Valente S. The usefulness of urodynamics in urogynaecological disorders. Clin Exp Obstet Gynecol. 1988;15(3):102-7. [pmid: 3402082].
204 Byrne DJ, Stewart PA, Gray BK. The role of urodynamics in female urinary stress incontinence. Br J Urol. Mar. 1987;59(3):228-9. [pmid: 3567483].
205 Wyman JF, Harkins SW, Choi SC, et al. Psychosocial impact of urinary incontinence in women. Obstet Gynecol. Sep. 1987;70(3 Pt 1):378-81. [pmid: 3627585].
206 Thiede HA, Saini VD. Urogynecology: comments and caveats. Am J Obstet Gynecol. Sep. 1987;157(3):563-8. [pmid: 3631157].
207 Ouslander J, Staskin D, Raz S, et al. Clinical versus urodynamic diagnosis in an incontinent geriatric female population. J Urol. Jan. 1987;137(1):68-71. [pmid: 3795368].
208 Montz FJ, Stanton SL. Q-Tip test in female urinary incontinence. Obstet Gynecol. Feb. 1986;67(2):258-60. [pmid: 3945436].
209 Glezerman M, Glasner M, Rikover M, et al. Evaluation of reliability of history in women complaining of urinary stress incontinence. Eur J Obstet Gynecol Reprod Biol. Mar. 1986;21(3):159-64. [pmid: 3956835].
210 Versi E, Cardozo LD. Perineal pad weighing versus videographic analysis in genuine stress incontinence. Br J Obstet Gynaecol. Apr. 1986;93(4):364-6. [pmid: 3964613].
211 Bates CP, Loose H, Stanton SL. The objective study of incontinence after repair operations. Surg Gynecol Obstet. Jan. 1973;136(1):17-22. [pmid: 4682258].
212 Arnold EP, Webster JR, Loose H, et al. Urodynamics of female incontinence: factors influencing the results of surgery. Am J Obstet Gynecol. Nov. 15. 1973;117(6):805-13. [pmid: 4795646].
213 Moolgaoker AS, Ardran GM, Smith JC, et al. The diagnosis and management of urinary incontinence in the female. J Obstet Gynaecol Br Commonw. Jun. 1972;79(6):481-97. [pmid: 5064185].
214 Sutherst JR, Brown MC. Comparison of single and multichannel cystometry in diagnosing bladder instability. Br Med J (Clin Res Ed). Jun. 9. 1984;288(6432):1720-2. [pmid: 6428513].
215 Eastwood HD, Warrell R. Urinary incontinence in the elderly female: prediction in diagnosis and outcome of management. Age Ageing. Jul. 1984;13(4):230-4. [pmid: 6475652].
216 Awad SA, McGinnis RH. Factors that influence the incidence of detrusor instability in women. J Urol. Jul. 1983;130(1):114-5. [pmid: 6683325].
217 Hilton P, Stanton SL. Algorithmic method for assessing urinary incontinence in elderly women. Br Med J (Clin Res Ed). Mar. 21. 1981;282(6268):940-2. [pmid: 6781660].
218 Bent AE, Richardson DA, Ostergard DR. Diagnosis of lower urinary tract disorders in postmenopausal patients. Am J Obstet Gynecol. Jan. 15. 1983;145(2):218-22. [pmid: 6849357].
219 Cardozo LD, Stanton SL. Genuine stress incontinence and detrusor instability--a review of 200 patients. Br J Obstet Gynaecol. Mar. 1980;87(3):184-90. [pmid: 7387918].
220 Haeusler G, Hanzal E, Joura E, et al. Differential diagnosis of detrusor instability and stress-incontinence by patient history: the Gaudenz-Incontinence-Questionnaire revisited. Acta Obstet Gynecol Scand. Sep. 1995;74(8):635-7. [pmid: 7660771].
221 Swift SE, Ostergard DR. Evaluation of current urodynamic testing methods in the diagnosis of genuine stress incontinence. Obstet Gynecol. Jul. 1995;86(1):85-91. [pmid: 7784028].
222 Shumaker SA, Wyman JF, Uebersax JS, et al. Health-related quality of life measures for women with urinary incontinence: the Incontinence Impact Questionnaire and the Urogenital Distress Inventory. Continence Program in Women (CPW) Research Group. Qual Life Res. Oct. 1994;3(5):291-306. [pmid: 7841963].
223 Sandvik H, Hunskaar S, Vanvik A, et al. Diagnostic classification of female urinary incontinence: an epidemiological survey corrected for validity. J Clin Epidemiol. Mar. 1995;48(3):339-43. [pmid: 7897455].
224 Caputo RM, Benson JT. The Q-tip test and urethrovesical junction mobility. Obstet Gynecol. Dec. 1993;82(6):892-6. [pmid: 8233260].
225 Versi E, Orrego G, Hardy E, et al. Evaluation of the home pad test in the investigation of female urinary incontinence. Br J Obstet Gynaecol. Feb. 1996;103(2):162-7. [pmid: 8616134].
226 Theofrastous JP, Cundiff GW, Harris RL, et al. The effect of vesical volume on Valsalva leak-point pressures in women with genuine stress urinary incontinence. Obstet Gynecol. May. 1996;87(5 Pt 1):711-4. [pmid: 8677072].
227 Jackson S, Donovan J, Brookes S, et al. The Bristol Female Lower Urinary Tract Symptoms questionnaire: development and psychometric testing. Br J Urol. Jun. 1996;77(6):805-12. [pmid: 8705212].
228 Cundiff GW, Harris RL, Coates KW, et al. Clinical predictors of urinary incontinence in women. Am J Obstet Gynecol. Aug. 1997;177(2):262-6. discussion 6–7. [pmid: 9290438].
229 Clarke B. The role of urodynamic assessment in the diagnosis of lower urinary tract disorders. Int Urogynecol J Pelvic Floor Dysfunct. 1997;8(4):196-9. [pmid: 9449295].
230 Videla FL, Wall LL. Stress incontinence diagnosed without multichannel urodynamic studies. Obstet Gynecol. Jun. 1998;91(6):965-8. [pmid: 9611005].
231 Yoon E, Swift S. A comparison of maximum cystometric bladder capacity with maximum environmental voided volumes. Int Urogynecol J Pelvic Floor Dysfunct. 1998;9(2):78-82. [pmid: 9694135].
232 Dinokno AC, Dimaculangan RR, Lim EU, et al. Office based criteria for predicting type II stress incontinence without further evaluation studies. J Urol. Apr. 1999;161(4):1263-7. [pmid: 10081882].
233 Miller JM, Ashton-Miller JA, Carchidi LT, et al. On the lack of correlation between self-report and urine loss measured with standing provocation test in older stress-incontinent women. J Womens Health. Mar. 1999;8(2):157-62. [pmid: 10100129].
234 Lemack GE, Zimmern PE. Predictability of urodynamic findings based on the Urogenital Distress Inventory-6 questionnaire. Urology. Sep. 1999;54(3):461-6. [pmid: 10475355].
235 Chiarelli P, Brown W, McElduff P. Leaking urine: prevalence and associated factors in Australian women. Neurourol Urodyn. 1999;18(6):567-77. [pmid: 10529705].
236 James M, Jackson S, Shepherd A, et al. Pure stress leakage symptomatology: is it safe to discount detrusor instability?. Br J Obstet Gynaecol. Dec. 1999;106(12):1255-8. [pmid: 10609718].
237 Morkved S, Bo K. Prevalence of urinary incontinence during pregnancy and postpartum. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(6):394-8. [pmid: 10614977].
238 Ishiko O, Hirai K, Sumi T, et al. The urinary incontinence score in the diagnosis of female urinary incontinence. Int J Gynaecol Obstet. Feb. 2000;68(2):131-7. [pmid: 10717817].
239 Lemack GE, Zimmern PE. Identifying patients who require urodynamic testing before surgery for stress incontinence based on questionnaire information and surgical history. Urology. Apr. 2000;55(4):506-11. [pmid: 10736492].
240 Gunthorpe W, Brown W, Redman S. The development and evaluation of an incontinence screening questionnaire for female primary care. Neurourol Urodyn. 2000;19(5):595-607. [pmid: 11002302].
241 Moore KN, Jensen L. Testing of the Incontinence Impact Questionnaire (IIQ-7) with men after radical prostatectomy. J Wound Ostomy Continence Nurs. Nov. 2000;27(6):304-12. [pmid: 11096410].
242 Weidner AC, Myers ER, Visco AG, et al. Which women with stress incontinence require urodynamic evaluation?. Am J Obstet Gynecol. Jan. 2001;184(2):20-7. [pmid: 11174474].
243 Harvey MA, Kristjansson B, Griffith D, et al. The Incontinence Impact Questionnaire and the Urogenital Distress Inventory: a revisit of their validity in women without a urodynamic diagnosis. Am J Obstet Gynecol. Jul. 2001;185(1):25-31. [pmid: 11483899].
244 FitzGerald MP, Brubaker L. Urinary incontinence symptom scores and urodynamic diagnoses. Neurourol Urodyn. 2002;21(1):30-5. [pmid: 11835421].
245 Stach-Lempinen B, Kujansuu E, Laippala P, et al. Visual analogue scale, urinary incontinence severity score and 15 D--psychometric testing of three different health-related quality-of-life instruments for urinary incontinent women. Scand J Urol Nephrol. Dec. 2001;35(6):476-83. [pmid: 11848427].
246 Klingele CJ, Carley ME, Hill RF. Patient characteristics that are associated with urodynamically diagnosed detrusor instability and genuine stress incontinence. Am J Obstet Gynecol. May. 2002;186(5):866-8. [pmid: 12015497].
247 Digesu GA, Khullar V, Cardozo L, et al. Overactive bladder symptoms: do we need urodynamics?. Neurourol Urodyn. 2003;22(2):105-8. [pmid: 12579626].
248 Amarenco G, Arnould B, Carita P, et al. European psychometric validation of the CONTILIFE: a Quality of Life questionnaire for urinary incontinence. Eur Urol. Apr. 2003;43(4):391-404. [pmid: 12667721].
249 Scarpero HM, Fiske J, Xue X, et al. American Urological Association Symptom Index for lower urinary tract symptoms in women: correlation with degree of bother and impact on quality of life. Urology. Jun. 2003;61(6):1118-22. [pmid: 12809877].
250 Bump RC, Norton PA, Zinner NR, et al. Mixed urinary incontinence symptoms: urodynamic findings, incontinence severity, and treatment response. Obstet Gynecol. Jul. 2003;102(1):76-83. [pmid: 12850610].
251 Warrell DW. Investigation and Treatment of Incontinence of Urine in Women Who Have Had a Prolapse Repair Operation. Br J Urol. Apr. 1965;37:233-9. [pmid: 14282088].
252 Kulseng-Hanssen S, Borstad E. The development of a questionnaire to measure the severity of symptoms and the quality of life before and after surgery for stress incontinence. BJOG. Nov. 2003;110(11):983-8. [pmid: 14592582].
253 Khan MS, Chaliha C, Leskova L, et al. The relationship between urinary symptom questionnaires and urodynamic diagnoses: an analysis of two methods of questionnaire administration. BJOG. May. 2004;111(5):468-74. [pmid: 15104612].
254 Yalcin I, Versi E, Benson JT, et al. Validation of a clinical algorithm to diagnose stress urinary incontinence for large studies. J Urol. Jun. 2004;171(6 Pt 1):2321-5. [pmid: 15126813].
255 Homma Y, Uemura S. Use of the short form of King’s Health Questionnaire to measure quality of life in patients with an overactive bladder. BJU Int. May. 2004;93(7):1009-13. [pmid: 15142153].
256 Abdel-fattah M, Barrington JW, Youssef M. The standard 1-hour pad test: does it have any value in clinical practice?. Eur Urol. Sep. 2004;46(3):377-80. [pmid: 15306111].
257 Lin LY, Yeh NH, Lin CY, et al. Comparisons of urodynamic characteristics between female patients with overactive bladder and overactive bladder plus stress urinary incontinence. Urology. Nov. 2004;64(5):945-9. [pmid: 15533483].
258 Matharu G, Donaldson MM, McGrother CW, et al. Relationship between urinary symptoms reported in a postal questionnaire and urodynamic diagnosis. Neurourol Urodyn. 2005;24(2):100-5. [pmid: 15605372].
259 Bradley CS, Rovner ES, Morgan MA, et al. A new questionnaire for urinary incontinence diagnosis in women: development and testing. Am J Obstet Gynecol. Jan. 2005;192(1):66-73. [pmid: 15672005].
260 Massolt ET, Groen J, Vierhout ME. Application of the Blaivas-Groutz bladder outlet obstruction nomogram in women with urinary incontinence. Neurourol Urodyn. 2005;24(3):237-42. [pmid: 15747342].
261 Oh SJ, Ku JH, Hong SK, et al. Factors influencing self-perceived disease severity in women with stress urinary incontinence combined with or without urge incontinence. Neurourol Urodyn. 2005;24(4):341-7. [pmid: 15791635].
262 Lukacz ES, Lawrence JM, Buckwalter JG, et al. Epidemiology of prolapse and incontinence questionnaire: validation of a new epidemiologic survey. Int Urogynecol J Pelvic Floor Dysfunct. Jul–Aug. 2005;16(4):272-84. [pmid: 15856132].
263 Bent AE, Gousse AE, Hendrix SL, et al. Validation of a two-item quantitative questionnaire for the triage of women with urinary incontinence. Obstet Gynecol. Oct. 2005;106(4):767-73. [pmid: 16199634].
264 Coyne KS, Zyczynski T, Margolis MK, et al. Validation of an overactive bladder awareness tool for use in primary care settings. Adv Ther. Jul–Aug. 2005;22(4):381-94. [pmid: 16418145].
265 Shimabukuro T, Takahashi Y, Naito K. Lower urinary tract symptoms in 1,912 apparently healthy persons of both sexes. Hinyokika Kiyo. Mar. 2006;52(3):189-95. [pmid: 16617872].
266 Brown JS, Bradley CS, Subak LL, et al. The sensitivity and specificity of a simple test to distinguish between urge and stress urinary incontinence. Ann Intern Med. May. 16. 2006;144(10):715-23. [pmid: 16702587].
267 Nager CW, Albo ME, Fitzgerald MP, et al. Reference urodynamic values for stress incontinent women. Neurourol Urodyn. 2007;26(3):333-40. [pmid: 17315221].
268 Borup K, Hvidman L, Nielsen JB, et al. Validity of a self-administered questionnaire, with reference to a clinical stress urinary incontinence test. Scand J Urol Nephrol. 2008;42(2):148-53. [pmid: 17853006].
269 Franco AV, Lee F, Fynes MM. Is there an alternative to pad tests? Correlation of subjective variables of severity of urinary loss to the 1-h pad test in women with stress urinary incontinence. BJU Int. Aug. 5. 2008;102(5):586-90. [pmid: 18384632].
270 Lowenstein L, Kenton K, FitzGerald MP, et al. Clinically useful measures in women with mixed urinary incontinence. Am J Obstet Gynecol. Jun. 2008;198(6):664 e1-3. discussion e3–4. [pmid: 18538148].
271 Costantini E, Lazzeri M, Bini V, et al. Sensitivity and specificity of one-hour pad test as a predictive value for female urinary incontinence. Urol Int. 2008;81(2):153-9. [pmid: 18758212].
272 Stav K, Dwyer PL, Rosamilia A. Women overestimate daytime urinary frequency: the importance of the bladder diary. J Urol. May. 2009;181(5):2176-80. [pmid: 19296975].
273 Tyagi V, Hamoodi I, Yousef M, et al. How reliable is history taking in diagnosing type of urinary incontinence?. Neurourology and Urodynamics. 2010;29:1134-5.
274 Shepherd AM, Powell PH, Ball AJ. The place of urodynamic studies in the investigation and treatment of female urinary tract symptoms. J Obstet Gynaecol. 1982;3:123-5.
275 Versi E, LC, Anand D. The use of pad tests in the investigation of female urinary incontinence. J Obstet Gynecol. 1988;8:270-3.
276 Ramsay N, Ali HM, Heslington K. Can scoring the severity of symptoms help to predict the urodynamic diagnosis?. Int Urogynecol J. 1995;6:267-70.
277 Ramsay IN, Hilton P, Rice N. The symptomatic characterization of patients with destrusor instability and those with genuine stress incontinence. Int Urogynecol J. 1993;4:23-6.
278 Phua SM, Shields LE. The role of urodynamics in evaluation of incontinent females. Singapore Med J. 1992;33:139-42. [pmid: 1621116].
279 Jarvis GJ, Hall S, Stamp S, et al. An assessment of urodynamic examination in incontinent women. Br J Obstet Gynaecol. Oct. 1980;87(10):893-6. [pmid: 7426486].
280 Diokno AC, Wells TJ, Brink CA. Urinary incontinence in elderly women: urodynamic evaluation. J Am Geriatr Soc. Oct. 1987;35(10):940-6. [pmid: 3655177].
281 Korda A, Krieger M, Hunter P, et al. The value of clinical symptoms in the diagnosis of urinary incontinence in the female. Aust N Z J Obstet Gynaecol. May. 1987;27(2):149-51. [pmid: 3675441].
282 Kujansuu E, Kauppila A. Scored urological history and urethrocystometry in the differential diagnosis of female urinary incontinence. Ann Chir Gynaecol. 1982;71(4):197-202. [pmid: 6889831].
283 Sunshine T, J, Glowacki GA. Clinical correlation of urodynamic testing in patients with urinary incontinence. Journal of Gynecologic Surgery. 1989;5:93-8.
284 Cantor TJ, Bates CP. A comparative study of symptoms and objective urodynamic findings in 214 incontinent women. Br J Obstet Gynaecol. Oct. 1980;87(10):889-92. [pmid: 7191720].
285 Fischer-Rasmussen W, Hansen RI, Stage P. Predictive values of diagnostic tests in the evaluation of female urinary stress incontinence. Acta Obstet Gynecol Scand. 1986;65(4):291-4. [pmid: 3739640].
286 Bergman A, McCarthy TA, Ballard CA, et al. Role of the Q-tip test in evaluating stress urinary incontinence. J Reprod Med. Apr. 1987;32(4):273-5. [pmid: 3585870].
287 Klovning A, Hunskaar S, Eriksen BC. Validity of a scored urological history in detecting detrusor instability in female urinary incontinence. Acta Obstet Gynecol Scand. Nov. 1996;75(10):941-5. [pmid: 9003097].
288 Contreras Ortiz O, Lombardo RJ, Pellicari A. Non-invasive diagnosis of bladder instability using the Bladder Instability Discriminant Index (BIDI). Zentralbl Gynakol. 1993;115(10):446-9. [pmid: 8273434].
289 Chen GD, Su TH, Lin LY. Applicability of perineal sonography in anatomical evaluation of bladder neck in women with and without genuine stress incontinence. J Clin Ultrasound. May. 1997;25(4):189-94. [pmid: 9142618].
290 Kiilholma PJ, Makinen JI, Pitkanen YA, et al. Perineal ultrasound: an alternative for radiography for evaluating stress urinary incontinence in females. Ann Chir Gynaecol Suppl. 1994;208:43-5. [pmid: 8092770].
291 Bergman A, Ballard CA, Platt LD. Ultrasonic evaluation of urethrovesical junction in women with stress urinary incontinence. J Clin Ultrasound. Jun. 1988;16(5):295-300. [pmid: 3152386].
292 Bergman A, McKenzie CJ, Richmond J, et al. Transrectal ultrasound versus cystography in the evaluation of anatomical stress urinary incontinence. Br J Urol. Sep. 1988;62(3):228-34. [pmid: 3056562].
293 Quinn MJ, Fanrsworth BA, Pollard WJ, et al. Vaginal ultrasound in the diagnosis of stress incontinence: a prospective comparison to urodynamic investigations. Neurourol Urodyn. 1989;8:302-3.
294 Glas AS, Lijmer JG, Prins MH, et al. The diagnostic odds ratio: a single indicator of test performance. J Clin Epidemiol. Nov. 2003;56(11):1129-35. [pmid: 14615004].
295 Yalcin I, Peng G, Viktrup L, et al. Reductions in stress urinary incontinence episodes: what is clinically important for women?. Neurourol Urodyn. Mar. 2010;29(3):344-7. [pmid: 19475576].
296 Shaw C, Matthews RJ, Perry SI, et al. Validity and reliability of an interviewer-administered questionnaire to measure the severity of lower urinary tract symptoms of storage abnormality: the Leicester Urinary Symptom Questionnaire. BJU Int. Aug. 2002;90(3):205-15. [pmid: 12133054].
297 Diokno AC, Brock BM, Brown MB, et al. Prevalence of urinary incontinence and other urological symptoms in the noninstitutionalized elderly. J Urol. Nov. 1986;136(5):1022-5. [pmid: 3490584].
298 Haab F, Richard F, Amarenco G, et al. Comprehensive evaluation of bladder and urethral dysfunction symptoms: development and psychometric validation of the Urinary Symptom Profile (USP) questionnaire. Urology. Apr. 2008;71(4):646-56. [pmid: 18313122].
299 Basra R, Artibani W, Cardozo L, et al. Design and validation of a new screening instrument for lower urinary tract dysfunction: the bladder control self-assessment questionnaire (B-SAQ). Eur Urol. Jul. 2007;52(1):230-7. [pmid: 17129667].
300 Blaivas JG, Panagopoulos G, Weiss JP, et al. Validation of the overactive bladder symptom score. J Urol. Aug. 2007;178(2):543-7. discussion 7. [pmid: 17570417].
301 Pleil AM, Coyne KS, Reese PR, et al. The validation of patient-rated global assessments of treatment benefit, satisfaction, and willingness to continue--the BSW. Value Health. Nov–Dec. 2005;8(Suppl 1):S25-34. [pmid: 16336486].
302 Burgio KL, Goode PS, Richter HE, et al. Global ratings of patient satisfaction and perceptions of improvement with treatment for urinary incontinence: validation of three global patient ratings. Neurourol Urodyn. 2006;25(5):411-7. [pmid: 16652380].
303 Colman S, Chapple C, Nitti V, et al. Validation of treatment benefit scale for assessing subjective outcomes in treatment of overactive bladder. Urology. Oct. 2008;72(4):803-7. [pmid: 18722655].
304 Abrams P, Cardozo L, Khoury S, et al. Incontinence. 4th International Consultation on Incontinence. Paris. July 5–8, 2008. Paris, France. Health Publications Ltd. 2009:331-412.
305 Zellner M, Madersbacher H, Palmtag H, et al. Trospium chloride and oxybutynin hydrochloride in a german study of adults with urinary urge incontinence: results of a 12-week, multicenter, randomized, double-blind, parallel-group, flexible-dose noninferiority trial. Clin Ther. Nov. 2009;31(11):2519-39. [pmid: 20109997].
306 U.S. Food and Drug Administration, Center for Drug Evaluation and Research. Medical Review for Enablex (Clarifenacin) Extended Release Tablets. 2004. Available at: www.accessdata.fda.gov/drugsatfda_docs/nda/2004/21-513_Enablex.cfm. Accessed June 25, 2010.
307 U.S. Food and Drug Administration, Center for Drug Evaluation and Research. Statistical Review for Enablex (Darifenacin Hydrobromide) Extended Release Tablets. 2004. Available at: www.accessdata.fda.gov/drugsatfda_docs/nda/2004/21-513_Enablex.cfm. Accessed June 25, 2010.
308 Dmochowski RR, Rosenberg MT, Zinner NR, et al. Extended-release trospium chloride improves quality of life in overactive bladder. Value Health. Mar. 2010;13(2):251-7. [pmid: 19818062].
309 NCT00444925. Clinical Trial to Evaluate the Efficacy and Safety of Fesoterodine in Comparison to Tolterodine for Overactive Bladder (OAB). Available at: www.clinicaltrials.gov/ct2/show/NCT00444925?term=NCT00444925&rank=1.
310 Dmochowski RR, Nitti V, Staskin D, et al. Transdermal oxybutynin in the treatment of adults with overactive bladder: combined results of two randomized clinical trials. World J Urol. Sep. 2005;23(4):263-70. [pmid: 16151816].
311 Haab F, Stewart L, Dwyer P. Darifenacin, an M3 selective receptor antagonist, is an effective and well-tolerated once-daily treatment for overactive bladder. Eur Urol. Apr. 2004;45(4):420-9. discussion 9. [pmid: 15041104].
312 Rogers R, Bachmann G, Jumadilova Z, et al. Efficacy of tolterodine on overactive bladder symptoms and sexual and emotional quality of life in sexually active women. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2008;19(11):1551-7. [pmid: 18685795].
313 Kaplan SA, Schneider T, Foote J, et al. Superior efficacy of fesoterodine over tolterodine with rapid onset: A prospective, head-to-head, placebo-controlled trial. Neurourology and Urodynamics. 2010;29:905-7.
314 Zinner NR, Mattiasson A, Stanton SL. Efficacy, safety, and tolerability of extended-release once-daily tolterodine treatment for overactive bladder in older versus younger patients. J Am Geriatr Soc. May. 2002;50(5):799-807. [pmid: 12028164].
315 NCT00168454. A Research Study for Patients With Overactive Bladder. 2008. http://clinicaltrials.gov/ct2/show/NCT00168454.
316 Chapple C. Fesoterodine a new effective and well-tolerated antimuscarinic for the treatment of urgency-frequency syndrome:results of a phase 2 controlled study. 2004 Congress of the International Continence Society. August 25–27, 2004. Paris, France. Abstract 142. 2004.
317 Landis JR, Kaplan S, Swift S, et al. Efficacy of antimuscarinic therapy for overactive bladder with varying degrees of incontinence severity. J Urol. Feb. 2004;171(2 Pt 1):752-6. [pmid: 14713803].
318 NCT00178191. Randomized Trial for Botox Urinary Incontinence. http://www.clinicaltrials.gov/ct2/show/NCT00178191?term=NCT00178191&rank=1.
319 Cardozo L, Drutz HP, Baygani SK, et al. Pharmacological treatment of women awaiting surgery for stress urinary incontinence. Obstet Gynecol. Sep. 2004;104(3):511-9. [pmid: 15339761].
320 Junemann KP, Hessdorfer E, Unamba-Oparah I, et al. Propiverine hydrochloride immediate and extended release: comparison of efficacy and tolerability in patients with overactive bladder. Urol Int. 2006;77(4):334-9. [pmid: 17135784].
321 Rentzhog L, Stanton SL, Cardozo L, et al. Efficacy and safety of tolterodine in patients with detrusor instability: a dose-ranging study. Br J Urol. Jan. 1998;81(1):42-8. [pmid: 9467475].
322 Abrams P, Freeman R, Anderstrom C, et al. Tolterodine, a new antimuscarinic agent: as effective but better tolerated than oxybutynin in patients with an overactive bladder. Br J Urol. Jun. 1998;81(6):801-10. [pmid: 9666761].
323 MacDiarmid SA, Anderson RU, Armstrong RB, et al. Efficacy and safety of extended release oxybutynin for the treatment of urge incontinence: an analysis of data from 3 flexible dosing studies. J Urol. Oct. 2005;174(4 Pt 1):1301-5. discussion 5. [pmid: 16145407].
324 Burgio KL, Goode PS, Richter HE, et al. Combined behavioral and individualized drug therapy versus individualized drug therapy alone for urge urinary incontinence in women. J Urol. Aug. 2010;184(2):598-603. [pmid: 20639023].
325 Dmochowski RR, Sand PK, Zinner NR, et al. Trospium 60 mg once daily (QD) for overactive bladder syndrome: results from a placebo-controlled interventional study. Urology. Mar. 2008;71(3):449-54. [pmid: 18342185].
326 Ozdedeli S, Karapolat H, Akkoc Y. Comparison of intravaginal electrical stimulation and trospium hydrochloride in women with overactive bladder syndrome: a randomized controlled study. Clin Rehabil. Apr. 2010;24(4):342-51. [pmid: 20212061].
327 U.S. Food and Drug Administration, Center for Drug Evaluation and Research. Medical Review for Sanctura (Trospium Chloride) Tablets. 2004. http://www.accessdata.fda.gov/drugsatfda_docs/nda/2004/21-595_Sanctura.cfm. Accessed on June 25 2010.
328 U.S. Food and Drug Administration, Center for Drug Evaluation and Research. Statistical Review for Sanctura (Trospium Chloride) Tablets. 2004. http://www.accessdata.fda.gov/drugsatfda_docs/nda/2004/21-595_Sanctura.cfm. Accessed on June 25 2010.
329 U.S. Food and Drug Administration, Center for Drug Evaluation and Research. Medical Review for Sanctura XR (Trospium Chloride) Extended Release Capsules. 2007. http://www.accessdata.fda.gov/drugsatfda_docs/nda/2007/022103s000TOC.cfm. Accessed on June 25 2010.
330 U.S. Food and Drug Administration, Center for Drug Evaluation and Research. Statistical Review for Sanctura XR (Trospium Chloride) Extended Release Capsules. 2007. http://www.accessdata.fda.gov/drugsatfda_docs/nda/2007/022103s000TOC.cfm. Accessed on June 25 2010.
331 Yalcin I, Bump RC. Validation of two global impression questionnaires for incontinence. Am J Obstet Gynecol. Jul. 2003;189(1):98-101. [pmid: 12861145].
332 Black N, Griffiths J, Pope C. Development of a symptom severity index and a symptom impact index for stress incontinence in women. Neurourol Urodyn. 1996;15(6):630-40. [pmid: 8916115].
333 Matza LS, Thompson CL, Krasnow J, et al. Test-retest reliability of four questionnaires for patients with overactive bladder: the overactive bladder questionnaire (OAB-q), patient perception of bladder condition (PPBC), urgency questionnaire (UQ), and the primary OAB symptom questionnaire (POSQ). Neurourol Urodyn. 2005;24(3):215-25. [pmid: 15747340].
334 Sandvik H, Hunskaar S, Seim A, et al. Validation of a severity index in female urinary incontinence and its implementation in an epidemiological survey. J Epidemiol Community Health. Dec. 1993;47(6):497-9. [pmid: 8120507].
335 Sandvik H, Seim A, Vanvik A, et al. A severity index for epidemiological surveys of female urinary incontinence: comparison with 48-hour pad-weighing tests. Neurourol Urodyn. 2000;19(2):137-45. [pmid: 10679830].
336 Uebersax JS, Wyman JF, Shumaker SA, et al. Short forms to assess life quality and symptom distress for urinary incontinence in women: the Incontinence Impact Questionnaire and the Urogenital Distress Inventory. Continence Program for Women Research Group. Neurourol Urodyn. 1995;14(2):131-9. [pmid: 7780440].
337 Barber MD, Spino C, Janz NK, et al. The minimum important differences for the urinary scales of the Pelvic Floor Distress Inventory and Pelvic Floor Impact Questionnaire. Am J Obstet Gynecol. May. 2009;200(5):580 e1-7. [pmid: 19375574].
338 Coyne KS, Matza LS, Kopp Z, et al. The validation of the patient perception of bladder condition (PPBC): a single-item global measure for patients with overactive bladder. Eur Urol. Jun. 2006;49(6):1079-86. [pmid: 16460875].
339 Capo JP Jr, Laramee C, Lucente V, et al. Solifenacin treatment for overactive bladder in Hispanic patients: patient-reported symptom bother and quality of life outcomes from the VESIcare Open-Label Trial. Int J Clin Pract. Jan. 2008;62(1):39-46. [pmid: 18036164].
340 Holtedahl K, Verelst M, Schiefloe A, et al. Usefulness of urodynamic examination in female urinary incontinence--lessons from a population-based, randomized, controlled study of conservative treatment. Scand J Urol Nephrol. Jun. 2000;34(3):169-74. [pmid: 10961470].
341 Majumdar A, Latthe P, Toozs-Hobson P. Urodynamics prior to treatment as an intervention: a pilot study. Neurourol Urodyn. Apr. 2010;29(4):522-6. [pmid: 19731310].
342 Nitti VW, Rovner ES, Bavendam T. Response to fesoterodine in patients with an overactive bladder and urgency urinary incontinence is independent of the urodynamic finding of detrusor overactivity. BJU Int. May. 2010;105(9):1268-75. [pmid: 19889062].
343 Malone-Lee JG, Al-Buheissi S. Does urodynamic verification of overactive bladder determine treatment success? Results from a randomized placebo-controlled study. BJU Int. Apr. 2009;103(7):931-7. [pmid: 19281469].
344 Malone-Lee J, Henshaw DJ, Cummings K. Urodynamic verification of an overactive bladder is not a prerequisite for antimuscarinic treatment response. BJU Int. Sep. 2003;92(4):415-7. [pmid: 12930431].
345 Agur W, Housami F, Drake M, et al. Could the National Institute for Health and Clinical Excellence guidelines on urodynamics in urinary incontinence put some women at risk of a bad outcome from stress incontinence surgery?. BJU international. Mar. 2009;103(5):635-9. [pmid: 19021606].
346 Impact of increased abdominal pressure during micturition on inguinal hernia development after radical prostatectomy: Analysis in pressure flow study. Joint Annual Meeting of the International Continence Society and International Urogynecological Association. 23–27 August, 2010. Toronto, Canada. 2010. Toronto, Canada.
347 Summitt RL Jr, Stovall TG, Bent AE, et al. Urinary incontinence: correlation of history and brief office evaluation with multichannel urodynamic testing. Am J Obstet Gynecol. Jun. 1992;166(6 Pt 1):1835-40. discussion 40–4. [pmid: 1615993].
348 Griffiths DJ, McCracken PN, Harrison GM, et al. Characteristics of urinary incontinence in elderly patients studied by 24-hour monitoring and urodynamic testing. Age Ageing. May. 1992;21(3):195-201. [pmid: 1615782].
349 Minimum important difference for validated instruments in women with urgency incontinence. Neurourology and Urodynamics; 2010; Joint Meeting of the International Continence Society and the International Urogynecological Association. Toronto, Canada. 23–27 August 2010. 29.
350 Brookes ST, Donovan JL, Wright M, et al. A scored form of the Bristol Female Lower Urinary Tract Symptoms questionnaire: data from a randomized controlled trial of surgery for women with stress incontinence. Am J Obstet Gynecol. Jul. 2004;191(1):73-82. [pmid: 15295345].
351 Reid FM, Smith AR, Dunn G. Which questionnaire? A psychometric evaluation of three patient-based outcome measures used to assess surgery for stress urinary incontinence. Neurourol Urodyn. 2007;26(1):123-8. [pmid: 16998861].
352 Abdel-Fattah M, Ramsay I, Barrington JW. A simple visual analogue scale to assess the quality of life in women with urinary incontinence. Eur J Obstet Gynecol Reprod Biol. Jul. 2007;133(1):86-9. [pmid: 16797114].
353 Avery K, Donovan J, Peters TJ, et al. ICIQ: a brief and robust measure for evaluating the symptoms and impact of urinary incontinence. Neurourol Urodyn. 2004;23(4):322-30. [pmid: 15227649].
354 Klovning A, Avery K, Sandvik H, et al. Comparison of two questionnaires for assessing the severity of urinary incontinence: The ICIQ-UI SF versus the incontinence severity index. Neurourol Urodyn. 2009;28(5):411-5. [pmid: 19214996].
355 Stothers L. Reliability, validity, and gender differences in the quality of life index of the SEAPI-QMM incontinence classification system. Neurourol Urodyn. 2004;23(3):223-8. [pmid: 15098217].
356 Rai GS, Kiniors M, Wientjes H. Urinary incontinence handicap inventory. Arch Gerontol Geriatr. Jul–Aug. 1994;19(1):7-10. [pmid: 15374289].
357 Hagen S, Hanley J, Capewell A. Test-retest reliability, validity, and sensitivity to change of the urogenital distress inventory and the incontinence impact questionnaire. Neurourol Urodyn. 2002;21(6):534-9. [pmid: 12382243].
358 Bjelic-Radisic V, Dorfer M, Tamussino K, et al. The Incontinence Outcome Questionnaire: an instrument for assessing patient-reported outcomes after surgery for stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Oct. 2007;18(10):1139-49. [pmid: 17308862].
359 Patrick DL, Martin ML, Bushnell DM, et al. Quality of life of women with urinary incontinence: further development of the incontinence quality of life instrument (I-QOL). Urology. Jan. 1999;53(1):71-6. [pmid: 9886591].
360 Bushnell DM, Martin ML, Summers KH, et al. Quality of life of women with urinary incontinence: cross-cultural performance of 15 language versions of the I-QOL. Qual Life Res. Oct. 2005;14(8):1901-13. [pmid: 16155777].
361 Wagner TH, Patrick DL, Bavendam TG, et al. Quality of life of persons with urinary incontinence: development of a new measure. Urology. Jan. 1996;47(1):67-71. discussion-2. [pmid: 8560665].
362 Oh SJ, Ku JH. Comparison of three disease-specific quality-of-life questionnaires (Bristol Female Lower Urinary Tract Symptoms, Incontinence Quality of Life and King’s Health Questionnaire) in women with stress urinary incontinence. Scand J Urol Nephrol. 2007;41(1):66-71. [pmid: 17366105].
363 Schurch B, Denys P, Kozma CM, et al. Reliability and validity of the Incontinence Quality of Life questionnaire in patients with neurogenic urinary incontinence. Arch Phys Med Rehabil. May. 2007;88(5):646-52. [pmid: 17466735].
364 Yalcin I, Patrick DL, Summers K, et al. Minimal clinically important differences in Incontinence Quality-of-Life scores in stress urinary incontinence. Urology. Jun. 2006;67(6):1304-8. [pmid: 16750246].
365 Hollingworth W, Campbell JD, Kowalski J, et al. Exploring the impact of changes in neurogenic urinary incontinence frequency and condition-specific quality of life on preference-based outcomes. Qual Life Res. Apr. 2010;19(3):323-31. [pmid: 20094804].
366 Kelleher CJ, Cardozo LD, Khullar V, et al. A new questionnaire to assess the quality of life of urinary incontinent women. Br J Obstet Gynaecol. Dec. 1997;104(12):1374-9. [pmid: 9422015].
367 Reese PR, Pleil AM, Okano GJ, et al. Multinational study of reliability and validity of the King’s Health Questionnaire in patients with overactive bladder. Qual Life Res. Jun. 2003;12(4):427-42. [pmid: 12797715].
368 Sand P, Zinner N, Newman D, et al. Oxybutynin transdermal system improves the quality of life in adults with overactive bladder: a multicentre, community-based, randomized study. BJU Int. Apr. 2007;99(4):836-44. [pmid: 17187655].
369 Kelleher CJ, Pleil AM, Reese PR, et al. How much is enough and who says so?. BJOG. Jun. 2004;111(6):605-12. [pmid: 15198790].
370 Can the patient global impression of improvement questionnaire predict the results of long quality of life and sexual function questionnaires?. Neurourology and Urodynamics; 2010; Joint Meeting of the International Continence Society and the International Urogynecological Association. Toronto, Canada. 23–27 August 2010. 29.
371 Shaw C, Matthews RJ, Perry SI, et al. Validity and reliability of a questionnaire to measure the impact of lower urinary tract symptoms on quality of life: the Leicester Impact Scale. Neurourol Urodyn. 2004;23(3):229-36. [pmid: 15098218].
372 Coyne K, Revicki D, Hunt T, et al. Psychometric validation of an overactive bladder symptom and health-related quality of life questionnaire: the OAB-q. Qual Life Res. Sep. 2002;11(6):563-74. [pmid: 12206577].
373 Coyne KS, Matza LS, Thompson CL, et al. Determining the importance of change in the overactive bladder questionnaire. J Urol. Aug. 2006;176(2):627-32. discussion 32. [pmid: 16813906].
374 Rogers RG, Kammerer-Doak D, Villarreal A, et al. A new instrument to measure sexual function in women with urinary incontinence or pelvic organ prolapse. Am J Obstet Gynecol. Mar. 2001;184(4):552-8. [pmid: 11262452].
375 Hendriks EJ, Bernards AT, Berghmans BC, et al. The psychometric properties of the PRAFAB-questionnaire: a brief assessment questionnaire to evaluate severity of urinary incontinence in women. Neurourol Urodyn. 2007;26(7):998-1007. [pmid: 17563109].
376 Hendriks EJ, Bernards AT, de Bie RA, et al. The minimal important change of the PRAFAB questionnaire in women with stress urinary incontinence: results from a prospective cohort study. Neurourol Urodyn. 2008;27(5):379-87. [pmid: 18288703].
377 Hendriks EJ, Bernards AT, Staal JB, et al. Factorial validity and internal consistency of the PRAFAB questionnaire in women with stress urinary incontinence. BMC Urol. 2008;8:1. [pmid: 18218110].
378 Lee PS, Reid DW, Saltmarche A, et al. Measuring the psychosocial impact of urinary incontinence: the York Incontinence Perceptions Scale (YIPS). J Am Geriatr Soc. Nov. 1995;43(11):1275-8. [pmid: 7594164].
379 Holtedahl K, Verelst M, Schiefloe A. A population based, randomized, controlled trial of conservative treatment for urinary incontinence in women. Acta Obstet Gynecol Scand. Jul. 1998;77(6):671-7. [pmid: 9688247].
380 Dessole S, Rubattu G, Ambrosini G, et al. Efficacy of low-dose intravaginal estriol on urogenital aging in postmenopausal women. Menopause. Jan–Feb. 2004;11(1):49-56. [pmid: 14716182].
381 Waetjen LE, Brown JS, Vittinghoff E, et al. The effect of ultralow-dose transdermal estradiol on urinary incontinence in postmenopausal women. Obstet Gynecol. Nov. 2005;106(5 Pt 1):946-52. [pmid: 16260511].
382 Rufford J, Hextall A, Cardozo L, et al. A double-blind placebo-controlled trial on the effects of 25 mg estradiol implants on the urge syndrome in postmenopausal women. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2003;14(2):78-83. [pmid: 12851747].
383 Schagen van Leeuwen JH, Lange RR, Jonasson AF, et al. Efficacy and safety of duloxetine in elderly women with stress urinary incontinence or stress-predominant mixed urinary incontinence. Maturitas. Jun. 20. 2008;60(2):138-47. [pmid: 18547757].
384 Millard RJ, Moore K, Rencken R, et al. Duloxetine vs placebo in the treatment of stress urinary incontinence: a four-continent randomized clinical trial. BJU Int. Feb. 2004;93(3):311-8. [pmid: 14764128].
385 Steers WD, Herschorn S, Kreder KJ, et al. Duloxetine compared with placebo for treating women with symptoms of overactive bladder. BJU Int. Aug. 2007;100(2):337-45. [pmid: 17511767].
386 Lin AT, Sun MJ, Tai HL, et al. Duloxetine versus placebo for the treatment of women with stress predominant urinary incontinence in Taiwan: a double-blind, randomized, placebo-controlled trial. BMC Urol. 2008;8:2. [pmid: 18221532].
387 Cardozo L, Lange R, Voss S, et al. Short- and long-term efficacy and safety of duloxetine in women with predominant stress urinary incontinence. Curr Med Res Opin. Feb. 2010;26(2):253-61. [pmid: 19929591].
388 Weinstein DL, Cohen JS, Liu C, et al. Duloxetine in the treatment of women with stress urinary incontinence: results from DESIRE (Duloxetine Efficacy and Safety for Incontinence in Racial and Ethnic populations). Curr Med Res Opin. Nov. 2006;22(11):2121-9. [pmid: 17076972].
389 Castro-Diaz D, Palma PC, Bouchard C, et al. Effect of dose escalation on the tolerability and efficacy of duloxetine in the treatment of women with stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Aug. 2007;18(8):919-29. [pmid: 17160693].
390 Norton PA, Zinner NR, Yalcin I, et al. Duloxetine versus placebo in the treatment of stress urinary incontinence. Am J Obstet Gynecol. Jul. 2002;187(1):40-8. [pmid: 12114886].
391 Dmochowski RR, Miklos JR, Norton PA, et al. Duloxetine versus placebo for the treatment of North American women with stress urinary incontinence. J Urol. Oct. 2003;170(4 Pt 1):1259-63. [pmid: 14501737].
392 van Kerrebroeck P, Abrams P, Lange R, et al. Duloxetine versus placebo in the treatment of European and Canadian women with stress urinary incontinence. BJOG. Mar. 2004;111(3):249-57. [pmid: 14961887].
393 Ghoniem GM, Van Leeuwen JS, Elser DM, et al. A randomized controlled trial of duloxetine alone, pelvic floor muscle training alone, combined treatment and no active treatment in women with stress urinary incontinence. J Urol. May. 2005;173(5):1647-53. [pmid: 15821528].
394 Duckett JR, Vella M, Kavalakuntla G, et al. Tolerability and efficacy of duloxetine in a nontrial situation. BJOG: An International Journal of Obstetrics & Gynaecology. May. 2007;114(5):543-7. [pmid: 17355360].
395 Vella M, Duckett J, Basu M. Duloxetine 1 year on: the long-term outcome of a cohort of women prescribed duloxetine. Int Urogynecol J Pelvic Floor Dysfunct. Jul. 2008;19(7):961-4. [pmid: 18231697].
396 Yalcin I, Bump RC. The effect of previous treatment experience and incontinence severity on the placebo response of stress urinary incontinence. Am J Obstet Gynecol. Jul. 2004;191(1):194-7. [pmid: 15295364].
397 Hurley DJ, Turner CL, Yalcin I, et al. Duloxetine for the treatment of stress urinary incontinence in women: an integrated analysis of safety. Eur J Obstet Gynecol Reprod Biol. Mar. 1. 2006;125(1):120-8. [pmid: 16188367].
398 Viktrup L, Yalcin I. Duloxetine treatment of stress urinary incontinence in women: effects of demographics, obesity, chronic lung disease, hypoestrogenism, diabetes mellitus, and depression on efficacy. Eur J Obstet Gynecol Reprod Biol. Jul. 2007;133(1):105-13. [pmid: 16769171].
399 Gahimer J, Wernicke J, Yalcin I, et al. A retrospective pooled analysis of duloxetine safety in 23,983 subjects. Curr Med Res Opin. Jan. 2007;23(1):175-84. [pmid: 17257478].
400 Bump RC, Voss S, Beardsworth A, et al. Long-term efficacy of duloxetine in women with stress urinary incontinence. BJU Int. Jul. 2008;102(2):214-8. [pmid: 18422764].
401 Kinchen KS, Obenchain R, Swindle R. Impact of duloxetine on quality of life for women with symptoms of urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Sep–Oct. 2005;16(5):337-44. [pmid: 15662490].
402 Bent AE, Gousse AE, Hendrix SL, et al. Duloxetine compared with placebo for the treatment of women with mixed urinary incontinence. Neurourol Urodyn. 2008;27(3):212-21. [pmid: 17580357].
403 Wernick JE, Lledo A, Raskin J, et al. An evaluation of the cardiovascular safety profile of duloxetine: findings from 42 placebo-controlled studies. Drug Saf. 2007;30(5):437-55. [pmid: 17472422].
404 Brunton S, Wang F, Edwards SB, et al. Profile of adverse events with duloxetine treatment: a pooled analysis of placebo-controlled studies. Drug Saf. May. 1. 2010;33(5):393-407. [pmid: 20397739].
405 Tapp AJ, Cardozo LD, Versi E, et al. The treatment of detrusor instability in post-menopausal women with oxybutynin chloride: a double blind placebo controlled study. Br J Obstet Gynaecol. Jun. 1990;97(6):521-6. [pmid: 2198921].
406 Szonyi G, Collas DM, Ding YY, et al. Oxybutynin with bladder retraining for detrusor instability in elderly people: a randomized controlled trial. Age Ageing. 1995/07/01 ed. 1995:287-91.
407 Burgio KL, Locher JL, Roth DL, et al. Psychological improvements associated with behavioral and drug treatment of urge incontinence in older women. J Gerontol B Psychol Sci Soc Sci. Jan. 2001;56(1):P46-51. [pmid: 11192337].
408 Chancellor MB, Appell RA, Sathyan G, et al. A comparison of the effects on saliva output of oxybutynin chloride and tolterodine tartrate. Clin Ther. May. 2001;23(5):753-60. [pmid: 11394733].
409 Lehtoranta K, Tainio H, Lukkari-Lax E, et al. Pharmacokinetics, efficacy, and safety of intravesical formulation of oxybutynin in patients with detrusor overactivity. Scand J Urol Nephrol. Feb. 2002;36(1):18-24. [pmid: 12002352].
410 Dmochowski RR, Davila GW, Zinner NR, et al. Efficacy and safety of transdermal oxybutynin in patients with urge and mixed urinary incontinence. J Urol. Aug. 2002;168(2):580-6. [pmid: 12131314].
411 Dmochowski RR, Sand PK, Zinner NR, et al. Comparative efficacy and safety of transdermal oxybutynin and oral tolterodine versus placebo in previously treated patients with urge and mixed urinary incontinence. Urology. Aug. 2003;62(2):237-42. [pmid: 12893326].
412 Lackner TE, Wyman JF, McCarthy TC, et al. Randomized, placebo-controlled trial of the cognitive effect, safety, and tolerability of oral extended-release oxybutynin in cognitively impaired nursing home residents with urge urinary incontinence. J Am Geriatr Soc. May. 2008;56(5):862-70. [pmid: 18410326].
413 Staskin DR, Dmochowski RR, Sand PK, et al. Efficacy and safety of oxybutynin chloride topical gel for overactive bladder: a randomized, double-blind, placebo controlled, multicenter study. J Urol. Apr. 2009;181(4):1764-72. [pmid: 19233423].
414 Wang AC, Chen MC, Kuo WY, et al. Urgency-free time interval as primary endpoint for evaluating the outcome of a randomized OAB treatment. Int Urogynecol J Pelvic Floor Dysfunct. Jul. 2009;20(7):819-25. [pmid: 19495544].
415 Thuroff JW, Bunke B, Ebner A, et al. Randomized, double-blind, multicenter trial on treatment of frequency, urgency and incontinence related to detrusor hyperactivity: oxybutynin versus propantheline versus placebo. J Urol. Apr. 1991;145(4):813-6. discussion 6–7. [pmid: 2005707].
416 Moore KH, Hay DM, Imrie AE, et al. Oxybutynin hydrochloride (3 mg) in the treatment of women with idiopathic detrusor instability. Br J Urol. Nov. 1990;66(5):479-85. [pmid: 2249115].
417 Enzelsberger H, Helmer H, Kurz C. Intravesical instillation of oxybutynin in women with idiopathic detrusor instability: a randomised trial. Br J Obstet Gynaecol. Nov. 1995;102(11):929-30. [pmid: 8534633].
418 Johnson TM 2nd, Burgio KL, Redden DT, et al. Effects of behavioral and drug therapy on nocturia in older incontinent women. J Am Geriatr Soc. May. 2005;53(5):846-50. [pmid: 15877562].
419 Anderson RU, Mobley D, Blank B, et al. Once daily controlled versus immediate release oxybutynin chloride for urge urinary incontinence. OROS Oxybutynin Study Group J Urol. Jun. 1999;161(6):1809-12. [pmid: 10332441].
420 Gupta SK, Sathyan G, Lindemulder EA, et al. Quantitative characterization of therapeutic index: application of mixed-effects modeling to evaluate oxybutynin dose-efficacy and dose-side effect relationships. Clin Pharmacol Ther. Jun. 1999;65(6):672-84. [pmid: 10391673].
421 Tincello DG, Adams EJ, Sutherst JR, et al. Oxybutynin for detrusor instability with adjuvant salivary stimulant pastilles to improve compliance: results of a multicentre, randomized controlled trial. BJU Int. Mar. 2000;85(4):416-20. [pmid: 10691817].
422 Versi E, Appell R, Mobley D, et al. Dry mouth with conventional and controlled-release oxybutynin in urinary incontinence. The Ditropan XL Study Group. Obstet Gynecol. May. 2000;95(5):718-21. [pmid: 10775736].
423 Davila GW, Daugherty CA, Sanders SW. A short-term, multicenter, randomized double-blind dose titration study of the efficacy and anticholinergic side effects of transdermal compared to immediate release oral oxybutynin treatment of patients with urge urinary incontinence. J Urol. Jul. 2001;166(1):140-5. [pmid: 11435842].
424 Barkin J, Corcos J, Radomski S, et al. A randomized, double-blind, parallel-group comparison of controlled- and immediate-release oxybutynin chloride in urge urinary incontinence. Clin Ther. Jul. 2004;26(7):1026-36. [pmid: 15336467].
425 Preik M, Albrecht D, O’Connell M, et al. Effect of controlled-release delivery on the pharmacokinetics of oxybutynin at different dosages: severity-dependent treatment of the overactive bladder. BJU Int. Oct. 2004;94(6):821-7. [pmid: 15476516].
426 Salvatore S, Khullar V, Cardozo L, et al. Long-term prospective randomized study comparing two different regimens of oxybutynin as a treatment for detrusor overactivity. Eur J Obstet Gynecol Reprod Biol. Apr. 1. 2005;119(2):237-41. [pmid: 15808387].
427 Corcos J, Casey R, Patrick A, et al. A double-blind randomized dose-response study comparing daily doses of 5, 10 and 15 mg controlled-release oxybutynin: balancing efficacy with severity of dry mouth. BJU Int. Mar. 2006;97(3):520-7. [pmid: 16469019].
428 Sand PK, Goldberg RP, Dmochowski RR, et al. The impact of the overactive bladder syndrome on sexual function: a preliminary report from the Multicenter Assessment of Transdermal Therapy in Overactive Bladder with Oxybutynin trial. Am J Obstet Gynecol. Dec. 2006;195(6):1730-5. [pmid: 17132474].
429 Gleason DM, Susset J, White C, et al. Evaluation of a new once-daily formulation of oxbutynin for the treatment of urinary urge incontinence. Ditropan XL Study Group. Urology. Sep. 1999;54(3):420-3. [pmid: 10475346].
430 Newman DK. The MATRIX study: assessment of health-related quality of life in adults with the use of transdermal oxybutynin. Director. Winter. 2008;16(1):22-5. [pmid: 19343871].
431 Pizzi LT, Talati A, Gemmen E, et al. Impact of transdermal oxybutynin on work productivity in patients with overactive bladder: results from the MATRIX study. Pharmacoeconomics. 2009;27(4):329-39. [pmid: 19485428].
432 Hussain RM, Hartigan-Go K, Thomas SH, et al. Effect of oxybutynin on the QTc interval in elderly patients with urinary incontinence. Br J Clin Pharmacol. Jan. 1996;41(1):73-5. [pmid: 8824696].
433 Nilsson CG, Lukkari E, Haarala M, et al. Comparison of a 10-mg controlled release oxybutynin tablet with a 5-mg oxybutynin tablet in urge incontinent patients. Neurourol Urodyn. 1997;16(6):533-42. [pmid: 9353802].
434 Bemelmans BL, Kiemeney LA, Debruyne FM. Low-dose oxybutynin for the treatment of urge incontinence: good efficacy and few side effects. Eur Urol. Jun. 2000;37(6):709-13. [pmid: 10828672].
435 Radomski SB, Caley B, Reiz JL, et al. Preliminary evaluation of a new controlled-release oxybutynin in urinary incontinence. Curr Med Res Opin. 2004;20(2):249-53. [pmid: 15006020].
436 Diokno A, Sand P, Labasky R, et al. Long-term safety of extended-release oxybutynin chloride in a community-dwelling population of participants with overactive bladder: a one-year study. Int Urol Nephrol. 2002;34(1):43-9. [pmid: 12549638].
437 Burgio KL, Locher JL, Goode PS, et al. Behavioral vs drug treatment for urge urinary incontinence in older women: a randomized controlled trial. JAMA. Dec. 16. 1998;280(23):1995-2000. [pmid: 9863850].
438 Goode PS. Behavioral and drug therapy for urinary incontinence. Urology. Mar. 2004;63(3 Suppl 1):58-64. [pmid: 15013654].
439 Madersbacher H, Halaska M, Voigt R, et al. A placebo-controlled, multicentre study comparing the tolerability and efficacy of propiverine and oxybutynin in patients with urgency and urge incontinence. BJU Int. Oct. 1999;84(6):646-51. [pmid: 10510109].
440 Goode PS, Burgio KL, Locher JL, et al. Urodynamic changes associated with behavioral and drug treatment of urge incontinence in older women. J Am Geriatr Soc. May. 2002;50(5):808-16. [pmid: 12028165].
441 Homma Y, Paick JS, Lee JG, et al. Clinical efficacy and tolerability of extended-release tolterodine and immediate-release oxybutynin in Japanese and Korean patients with an overactive bladder: a randomized, placebo-controlled trial. BJU Int. Nov. 2003;92(7):741-7. [pmid: 14616458].
442 Homma Y, Kawabe K. Health-related quality of life of Japanese patients with overactive bladder treated with extended-release tolterodine or immediate-release oxybutynin: a randomized, placebo-controlled trial. World J Urol. Oct. 2004;22(4):251-6. [pmid: 15455256].
443 Wang AC, Chih SY, Chen MC. Comparison of electric stimulation and oxybutynin chloride in management of overactive bladder with special reference to urinary urgency: a randomized placebo-controlled trial. Urology. Nov. 2006;68(5):999-1004. [pmid: 17113893].
444 Homma Y, Koyama N. Minimal clinically important change in urinary incontinence detected by a quality of life assessment tool in overactive bladder syndrome with urge incontinence. Neurourol Urodyn. 2006;25(3):228-35. [pmid: 16532466].
445 Cartwright R, Srikrishna S, Cardozo L, et al. Patient-selected goals in overactive bladder: a placebo controlled randomized double-blind trial of transdermal oxybutynin for the treatment of urgency and urge incontinence. BJU Int. Jan. 2011;107(1):70-6. [pmid: 20626389].
446 Zinner N, Tuttle J, Marks L. Efficacy and tolerability of darifenacin, a muscarinic M3 selective receptor antagonist (M3 SRA), compared with oxybutynin in the treatment of patients with overactive bladder. World J Urol. Sep. 2005;23(4):248-52. [pmid: 16096831].
447 Gupta SK, Sathyan G. Pharmacokinetics of an oral once-a-day controlled-release oxybutynin formulation compared with immediate-release oxybutynin. J Clin Pharmacol. Mar. 1999;39(3):289-96. [pmid: 10073329].
448 Millard R, Tuttle J, Moore K, et al. Clinical efficacy and safety of tolterodine compared to placebo in detrusor overactivity. J Urol. May. 1999;161(5):1551-5. [pmid: 10210394].
449 Jonas U, Hofner K, Madersbacher H, et al. Efficacy and safety of two doses of tolterodine versus placebo in patients with detrusor overactivity and symptoms of frequency, urge incontinence, and urgency: urodynamic evaluation. The International Study Group. World J Urol. 1997;15(2):144-51. [pmid: 9144906].
450 Drutz HP, Appell RA, Gleason D, et al. Clinical efficacy and safety of tolterodine compared to oxybutynin and placebo in patients with overactive bladder. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(5):283-9. [pmid: 10543335].
451 Van Kerrebroeck P, Kreder K, Jonas U, et al. Tolterodine once-daily: superior efficacy and tolerability in the treatment of the overactive bladder. Urology. Mar. 2001;57(3):414-21. [pmid: 11248608].
452 Malone-Lee JG, Walsh JB, Maugourd MF. Tolterodine: a safe and effective treatment for older patients with overactive bladder. J Am Geriatr Soc. Jun. 2001;49(6):700-5. [pmid: 11454106].
453 Jacquetin B, Wyndaele J. Tolterodine reduces the number of urge incontinence episodes in patients with an overactive bladder. Eur J Obstet Gynecol Reprod Biol. Sep. 2001;98(1):97-102. [pmid: 11516807].
454 Kelleher CJ, Reese PR, Pleil AM, et al. Health-related quality of life of patients receiving extended-release tolterodine for overactive bladder. The American journal of managed care. 2002:S608-15. [pmid: 12516955].
455 Swift S, Garely A, Dimpfl T, et al. A new once-daily formulation of tolterodine provides superior efficacy and is well tolerated in women with overactive bladder. Int Urogynecol J Pelvic Floor Dysfunct. Feb. 2003;14(1):50-4. discussion 4–5. [pmid: 12601517].
456 Freeman R, Hill S, Millard R, et al. Reduced perception of urgency in treatment of overactive bladder with extended-release tolterodine. Obstet Gynecol. Sep. 2003;102(3):605-11. [pmid: 12962951].
457 Khullar V, Hill S, Laval KU, et al. Treatment of urge-predominant mixed urinary incontinence with tolterodine extended release: a randomized, placebo-controlled trial. Urology. Aug. 2004;64(2):269-74. discussion 74–5. [pmid: 15302476].
458 DuBeau CE, Khullar V, Versi E. “Unblinding” in randomized controlled drug trials for urinary incontinence: Implications for assessing outcomes when adverse effects are evident. Neurourol Urodyn. 2005;24(1):13-20. [pmid: 15570576].
459 Dmochowski R, Kreder K, MacDiarmid S, et al. The clinical efficacy of tolterodine extended-release is maintained for 24 h in patients with overactive bladder. BJU Int. Jul. 2007;100(1):107-10. [pmid: 17552957].
460 Chapple C, Van Kerrebroeck P, Tubaro A, et al. Clinical efficacy, safety, and tolerability of once-daily fesoterodine in subjects with overactive bladder. Eur Urol. Oct. 2007;52(4):1204-12. [pmid: 17651893].
461 Herschorn S, Swift S, Guan Z, et al. Comparison of fesoterodine and tolterodine extended release for the treatment of overactive bladder: a head-to-head placebo-controlled trial. BJU Int. Jan. 2010;105(1):58-66. [pmid: 20132103].
462 Robinson D, Cardozo L, Terpstra G, et al. A randomized double-blind placebo-controlled multicentre study to explore the efficacy and safety of tamsulosin and tolterodine in women with overactive bladder syndrome. BJU Int. Oct. 2007;100(4):840-5. [pmid: 17822465].
463 Herschorn S, Heesakkers J, Castro-Diaz D, et al. Effects of tolterodine extended release on patient perception of bladder condition and overactive bladder symptoms*. Curr Med Res Opin. Dec. 2008;24(12):3513-21. [pmid: 19032133].
464 Rogers RG, Bachmann G, Scarpero H, et al. Effects of tolterodine ER on patient-reported outcomes in sexually active women with overactive bladder and urgency urinary incontinence. Curr Med Res Opin. Sep. 2009;25(9):2159-65. [pmid: 19601704].
465 Junemann KP, Al-Shukri S. Efficacy and tolerability of trospium cholride and tolterodine in 234 patients with urge syndrome: a double-bline, placebo-controlled, multicentre clinical trial. Neurourol Urodyn. 2000;19:488-90.
466 Rogers RG, Omotosho T, Bachmann G, et al. Continued symptom improvement in sexually active women with overactive bladder and urgency urinary incontinence treated with tolterodine ER for 6 months. Int Urogynecol J Pelvic Floor Dysfunct. Apr. 2009;20(4):381-5. [pmid: 19132285].
467 Wein AJ, Khullar V, Wang JT, et al. Achieving continence with antimuscarinic therapy for overactive bladder: effects of baseline incontinence severity and bladder diary duration. BJU Int. Feb. 2007;99(2):360-3. [pmid: 17155987].
468 Chapple CR, Van Kerrebroeck PE, Junemann KP, et al. Comparison of fesoterodine and tolterodine in patients with overactive bladder. BJU Int. Nov. 2008;102(9):1128-32. [pmid: 18647298].
469 Kreder KJ Jr, Brubaker L, Mainprize T. Tolterodine is equally effective in patients with mixed incontinence and those with urge incontinence alone. BJU Int. Sep. 2003;92(4):418-21. [pmid: 12930432].
470 Coyne KS, Elinoff V, Gordon DA, et al. Relationships between improvements in symptoms and patient assessments of bladder condition, symptom bother and health-related quality of life in patients with overactive bladder treated with tolterodine. Int J Clin Pract. Jun. 2008;62(6):925-31. [pmid: 18479285].
471 Elinoff V, Bavendam T, Glasser DB, et al. Symptom-specific efficacy of tolterodine extended release in patients with overactive bladder: the IMPACT trial. Int J Clin Pract. Jun. 2006;60(6):745-51. [pmid: 16805763].
472 Roberts R, Bavendam T, Glasser DB, et al. Tolterodine extended release improves patient-reported outcomes in overactive bladder: results from the IMPACT trial. Int J Clin Pract. Jun. 2006;60(6):752-8. [pmid: 16805764].
473 Sussman DO, Kraus SR, Carlsson M, et al. Onset of efficacy of tolterodine extended release in patients with overactive bladder. Curr Med Res Opin. Apr. 2007;23(4):777-81. [pmid: 17407634].
474 Michel MC, Oelke M, Goepel M, et al. Relationships among symptoms, bother, and treatment satisfaction in overactive bladder patients. Neurourol Urodyn. 2007;26(2):190-5. [pmid: 17096320].
475 Michel MC, de la Rosette JJ, Piro M, et al. Does concomitant stress incontinence alter the efficacy of tolterodine in patients with overactive bladder?. J Urol. Aug. 2004;172(2):601-4. [pmid: 15247741].
476 Michel MC, Schneider T, Krege S, et al. Does gender or age affect the efficacy and safety of tolterodine?. J Urol. Sep. 2002;168(3):1027-31. [pmid: 12187215].
477 Chapple CR, Arano P, Bosch JL, et al. Solifenacin appears effective and well tolerated in patients with symptomatic idiopathic detrusor overactivity in a placebo- and tolterodine-controlled phase 2 dose-finding study. BJU Int. Jan. 2004;93(1):71-7. [pmid: 14678372].
478 Chapple CR, Rechberger T, Al-Shukri S, et al. Randomized, double-blind placebo- and tolterodine-controlled trial of the once-daily antimuscarinic agent solifenacin in patients with symptomatic overactive bladder. BJU Int. Feb. 2004;93(3):303-10. [pmid: 14764127].
479 Chapple C, DuBeau C, Ebinger U, et al. Darifenacin treatment of patients >or= 65 years with overactive bladder: results of a randomized, controlled, 12-week trial. Curr Med Res Opin. Oct. 2007;23(10):2347-58. [pmid: 17706004].
480 Lipton RB, Kolodner K, Wesnes K. Assessment of cognitive function of the elderly population: effects of darifenacin. J Urol. Feb. 2005;173(2):493-8. [pmid: 15643227].
481 Steers W, Corcos J, Foote J, et al. An investigation of dose titration with darifenacin, an M3-selective receptor antagonist. BJU Int. Mar. 2005;95(4):580-6. [pmid: 15705084].
482 Hill S, Khullar V, Wyndaele JJ, et al. Dose response with darifenacin, a novel once-daily M3 selective receptor antagonist for the treatment of overactive bladder: results of a fixed dose study. Int Urogynecol J Pelvic Floor Dysfunct. May. 2006;17(3):239-47. [pmid: 15999217].
483 Zinner N, Susset J, Gittelman M, et al. Efficacy, tolerability and safety of darifenacin, an M(3) selective receptor antagonist: an investigation of warning time in patients with OAB. Int J Clin Pract. Jan. 2006;60(1):119-26. [pmid: 16409440].
484 Haab F, Corcos J, Siami P, et al. Long-term treatment with darifenacin for overactive bladder: results of a 2-year, open-label extension study. BJU Int. Nov. 2006;98(5):1025-32. [pmid: 16879437].
485 Zinner N, Kobashi KC, Ebinger U, et al. Darifenacin treatment for overactive bladder in patients who expressed dissatisfaction with prior extended-release antimuscarinic therapy. Int J Clin Pract. Nov. 2008;62(11):1664-74. [pmid: 18811599].
486 Chapple C, Steers W, Norton P, et al. A pooled analysis of three phase III studies to investigate the efficacy, tolerability and safety of darifenacin, a muscarinic M3 selective receptor antagonist, in the treatment of overactive bladder. BJU Int. May. 2005;95(7):993-1001. [pmid: 15839920].
487 Foote J, Glavind K, Kralidis G, et al. Treatment of overactive bladder in the older patient: pooled analysis of three phase III studies of darifenacin, an M3 selective receptor antagonist. Eur Urol. Sep. 2005;48(3):471-7. [pmid: 15990219].
488 Abrams P, Kelleher C, Huels J, et al. Clinical relevance of health-related quality of life outcomes with darifenacin. BJU Int. Jul. 2008;102(2):208-13. [pmid: 18325056].
489 Chapple CR. Darifenacin: a novel M3 muscarinic selective receptor antagonist for the treatment of overactive bladder. Expert Opin Investig Drugs. Nov. 2004;13(11):1493-500. [pmid: 15500396].
490 Cardozo L, Lisec M, Millard R, et al. Randomized, double-blind placebo controlled trial of the once daily antimuscarinic agent solifenacin succinate in patients with overactive bladder. J Urol. Nov. 2004;172(5 Pt 1):1919-24. [pmid: 15540755].
491 Haab F, Cardozo L, Chapple C, et al. Long-term open-label solifenacin treatment associated with persistence with therapy in patients with overactive bladder syndrome. Eur Urol. Mar. 2005;47(3):376-84. [pmid: 15716204].
492 Vardy MD, Mitcheson HD, Samuels TA, et al. Effects of solifenacin on overactive bladder symptoms, symptom bother and other patient-reported outcomes: results from VIBRANT - a double-blind, placebo-controlled trial. Int J Clin Pract. Dec. 2009;63(12):1702-14. [pmid: 19930331].
493 Cardozo L, Hessdorfer E, Milani R, et al. Solifenacin in the treatment of urgency and other symptoms of overactive bladder: results from a randomized, double-blind, placebo-controlled, rising-dose trial. BJU Int. Nov. 2008;102(9):1120-7. [pmid: 18990175].
494 Karram MM, Toglia MR, Serels SR, et al. Treatment with solifenacin increases warning time and improves symptoms of overactive bladder: results from VENUS, a randomized, double-blind, placebo-controlled trial. Urology. Jan. 2009;73(1):14-8. [pmid: 18995887].
495 Toglia MR, Serels SR, Laramee C, et al. Solifenacin for overactive bladder: patient-reported outcomes from a large placebo-controlled trial. Postgrad Med. Sep. 2009;121(5):151-8. [pmid: 19820284].
496 Chu F, Smith N, Uchida T. Efficacy and safety of solifenacin succinate 10 mg once Daily: A multicenter, phase III, randomized, double-blind, placebo-controlled, parallel-group trial in patients with overactive bladder. Current Therapeutic Research. December. 2009;70(6):405-20. [doi: 10.1016/j.curtheres.2009.11.001].
497 Cardozo L, Castro-Diaz D, Gittelman M, et al. Reductions in overactive bladder-related incontinence from pooled analysis of phase III trials evaluating treatment with solifenacin. Int Urogynecol J Pelvic Floor Dysfunct. Sep. 2006;17(5):512-9. [pmid: 16625311].
498 Kelleher C, Cardozo L, Kobashi K, et al. Solifenacin: as effective in mixed urinary incontinence as in urge urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2006;17(4):382-8. [pmid: 16283422].
499 Staskin DR, Te AE. Short- and long-term efficacy of solifenacin treatment in patients with symptoms of mixed urinary incontinence. BJU Int. Jun. 2006;97(6):1256-61. [pmid: 16686722].
500 Garely AD, Kaufman JM, Sand PK, et al. Symptom bother and health-related quality of life outcomes following solifenacin treatment for overactive bladder: the VESIcare Open-Label Trial (VOLT). Clin Ther. Nov. 2006;28(11):1935-46. [pmid: 17213014].
501 Garely AD, Lucente V, Vapnek J, et al. Solifenacin for overactive bladder with incontinence: symptom bother and health-related quality of life outcomes. Ann Pharmacother. Mar. 2007;41(3):391-8. [pmid: 17341526].
502 Yamaguchi O, Marui E, Kakizaki H, et al. Randomized, double-blind, placebo- and propiverine-controlled trial of the once-daily antimuscarinic agent solifenacin in Japanese patients with overactive bladder. BJU Int. Sep. 2007;100(3):579-87. [pmid: 17669143].
503 Dmochowski RR, Peters KM, Morrow JD, et al. Randomized, double-blind, placebo-controlled trial of flexible-dose fesoterodine in subjects with overactive bladder. Urology. Jan. 2010;75(1):62-8. [pmid: 19931895].
504 Malhotra B, Wood N, Sachse R, et al. Thorough QT study of the effect of fesoterodine on cardiac repolarization. Int J Clin Pharmacol Ther. May. 2010;48(5):309-18. [pmid: 20420787].
505 NCT00536484. Fesoterodine Flexible Dose Study. http://www.clinicaltrials.gov/ct2/show/NCT00536484?term=NCT00536484&rank=1.
506 Nitti CVW, Dmochowski R, Sand PK, et al. Efficacy, safety and tolerability of fesoterodine for overactive bladder syndrome. J Urol. Dec. 2007;178(6):2488-94. [pmid: 17937959].
507 Khullar V, Rovner ES, Dmochowski R, et al. Fesoterodine dose response in subjects with overactive bladder syndrome. Urology. May. 2008;71(5):839-43. [pmid: 18342923].
508 Cardozo L, Khullar V, Wang JT, et al. Fesoterodine in patients with overactive bladder syndrome: can the severity of baseline urgency urinary incontinence predict dosing requirement?. BJU Int. 2010. Feb. 11. [pmid: 20151972].
509 Staskin DR, Harnett MD. Effect of trospium chloride on somnolence and sleepiness in patients with overactive bladder. Curr Urol Rep. Dec. 2004;5(6):423-6. [pmid: 15541209].
510 Rudy D, Cline K, Harris R, et al. Multicenter phase III trial studying trospium chloride in patients with overactive bladder. Urology. Feb. 2006;67(2):275-80. [pmid: 16461077].
511 Rudy D, Cline K, Harris R, et al. Time to onset of improvement in symptoms of overactive bladder using antimuscarinic treatment. BJU Int. Mar. 2006;97(3):540-6. [pmid: 16469022].
512 Sand PK, Dmochowski RR, Zinner NR, et al. Trospium chloride extended release is effective and well tolerated in women with overactive bladder syndrome. Int Urogynecol J Pelvic Floor Dysfunct. 2009. Aug. 29. [pmid: 19727537].
513 Zinner N, Gittelman M, Harris R, et al. Trospium chloride improves overactive bladder symptoms: a multicenter phase III trial. J Urol. Jun. 2004;171(6 Pt 1):2311-5. quiz 435. [pmid: 15126811].
514 Staskin D, Sand P, Zinner N, et al. Once daily trospium chloride is effective and well tolerated for the treatment of overactive bladder: results from a multicenter phase III trial. J Urol. Sep. 2007;178(3 Pt 1):978-83. discussion 83–4. [pmid: 17632131].
515 Staskin DR, Rosenberg MT, Sand PK, et al. Trospium chloride once-daily extended release is effective and well tolerated for the treatment of overactive bladder syndrome: an integrated analysis of two randomised, phase III trials. Int J Clin Pract. Dec. 2009;63(12):1715-23. [pmid: 19930332].
516 Dorschner W, Stolzenburg JU, Griebenow R, et al. Efficacy and cardiac safety of propiverine in elderly patients - a double-blind, placebo-controlled clinical study. Eur Urol. Jun. 2000;37(6):702-8. [pmid: 10828671].
517 Abrams P, Cardozo L, Chapple C, et al. Comparison of the efficacy, safety, and tolerability of propiverine and oxybutynin for the treatment of overactive bladder syndrome. Int J Urol. Jun. 2006;13(6):692-8. [pmid: 16834644].
518 Lee KS, Lee HW, Choo MS, et al. Urinary urgency outcomes after propiverine treatment for an overactive bladder: the ‘Propiverine study on overactive bladder including urgency data’. BJU Int. Jun. 2010;105(11):1565-70. [pmid: 19912183].
519 Ghei M, Maraj BH, Miller R, et al. Effects of botulinum toxin B on refractory detrusor overactivity: a randomized, double-blind, placebo controlled, crossover trial. J Urol. Nov. 2005;174(5):1873-7. discussion 7. [pmid: 16217327].
520 Brubaker L, Richter HE, Visco A, et al. Refractory idiopathic urge urinary incontinence and botulinum A injection. J Urol. Jul. 2008;180(1):217-22. [pmid: 18499184].
521 Flynn MK, Amundsen CL, Perevich M, et al. Outcome of a randomized, double-blind, placebo controlled trial of botulinum A toxin for refractory overactive bladder. J Urol. Jun. 2009;181(6):2608-15. [pmid: 19375091].
522 Anger JT, Weinberg A, Suttorp MJ, et al. Outcomes of intravesical botulinum toxin for idiopathic overactive bladder symptoms: a systematic review of the literature. J Urol. Jun. 2010;183(6):2258-64. [pmid: 20400142].
523 Dmochowski R, Chapple C, Nitti VW, et al. Efficacy and Safety of OnabotulinumtoxinA for Idiopathic Overactive Bladder: A Double-Blind, Placebo Controlled, Randomized, Dose Ranging Trial. J Urol. 2010. Oct. 16. [pmid: 20952013].
524 Rios LA, Panhoca R, Mattos D Jr, et al. Intravesical resiniferatoxin for the treatment of women with idiopathic detrusor overactivity and urgency incontinence: A single dose, 4 weeks, double-blind, randomized, placebo controlled trial. Neurourol Urodyn. 2007;26(6):773-8. [pmid: 17638305].
525 Naglie G, Radomski SB, Brymer C, et al. A randomized, double-blind, placebo controlled crossover trial of nimodipine in older persons with detrusor instability and urge incontinence. J Urol. Feb. 2002;167(2 Pt 1):586-90. [pmid: 11792923].
526 Chompootaweep S, Nunthapisud P, Trivijitsilp P, et al. The use of two estrogen preparations (a combined contraceptive pill versus conjugated estrogen cream) intravaginally to treat urogenital symptoms in postmenopausal Thai women: a comparative study. Clin Pharmacol Ther. Aug. 1998;64(2):204-10. [pmid: 9728901].
527 Lose G, Englev E. Oestradiol-releasing vaginal ring versus oestriol vaginal pessaries in the treatment of bothersome lower urinary tract symptoms. BJOG. Aug. 2000;107(8):1029-34. [pmid: 10955437].
528 Nelken RS, Ozel BZ, Leegant AR, et al. Randomized trial of estradiol vaginal ring versus oral oxybutynin for the treatment of overactive bladder. Menopause. Sep. 2011;18(9):962-6. [pmid: 21532512].
529 Chapple CR, Abrams P. Comparison of darifenacin and oxybutynin in patients with overactive bladder: assessment of ambulatory urodynamics and impact on salivary flow. Eur Urol. Jul. 2005;48(1):102-9. [pmid: 15936869].
530 Appell RA, Sand P, Dmochowski R, et al. Prospective randomized controlled trial of extended-release oxybutynin chloride and tolterodine tartrate in the treatment of overactive bladder: results of the OBJECT Study. Mayo Clin Proc. Apr. 2001;76(4):358-63. [pmid: 11322350].
531 Lee JG, Hong JY, Choo MS, et al. Tolterodine: as effective but better tolerated than oxybutynin in Asian patients with symptoms of overactive bladder. Int J Urol. May. 2002;9(5):247-52. [pmid: 12060436].
532 Leung HY, Yip SK, Cheon C, et al. A randomized controlled trial of tolterodine and oxybutynin on tolerability and clinical efficacy for treating Chinese women with an overactive bladder. BJU Int. Sep. 2002;90(4):375-80. [pmid: 12175392].
533 Diokno AC, Appell RA, Sand PK, et al. Prospective, randomized, double-blind study of the efficacy and tolerability of the extended-release formulations of oxybutynin and tolterodine for overactive bladder: results of the OPERA trial. Mayo Clin Proc. Jun. 2003;78(6):687-95. [pmid: 12934777].
534 Sand PK, Miklos J, Ritter H, et al. A comparison of extended-release oxybutynin and tolterodine for treatment of overactive bladder in women. Int Urogynecol J Pelvic Floor Dysfunct. Jul–Aug. 2004;15(4):243-8. [pmid: 15517668].
535 Armstrong RB, Luber KM, Peters KM. Comparison of dry mouth in women treated with extended-release formulations of oxybutynin or tolterodine for overactive bladder. Int Urol Nephrol. 2005;37(2):247-52. [pmid: 16142551].
536 Armstrong RB, Dmochowski RR, Sand PK, et al. Safety and tolerability of extended-release oxybutynin once daily in urinary incontinence: combined results from two phase 4 controlled clinical trials. Int Urol Nephrol. 2007;39(4):1069-77. [pmid: 17333521].
537 Chu FM, Dmochowski RR, Lama DJ, et al. Extended-release formulations of oxybutynin and tolterodine exhibit similar central nervous system tolerability profiles: a subanalysis of data from the OPERA trial. Am J Obstet Gynecol. Jun. 2005;192(6):1849-54. discussion 54–5. [pmid: 15970828].
538 Milani R, Scalambrino S, Milia R, et al. Double-blind crossover comparison of flavoxate and oxybutynin in women affected by urinary urge syndrome. Int Urogynecol J. 1993:3-8.
539 Junemann KP, Halaska M, Rittstein T, et al. Propiverine versus tolterodine: efficacy and tolerability in patients with overactive bladder. Eur Urol. Sep. 2005;48(3):478-82. [pmid: 15967567].
540 Kelleher CJ, Tubaro A, Wang JT, et al. Impact of fesoterodine on quality of life: pooled data from two randomized trials. BJU Int. Jul. 2008;102(1):56-61. [pmid: 18564231].
541 Chapple CR, Martinez-Garcia R, Selvaggi L, et al. A comparison of the efficacy and tolerability of solifenacin succinate and extended release tolterodine at treating overactive bladder syndrome: results of the STAR trial. Eur Urol. Sep. 2005;48(3):464-70. [pmid: 15990220].
542 Chapple CR, Fianu-Jonsson A, Indig M, et al. Treatment outcomes in the STAR study: a subanalysis of solifenacin 5 mg and tolterodine ER 4 mg. Eur Urol. Oct. 2007;52(4):1195-203. [pmid: 17574730].
543 Choo MS, Lee JZ, Lee JB, et al. Efficacy and safety of solifenacin succinate in Korean patients with overactive bladder: a randomised, prospective, double-blind, multicentre study. Int J Clin Pract. Nov. 2008;62(11):1675-83. [pmid: 19143854].
544 But I, Pakiz M, Hlebic G, et al. Comparison of efficacy and tolerability of two selective M3 receptor antagonists Solifenacin and Darifenacin in women with overactive bladder- the Solidar study. Neurourology and Urodynamics. 2010;29:1217-9.
545 Herschorn S, Stothers L, Carlson K, et al. Tolerability of 5 mg Solifenacin Once Daily Versus 5 mg Oxybutynin Immediate Release 3 Times Daily: Results of the VECTOR Trial. J Urol. 2010. Mar. 17. [pmid: 20303119].
546 Halaska M, Ralph G, Wiedemann A, et al. Controlled, double-blind, multicentre clinical trial to investigate long-term tolerability and efficacy of trospium chloride in patients with detrusor instability. World J Urol. May. 2003;20(6):392-9. [pmid: 12811500].
547 Bodeker RH, Madersbacher H, Neumeister C, et al. Dose escalation improves therapeutic outcome: post hoc analysis of data from a 12-week, multicentre, double-blind, parallel-group trial of trospium chloride in patients with urinary urge incontinence. BMC Urol. 2010;10:15. [pmid: 20840754].
548 Cardozo L, Thorpe A, Warner J, et al. The cost-effectiveness of solifenacin vs fesoterodine, oxybutynin immediate-release, propiverine, tolterodine extended-release and tolterodine immediate-release in the treatment of patients with overactive bladder in the UK National Health Service. BJU Int. 2010. Feb. 3. [pmid: 20132203].
549 Sand PK, Johnson TM Ii, Rovner ES, et al. Trospium chloride once-daily extended release is efficacious and tolerated in elderly subjects (aged >/= 75 years) with overactive bladder syndrome. BJU Int. Feb. 2011;107(4):612-20. [pmid: 20707790].
550 Staskin DR, Cardozo L. Baseline incontinence severity is predictive of the percentage of patients continent after receiving once-daily trospium chloride extended release. Int J Clin Pract. Jun. 2009;63(6):973-6. [pmid: 19459997].
551 Anderson RU, MacDiarmid S, Kell S, et al. Effectiveness and tolerability of extended-release oxybutynin vs extended-release tolterodine in women with or without prior anticholinergic treatment for overactive bladder. Int Urogynecol J Pelvic Floor Dysfunct. Sep. 2006;17(5):502-11. [pmid: 16724169].
552 Sand PK, Rovner ES, Watanabe JH, et al. Once-daily trospium chloride 60 mg extended release in subjects with overactive bladder syndrome who use multiple concomitant medications: Post hoc analysis of pooled data from two randomized, placebo-controlled trials. Drugs Aging. Feb. 1. 2011;28(2):151-60. [pmid: 21275440].
553 Chancellor MB, Oefelein MG, Vasavada S. Obesity is associated with a more severe overactive bladder disease state that is effectively treated with once-daily administration of trospium chloride extended release. Neurourol Urodyn. Apr. 2010;29(4):551-4. [pmid: 19634167].
554 Kim H, Yoshida H, Suzuki T. Exercises treatment to reduce the urine leakage in elderly community-dwelling Japanese women with stress, urge, and mixed urinary incontinence. 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. 2009.
555 Lagro-Janssen TL, Debruyne FM, Smits AJ, et al. Controlled trial of pelvic floor exercises in the treatment of urinary stress incontinence in general practice. Br J Gen Pract. Nov. 1991;41(352):445-9. [pmid: 1807303].
556 Burns PA, Pranikoff K, Nochajski T, et al. Treatment of stress incontinence with pelvic floor exercises and biofeedback. J Am Geriatr Soc. Mar. 1990;38(3):341-4. [pmid: 2179379].
557 Burns PA, Pranikoff K, Nochajski TH, et al. A comparison of effectiveness of biofeedback and pelvic muscle exercise treatment of stress incontinence in older community-dwelling women. J Gerontol. Jul. 1993;48(4):M167-74. [pmid: 8315230].
558 Bo K, Talseth T, Holme I. Single blind, randomised controlled trial of pelvic floor exercises, electrical stimulation, vaginal cones, and no treatment in management of genuine stress incontinence in women. BMJ. Feb. 20. 1999;318(7182):487-93. [pmid: 10024253].
559 Bo K, Talseth T, Vinsnes A. Randomized controlled trial on the effect of pelvic floor muscle training on quality of life and sexual problems in genuine stress incontinent women. Acta Obstet Gynecol Scand. Jul. 2000;79(7):598-603. [pmid: 10929962].
560 Aksac B, Aki S, Karan A, et al. Biofeedback and pelvic floor exercises for the rehabilitation of urinary stress incontinence. Gynecol Obstet Invest. 2003;56(1):23-7. [pmid: 12867764].
561 Williams KS, Assassa RP, Gillies CL, et al. A randomized controlled trial of the effectiveness of pelvic floor therapies for urodynamic stress and mixed incontinence. BJU Int. Nov. 2006;98(5):1043-50. [pmid: 17034605].
562 Kim H, Suzuki T, Yoshida Y, et al. Effectiveness of multidimensional exercises for the treatment of stress urinary incontinence in elderly community-dwelling Japanese women: a randomized, controlled, crossover trial. J Am Geriatr Soc. Dec. 2007;55(12):1932-9. [pmid: 17944890].
563 Castro RA, Arruda RM, Zanetti MR, et al. Single-blind, randomized, controlled trial of pelvic floor muscle training, electrical stimulation, vaginal cones, and no active treatment in the management of stress urinary incontinence. Clinics (Sao Paulo). Aug. 2008;63(4):465-72. [pmid: 18719756].
564 Hung HC, Hsiao SM, Chih SY, et al. An alternative intervention for urinary incontinence: retraining diaphragmatic, deep abdominal and pelvic floor muscle coordinated function. Man Ther. Jun. 2010;15(3):273-9. [pmid: 20185357].
565 Sung MS, Choi YH, Back SH, et al. The effect of pelvic floor muscle exercises on genuine stress incontinence among Korean women--focusing on its effects on the quality of life. Yonsei Med J. Apr. 2000;41(2):237-51. [pmid: 10817026].
566 Tibaek S, Jensen R, Lindskov G, et al. Can quality of life be improved by pelvic floor muscle training in women with urinary incontinence after ischemic stroke? A randomised, controlled and blinded study. Int Urogynecol J Pelvic Floor Dysfunct. Mar–Apr. 2004;15(2):117-23. discussion 23. [pmid: 15014939].
567 Tibaek S, Gard G, Jensen R. Is there a long-lasting effect of pelvic floor muscle training in women with urinary incontinence after ischemic stroke? A 6-month follow-up study. Int Urogynecol J Pelvic Floor Dysfunct. Mar. 2007;18(3):281-7. [pmid: 16673051].
568 Macaulay M, van den Heuvel E, Jowitt F, et al. A noninvasive continence management system: development and evaluation of a novel toileting device for women. J Wound Ostomy Continence Nurs. Nov–Dec. 2007;34(6):641-8. [pmid: 18030103].
569 Donnelly MJ, Powell-Morgan S, Olsen AL, et al. Vaginal pessaries for the management of stress and mixed urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Sep–Oct. 2004;15(5):302-7. [pmid: 15300365].
570 Brincat C, Kenton K, Pat Fitzgerald M, et al. Sexual activity predicts continued pessary use. Am J Obstet Gynecol. Jul. 2004;191(1):198-200. [pmid: 15295365].
571 Maito JM, Quam ZA, Craig E, et al. Predictors of successful pessary fitting and continued use in a nurse-midwifery pessary clinic. J Midwifery Womens Health. Mar–Apr. 2006;51(2):78-84. [pmid: 16504903].
572 Sulak PJ, Kuehl TJ, Shull BL. Vaginal pessaries and their use in pelvic relaxation. J Reprod Med. Dec. 1993;38(12):919-23. [pmid: 8120847].
573 Clemons JL, Aguilar VC, Tillinghast TA, et al. Patient satisfaction and changes in prolapse and urinary symptoms in women who were fitted successfully with a pessary for pelvic organ prolapse. Am J Obstet Gynecol. Apr. 2004;190(4):1025-9. [pmid: 15118635].
574 Farrell SA, Baydock S, Amir B, et al. Effectiveness of a new self-positioning pessary for the management of urinary incontinence in women. Am J Obstet Gynecol. May. 2007;196(5):474 e1-8. [pmid: 17466709].
575 Nguyen JN, Jones CR. Pessary treatment of pelvic relaxation: factors affecting successful fitting and continued use. J Wound Ostomy Continence Nurs. Jul–Aug. 2005;32(4):255-61. quiz 62–3. [pmid: 16030465].
576 Brubaker L, Shott S, Tomezsko J, et al. Pelvic floor fitness using lay instructors. Obstet Gynecol. Jun. 2008;111(6):1298-304. [pmid: 18515512].
577 Sand PK, Richardson DA, Staskin DR, et al. Pelvic floor electrical stimulation in the treatment of genuine stress incontinence: a multicenter, placebo-controlled trial. Am J Obstet Gynecol. Jul. 1995;173(1):72-9. [pmid: 7631730].
578 Brubaker L, Benson JT, Bent A, et al. Transvaginal electrical stimulation for female urinary incontinence. Am J Obstet Gynecol. Sep. 1997;177(3):536-40. [pmid: 9322620].
579 Luber KM, Wolde-Tsadik G. Efficacy of functional electrical stimulation in treating genuine stress incontinence: a randomized clinical trial. Neurourol Urodyn. 1997;16(6):543-51. [pmid: 9353803].
580 Yamanishi T, Yasuda K, Sakakibara R, et al. Pelvic floor electrical stimulation in the treatment of stress incontinence: an investigational study and a placebo controlled double-blind trial. The Journal of urology. 1997:2127-31. [pmid: 9366328].
581 Yamanishi T, Yasuda K, Sakakibara R, et al. Randomized, double-blind study of electrical stimulation for urinary incontinence due to detrusor overactivity. Urology. Mar. 2000;55(3):353-7. [pmid: 10699609].
582 Jeyaseelan SM, Haslam EJ, Winstanley J, et al. An evaluation of a new pattern of electrical stimulation as a treatment for urinary stress incontinence: a randomized, double-blind, controlled trial. Clin Rehabil. Dec. 2000;14(6):631-40. [pmid: 11128739].
583 Amaro JL, Gameiro MO, Kawano PR, et al. Intravaginal electrical stimulation: a randomized, double-blind study on the treatment of mixed urinary incontinence. Acta Obstet Gynecol Scand. 2006;85(5):619-22. [pmid: 16752244].
584 Blowman C, Pickles C, Emery S, et al. Prospective double blind controlled trial of intensive physiotherapy with and without stimulation of the pelvic floor in treatment of genuine stress incontinence. Physiotherapy. October. 1991;77(10):661-4.
585 Indrekvam S, Sandvik H, Hunskaar S. A Norwegian national cohort of 3198 women treated with home-managed electrical stimulation for urinary incontinence--effectiveness and treatment results. Scand J Urol Nephrol. Feb. 2001;35(1):32-9. [pmid: 11291684].
586 Amaro JL, Gameiro MO, Padovani CR. Effect of intravaginal electrical stimulation on pelvic floor muscle strength. Int Urogynecol J Pelvic Floor Dysfunct. Sep–Oct. 2005;16(5):355-8. [pmid: 15647885].
587 Fujishiro T, Enomoto H, Ugawa Y, et al. Magnetic stimulation of the sacral roots for the treatment of stress incontinence: an investigational study and placebo controlled trial. J Urol. Oct. 2000;164(4):1277-9. [pmid: 10992380].
588 But I. Conservative treatment of female urinary incontinence with functional magnetic stimulation. Urology. Mar. 2003;61(3):558-61. [pmid: 12639647].
589 But I, Faganelj M, Sostaric A. Functional magnetic stimulation for mixed urinary incontinence. J Urol. May. 2005;173(5):1644-6. [pmid: 15821527].
590 Manganotti P, Zaina F, Vedovi E, et al. Repetitive magnetic stimulation of the sacral roots for the treatment of stress incontinence: a brief report. Eura Medicophys. Sep. 2007;43(3):339-44. [pmid: 17259914].
591 Gilling PJ, Wilson LC, Westenberg AM, et al. A double-blind randomized controlled trial of electromagnetic stimulation of the pelvic floor vs sham therapy in the treatment of women with stress urinary incontinence. BJU Int. May. 2009;103(10):1386-90. [pmid: 19154474].
592 Galloway NT, El-Galley RE, Sand PK, et al. Update on extracorporeal magnetic innervation (EXMI) therapy for stress urinary incontinence. Urology. Dec. 4. 2000;56(6 Suppl 1):82-6. [pmid: 11114568].
593 Bellin P, Smith J, Poll W, et al. Results of a multicenter trial of the CapSure (Re/Stor) Continence shield on women with stress urinary incontinence. Urology. May. 1998;51(5):697-706. [pmid: 9610582].
594 Morris AR, Moore KH. The Contiform incontinence device - efficacy and patient acceptability. Int Urogynecol J Pelvic Floor Dysfunct. Dec. 2003;14(6):412-7. [pmid: 14677003].
595 Allen WA, Leek H, Izurieta A, et al. Update: the “Contiform” intravaginal device in four sizes for the treatment of stress incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2008;19(6):757-61. [pmid: 18183342].
596 Sander P, Thyssen H, Lose G, et al. Effect of a vaginal device on quality of life with urinary stress incontinence. Obstet Gynecol. Mar. 1999;93(3):407-11. [pmid: 10074989].
597 Hahn I, Milsom I. Treatment of female stress urinary incontinence with a new anatomically shaped vaginal device (Conveen Continence Guard). Br J Urol. May. 1996;77(5):711-5. [pmid: 8689116].
598 Nilsson CG. Effectiveness of the conveen continence guard (a disposable vaginal device) in the treatment of complicated female stress incontinence. Acta Obstet Gynecol Scand. Dec. 2000;79(12):1052-5. [pmid: 11130086].
599 Pieper B, Cleland V. An external urine-collection device for women: a clinical trial. J ET Nurs. Mar–Apr. 1993;20(2):51-5. [pmid: 8507726].
600 Versi E, Harvey MA. Efficacy of an external urethral device in women with genuine stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 1998;9(5):271-4. [pmid: 9849759].
601 Versi E, Griffiths DJ, Harvey MA. A new external urethral occlusive device for female urinary incontinence. Obstet Gynecol. Aug. 1998;92(2):286-91. [pmid: 9699768].
602 Sirls LT, Foote JE, Kaufman JM, et al. Long-term results of the FemSoft urethral insert for the management of female stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(2):88-95. discussion. [pmid: 12054188].
603 Staskin D, Bavendam T, Miller J, et al. Effectiveness of a urinary control insert in the management of stress urinary incontinence: early results of a multicenter study. Urology. May. 1996;47(5):629-36. [pmid: 8650857].
604 Kocjancic E, Crivellaro S, Smith JJ 3rd, et al. Adjustable continence therapy for treatment of recurrent female urinary incontinence. J Endourol. Jul. 2008;22(7):1403-7. [pmid: 18613782].
605 Brubaker L, Harris T, Gleason D, et al. The external urethral barrier for stress incontinence: a multicenter trial of safety and efficacy. Miniguard Investigators Group. Obstet Gynecol. Jun. 1999;93(6):932-7. [pmid: 10362157].
606 Moore KH, Simons A, Dowell C, et al. Efficacy and user acceptability of the urethral occlusive device in women with urinary incontinence. J Urol. Aug. 1999;162(2):464-8. [pmid: 10411058].
607 Sand PK, Staskin D, Miller J, et al. Effect of a urinary control insert on quality of life in incontinent women. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(2):100-5. [pmid: 10384971].
608 Aboseif SR, Franke EI, Nash SD, et al. The adjustable continence therapy system for recurrent female stress urinary incontinence: 1-year results of the North America Clinical Study Group. J Urol. May. 2009;181(5):2187-91. [pmid: 19296967].
609 Appell RA, Juma S, Wells WG, et al. Transurethral radiofrequency energy collagen micro-remodeling for the treatment of female stress urinary incontinence. Neurourol Urodyn. 2006;25(4):331-6. [pmid: 16673379].
610 Lee PE, Kung RC, Drutz HP. Periurethral autologous fat injection as treatment for female stress urinary incontinence: a randomized double-blind controlled trial. J Urol. Jan. 2001;165(1):153-8. [pmid: 11125386].
611 van Kerrebroeck P, ter Meulen F, Larsson G, et al. Treatment of stress urinary incontinence using a copolymer system: impact on quality of life. BJU Int. Nov. 2004;94(7):1040-3. [pmid: 15541124].
612 Chapple CR, Haab F, Cervigni M, et al. An open, multicentre study of NASHA/Dx Gel (Zuidex) for the treatment of stress urinary incontinence. Eur Urol. Sep. 2005;48(3):488-94. [pmid: 15967568].
613 van Kerrebroeck P, ter Meulen F, Larsson G, et al. Efficacy and safety of a novel system (NASHA/Dx copolymer using the Implacer device) for treatment of stress urinary incontinence. Urology. Aug. 2004;64(2):276-81. [pmid: 15302478].
614 Fantl JA, Wyman JF, McClish DK, et al. Efficacy of bladder training in older women with urinary incontinence. JAMA. Feb. 6. 1991;265(5):609-13. [pmid: 1987410].
615 Subak LL, Quesenberry CP, Posner SF, et al. The effect of behavioral therapy on urinary incontinence: a randomized controlled trial. Obstet Gynecol. Jul. 2002;100(1):72-8. [pmid: 12100806].
616 Wyman JF, Fantl JA, McClish DK, et al. Quality of life following bladder training in older women with urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 1997;8(4):223-9. [pmid: 9449301].
617 Peters KM, Carrico DJ, Perez-Marrero RA, et al. Randomized trial of percutaneous tibial nerve stimulation versus Sham efficacy in the treatment of overactive bladder syndrome: results from the SUmiT trial. J Urol. Apr. 2010;183(4):1438-43. [pmid: 20171677].
618 Peters K, Carrico DJ, Perez-Marrero RA, et al. 12 week results from the Sumit trial: Percutaneous tibial nerve stimulation vs validated sham in those exposed to pharmacologic therapy. Neurourology and Urodynamics. 2010;29:988-9.
619 Finazzi-Agro E, Petta F, Sciobica F, et al. Percutaneous tibial nerve stimulation effects on detrusor overactivity incontinence are not due to a placebo effect: a randomized, double-blind, placebo controlled trial. J Urol. Nov. 2010;184(5):2001-6. [pmid: 20850833].
620 Schreiner L, dos Santos TG, Knorst MR, et al. Randomized trial of transcutaneous tibial nerve stimulation to treat urge urinary incontinence in older women. Int Urogynecol J Pelvic Floor Dysfunct. Sep. 2010;21(9):1065-70. [pmid: 20458465].
621 MacDiarmid SA, Peters KM, Shobeiri SA, et al. Long-term durability of percutaneous tibial nerve stimulation for the treatment of overactive bladder. J Urol. Jan. 2010;183(1):234-40. [pmid: 19913821].
622 Surwit E, Campbell JD, Karaszewski K. Neuromodulation of the pudendal, hypogastric, and tibial nerves with pelvic floor muscle rehabilitation in the treatment of urinary urge incontinence. Neuromodulation: Technology at the Neural Interface. 2009;12(3):175-9.
623 Finazzi Agro E, Campagna A, Sciobica F, et al. Posterior tibial nerve stimulation: is the once-a-week protocol the best option?. Minerva Urol Nefrol. Jun. 2005;57(2):119-23. [pmid: 15951736].
624 Vandoninck V, van Balken MR, Finazzi Agro E, et al. Percutaneous tibial nerve stimulation in the treatment of overactive bladder: urodynamic data. Neurourol Urodyn. 2003;22(3):227-32. [pmid: 12707873].
625 Vandoninck V, Van Balken MR, Finazzi Agro E, et al. Posterior tibial nerve stimulation in the treatment of urge incontinence. Neurourol Urodyn. 2003;22(1):17-23. [pmid: 12478596].
626 Vandoninck V, van Balken MR, Finazzi Agro E, et al. Posterior tibial nerve stimulation in the treatment of voiding dysfunction: urodynamic data. Neurourol Urodyn. 2004;23(3):246-51. [pmid: 15098221].
627 Lagro-Janssen AL, Debruyne FM, Smits AJ, et al. The effects of treatment of urinary incontinence in general practice. Fam Pract. Sep. 1992;9(3):284-9. [pmid: 1459383].
628 O’Brien J, Austin M, Sethi P, et al. Urinary incontinence: prevalence, need for treatment, and effectiveness of intervention by nurse. BMJ. Nov. 23. 1991;303(6813):1308-12. [pmid: 1747675].
629 McFall SL, Yerkes AM, Cowan LD. Outcomes of a small group educational intervention for urinary incontinence: episodes of incontinence and other urinary symptoms. J Aging Health. May. 2000;12(2):250-67. [pmid: 11010699].
630 McFall SL, Yerkes AM, Cowan LD. Outcomes of a small group educational intervention for urinary incontinence: health-related quality of life. J Aging Health. Aug. 2000;12(3):301-17. [pmid: 11067699].
631 Diokno AC, Sampselle CM, Herzog AR, et al. Prevention of urinary incontinence by behavioral modification program: a randomized, controlled trial among older women in the community. J Urol. Mar. 2004;171(3):1165-71. [pmid: 14767293].
632 Kumari S, Jain V, Mandal AK, et al. Behavioral therapy for urinary incontinence in India. Int J Gynaecol Obstet. Nov. 2008;103(2):125-30. [pmid: 18755458].
633 McFall S, Yerkes AM, Bernard M, et al. Evaluation and treatment of urinary incontinence. Report of a physician survey. Arch Fam Med. Mar–Apr. 1997;6(2):114-9. [pmid: 9075444].
634 Williams KS, Assassa RP, Cooper NJ, et al. Clinical and cost-effectiveness of a new nurse-led continence service: a randomised controlled trial. Br J Gen Pract. Sep. 2005;55(518):696-703. [pmid: 16176737].
635 Kim JI. Continence efficacy intervention program for community residing women with stress urinary incontinence in Japan. Public Health Nurs. Jan–Feb. 2001;18(1):64-72. [pmid: 11251875].
636 Moore KH, O’Sullivan RJ, Simons A, et al. Randomised controlled trial of nurse continence advisor therapy compared with standard urogynaecology regimen for conservative incontinence treatment: efficacy, costs and two year follow up. BJOG. Jul. 2003;110(7):649-57. [pmid: 12842055].
637 O’Brien J. Evaluating primary care interventions for incontinence. Nurs Stand. Feb. 28. 1996;10(23):40-3. [pmid: 8695463].
638 Du Moulin MF, Hamers JP, Paulus A, et al. Effects of introducing a specialized nurse in the care of community-dwelling women suffering from urinary incontinence: a randomized controlled trial. J Wound Ostomy Continence Nurs. Nov–Dec. 2007;34(6):631-40. [pmid: 18030102].
639 Chadha Y, Mollison J, Howie F, et al. Guidelines in gynaecology: evaluation in menorrhagia and in urinary incontinence. BJOG. Apr. 2000;107(4):535-43. [pmid: 10759275].
640 Borrie MJ, Bawden M, Speechley M, et al. Interventions led by nurse continence advisers in the management of urinary incontinence: a randomized controlled trial. CMAJ. May. 14. 2002;166(10):1267-73. [pmid: 12041843].
641 Diokno AC, Ocampo MS Jr, Ibrahim IA, et al. Group session teaching of behavioral modification program (BMP) for urinary incontinence: a randomized controlled trial among incontinent women. Int Urol Nephrol. Jun. 2010;42(2):375-81. [pmid: 19701691].
642 Subak LL, Wing R, West DS, et al. Weight loss to treat urinary incontinence in overweight and obese women. N Engl J Med. Jan. 29. 2009;360(5):481-90. [pmid: 19179316].
643 Subak LL, Whitcomb E, Shen H, et al. Weight loss: a novel and effective treatment for urinary incontinence. J Urol. Jul. 2005;174(1):190-5. [pmid: 15947625].
644 Huang AJ, Stewart AL, Hernandez AL, et al. Sexual function among overweight and obese women with urinary incontinence in a randomized controlled trial of an intensive behavioral weight loss intervention. J Urol. May. 2009;181(5):2235-42. [pmid: 19296980].
645 Auwad W, Steggles P, Bombieri L, et al. Moderate weight loss in obese women with urinary incontinence: a prospective longitudinal study. Int Urogynecol J Pelvic Floor Dysfunct. Sep. 2008;19(9):1251-9. [pmid: 18421406].
646 Manonai J, Songchitsomboon S, Chanda K, et al. The effect of a soy-rich diet on urogenital atrophy: a randomized, cross-over trial. Maturitas. May. 20. 2006;54(2):135-40. [pmid: 16297576].
647 Emmons SL, Otto L. Acupuncture for overactive bladder: a randomized controlled trial. Obstet Gynecol. Jul. 2005;106(1):138-43. [pmid: 15994629].
648 Kim JH, Nam D, Park MK, et al. Randomized control trial of hand acupuncture for female stress urinary incontinence. Acupunct Electrother Res. 2008;33(3–4):179-92. [pmid: 19301628].
649 Bergstrom K, Carlsson CP, Lindholm C, et al. Improvement of urge- and mixed-type incontinence after acupuncture treatment among elderly women - a pilot study. J Auton Nerv Syst. Mar. 15. 2000;79(2–3):173-80. [pmid: 10699649].
650 Bo K, Kvarstein B, Nygaard I. Lower urinary tract symptoms and pelvic floor muscle exercise adherence after 15 years. Obstet Gynecol. May. 2005;105(5 Pt 1):999-1005. [pmid: 15863536].
651 de Oliveira Camargo F, Rodrigues AM, Arruda RM, et al. Pelvic floor muscle training in female stress urinary incontinence: comparison between group training and individual treatment using PERFECT assessment scheme. Int Urogynecol J Pelvic Floor Dysfunct. 2009. Aug. 19. [pmid: 19690792].
652 Zanetti MR, de Castro RA, Rotta AL, et al. Impact of supervised physiotherapeutic pelvic floor exercises for treating female stress urinary incontinence. Sao Paulo Med J. Sep. 6. 2007;125(5):265-9. [pmid: 18094892].
653 Burgio KL, Goode PS, Locher JL, et al. Behavioral training with and without biofeedback in the treatment of urge incontinence in older women: a randomized controlled trial. JAMA. Nov. 13. 2002;288(18):2293-9. [pmid: 12425706].
654 Felicissimo MF, Carneiro MM, Saleme CS, et al. Intensive supervised versus unsupervised pelvic floor muscle training for the treatment of stress urinary incontinence: a randomized comparative trial. Int Urogynecol J Pelvic Floor Dysfunct. Jul. 2010;21(7):835-40. [pmid: 20179901].
655 Ng SC, Lin TL, Chang SJ, et al. Nursing intervention to enhance efficacy of home practice of pelvic floor muscle exercises in treating mixed urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. May. 2008;19(5):637-42. [pmid: 18004495].
656 Tsai YC, Liu CH. The effectiveness of pelvic floor exercises, digital vaginal palpation and interpersonal support on stress urinary incontinence: an experimental study. Int J Nurs Stud. Sep. 2009;46(9):1181-6. [pmid: 19361800].
657 Konstantinidou E, Apostolidis A, Kondelidis N, et al. Short-term efficacy of group pelvic floor training under intensive supervision versus unsupervised home training for female stress urinary incontinence: a randomized pilot study. Neurourol Urodyn. 2007;26(4):486-91. [pmid: 17245777].
658 Pages IH, Jahr S, Schaufele MK, et al. Comparative analysis of biofeedback and physical therapy for treatment of urinary stress incontinence in women. Am J Phys Med Rehabil. Jul. 2001;80(7):494-502. [pmid: 11421517].
659 Janssen CC, Lagro-Janssen AL, Felling AJ. The effects of physiotherapy for female urinary incontinence: individual compared with group treatment. BJU Int. Feb. 2001;87(3):201-6. [pmid: 11167642].
660 Morkved S, Bo K, Fjortoft T. Effect of adding biofeedback to pelvic floor muscle training to treat urodynamic stress incontinence. Obstet Gynecol. Oct. 2002;100(4):730-9. [pmid: 12383542].
661 Glavind K, Nohr SB, Walter S. Biofeedback and physiotherapy versus physiotherapy alone in the treatment of genuine stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 1996;7(6):339-43. [pmid: 9203484].
662 Aukee P, Immonen P, Penttinen J, et al. Increase in pelvic floor muscle activity after 12 weeks’ training: a randomized prospective pilot study. Urology. Dec. 2002;60(6):1020-3. discussion 3–4. [pmid: 12475661].
663 McDowell D, Ashe RG, Marshall K, et al. Comparison of pelvic floor muscle training, electromyography biofeedback, and neuromuscular electrical stimulation for bladder dysfunction in people with multiple sclerosis: a randomized pilot study. Neurourol Urodyn. 2006;25(4):337-48. [pmid: 16637070].
664 Wong KS, Fung KY, Fung SM, et al. Biofeedback of pelvic floor muscles in the management of genuine stress incontinence in Chinese women. Physiotherapy. 2001:644-8.
665 Hahn I, Sommar S, Fall M. A comparative study of pelvic floor training and electrical stimulation for the treatment of genuine female stress urinary incontinence. Neurourology and Urodynamics. 1991;10(6):545-54.
666 Smith JJ 3rd. Intravaginal stimulation randomized trial. J Urol. Jan. 1996;155(1):127-30. [pmid: 7490809].
667 Oldham J, McBride K, Herbert J. Evaluation of a new electrostim technology for the treatment of urinary incontinence in women: a randomised controlled trial. Neurourology and Urodynamics. 2010;29:1067.
668 Gameiro MO, Moreira EH, Gameiro FO, et al. Vaginal weight cone versus assisted pelvic floor muscle training in the treatment of female urinary incontinence. A prospective, single-blind, randomized trial. Int Urogynecol J Pelvic Floor Dysfunct. Apr. 2010;21(4):395-9. [pmid: 20052573].
669 Harvey CA. A Randomised, Single-Blind Comparison of Pelvic Floor Muscle Exercises With Biofeedback Versus Weighted Vaginal Cones in the Management of Genuine Stress Incontinence. A Pilot Study. 2002.
670 Seo JT, Yoon H, Kim YH. A randomized prospective study comparing new vaginal cone and FES-Biofeedback. Yonsei Med J. Oct. 31. 2004;45(5):879-84. [pmid: 15515199].
671 Cammu H, Van Nylen M. Pelvic floor exercises versus vaginal weight cones in genuine stress incontinence. Eur J Obstet Gynecol Reprod Biol. Mar. 1998;77(1):89-93. [pmid: 9550207].
672 Arvonen T, Fianu-Jonasson A, Tyni-Lenne R. Effectiveness of two conservative modes of physical therapy in women with urinary stress incontinence. Neurourol Urodyn. 2001;20(5):591-9. [pmid: 11574936].
673 Richter HE, Burgio KL, Brubaker L, et al. Continence pessary compared with behavioral therapy or combined therapy for stress incontinence: a randomized controlled trial. Obstet Gynecol. Mar. 2010;115(3):609-17. [pmid: 20177294].
674 Liebergall-Wischnitzer M, Hochner-Celnikier D, Lavy Y, et al. Randomized trial of circular muscle versus pelvic floor training for stress urinary incontinence in women. J Womens Health (Larchmt). Mar. 2009;18(3):377-85. [pmid: 19281321].
675 Liebergall-Wischnitzer M, Hochner-Celnikier D, Lavy Y, et al. Paula method of circular muscle exercises for urinary stress incontinence--a clinical trial. Int Urogynecol J Pelvic Floor Dysfunct. Sep–Oct. 2005;16(5):345-51. [pmid: 15660184].
676 Sherman RA, Davis GD, Wong MF. Behavioral treatment of exercise-induced urinary incontinence among female soldiers. Mil Med. Oct. 1997;162(10):690-4. [pmid: 9339085].
677 Alewijnse D, Metsemakers JF, Mesters IE, et al. Effectiveness of pelvic floor muscle exercise therapy supplemented with a health education program to promote long-term adherence among women with urinary incontinence. Neurourol Urodyn. 2003;22(4):284-95. [pmid: 12808702].
678 Gallo ML, Staskin DR. Cues to action: pelvic floor muscle exercise compliance in women with stress urinary incontinence. Neurourol Urodyn. 1997;16(3):167-77. [pmid: 9136139].
679 Borello-France DF, Zyczynski HM, Downey PA, et al. Effect of pelvic-floor muscle exercise position on continence and quality-of-life outcomes in women with stress urinary incontinence. Phys Ther. Jul. 2006;86(7):974-86. [pmid: 16813477].
680 Demirturk F, Akbayrak T, Karakaya IC, et al. Interferential current versus biofeedback results in urinary stress incontinence. Swiss Medical Weekly. May. 31. 2008;138(21–22):317-21. [pmid: 18516753].
681 Thyssen H, Bidmead J, Lose G, et al. A new intravaginal device for stress incontinence in women. BJU Int. Dec. 2001;88(9):889-92. [pmid: 11851609].
682 Nygaard I. Prevention of exercise incontinence with mechanical devices. J Reprod Med. Feb. 1995;40(2):89-94. [pmid: 7738934].
683 Andersen RC. Long-term follow-up comparison of Durasphere and Contigen in the treatment of stress urinary incontinence. Journal of Lower Genital Tract Disease. 2002;(4):239-43. [pmid: 17051030].
684 Robinson H, Schulz J, Flood C, et al. A randomized controlled trial of the NEAT expandable tip continence device. Int Urogynecol J Pelvic Floor Dysfunct. Aug. 2003;14(3):199-203. discussion. [pmid: 12955343].
685 Thornburn P, Fader M, Dean G, et al. Improving the performance of small incontinence pads: a study of “wet comfort”. J Wound Ostomy Continence Nurs. Jul. 1997;24(4):219-25. [pmid: 9274279].
686 Mayer RD, Dmochowski RR, Appell RA, et al. Multicenter prospective randomized 52-week trial of calcium hydroxylapatite versus bovine dermal collagen for treatment of stress urinary incontinence. Urology. May. 2007;69(5):876-80. [pmid: 17482925].
687 Bano F, Barrington JW, Dyer R. Comparison between porcine dermal implant (Permacol) and silicone injection (Macroplastique) for urodynamic stress incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Mar–Apr. 2005;16(2):147-50. discussion 50. [pmid: 15378234].
688 Schulz JA, Nager CW, Stanton SL, et al. Bulking agents for stress urinary incontinence: short-term results and complications in a randomized comparison of periurethral and transurethral injections. Int Urogynecol J Pelvic Floor Dysfunct. Jul–Aug. 2004;15(4):261-5. [pmid: 15517671].
689 Ghoniem G, Corcos J, Comiter C, et al. Cross-linked polydimethylsiloxane injection for female stress urinary incontinence: results of a multicenter, randomized, controlled, single-blind study. J Urol. Jan. 2009;181(1):204-10. [pmid: 19013613].
690 Strasser H, Marksteiner R, Margreiter E, et al. Autologous myoblasts and fibroblasts versus collagen for treatment of stress urinary incontinence in women: a randomised controlled trial. Lancet. Jun. 30. 2007;369(9580):2179-86. [pmid: 17604800].
691 Lightner D, Calvosa C, Andersen R, et al. A new injectable bulking agent for treatment of stress urinary incontinence: results of a multicenter, randomized, controlled, double-blind study of Durasphere. Urology. Jul. 2001;58(1):12-5. [pmid: 11445471].
692 Lightner D, Rovner E, Corcos J, et al. Randomized controlled multisite trial of injected bulking agents for women with intrinsic sphincter deficiency: mid-urethral injection of Zuidex via the Implacer versus proximal urethral injection of Contigen cystoscopically. Urology. Oct. 2009;74(4):771-5. [pmid: 19660800].
693 Starr CH. The numbers lie. Bus Health. Spring. 2002;(Spec No:4–7):23. [pmid: 11974569].
694 Dowd T, Kolcaba K, Steiner R. Using cognitive strategies to enhance bladder control and comfort. Holist Nurs Pract. Jan. 2000;14(2):91-103. [pmid: 12119974].
695 Elser DM, Wyman JF, McClish DK, et al. The effect of bladder training, pelvic floor muscle training, or combination training on urodynamic parameters in women with urinary incontinence. Continence Program for Women Research Group. Neurourol Urodyn. 1999;18(5):427-36. [pmid: 10494113].
696 Ramsay IN, Ali HM, Hunter M, et al. A prospective, randomized controlled trial of inpatient versus outpatient continence programs in the treatment of urinary incontinence in the female. Int Urogynecol J Pelvic Floor Dysfunct. 1996;7(5):260-3. [pmid: 9127183].
697 Hui E, Lee PS, Woo J. Management of urinary incontinence in older women using videoconferencing versus conventional management: a randomized controlled trial. J Telemed Telecare. 2006;12(7):343-7. [pmid: 17059650].
698 Lamb SE, Pepper J, Lall R, et al. Group treatments for sensitive health care problems: a randomised controlled trial of group versus individual physiotherapy sessions for female urinary incontinence. BMC Womens Health. 2009;9:26. [pmid: 19751517].
699 Wing RR, West DS, Grady D, et al. Effect of weight loss on urinary incontinence in overweight and obese women: results at 12 and 18 months. J Urol. Sep. 2010;184(3):1005-10. [pmid: 20643425].
700 Karademir K, Baykal K, Sen B, et al. A peripheric neuromodulation technique for curing detrusor overactivity: Stoller afferent neurostimulation. Scand J Urol Nephrol. 2005;39(3):230-3. [pmid: 16118096].
701 Fitzgerald MP, Lemack G, Wheeler T, et al. Nocturia, nocturnal incontinence prevalence, and response to anticholinergic and behavioral therapy. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2008;19(11):1545-50. [pmid: 18704249].
702 Burgio KL, Kraus SR, Menefee S, et al. Behavioral therapy to enable women with urge incontinence to discontinue drug treatment: a randomized trial. Ann Intern Med. Aug. 5. 2008;149(3):161-9. [pmid: 18678843].
703 Zimmern P, Litman HJ, Mueller E, et al. Effect of fluid management on fluid intake and urge incontinence in a trial for overactive bladder in women. BJU Int. Jun. 2010;105(12):1680-5. [pmid: 19912207].
704 Herschorn S, Becker D, Miller E, et al. Impact of a health education intervention in overactive bladder patients. Can J Urol. Dec. 2004;11(6):2430-7. [pmid: 15636668].
705 Goode PS, Burgio KL, Kraus SR, et al. Correlates and predictors of patient satisfaction with drug therapy and combined drug therapy and behavioral training for urgency urinary incontinence in women. Int Urogynecol J. Mar. 2011;22(3):327-34. [pmid: 20945064].
706 Peters KM, Macdiarmid SA, Wooldridge LS, et al. Randomized trial of percutaneous tibial nerve stimulation versus extended-release tolterodine: results from the overactive bladder innovative therapy trial. J Urol. Sep. 2009;182(3):1055-61. [pmid: 19616802].
707 Franzen K, Johansson JE, Lauridsen I, et al. Electrical stimulation compared with tolterodine for treatment of urge/urge incontinence amongst women--a randomized controlled trial. Int Urogynecol J Pelvic Floor Dysfunct. Dec. 2010;21(12):1517-24. [pmid: 20585755].
708 Mattiasson A, Blaakaer J, Hoye K, et al. Simplified bladder training augments the effectiveness of tolterodine in patients with an overactive bladder. BJU Int. Jan. 2003;91(1):54-60. [pmid: 12614251].
709 Mattiasson A, Masala A, Morton R, et al. Efficacy of simplified bladder training in patients with overactive bladder receiving a solifenacin flexible-dose regimen: results from a randomized study. BJU Int. 2009. Oct. 10. [pmid: 19818077].
710 Chancellor MB, Kianifard F, Beamer E, et al. A comparison of the efficacy of darifenacin alone vs. darifenacin plus a Behavioural Modification Programme upon the symptoms of overactive bladder. Int J Clin Pract. Apr. 2008;62(4):606-13. [pmid: 18324952].
711 Berghmans LC, Frederiks CM, de Bie RA, et al. Efficacy of biofeedback, when included with pelvic floor muscle exercise treatment, for genuine stress incontinence. Neurourol Urodyn. 1996;15(1):37-52. [pmid: 8696355].
712 Goode PS, Burgio KL, Locher JL, et al. Effect of behavioral training with or without pelvic floor electrical stimulation on stress incontinence in women: a randomized controlled trial. JAMA. Jul. 16. 2003;290(3):345-52. [pmid: 12865375].
713 Wang AC, Wang YY, Chen MC. Single-blind, randomized trial of pelvic floor muscle training, biofeedback-assisted pelvic floor muscle training, and electrical stimulation in the management of overactive bladder. Urology. Jan. 2004;63(1):61-6. [pmid: 14751349].
714 Dmochowski RR, Blaivas JM, Gormley EA, et al. Update of AUA guideline on the surgical management of female stress urinary incontinence. J Urol. May. 2010;183(5):1906-14. [pmid: 20303102].
715 Nager CW, Kraus SR, Kenton K, et al. Urodynamics, the supine empty bladder stress test, and incontinence severity. Neurourol Urodyn. Sep. 2010;29(7):1306-11. [pmid: 20127832].
716 Martin JL, Williams KS, Sutton AJ, et al. Systematic review and meta-analysis of methods of diagnostic assessment for urinary incontinence. Neurourol Urodyn. 2006;25:674-83. [pmid: 17016795].
717 Abrams P. Identifying and evaluating urinary incontinence in a female population. Eur Urol. 1997;32(Suppl 2):1-2. [pmid: 9248805].
718 Ireton RC, Krieger JN, Cardenas DD, et al. Bladder volume determination using a dedicated, portable ultrasound scanner. J Urol. May. 1990;143(5):909-11. [pmid: 2184254].
719 Goode PS, Locher JL, Bryant RL, et al. Measurement of postvoid residual urine with portable transabdominal bladder ultrasound scanner and urethral catheterization. Int Urogynecol J Pelvic Floor Dysfunct. 2000;11(5):296-300. [pmid: 11052565].
720 Ouslander JG, Simmons S, Tuico E, et al. Use of a portable ultrasound device to measure post-void residual volume among incontinent nursing home residents. J Am Geriatr Soc. Nov. 1994;42(11):1189-92. [pmid: 7963206].
721 Ghoniem G, Stanford E, Kenton K, et al. Evaluation and outcome measures in the treatment of female urinary stress incontinence: International Urogynecological Association (IUGA) guidelines for research and clinical practice. International Urogynecology Journal. Jan. 2008;19(1):5-33. [pmid: 21118].
722 Campbell JD, Gries KS, Watanabe JH, et al. Treatment success for overactive bladder with urinary urge incontinence refractory to oral antimuscarinics: a review of published evidence. BMC Urol. 2009;9:18. [pmid: 19930578].
723 McDonagh MS, Selover D, Santa J, et al. Drug class review on agents for overactive bladder, Final report Oregon Health & Science University. Dec. 2005.
724 Layton D, Pearce GL, Shakir SA. Safety profile of tolterodine as used in general practice in England: results of prescription-event monitoring. Drug Saf. 2001;24(9):703-13. [pmid: 11522122].
725 Jumadilova Z, Varadharajan S, Girase P, et al. Retrospective evaluation of outcomes in patients with overactive bladder receiving tolterodine versus oxybutynin. Am J Health Syst Pharm. Dec. 1. 2006;63(23):2357-64. [pmid: 17106009].
726 Wang PS, Levin R, Zhao SZ, et al. Urinary antispasmodic use and the risks of ventricular arrhythmia and sudden death in older patients. J Am Geriatr Soc. Jan. 2002;50(1):117-24. [pmid: 12028256].
726 Wang PS, Levin R, Zhao SZ, et al. Urinary antispasmodic use and the risks of ventricular arrhythmia and sudden death in older patients. J Am Geriatr Soc. 2002;50(1):117-24. [pmid: 12028256].
727 Ioannidis JPA, Lau J. Heterogeneity of the baseline risk within patient populations of clinical trials: a proposed evaluation algorithm. Am J Epidemiol. 1998;148:1117-26. [pmid: 9850135].
728 Arends LR, Hoes AW, Lubsen J, et al. Baseline risk as predictor of treatment benefit: three clinical = meta-re-analyses. Stat Med. 2000;19:3497-518. [pmid: 11122510].
729 Thompson SG. Why sources of heterogeneity in meta-analysis should be investigated. BMJ. 1994;309:1351-5. [pmid: 7866085].
730 Ko Y, Malone DC, Armstrong EP. Pharmacoeconomic evaluation of antimuscarinic agents for the treatment of overactive bladder. Pharmacotherapy. 2006;26(12):1694-702. [pmid: 17125433].
731 Yu YF, Nichol MB, Yu AP, et al. Persistence and adherence of medications for chronic overactive bladder/urinary incontinence in the California Medicaid program. Value Health. 2005;8(4):495-505. [pmid: 16091027].
732 . Prescribing antimuscarinics for overactive bladder; how many chances do we have to get it right? Neurourology and Urodynamics; 2010; Joint Meeting of the International Continence Society and the International Urogynecological Association, Toronto, Canada, 23-27 August 2010. 29.
733 Perfetto EM, Subedi P, Jumadilova Z. Treatment of overactive bladder: a model comparing extended-release formulations of tolterodine and oxybutynin. Am J Manag Care. Suppl. 2005;11(4):S150-7. [pmid: 16161388].
734 Hughes DA, Dubois D. Cost-effectiveness analysis of extended-release formulations of oxybutynin and tolterodine for the management of urge incontinence. Pharmacoeconomics. 2004;22(16):1047-59. [pmid: 15524493].
735 O'Brien BJ, Goeree R, Bernard L, et al. Cost-Effectiveness of tolterodine for patients with urge incontinence who discontinue initial therapy with oxybutynin: a Canadian perspective. Clin Ther. 2001;23(12):2038-49. [pmid: 11813937].
736 Varadharajan S, Jumadilova Z, Girase P, et al. Economic impact of extended-release tolterodine versus immediate- and extended-release oxybutynin among commercially insured persons with overactive bladder. Am J Manag Care. Suppl. 2005;11(4):S140-9. [pmid: 16161387].
737 Wieseler B, McGauran N, Kaiser T. Finding studies on reboxetine: a tale of hide and seek. BMJ. 2010;341:c4942. [pmid: 20940211].
738 Imamura M, Abrams P, Bain C, et al. Systematic review and economic modelling of the effectiveness and cost-effectiveness of non-surgical treatments for women with stress urinary incontinence. Health Technol Assess. 2010;14(40):1-188. [pmid: 20738930].
739 National Institute for Health and Clinical Excellence. Percutaneous posterior tibial nerve stimulation for overactive bladder syndrome: guidance. Oct 27 2010http://www.nice.org.uk/nicemedia/live/12412/51304/51304.pdf
740 Goode PS, Burgio KL, Richter HE, et al. Incontinence in older women. JAMA. 2010;303(21):2172-81. [pmid: 20516418].
741 Thuroff JW, Abrams P, Andersson KE, et al. EAU Guidelines on Urinary Incontinence. Eur Urol. 2011;59(3):387-400. [pmid: 21130559].