# Peer Reviewers

We considered peer reviewer comments on a preliminary draft of this report in the preparation of this final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

Matthew Barber, M.D.

Cleveland Clinic

Cleveland, OH

Sandra Engberg, Ph.D., R.N., CRNP

University of Pittsburgh

Pittsburgh, PA

Ingrid Nygaard, M.D.

University of Utah School of Medicine

Salt Lake City, UT

Eric Rovner, M.D.

Medical University of South Carolina

Charleston, SC

David Thom, M.D. M.P.H., Ph.D.

San Francisco General Hospital

San Francisco, CA