# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, we consulted several technical and content experts. Broad expertise and perspectives are sought. Divergent and conflicted opinions are common and perceived as health scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, and/or methodologic approaches do not necessarily represent the views of individual technical and content experts.

Alan M. Adelman, M.D., M.S.

Penn State University

Hershey, PA

Apostolos Panagiotis Dallas, M.D.

Carilion Roanoke Memorial Hospital

Roanoke, VA

Catherine DuBeau, M.D.

UMass Memorial Medical Center

Worcester, MA

Mary Forciea, M.D., FACP

University of Pennsylvania

Philadelphia, PA

Leah Hole-Curry, J.D.

Washington Health Care Authority

Olympia, WA

Diane Newman, R.N.C., M.S.N., CRNP, FAAN

University of Pennsylvania Medical Center

Philadelphia, PA

Ingrid Nygaard, M.D.

University of Utah School of Medicine

Salt Lake City, UT

Mary Patrick, R.N.

Department of Public Health & Human Services

Helena, MT

Suzanne Pope, M.B.A.

American Urological Association

Linthicum, MD

Amir Qaseem, M.D., Ph.D., M.H.A., FACP

American College of Physicians

Philadelphia, PA

Kenneth G. Schellhase, M.D., M.P.H.

Medical College of Wisconsin

Milwaukee, WI

Paul Shekelle, M.D.

RAND Corporation

Santa Monica, CA

J. Christian Winters, M.D., FACS

LSU Health Sciences Center

Metairie, LA