# Key Informants

Alan M. Adelman, M.D., M.S.

Penn State University

Hershey, PA

Apostolos Panagiotis Dallas, M.D.

Carilion Roanoke Memorial Hospital

Roanoke, VA

Catherine DuBeau, M.D.

UMass Memorial Medical Center

Worcester, MA

Mary Forciea, M.D., FACP

University of Pennsylvania

Philadelphia, PA

Jessica Griffin, M.S.

Oregon Evidence-based Practice Center

Portland, OR

Leah Hole-Curry, J.D.

Washington Health Care Authority

Olympia, WA

Lore Joplin

Oregon Health & Science University

Portland, OR

Kay Mattson, M.S.W., M.P.H.

Oregon Health and Science University

Portland, OR

Diane Newman, R.N.C., M.S.N., CRNP FAAN

University of Pennsylvania Medical Center

Philadelphia, Pennsylvania

Ingrid Nygaard, M.D.

University of Utah School of Medicine

Salt Lake City, UT

Mary Patrick, R.N.

Department of Public Health & Human Services

Helena, MT

Suzanne Pope, M.B.A.

American Urological Association

Linthicum, MD

Amir Qaseem, M.D., Ph.D., M.H.A., FACP

American College of Physicians

Philadelphia, PA

Kenneth G. Schellhase, M.D., M.P.H.

Medical College of Wisconsin

Milwaukee, WI

Paul Shekelle, M.D.

RAND Corporation

Santa Monica, CA

J. Christian Winters, M.D., FACS

LSU Health Sciences Center

Metairie, LA