# Discussion

## Key Findings

A number of important findings emerged from this review.

### Diagnosis

Clinical evaluation with validated tools for diagnosis of UI, its type, frequency, severity, and impact on quality of life informs nonsurgical treatment decisions.

Compared with diagnosis by patients’ symptom reports, multichannel urodynamics did not better predict which patients would benefit from nonsurgical treatments.

### Measuring Treatment Success

Women with daily stress UI perceived important clinical benefit from reductions of approximately 50 percent in UI frequency, and important incremental clinical value from reductions of 75 percent and 90 to 100 percent.

Women reported improved quality of life and clinical success only when they experienced a greater than 70 percent reduction in UI episode frequency assessed by a voiding diary.

More than 60 percent of women with persistent urgency, stress, or mixed UI reported complete treatment satisfaction when they experienced more than 70 percent reduction of UI episodes. Validated tools have been used to assess minimum important differences in UI in women.

Validated tools have been used to assess threshold values of clinical importance for evaluating treatment success.

### Pharmacological Treatments

All anticholinergic medications were more effective than placebo in achieving continence and improving UI, but the degree of benefit was low for all drugs, with fewer than 200 cases of continence attributable to treatment per 1,000 patients treated (absolute risk difference with placebo <20 percent).

Treatment benefits, including continence, were achieved with antimuscarinic drugs, including trospium, solifenacin, fesoterodine, tolterodine, and oxybutynin.

Drugs for urgency UI demonstrated similar effectiveness. Treatment discontinuation due to adverse effects was most common with oxybutynin and least common with solifenacin.

Pharmacological treatments for stress UI, including off-label use of low-dose topical estrogen formulations, may improve stress UI in postmenopausal women.

Duloxetine has an unfavorable balance between improvement in stress UI and treatment discontinuation due to adverse effects.

Compliance rates for prescription drugs are low; discontinuation due to side effects is common. Dry mouth, constipation, and blurred vision were among the most frequent adverse effects.

There is insufficient evidence of the long-term safety of pharmacological treatments.

Women with urgency UI whose prior treatments failed may benefit from solifenacin; however, poor responders would not benefit from increasing the dose of the drug.

Oxybutynin, trospium, and darifenacin improved UI in older women.

### Nonpharmacological Treatments

Nonpharmacological treatments result in significant clinical benefit with a low risk of adverse effects. The magnitude of benefit is large, with more than 100 percent relative difference in continence rates. Women with stress UI can achieve continence performing PFMT. Continence rates are similar between those who undergo PFMT with and without biofeedback.

### UI Diagnosis

Diagnosis of different types of UI in ambulatory care settings includes clinical history and evaluation, voiding diary, and validated scales. Urodynamic diagnosis is more invasive and not applicable to ambulatory settings. Although it more sensitively distinguishes detrusor overactivity, it did not better predict treatment benefits for patients undergoing nonsurgical UI treatments. Baseline urodynamic diagnosis did, however, better predict harms from surgery for women with refractory stress UI by identifying women with detrusor overactivity, which is associated with greater risk of postsurgical urgency UI. Diagnosis of pure urodynamic stress UI or detrusor overactivity can influence treatment decisions for women undergoing surgical treatments for urogenital prolapse or pelvic floor trauma.345,714 An ongoing trial conducted by the Urinary Incontinence Treatment Network will shed light on the association between utility of urodynamic testing and better prediction of outcomes of stress UI surgery.715

Previously published systematic reviews also demonstrated a weak association between self-reported UI symptoms and instrumental urodynamic findings.73,716 However, investigators still use urodynamic evaluation as a reference method. In contrast, guidelines recommend urodynamic evaluation as one component of the complex algorithm for women with pelvic floor dysfunction.10 Evaluations of women who report UI symptoms begin with physical examination and exclusion of several potential underlying conditions, including urinary tract infection, pelvic organ prolapse, poor bladder emptying, and post-void residual volume determination.69 Examination methods for urinary tract infection and pelvic organ prolapse have been addressed by previous reviews, and are beyond our scope.69,717 Measurement of PVR urine volume can be used to diagnose UI associated with poor bladder emptying. Some experts consider urinary catheterization the gold standard for measuring PVR.718 However, invasive urinary catheterization can be performed only in specialized care settings. Portable ultrasound is an accurate and feasible method for estimating PVR urine volume in ambulatory care settings.719,720 Ultrasound is preferable to catheterization when decreased bladder emptying is suspected.69 Vaginal and transrectal ultrasound accurately diagnosed urodynamic stress UI.291,292 Other instrumental radiological and magnetic resonance imaging is useful for diagnosis of anatomical pelvic pathology including fibroids, ovarian and uterine tumors, foreign bodies, or diverticulum.10 Associations are unclear between the criteria for excessive bladder neck mobility identified via ultrasound or MRI and UI treatment outcomes.

Considering the multifactorial syndromatic nature of UI, any one instrument, symptom, or test cannot accurately diagnosis UI type. Clinicians utilize several aspects of patient history, pelvic exam, and other assorted factors to determine UI type and severity.

#### Diagnosis of Baseline Frequency, Severity, and Bothersomeness of UI

Urodynamic evaluations diagnose the presence of UI but not baseline severity, frequency, or bothersomeness of the condition, all of which help inform the best treatment options. Ambulatory care physicians may choose between several validated tools for diagnosing predominant stress or urgency UI and for judging treatment effectiveness. Treatment effectiveness for female UI should be assessed according to issues women value: 50 to 70 percent or greater reduction in UI episode frequency, meaningful changes in quality of life measures, and overall treatment satisfaction.721 Women do not consider small reductions in UI frequency or in urinary loss as treatment success, even though such reductions are statistically significant.295 Clinically important differences have been determined for several questionnaires and scales.259,264,296–299 Many validated tools are available to monitor quality of life in women with different UI types. Several tools that define clinically important differences in scores can be used to assess treatment success in clinical settings.300–302 All tools for assessing symptom bother have been validated. The Incontinence Severity Index,334,335 Patient Global Impression of Improvement and of Severity,331 Urogenital Distress Inventory,222,336,337 and Patient Perception of Bladder Condition333,338,339 have identified minimum thresholds levels for improvements of clinical importance in UI. Treatment success in clinical settings can be determined according to improvements that meet or exceed these threshold levels.

### UI Treatment

#### Defining and Measuring Outcomes of Treatments for UI

Meaningful assessment of treatment outcomes depends on how those outcomes are defined. Market approval and coverage decisions have been made based on intermediate outcomes rather than on continence or on women’s treatment satisfaction. Despite intensive discussions about the importance of patient centered outcomes, the majority of drug studies aimed to detect statistical differences in the frequency of UI episodes. The most common outcome examined by RCTs was a reduction in UI episode frequency.115,305–326 Previous reviews of drugs for overactive bladder also focused on a reduction in the frequency of UI episodes and the frequency of micturitions.112,722,723 The FDA reviews focused primarily on the same continuous reduction in UI episode frequency, and not on continence or self-reported treatment success and satisfaction.115,306,307,327–330 In contrast, our review emphasized the role of clinical outcomes, including continence, quality of life, and adverse effects of treatment.

#### Treatments for UI

PFMT, bladder training, and electrical stimulation more often result in continence than does no active treatment. Weight loss and exercise improve UI in obese women. Long-term adherence to and benefits of these treatments are not clear, nor are specific characteristics of women associated with better benefits and compliance. The best time to start pelvic muscle floor exercise and bladder training in relation to either menopause or the onset of UI is not clear. Adverse effects with nonpharmacological treatments were uncommon and the magnitude of effect was large.

All drugs for overactive bladder, when compared to placebo, demonstrated better rates of continence and improved UI. All drugs offered similar benefits, but treatment discontinuation due to adverse effects was most common with oxybutynin. Informed decisions, therefore, should consider the drugs’ adverse effects. RCTs rarely reported long-term comparative drug safety. In contrast with RCTs, continuous prescription-event monitoring as a part of postmarketing surveillance has provided valuable information about unfavorable long-term safety of tolterodine, which posed significantly higher risk of hallucinations than 10 drugs of other therapeutic classes.724 Postmarketing surveillance may provide data on long-term safety of UI drugs when combined with other medications for comorbidities. RCTs did not examine the role of concurrent treatments. For instance, limited information exists on the cognitive effects of drugs in older adults. Older adults had lower risk of depression with tolterodine ER than with oxybutynin IR group (HR, 0.865; 95 percent CI, 0.78 to 0.95).725 The relative risks of ventricular arrhythmias (adjusted RR 5.5, 95 percent CI, 1.3 to 22.3) or sudden death (adjusted RR 21.5, 95 percent CI, 5.2 to 88.3) were very high in elderly patients using UI medications in combination with antihistamine/cytochrome inhibitors.726

Only a few RCTs examined the comparative effectiveness of drugs and nonpharmacological treatments. Direct evidence was insufficient to draw valid conclusions about the benefits of combined modalities compared to monotherapy. Existing guidelines recommend PFMT combined with stress and bladder training as the first treatment choice for women with urgency UI but do not provide evidence-based recommendations about combined therapy.118 Other guidelines list many treatment options, including electrical intravaginal stimulation and percutaneous tibial nerve stimulation, but do not provide evidence-based recommendations about first therapy options or combined modalities. Existing guidelines may provide individualized treatment recommendations based on age or predominant type of UI, but they do not address baseline severity of UI or comorbidities.

Meanwhile, very few studies provided evidence for individualized treatment decisions. Evidence of aggregate treatment effects may not be applicable to individuals with specific characteristics.727 An average treatment effect in a clinically diverse population may not reflect the actual effect for a specific group.728 Yet, few existing studies examined the role of clinical predictors of treatment failure and success in patient subpopulations.729 Patient comorbidity and baseline severity of UI were associated with differences in treatment benefits. The direction and magnitude of the association varied. Benefits from solifenacin and fesoterodine were greater in those with more than two or three daily episodes of UI; trospium was not better than placebo in those with frequent baseline UI (>5 episodes/day). We are not certain which factors are associated with differences in harms.

Very limited evidence exists for long-term benefits and harms from drugs and nonpharmacological treatments for UI. The bulk of RCTs reported clinical outcomes at 12 to 24 weeks of treatment. A few nonrandomized studies and long-term followup RCTs reported rates of benefits and harms with active treatments, but did not include control comparisons. Such uncontrolled crude rates cannot provide valid information about long-term effects.

Very few studies addressed adherence to prescribed nonpharmacological and drug regimens. Observational economic evaluations730–732 demonstrated greater absolute rates of treatment discontinuation due to adverse effects or treatment failure than have been demonstrated in RCTs. Long-term adherence to drug treatment for overactive bladder was as low as 13 percent.725 Among possible explanatory factors for poor adherence is that polypharmacy or previous use of the drugs for urinary tract infections was associated with adherence to drugs for overactive bladder in California Medicaid program beneficiaries.731

Cost-effectiveness analyses730,733–736 were beyond the scope of our review. Our review provides valid information about treatment benefits according to patient-centered outcomes including continence, and about adverse effects that can be used for cost-effectiveness analyses.

The quality of most drug RCTs was good. The majority of drug studies were double blind with adequate randomization, clear reporting of planned intention to treat analysis, and adequate allocation concealment. Benefits and harms with drugs did not differ by individual quality criteria. We concluded low risk of bias in drug studies.

The quality of most nonpharmacological RCTs was good. Baseline data demonstrated adequacy of randomization in the majority of RCTs. Double or single blinding was reported in approximately half of RCTs. Quality of the studies, including intention to treat principle and adequacy of allocation concealment, did not demonstrate significant modification of the association between treatments and patient outcomes. We concluded moderate risk of bias in nonpharmacological studies.

Our review has limitations. We restricted our review to English language studies published in journals, presented at scientific meetings, reviewed by the FDA,737 or reported on the ClinicalTrials.gov Web site. Even after such an exhaustive review of evidence, we do not know how many studies we missed in our review. We did not review regulatory documents or grant databases from other countries. Evidence was insufficient for individualized treatment recommendations by age, race, comorbidity, and baseline UI. Evidence specific to women whose prior treatments had failed was also insufficient. However, previous research has demonstrated that women with stress UI whose conservative treatments failed may benefit from tension-free vaginal tape procedure.738 For women with urgency UI whose conservative treatments failed, percutaneous tibial nerve stimulation,739 sacral neuromodulation,740 and botulinum toxin injections741 may be of benefit. We were unable to explain the substantial variability in outcome rates with placebo treatments. Future large, well-designed head-to-head randomized trials may conclude superior efficacy of combined treatment modalities with nonsurgical treatments.

Our findings can inform clinicians’ evidence-based recommendations for UI diagnosis and management (Tables 17 and 18). Ambulatory care physicians may arrive at treatment decisions and monitor treatment effectiveness by diagnosing predominant stress or urgency UI and evaluating the frequency, severity, and quality of life at baseline and with treatment. Nonpharmacological treatments offer a better balance between benefits and adverse effects than do drugs. First treatment choice, therefore, might be based on known benefits and harms with nonpharmacological and drug treatments, along with patient preference. Evidence was insufficient to conclude better benefits from nonpharmacological treatments combined with drugs. Women’s opinions about treatment success should be considered before combining nonpharmacological treatments with available drugs or increasing the doses of the drugs.

Table 17 Conclusions about diagnosis of UI in women

Conclusions about diagnosis of UI | Level of evidence
Symptoms of stress UI, urgency, or urgency UI have minimal or small diagnostic value to identify women with urodynamic stress UI or detrusor overactivity. | High
Complex clinical algorithms demonstrated better diagnostic performance than symptoms. Individual studies suggested good diagnostic value for questionnaires on the epidemiology of prolapse and incontinence. | Moderate
Women in ambulatory care settings can be accurately diagnosed with UI after obtaining clinical history and evaluation, a voiding diary to assess predominant stress or urgency UI, cough stress test, and exclusion of urogenital prolapse and urinary tract infections. | High
Decisions to start treatments can be based on assessment of frequency, severity, and bothersomeness of UI with validated tools. | High
Urodynamic examination was not associated with better outcomes after nonsurgical treatments for UI. | Moderate
Monitoring treatment success can address differences in the voiding diary (>50–70 percent in frequency of UI episodes) and scales measuring quality of life that are important for women, and womens’ impressions of global improvement and treatment satisfaction. A variety of the validated tools are available to monitor quality of life in women with UI and with different UI types. Several tools that can define clinically important differences in scores can be used to assess treatment success in clinical settings. | High

Table 18 Conclusions about management of UI in women

Conclusions | Level of evidence
Drug treatment for predominant stress UI
Duloxetine was worse than placebo at resolving stress UI. | Low
Duloxetine improved stress UI in women. | High
Risk of adverse effects was significantly higher with duloxetine compared to placebo. Women stopped taking the drug because of nausea, somnolence, insomnia, dizziness, headache, fatigue, diarrhea, and constipation. | High
Drug treatment for predominant urgency UI
Oxybutynin increased continence rates and improved UI compared to placebo. | High
Oxybutynin increased treatment discontinuation due to adverse effects compared to placebo. Dry mouth was the most common adverse effect. | High
Immediate-release oxybutynin resulted in greater rates of adverse effects and dry mouth when compared to controlled-release oral or transdermal oxybutynin. | Low
Higher vs. lower doses of oxybutynin resulted in greater improvement in UI, the same rates of dry mouth, but greater treatment withdrawal. | Low
Tolterodine increased continence rates and improved UI when compared to placebo. | High
Tolterodine improved quality of life in women with urgency UI. | Low
Adverse effects, including autonomic nervous system disorders, abdominal pain, dry mouth, dyspepsia, and fatigue, were significantly more common in women taking tolterodine compared to placebo. | High
Discontinuation of the treatment and stopping the treatment due to adverse effects did not differ with tolterodine compared to placebo. | High
Darifenacin, 7.5 and 15 mg, improved urgency UI and several domains of quality of life when compared to placebo. | High
Adverse effects were more common with darifenacin than placebo. Among examined adverse effects, darifenacin increased rates of constipation, dry mouth, dyspepsia, and headache. | Moderate
Larger dose, 30 mg of darifenacin/day, did not result in better benefits but caused greater rates of adverse effects. | High
Treatment discontinuation rates because of adverse effects were the same with darifenacin vs. placebo. | High
Solifenacin increased continence rates, with greater benefits with the larger dose of the drug in women with urgency and mixed UI. | High
Solifenacin increased risk of dry mouth, constipation, and blurred vision; 10 mg of solifenacin increased the risk of severe dry mouth and constipation. | High
Treatment discontinuation because of adverse effects was more common with solifenacin compared to placebo. | High
Fesoterodine increased continence rate when compared to placebo. | Low
Fesoterodine improved urgency UI compared to placebo, with a better response with 8 mg vs. 4 mg. | High
Fesoterodine improved quality of life in women with urgency UI. | Low
Fesoterodine treatment resulted in higher rates of adverse effects and discontinuation of the treatments because of adverse effects compared to placebo. Adverse effects were more common with 8 mg compared to 4 mg of fesoterodine. | High
Trospium increased continence rate when compared to placebo. | High
Women experienced dry mouth, dry eye, dry skin, and constipation more often with the drug than with placebo. | Moderate
Treatment discontinuation because of adverse effects was more common with trospium than with placebo. | High
Fesoterodine resulted in greater rates of continence when compared to tolterodine. | Low
Fesoterodine resulted in greater rates of improved UI when compared to tolterodine. | High
Fesoterodine resulted in greater treatment discontinuation due to adverse effects when compared to tolterodine. | Moderate
Oxybutynin resulted in greater treatment discontinuation due to adverse effects when compared to tolterodine. | High
Improvement in UI did not differ with oxybutynin when compared to tolterodine. | Moderate
Adherence to drug treatments is low; more than 50 percent of women stopped treatments within 1 year. | Moderate
Role of women characteristics in association with treatment effects
Age did not modify the effects of the tested drugs on examined clinical outcomes. | Moderate
Duloxetine was no better than a placebo in improving UI in older women. | High
Solifenacin increased continence rate when compared to placebo, irrespective of age. | High
Baseline frequency of UI did not dramatically modify the effects of the drugs on clinical outcomes. Subjects with more frequent UI had slightly greater benefits when compared to placebo. | Low
Solifenacin was effective irrespective of the response to previous treatments, even though poor responders did not benefit from increasing the dose of the drug. | High
Trospium was more effective than placebo in achieving continence in obese and nonobese adults. | High
Trospium reduced number of urgency UI episodes irrespective of taking concomitant drugs. Adverse effects were more common in those taking seven or more concomitant medications. | Moderate
Nonpharmacological treatments
Stress UI
Pelvic floor muscle training increased continence rate and improved UI when compared to no active treatment. | High
PFMT also improved several domains of quality of life in women with UI. | Low
PFMT with biofeedback increased continence rate when compared to usual care. | Low
PFMT with biofeedback improved UI when compared to usual care. | High
Electrical stimulation increased continence rate and improved UI when compared to sham stimulation. | High
Electrical stimulation improved quality of life when compared to sham stimulation. | Moderate
Magnetic stimulation improved UI but did not increase urinary continence rates when compared to sham stimulation. | Moderate
Magnetic stimulation improved quality of life. | Low
Uncontrolled studies of intravaginal and intraurethral devices demonstrated improvement in UI but also high discontinuation rates and evident harms. | Low
Continence did not differ with PFMT + biofeedback when compared to PFMT. | High
Continence did not differ with supervised PFMT when compared to PFMT. | High
Continence did not differ with PFMT when compared to electrical stimulation. | Moderate
Urgency UI
Bladder training improved UI compared to usual care. | Low
PFMT combined with bladder training increased continence rate and improved UI. | High
PFMT combined with bladder training reduced severity of UI. | Low
Percutaneous tibial nerve stimulation improved predominant urgency UI. | Moderate
Continence did not differ with PFMT + bladder training when compared to bladder training. | High
Mixed UI
Continence services that were implemented by specialized health care providers increased continence and improved UI when compared to usual care. | Low
Weight loss and exercise improved UI in obese women. | Moderate
Acupuncture improved quality of life when compared to sham acupuncture. | Low

## Future Research

Our report points to areas for future research (Table 19). First, future research should clarify which female characteristics are associated with greater benefits and lower harms of treatments and better treatment adherence. Second, treatment success should be assessed with outcomes centered on women, including long-term continence, clinically important reduction in UI episodes, and improvement in scales of severity and quality of life. More work is needed on how physiological measures correspond with symptoms. Third, all harms should be analyzed, regardless of investigator judgment about possible association with tested treatments. Fourth, better drugs are needed. Few of the currently used medications are sustained for even a year, and fewer still are very effective. Fifth, nonsurgical treatments for predominant stress UI are limited to PFMT, with very few ongoing studies of bulking agents and devices. One issue with PFMT is sustaining it. Programs should explore how to extend the period of adherence. Future research should explore new treatment options for women with stress UI and should also address the preventive potential of various nonpharmacological treatments, including PFMT, bladder training, and electrical stimulation, for premenopausal women. The results from all studies, including 25 closed and 124 ongoing registered studies, should be made available for future reviews of the evidence.

Table 19 Future research recommendations

Key question | Results of literature review | Types of studies needed to answer question | Future research recommendation
What constitutes an adequate diagnostic evaluation for women in the ambulatory care setting on which to base treatment of urinary incontinence (UI)? | Symptoms of stress UI, urgency, or urgency UI have minimal or small diagnostic value to identify women with pure urodynamic stress UI or detrusor overactivity. Urodynamic examination was not associated with better outcomes after nonsurgical treatments for UI. Monitoring treatment success can address differences in the voiding diary (>70 percent in the frequency of UI episodes) and scales measuring quality of life that are important for women, and women’s impressions of global improvement and treatment satisfaction. | Observational studies | Examine the association between diagnostic algorithms that include voiding diary, validated questionnaires to determine frequency and severity of pure or predominant stress and urgency UI, and baseline quality of life with or without portable ultrasound with the effects of nonpharmacological treatments. Determine minimal clinically important reduction in frequency and severity of different types of UI in women subpopulations by age, baseline severity and frequency, and bothersomeness. Examine the association between diagnostic values with women’s treatment preferences. Determine whether women in clinical settings receive adequate diagnostic evaluation to differentiate pelvic floor trauma, pelvic organ prolapsed, urinary tract infection, and UI associated with poor bladder emptying. Examine treatment effects in women who failed initial diagnostic evaluation (delayed diagnosis).
How effective is the pharmacological treatment of UI in women? | Women with predominant urgency UI may achieve continence taking antimuscarinic drugs including trospium, solifenacin, fesoterodine, tolterodine, or oxybutynin. Degree of the benefits was low for all drugs (absolute risk difference <20 percent). Drugs demonstrated similar effectiveness, but treatment discontinuation due to adverse effects was most common after oxybutynin and least common after solifenacin. Dry mouth, constipation, and blurred vision are among the most frequent adverse effects. Evidence of long-term safety of pharmacological treatments is insufficient. | Head-to-head trials Pooled analysis of individual patient data | Examine effectiveness of the drugs on long term continence and adverse effects in women with pure urgency vs. mixed UI. Examine comparative effectiveness of all available antimusarinic drugs on continence, reduction by 70% in UI episodes, quality of life, adverse effects, and discontinuation due to adverse effects in female subgroups by age, race, baseline predominant type and severity of UI, comorbidities, and prior treatment status.
How effective is the nonpharmacological treatment of UI in women? | Nonpharmacological treatments result in significant clinical benefit with low risk of adverse effects. Women with predominant stress UI can achieve continence performing PFMT. Continence rates are similar between those who undergo PFMT with and without biofeedback. Women with predominant urgency UI can achieve continence performing PFMT with bladder training and/or electrical stimulation. Weight loss may improve UI in obese women. | Head-to-head trials Pooled analysis of individual patient data | Examine effectiveness of nonpharmacological treatments on long-term continence and treatment adherence in women with pure urgency or stress vs. mixed UI. Examine comparative effectiveness of nonpharmacological treatments on continence, reduction by 70% in UI episodes, quality of life, and treatment adherence in female subgroups by age, race, baseline predominant type and severity of UI, comorbidities, and prior treatment status. Examine continence in women with UI by the onset time of UI and the order of the prescribed nonpharmacological treatments. Examine which women subpopulations may benefit from combined (drugs + nondrug) treatments. Examine the effectiveness of different methods for delivering nonpharmacological treatments on short-term and long-term continence, reduction by 70% in UI episodes, quality of life, and treatment adherence in female subgroups by age, race, baseline predominant type and severity of UI, comorbidities, and prior treatment status.