# Appendixes

Appendix A Search Strings

Appendix B Excluded Studies

Appendix C Analysis of Results From Ongoing Studies

Appendix D Analytical Framework

Appendix E Abstraction Forms

Appendix F Evidence Tables and Evidence Figures