# Evidence Tables and Evidence Figures

Appendix Table F1 Grading the level of evidence for clinical outcomes that were examined in RCTs (direct evidence)

Appendix Table F2 Review of grey literature

Appendix Table F3 Quality Assessment of Diagnostic Accuracy Studies (QUADAS)

Appendix Table F4 Eligible studies of diagnostic methods

Appendix Figure F1 Distribution of sample sizes of studies of diagnostic values of tests for UI

Horizontal axis - categories of the sample size of the studies

Vertical axis - number of studies

Figure F1 is a bar graph that shows the distribution of sample sizes of studies of diagnostic values of tests for UI. The data came from the analysis of the sample sizes of 99 studies that reported diagnostic values of the tests for UI. The horizontal axis represents the following categories of the sample size of the studies: more than 10,000, more than 1,000, between 500 and 1,000, between 100 and 500, and less than 100 enrolled subjects. The vertical axis represents a number of studies. Black bars demonstrate the number of the studies for each category of the sample size. The figure demonstrated that the majority of the studies (56 studies) enrolled between 100 and 500 subjects.

Appendix Table F5 Diagnostic value of symptoms of stress incontinence compared to multichannel urodynamics (“gold standard”) for stress UI

Appendix Figure F2 Sensitivity of symptoms of stress incontinence compared to multichannel urodynamics (“gold standard”) for any stress UI69,72–75,78,82,83,85,88–92,97–103,105,106,131–134

Figure F2 is a forest plot diagram depicting sensitivity of symptoms of stress incontinence compared to multichannel urodynamics (“gold standard”) for any stress UI. The data came from 27 studies. The plot has two columns. The left-hand column lists the last name of the first author for each study and the year of publication. The right-hand column is a plot of sensitivity as percentage with 95% CI of patients with urodynamic stress UI who had symptoms of stress incontinence. Pooled with random effects model mean sensitivity is presented by a square incorporating confidence intervals represented by horizontal lines. The figure demonstrates that, on average, 93% (95% CI 90; 95) of women with symptoms of stress UI have positive urodynamic diagnosis of stress UI.

Appendix Figure F3 Specificity of symptoms of stress incontinence compared to multichannel urodynamics (“gold standard”) for any stress UI69,72–75,78,82,83,85,88–92,97–103,105,106,131–134

Figure F3 is a forest plot diagram depicting specificity of symptoms of stress incontinence compared to multichannel urodynamics (“gold standard”) for any stress UI. The data came from 27 studies. The plot has two columns. The left-hand column lists the last name of the first author for each study and the year of publication. The right-hand column is a plot of specificity as percentage with 95% CI of the subjects without urodynamic stress UI and without symptoms of stress incontinence. Pooled with random effects model mean specificity is presented by a square incorporating confidence intervals represented by horizontal lines. The figure demonstrates that on average, 41% (95% CI 34; 49) of women without symptoms of stress UI have negative urodynamic tests of stress UI.

Appendix Table F6 Pooled diagnostic value of symptoms of stress incontinence compared to multichannel urodynamics (“gold standard”) for any stress UI69,72–75,78,82,83,85,88–92,97–103,105,106,131–134

Appendix Table F7 Diagnostic value of urgency UI symptoms compared to multichannel urodynamics (“gold standard”) for detrusor overactivity

Appendix Figure F4 Sensitivity of urgency UI symptoms compared to multichannel urodynamics (“gold standard”) for any detrusor overactivity72–75,78,82–85,88–91,97–99,102–106,133,134

Figure F4 is a forest plot diagram depicting sensitivity of urge symptoms compared to multichannel urodynamics (“gold standard”) for any detrusor overactivity. The data came from 23 studies. The plot has two columns. The left-hand column lists the last name of the first author for each study and the year of the publication. The right-hand column is a plot of sensitivity as percentage with 95% CI of the subjects with symptoms of urgency UI and positive urodynamic diagnosis of detrusor overactivity. Pooled with random effects model mean sensitivity is presented by a square incorporating confidence intervals represented by horizontal lines. The figure demonstrates that on average, 82% (95% CI 76; 87%) of women with symptoms of urgency UI have a positive urodynamic test of detrusor overactivity.

Appendix Figure F5 Specificity of urgency UI symptoms compared to multichannel urodynamics (“gold standard”) for any detrusor overactivity72–75,78,82–85,88–91,97–99,102–106,133,134

Figure F5 is a forest plot diagram depicting specificity of urge symptoms compared to multichannel urodynamics (“gold standard”) for any detrusor overactivity. The data came from 23 studies. The plot has two columns. The left-hand column lists the last name of the first author for each study and the year of the publication. The right-hand column is a plot of specificity as a percentage with 95% CI of the subjects without symptoms of urgency UI and with negative urodynamic tests for detrusor overactivity. Pooled with random effects model mean specificity is presented by a square incorporating confidence intervals represented by horizontal lines. The figure demonstrates that on average, 51% (95% CI 44; 59) of women without symptoms of urgency UI have a negative urodynamic test for detrusor overactivity.

Appendix Table F8 Diagnostic value of urgency UI symptoms compared to multichannel urodynamics (“gold standard”) for pure detrusor overactivity

Appendix Figure F6 Sensitivity of urgency UI symptoms compared to multichannel urodynamics (“gold standard”) for pure detrusor overactivity72–75,82,83,85,88,90,91,95–98,102,103,105

Figure F6 is a forest plot diagram depicting sensitivity of urge symptoms compared to multichannel urodynamics (“gold standard”) for pure detrusor overactivity. The data came from 17 studies. The plot has two columns. The left-hand column lists the last name of the first author for each study and the year of the publication. The right-hand column is a plot of sensitivity as percentage with 95% CI of the subjects with symptoms of urgency UI and with positive urodynamic test for pure detrusor overactivity (meaning detrusor overactivity without urodynamic stress urinary incontinence). Pooled with random effects model mean sensitivity is presented by a square incorporating confidence intervals represented by horizontal lines. The figure demonstrates that on average, 84% (95% CI 78; 89) of women with symptoms of urgency UI have a positive urodynamic test for pure detrusor overactivity.

Appendix Figure F7 Specificity of urgency UI symptoms compared to multichannel urodynamics (“gold standard”) for pure detrusor overactivity72–75,82,83,85,88,90,91,95–98,102,103,105

Figure F7 is a forest plot diagram depicting specificity of urge symptoms compared to multichannel urodynamics (“gold standard”) for pure detrusor overactivity. The data came from 17 studies. The plot has two columns. The left-hand column lists the last name of the first author for each study and the year of publication. The right-hand column is a plot of specificity as percentage with 95% CI of the subjects without symptoms of urgency UI and with negative urodynamic test for pure detrusor overactivity (meaning detrusor overactivity without urodynamic stress UI). Pooled with random effects model mean specificity is presented by a square incorporating confidence intervals represented by horizontal lines. The figure demonstrates that on average, 43% (95% CI 36; 50) of women without symptoms of urgency UI have a negative urodynamic test for pure detrusor overactivity.

Appendix Table F9 Pooled Diagnostic value of urgency UI symptoms compared to multichannel urodynamics (“gold standard”) for pure detrusor overactivity

Appendix Table F10 Diagnostic value of urgency symptoms with or without UI compared to multichannel urodynamics (“gold standard”) for detrusor overactivity

Appendix Figure F8 Sensitivity of urgency symptoms with or without UI compared to multichannel urodynamics (“gold standard”) for any detrusor overactivity68,72–74,84,97,103,105,106

Figure F8 is a forest plot diagram depicting sensitivity of urgency symptoms compared to multichannel urodynamics (“gold standard”) for any detrusor overactivity. The data came from 9 studies. The plot has two columns. The left-hand column lists the last name of the first author for each study and the year of publication. The right-hand column is a plot of sensitivity as percentage with 95% CI of the subjects with symptoms of urgency and with positive urodynamic test for detrusor overactivity. Pooled with random effects model mean sensitivity is presented by a square incorporating confidence intervals represented by horizontal lines. The figure demonstrates that on average, 84% (95% CI 59; 95) of women with symptoms of urgency have a positive urodynamic test for detrusor overactivity.

Appendix Figure F9 Specificity of urgency symptoms with or without UI compared to multichannel urodynamics (“gold standard”) for any detrusor overactivity68,72–74,84,97,105 103,106

Figure F9 is a forest plot diagram depicting specificity of urgency symptoms compared to multichannel urodynamics (“gold standard”) for any detrusor overactivity. The data came from 9 studies. The plot has two columns. The left-hand column lists the last name of the first author for each study and the year of the publication. The right-hand column is a plot of specificity as percentage with 95% CI of the subjects without symptoms of urgency and with a negative urodynamic test for detrusor overactivity. Pooled with random effects model mean specificity is presented by a square incorporating confidence intervals represented by horizontal lines. The figure demonstrates that on average, 39% (95% CI 17; 67) of women without symptoms of urgency have a negative urodynamic test for detrusor overactivity.

Appendix Table F11 Pooled diagnostic value of urgency symptoms with or without UI compared to multichannel urodynamics (“gold standard”) for any detrusor overactivity

Appendix Table F12 Diagnostic value of urgency symptoms with or without UI compared to multichannel urodynamics (“gold standard”) for pure detrusor overactivity

Appendix Figure F10 Sensitivity of urgency symptoms with or without UI compared to multichannel urodynamics (“gold standard”) for pure detrusor overactivity72–74,97,103,105

Figure F10 is a forest plot diagram depicting sensitivity of urgency symptoms compared to multichannel urodynamics (“gold standard”) for pure detrusor overactivity. The data came from 6 studies. The plot has two columns. The left-hand column lists the last name of the first author for each study and the year of publication. The right-hand column is a plot of sensitivity as percentage with 95% CI of the subjects with symptoms of urgency and with a positive urodynamic test for pure detrusor overactivity (meaning detrusor overactivity without urodynamic stress UI). Pooled with random effects model mean sensitivity is presented by a square incorporating confidence intervals represented by horizontal lines. The figure demonstrates that on average, 86% (95% CI 83; 89) of women with symptoms of urgency have a positive urodynamic test for pure detrusor overactivity.

Appendix Figure F11 Specificity of urgency symptoms with or without UI compared to multichannel urodynamics (“gold standard”) for pure detrusor overactivity72–74,97,103,105

Figure F11 is a forest plot diagram depicting specificity of urgency symptoms compared to multichannel urodynamics (“gold standard”) for pure detrusor overactivity. The data came from 6 studies. The plot has two columns. The left-hand column lists the last name of the first author for each study and the year of the publication. The right-hand column is a plot of specificity as percentage with 95% CI of the subjects without symptoms of urgency and with a negative urodynamic test for pure detrusor overactivity (meaning detrusor overactivity without urodynamic stress UI). Pooled with random effects model mean specificity is presented by a square incorporating confidence intervals represented by horizontal lines. The figure demonstrates that on average, 31% (95% CI 24; 39) of women without symptoms of urgency have a negative urodynamic test for pure detrusor overactivity.

Appendix Table F13 Pooled diagnostic value of urgency symptoms with or without UI compared to multichannel urodynamics (“gold standard”) for pure detrusor overactivity

Appendix Table F14 Diagnostic value of mixed symptoms compared to multichannel urodynamics (“gold standard”) for mixed UI

Appendix Figure F12 Sensitivity of mixed symptoms compared to multichannel urodynamics (“gold standard”) for mixed UI75,82,83,85,88,90,91,93,98,99,102

Figure F12 is a forest plot diagram depicting sensitivity of mixed symptoms compared to multichannel urodynamics (“gold standard”) for mixed UI. The data came from 11 studies. The plot has two columns. The left-hand column lists the last name of the first author for each study and the year of publication. The right-hand column is a plot of sensitivity as percentage with 95% CI of the subjects with symptoms of mixed UI and with a positive urodynamic test for detrusor overactivity and urodynamic stress UI. Pooled with random effects model mean sensitivity is presented by a square incorporating confidence intervals represented by horizontal lines. The figure demonstrates that on average, 73% (95% CI 61; 82) of women with symptoms of mixed UI have a positive urodynamic test for detrusor overactivity and urodynamic stress UI.

Appendix Figure F13 Specificity of mixed symptoms compared to multichannel urodynamics (“gold standard”) for mixed UI75,82,83,85,88,90,91,93,98,99,102

Figure F13 is a forest plot diagram depicting specificity of mixed symptoms compared to multichannel urodynamics (“gold standard”) for mixed UI. The data came from 11 studies. The plot has two columns. The left-hand column lists the last name of the first author for each study and the year of publication. The right-hand column is a plot of specificity as percentage with 95% CI of the subjects without symptoms of mixed UI and with negative urodynamic test for detrusor overactivity or urodynamic stress UI. Pooled with random effects model mean specificity is presented by a square incorporating confidence intervals represented by horizontal lines. The figure demonstrates that on average, 53% (95% CI 40; 6%) of women without symptoms of mixed UI have a negative urodynamic test for detrusor overactivity or urodynamic stress UI.

Appendix Table F15 Pooled Diagnostic value of mixed symptoms compared to multichannel urodynamics (“gold standard”) for mixed UI

Appendix Table F16 Diagnostic value of pad test compared to multichannel urodynamics (“gold standard”) for stress UI

Appendix Figure F14 Sensitivity of pad test compared to multichannel urodynamics (“gold standard”) for any stress UI70,77,80

Figure F14 is a forest plot diagram depicting sensitivity of pad tests compared to multichannel urodynamics (“gold standard”) for any stress UI. The data came from 3 studies. The plot has two columns. The left-hand column lists the last name of the first author for each study and the year of publication. The right-hand column is a plot of sensitivity as percentage with 95% CI of the subjects with positive pad test and with positive urodynamic test for stress UI. Pooled with random effects model mean sensitivity is presented by a square incorporating confidence intervals represented by horizontal lines. The figure demonstrates that on average, 84% (95% CI 76; 90) of women with a positive pad test have positive urodynamic test for stress UI.

Appendix Figure F15 Specificity of pad test compared to multichannel urodynamics (“gold standard”) for any stress UI70,77,80

Figure F15 is a forest plot diagram depicting specificity of pad tests compared to multichannel urodynamics (“gold standard”) for any stress UI. The data came from 3 studies. The plot has two columns. The left-hand column lists the last name of the first author for each study and the year of publication. The right-hand column is a plot of specificity as percentage with 95% CI of the subjects with a negative pad test and with negative urodynamic test for stress UI. Pooled with random effects model mean specificity is presented by a square incorporating confidence intervals represented by horizontal lines. The figure demonstrates that on average, 77% (95% CI 72; 82) of women with a negative pad test have negative urodynamic test for stress UI.

Appendix Table 17 Pooled Diagnostic value of pad test compared to multichannel urodynamics (“gold standard”) for any stress UI

Appendix Figure F16 Sensitivity of pad test compared to multichannel urodynamics (“gold standard”) for any detrusor overactivity77,80

Figure F16 is a forest plot diagram depicting sensitivity of pad tests compared to multichannel urodynamics (“gold standard”) for any detrusor overactivity. The data came from 2 studies. The plot has two columns. The left-hand column lists the last name of the first author for each study and the year of publication. The right-hand column is a plot of sensitivity as percentage with 95% CI of the subjects with positive pad tests and with positive urodynamic tests for detrusor overactivity. Pooled with random effects model mean sensitivity is presented by a square incorporating confidence intervals represented by horizontal lines. The figure demonstrates that on average, 72% (95% CI 30; 94) of women with a positive pad test have positive urodynamic test for detrusor overactivity.

Appendix Figure F17 Specificity of pad test compared to multichannel urodynamics (“gold standard”) for any detrusor overactivity77,80

Figure F17 is a forest plot diagram depicting specificity of pad tests compared to multichannel urodynamics (“gold standard”) for any detrusor overactivity. The data came from 2 studies. The plot has two columns. The left-hand column lists the last name of the first author for each study and the year of publication. The right-hand column is a plot of specificity as percentage with 95% CI of the subjects with negative pad tests and with negative urodynamic tests for detrusor overactivity. Pooled with random effects model mean specificity is presented by a square incorporating confidence intervals represented by horizontal lines. The figure demonstrates that on average, 56% (95% CI 38; 72) of women with a negative pad test have negative urodynamic test for detrusor overactivity.

Appendix Table F18 Pooled diagnostic value of pad test compared to multichannel urodynamics (“gold standard”) for any detrusor overactivity

Appendix Table F19 Diagnostic value of symptoms compared to clinical diagnosis (“gold standard”) for different types of urinary incontinence

Appendix Figure F18 Sensitivity of urgency UI symptoms compared to clinical diagnosis (“gold standard”) for any detrusor overactivity (Bradley et al uses a composite diagnostic score)71,76,81,87

Figure F18 is a forest plot diagram depicting sensitivity of urge symptoms compared to clinical diagnosis (“gold standard”) of any detrusor overactivity. The data came from 4 studies. The plot has two columns. The left-hand column lists the last name of the first author for each study and the year of publication. The right-hand column is a plot of sensitivity as percentage with 95% CI of the subjects with symptoms of urgency UI and with clinical diagnosis of detrusor overactivity. Pooled with random effects model mean sensitivity is presented by a square incorporating confidence intervals represented by horizontal lines. The figure demonstrates that on average, 82% (95% CI 73; 89) of women with symptoms of urgency UI have clinical diagnosis of detrusor overactivity.

Appendix Figure F19 Specificity of urgency UI symptoms compared to clinical diagnosis (“gold standard”) for any detrusor overactivity (Bradley et al uses a composite diagnostic scores)71,76,81,87

Figure F19 is a forest plot diagram depicting specificity of urge symptoms compared to clinical diagnosis (“gold standard”) of any detrusor overactivity. The data came from 4 studies. The plot has two columns. The left-hand column lists the last name of the first author for each study and the year of publication. The right-hand column is a plot of specificity as percentage with 95% CI of the subjects without symptoms of urgency UI and without clinical diagnosis of detrusor overactivity. Pooled with random effects model mean specificity is presented by a square incorporating confidence intervals represented by horizontal lines. The figure demonstrates that on average, 67% (95% CI 53; 79) of women without symptoms of urgency UI did not have clinical diagnosis of detrusor overactivity.

Appendix Table F20 Pooled Diagnostic value of urgency UI symptoms compared to clinical diagnosis (“gold standard”) for any detrusor overactivity

Appendix Figure F20 Sensitivity of stress UI symptoms compared to clinical diagnosis (“gold standard”) for any stress UI71,76,81,87,121

Figure F20 is a forest plot diagram depicting sensitivity of symptoms compared to clinical diagnosis (“gold standard”) of stress urinary incontinence. The data came from 5 studies. The plot has two columns. The left-hand column lists the last name of the first author for each study and the year of the publication. The right-hand column is a plot of sensitivity as percentage with 95% CI of the subjects with symptoms of stress urinary incontinence and with clinical diagnosis of stress urinary incontinence. Pooled with random effects model mean sensitivity is presented by a square incorporating confidence intervals represented by horizontal lines. Figure demonstrates that in average, 88% (95%CI 68; 96 %) of women with symptoms of stress urinary incontinence have clinical diagnosis of stress UI.

Appendix Figure F21 Specificity of stress UI symptoms compared to clinical diagnosis (“gold standard”) for any stress UI71,76,81,87,121

Figure F21 is a forest plot diagram depicting specificity of symptoms compared to clinical diagnosis (“gold standard”) of stress urinary incontinence. The data came from 5 studies. The plot has two columns. The left-hand column lists the last name of the first author for each study and the year of the publication. The right-hand column is a plot of specificity as percentage with 95% CI of the subjects without symptoms of stress urinary incontinence and without clinical diagnosis of stress urinary incontinence. Pooled with random effects model mean specificity is presented by a square incorporating confidence intervals represented by horizontal lines. Figure demonstrates that in average, 67% (95%CI 54; 78 %) of women without symptoms of stress urinary incontinence did not have clinical diagnosis of stress UI.

Appendix Table F21 Pooled diagnostic value of stress UI symptoms compared to clinical diagnosis (“gold standard”) for any stress UI

Appendix Figure F22 Sensitivity of mixed symptoms compared to clinical diagnosis (“gold standard”) for mixed UI71,76,81

Figure F22 is a forest plot diagram depicting sensitivity of mixed symptoms compared to clinical diagnosis (“gold standard”) for mixed urinary incontinence. The data came from 3 studies. The plot has two columns. The left-hand column lists the last name of the first author for each study and the year of the publication. The right-hand column is a plot of sensitivity as percentage with 95% CI of the subjects with symptoms of mixed urinary incontinence and with clinical diagnosis of mixed urinary incontinence. Pooled with random effects model mean sensitivity is presented by a square incorporating confidence intervals represented by horizontal lines. Figure demonstrates that in average, 65% (95%CI 36; 86 %) of women with symptoms of mixed urinary incontinence have clinical diagnosis of mixed UI.

Appendix Figure F23 Specificity of mixed symptoms compared to clinical diagnosis (“gold standard”) for mixed UI71,76,81

Figure F23 is a forest plot diagram depicting specificity of mixed symptoms compared to clinical diagnosis (“gold standard”) for mixed urinary incontinence. The data came from 3 studies. The plot has two columns. The left-hand column lists the last name of the first author for each study and the year of the publication. The right-hand column is a plot of specificity as percentage with 95% CI of the subjects without symptoms of mixed urinary incontinence and without clinical diagnosis of mixed urinary incontinence. Pooled with random effects model mean specificity is presented by a square incorporating confidence intervals represented by horizontal lines. Figure demonstrates that in average, 54% (95%CI 21; 84 %) of women without symptoms of mixed urinary incontinence did not have clinical diagnosis of mixed UI.

Appendix Table F22 Diagnostic value of mixed symptoms compared to clinical diagnosis (“gold standard”) for mixed UI

Appendix Table F23 Diagnostic value of urgency UI symptoms compared to clinical diagnosis for detrusor overactivity

Appendix Figure F24 Sensitivity of urgency UI symptoms compared to clinical diagnosis for pure detrusor overactivity71,76

Figure F24 is a forest plot diagram depicting sensitivity of urge symptoms compared to clinical diagnosis for pure detrusor overactivity. The data came from 2 studies. The plot has two columns. The left-hand column lists the last name of the first author for each study and the year of the publication. The right-hand column is a plot of sensitivity as percentage with 95% CI of the subjects with urge symptoms and with clinical diagnosis of pure detrusor overactivity. Pooled with random effects model mean sensitivity is presented by a square incorporating confidence intervals represented by horizontal lines. Figure demonstrates that in average, 70% (95%CI 43; 88 %) of women with urge symptoms have clinical diagnosis of pure detrusor overactivity.

Appendix Figure F25 Specificity of urgency UI symptoms compared to clinical diagnosis for pure detrusor overactivity71,76

Figure F25 is a forest plot diagram depicting specificity of urge symptoms compared to clinical diagnosis for pure detrusor overactivity. The data came from 2 studies. The plot has two columns. The left-hand column lists the last name of the first author for each study and the year of publication. The right-hand column is a plot of specificity as percentage with 95% CI of the subjects without urge symptoms and without clinical diagnosis of pure detrusor overactivity. Pooled with random effects model mean specificity is presented by a square incorporating confidence intervals represented by horizontal lines. The figure demonstrates that on average, 55% (95% CI 28; 79) of women without urge symptoms did not have clinical diagnosis of pure detrusor overactivity.

Appendix Table F24 Pooled diagnostic value of urgency UI symptoms compared to clinical diagnosis for detrusor overactivity

Appendix Table F25 Clinical outcomes after fesoterodine in patients with an overactive bladder and urgency UI by the urodynamic finding of detrusor overactivity (DO) (results from individual RCT)

Appendix Table F26 Clinical outcomes after nonpharmacological treatments in nonrandomized studies

Appendix Table F27 Pharmacological treatments for female UI

Appendix Table F28 Quality of the studies that examined pharmacological treatments for UI

Table F29 Effects from local estrogen therapy compared to no active treatment

Appendix Table F30 Continence after topical estrogen treatment compared to no active treatment (individual RCTs)

Appendix Table F31 Improvement in incontinence after topical estrogen treatment compared to no active treatment (individual RCTs)

Appendix Table F32 Clinical outcomes after topical estrogen therapy compared to no treatment (individual RCTs)

Appendix Table F33 Clinical outcomes after pharmacological treatments in nonrandomized studies

Appendix Table F34 Continence after duloxetine vs. placebo, random effects model

Appendix Table F35 Continence after different doses of duloxetine

Appendix Table F36 Improvement in UI after duloxetine vs. placebo (random effects model)

Appendix Table F37 Perceived treatment success after different doses of duloxetine

Appendix Table F38 Treatment failure after duloxetine vs. placebo (random effects model)

Appendix Table F39 Quality of life after duloxetine vs. placebo

Appendix Table F40 Adverse effects after duloxetine vs. placebo, random effects model

Appendix Table F41 Adverse effects after duloxetine treatments compared to placebo (pooled results from RCTs)

Appendix Table F42 Outcomes after different doses of duloxetine

Appendix Table F43 Adverse effects that result in discontinuation of the treatment after duloxetine vs. placebo, random effects models

Appendix Table F44 Exploring clinical diversity in discontinuation rates due to adverse effects after duloxetine when compared to placebo

Appendix Table F45 Exploring heterogeneity in discontinuation rates due to adverse effects after duloxetine compared to placebo (results from meta-regression)

Appendix Table F46 Exploring methodological diversity in discontinuation rates due to adverse effects after duloxetine compared to placebo

Appendix Table F47 Clinical outcomes after drugs vs. placebo (pooled with random effects models results from RCTs)

Appendix Table F48 Exploring statistical heterogeneity by treatment, clinical, or study characteristics with meta-regression (restricted maximum likelihood estimate of between-study variance, constant values not reported)

Appendix Table F49 Severity and quality of life after oxybutynin (individual RCTs)

Appendix Table F50 Domains of quality of life after oxybutynin treatments (individual RCTs)

Appendix Table F51 Clinical outcomes after oxybutynin treatments (individual RCTs)

Appendix Table F52 Clinical outcomes after tolterodine vs. placebo in secondary data analyses

Appendix Table F53 Clinical outcomes after different doses and clinical formulations of tolterodine

Appendix Table F54 Clinical outcomes after tolterodine vs. placebo, the results from randomized controlled clinical trials pooled with random effects models

Appendix Table F55 Clinical outcomes after darifenacin vs. placebo in pooled analyses of individual patient data from RCTs (high level of evidence)

Appendix Table F56 Dose response association between clinical outcomes and darifenacin in pooled analyses of individual patient data from RCTs (high level of evidence)

Appendix Table F57 Significant dose response association with clinical outcomes after darifenacin (individual RCTs)

Appendix Table F58 Clinical outcomes after solifenacin vs. placebo, pooled individual patient data from RCTs (high level of evidence)

Appendix Table F59 Evidence of dose response association in clinical outcomes after solifenacin 5 vs.10mg/day (pooled individual patient data from RCTs)

Appendix Table F60 Results from VIBRANT trial

Appendix Table F61 Clinical outcomes after fesoterodine vs. placebo, secondary data from post hoc and pooled analyses

Appendix Table F62 Significant dose response effects of fesoterodine

Appendix Table F63 Clinical outcomes after fesoterodine vs. placebo

Appendix Table F64 Clinical outcomes after propiverine vs. placebo, individual RCTs

Appendix Table F65 Clinical outcomes after botulinum toxin vs. placebo, individual RCTs

Appendix Table F66 Quality of life after botulinum toxin vs. placebo, individual RCTs

Appendix Table F67 Outcomes after intravesical 100ml of 50nM-single dose injection of resiniferatoxin vs. placebo, individual RCTs

Appendix Table F68 Outcomes after nimodipine, 60mg/day, vs. placebo, individual RCT

Appendix Table F69 Comparative effectiveness of local estrogen therapy

Appendix Table F70 Comparative effectiveness of estrogen topical treatments (individual RCTs)

Appendix Table F71 Adverse effects of pharmacological treatments for UI when compared to each other

Appendix Table F72 Dry mouth after pharmacological treatments for UI when compared to each other

Appendix Figure F26 Gain in quality adjusted life years per 1,000 treated patients477

Figure F26 is a bar diagram depicting gains in quality adjusted life years per 1,000 treated patients after drugs for UI. The data came from evidence-based cost utility analysis. The horizontal axis presents total gains in quality adjusted life years per 1,000 treated. The black bars present gains in quality adjusted life years after each drug formulation. The figure demonstrates the largest gain in quality adjusted life years per 1,000 treated after administration of solifenacin.

Appendix Table F73 Constipation after pharmacological treatments for UI when compared to each other

Appendix Table F74 Discontinuation due to adverse effects after pharmacological treatments for UI when compared to each other

Appendix Table F75 Comparative effectiveness of drugs on continence

Appendix Table F76 Comparative effectiveness of oxybutynin vs. tolterodine (secondary data analyses using individual patient data from RCTs)

Appendix Table F77 Comparative effectiveness of drugs on improved UI

Appendix Table F78 Comparative effectiveness of tolterodine-ER 4mg/day vs. fesoterodine, evidence secondary data analysis

Appendix Table F79 Improvement in UI after pharmacological treatments for UI

Appendix Table F80 Blurred vision after pharmacological treatments for UI when compared to each other

Appendix Table F81 Randomized controlled clinical trials of nonpharmacological nonsurgical treatment for UI

Appendix Table F82 Sponsorship and conflict of interest in studies of nonpharmacological treatments for UI

Appendix Table 83 Quality of randomized controlled clinical trials of nonpharmacological nonsurgical treatments for UI

Appendix Table F84 Comparative effectiveness of nonpharmacological treatments on improvement of incontinence

Appendix Table F85 Effectiveness of nonpharmacological treatments on stress UI in women (results from poorly reported randomized controlled clinical trials)

Appendix Table F86 Subgroup analysis of continence with different nonpharmacological treatments by baseline type of UI (results from individual RCTs were pooled with random effects model)

Appendix Table F87 Clinical outcomes after pelvic floor muscle training compared to no active treatment (results from RCTs pooled with random effects models)

Appendix Table F88 Quality of life after pelvic floor muscle training compared to no active treatment (individual RCTs)

Appendix Table F89 Scoring of quality of life after pelvic floor muscle training compared to no active treatment (individual RCTs)

Appendix Table F90 Clinical outcomes after vaginal cones compared to no active treatment (results from RCTs pooled with random effects models)

Appendix Table F91 Scoring of quality of life after vaginal cones compared to no active treatment (results from individual RCT)

Appendix Table F92 Clinical outcomes after pelvic floor muscle training combined with biofeedback compared to no active treatment (results from RCTs pooled with random effects models)

Appendix Table F93 Scoring of quality of life after pelvic floor muscle training with biofeedback using vaginal EMG probe compared to no active treatment (individual RCT)

Appendix Table F94 Continence after supervised pelvic floor muscle training when compared to no active treatment, individual RCTs

Appendix Table F95 Scoring of quality of life after supervised pelvic floor muscle training compared to no active treatment (individual RCTs)

Appendix Table F96 Clinical outcomes after electrical intravaginal stimulation compared to no active treatment (results from RCTs pooled with random effects models)

Appendix Table F97 Improvement in UI after nonpharmacological treatments compared to no active treatment

Appendix Table F98 Scoring of quality of life after electrical stimulation compared to no active treatment (results from individual RCTs)

Appendix Table F99 Clinical outcomes after electrical stimulation compared to no active treatments (results from individual RCTs)

Appendix Table F100 Clinical outcomes after nonpharmacological treatments compared to no active treatment

Appendix Table F101 Clinical outcomes after magnetic stimulation compared to no active treatment (results from RCTs pooled with random effects models)

Appendix Table F102 Pooled analysis of improvement in incontinence after magnetic stimulation when compared to no active treatment, random effects model

Appendix Table F103 Scoring of quality of life after magnetic stimulation compared to no active treatment (results from RCTs)

Appendix Table F104 Improvement in incontinence after injection of bulking agents when compared to no active treatment, results from individual RCTs

Appendix Table F105 Scoring of quality of life after bulking agent when compared to no active treatment, results from individual RCT

Appendix Table F106 Clinical outcomes after bladder training compared to no active treatment (results from RCTs pooled with random effects models)

Appendix Table F107 Scoring of quality of life after bladder training compared to no active treatment (individual RCT)

Appendix Table F108 Clinical outcomes after percutaneous electrical stimulation compared to no active treatment (results from RCTs pooled with random effects models)

Appendix Table F109 Clinical outcomes after pelvic floor muscle training combined with bladder training compared to no active treatment (results from RCTs pooled with random effects models)

Appendix Table F110 Clinical outcomes after pelvic floor muscle training combined with bladder training when compared to no active treatment, individual RCTs

Appendix Table F111 Scoring of quality of life after pelvic floor muscle training combined with bladder training compared to no active treatment (individual RCT)

Appendix Table F112 Clinical outcomes after continence service compared to no active treatment (results from RCTs pooled with random effects models)

Appendix Table F113 Improvement in urinary incontinence after interventions that were implemented by continence specialists when compared to no active treatment, individual RCTs

Appendix Table F114 Quality of life after interventions that were implemented by continence specialists when compared to no active treatment, individual RCTs

Appendix Table F115 Scoring of quality of life after interventions that were implemented by continence specialists when compared to no active treatment (individual RCTs)

Appendix Table F116 Clinical outcomes after weight loss program compared to no active treatment (results from RCTs pooled with random effects models)

Appendix Table F117 Quality of life after intensive weight loss programs when compared to no active treatment (individual RCTs)

Appendix Table F118 Urinary incontinence, treatment failure and discontinuation after intensive weight loss programs when compared to no active treatment, individual RCTs

Appendix Table F119 Urinary incontinence after a diet high in soy protein (individual RCT)

Appendix Table F120 UI after acupuncture compared to no active treatment (results from individual RCTs)

Appendix Table F121 Scoring of quality of life after acupuncture compared to no active treatment (results from individual RCTs)

Appendix Table F122 Clinical outcomes after supervised PFMT combined with bladder training compared to self administered PFMT (results from RCTs pooled with random effects models)

Appendix Table F123 Improvement in UI rates compared between nonpharmacological treatments

Appendix Table F124 Failure rates compared between nonpharmacological treatments

Appendix Table F125 Quality of life after supervised vs. self-administered PFMT programs (individual RCTs)

Appendix Table F126 Scoring of quality of life after supervised vs. self-administered PFMT programs (individual RCTs)

Appendix Table F127 Continence and improvement in incontinence after complex group and individual pelvic floor muscle training programs, individual RCTs

Appendix Table F128 Scoring of quality of life after PFMT with biofeedback using vaginal EMG probe when compared to PFMT (individual RCTs)

Appendix Table F129 Clinical outcomes after pelvic floor muscle training with biofeedback using vaginal EMG probe when compared to pelvic floor muscle training, individual RCT

Appendix Table F130 Clinical outcomes after PFMT compared to electrical stimulation (results from RCTs pooled with random effects models)

Appendix Table F131 Clinical outcomes compared after different nonpharmacological treatments (results from individual RCTs)

Appendix Table F132 Clinical outcomes after PFMT compared to vaginal cones (results from RCTs pooled with random effects models)

Appendix Table F133 Scoring of quality of life after PFMT with biofeedback vs. vaginal cones (individual RCTs)

Appendix Table F134 Comparative effectiveness of circular muscle exercises (Paula method) vs. PFMT (individual RCT)

Appendix Table F135 Scoring of quality of life after circular muscle exercises (Paula method) vs. PFMT (individual RCTs)

Appendix Table F136 Clinical outcomes after circular muscle exercises (Paula method) vs. PFMT (individual RCTs)

Appendix Table F137 Comparative effectiveness on quality of life after PFMT vs. active controls (individual RCTs)

Appendix Table F138 Scoring of quality of life after PFMT (individual RCTs)

Appendix Table F139 Continence after PFMT with personal reminders and self-help guides or different positions during exercise (individual RCTs)

Appendix Table F140 Comparative effectiveness of medical devices (individual RCTs)

Appendix Table F141 Scoring of quality of life after medical devices compared to active controls (individual RCTs)

Appendix Table F142 Comparative effectiveness of medical devices on quality of life (individual RCT)

Appendix Table F143 Comparative comfort in using different pads for urinary incontinence (individual RCT)

Appendix Table F144 Comparative effectiveness of bulking agents (individual RCTs)

Appendix Table F145 Quality of life scores after bulking agents (individual RCTs)

Appendix Table F146 Clinical outcomes after bulking agents (individual RCTs)

Appendix Table F147 Comparative effectiveness of nonpharmacological treatments on continence (insufficient evidence)

Appendix Table F148 Clinical outcomes after PFMT combined with bladder training compared to PFMT alone (results from RCTs pooled with random effects models)

Appendix Table F149 Clinical outcomes after PFMT combined with bladder training compared to bladder training alone (results from RCTs pooled with random effects models

Appendix Table F150 Quality of life scoring after continence program vs. PFMT (individual RCT)

Appendix Table F151 Nonsignificant differences in comparative effectiveness of oxybutynin when compared to nonpharmacological treatments (results from individual randomized controlled clinical trials)

Appendix Table F152 Comparative effectiveness of combined therapy with tolterodine ER, 4 mg daily and behavioral intervention with pelvic floor muscle training vs. tolterodine ER, 4 mg daily monotherapy. Urinary Incontinence Treatment Network: behavior enhances drug reduction of incontinence, (BE-DRI) randomized controlled clinical trial

Appendix Table F153 Comparative effectiveness of percutaneous tibial nerve stimulation versus extended-release tolterodine (results from overactive bladder innovative therapy trial)

Appendix Table F154 Nonsignificant differences in comparative effectiveness of flexible-dose solifenacin 5/10 mg with and without simplified bladder training in patients with overactive bladder syndrome (results from individual randomized controlled clinical trial)

Appendix Table F155 Comparative effectiveness of intravaginal electrical stimulation and trospium hydrochloride in women with overactive bladder syndrome (results from individual randomized controlled clinical trial)

## References for Appendix F

(Note that this set of references is different from those in the text of the report and the numbers are different.)

1 U.S. Food and Drug Administration CfDEaR. 510(k) Summary for Pelvex hometrainer. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf/K002043.pdf. Accessed June 25, 2010.
2 U.S. Food and Drug Administration CfDEaR. 510(k) summary for Vitala(tm) continence Control Device. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf8/K083785.pdf. Accessed June 25, 2010.
3 U.S. Food and Drug Administration CfDEaR. 510(k) Summary for uresta Pessary. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf8/K083769.pdf. Accessed June 25, 2010.
4 U.S. Food and Drug Administration CfDEaR. 510(k) Summary for PelvicFlexer. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf/K011688.pdf. Accessed June 25, 2010.
5 U.S. Food and Drug Administration CfDEaR. 510(k) Summary for Hollister Contimed Pressure Biofeedback device. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf/K960311.pdf. Accessed June 25, 2010.
6 U.S. Food and Drug Administration CfDEaR. 510(k) Summary of pathway vaginal emg/stimulation perineometer sensor. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf/K993976.pdf. Accessed June 25, 2010.
7 U.S. Food and Drug Administration CfDEaR. 501(k) summary for UroMed Alternative Bladder Control Continence Device. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf/K971992pdf (http://www.accessdata.fda.gov/cdrh_docs/pdf/1992pdfK97). Accessed June 25, 2010.
8 U.S. Food and Drug Administration CfDEaR. 510(k) Summary for InCare Pelvic Floor Therapy System with Desktop Computer. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf/K961872pdf. Accessed June 25, 2010.
9 U.S. Food and Drug Administration CfDEaR. 510(k) summary review for perineometer and vaginal probe. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf/K970145.pdf. Accessed June 25, 2010.
10 U.S. Food and Drug Administration CfDEaR. 510(k) summary for vaginal stimulation/emg probe - tampon. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf/K971541.pdf. Accessed June 25, 2010.
11 U.S. Food and Drug Administration CfDEaR. 510(k) Summary for innoSense pelvic floor stimulation and electromyography system. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf/K971527.pdf. Accessed June 25, 2010.
12 U.S. Food and Drug Administration CfDEaR. 510(k) summary for vaginal stimulation/emg probe - small. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf/K970602.pdf. Accessed June 25, 2010.
13 U.S. Food and Drug Administration CfDEaR. 510(k) summary for periform perineometric probe and pelvic floor contraction indicator. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf/K981277.pdf. Accessed June 25, 2010.
14 U.S. Food and Drug Administration CfDEaR. 510(k) summary review for peritron perineometer. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf/K983052.pdf. Accessed June 25, 2010.
15 U.S. Food and Drug Administration CfDEaR. 510(k) summary for reflex treatment system. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf/K994079.pdf. Accessed June 25, 2010.
16 U.S. Food and Drug Administration CfDEaR. 510(k) Summary for Mentor EvaCare Vaginal Pessaries. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf/K993308.pdf. Accessed June 25, 2010.
17 U.S. Food and Drug Administration CfDEaR. 510(k) Summary for PelvX Incontinence Dish. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf/K990593.pdf. Accessed June 25, 2010.
18 U.S. Food and Drug Administration CfDEaR. Summary for pelvic muscle therapy. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf/K002830.pdf. Accessed June 25, 2010.
19 U.S. Food and Drug Administration CfDEaR. 510(k) summary accuset sensor. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf/K001386.pdf. Accessed June 25, 2010.
20 U.S. Food and Drug Administration CfDEaR. 510(k) summary for femiscan clinic system and personal system. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf/K993411.pdf. Accessed June 25, 2010.
21 U.S. Food and Drug Administration CfDEaR. Summary Review for InCare Pelvic Floor Therapy System. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf/K013612.pdf. Accessed June 25, 2010.
22 U.S. Food and Drug Administration CfDEaR. 510(k) Summary for InCare Pressure Biofeedback Vaginal and Anal Pressure Probes. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf/K013653.pdf. Accessed June 25, 2010.
23 U.S. Food and Drug Administration CfDEaR. 510(k) Summary for MTI ST#1 Silicone Pessary. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf2/K020512.pdf. Accessed June 25, 2010.
24 U.S. Food and Drug Administration CfDEaR. 510(k) Summary for Portex Ring Pessary. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf/K012277.pdf. Accessed June 25, 2010.
25 U.S. Food and Drug Administration CfDEaR. 510(k) Summary for marina Medical Silicone Pessary. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf3/K031463.pdf. Accessed June 25, 2010.
26 U.S. Food and Drug Administration CfDEaR. 510(k) Summary for Kolpexin Sphere. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf3/K032644.pdf. Accessed June 25, 2010.
27 U.S. Food and Drug Administration CfDEaR. 510(k) Summary for Intra-vaginal stress incontinence device. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf6/K060526.pdf. Accessed June 25, 2010.
28 U.S. Food and Drug Administration CfDEaR. 510(k) Summary for pathway vaginal/rectal perineometer probe. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf/K974036.pdf. Accessed June 25, 2010.
29 U.S. Food and Drug Administration CfDEaR. 510(k) summary for anal stimulation/emg probe - w/Stop. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf/K990456.pdf. Accessed June 25, 2010.
30 U.S. Food and Drug Administration CfDEaR. 510(k) Summary for InCare Pelvic Floor Therapy System with Desktop Computer. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf/K961872pdf. Accessed June 25, 2010.
31 U.S. Food and Drug Administration CfDEaR. 510(k) summary for liberty plus system pfs-300. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf/K970077.pdf. Accessed June 25, 2010.
32 U.S. Food and Drug Administration CfDEaR. Medical Review for Gelnique (oxybutynin chloride) 10% gel. Available at: http://www.accessdata.fda.gov/drugsatfda_docs/nda/2009/022204s000_gelnique_toc.cfm. Accessed June 25, 2010.
33 Staskin DR, Dmochowski RR, Sand PK, et al. Efficacy and safety of oxybutynin chloride topical gel for overactive bladder: a randomized, double-blind, placebo controlled, multicenter study. J Urol. Apr. 2009;181(4):1764-72. [pmid: 19233423].
34 U.S. Food and Drug Administration CfDEaR. Medical Review for PAMELOR (Brand Name Drug). Available at: http://www.accessdata.fda.gov/drugsatfda_docs/nda/2001/018012_s024_PAMELOR%20CAPSULES.pdf. Accessed June 25, 2010.
35 U.S. Food and Drug Administration CfDEaR. Medical Review for Sanctura (Trospium Chloride) Tablets. Available at: http://www.accessdata.fda.gov/drugsatfda_docs/nda/2004/21-595_Sanctura.cfm. Accessed June 25, 2010.
36 Rudy D, Cline K, Harris R, et al. Time to onset of improvement in symptoms of overactive bladder using antimuscarinic treatment. BJU Int. Mar. 2006;97(3):540-6. [pmid: 16469022].
37 Zinner N, Gittelman M, Harris R, et al. Trospium chloride improves overactive bladder symptoms: a multicenter phase III trial. J Urol. Jun. 2004;171(6 Pt 1):2311-5. quiz 435. [pmid: 15126811].
38 U.S. Food and Drug Administration CfDEaR. Medical Review for VesiCare (Solifenacin Succinate) Tablets. Available at: http://www.accessdata.fda.gov/drugsatfda_docs/nda/2004/21-518_VesiCare.cfm. Accessed June 25, 2010.
39 Staskin DR, Te AE. Short- and long-term efficacy of solifenacin treatment in patients with symptoms of mixed urinary incontinence. BJU Int. Jun. 2006;97(6):1256-61. [pmid: 16686722].
40 U.S. Food and Drug Administration CfDEaR. Medical Review for Sanctura XR (Trospium Chloride) Extended Release Capsules. Available at: http://www.accessdata.fda.gov/drugsatfda_docs/nda/2007/022103s000TOC.cfm. Accessed June 25, 2010.
41 U.S. Food and Drug Administration CfDEaR. Medical Review for Ditropan XL ( Oxybutinin Chloride) Tablets. Available at: http://www.accessdata.fda.gov/drugsatfda_docs/nda/98/20897.cfm. Accessed June 25, 2010.
42 Versi E, Appell R, Mobley D, et al. Dry mouth with conventional and controlled-release oxybutynin in urinary incontinence. The Ditropan XL Study Group Obstet Gynecol. May. 2000;95(5):718-21. [pmid: 10775736].
43 U.S. Food and Drug Administration CfDEaR. Medical Review for Enablex (Clarifenacin) Extended Release Tablets. Available at: http://www.accessdata.fda.gov/drugsatfda_docs/nda/2004/21-513_Enablex.cfm. Accessed June 25, 2010.
44 Hill S, Khullar V, Wyndaele JJ, et al. Dose response with darifenacin, a novel once-daily M3 selective receptor antagonist for the treatment of overactive bladder: results of a fixed dose study. Int Urogynecol J Pelvic Floor Dysfunct. May. 2006;17(3):239-47. [pmid: 15999217].
45 Steers W, Corcos J, Foote J, et al. An investigation of dose titration with darifenacin, an M3-selective receptor antagonist. BJU Int. Mar. 2005;95(4):580-6. [pmid: 15705084].
46 U.S. Food and Drug Administration CfDEaR. Statistical Review for Sanctura XR (Trospium Chloride) Extended Release Capsules. Available at: http://www.accessdata.fda.gov/drugsatfda_docs/nda/2007/022103s000TOC.cfm. Accessed June 25, 2010.
47 Staskin D, Sand P, Zinner N, et al. Once daily trospium chloride is effective and well tolerated for the treatment of overactive bladder: results from a multicenter phase III trial. J Urol. Sep. 2007;178(3 Pt 1):978-83. discussion 83–4. [pmid: 17632131].
48 Dmochowski RR, Sand PK, Zinner NR, et al. Trospium 60 mg once daily (QD) for overactive bladder syndrome: results from a placebo-controlled interventional study. Urology. Mar. 2008;71(3):449-54. [pmid: 18342185].
49 Health Canada. Product Monograph for ENABLEX. Available at: http://webprod.hc-sc.gc.ca/dpd-bdpp/info.do?lang=eng&code=75871. Accessed June 25, 2010.
50 Abrams P, Kelleher C, Huels J, et al. Clinical relevance of health-related quality of life outcomes with darifenacin. BJU Int. Jul. 2008;102(2):208-13. [pmid: 18325056].
51 U.S. Food and Drug Administration CfDEaR. Product Monograph for SANCTURA XR. Available at: http://webprod.hc-sc.gc.ca/dpd-bdpp/dispatch-repartition.do?lang=eng. Accessed June 25, 2010.
52 Staskin DR, Rosenberg MT, Sand PK, et al. Trospium chloride once-daily extended release is effective and well tolerated for the treatment of overactive bladder syndrome: an integrated analysis of two randomised, phase III trials. Int J Clin Pract. Dec. 2009;63(12):1715-23. [pmid: 19930332].
53 Cardozo L, Lisec M, Millard R, et al. Randomized, double-blind placebo controlled trial of the once daily antimuscarinic agent solifenacin succinate in patients with overactive bladder. J Urol. Nov. 2004;172(5 Pt 1):1919-24. [pmid: 15540755].
54 Chapple CR, Rechberger T, Al-Shukri S, et al. Randomized, double-blind placebo- and tolterodine-controlled trial of the once-daily antimuscarinic agent solifenacin in patients with symptomatic overactive bladder. BJU Int. Feb. 2004;93(3):303-10. [pmid: 14764127].
55 NCT00168454. A Research Study for Patients With Overactive Bladder. 2008.
56 NCT00178191. Randomized Trial for Botox Urinary Incontinence. Available at: http://www.clinicaltrials.gov/ct2/show/NCT00178191?term=NCT00178191&rank=1.
57 NCT00269750. A Study Comparing the Efficacy and Safety of OROS® Oxybutynin to That of Ditropan® (Immediate-release Oxybutynin) for the Treatment of Patients With Urge or Mixed Urinary Incontinence. Available at: http://clinicaltrials.gov/show/NCT00269750. Accessed June 25, 2010.
58 NCT00444925. Clinical Trial to Evaluate the Efficacy and Safety of Fesoterodine in Comparison to Tolterodine for Overactive Bladder (OAB). Available at: http://www.clinicaltrials.gov/ct2/show/NCT00444925?term=NCT00444925&rank=1.
59 NCT00536484. Fesoterodine Flexible Dose Study. Available at: http://www.clinicaltrials.gov/ct2/show/NCT00536484?term=NCT00536484&rank=1.
60 U.S. Food and Drug Administration CfDEaR. Solifenacin in a flexible dose regimen with tolterodine as an active comparator in a double-blind, double-dummy, randomized overactive bladder symptom trial (STAR). Available at: http://www.clinicalstudyresults.org/documents/company-study_8350_0.pdf. Accessed June 25, 2010.
61 Chapple CR, Martinez-Garcia R, Selvaggi L, et al. A comparison of the efficacy and tolerability of solifenacin succinate and extended release tolterodine at treating overactive bladder syndrome: results of the STAR trial. Eur Urol. Sep. 2005;48(3):464-70. [pmid: 15990220].
62 U.S. Food and Drug Administration CfDEaR. Solifenacin in the treatment of urgency symptoms of overactive bladder in a rising dose, randomized, placebo-controlled, double-blind trial (SUNRISE). Available at: http://www.clinicalstudyresults.org/documents/company-study_8351_0.pdf. Accessed June 25, 2010.
63 Cardozo L, Hessdorfer E, Milani R, et al. Solifenacin in the treatment of urgency and other symptoms of overactive bladder: results from a randomized, double-blind, placebo-controlled, rising-dose trial. BJU Int. Nov. 2008;102(9):1120-7. [pmid: 18990175].
64 U.S. Food and Drug Administration CfDEaR. Solifenacin succinate in a flexible dose regimen with simplified bladder training versus solifenacin succinate in a flexible dose regimen alone in a prospective, randomized, parallel group, overactive bladder symptom study. Available at: http://www.clinicalstudyresults.org/documents/company-study_8352_0.pdf. Accessed June 25, 2010.
65 Mattiasson A, Masala A, Morton R, et al. Efficacy of simplified bladder training in patients with overactive bladder receiving a solifenacin flexible-dose regimen: results from a randomized study. BJU Int. Oct. 2009;10. [pmid: 19818077].
66 Whiting PF, Weswood ME, Rutjes AW, et al. Evaluation of QUADAS, a tool for the quality assessment of diagnostic accuracy studies. BMC Med Res Methodol. 2006;6:9. [pmid: 16519814].
67 Methods Guide for Medical Test Reviews. Methods Guide for Medical Test Reviews. Rockville, MD. Agency for Healthcare Research and Quality. 2010.
68 Digesu GA, Khullar V, Cardozo L, et al. Overactive bladder symptoms: do we need urodynamics?. Neurourol Urodyn. 2003;22(2):105-8. [pmid: 12579626].
69 Khan MS, Chaliha C, Leskova L, et al. The relationship between urinary symptom questionnaires and urodynamic diagnoses: an analysis of two methods of questionnaire administration. BJOG. May. 2004;111(5):468-74. [pmid: 15104612].
70 Versi E, Orrego G, Hardy E, et al. Evaluation of the home pad test in the investigation of female urinary incontinence. Br J Obstet Gynaecol. Feb. 1996;103(2):162-7. [pmid: 8616134].
71 Sandvik H, Hunskaar S, Vanvik A, et al. Diagnostic classification of female urinary incontinence: an epidemiological survey corrected for validity. J Clin Epidemiol. Mar. 1995;48(3):339-43. [pmid: 7897455].
72 Clarke B. The role of urodynamic assessment in the diagnosis of lower urinary tract disorders. Int Urogynecol J Pelvic Floor Dysfunct. 1997;8(4):196-9. [pmid: 9449295].
73 Jarvis GJ, Hall S, Stamp S, et al. An assessment of urodynamic examination in incontinent women. Br J Obstet Gynaecol. Oct. 1980;87(10):893-6. [pmid: 7426486].
74 Hilton P, Stanton SL. Algorithmic method for assessing urinary incontinence in elderly women. Br Med J (Clin Res Ed). Mar. 21. 1981;282(6268):940-2. [pmid: 6781660].
75 Cundiff GW, Harris RL, Coates KW, et al. Clinical predictors of urinary incontinence in women. Am J Obstet Gynecol. Aug. 1997;177(2):262-6. discussion 6–7. [pmid: 9290438].
76 Brown JS, Bradley CS, Subak LL, et al. The sensitivity and specificity of a simple test to distinguish between urge and stress urinary incontinence. Ann Intern Med. May. 16. 2006;144(10):715-23. [pmid: 16702587].
77 Costantini E, Lazzeri M, Bini V, et al. Sensitivity and specificity of one-hour pad test as a predictive value for female urinary incontinence. Urol Int. 2008;81(2):153-9. [pmid: 18758212].
78 Ishiko O, Hirai K, Sumi T, et al. The urinary incontinence score in the diagnosis of female urinary incontinence. Int J Gynaecol Obstet. Feb. 2000;68(2):131-7. [pmid: 10717817].
79 Shepherd AM, Powell PH, Ball AJ. The place of urodynamic studies in the investigation and treatment of female urinary tract symptoms. J Obstet Gynaecol. 1982;3:123-5.
80 Versi E, LC, Anand D. The use of pad tests in the investigation of female urinary incontinence. J Obstet Gynecol. 1988;8:270-3. no-2.
81 Bradley CS, Rovner ES, Morgan MA, et al. A new questionnaire for urinary incontinence diagnosis in women: development and testing. Am J Obstet Gynecol. Jan. 2005;192(1):66-73. [pmid: 15672005].
82 FitzGerald MP, Brubaker L. Urinary incontinence symptom scores and urodynamic diagnoses. Neurourol Urodyn. 2002;21(1):30-5. [pmid: 11835421].
83 Sand PK, Hill RC, Ostergard DR. Incontinence history as a predictor of detrusor stability. Obstet Gynecol. Feb. 1988;71(2):257-60. [pmid: 3336562].
84 Cantor TJ, Bates CP. A comparative study of symptoms and objective urodynamic findings in 214 incontinent women. Br J Obstet Gynaecol. Oct. 1980;87(10):889-92. [pmid: 7191720].
85 Valente S. The usefulness of urodynamics in urogynaecological disorders. Clin Exp Obstet Gynecol. 1988;15(3):102-7. [pmid: 3402082].
86 Hastie KJ, Moisey CU. Are urodynamics necessary in female patients presenting with stress incontinence?. Br J Urol. Feb. 1989;63(2):155-6. [pmid: 2702401].
87 Bent AE, Richardson DA, Ostergard DR. Diagnosis of lower urinary tract disorders in postmenopausal patients. Am J Obstet Gynecol. Jan. 15. 1983;145(2):218-22. [pmid: 6849357].
88 De Muylder X, Claes H, Neven P, et al. Usefulness of urodynamic investigations in female incontinence. Eur J Obstet Gynecol Reprod Biol. May. 13. 1992;44(3):205-8. [pmid: 1607060].
89 Farrar DJ, Whiteside CG, Osborne JL, et al. A urosynamic analysis of micturition symptoms in the female. Surg Gynecol Obstet. Dec. 1975;141(6):875-81. [pmid: 1188564].
90 Lagro-Janssen AL, Debruyne FM, van Weel C. Value of the patient’s case history in diagnosing urinary incontinence in general practice. Br J Urol. Jun. 1991;67(6):569-72. [pmid: 2070199].
91 Ouslander J, Staskin D, Raz S, et al. Clinical versus urodynamic diagnosis in an incontinent geriatric female population. J Urol. Jan. 1987;137(1):68-71. [pmid: 3795368].
92 Bergman A, Bader K. Reliability of the patient’s history in the diagnosis of urinary incontinence. Int J Gynaecol Obstet. Jul. 1990;32(3):255-9. [pmid: 1972118].
93 Haylen BT, Sutherst JR, Frazer MI. Is the investigation of most stress incontinence really necessary?. Br J Urol. Aug. 1989;64(2):147-9. [pmid: 2765780].
94 Versi E, Cardozo LD. Perineal pad weighing versus videographic analysis in genuine stress incontinence. Br J Obstet Gynaecol. Apr. 1986;93(4):364-6. [pmid: 3964613].
95 Bates CP, Loose H, Stanton SL. The objective study of incontinence after repair operations. Surg Gynecol Obstet. Jan. 1973;136(1):17-22. [pmid: 4682258].
96 Arnold EP, Webster JR, Loose H, et al. Urodynamics of female incontinence: factors influencing the results of surgery. Am J Obstet Gynecol. Nov. 15. 1973;117(6):805-13. [pmid: 4795646].
97 Moolgaoker AS, Ardran GM, Smith JC, et al. The diagnosis and management of urinary incontinence in the female. J Obstet Gynaecol Br Commonw. Jun. 1972;79(6):481-97. [pmid: 5064185].
98 Warrell DW. Investigation and Treatment of Incontinence of Urine in Women Who Have Had a Prolapse Repair Operation. Br J Urol. Apr. 1965;37:233-9. [pmid: 14282088].
99 Klingele CJ, Carley ME, Hill RF. Patient characteristics that are associated with urodynamically diagnosed detrusor instability and genuine stress incontinence. Am J Obstet Gynecol. May. 2002;186(5):866-8. [pmid: 12015497].
100 Niecestro RM, Wheeler JS Jr, Nanninga J, et al. Use of stresscath for diagnosing stress incontinence. Urology. Mar. 1992;39(3):266-9. [pmid: 1546422].
101 Diokno AC, Normolle DP, Brown MB, et al. Urodynamic tests for female geriatric urinary incontinence. Urology. Nov. 1990;36(5):431-9. [pmid: 2238302].
102 Tyagi V, Hamoodi I, Yousef M, et al. How reliable is history taking in diagnosing type of urinary incontinence?. Paper presented at: Neurourology and Urodynamics, 2010; Joint Meeting of the International Continence Society and the International Urogynecological Association. Toronto, Canada. 23–27 August 2010.
103 Thiede HA, Saini VD. Urogynecology: comments and caveats. Am J Obstet Gynecol. Sep. 1987;157(3):563-8. [pmid: 3631157].
104 Awad SA, McGinnis RH. Factors that influence the incidence of detrusor instability in women. J Urol. Jul. 1983;130(1):114-5. [pmid: 6683325].
105 Glezerman M, Glasner M, Rikover M, et al. Evaluation of reliability of history in women complaining of urinary stress incontinence. Eur J Obstet Gynecol Reprod Biol. Mar. 1986;21(3):159-64. [pmid: 3956835].
106 Walters MD, Shields LE. The diagnostic value of history, physical examination, and the Q-tip cotton swab test in women with urinary incontinence. Am J Obstet Gynecol. Jul. 1988;159(1):145-9. [pmid: 3394734].
107 Versi E, Cardozo L, Anand D, et al. Symptoms analysis for the diagnosis of genuine stress incontinence. Br J Obstet Gynaecol. Aug. 1991;98(8):815-9. [pmid: 1911591].
108 Bump RC, Norton PA, Zinner NR, et al. Mixed urinary incontinence symptoms: urodynamic findings, incontinence severity, and treatment response. Obstet Gynecol. Jul. 2003;102(1):76-83. [pmid: 12850610].
109 Yalcin I, Versi E, Benson JT, et al. Validation of a clinical algorithm to diagnose stress urinary incontinence for large studies. J Urol. Jun. 2004;171(6 Pt 1):2321-5. [pmid: 15126813].
110 Videla FL, Wall LL. Stress incontinence diagnosed without multichannel urodynamic studies. Obstet Gynecol. Jun. 1998;91(6):965-8. [pmid: 9611005].
111 Dinokno AC, Dimaculangan RR, Lim EU, et al. Office based criteria for predicting type II stress incontinence without further evaluation studies. J Urol. Apr. 1999;161(4):1263-7. [pmid: 10081882].
112 Lemack GE, Zimmern PE. Predictability of urodynamic findings based on the Urogenital Distress Inventory-6 questionnaire. Urology. Sep. 1999;54(3):461-6. [pmid: 10475355].
113 Ramsay N, Ali HM, Heslington K. Can scoring the severity of symptoms help to predict the urodynamic diagnosis. Int Urogynecol J. 1995;6:267-70. no-3.
114 Ramsay IN, Hilton P, Rice N. The symptomatic characterization of patients with destrusor instability and those with genuine stress incontinence. Int Urogynecol J. 1993;4:23-6. No-4.
115 Montz FJ, Stanton SL. Q-Tip test in female urinary incontinence. Obstet Gynecol. Feb. 1986;67(2):258-60. [pmid: 3945436].
116 Haeusler G, Hanzal E, Joura E, et al. Differential diagnosis of detrusor instability and stress-incontinence by patient history: the Gaudenz-Incontinence-Questionnaire revisited. Acta Obstet Gynecol Scand. Sep. 1995;74(8):635-7. [pmid: 7660771].
117 Nager CW, Albo ME, Fitzgerald MP, et al. Reference urodynamic values for stress incontinent women. Neurourol Urodyn. 2007;26(3):333-40. [pmid: 17315221].
118 Matharu G, Donaldson MM, McGrother CW, et al. Relationship between urinary symptoms reported in a postal questionnaire and urodynamic diagnosis. Neurourol Urodyn. 2005;24(2):100-5. [pmid: 15605372].
119 Coyne KS, Zyczynski T, Margolis MK, et al. Validation of an overactive bladder awareness tool for use in primary care settings. Adv Ther. Jul–Aug. 2005;22(4):381-94. [pmid: 16418145].
120 Lukacz ES, Lawrence JM, Buckwalter JG, et al. Epidemiology of prolapse and incontinence questionnaire: validation of a new epidemiologic survey. Int Urogynecol J Pelvic Floor Dysfunct. Jul–Aug. 2005;16(4):272-84. [pmid: 15856132].
121 Fischer-Rasmussen W, Hansen RI, Stage P. Predictive values of diagnostic tests in the evaluation of female urinary stress incontinence. Acta Obstet Gynecol Scand. 1986;65(4):291-4. [pmid: 3739640].
122 Summitt RL Jr, Stovall TG, Bent AE, et al. Urinary incontinence: correlation of history and brief office evaluation with multichannel urodynamic testing. Am J Obstet Gynecol. Jun. 1992;166(6 Pt 1):1835-40. discussion 40–4. [pmid: 1615993].
123 Griffiths DJ, McCracken PN, Harrison GM, et al. Characteristics of urinary incontinence in elderly patients studied by 24-hour monitoring and urodynamic testing. Age Ageing. May. 1992;21(3):195-201. [pmid: 1615782].
124 Chen GD, Su TH, Lin LY. Applicability of perineal sonography in anatomical evaluation of bladder neck in women with and without genuine stress incontinence. J Clin Ultrasound. May. 1997;25(4):189-94. [pmid: 9142618].
125 Kiilholma PJ, Makinen JI, Pitkanen YA, et al. Perineal ultrasound: an alternative for radiography for evaluating stress urinary incontinence in females. Ann Chir Gynaecol Suppl. 1994;208:43-5. [pmid: 8092770].
126 Contreras Ortiz O, Lombardo RJ, Pellicari A. Non-invasive diagnosis of bladder instability using the Bladder Instability Discriminant Index (BIDI). Zentralbl Gynakol. 1993;115(10):446-9. [pmid: 8273434].
127 Bergman A, Ballard CA, Platt LD. Ultrasonic evaluation of urethrovesical junction in women with stress urinary incontinence. J Clin Ultrasound. Jun. 1988;16(5):295-300. [pmid: 3152386].
128 Bergman A, McKenzie CJ, Richmond J, et al. Transrectal ultrasound versus cystography in the evaluation of anatomical stress urinary incontinence. Br J Urol. Sep. 1988;62(3):228-34. [pmid: 3056562].
129 Bergman A, McCarthy TA, Ballard CA, et al. Role of the Q-tip test in evaluating stress urinary incontinence. J Reprod Med. Apr. 1987;32(4):273-5. [pmid: 3585870].
130 Klovning A, Hunskaar S, Eriksen BC. Validity of a scored urological history in detecting detrusor instability in female urinary incontinence. Acta Obstet Gynecol Scand. Nov. 1996;75(10):941-5. [pmid: 9003097].
131 Sunshine TJ, Glowacki GA. Clinical correlation of urodynamic testing in patients with urinary incontinence. Journal of Gynecologic Surgery. 1989;5:93-8. 131.
132 Kujansuu E, Kauppila A. Scored urological history and urethrocystometry in the differential diagnosis of female urinary incontinence. Ann Chir Gynaecol. 1982;71(4):197-202. [pmid: 6889831].
133 Diokno AC, Wells TJ, Brink CA. Urinary incontinence in elderly women: urodynamic evaluation. J Am Geriatr Soc. Oct. 1987;35(10):940-6. [pmid: 3655177].
134 Korda A, Krieger M, Hunter P, et al. The value of clinical symptoms in the diagnosis of urinary incontinence in the female. Aust N Z J Obstet Gynaecol. May. 1987;27(2):149-51. [pmid: 3675441].
135 Quinn MJ, Fanrsworth BA, Pollard WJ, et al. Vaginal ultrasound in the diagnosis of stress incontinence: a prospective comparison to urodynamic investigations. Neurourol Urodyn. 1989;8:302-3.
136 Abdel-fattah M, Barrington JW, Youssef M. The standard 1-hour pad test: does it have any value in clinical practice?. Eur Urol. Sep. 2004;46(3):377-80. [pmid: 15306111].
137 Amarenco G, Arnould B, Carita P, et al. European psychometric validation of the CONTILIFE: a Quality of Life questionnaire for urinary incontinence. Eur Urol. Apr. 2003;43(4):391-404. [pmid: 12667721].
138 Amundsen C, Lau M, English SF, et al. Do urinary symptoms correlate with urodynamic findings?. J Urol. Jun. 1999;161(6):1871-4. [pmid: 10332456].
139 Bent AE, Gousse AE, Hendrix SL, et al. Validation of a two-item quantitative questionnaire for the triage of women with urinary incontinence. Obstet Gynecol. Oct. 2005;106(4):767-73. [pmid: 16199634].
140 Borup K, Hvidman L, Nielsen JB, et al. Validity of a self-administered questionnaire, with reference to a clinical stress urinary incontinence test. Scand J Urol Nephrol. 2008;42(2):148-53. [pmid: 17853006].
141 Byrne DJ, Stewart PA, Gray BK. The role of urodynamics in female urinary stress incontinence. Br J Urol. Mar. 1987;59(3):228-9. [pmid: 3567483].
142 Caputo RM, Benson JT. The Q-tip test and urethrovesical junction mobility. Obstet Gynecol. Dec. 1993;82(6):892-6. [pmid: 8233260].
143 Cardozo LD, Stanton SL. Genuine stress incontinence and detrusor instability--a review of 200 patients. Br J Obstet Gynaecol. Mar. 1980;87(3):184-90. [pmid: 7387918].
144 Chiarelli P, Brown W, McElduff P. Leaking urine: prevalence and associated factors in Australian women. Neurourol Urodyn. 1999;18(6):567-77. [pmid: 10529705].
145 Drutz HP, Mandel F. Urodynamic analysis of urinary incontinence symptoms in women. Am J Obstet Gynecol. Aug. 1. 1979;134(7):789-92. [pmid: 463981].
146 Eastwood HD, Warrell R. Urinary incontinence in the elderly female: prediction in diagnosis and outcome of management. Age Ageing. Jul. 1984;13(4):230-4. [pmid: 6475652].
147 Eastwood HD. Urodynamic studies in the management of urinary incontinence in the elderly. Age Ageing. Feb. 1979;8(1):41-8. [pmid: 443110].
148 Jensen JK, Nielsen FR Jr, Ostergard DR. The role of patient history in the diagnosis of urinary incontinence. Obstet Gynecol. May. 1994;83(5 Pt 2):904-10. [pmid: 8159393].
149 Gunthorpe W, Brown W, Redman S. The development and evaluation of an incontinence screening questionnaire for female primary care. Neurourol Urodyn. 2000;19(5):595-607. [pmid: 11002302].
150 Harvey MA, Kristjansson B, Griffith D, et al. The Incontinence Impact Questionnaire and the Urogenital Distress Inventory: a revisit of their validity in women without a urodynamic diagnosis. Am J Obstet Gynecol. Jul. 2001;185(1):25-31. [pmid: 11483899].
151 Homma Y, Uemura S. Use of the short form of King’s Health Questionnaire to measure quality of life in patients with an overactive bladder. BJU Int. May. 2004;93(7):1009-13. [pmid: 15142153].
152 Jackson S, Donovan J, Brookes S, et al. The Bristol Female Lower Urinary Tract Symptoms questionnaire: development and psychometric testing. Br J Urol. Jun. 1996;77(6):805-12. [pmid: 8705212].
153 James M, Jackson S, Shepherd A, et al. Pure stress leakage symptomatology: is it safe to discount detrusor instability?. Br J Obstet Gynaecol. Dec. 1999;106(12):1255-8. [pmid: 10609718].
154 Kinchen KS, Lee J, Fireman B, et al. The prevalence, burden, and treatment of urinary incontinence among women in a managed care plan. J Womens Health (Larchmt). Apr. 2007;16(3):415-22. [pmid: 17439386].
155 Kulseng-Hanssen S, Borstad E. The development of a questionnaire to measure the severity of symptoms and the quality of life before and after surgery for stress incontinence. BJOG. Nov. 2003;110(11):983-8. [pmid: 14592582].
156 Lagro-Janssen TL, Smits AJ, Van Weel C. Women with urinary incontinence: self-perceived worries and general practitioners’ knowledge of problem. Br J Gen Pract. Aug. 1990;40(337):331-4. [pmid: 2121179].
157 Lemack GE, Zimmern PE. Identifying patients who require urodynamic testing before surgery for stress incontinence based on questionnaire information and surgical history. Urology. Apr. 2000;55(4):506-11. [pmid: 10736492].
158 Lin LY, Yeh NH, Lin CY, et al. Comparisons of urodynamic characteristics between female patients with overactive bladder and overactive bladder plus stress urinary incontinence. Urology. Nov. 2004;64(5):945-9. [pmid: 15533483].
159 Lowenstein L, Kenton K, FitzGerald MP, et al. Clinically useful measures in women with mixed urinary incontinence. Am J Obstet Gynecol. Jun. 2008;198(6):664 e1-3. discussion e3–4. [pmid: 18538148].
160 Massolt ET, Groen J, Vierhout ME. Application of the Blaivas-Groutz bladder outlet obstruction nomogram in women with urinary incontinence. Neurourol Urodyn. 2005;24(3):237-42. [pmid: 15747342].
161 Miller JM, Ashton-Miller JA, Carchidi LT, et al. On the lack of correlation between self-report and urine loss measured with standing provocation test in older stress-incontinent women. J Womens Health. Mar. 1999;8(2):157-62. [pmid: 10100129].
162 Morkved S, Bo K. Prevalence of urinary incontinence during pregnancy and postpartum. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(6):394-8. [pmid: 10614977].
163 Oh SJ, Ku JH, Hong SK, et al. Factors influencing self-perceived disease severity in women with stress urinary incontinence combined with or without urge incontinence. Neurourol Urodyn. 2005;24(4):341-7. [pmid: 15791635].
164 Phua SM, Shields LE. The role of urodynamics in evaluation of incontinent females. Singapore Med J. 1992;33:139-42. [pmid: 1621116].
165 Rosenzweig BA, Pushkin S, Blumenfeld D, et al. Prevalence of abnormal urodynamic test results in continent women with severe genitourinary prolapse. Obstet Gynecol. Apr. 1992;79(4):539-42. [pmid: 1553172].
166 Sand PK, Brubaker LT, Novak T. Simple standing incremental cystometry as a screening method for detrusor instability. Obstet Gynecol. Mar. 1991;77(3):453-7. [pmid: 1992416].
167 Scarpero HM, Fiske J, Xue X, et al. American Urological Association Symptom Index for lower urinary tract symptoms in women: correlation with degree of bother and impact on quality of life. Urology. Jun. 2003;61(6):1118-22. [pmid: 12809877].
168 Shimabukuro T, Takahashi Y, Naito K. Lower urinary tract symptoms in 1,912 apparently healthy persons of both sexes. Hinyokika Kiyo. Mar. 2006;52(3):189-95. [pmid: 16617872].
169 Shumaker SA, Wyman JF, Uebersax JS, et al. Health-related quality of life measures for women with urinary incontinence: the Incontinence Impact Questionnaire and the Urogenital Distress Inventory. Continence Program in Women (CPW) Research Group. Qual Life Res. Oct. 1994;3(5):291-306. [pmid: 7841963].
170 Stach-Lempinen B, Kujansuu E, Laippala P, et al. Visual analogue scale, urinary incontinence severity score and 15 D--psychometric testing of three different health-related quality-of-life instruments for urinary incontinent women. Scand J Urol Nephrol. Dec. 2001;35(6):476-83. [pmid: 11848427].
171 Stav K, Dwyer PL, Rosamilia A. Women overestimate daytime urinary frequency: the importance of the bladder diary. J Urol. May. 2009;181(5):2176-80. [pmid: 19296975].
172 Sutherst JR, Brown MC. Comparison of single and multichannel cystometry in diagnosing bladder instability. Br Med J (Clin Res Ed). Jun. 9. 1984;288(6432):1720-2. [pmid: 6428513].
173 Swift SE, Ostergard DR. Evaluation of current urodynamic testing methods in the diagnosis of genuine stress incontinence. Obstet Gynecol. Jul. 1995;86(1):85-91. [pmid: 7784028].
174 Swithinbank LV, Donovan JL, du Heaume JC, et al. Urinary symptoms and incontinence in women: relationships between occurrence, age, and perceived impact. Br J Gen Pract. Nov. 1999;49(448):897-900. [pmid: 10818656].
175 Theofrastous JP, Cundiff GW, Harris RL, et al. The effect of vesical volume on Valsalva leak-point pressures in women with genuine stress urinary incontinence. Obstet Gynecol. May. 1996;87(5 Pt 1):711-4. [pmid: 8677072].
176 Weidner AC, Myers ER, Visco AG, et al. Which women with stress incontinence require urodynamic evaluation?. Am J Obstet Gynecol. Jan. 2001;184(2):20-7. [pmid: 11174474].
177 Wyman JF, Choi SC, Harkins SW, et al. The urinary diary in evaluation of incontinent women: a test-retest analysis. Obstet Gynecol. Jun. 1988;71(6 Pt 1):812-7. [pmid: 3368165].
178 Wyman JF, Harkins SW, Choi SC, et al. Psychosocial impact of urinary incontinence in women. Obstet Gynecol. Sep. 1987;70(3 Pt 1):378-81. [pmid: 3627585].
179 Yoon E, Swift S. A comparison of maximum cystometric bladder capacity with maximum environmental voided volumes. Int Urogynecol J Pelvic Floor Dysfunct. 1998;9(2):78-82. [pmid: 9694135].
180 Nitti VW, Rovner ES, Bavendam T. Response to fesoterodine in patients with an overactive bladder and urgency urinary incontinence is independent of the urodynamic finding of detrusor overactivity. BJU Int. May. 2010;105(9):1268-75. [pmid: 19889062].
181 Auwad W, Steggles P, Bombieri L, et al. Moderate weight loss in obese women with urinary incontinence: a prospective longitudinal study. Int Urogynecol J Pelvic Floor Dysfunct. Sep. 2008;19(9):1251-9. [pmid: 18421406].
182 Wing RR, Creasman JM, West DS, et al. Improving urinary incontinence in overweight and obese women through modest weight loss. Obstet Gynecol. Aug. 2010;116(2 Pt 1):284-92. [pmid: 20664387].
183 Hines SH, Seng JS, Messer KL, et al. Adherence to a behavioral program to prevent incontinence. West J Nurs Res. Feb. 2007;29(1):36-56. discussion 7–64. [pmid: 17228060].
184 Sugaya K, Owan T, Hatano T, et al. Device to promote pelvic floor muscle training for stress incontinence. Int J Urol. Aug. 2003;10(8):416-22. [pmid: 12887362].
185 Brubaker L, Shott S, Tomezsko J, et al. Pelvic floor fitness using lay instructors. Obstet Gynecol. Jun. 2008;111(6):1298-304. [pmid: 18515512].
186 Wang AC. Bladder-sphincter biofeedback as treatment of detrusor instability in women who failed to respond to oxybutynin. Chang Gung Med J. Oct. 2000;23(10):590-9. [pmid: 11126150].
187 Bellin P, Smith J, Poll W, et al. Results of a multicenter trial of the CapSure (Re/Stor) Continence shield on women with stress urinary incontinence. Urology. May. 1998;51(5):697-706. [pmid: 9610582].
188 Crivellaro S, Tosco L, Martinez Bustamante L, et al. Long term results of the adjustable continence therapy (ACT) for recurrent female stress urinary incontinence. Paper presented at: Neurourology and Urodynamics, 2010; Joint Meeting of the International Continence Society and the International Urogynecological Association. Toronto, Canada. 23–27 August 2010.
189 Morris AR, Moore KH. The Contiform incontinence device - efficacy and patient acceptability. Int Urogynecol J Pelvic Floor Dysfunct. Dec. 2003;14(6):412-7. [pmid: 14677003].
190 Allen WA, Leek H, Izurieta A, et al. Update: the “Contiform” intravaginal device in four sizes for the treatment of stress incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2008;19(6):757-61. [pmid: 18183342].
191 Sander P, Thyssen H, Lose G, et al. Effect of a vaginal device on quality of life with urinary stress incontinence. Obstet Gynecol. Mar. 1999;93(3):407-11. [pmid: 10074989].
192 Hahn I, Milsom I. Treatment of female stress urinary incontinence with a new anatomically shaped vaginal device (Conveen Continence Guard). Br J Urol. May. 1996;77(5):711-5. [pmid: 8689116].
193 Nilsson CG. Effectiveness of the conveen continence guard (a disposable vaginal device) in the treatment of complicated female stress incontinence. Acta Obstet Gynecol Scand. Dec. 2000;79(12):1052-5. [pmid: 11130086].
194 Pieper B, Cleland V. An external urine-collection device for women: a clinical trial. J ET Nurs. Mar–Apr. 1993;20(2):51-5. [pmid: 8507726].
195 Versi E, Harvey MA. Efficacy of an external urethral device in women with genuine stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 1998;9(5):271-4. [pmid: 9849759].
196 Versi E, Griffiths DJ, Harvey MA. A new external urethral occlusive device for female urinary incontinence. Obstet Gynecol. Aug. 1998;92(2):286-91. [pmid: 9699768].
197 Sirls LT, Foote JE, Kaufman JM, et al. Long-term results of the FemSoft urethral insert for the management of female stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(2):88-95. discussion. [pmid: 12054188].
198 Macaulay M, van den Heuvel E, Jowitt F, et al. A noninvasive continence management system: development and evaluation of a novel toileting device for women. J Wound Ostomy Continence Nurs. Nov–Dec. 2007;34(6):641-8. [pmid: 18030103].
199 Donnelly MJ, Powell-Morgan S, Olsen AL, et al. Vaginal pessaries for the management of stress and mixed urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Sep–Oct. 2004;15(5):302-7. [pmid: 15300365].
200 Brincat C, Kenton K, Pat Fitzgerald M, et al. Sexual activity predicts continued pessary use. Am J Obstet Gynecol. Jul. 2004;191(1):198-200. [pmid: 15295365].
201 Maito JM, Quam ZA, Craig E, et al. Predictors of successful pessary fitting and continued use in a nurse-midwifery pessary clinic. J Midwifery Womens Health. Mar–Apr. 2006;51(2):78-84. [pmid: 16504903].
202 Sulak PJ, Kuehl TJ, Shull BL. Vaginal pessaries and their use in pelvic relaxation. J Reprod Med. Dec. 1993;38(12):919-23. [pmid: 8120847].
203 Clemons JL, Aguilar VC, Tillinghast TA, et al. Patient satisfaction and changes in prolapse and urinary symptoms in women who were fitted successfully with a pessary for pelvic organ prolapse. Am J Obstet Gynecol. Apr. 2004;190(4):1025-9. [pmid: 15118635].
204 Farrell SA, Baydock S, Amir B, et al. Effectiveness of a new self-positioning pessary for the management of urinary incontinence in women. Am J Obstet Gynecol. May. 2007;196(5):474 e1-8. [pmid: 17466709].
205 Nguyen JN, Jones CR. Pessary treatment of pelvic relaxation: factors affecting successful fitting and continued use. J Wound Ostomy Continence Nurs. Jul–Aug. 2005;32(4):255-61. quiz 62–3. [pmid: 16030465].
206 Staskin D, Bavendam T, Miller J, et al. Effectiveness of a urinary control insert in the management of stress urinary incontinence: early results of a multicenter study. Urology. May. 1996;47(5):629-36. [pmid: 8650857].
207 Kocjancic E, Crivellaro S, Smith JJ 3rd, et al. Adjustable continence therapy for treatment of recurrent female urinary incontinence. J Endourol. Jul. 2008;22(7):1403-7. [pmid: 18613782].
208 Brubaker L, Harris T, Gleason D, et al. The external urethral barrier for stress incontinence: a multicenter trial of safety and efficacy. Miniguard Investigators Group. Obstet Gynecol. Jun. 1999;93(6):932-7. [pmid: 10362157].
209 Moore KH, Simons A, Dowell C, et al. Efficacy and user acceptability of the urethral occlusive device in women with urinary incontinence. J Urol. Aug. 1999;162(2):464-8. [pmid: 10411058].
210 Sand PK, Staskin D, Miller J, et al. Effect of a urinary control insert on quality of life in incontinent women. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(2):100-5. [pmid: 10384971].
211 Aboseif SR, Franke EI, Nash SD, et al. The adjustable continence therapy system for recurrent female stress urinary incontinence: 1-year results of the North America Clinical Study Group. J Urol. May. 2009;181(5):2187-91. [pmid: 19296967].
212 Indrekvam S, Sandvik H, Hunskaar S. A Norwegian national cohort of 3198 women treated with home-managed electrical stimulation for urinary incontinence--effectiveness and treatment results. Scand J Urol Nephrol. Feb. 2001;35(1):32-9. [pmid: 11291684].
213 Galloway NT, El-Galley RE, Sand PK, et al. Update on extracorporeal magnetic innervation (EXMI) therapy for stress urinary incontinence. Urology. Dec. 4. 2000;56(6 Suppl 1):82-6. [pmid: 11114568].
214 Bergstrom K, Carlsson CP, Lindholm C, et al. Improvement of urge- and mixed-type incontinence after acupuncture treatment among elderly women - a pilot study. J Auton Nerv Syst. Mar. 15. 2000;79(2–3):173-80. [pmid: 10699649].
215 Nuhoglu B, Fidan V, Ayyildiz A, et al. Stoller afferent nerve stimulation in woman with therapy resistant over active bladder; a 1-year follow up. Int Urogynecol J Pelvic Floor Dysfunct. May. 2006;17(3):204-7. [pmid: 16049624].
216 van Kerrebroeck P, ter Meulen F, Larsson G, et al. Treatment of stress urinary incontinence using a copolymer system: impact on quality of life. BJU Int. Nov. 2004;94(7):1040-3. [pmid: 15541124].
217 van Kerrebroeck P, ter Meulen F, Larsson G, et al. Efficacy and safety of a novel system (NASHA/Dx copolymer using the Implacer device) for treatment of stress urinary incontinence. Urology. Aug. 2004;64(2):276-81. [pmid: 15302478].
218 Chapple CR, Haab F, Cervigni M, et al. An open, multicentre study of NASHA/Dx Gel (Zuidex) for the treatment of stress urinary incontinence. Eur Urol. Sep. 2005;48(3):488-94. [pmid: 15967568].
219 Tannenbaum C, Straus SE, Thorped K, et al. Effectiveness of a new evidence-based self-management tool for incontinent older women. Paper presented at: Neurourology and Urodynamics, 2010; Joint Meeting of the International Continence Society and the International Urogynecological Association. Toronto, Canada. 23–27 August 2010.
220 Vandoninck V, van Balken MR, Finazzi Agro E, et al. Percutaneous tibial nerve stimulation in the treatment of overactive bladder: urodynamic data. Neurourol Urodyn. 2003;22(3):227-32. [pmid: 12707873].
221 Vandoninck V, Van Balken MR, Finazzi Agro E, et al. Posterior tibial nerve stimulation in the treatment of urge incontinence. Neurourol Urodyn. 2003;22(1):17-23. [pmid: 12478596].
222 Govier FE, Litwiller S, Nitti V, et al. Percutaneous afferent neuromodulation for the refractory overactive bladder: results of a multicenter study. J Urol. Apr. 2001;165(4):1193-8. [pmid: 11257669].
223 Wooldridge LS. Percutaneous tibial nerve stimulation for the treatment of urinary frequency, urinary urgency, and urge incontinence: results from a community-based clinic. Urol Nurs. May–Jun. 2009;29(3):177-85. [pmid: 19579411].
224 Vandoninck V, van Balken MR, Finazzi Agro E, et al. Posterior tibial nerve stimulation in the treatment of voiding dysfunction: urodynamic data. Neurourol Urodyn. 2004;23(3):246-51. [pmid: 15098221].
225 Surwit E, Campbell JD, Karaszewski K. Neuromodulation of the pudendal, hypogastric, and tibial nerves with pelvic floor muscle rehabilitation in the treatment of urinary urge incontinence. Neuromodulation: Technology at the Neural Interface 2009. 2009;12(3):175-9.
226 Abrams P, Freeman R, Anderstrom C, et al. Tolterodine, a new antimuscarinic agent: as effective but better tolerated than oxybutynin in patients with an overactive bladder. Br J Urol. Jun. 1998;81(6):801-10. [pmid: 9666761].
227 Abrams P, Cardozo L, Chapple C, et al. Comparison of the efficacy, safety, and tolerability of propiverine and oxybutynin for the treatment of overactive bladder syndrome. Int J Urol. Jun. 2006;13(6):692-8. [pmid: 16834644].
228 Altan-Yaycioglu R, Yaycioglu O, Aydin Akova Y, et al. Ocular side-effects of tolterodine and oxybutynin, a single-blind prospective randomized trial. Br J Clin Pharmacol. May. 2005;59(5):588-92. [pmid: 15842558].
229 Appell RA. Clinical efficacy and safety of tolterodine in the treatment of overactive bladder: a pooled analysis. Urology. Dec. 1997;50(6A Suppl):90-6. discussion 7–9. [pmid: 9426760].
230 Appell RA, Sand P, Dmochowski R, et al. Prospective randomized controlled trial of extended-release oxybutynin chloride and tolterodine tartrate in the treatment of overactive bladder: results of the OBJECT Study. Mayo Clin Proc. Apr. 2001;76(4):358-63. [pmid: 11322350].
231 Armstrong RB, Luber KM, Peters KM. Comparison of dry mouth in women treated with extended-release formulations of oxybutynin or tolterodine for overactive bladder. Int Urol Nephrol. 2005;37(2):247-52. [pmid: 16142551].
232 Armstrong RB, Dmochowski RR, Sand PK, et al. Safety and tolerability of extended-release oxybutynin once daily in urinary incontinence: combined results from two phase 4 controlled clinical trials. Int Urol Nephrol. 2007;39(4):1069-77. [pmid: 17333521].
233 Barkin J, Corcos J, Radomski S, et al. A randomized, double-blind, parallel-group comparison of controlled- and immediate-release oxybutynin chloride in urge urinary incontinence. Clin Ther. Jul. 2004;26(7):1026-36. [pmid: 15336467].
234 Bent AE, Gousse AE, Hendrix SL, et al. Duloxetine compared with placebo for the treatment of women with mixed urinary incontinence. Neurourol Urodyn. 2008;27(3):212-21. [pmid: 17580357].
235 Birns J, Lukkari E, Malone-Lee JG. A randomized controlled trial comparing the efficacy of controlled-release oxybutynin tablets (10 mg once daily) with conventional oxybutynin tablets (5 mg twice daily) in patients whose symptoms were stabilized on 5 mg twice daily of oxybutynin. BJU Int. May. 2000;85(7):793-8. [pmid: 10792154].
236 Blom MW, Sommers DK. The effects of an estradiol transdermal therapeutic system, alone and in combination with naproxen, on urge incontinence in elderly women: a pilot study. Current Therapeutic Research. 1995;56(10):1100-4. [doi: 10.1013/0011.393].
237 Bodeker RH, Madersbacher H, Neumeister C, et al. Dose escalation improves therapeutic outcome: post hoc analysis of data from a 12-week, multicentre, double-blind, parallel-group trial of trospium chloride in patients with urinary urge incontinence. BMC Urol. 2010;10:15. [pmid: 20840754].
238 Brubaker L, Richter HE, Visco A, et al. Refractory idiopathic urge urinary incontinence and botulinum A injection. J Urol. Jul. 2008;180(1):217-22. [pmid: 18499184].
239 Brunton S, Wang F, Edwards SB, et al. Profile of adverse events with duloxetine treatment: a pooled analysis of placebo-controlled studies. Drug Saf. May. 1. 2010;33(5):393-407. [pmid: 20397739].
240 Bump RC, Voss S, Beardsworth A, et al. Long-term efficacy of duloxetine in women with stress urinary incontinence. BJU Int. Jul. 2008;102(2):214-8. [pmid: 18422764].
241 Burgio KL, Locher JL, Roth DL, et al. Psychological improvements associated with behavioral and drug treatment of urge incontinence in older women. J Gerontol B Psychol Sci Soc Sci. Jan. 2001;56(1):P46-51. [pmid: 11192337].
242 Burgio KL, Locher JL, Goode PS. Combined behavioral and drug therapy for urge incontinence in older women. J Am Geriatr Soc. Apr. 2000;48(4):370-4. [pmid: 10798461].
243 Burgio KL, Locher JL, Goode PS, et al. Behavioral vs drug treatment for urge urinary incontinence in older women: a randomized controlled trial. JAMA. Dec. 16. 1998;280(23):1995-2000. [pmid: 9863850].
244 Burgio KL, Kraus SR, Menefee S, et al. Behavioral therapy to enable women with urge incontinence to discontinue drug treatment: a randomized trial. Ann Intern Med. Aug. 5. 2008;149(3):161-9. [pmid: 18678843].
245 Fitzgerald MP, Lemack G, Wheeler T, et al. Nocturia, nocturnal incontinence prevalence, and response to anticholinergic and behavioral therapy. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2008;19(11):1545-50. [pmid: 18704249].
246 Zimmern P, Litman HJ, Mueller E, et al. Effect of fluid management on fluid intake and urge incontinence in a trial for overactive bladder in women. BJU Int. Jun. 2010;105(12):1680-5. [pmid: 19912207].
247 Burgio KL, Goode PS, Richter HE, et al. Combined behavioral and individualized drug therapy versus individualized drug therapy alone for urge urinary incontinence in women. J Urol. Aug. 2010;184(2):598-603. [pmid: 20639023].
248 But I, Pakiz M, Hlebic G, et al. Comparison of efficacy and tolerability of two selective M3 receptor antagonists Solifenacin and Darifenacin in women with overactive bladder- the Solidar study. Paper presented at: Neurourology and Urodynamics, 2010; Joint Meeting of the International Continence Society and the International Urogynecological Association. Toronto, Canada. 23–27 August 2010.
249 Cardozo L, Lange R, Voss S, et al. Short- and long-term efficacy and safety of duloxetine in women with predominant stress urinary incontinence. Curr Med Res Opin. Feb. 2010;26(2):253-61. [pmid: 19929591].
250 Cardozo L, Castro-Diaz D, Gittelman M, et al. Reductions in overactive bladder-related incontinence from pooled analysis of phase III trials evaluating treatment with solifenacin. Int Urogynecol J Pelvic Floor Dysfunct. Sep. 2006;17(5):512-9. [pmid: 16625311].
251 Cardozo L, Drutz HP, Baygani SK, et al. Pharmacological treatment of women awaiting surgery for stress urinary incontinence. Obstet Gynecol. Sep. 2004;104(3):511-9. [pmid: 15339761].
252 Cartwright R, Srikrishna S, Cardozo L, et al. Patient-selected goals in overactive bladder: a placebo controlled randomized double-blind trial of transdermal oxybutynin for the treatment of urgency and urge incontinence. BJU Int. Jan. 2011;107(1):70-6. [pmid: 20626389].
253 Castro RA, Arruda RM, Zanetti MR, et al. Single-blind, randomized, controlled trial of pelvic floor muscle training, electrical stimulation, vaginal cones, and no active treatment in the management of stress urinary incontinence. Clinics (Sao Paulo). Aug. 2008;63(4):465-72. [pmid: 18719756].
254 Castro-Diaz D, Palma PC, Bouchard C, et al. Effect of dose escalation on the tolerability and efficacy of duloxetine in the treatment of women with stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Aug. 2007;18(8):919-29. [pmid: 17160693].
255 Chancellor MB, Appell RA, Sathyan G, et al. A comparison of the effects on saliva output of oxybutynin chloride and tolterodine tartrate. Clin Ther. May. 2001;23(5):753-60. [pmid: 11394733].
256 Chancellor MB, Kianifard F, Beamer E, et al. A comparison of the efficacy of darifenacin alone vs. darifenacin plus a Behavioural Modification Programme upon the symptoms of overactive bladder. Int J Clin Pract. Apr. 2008;62(4):606-13. [pmid: 18324952].
257 Chancellor MB, Oefelein MG, Vasavada S. Obesity is associated with a more severe overactive bladder disease state that is effectively treated with once-daily administration of trospium chloride extended release. Neurourol Urodyn. Apr. 2010;29(4):551-4. [pmid: 19634167].
258 Chapple CR, Abrams P. Comparison of darifenacin and oxybutynin in patients with overactive bladder: assessment of ambulatory urodynamics and impact on salivary flow. Eur Urol. Jul. 2005;48(1):102-9. [pmid: 15936869].
259 Chapple C, Van Kerrebroeck P, Tubaro A, et al. Clinical efficacy, safety, and tolerability of once-daily fesoterodine in subjects with overactive bladder. Eur Urol. Oct. 2007;52(4):1204-12. [pmid: 17651893].
260 Chapple CR, Van Kerrebroeck PE, Junemann KP, et al. Comparison of fesoterodine and tolterodine in patients with overactive bladder. BJU Int. Nov. 2008;102(9):1128-32. [pmid: 18647298].
261 Chapple C, DuBeau C, Ebinger U, et al. Darifenacin treatment of patients >or= 65 years with overactive bladder: results of a randomized, controlled, 12-week trial. Curr Med Res Opin. Oct. 2007;23(10):2347-58. [pmid: 17706004].
262 Chapple C, Steers W, Norton P, et al. A pooled analysis of three phase III studies to investigate the efficacy, tolerability and safety of darifenacin, a muscarinic M3 selective receptor antagonist, in the treatment of overactive bladder. BJU Int. May. 2005;95(7):993-1001. [pmid: 15839920].
263 Chapple CR, Fianu-Jonsson A, Indig M, et al. Treatment outcomes in the STAR study: a subanalysis of solifenacin 5 mg and tolterodine ER 4 mg. Eur Urol. Oct. 2007;52(4):1195-203. [pmid: 17574730].
264 Chapple CR, Cardozo L, Steers WD, et al. Solifenacin significantly improves all symptoms of overactive bladder syndrome. Int J Clin Pract. Aug. 2006;60(8):959-66. [pmid: 16893438].
265 Chapple CR, Arano P, Bosch JL, et al. Solifenacin appears effective and well tolerated in patients with symptomatic idiopathic detrusor overactivity in a placebo- and tolterodine-controlled phase 2 dose-finding study. BJU Int. Jan. 2004;93(1):71-7. [pmid: 14678372].
266 Chapple C. Fesoterodine a new effective and well-tolerated antimuscarinic for the treatment of urgency-frequency syndrome:results of a phase 2 controlled study. Paper presented at: 2004 Congress of the International Continence Society. August 25–27, 2004. Paris, France. Abstract 142. 2004.
267 Chompootaweep S, Nunthapisud P, Trivijitsilp P, et al. The use of two estrogen preparations (a combined contraceptive pill versus conjugated estrogen cream) intravaginally to treat urogenital symptoms in postmenopausal Thai women: a comparative study. Clin Pharmacol Ther. Aug. 1998;64(2):204-10. [pmid: 9728901].
268 Choo MS, Lee JZ, Lee JB, et al. Efficacy and safety of solifenacin succinate in Korean patients with overactive bladder: a randomised, prospective, double-blind, multicentre study. Int J Clin Pract. Nov. 2008;62(11):1675-83. [pmid: 19143854].
269 Chu F, Smith N, Uchida T. Efficacy and safety of solifenacin succinate 10 mg once Daily: A multicenter, phase III, randomized, double-blind, placebo-controlled, parallel-group trial in patients with overactive bladder. Current Therapeutic Research. December. 2009;70(6):405-20. [doi: 10.1016/j.curtheres.2009.11.001].
270 Corcos J, Casey R, Patrick A, et al. A double-blind randomized dose-response study comparing daily doses of 5, 10 and 15 mg controlled-release oxybutynin: balancing efficacy with severity of dry mouth. BJU Int. Mar. 2006;97(3):520-7. [pmid: 16469019].
271 Davila GW, Daugherty CA, Sanders SW. A short-term, multicenter, randomized double-blind dose titration study of the efficacy and anticholinergic side effects of transdermal compared to immediate release oral oxybutynin treatment of patients with urge urinary incontinence. J Urol. Jul. 2001;166(1):140-5. [pmid: 11435842].
272 Dessole S, Rubattu G, Ambrosini G, et al. Efficacy of low-dose intravaginal estriol on urogenital aging in postmenopausal women. Menopause. Jan–Feb. 2004;11(1):49-56. [pmid: 14716182].
273 Diokno AC, Appell RA, Sand PK, et al. Prospective, randomized, double-blind study of the efficacy and tolerability of the extended-release formulations of oxybutynin and tolterodine for overactive bladder: results of the OPERA trial. Mayo Clin Proc. Jun. 2003;78(6):687-95. [pmid: 12934777].
274 Chu FM, Dmochowski RR, Lama DJ, et al. Extended-release formulations of oxybutynin and tolterodine exhibit similar central nervous system tolerability profiles: a subanalysis of data from the OPERA trial. Am J Obstet Gynecol. Jun. 2005;192(6):1849-54. discussion 54–5. [pmid: 15970828].
275 Anderson RU, MacDiarmid S, Kell S, et al. Effectiveness and tolerability of extended-release oxybutynin vs extended-release tolterodine in women with or without prior anticholinergic treatment for overactive bladder. Int Urogynecol J Pelvic Floor Dysfunct. Sep. 2006;17(5):502-11. [pmid: 16724169].
276 Dmochowski RR, Davila GW, Zinner NR, et al. Efficacy and safety of transdermal oxybutynin in patients with urge and mixed urinary incontinence. J Urol. Aug. 2002;168(2):580-6. [pmid: 12131314].
277 Dmochowski RR, Nitti V, Staskin D, et al. Transdermal oxybutynin in the treatment of adults with overactive bladder: combined results of two randomized clinical trials. World J Urol. Sep. 2005;23(4):263-70. [pmid: 16151816].
278 Dmochowski RR, Sand PK, Zinner NR, et al. Comparative efficacy and safety of transdermal oxybutynin and oral tolterodine versus placebo in previously treated patients with urge and mixed urinary incontinence. Urology. Aug. 2003;62(2):237-42. [pmid: 12893326].
279 Dmochowski RR, Miklos JR, Norton PA, et al. Duloxetine versus placebo for the treatment of North American women with stress urinary incontinence. J Urol. Oct. 2003;170(4 Pt 1):1259-63. [pmid: 14501737].
280 Dmochowski R, Kreder K, MacDiarmid S, et al. The clinical efficacy of tolterodine extended-release is maintained for 24 h in patients with overactive bladder. BJU Int. Jul. 2007;100(1):107-10. [pmid: 17552957].
281 Dmochowski R, Chapple C, Nitti VW, et al. Efficacy and Safety of OnabotulinumtoxinA for Idiopathic Overactive Bladder: A Double-Blind, Placebo Controlled, Randomized, Dose Ranging Trial. J Urol. Oct. 2010;16. [pmid: 20952013].
282 Dorschner W, Stolzenburg JU, Griebenow R, et al. Efficacy and cardiac safety of propiverine in elderly patients - a double-blind, placebo-controlled clinical study. Eur Urol. Jun. 2000;37(6):702-8. [pmid: 10828671].
283 Drutz HP, Appell RA, Gleason D, et al. Clinical efficacy and safety of tolterodine compared to oxybutynin and placebo in patients with overactive bladder. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(5):283-9. [pmid: 10543335].
284 DuBeau CE, Khullar V, Versi E. “Unblinding” in randomized controlled drug trials for urinary incontinence: Implications for assessing outcomes when adverse effects are evident. Neurourol Urodyn. 2005;24(1):13-20. [pmid: 15570576].
285 Duckett JR, Vella M, Kavalakuntla G, et al. Tolerability and efficacy of duloxetine in a nontrial situation. BJOG: An International Journal of Obstetrics & Gynaecology. May. 2007;114(5):543-7. [pmid: 17355360].
286 Enzelsberger H, Helmer H, Kurz C. Intravesical instillation of oxybutynin in women with idiopathic detrusor instability: a randomised trial. Br J Obstet Gynaecol. Nov. 1995;102(11):929-30. [pmid: 8534633].
287 Flynn MK, Amundsen CL, Perevich M, et al. Outcome of a randomized, double-blind, placebo controlled trial of botulinum A toxin for refractory overactive bladder. J Urol. Jun. 2009;181(6):2608-15. [pmid: 19375091].
288 Foote J, Glavind K, Kralidis G, et al. Treatment of overactive bladder in the older patient: pooled analysis of three phase III studies of darifenacin, an M3 selective receptor antagonist. Eur Urol. Sep. 2005;48(3):471-7. [pmid: 15990219].
289 Franzen K, Johansson JE, Lauridsen I, et al. Electrical stimulation compared with tolterodine for treatment of urge/urge incontinence amongst women--a randomized controlled trial. Int Urogynecol J Pelvic Floor Dysfunct. Dec. 2010;21(12):1517-24. [pmid: 20585755].
290 Freeman R, Hill S, Millard R, et al. Reduced perception of urgency in treatment of overactive bladder with extended-release tolterodine. Obstet Gynecol. Sep. 2003;102(3):605-11. [pmid: 12962951].
291 Gahimer J, Wernicke J, Yalcin I, et al. A retrospective pooled analysis of duloxetine safety in 23,983 subjects. Curr Med Res Opin. Jan. 2007;23(1):175-84. [pmid: 17257478].
292 Ghei M, Maraj BH, Miller R, et al. Effects of botulinum toxin B on refractory detrusor overactivity: a randomized, double-blind, placebo controlled, crossover trial. J Urol. Nov. 2005;174(5):1873-7. discussion 7. [pmid: 16217327].
293 Ghoniem GM, Van Leeuwen JS, Elser DM, et al. A randomized controlled trial of duloxetine alone, pelvic floor muscle training alone, combined treatment and no active treatment in women with stress urinary incontinence. J Urol. May. 2005;173(5):1647-53. [pmid: 15821528].
294 Goode PS, Burgio KL, Locher JL, et al. Urodynamic changes associated with behavioral and drug treatment of urge incontinence in older women. J Am Geriatr Soc. May. 2002;50(5):808-16. [pmid: 12028165].
295 Goode PS. Behavioral and drug therapy for urinary incontinence. Urology. Mar. 2004;63(3 Suppl 1):58-64. [pmid: 15013654].
296 Gupta SK, Sathyan G. Pharmacokinetics of an oral once-a-day controlled-release oxybutynin formulation compared with immediate-release oxybutynin. J Clin Pharmacol. Mar. 1999;39(3):289-96. [pmid: 10073329].
297 Gupta SK, Sathyan G, Lindemulder EA, et al. Quantitative characterization of therapeutic index: application of mixed-effects modeling to evaluate oxybutynin dose-efficacy and dose-side effect relationships. Clin Pharmacol Ther. Jun. 1999;65(6):672-84. [pmid: 10391673].
298 Gousse A, Kanagarajah P, Ayyathurai R, et al. A single center, prospective, randomized study to evaluate the effect of repeat intradetrusor injections of botulinum toxin-A for refractory idiopathic overactive bladder patients: Dose difference between 100U and 150U. Paper presented at: Neuorurology and Urodynamics, 2010; Joint Meeting of the International Continence Society and the International Urogynecological Association. Toronto, Canada. 23–27 August 2010.
299 Haab F, Corcos J, Siami P, et al. Long-term treatment with darifenacin for overactive bladder: results of a 2-year, open-label extension study. BJU Int. Nov. 2006;98(5):1025-32. [pmid: 16879437].
300 Haab F, Cardozo L, Chapple C, et al. Long-term open-label solifenacin treatment associated with persistence with therapy in patients with overactive bladder syndrome. Eur Urol. Mar. 2005;47(3):376-84. [pmid: 15716204].
301 Haab F, Stewart L, Dwyer P. Darifenacin, an M3 selective receptor antagonist, is an effective and well-tolerated once-daily treatment for overactive bladder. Eur Urol. Apr. 2004;45(4):420-9. discussion 9. [pmid: 15041104].
302 Halaska M, Ralph G, Wiedemann A, et al. Controlled, double-blind, multicentre clinical trial to investigate long-term tolerability and efficacy of trospium chloride in patients with detrusor instability. World J Urol. May. 2003;20(6):392-9. [pmid: 12811500].
303 Herschorn S, Becker D, Miller E, et al. Impact of a health education intervention in overactive bladder patients. Can J Urol. Dec. 2004;11(6):2430-7. [pmid: 15636668].
304 Herschorn S, Stothers L, Carlson K, et al. Tolerability of 5 mg Solifenacin Once Daily Versus 5 mg Oxybutynin Immediate Release 3 Times Daily: Results of the VECTOR Trial. J Urol. Mar. 2010;17. [pmid: 20303119].
305 Herschorn S, Heesakkers J, Castro-Diaz D, et al. Effects of tolterodine extended release on patient perception of bladder condition and overactive bladder symptoms*. Curr Med Res Opin. Dec. 2008;24(12):3513-21. [pmid: 19032133].
306 Ho CH, Chang TC, Lin HH, et al. Solifenacin and tolterodine are equally effective in the treatment of overactive bladder symptoms. J Formos Med Assoc. Oct. 2010;109(10):702-8. [pmid: 20970066].
307 Holtedahl K, Verelst M, Schiefloe A, et al. Usefulness of urodynamic examination in female urinary incontinence--lessons from a population-based, randomized, controlled study of conservative treatment. Scand J Urol Nephrol. Jun. 2000;34(3):169-74. [pmid: 10961470].
308 Holtedahl K, Verelst M, Schiefloe A. A population based, randomized, controlled trial of conservative treatment for urinary incontinence in women. Acta Obstet Gynecol Scand. Jul. 1998;77(6):671-7. [pmid: 9688247].
309 Homma Y, Koyama N. Minimal clinically important change in urinary incontinence detected by a quality of life assessment tool in overactive bladder syndrome with urge incontinence. Neurourol Urodyn. 2006;25(3):228-35. [pmid: 16532466].
310 Homma Y, Kawabe K. Health-related quality of life of Japanese patients with overactive bladder treated with extended-release tolterodine or immediate-release oxybutynin: a randomized, placebo-controlled trial. World J Urol. Oct. 2004;22(4):251-6. [pmid: 15455256].
311 Homma Y, Paick JS, Lee JG, et al. Clinical efficacy and tolerability of extended-release tolterodine and immediate-release oxybutynin in Japanese and Korean patients with an overactive bladder: a randomized, placebo-controlled trial. BJU Int. Nov. 2003;92(7):741-7. [pmid: 14616458].
312 Hurley DJ, Turner CL, Yalcin I, et al. Duloxetine for the treatment of stress urinary incontinence in women: an integrated analysis of safety. Eur J Obstet Gynecol Reprod Biol. Mar. 1. 2006;125(1):120-8. [pmid: 16188367].
313 Viktrup L, Yalcin I. Duloxetine treatment of stress urinary incontinence in women: effects of demographics, obesity, chronic lung disease, hypoestrogenism, diabetes mellitus, and depression on efficacy. Eur J Obstet Gynecol Reprod Biol. Jul. 2007;133(1):105-13. [pmid: 16769171].
314 Ishiko O, Hirai K, Sumi T, et al. Hormone replacement therapy plus pelvic floor muscle exercise for postmenopausal stress incontinence. A randomized, controlled trial. J Reprod Med. Mar. 2001;46(3):213-20. [pmid: 11304861].
315 Jackson S, Shepherd A, Brookes S, et al. The effect of oestrogen supplementation on post-menopausal urinary stress incontinence: a double-blind placebo-controlled trial. Br J Obstet Gynaecol. Jul. 1999;106(7):711-8. [pmid: 10428529].
316 Jacquetin B, Wyndaele J. Tolterodine reduces the number of urge incontinence episodes in patients with an overactive bladder. Eur J Obstet Gynecol Reprod Biol. Sep. 2001;98(1):97-102. [pmid: 11516807].
317 Johnson TM 2nd, Burgio KL, Redden DT, et al. Effects of behavioral and drug therapy on nocturia in older incontinent women. J Am Geriatr Soc. May. 2005;53(5):846-50. [pmid: 15877562].
318 Jonas U, Hofner K, Madersbacher H, et al. Efficacy and safety of two doses of tolterodine versus placebo in patients with detrusor overactivity and symptoms of frequency, urge incontinence, and urgency: urodynamic evaluation. The International Study Group. World J Urol. 1997;15(2):144-51. [pmid: 9144906].
319 Junemann KP, Hessdorfer E, Unamba-Oparah I, et al. Propiverine hydrochloride immediate and extended release: comparison of efficacy and tolerability in patients with overactive bladder. Urol Int. 2006;77(4):334-9. [pmid: 17135784].
320 Junemann KP, Al-Shukri S. Efficacy and tolerability of trospium cholride and tolterodine in 234 patients with urge syndrome: a double-bline, placebo-controlled, multicentre clinical trial. Neurourol Urodyn. 2000;19:488-90. 85B.
321 Junemann KP, Halaska M, Rittstein T, et al. Propiverine versus tolterodine: efficacy and tolerability in patients with overactive bladder. Eur Urol. Sep. 2005;48(3):478-82. [pmid: 15967567].
322 Kaplan SA, Schneider T, Foote J, et al. Superior efficacy of fesoterodine over tolterodine with rapid onset: A prospective, head-to-head, placebo-controlled trial. Paper presented at: Neurourology and Urodynamics, 2010; Joint Meeting of the International Continence Society and the International Urogynecological Association. Toronto, Canada. 23–27 August 2010.
323 Karademir K, Baykal K, Sen B, et al. A peripheric neuromodulation technique for curing detrusor overactivity: Stoller afferent neurostimulation. Scand J Urol Nephrol. 2005;39(3):230-3. [pmid: 16118096].
324 Karram MM, Toglia MR, Serels SR, et al. Treatment with solifenacin increases warning time and improves symptoms of overactive bladder: results from VENUS, a randomized, double-blind, placebo-controlled trial. Urology. Jan. 2009;73(1):14-8. [pmid: 18995887].
325 Toglia MR, Serels SR, Laramee C, et al. Solifenacin for overactive bladder: patient-reported outcomes from a large placebo-controlled trial. Postgrad Med. Sep. 2009;121(5):151-8. [pmid: 19820284].
326 Kelleher C, Cardozo L, Kobashi K, et al. Solifenacin: as effective in mixed urinary incontinence as in urge urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2006;17(4):382-8. [pmid: 16283422].
327 Kelleher CJ, Reese PR, Pleil AM, et al. Health-related quality of life of patients receiving extended-release tolterodine for overactive bladder. The American journal of managed care. 2002:S608-15. [pmid: 12516955].
328 Kelleher CJ, Tubaro A, Wang JT, et al. Impact of fesoterodine on quality of life: pooled data from two randomized trials. BJU Int. Jul. 2008;102(1):56-61. [pmid: 18564231].
329 Khullar V, Hill S, Laval KU, et al. Treatment of urge-predominant mixed urinary incontinence with tolterodine extended release: a randomized, placebo-controlled trial. Urology. Aug. 2004;64(2):269-74. discussion 74–5. [pmid: 15302476].
330 Khullar V, Rovner ES, Dmochowski R, et al. Fesoterodine dose response in subjects with overactive bladder syndrome. Urology. May. 2008;71(5):839-43. [pmid: 18342923].
331 Kinchen KS, Obenchain R, Swindle R. Impact of duloxetine on quality of life for women with symptoms of urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Sep–Oct. 2005;16(5):337-44. [pmid: 15662490].
332 Kreder KJ Jr, Brubaker L, Mainprize T. Tolterodine is equally effective in patients with mixed incontinence and those with urge incontinence alone. BJU Int. Sep. 2003;92(4):418-21. [pmid: 12930432].
333 Lackner TE, Wyman JF, McCarthy TC, et al. Randomized, placebo-controlled trial of the cognitive effect, safety, and tolerability of oral extended-release oxybutynin in cognitively impaired nursing home residents with urge urinary incontinence. J Am Geriatr Soc. May. 2008;56(5):862-70. [pmid: 18410326].
334 Landis JR, Kaplan S, Swift S, et al. Efficacy of antimuscarinic therapy for overactive bladder with varying degrees of incontinence severity. J Urol. Feb. 2004;171(2 Pt 1):752-6. [pmid: 14713803].
335 Lee JG, Hong JY, Choo MS, et al. Tolterodine: as effective but better tolerated than oxybutynin in Asian patients with symptoms of overactive bladder. Int J Urol. May. 2002;9(5):247-52. [pmid: 12060436].
336 Lee KS, Lee HW, Choo MS, et al. Urinary urgency outcomes after propiverine treatment for an overactive bladder: the ‘Propiverine study on overactive bladder including urgency data’. BJU Int. Jun. 2010;105(11):1565-70. [pmid: 19912183].
337 Lehtoranta K, Tainio H, Lukkari-Lax E, et al. Pharmacokinetics, efficacy, and safety of intravesical formulation of oxybutynin in patients with detrusor overactivity. Scand J Urol Nephrol. Feb. 2002;36(1):18-24. [pmid: 12002352].
338 Leung HY, Yip SK, Cheon C, et al. A randomized controlled trial of tolterodine and oxybutynin on tolerability and clinical efficacy for treating Chinese women with an overactive bladder. BJU Int. Sep. 2002;90(4):375-80. [pmid: 12175392].
339 Lin AT, Sun MJ, Tai HL, et al. Duloxetine versus placebo for the treatment of women with stress predominant urinary incontinence in Taiwan: a double-blind, randomized, placebo-controlled trial. BMC Urol. 2008;8:2. [pmid: 18221532].
340 Lipton RB, Kolodner K, Wesnes K. Assessment of cognitive function of the elderly population: effects of darifenacin. J Urol. Feb. 2005;173(2):493-8. [pmid: 15643227].
341 Lose G, Englev E. Oestradiol-releasing vaginal ring versus oestriol vaginal pessaries in the treatment of bothersome lower urinary tract symptoms. BJOG. Aug. 2000;107(8):1029-34. [pmid: 10955437].
342 MacDiarmid SA, Anderson RU, Armstrong RB, et al. Efficacy and safety of extended release oxybutynin for the treatment of urge incontinence: an analysis of data from 3 flexible dosing studies. J Urol. Oct. 2005;174(4 Pt 1):1301-5. discussion 5. [pmid: 16145407].
343 Madersbacher H, Halaska M, Voigt R, et al. A placebo-controlled, multicentre study comparing the tolerability and efficacy of propiverine and oxybutynin in patients with urgency and urge incontinence. BJU Int. Oct. 1999;84(6):646-51. [pmid: 10510109].
344 Malhotra B, Wood N, Sachse R, et al. Thorough QT study of the effect of fesoterodine on cardiac repolarization. Int J Clin Pharmacol Ther. May. 2010;48(5):309-18. [pmid: 20420787].
345 Malone-Lee JG, Al-Buheissi S. Does urodynamic verification of overactive bladder determine treatment success? Results from a randomized placebo-controlled study. BJU Int. Apr. 2009;103(7):931-7. [pmid: 19281469].
346 Malone-Lee JG, Walsh JB, Maugourd MF. Tolterodine: a safe and effective treatment for older patients with overactive bladder. J Am Geriatr Soc. Jun. 2001;49(6):700-5. [pmid: 11454106].
347 Mattiasson A, Blaakaer J, Hoye K, et al. Simplified bladder training augments the effectiveness of tolterodine in patients with an overactive bladder. BJU Int. Jan. 2003;91(1):54-60. [pmid: 12614251].
348 Milani R, Scalambrino S, Milia R, et al. Double-blind crossover comparison of flavoxate and oxybutynin in women affected by urinary urge syndrome. Int Urogynecol J. 1993:3-8.
349 Millard R, Tuttle J, Moore K, et al. Clinical efficacy and safety of tolterodine compared to placebo in detrusor overactivity. J Urol. May. 1999;161(5):1551-5. [pmid: 10210394].
350 Millard RJ, Moore K, Rencken R, et al. Duloxetine vs placebo in the treatment of stress urinary incontinence: a four-continent randomized clinical trial. BJU Int. Feb. 2004;93(3):311-8. [pmid: 14764128].
351 Moore KH, Hay DM, Imrie AE, et al. Oxybutynin hydrochloride (3 mg) in the treatment of women with idiopathic detrusor instability. Br J Urol. Nov. 1990;66(5):479-85. [pmid: 2249115].
352 Naglie G, Radomski SB, Brymer C, et al. A randomized, double-blind, placebo controlled crossover trial of nimodipine in older persons with detrusor instability and urge incontinence. J Urol. Feb. 2002;167(2 Pt 1):586-90. [pmid: 11792923].
353 Nitti CVW, Dmochowski R, Sand PK, et al. Efficacy, safety and tolerability of fesoterodine for overactive bladder syndrome. J Urol. Dec. 2007;178(6):2488-94. [pmid: 17937959].
354 Norton P, Karram M, Wall LL, et al. Randomized double-blind trial of terodiline in the treatment of urge incontinence in women. Obstet Gynecol. Sep. 1994;84(3):386-91. [pmid: 8058236].
355 Norton PA, Zinner NR, Yalcin I, et al. Duloxetine versus placebo in the treatment of stress urinary incontinence. Am J Obstet Gynecol. Jul. 2002;187(1):40-8. [pmid: 12114886].
356 Sahai A, Kalsi V, Khan MS, et al. Techniques for the intradetrusor administration of botulinum toxin. BJU Int. Apr. 2006;97(4):675-8. [pmid: 16536751].
357 Effects of terodiline on urinary incontinence among older non-institutionalized women. Terodiline in the Elderly American Multicenter Study Group. J Am Geriatr Soc. Sep. 1993;41(9):915-22. [pmid: 8409177].
358 Ozdedeli S, Karapolat H, Akkoc Y. Comparison of intravaginal electrical stimulation and trospium hydrochloride in women with overactive bladder syndrome: a randomized controlled study. Clin Rehabil. Apr. 2010;24(4):342-51. [pmid: 20212061].
359 Peters KM, Macdiarmid SA, Wooldridge LS, et al. Randomized trial of percutaneous tibial nerve stimulation versus extended-release tolterodine: results from the overactive bladder innovative therapy trial. J Urol. Sep. 2009;182(3):1055-61. [pmid: 19616802].
360 MacDiarmid SA, Peters KM, Shobeiri SA, et al. Long-term durability of percutaneous tibial nerve stimulation for the treatment of overactive bladder. J Urol. Jan. 2010;183(1):234-40. [pmid: 19913821].
361 Pontari MA, Mohamed FB, Lebovitch S, et al. Central nervous system findings on functional magnetic resonance imaging in patients before and after treatment with anticholinergic medication. J Urol. May. 2010;183(5):1899-905. [pmid: 20303095].
362 Rentzhog L, Stanton SL, Cardozo L, et al. Efficacy and safety of tolterodine in patients with detrusor instability: a dose-ranging study. Br J Urol. Jan. 1998;81(1):42-8. [pmid: 9467475].
363 Richter HE, Burgio KL, Brubaker L, et al. Continence pessary compared with behavioral therapy or combined therapy for stress incontinence: a randomized controlled trial. Obstet Gynecol. Mar. 2010;115(3):609-17. [pmid: 20177294].
364 Rios LA, Panhoca R, Mattos D Jr, et al. Intravesical resiniferatoxin for the treatment of women with idiopathic detrusor overactivity and urgency incontinence: A single dose, 4 weeks, double-blind, randomized, placebo controlled trial. Neurourol Urodyn. 2007;26(6):773-8. [pmid: 17638305].
365 Robinson D, Cardozo L, Terpstra G, et al. A randomized double-blind placebo-controlled multicentre study to explore the efficacy and safety of tamsulosin and tolterodine in women with overactive bladder syndrome. BJU Int. Oct. 2007;100(4):840-5. [pmid: 17822465].
366 Rogers RG, Bachmann G, Scarpero H, et al. Effects of tolterodine ER on patient-reported outcomes in sexually active women with overactive bladder and urgency urinary incontinence. Curr Med Res Opin. Sep. 2009;25(9):2159-65. [pmid: 19601704].
367 Rogers R, Bachmann G, Jumadilova Z, et al. Efficacy of tolterodine on overactive bladder symptoms and sexual and emotional quality of life in sexually active women. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2008;19(11):1551-7. [pmid: 18685795].
368 Rogers RG, Omotosho T, Bachmann G, et al. Continued symptom improvement in sexually active women with overactive bladder and urgency urinary incontinence treated with tolterodine ER for 6 months. Int Urogynecol J Pelvic Floor Dysfunct. Apr. 2009;20(4):381-5. [pmid: 19132285].
369 Rudy D, Cline K, Harris R, et al. Multicenter phase III trial studying trospium chloride in patients with overactive bladder. Urology. Feb. 2006;67(2):275-80. [pmid: 16461077].
370 Rufford J, Hextall A, Cardozo L, et al. A double-blind placebo-controlled trial on the effects of 25 mg estradiol implants on the urge syndrome in postmenopausal women. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2003;14(2):78-83. [pmid: 12851747].
371 Salvatore S, Khullar V, Cardozo L, et al. Long-term prospective randomized study comparing two different regimens of oxybutynin as a treatment for detrusor overactivity. Eur J Obstet Gynecol Reprod Biol. Apr. 1. 2005;119(2):237-41. [pmid: 15808387].
372 Sand PK, Morrow JD, Bavendam T, et al. Efficacy and tolerability of fesoterodine in women with overactive bladder. Int Urogynecol J Pelvic Floor Dysfunct. Jul. 2009;20(7):827-35. [pmid: 19495545].
373 Sand PK, Miklos J, Ritter H, et al. A comparison of extended-release oxybutynin and tolterodine for treatment of overactive bladder in women. Int Urogynecol J Pelvic Floor Dysfunct. Jul–Aug. 2004;15(4):243-8. [pmid: 15517668].
374 Sand PK, Dmochowski RR, Zinner NR, et al. Trospium chloride extended release is effective and well tolerated in women with overactive bladder syndrome. Int Urogynecol J Pelvic Floor Dysfunct. Aug. 2009;29. [pmid: 19727537].
375 Dmochowski RR, Rosenberg MT, Zinner NR, et al. Extended-release trospium chloride improves quality of life in overactive bladder. Value Health. Mar. 2010;13(2):251-7. [pmid: 19818062].
376 Sand PK, Goldberg RP, Dmochowski RR, et al. The impact of the overactive bladder syndrome on sexual function: a preliminary report from the Multicenter Assessment of Transdermal Therapy in Overactive Bladder with Oxybutynin trial. Am J Obstet Gynecol. Dec. 2006;195(6):1730-5. [pmid: 17132474].
377 Sand P, Zinner N, Newman D, et al. Oxybutynin transdermal system improves the quality of life in adults with overactive bladder: a multicentre, community-based, randomized study. BJU Int. Apr. 2007;99(4):836-44. [pmid: 17187655].
378 Schagen van Leeuwen JH, Lange RR, Jonasson AF, et al. Efficacy and safety of duloxetine in elderly women with stress urinary incontinence or stress-predominant mixed urinary incontinence. Maturitas. Jun. 20. 2008;60(2):138-47. [pmid: 18547757].
379 Staskin DR, Harnett MD. Effect of trospium chloride on somnolence and sleepiness in patients with overactive bladder. Curr Urol Rep. Dec. 2004;5(6):423-6. [pmid: 15541209].
380 Staskin DR, Cardozo L. Baseline incontinence severity is predictive of the percentage of patients continent after receiving once-daily trospium chloride extended release. Int J Clin Pract. Jun. 2009;63(6):973-6. [pmid: 19459997].
381 Steers WD, Herschorn S, Kreder KJ, et al. Duloxetine compared with placebo for treating women with symptoms of overactive bladder. BJU Int. Aug. 2007;100(2):337-45. [pmid: 17511767].
382 Swift S, Garely A, Dimpfl T, et al. A new once-daily formulation of tolterodine provides superior efficacy and is well tolerated in women with overactive bladder. Int Urogynecol J Pelvic Floor Dysfunct. Feb. 2003;14(1):50-4. discussion 4–5. [pmid: 12601517].
383 Szonyi G, Collas DM, Ding YY, et al. Oxybutynin with bladder retraining for detrusor instability in elderly people: a randomized controlled trial. Age Ageing. 1995/07/01 ed. 1995;24:287-91. [pmid: 7484484].
384 Takei M, Homma Y. Long-term safety, tolerability and efficacy of extended-release tolterodine in the treatment of overactive bladder in Japanese patients. Int J Urol. May. 2005;12(5):456-64. [pmid: 15948744].
385 Tapp AJ, Cardozo LD, Versi E, et al. The treatment of detrusor instability in post-menopausal women with oxybutynin chloride: a double blind placebo controlled study. Br J Obstet Gynaecol. Jun. 1990;97(6):521-6. [pmid: 2198921].
386 Tincello DG, Adams EJ, Sutherst JR, et al. Oxybutynin for detrusor instability with adjuvant salivary stimulant pastilles to improve compliance: results of a multicentre, randomized controlled trial. BJU Int. Mar. 2000;85(4):416-20. [pmid: 10691817].
387 Thuroff JW, Bunke B, Ebner A, et al. Randomized, double-blind, multicenter trial on treatment of frequency, urgency and incontinence related to detrusor hyperactivity: oxybutynin versus propantheline versus placebo. J Urol. Apr. 1991;145(4):813-6. discussion 6–7. [pmid: 2005707].
388 Toglia MR, Ostergard DR, Appell RA, et al. Solifenacin for overactive bladder: secondary analysis of data from VENUS based on baseline continence status. Int Urogynecol J Pelvic Floor Dysfunct. Jul. 2010;21(7):847-54. [pmid: 20339833].
389 U.S. Food and Drug Administration CfDEaR. Statistical Review for Sanctura (Trospium Chloride) Tablets. Available at: http://www.accessdata.fda.gov/drugsatfda_docs/nda/2004/21-595_Sanctura.cfm. Accessed June 25, 2010.
390 U.S. Food and Drug Administration CfDEaR. Statistical Review for Enablex (Darifenacin Hydrobromide) Extended Release Tablets. Available at: http://www.accessdata.fda.gov/drugsatfda_docs/nda/2004/21-513_Enablex.cfm. Accessed June 25, 2010.
391 Anderson RU, Mobley D, Blank B, et al. Once daily controlled versus immediate release oxybutynin chloride for urge urinary incontinence. OROS Oxybutynin Study Group. J Urol. Jun. 1999;161(6):1809-12. [pmid: 10332441].
392 Preik M, Albrecht D, O’Connell M, et al. Effect of controlled-release delivery on the pharmacokinetics of oxybutynin at different dosages: severity-dependent treatment of the overactive bladder. BJU Int. Oct. 2004;94(6):821-7. [pmid: 15476516].
393 van Kerrebroeck P, Abrams P, Lange R, et al. Duloxetine versus placebo in the treatment of European and Canadian women with stress urinary incontinence. BJOG. Mar. 2004;111(3):249-57. [pmid: 14961887].
394 Van Kerrebroeck P, Kreder K, Jonas U, et al. Tolterodine. once. -daily: superior efficacy and tolerability in the treatment of the overactive bladder. Urology. Mar. 2001;57(3):414-21. [pmid: 11248608].
395 Vardy MD, Mitcheson HD, Samuels TA, et al. Effects of solifenacin on overactive bladder symptoms, symptom bother and other patient-reported outcomes: results from VIBRANT - a double-blind, placebo-controlled trial. Int J Clin Pract. Dec. 2009;63(12):1702-14. [pmid: 19930331].
396 Vella M, Duckett J, Basu M. Duloxetine 1 year on: the long-term outcome of a cohort of women prescribed duloxetine. Int Urogynecol J Pelvic Floor Dysfunct. Jul. 2008;19(7):961-4. [pmid: 18231697].
397 Gleason DM, Susset J, White C, et al. Evaluation of a new once-daily formulation of oxbutynin for the treatment of urinary urge incontinence. Ditropan XL Study Group. Urology. Sep. 1999;54(3):420-3. [pmid: 10475346].
398 von Holst T, Salbach B. Efficacy and tolerability of a new 7-day transdermal estradiol patch versus placebo in hysterectomized women with postmenopausal complaints. Maturitas. 2000/03/14 ed. 2000;34:143-53. [pmid: 10714909].
399 Waetjen LE, Brown JS, Vittinghoff E, et al. The effect of ultralow-dose transdermal estradiol on urinary incontinence in postmenopausal women. Obstet Gynecol. Nov. 2005;106(5 Pt 1):946-52. [pmid: 16260511].
400 Wagg A, Wyndaele JJ, Sieber P. Efficacy and tolerability of solifenacin in elderly subjects with overactive bladder syndrome: a pooled analysis. Am J Geriatr Pharmacother. Mar. 2006;4(1):14-24. [pmid: 16730617].
401 Wang AC, Chih SY, Chen MC. Comparison of electric stimulation and oxybutynin chloride in management of overactive bladder with special reference to urinary urgency: a randomized placebo-controlled trial. Urology. Nov. 2006;68(5):999-1004. [pmid: 17113893].
402 Wang AC, Chen MC, Kuo WY, et al. Urgency-free time interval as primary endpoint for evaluating the outcome of a randomized OAB treatment. Int Urogynecol J Pelvic Floor Dysfunct. Jul. 2009;20(7):819-25. [pmid: 19495544].
403 Mazur D, Wehnert J, Dorschner W, et al. Clinical and urodynamic effects of propiverine in patients suffering from urgency and urge incontinence. A multicentre dose-optimizing study. Scand J Urol Nephrol. Sep. 1995;29(3):289-94. [pmid: 8578271].
404 Weil EH, Eerdmans PH, Dijkman GA, et al. Randomized double-blind placebo-controlled multicenter evaluation of efficacy and dose finding of midodrine hydrochloride in women with mild to moderate stress urinary incontinence: a phase II study. Int Urogynecol J Pelvic Floor Dysfunct. 1998;9(3):145-50. [pmid: 9745973].
405 Wein AJ, Khullar V, Wang JT, et al. Achieving continence with antimuscarinic therapy for overactive bladder: effects of baseline incontinence severity and bladder diary duration. BJU Int. Feb. 2007;99(2):360-3. [pmid: 17155987].
406 Weinstein DL, Cohen JS, Liu C, et al. Duloxetine in the treatment of women with stress urinary incontinence: results from DESIRE (Duloxetine Efficacy and Safety for Incontinence in Racial and Ethnic populations). Curr Med Res Opin. Nov. 2006;22(11):2121-9. [pmid: 17076972].
407 Wiseman PA, Malone-Lee J, Rai GS. Terodiline with bladder retraining for treating detrusor instability in elderly people. BMJ. Apr. 27. 1991;302(6783):994-6. [pmid: 2039897].
408 Yalcin I, Patrick DL, Summers K, et al. Minimal clinically important differences in Incontinence Quality-of-Life scores in stress urinary incontinence. Urology. Jun. 2006;67(6):1304-8. [pmid: 16750246].
409 Yalcin I, Bump RC. The effect of previous treatment experience and incontinence severity on the placebo response of stress urinary incontinence. Am J Obstet Gynecol. Jul. 2004;191(1):194-7. [pmid: 15295364].
410 Yamaguchi O, Marui E, Kakizaki H, et al. Randomized, double-blind, placebo- and propiverine-controlled trial of the once-daily antimuscarinic agent solifenacin in Japanese patients with overactive bladder. BJU Int. Sep. 2007;100(3):579-87. [pmid: 17669143].
411 Zellner M, Madersbacher H, Palmtag H, et al. Trospium chloride and oxybutynin hydrochloride in a german study of adults with urinary urge incontinence: results of a 12-week, multicenter, randomized, double-blind, parallel-group, flexible-dose noninferiority trial. Clin Ther. Nov. 2009;31(11):2519-39. [pmid: 20109997].
412 Zinner N, Tuttle J, Marks L. Efficacy and tolerability of darifenacin, a muscarinic M3 selective receptor antagonist (M3 SRA), compared with oxybutynin in the treatment of patients with overactive bladder. World J Urol. Sep. 2005;23(4):248-52. [pmid: 16096831].
413 Zinner N, Kobashi KC, Ebinger U, et al. Darifenacin treatment for overactive bladder in patients who expressed dissatisfaction with prior extended-release antimuscarinic therapy. Int J Clin Pract. Nov. 2008;62(11):1664-74. [pmid: 18811599].
414 Zinner N, Susset J, Gittelman M, et al. Efficacy, tolerability and safety of darifenacin, an M(3) selective receptor antagonist: an investigation of warning time in patients with OAB. Int J Clin Pract. Jan. 2006;60(1):119-26. [pmid: 16409440].
415 Zinner NR, Mattiasson A, Stanton SL. Efficacy, safety, and tolerability of extended-release once-daily tolterodine treatment for overactive bladder in older versus younger patients. J Am Geriatr Soc. May. 2002;50(5):799-807. [pmid: 12028164].
416 Zinner N, Harnett M, Sabounjian L, et al. The overactive bladder-symptom composite score: a composite symptom score of toilet voids, urgency severity and urge urinary incontinence in patients with overactive bladder. J Urol. May. 2005;173(5):1639-43. [pmid: 15821526].
417 McHorney CA, Victor Spain C, Alexander CM, et al. Validity of the adherence estimator in the prediction of 9-month persistence with medications prescribed for chronic diseases: a prospective analysis of data from pharmacy claims. Clin Ther. Nov. 2009;31(11):2584-607. [pmid: 20110004].
418 Yeaw J, Benner JS, Walt JG, et al. Comparing adherence and persistence across 6 chronic medication classes. J Manag Care Pharm. Nov–Dec. 2009;15(9):728-40. [pmid: 19954264].
419 Michel MC. Fesoterodine: a novel muscarinic receptor antagonist for the treatment of overactive bladder syndrome. Expert Opin Pharmacother. Jul. 2008;9(10):1787-96. [pmid: 18570610].
420 Cole P. Fesoterodine, an advanced antimuscarininc for the treatment of overactive bladder: a safety update. Drugs of the Future. 2004;29(7):715-20.
421 Kelleher C, Snedecor S, Lee R, et al. Evaluating pharmacologic treatment of overactive bladder: The economic costs and benefits of fesoterodine. UroToday International Journal. 2008;1(0).
422 Kelleher CJ, Kreder KJ, Pleil AM, et al. Long-term health-related quality of life of patients receiving extended-release tolterodine for overactive bladder. Am J Manag Care. Dec. 2002;8(19 Suppl):S616-30. [pmid: 12516956].
423 Siami P, Seidman LS, Lama D. A multicenter, prospective, open-label study of tolterodine extended-release 4 mg for overactive bladder: the speed of onset of therapeutic assessment trial (STAT). Clin Ther. Apr. 2002;24(4):616-28. [pmid: 12017406].
424 Kreder K, Mayne C, Jonas U. Long-term safety, tolerability and efficacy of extended-release tolterodine in the treatment of overactive bladder. Eur Urol. Jun. 2002;41(6):588-95. [pmid: 12074774].
425 Wernick JE, Lledo A, Raskin J, et al. An evaluation of the cardiovascular safety profile of duloxetine: findings from 42 placebo-controlled studies. Drug Saf. 2007;30(5):437-55. [pmid: 17472422].
426 Michel MC, Methfessel D, Minarzyk A, et al. Safety and tolerability of duloxetine in the treatment of female stress urinary incontinence (SUI) in general practice in Germany: Results from a large observational study. Paper presented at: International Continence Society. 2009. 2009.
427 Serati M, Salvatore S, Uccella S, et al. Is there a synergistic effect of topical oestrogens when administered with antimuscarinics in the treatment of symptomatic detrusor overactivity?. Eur Urol. Mar. 2009;55(3):713-9. [pmid: 18584946].
428 Ghei M, Miller R, Malone-Lee J. Case series data to encourage randomized trials of bladder retraining compared to antimuscarinic agents. J Urol. Apr. 2006;175(4):1411-5. discussion 5–6. [pmid: 16516010].
429 Garely AD, Kaufman JM, Sand PK, et al. Symptom bother and health-related quality of life outcomes following solifenacin treatment for overactive bladder: the VESIcare Open-Label Trial (VOLT). Clin Ther. Nov. 2006;28(11):1935-46. [pmid: 17213014].
430 Capo JP Jr, Laramee C, Lucente V, et al. Solifenacin treatment for overactive bladder in Hispanic patients: patient-reported symptom bother and quality of life outcomes from the VESIcare Open-Label Trial. Int J Clin Pract. Jan. 2008;62(1):39-46. [pmid: 18036164].
431 Sand PK, Steers WD, Dmochowski R, et al. Patient-reported most bothersome symptoms in OAB: post hoc analysis of data from a large, open-label trial of solifenacin. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2009;20(6):667-75. [pmid: 19434385].
432 Mallett V, Burks D, Garely AD, et al. Solifenacin treatment for overactive bladder in black patients: patient-reported symptom bother and health-related quality of life outcomes. Curr Med Res Opin. Apr. 2007;23(4):821-31. [pmid: 17407639].
433 Chancellor MB, Zinner N, Whitmore K, et al. Efficacy of solifenacin in patients previously treated with tolterodine extended release 4 mg: results of a 12-week, multicenter, open-label, flexible-dose study. Clin Ther. Oct. 2008;30(10):1766-81. [pmid: 19014833].
434 Swift SE, Siami P, Forero-Schwanhaeuser S. Diary and patient-reported outcomes in patients with severe overactive bladder switching from tolterodine extended release 4 mg/day to solifenacin treatment: An open-label, flexible-dosing, multicentre study. Clin Drug Investig. 2009;29(5):305-16. [pmid: 19366272].
435 Zinner N, Noe L, Rasouliyan L, et al. Impact of solifenacin on quality of life, medical care use, work productivity, and health utility in the elderly: an exploratory subgroup analysis. Am J Geriatr Pharmacother. Dec. 2009;7(6):373-82. [pmid: 20129258].
436 Zinner N, Noe L, Rasouliyan L, et al. Impact of solifenacin on resource utilization, work productivity and health utility in overactive bladder patients switching from tolterodine ER. Curr Med Res Opin. Jun. 2008;24(6):1583-91. [pmid: 18423103].
437 Sexton CC, Coyne KS, Vats V, et al. Impact of overactive bladder on work productivity in the United States: results from EpiLUTS. Am J Manag Care. Mar. 2009;15(4 Suppl):S98-107. [pmid: 19355804].
438 Irwin DE, Milsom I, Kopp Z, et al. Impact of overactive bladder symptoms on employment, social interactions and emotional well-being in six European countries. BJU Int. Jan. 2006;97(1):96-100. [pmid: 16336336].
439 Wu EQ, Birnbaum H, Marynchenko M, et al. Employees with overactive bladder: work loss burden. J Occup Environ Med. May. 2005;47(5):439-46. [pmid: 15891521].
440 Pelletier EM, Vats V, Clemens JQ. Pharmacotherapy adherence and costs versus nonpharmacologic management in overactive bladder. Am J Manag Care. Mar. 2009;15(4 Suppl):S108-14. [pmid: 19355799].
441 Schabert VF, Bavendam T, Goldberg EL, et al. Challenges for managing overactive bladder and guidance for patient support. Am J Manag Care. Mar. 2009;15(4 Suppl):S118-22. [pmid: 19355801].
442 Bolge S. Impact of successful treatment of overactive bladder on health care resource use and productivity. Drug Benefits Trends. 2006;18:244-55.
443 Dmochowski RR, Newman DK. Impact of overactive bladder on women in the United States: results of a national survey. Curr Med Res Opin. Jan. 2007;23(1):65-76. [pmid: 17257467].
444 Zhou Z, Jensen G. Insurance claims costs for overactive bladder disorder. Drug Benefits Trends. 2001;13(4):45-8. 53. 8.
445 Brubaker L, Fanning K, Goldberg EL, et al. Predictors of discontinuing overactive bladder medications. BJU Int. May. 2010;105(9):1283-90. [pmid: 19912189].
446 Benner JS, Nichol MB, Rovner ES, et al. Patient-reported reasons for discontinuing overactive bladder medication. BJU Int. May. 2010;105(9):1276-82. [pmid: 19912188].
447 Coyne KS, Elinoff V, Gordon DA, et al. Relationships between improvements in symptoms and patient assessments of bladder condition, symptom bother and health-related quality of life in patients with overactive bladder treated with tolterodine. Int J Clin Pract. Jun. 2008;62(6):925-31. [pmid: 18479285].
448 Elinoff V, Bavendam T, Glasser DB, et al. Symptom-specific efficacy of tolterodine extended release in patients with overactive bladder: the IMPACT trial. Int J Clin Pract. Jun. 2006;60(6):745-51. [pmid: 16805763].
449 Michel MC, Oelke M, Goepel M, et al. Relationships among symptoms, bother, and treatment satisfaction in overactive bladder patients. Neurourol Urodyn. 2007;26(2):190-5. [pmid: 17096320].
450 Michel MC, de la Rosette JJ, Piro M, et al. Does concomitant stress incontinence alter the efficacy of tolterodine in patients with overactive bladder?. J Urol. Aug. 2004;172(2):601-4. [pmid: 15247741].
451 Michel MC, Schneider T, Krege S, et al. Does gender or age affect the efficacy and safety of tolterodine?. J Urol. Sep. 2002;168(3):1027-31. [pmid: 12187215].
452 Roberts R, Bavendam T, Glasser DB, et al. Tolterodine extended release improves patient-reported outcomes in overactive bladder: results from the IMPACT trial. Int J Clin Pract. Jun. 2006;60(6):752-8. [pmid: 16805764].
453 Sussman DO, Kraus SR, Carlsson M, et al. Onset of efficacy of tolterodine extended release in patients with overactive bladder. Curr Med Res Opin. Apr. 2007;23(4):777-81. [pmid: 17407634].
454 Lawrence M, Guay DR, Benson SR, et al. Immediate-release oxybutynin versus tolterodine in detrusor overactivity: a population analysis. Pharmacotherapy. Apr. 2000;20(4):470-5. [pmid: 10772377].
455 Shaya FT, Blume S, Gu A, et al. Persistence with overactive bladder pharmacotherapy in a Medicaid population. Am J Manag Care. Jul. 2005;11(4 Suppl):S121-9. [pmid: 16161385].
456 Hussain RM, Hartigan-Go K, Thomas SH, et al. Effect of oxybutynin on the QTc interval in elderly patients with urinary incontinence. Br J Clin Pharmacol. Jan. 1996;41(1):73-5. [pmid: 8824696].
457 Nilsson CG, Lukkari E, Haarala M, et al. Comparison of a 10-mg controlled release oxybutynin tablet with a 5-mg oxybutynin tablet in urge incontinent patients. Neurourol Urodyn. 1997;16(6):533-42. [pmid: 9353802].
458 Bemelmans BL, Kiemeney LA, Debruyne FM. Low-dose oxybutynin for the treatment of urge incontinence: good efficacy and few side effects. Eur Urol. Jun. 2000;37(6):709-13. [pmid: 10828672].
459 Radomski SB, Caley B, Reiz JL, et al. Preliminary evaluation of a new controlled-release oxybutynin in urinary incontinence. Curr Med Res Opin. 2004;20(2):249-53. [pmid: 15006020].
460 Wang PS, Levin R, Zhao SZ, et al. Urinary antispasmodic use and the risks of ventricular arrhythmia and sudden death in older patients. J Am Geriatr Soc. Jan. 2002;50(1):117-24. [pmid: 12028256].
461 Diokno A, Sand P, Labasky R, et al. Long-term safety of extended-release oxybutynin chloride in a community-dwelling population of participants with overactive bladder: a one-year study. Int Urol Nephrol. 2002;34(1):43-9. [pmid: 12549638].
462 Pizzi LT, Talati A, Gemmen E, et al. Impact of transdermal oxybutynin on work productivity in patients with overactive bladder: results from the MATRIX study. Pharmacoeconomics. 2009;27(4):329-39. [pmid: 19485428].
463 Newman DK. The MATRIX study: assessment of health-related quality of life in adults with the use of transdermal oxybutynin. Director. Winter. 2008;16(1):22-5. [pmid: 19343871].
464 Wyndaele JJ, Goldfischer ER, Morrow JD, et al. Effects of flexible-dose fesoterodine on overactive bladder symptoms and treatment satisfaction: an open-label study. Int J Clin Pract. Apr. 2009;63(4):560-7. [pmid: 19348029].
465 Werner M, Schmid DM, Schussler B. Efficacy of botulinum-A toxin in the treatment of detrusor overactivity incontinence: a prospective nonrandomized study. Am J Obstet Gynecol. May. 2005;192(5):1735-40. [pmid: 15902187].
466 Balkrishnan R, Bhosle MJ, Camacho FT, et al. Predictors of medication adherence and associated health care costs in an older population with overactive bladder syndrome: a longitudinal cohort study. J Urol. Mar. 2006;175(3 Pt 1):1067-71. discussion 71–2. [pmid: 16469620].
467 Yu YF, Nichol MB, Yu AP, et al. Persistence and adherence of medications for chronic overactive bladder/urinary incontinence in the california medicaid program. Value Health. Jul–Aug. 2005;8(4):495-505. [pmid: 16091027].
468 Perfetto EM, Subedi P, Jumadilova Z. Treatment of overactive bladder: a model comparing extended-release formulations of tolterodine and oxybutynin. Am J Manag Care. Jul. 2005;11(4 Suppl):S150-7. [pmid: 16161388].
469 Hughes DA, Dubois D. Cost-effectiveness analysis of extended-release formulations of oxybutynin and tolterodine for the management of urge incontinence. Pharmacoeconomics. 2004;22(16):1047-59. [pmid: 15524493].
470 O’Brien BJ, Goeree R, Bernard L, et al. Cost-Effectiveness of tolterodine for patients with urge incontinence who discontinue initial therapy with oxybutynin: a Canadian perspective. Clin Ther. Dec. 2001;23(12):2038-49. [pmid: 11813937].
471 Varadharajan S, Jumadilova Z, Girase P, et al. Economic impact of extended-release tolterodine versus immediate- and extended-release oxybutynin among commercially insured persons with overactive bladder. Am J Manag Care. Jul. 2005;11(4 Suppl):S140-9. [pmid: 16161387].
472 Ko Y, Malone DC, Armstrong EP. Pharmacoeconomic evaluation of antimuscarinic agents for the treatment of overactive bladder. Pharmacotherapy. Dec. 2006;26(12):1694-702. [pmid: 17125433].
473 Chapple CR. Darifenacin: a novel M3 muscarinic selective receptor antagonist for the treatment of overactive bladder. Expert Opin Investig Drugs. Nov. 2004;13(11):1493-500. [pmid: 15500396].
474 Dmochowski RR, Peters KM, Morrow JD, et al. Randomized, double-blind, placebo-controlled trial of flexible-dose fesoterodine in subjects with overactive bladder. Urology. Jan. 2010;75(1):62-8. [pmid: 19931895].
475 Herschorn S, Swift S, Guan Z, et al. Comparison of fesoterodine and tolterodine extended release for the treatment of overactive bladder: a head-to-head placebo-controlled trial. BJU Int. Jan. 2010;105(1):58-66. [pmid: 20132103].
476 Cardozo L, Khullar V, Wang JT, et al. Fesoterodine in patients with overactive bladder syndrome: can the severity of baseline urgency urinary incontinence predict dosing requirement?. BJU Int. Feb. 2010;11. [pmid: 20151972].
477 Cardozo L, Thorpe A, Warner J, et al. The cost-effectiveness of solifenacin vs fesoterodine, oxybutynin immediate-release, propiverine, tolterodine extended-release and tolterodine immediate-release in the treatment of patients with overactive bladder in the UK National Health Service. BJU Int. Feb. 2010;3. [pmid: 20132203].
478 Aksac B, Aki S, Karan A, et al. Biofeedback and pelvic floor exercises for the rehabilitation of urinary stress incontinence. Gynecol Obstet Invest. 2003;56(1):23-7. [pmid: 12867764].
479 Alewijnse D, Metsemakers JF, Mesters IE, et al. Effectiveness of pelvic floor muscle exercise therapy supplemented with a health education program to promote long-term adherence among women with urinary incontinence. Neurourol Urodyn. 2003;22(4):284-95. [pmid: 12808702].
480 Amaro JL, Gameiro MO, Padovani CR. Effect of intravaginal electrical stimulation on pelvic floor muscle strength. Int Urogynecol J Pelvic Floor Dysfunct. Sep–Oct. 2005;16(5):355-8. [pmid: 15647885].
481 Amaro JL, Gameiro MO, Kawano PR, et al. Intravaginal electrical stimulation: a randomized, double-blind study on the treatment of mixed urinary incontinence. Acta Obstet Gynecol Scand. 2006;85(5):619-22. [pmid: 16752244].
482 Andersen RC. Long-term follow-up comparison of Durasphere and Contigen in the treatment of stress urinary incontinence. Journal of Lower Genital Tract Disease. 2002;(4):239-43. CN-00443954 PubMed ID. [pmid: 17051030].
483 Appell RA, Juma S, Wells WG, et al. Transurethral radiofrequency energy collagen micro-remodeling for the treatment of female stress urinary incontinence. Neurourol Urodyn. 2006;25(4):331-6. [pmid: 16673379].
484 Arvonen T, Fianu-Jonasson A, Tyni-Lenne R. Effectiveness of two conservative modes of physical therapy in women with urinary stress incontinence. Neurourol Urodyn. 2001;20(5):591-9. [pmid: 11574936].
485 Aukee P, Immonen P, Penttinen J, et al. Increase in pelvic floor muscle activity after 12 weeks’ training: a randomized prospective pilot study. Urology. Dec. 2002;60(6):1020-3. discussion 3–4. [pmid: 12475661].
486 Aukee P, Immonen P, Laaksonen DE, et al. The effect of home biofeedback training on stress incontinence. Acta Obstet Gynecol Scand. Oct. 2004;83(10):973-7. [pmid: 15453897].
487 Bano F, Barrington JW, Dyer R. Comparison between porcine dermal implant (Permacol) and silicone injection (Macroplastique) for urodynamic stress incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Mar–Apr. 2005;16(2):147-50. discussion 50. [pmid: 15378234].
488 Barroso JC, Ramos JG, Martins-Costa S, et al. Transvaginal electrical stimulation in the treatment of urinary incontinence. BJU Int. Feb. 2004;93(3):319-23. [pmid: 14764129].
489 Berghmans LC, Frederiks CM, de Bie RA, et al. Efficacy of biofeedback, when included with pelvic floor muscle exercise treatment, for genuine stress incontinence. Neurourol Urodyn. 1996;15(1):37-52. [pmid: 8696355].
490 Berghmans B, van Waalwijk van Doorn E, Nieman F, et al. Efficacy of physical therapeutic modalities in women with proven bladder overactivity. Eur Urol. Jun. 2002;41(6):581-7. [pmid: 12074773].
491 Blowman C, Pickles c, Emery S, et al. Prospective double blind controlled trial of intensive physiotherapy with and without stimulation of the pelvic floor in treatment of genuine stress incontinence. Physiotherapy. October. 1991;77(10):661-4.
492 Bo K, Talseth T. Change in urethral pressure during voluntary pelvic floor muscle contraction and vaginal electrical stimulation. Int Urogynecol J Pelvic Floor Dysfunct. 1997;8(1):3-6. discussion -7. [pmid: 9260089].
493 Bo K, Talseth T, Holme I. Single blind, randomised controlled trial of pelvic floor exercises, electrical stimulation, vaginal cones, and no treatment in management of genuine stress incontinence in women. BMJ. Feb. 20. 1999;318(7182):487-93. [pmid: 10024253].
494 Bo K, Talseth T, Vinsnes A. Randomized controlled trial on the effect of pelvic floor muscle training on quality of life and sexual problems in genuine stress incontinent women. Acta Obstet Gynecol Scand. Jul. 2000;79(7):598-603. [pmid: 10929962].
495 Bo K, Kvarstein B, Nygaard I. Lower urinary tract symptoms and pelvic floor muscle exercise adherence after 15 years. Obstet Gynecol. May. 2005;105(5 Pt 1):999-1005. [pmid: 15863536].
496 Borawski KM, Foster RT, Webster GD, et al. Predicting implantation with a neuromodulator using two different test stimulation techniques: A prospective randomized study in urge incontinent women. Neurourol Urodyn. 2007;26(1):14-8. [pmid: 17123297].
497 Borello-France DF, Zyczynski HM, Downey PA, et al. Effect of pelvic-floor muscle exercise position on continence and quality-of-life outcomes in women with stress urinary incontinence. Phys Ther. Jul. 2006;86(7):974-86. [pmid: 16813477].
498 Borello-France DF, Downey PA, Zyczynski HM, et al. Continence and quality-of-life outcomes 6 months following an intensive pelvic-floor muscle exercise program for female stress urinary incontinence: a randomized trial comparing low- and high-frequency maintenance exercise. Phys Ther. Dec. 2008;88(12):1545-53. [pmid: 18820095].
499 Borrie MJ, Bawden M, Speechley M, et al. Interventions led by nurse continence advisers in the management of urinary incontinence: a randomized controlled trial. CMAJ. May. 14. 2002;166(10):1267-73. [pmid: 12041843].
500 Bower WF, Moore KH, Adams RD, et al. A urodynamic study of surface neuromodulation versus sham in detrusor instability and sensory urgency. J Urol. Dec. 1998;160(6 Pt 1):2133-6. [pmid: 9817339].
501 Boyington AR, Dougherty MC, Phetrasuwan S. Effectiveness of a computer-based system to deliver a continence health promotion intervention. J Wound Ostomy Continence Nurs. Jul–Aug. 2005;32(4):246-54. [pmid: 16030464].
502 Brown JS, Wing R, Barrett-Connor E, et al. Lifestyle intervention is associated with lower prevalence of urinary incontinence: the Diabetes Prevention Program. Diabetes Care. Feb. 2006;29(2):385-90. [pmid: 16443892].
503 Brubaker L, Benson JT, Bent A, et al. Transvaginal electrical stimulation for female urinary incontinence. Am J Obstet Gynecol. Sep. 1997;177(3):536-40. [pmid: 9322620].
504 Bryant CM, Dowell CJ, Fairbrother G. Caffeine reduction education to improve urinary symptoms. Br J Nurs. Apr 25–May 8. 2002;11(8):560-5. [pmid: 11979209].
505 Burgio KL, Goode PS, Locher JL, et al. Behavioral training with and without biofeedback in the treatment of urge incontinence in older women: a randomized controlled trial. JAMA. Nov. 13. 2002;288(18):2293-9. [pmid: 12425706].
506 Burns PA, Pranikoff K, Nochajski T, et al. Treatment of stress incontinence with pelvic floor exercises and biofeedback. J Am Geriatr Soc. Mar. 1990;38(3):341-4. [pmid: 2179379].
507 Burns PA, Pranikoff K, Nochajski TH, et al. A comparison of effectiveness of biofeedback and pelvic muscle exercise treatment of stress incontinence in older community-dwelling women. J Gerontol. Jul. 1993;48(4):M167-74. [pmid: 8315230].
508 But I. Conservative treatment of female urinary incontinence with functional magnetic stimulation. Urology. Mar. 2003;61(3):558-61. [pmid: 12639647].
509 But I, Faganelj M, Sostaric A. Functional magnetic stimulation for mixed urinary incontinence. J Urol. May. 2005;173(5):1644-6. [pmid: 15821527].
510 de Oliveira Camargo F, Rodrigues AM, Arruda RM, et al. Pelvic floor muscle training in female stress urinary incontinence: comparison between group training and individual treatment using PERFECT assessment scheme. Int Urogynecol J Pelvic Floor Dysfunct. Aug. 2009;19. [pmid: 19690792].
511 Cammu H, Van Nylen M. Pelvic floor exercises versus vaginal weight cones in genuine stress incontinence. Eur J Obstet Gynecol Reprod Biol. Mar. 1998;77(1):89-93. [pmid: 9550207].
512 Chadha Y, Mollison J, Howie F, et al. Guidelines in gynaecology: evaluation in menorrhagia and in urinary incontinence. BJOG. Apr. 2000;107(4):535-43. [pmid: 10759275].
513 Corcos J, Collet JP, Shapiro S, et al. Multicenter randomized clinical trial comparing surgery and collagen injections for treatment of female stress urinary incontinence. Urology. May. 2005;65(5):898-904. [pmid: 15882720].
514 Demain S, Smith JF, Hiller L, et al. Comparison of group and individual physiotherapy for female urinary incontinence in primary care. Physiotherapy. 2001:235-42.
515 Demirturk F, Akbayrak T, Karakaya IC, et al. Interferential current versus biofeedback results in urinary stress incontinence. Swiss Medical Weekly. May. 31. 2008;138(21–22):317-21. [pmid: 18516753].
516 Diokno AC, Sampselle CM, Herzog AR, et al. Prevention of urinary incontinence by behavioral modification program: a randomized, controlled trial among older women in the community. J Urol. Mar. 2004;171(3):1165-71. [pmid: 14767293].
517 Diokno AC, Ocampo MS Jr, Ibrahim IA, et al. Group session teaching of behavioral modification program (BMP) for urinary incontinence: a randomized controlled trial among incontinent women. Int Urol Nephrol. Jun. 2010;42(2):375-81. [pmid: 19701691].
518 Dougherty MC, Dwyer JW, Pendergast JF, et al. A randomized trial of behavioral management for continence with older rural women. Res Nurs Health. Feb. 2002;25(1):3-13. [pmid: 11807915].
519 Dowd TT, Campbell JM, Jones JA. Fluid intake and urinary incontinence in older community-dwelling women. J Community Health Nurs. 1996;13(3):179-86. [pmid: 8916607].
520 Dowd T, Kolcaba K, Steiner R. Using cognitive strategies to enhance bladder control and comfort. Holist Nurs Pract. Jan. 2000;14(2):91-103. [pmid: 12119974].
521 Dumoulin C, Lemieux MC, Bourbonnais D, et al. Physiotherapy for persistent postnatal stress urinary incontinence: a randomized controlled trial. Obstet Gynecol. Sep. 2004;104(3):504-10. [pmid: 15339760].
522 Elser DM, Wyman JF, McClish DK, et al. The effect of bladder training, pelvic floor muscle training, or combination training on urodynamic parameters in women with urinary incontinence. Continence Program for Women Research Group. Neurourol Urodyn. 1999;18(5):427-36. [pmid: 10494113].
523 Emmons SL, Otto L. Acupuncture for overactive bladder: a randomized controlled trial. Obstet Gynecol. Jul. 2005;106(1):138-43. [pmid: 15994629].
524 Engberg S, Sereika SM, McDowell BJ, et al. Effectiveness of prompted voiding in treating urinary incontinence in cognitively impaired homebound older adults. J Wound Ostomy Continence Nurs. Sep. 2002;29(5):252-65. [pmid: 12510471].
525 Fantl JA, Wyman JF, McClish DK, et al. Efficacy of bladder training in older women with urinary incontinence. JAMA. Feb. 6. 1991;265(5):609-13. [pmid: 1987410].
526 Felicissimo MF, Carneiro MM, Saleme CS, et al. Intensive supervised versus unsupervised pelvic floor muscle training for the treatment of stress urinary incontinence: a randomized comparative trial. Int Urogynecol J Pelvic Floor Dysfunct. Jul. 2010;21(7):835-40. [pmid: 20179901].
527 Finazzi Agro E, Campagna A, Sciobica F, et al. Posterior tibial nerve stimulation: is the once-a-week protocol the best option?. Minerva Urol Nefrol. Jun. 2005;57(2):119-23. [pmid: 15951736].
528 Finazzi-Agro E, Petta F, Sciobica F, et al. Percutaneous tibial nerve stimulation effects on detrusor overactivity incontinence are not due to a placebo effect: a randomized, double-blind, placebo controlled trial. J Urol. Nov. 2010;184(5):2001-6. [pmid: 20850833].
529 Fujishiro T, Enomoto H, Ugawa Y, et al. Magnetic stimulation of the sacral roots for the treatment of stress incontinence: an investigational study and placebo controlled trial. J Urol. Oct. 2000;164(4):1277-9. [pmid: 10992380].
530 Fujishiro T, Takahashi S, Enomoto H, et al. Magnetic stimulation of the sacral roots for the treatment of urinary frequency and urge incontinence: an investigational study and placebo controlled trial. J Urol. Sep. 2002;168(3):1036-9. [pmid: 12187217].
531 Gallo ML, Staskin DR. Cues to action: pelvic floor muscle exercise compliance in women with stress urinary incontinence. Neurourol Urodyn. 1997;16(3):167-77. [pmid: 9136139].
532 Gameiro MO, Moreira EH, Gameiro FO, et al. Vaginal weight cone versus assisted pelvic floor muscle training in the treatment of female urinary incontinence. A prospective, single-blind, randomized trial. Int Urogynecol J Pelvic Floor Dysfunct. Apr. 2010;21(4):395-9. [pmid: 20052573].
533 Ghoniem G, Corcos J, Comiter C, et al. Cross-linked polydimethylsiloxane injection for female stress urinary incontinence: results of a multicenter, randomized, controlled, single-blind study. J Urol. Jan. 2009;181(1):204-10. [pmid: 19013613].
534 Gilling PJ, Wilson LC, Westenberg AM, et al. A double-blind randomized controlled trial of electromagnetic stimulation of the pelvic floor vs sham therapy in the treatment of women with stress urinary incontinence. BJU Int. May. 2009;103(10):1386-90. [pmid: 19154474].
535 Glavind K, Nohr SB, Walter S. Biofeedback and physiotherapy versus physiotherapy alone in the treatment of genuine stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 1996;7(6):339-43. [pmid: 9203484].
536 Glavind K. Use of a vaginal sponge during aerobic exercises in patients with stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 1997;8(6):351-3. [pmid: 9609334].
537 Gorman R. Expert system for management of urinary incontinence in women. Proc Annu Symp Comput Appl Med Care. 1995:527-31. [pmid: 8563340].
538 Hahn I, Sommar S, Fall M. A comparative study of pelvic floor training and electrical stimulation for the treatment of genuine female stress urinary incontinence. Neurourology and Urodynamics. 1991;10(6):545-54.
539 Harvey CA. A Randomised, Single-Blind Comparison of Pelvic Floor Muscle Exercises With Biofeedback Versus Weighted Vaginal Cones in the Management of Genuine Stress Incontinence: A Pilot Study. [pmid: 2002318].
540 Hu TW, Igou JF, Kaltreider DL, et al. A clinical trial of a behavioral therapy to reduce urinary incontinence in nursing homes. Outcome and implications. JAMA. May. 12. 1989;261(18):2656-62. [pmid: 2496240].
541 Huang AJ, Stewart AL, Hernandez AL, et al. Sexual function among overweight and obese women with urinary incontinence in a randomized controlled trial of an intensive behavioral weight loss intervention. J Urol. May. 2009;181(5):2235-42. [pmid: 19296980].
542 Hui E, Lee PS, Woo J. Management of urinary incontinence in older women using videoconferencing versus conventional management: a randomized controlled trial. J Telemed Telecare. 2006;12(7):343-7. [pmid: 17059650].
543 Hung HC, Hsiao SM, Chih SY, et al. An alternative intervention for urinary incontinence: retraining diaphragmatic, deep abdominal and pelvic floor muscle coordinated function. Man Ther. Jun. 2010;15(3):273-9. [pmid: 20185357].
544 Janssen CC, Lagro-Janssen AL, Felling AJ. The effects of physiotherapy for female urinary incontinence: individual compared with group treatment. BJU Int. Feb. 2001;87(3):201-6. [pmid: 11167642].
545 Jeyaseelan SM, Haslam EJ, Winstanley J, et al. An evaluation of a new pattern of electrical stimulation as a treatment for urinary stress incontinence: a randomized, double-blind, controlled trial. Clin Rehabil. Dec. 2000;14(6):631-40. [pmid: 11128739].
546 Kim H, Yoshida H, Suzuki T. Exercises treatment to reduce the urine leakage in elderly community-dwelling Japanese women with stress, urge, and mixed urinary incontinence. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. 2009. San Francisco.
547 Kim JI. Continence efficacy intervention program for community residing women with stress urinary incontinence in Japan. Public Health Nurs. Jan–Feb. 2001;18(1):64-72. [pmid: 11251875].
548 Kim H, Suzuki T, Yoshida Y, et al. Effectiveness of multidimensional exercises for the treatment of stress urinary incontinence in elderly community-dwelling Japanese women: a randomized, controlled, crossover trial. J Am Geriatr Soc. Dec. 2007;55(12):1932-9. [pmid: 17944890].
549 Kim JH, Nam D, Park MK, et al. Randomized control trial of hand acupuncture for female stress urinary incontinence. Acupunct Electrother Res. 2008;33(3–4):179-92. [pmid: 19301628].
550 Kincade JE, Dougherty MC, Carlson JR, et al. Randomized clinical trial of efficacy of self-monitoring techniques to treat urinary incontinence in women. Neurourol Urodyn. 2007;26(4):507-11. [pmid: 17366526].
551 Konstantinidou E, Apostolidis A, Kondelidis N, et al. Short-term efficacy of group pelvic floor training under intensive supervision versus unsupervised home training for female stress urinary incontinence: a randomized pilot study. Neurourol Urodyn. 2007;26(4):486-91. [pmid: 17245777].
552 Kumari S, Jain V, Mandal AK, et al. Behavioral therapy for urinary incontinence in India. Int J Gynaecol Obstet. Nov. 2008;103(2):125-30. [pmid: 18755458].
553 Lagro-Janssen AL, Debruyne FM, Smits AJ, et al. The effects of treatment of urinary incontinence in general practice. Fam Pract. Sep. 1992;9(3):284-9. [pmid: 1459383].
554 Lagro-Janssen TL, Debruyne FM, Smits AJ, et al. Controlled trial of pelvic floor exercises in the treatment of urinary stress incontinence in general practice. Br J Gen Pract. Nov. 1991;41(352):445-9. [pmid: 1807303].
555 Lamb SE, Pepper J, Lall R, et al. Group treatments for sensitive health care problems: a randomised controlled trial of group versus individual physiotherapy sessions for female urinary incontinence. BMC Womens Health. 2009;9:26. [pmid: 19751517].
556 Lappin MS, Lawrie FW, Richards TL, et al. Effects of a pulsed electromagnetic therapy on multiple sclerosis fatigue and quality of life: a double-blind, placebo controlled trial. Altern Ther Health Med. Jul–Aug. 2003;9(4):38-48. [pmid: 12868251].
557 Laycock J, Brown J, Cusack C, et al. Pelvic floor reeducation for stress incontinence: comparing three methods. Br J Community Nurs. May. 2001;6(5):230-7. [pmid: 11893948].
558 Lee PE, Kung RC, Drutz HP. Periurethral autologous fat injection as treatment for female stress urinary incontinence: a randomized double-blind controlled trial. J Urol. Jan. 2001;165(1):153-8. [pmid: 11125386].
559 Liebergall-Wischnitzer M, Hochner-Celnikier D, Lavy Y, et al. Randomized trial of circular muscle versus pelvic floor training for stress urinary incontinence in women. J Womens Health (Larchmt). Mar. 2009;18(3):377-85. [pmid: 19281321].
560 Liebergall-Wischnitzer M, Hochner-Celnikier D, Lavy Y, et al. Paula method of circular muscle exercises for urinary stress incontinence--a clinical trial. Int Urogynecol J Pelvic Floor Dysfunct. Sep–Oct. 2005;16(5):345-51. [pmid: 15660184].
561 Lightner D, Calvosa C, Andersen R, et al. A new injectable bulking agent for treatment of stress urinary incontinence: results of a multicenter, randomized, controlled, double-blind study of Durasphere. Urology. Jul. 2001;58(1):12-5. [pmid: 11445471].
562 Lightner D, Rovner E, Corcos J, et al. Randomized controlled multisite trial of injected bulking agents for women with intrinsic sphincter deficiency: mid-urethral injection of Zuidex via the Implacer versus proximal urethral injection of Contigen cystoscopically. Urology. Oct. 2009;74(4):771-5. [pmid: 19660800].
563 Luber KM, Wolde-Tsadik G. Efficacy of functional electrical stimulation in treating genuine stress incontinence: a randomized clinical trial. Neurourol Urodyn. 1997;16(6):543-51. [pmid: 9353803].
564 Majumdar A, Latthe P, Toozs-Hobson P. Urodynamics prior to treatment as an intervention: a pilot study. Neurourol Urodyn. Apr. 2010;29(4):522-6. [pmid: 19731310].
565 Manganotti P, Zaina F, Vedovi E, et al. Repetitive magnetic stimulation of the sacral roots for the treatment of stress incontinence: a brief report. Eura Medicophys. Sep. 2007;43(3):339-44. [pmid: 17259914].
566 Manonai J, Songchitsomboon S, Chanda K, et al. The effect of a soy-rich diet on urogenital atrophy: a randomized, cross-over trial. Maturitas. May. 20. 2006;54(2):135-40. [pmid: 16297576].
567 Mayer RD, Dmochowski RR, Appell RA, et al. Multicenter prospective randomized 52-week trial of calcium hydroxylapatite versus bovine dermal collagen for treatment of stress urinary incontinence. Urology. May. 2007;69(5):876-80. [pmid: 17482925].
568 McDowell D, Ashe RG, Marshall K, et al. Comparison of pelvic floor muscle training, electromyography biofeedback, and neuromuscular electrical stimulation for bladder dysfunction in people with multiple sclerosis: a randomized pilot study. Neurourol Urodyn. 2006;25(4):337-48. [pmid: 16637070].
569 McDowell BJ, Engberg S, Sereika S, et al. Effectiveness of behavioral therapy to treat incontinence in homebound older adults. J Am Geriatr Soc. Mar. 1999;47(3):309-18. [pmid: 10078893].
570 McFall SL, Yerkes AM, Cowan LD. Outcomes of a small group educational intervention for urinary incontinence: health-related quality of life. J Aging Health. Aug. 2000;12(3):301-17. [pmid: 11067699].
571 McFall SL, Yerkes AM, Cowan LD. Outcomes of a small group educational intervention for urinary incontinence: episodes of incontinence and other urinary symptoms. J Aging Health. May. 2000;12(2):250-67. [pmid: 11010699].
572 Miller JM, Ashton-Miller JA, DeLancey JO. A pelvic muscle precontraction can reduce cough-related urine loss in selected women with mild SUI. J Am Geriatr Soc. Jul. 1998;46(7):870-4. [pmid: 9670874].
573 Moore KH, O’Sullivan RJ, Simons A, et al. Randomised controlled trial of nurse continence advisor therapy compared with standard urogynaecology regimen for conservative incontinence treatment: efficacy, costs and two year follow up. BJOG. Jul. 2003;110(7):649-57. [pmid: 12842055].
574 Morkved S, Bo K, Fjortoft T. Effect of adding biofeedback to pelvic floor muscle training to treat urodynamic stress incontinence. Obstet Gynecol. Oct. 2002;100(4):730-9. [pmid: 12383542].
575 Du Moulin MF, Hamers JP, Paulus A, et al. Effects of introducing a specialized nurse in the care of community-dwelling women suffering from urinary incontinence: a randomized controlled trial. J Wound Ostomy Continence Nurs. Nov–Dec. 2007;34(6):631-40. [pmid: 18030102].
576 Nager CW, Richter HE, Nygaard I, et al. Incontinence pessaries: size, POPQ measures, and successful fitting. Int Urogynecol J Pelvic Floor Dysfunct. Sep. 2009;20(9):1023-8. [pmid: 19533009].
577 Ng SC, Lin TL, Chang SJ, et al. Nursing intervention to enhance efficacy of home practice of pelvic floor muscle exercises in treating mixed urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. May. 2008;19(5):637-42. [pmid: 18004495].
578 Nielsen KK, Walter S, Maegaard E, et al. The urethral plug II: an alternative treatment in women with genuine urinary stress incontinence. Br J Urol. Oct. 1993;72(4):428-32. [pmid: 8261298].
579 Nygaard I. Prevention of exercise incontinence with mechanical devices. J Reprod Med. Feb. 1995;40(2):89-94. [pmid: 7738934].
580 Nygaard IE, Kreder KJ, Lepic MM, et al. Efficacy of pelvic floor muscle exercises in women with stress, urge, and mixed urinary incontinence. Am J Obstet Gynecol. Jan. 1996;174(1 Pt 1):120-5. [pmid: 8571994].
581 O’Brien J, Austin M, Sethi P, et al. Urinary incontinence: prevalence, need for treatment, and effectiveness of intervention by nurse. BMJ. Nov. 23. 1991;303(6813):1308-12. [pmid: 1747675].
582 O’Brien J. Evaluating primary care interventions for incontinence. Nurs Stand. Feb. 28. 1996;10(23):40-3. [pmid: 8695463].
583 Oldham J, McBride K, Herbert J. Evaluation of a new electrostim technology for the treatment of urinary incontinence in women: a randomised controlled trial. Paper presented at: Neurourology and Urodynamics, 2010; Joint Meeting of the International Continence Society and the International Urogynecological Association. Toronto, Canada. 23–27 August 2010.
584 O’Sullivan R, Simons A, Prashar S, et al. Is objective cure of mild undifferentiated incontinence more readily achieved than that of moderate incontinence? Costs and 2-year outcome. Int Urogynecol J Pelvic Floor Dysfunct. Aug. 2003;14(3):193-8. discussion 8. [pmid: 12955342].
585 Pages IH, Jahr S, Schaufele MK, et al. Comparative analysis of biofeedback and physical therapy for treatment of urinary stress incontinence in women. Am J Phys Med Rehabil. Jul. 2001;80(7):494-502. [pmid: 11421517].
586 Peters KM, Carrico DJ, Perez-Marrero RA, et al. Randomized trial of percutaneous tibial nerve stimulation versus Sham efficacy in the treatment of overactive bladder syndrome: results from the SUmiT trial. J Urol. Apr. 2010;183(4):1438-43. [pmid: 20171677].
587 Peters K, Carrico DJ, Perez-Marrero RA, et al. 12 week results from the Sumit trial: Percutaneous tibial nerve stimulation vs validated sham in those exposed to pharmacologic therapy. Paper presented at: Neurourology and Urodynamics, 2010; Joint Meeting of the International Continence Society and the International Urogynecological Association. Toronto, Canada. 23–27 August 2010.
588 Ramsay IN, Ali HM, Hunter M, et al. A prospective, randomized controlled trial of inpatient versus outpatient continence programs in the treatment of urinary incontinence in the female. Int Urogynecol J Pelvic Floor Dysfunct. 1996;7(5):260-3. [pmid: 9127183].
589 Richter HE, Burgio KL, Goode PS, et al. Non-surgical management of stress urinary incontinence: ambulatory treatments for leakage associated with stress (ATLAS) trial. Clin Trials. 2007;4(1):92-101. [pmid: 17327249].
590 Robinson H, Schulz J, Flood C, et al. A randomized controlled trial of the NEAT expandable tip continence device. Int Urogynecol J Pelvic Floor Dysfunct. Aug. 2003;14(3):199-203. discussion. [pmid: 12955343].
591 Sand PK, Richardson DA, Staskin DR, et al. Pelvic floor electrical stimulation in the treatment of genuine stress incontinence: a multicenter, placebo-controlled trial. Am J Obstet Gynecol. Jul. 1995;173(1):72-9. [pmid: 7631730].
592 Schreiner L, dos Santos TG, Knorst MR, et al. Randomized trial of transcutaneous tibial nerve stimulation to treat urge urinary incontinence in older women. Int Urogynecol J Pelvic Floor Dysfunct. Sep. 2010;21(9):1065-70. [pmid: 20458465].
593 Schulz JA, Nager CW, Stanton SL, et al. Bulking agents for stress urinary incontinence: short-term results and complications in a randomized comparison of periurethral and transurethral injections. Int Urogynecol J Pelvic Floor Dysfunct. Jul–Aug. 2004;15(4):261-5. [pmid: 15517671].
594 Seo JT, Yoon H, Kim YH. A randomized prospective study comparing new vaginal cone and FES-Biofeedback. Yonsei Med J. Oct. 31. 2004;45(5):879-84. [pmid: 15515199].
595 Sherman RA, Davis GD, Wong MF. Behavioral treatment of exercise-induced urinary incontinence among female soldiers. Mil Med. Oct. 1997;162(10):690-4. [pmid: 9339085].
596 Smith JJ 3rd. Intravaginal stimulation randomized trial. J Urol. Jan. 1996;155(1):127-30. [pmid: 7490809].
597 Spruijt J, Vierhout M, Verstraeten R, et al. Vaginal electrical stimulation of the pelvic floor: a randomized feasibility study in urinary incontinent elderly women. Acta Obstet Gynecol Scand. Nov. 2003;82(11):1043-8. [pmid: 14616279].
598 Strasser H, Marksteiner R, Margreiter E, et al. Autologous myoblasts and fibroblasts versus collagen for treatment of stress urinary incontinence in women: a randomised controlled trial. Lancet. Jun. 30. 2007;369(9580):2179-86. [pmid: 17604800].
599 Subak LL, Quesenberry CP, Posner SF, et al. The effect of behavioral therapy on urinary incontinence: a randomized controlled trial. Obstet Gynecol. Jul. 2002;100(1):72-8. [pmid: 12100806].
600 Subak LL, Whitcomb E, Shen H, et al. Weight loss: a novel and effective treatment for urinary incontinence. J Urol. Jul. 2005;174(1):190-5. [pmid: 15947625].
601 Subak LL, Wing R, West DS, et al. Weight loss to treat urinary incontinence in overweight and obese women. N Engl J Med. Jan. 29. 2009;360(5):481-90. [pmid: 19179316].
602 Sung MS, Choi YH, Back SH, et al. The effect of pelvic floor muscle exercises on genuine stress incontinence among Korean women--focusing on its effects on the quality of life. Yonsei Med J. Apr. 2000;41(2):237-51. [pmid: 10817026].
603 Sung MS, Hong JY, Choi YH, et al. FES-biofeedback versus intensive pelvic floor muscle exercise for the prevention and treatment of genuine stress incontinence. J Korean Med Sci. Jun. 2000;15(3):303-8. [pmid: 10895973].
604 Swithinbank L, Hashim H, Abrams P. The effect of fluid intake on urinary symptoms in women. J Urol. Jul. 2005;174(1):187-9. [pmid: 15947624].
605 Tibaek S, Gard G, Jensen R. Is there a long-lasting effect of pelvic floor muscle training in women with urinary incontinence after ischemic stroke? A 6-month follow-up study. Int Urogynecol J Pelvic Floor Dysfunct. Mar. 2007;18(3):281-7. [pmid: 16673051].
606 Theofrastous JP, Wyman JF, Bump RC, et al. Effects of pelvic floor muscle training on strength and predictors of response in the treatment of urinary incontinence. Neurourol Urodyn. 2002;21(5):486-90. [pmid: 12232886].
607 Thornburn P, Fader M, Dean G, et al. Improving the performance of small incontinence pads: a study of “wet comfort”. J Wound Ostomy Continence Nurs. Jul. 1997;24(4):219-25. [pmid: 9274279].
608 Thyssen H, Bidmead J, Lose G, et al. A new intravaginal device for stress incontinence in women. BJU Int. Dec. 2001;88(9):889-92. [pmid: 11851609].
609 Tibaek S, Jensen R, Lindskov G, et al. Can quality of life be improved by pelvic floor muscle training in women with urinary incontinence after ischemic stroke? A randomised, controlled and blinded study. Int Urogynecol J Pelvic Floor Dysfunct. Mar–Apr. 2004;15(2):117-23. discussion 23. [pmid: 15014939].
610 Tibaek S, Gard G, Jensen R. Pelvic floor muscle training is effective in women with urinary incontinence after stroke: a randomised, controlled and blinded study. Neurourol Urodyn. 2005;24(4):348-57. [pmid: 15791633].
611 Tsai YC, Liu CH. The effectiveness of pelvic floor exercises, digital vaginal palpation and interpersonal support on stress urinary incontinence: an experimental study. Int J Nurs Stud. Sep. 2009;46(9):1181-6. [pmid: 19361800].
612 Wang AC, Wang YY, Chen MC. Single-blind, randomized trial of pelvic floor muscle training, biofeedback-assisted pelvic floor muscle training, and electrical stimulation in the management of overactive bladder. Urology. Jan. 2004;63(1):61-6. [pmid: 14751349].
613 Wells TJ, Brink CA, Diokno AC, et al. Pelvic muscle exercise for stress urinary incontinence in elderly women. J Am Geriatr Soc. Aug. 1991;39(8):785-91. [pmid: 2071809].
614 Williams KS, Assassa RP, Cooper NJ, et al. Clinical and cost-effectiveness of a new nurse-led continence service: a randomised controlled trial. Br J Gen Pract. Sep. 2005;55(518):696-703. [pmid: 16176737].
615 Williams KS, Assassa RP, Gillies CL, et al. A randomized controlled trial of the effectiveness of pelvic floor therapies for urodynamic stress and mixed incontinence. BJU Int. Nov. 2006;98(5):1043-50. [pmid: 17034605].
616 Wing RR, West DS, Grady D, et al. Effect of weight loss on urinary incontinence in overweight and obese women: results at 12 and 18 months. J Urol. Sep. 2010;184(3):1005-10. [pmid: 20643425].
617 Wong KS, Fung KY, Fung SM, et al. Biofeedback of pelvic floor muscles in the management of genuine stress incontinence in Chinese women. Physiotherapy. 2001:644-8.
618 Wyman JF, Fantl JA, McClish DK, et al. Quality of life following bladder training in older women with urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 1997;8(4):223-9. [pmid: 9449301].
619 Wyman JF, Fantl JA, McClish DK, et al. Comparative efficacy of behavioral interventions in the management of female urinary incontinence. Continence Program for Women Research Group. Am J Obstet Gynecol. Oct. 1998;179(4):999-1007. [pmid: 9790388].
620 Yamanishi T, Yasuda K, Sakakibara R, et al. Pelvic floor electrical stimulation in the treatment of stress incontinence: an investigational study and a placebo controlled double-blind trial. The Journal of urology. 1997:2127-31. [pmid: 9366328].
621 Yamanishi T, Yasuda K, Sakakibara R, et al. Randomized, double-blind study of electrical stimulation for urinary incontinence due to detrusor overactivity. Urology. Mar. 2000;55(3):353-7. [pmid: 10699609].
622 Yoon HS, Song HH, Ro YJ. A comparison of effectiveness of bladder training and pelvic muscle exercise on female urinary incontinence. Int J Nurs Stud. Jan. 2003;40(1):45-50. [pmid: 12550149].
623 Zanetti MR, de Castro RA, Rotta AL, et al. Impact of supervised physiotherapeutic pelvic floor exercises for treating female stress urinary incontinence. Sao Paulo Med J. Sep. 6. 2007;125(5):265-9. [pmid: 18094892].
624 Clarke-O’Neill S, Pettersson L, Fader M, et al. A multicentre comparative evaluation: washable pants with an integral pad for light incontinence. J Clin Nurs. Jan. 2002;11(1):79-89. [pmid: 11845759].
625 Tomlinson BU, Dougherty MC, Pendergast JF, et al. Dietary caffeine, fluid intake and urinary incontinence in older rural women. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(1):22-8. [pmid: 10207763].
626 Goode PS, Burgio KL, Locher JL, et al. Effect of behavioral training with or without pelvic floor electrical stimulation on stress incontinence in women: a randomized controlled trial. JAMA. Jul. 16. 2003;290(3):345-52. [pmid: 12865375].
627 Coleman EA, Grothaus LC, Sandhu N, et al. Chronic care clinics: a randomized controlled trial of a new model of primary care for frail older adults. J Am Geriatr Soc. Jul. 1999;47(7):775-83. [pmid: 10404919].
628 Hahn I, Naucler J, Sommar S, et al. Urodynamic assessment of pelvic floor training. World Journal of Urology. 1991;9(3):162-6.
629 Laycock J, Jerwood D. Does pre-modulated interferential therapy cure genuine stress incontinence?. Physiotherapy. 10. August. 1993;79(8):553-60.
630 Borello-France D, Burgio KL, Goode PS, et al. Adherence to Behavioral Interventions for Urge Incontinence When Combined With Drug Therapy: Adherence Rates, Barriers, and Predictors. Phys Ther. Jul. 2010;29. [pmid: 20671098].
631 Griffiths F, Pepper J, Jorstad-Stein EC, et al. Group versus individual sessions delivered by a physiotherapist for female urinary incontinence: an interview study with women attending group sessions nested within a randomised controlled trial. BMC Womens Health. 2009;9:25. [pmid: 19744315].
632 Engberg S, Cohen S, Sereika SM. The efficacy of acupuncture in treating urge and mixed incontinence in women: a pilot study. J Wound Ostomy Continence Nurs. Nov–Dec. 2009;36(6):661-70. [pmid: 19920749].
633 MacDiarmid S, Peters KM, Wooldridge L. 12 month percutaneous tibial nerve stimulation treatment interval results: Outcomes from the Orbit trial. Paper presented at: Neurourology and Urodynamics, 2010; Joint Meeting of the International Continence Society and the International Urogynecological Association. Toronto, Canada. 23–27 August 2010.
634 Dunn M, Brandt D, Nygaard I. Treatment of exercise incontinence with a urethral insert: a pilot study in women. Phys Sportsmed. Jan. 2002;30(1):45-8. [pmid: 20086499].
635 Yang SC, Park DS, Lee JM, et al. Laparoscopic extraperitoneal bladder neck suspension (LEBNS) for stress urinary incontinence. J Korean Med Sci. Dec. 1995;10(6):426-30. [pmid: 8924227].