# Abstraction Forms

Data Abstraction Form for Question 1 What constitutes an adequate diagnostic evaluation in the primary care setting on which to base treatment of UI?

Data Abstraction Form for Questions 2 and 3 How effective is the pharmacological treatment of UI? How effective is the nonpharmacological treatment of UI?